# Appendix A Peer Reviewers

## ECP BP: Peer Reviewers

In addition to members of the technical advisory group, the partner and individuals within the AHRQ, feedback was received from individuals from the following organizations.

American Academy of Family Physicians American Academy of Neurology Association for the Advancement of Medical Instrumentation American Association of Health Plans American College of Cardiology American College of Physicians-American Society of Internal Medicine American Society of Hypertension National High Blood Pressure Education Program Coordinating Committee