# Evidence Tables

Evidence Tables Index

Question Number | Evidence Table Number | Title | Page Number
1 | 1 | Summary of quality characteristics for articles addressing question #1a-c | 73
| 2 | Summary of population characteristics for articles addressing question #1a-c | 75
| 3 | Summary of clinic measurement for articles addressing question #1a-c | 81
| 4 | Summary of self measurement for articles addressing question #1a-c | 83
| 5 | Summary of ambulatory measurement for articles addressing question #1 | 84
1a | 6 | Distribution of readings between clinic and self-measured blood pressure (question #1a) | 86
1a | 7 | Distribution of readings between clinic blood pressure and ambulatory blood pressure measurement, systolic (question #1a) | 87
1a | 8 | Distribution of readings between clinic and ambulatory blood pressure, diastolic (question #1a) | 88
1a | 9 | Distribution of readings between self-measured blood pressure and ambulatory blood pressure measurement, systolic (question #1a) | 89
1a | 10 | Distribution between self-measured blood pressure and ambulatory blood pressure measurement, diastolic (question #1a) | 90
1b | 11 | Prevalence of white coat hypertension by self-measured blood pressure (question #1b) | 91
1c | 12 | Prevalence of white coat hypertension by ambulatory blood pressure (question #1c) | 92
1c | 13 | Reproducibility of white coat hypertension (WCH) (question #1c) | 98
2 | 14 | Summary of quality characteristics for articles addressing question #2 | 99
| 15 | Summary of population characteristics for articles addressing question #2 | 100
| 16 | Summary of clinic measurements for articles addressing question #2 | 101
| 17 | Summary of self measurement for articles addressing question #2 | 102
| 18 | Characteristics of measures of left ventricular mass (question #2) | 103
| 19 | Correlation of clinic and self-measured blood pressure with left ventricular mass (question #2) | 104
| 20 | Characteristics of albuminuria measurement (question #2) | 105
| 21 | Correlation of clinic and self-measured blood pressure with albuminuria (question #2) | 106
2b | 22 | Summary of quality characteristics for prospective studies addressing question #2 (question #2b) | 107
2b | 23 | Summary of population characteristics for prospective studies addressing question #2 (question #2b) | 108
2b | 24 | Summary of clinic measurement characteristics for prospective studies (question #2b) | 109
2b | 25 | Summary of self measurement characteristics for prospective studies addressing question #2 (question #2b) | 110
2b | 26 | Summary of methods in prospective studies (question #2b) | 111
2b | 27 | Prediction of outcome by clinic blood pressure and self-measured blood pressure (question #2b) | 112
2d | 28 | Summary of quality characteristics for self-measured blood pressure trials (question #2d) | 113
2d | 29 | Summary of population characteristics for self-measured blood pressure trials (question #2d) | 115
2d | 30 | Summary of methods for self-measured blood pressure trials (question #2d) | 117
2d | 31 | Characteristics of outcome measurements in self-measured blood pressure trials (question #2d) | 121
2d | 32 | Results of self-measured blood pressure trials (question #2d) | 122
3 | 33 | Summary of quality characteristics for articles addressing question #3 | 125
| 34 | Summary of population characteristics for articles addressing question #3 | 127
| 35 | Summary of clinic measurement characteristics for articles addressing question #3 | 132
| 36 | Summary of ambulatory blood pressure measurement for articles addressing question #3 | 134
| 37 | Characteristics of measures of left ventricular mass (question #3) | 136
| 38 | Correlation of clinic and ambulatory blood pressure with left ventricular mass (question #3) | 138
| 39 | Correlation of left ventricular mass with ambulatory blood pressure defined white coat hypertension (question #3) | 140
| 40 | Characteristics of albuminuria measurement (question #3) | 141
| 41 | Correlations of clinic and ambulatory blood pressure with albuminuria (question #3) | 142
| 42 | Correlation of ambulatory blood pressure defined white coat hypertension with albuminuria (question #3) | 143
3b | 43 | Summary of quality characteristics for prospective studies addressing question #3 (question #3b) | 144
3b | 44 | Summary of population characteristics for prospective studies of ambulatory blood pressure measurement (question #3b) | 146
3b | 45 | Summary of methods for prospective studies of ambulatory blood pressure measurement (question #3b) | 148
3b | 46 | Prediction of outcome by clinic blood pressure and systolic ambulatory blood pressure (question #3b) | 152
3b | 47 | Prediction of outcome by clinic blood pressure and diastolic ambulatory blood pressure (question #3b) | 155
3b | 48 | Prediction of Outcome by pattern of ambulatory blood pressure (white coat hypertension and dipping status) (question #3b) | 157
3d | 49 | Summary of quality characteristics in ambulatory blood pressure measurement trials (question #3d) | 159
3d | 50 | Summary of population characteristics for ambulatory blood pressure measurement trials (question #3d) | 160
3d | 51 | Summary of methods in ambulatory blood pressure measurement trials (question #3d) | 161
3d | 52 | Characteristics of outcome measurements in ambulatory blood pressure measurement trials (question #3d) | 162
3d | 53 | Effect of ambulatory blood pressure measurement interventions on clinic blood pressure (question #3d) | 163
3d | 54 | Effect of ambulatory blood pressure measurement interventions on 24 hour, daytime and nighttime ambulatory blood pressure (question #3d) | 164

Evidence Table 1: Summary of quality characteristics for articles addressing question #1a-c

Study (question) | Center | Funding | Adequate Description | | Clinic BP Observer | | | Self BP Instructions Provided | Ambulatory BP Trained | Statistical Variability Reported
Study (question) | Center | Funding | Eligibility | Baseline Characteristics | Trained | Blinded | Standard Technique | Self BP Instructions Provided | Ambulatory BP Trained | Statistical Variability Reported
Abe, 1987(a, b) | single | can't tell | N | Y | can't tell | N | N | can't tell | NA | Y
Aylett, 1999 (b) | multi | industry | Y | Y | can't tell | N | can't tell | Y | NA | N
Helmers, 2000 (c) | multi | govt | Y | Y | can't tell | Y | can't tell | NA | can't tell | Y
Hoegholm, 1999 (c) | multi | can't tell | Y | Y | N | Y | N | NA | can't tell | Y
Inden, 1998 (c) | single | can't tell | Y | Y | can't tell | N | can't tell | NA | Y | N
Ironson, 1989 (a) | single | govt | Y | Y | can't tell | N | Y | NA | can't tell | Y
Jula, 1999 (a) | single | can't tell | Y | Y | Y | Y | Y | Y | can't tell | Y
Khoury, 1992 (a) | single | can't tell | N | N | can't tell | Y | can't tell | NA | can't tell | Y
MacDonald, 1999 (c) | single | govt, other | Y | Y | can't tell | Y | Y | NA | can't tell | Y
Manning, 1999 (c) | single | can't tell | Y | Y | can't tell | Y | Y | NA | Y | Y
Martinez, 1999 (c) | multi | industry | Y | Y | Y | Y | Y | NA | Y | Y
Martinez, 2001 (c) | multi | govt, industry | Y | Y | can't tell | Y | Y | NA | Y | Y
Mengden, 1991 (a) | single | can't tell | N | N | can't tell | N | N | Y | NA | Y
Modesti, 1994 (a) | single | can't tell | Y | Y | can't tell | N | Y | NA | Y | Y
Myers, 1995a (c) | single | can't tell | N | Y | Y | N | Y | NA | can't tell | Y
Myers, 1995b (a) | single | can't tell | Y | Y | Y | Y | can't tell | NA | can't tell | Y
Narkiewicz, 1995 (a) | multi | can't tell | Y | Y | can't tell | N | Y | NA | Y | Y
Nielsen, 1986 (a) | can't tell | can't tell | N | N | can't tell | N | N | Y | NA | Y
Owens, 1999 (c) | single | other | N | N | can't tell | Y | Y | NA | Y | Y
Palatini, 1998 (c) | multi | can't tell | Y | Y | can't tell | N | Y | NA | Y | Y
Pierdomenico, 1995 (c) | single | can't tell | Y | Y | can't tell | N | Y | NA | Y | Y
Sega, 1994 (a) | multi | other | Y | N | can't tell | N | Y | Y | Y | Y
Staessen, 1999 (a) | multi | govt, industry | Y | Y | can't tell | N | can't tell | NA | can't tell | Y
Stergiou, 1998a (a) | single | can't tell | Y | Y | can't tell | N | Y | Y | Y | Y
Stergiou, 1998b (b, c) | single | can't tell | Y | Y | can't tell | N | Y | Y | can't tell | Y
Stergiou, 2000 (b, c) | single | can't tell | Y | Y | Y | Y | Y | can't tell | can't tell | Y
Thijs, 1996 (a) | multi | industry | Y | Y | can't tell | N | can't tell | NA | can't tell | Y
Tochikubo, 1999 (c) | single | can't tell | Y | Y | can't tell | Y | can't tell | NA | can't tell | Y
Verdecchia, 1992 (c) | single | can't tell | Y | Y | can't tell | Y | Y | NA | can't tell | Y
Verdecchia, 1995 (c) | multi | other | Y | Y | can't tell | N | can't tell | NA | can't tell | Y
Verdecchia, 1996 (c) | single | can't tell | Y | N | can't tell | N | Y | NA | Y | Y
Weisser, 1994 (a) | multi | can't tell | N | Y | can't tell | N | N | Y | NA | Y
Zachariah, 1988 (a) | can't tell | can't tell | N | Y | can't tell | N | Y | NA | can't tell | Y
Zachariah, 1991(a) | single | can't tell | N | N | can't tell | N | Y | NA | can't tell | Y
Zawadzka, 1998 (a, c) | can't tell | govt | N | N | can't tell | Y | can't tell | NA | Y | Y

Evidence Table 2: Summary of population characteristics for articles addressing question #1a-c

Study (question) | N | Setting | Target Population | Exclusions | Male (%) | Black (%) | Mean Age, years (SD) | HTN (%) | On BP medication (%)
Abe, 1987 (a,b) | 100 | hypertension clinic | hypertensives | anti-hypertensive medication; secondary hypertension | 56 | | 52 (8) | 96 | 0
Aylett, 1999 (b) | 660 | general clinic | hypertensives; anti-hypertensive medication | | 42 | | | 100 | 100
Uncontrolled hypertensive | 258 | | | | | | | 100
Untreated hypertensive | 236 | | | | | | | 100
Helmers, 2000 (c) | 194 | can't tell | hypertensives | age < 20 and > 65; anti-hypertensive medication; active CHD/CVD | 66 | | | 100 | 0
Hoegholm, 1999 (c) | 566 | general practitioners | hypertensives; normotensives | anti-hypertensive medication; diabetes; active CHD/CVD | 47.5 | | | 7.4 | 0
Inden, 1998 (c) | 232 | hypertension clinic | hypertensives | anti-hypertensive medication | 46.9 | | | 100 | 0
Ironson, 1989 (a) | 119 | can't tell | | active CHD/CVD; dizzy spells; asthma | 60.5 | 50.4 | 34.4 (5.4) | | 0
Jula, 1999 (a) | 233 | general clinic | age between 34 and 55; hypertensives | pregnancy; anti-hypertensive medication; diabetes; active CHD/CVD; valvular heart disease | 58.4 | | 46 (4.9) | 100 | 0
Khoury, 1992 (a) | 131 | general clinic | clinic DBP 90 -115mmHg | | 52.7 | 0 | 53.9 | 100
Women | 62 | | | | 0 | 0 | 60.2
Men | 69 | | | | 100 | 0 | 50.2
Age >65 | 39 | | | | | 0 | 75.5
Age <65 | 92 | | | | | 0 | 46.3
MacDonald, 1999 (c) | 103 | hypertension clinic | age >17; hypertensives; at least 2 BP meds | active CHD/CVD; LVH or target organ damage | 53.4 | | 59.4 | 100 | 100
Women | 48 | | | | 0 | | 61.1 | 100 | 100
Men | 55 | | | | 100 | | 58.4 | 100 | 100
Manning, 1999 (c) | 186 | hypertension clinic | hypertensives | anti-hypertensive medication | 51.1 | | 46 | 100 | 0
Martinez, 1999 (c) | 345 | general clinic | age between 18 and 75; hypertensives; Caucasians | normotensives; anti-hypertensive medication; target organ damage; valvular disease | 47.8 | 0 | 51.8 (10.6) | 100 | 0
Men | 165 | | | | 100 | 0 | | 100 | 0
Women | 180 | | | | | 0 | | 100 | 0
Martinez, 2001 (c) | 223 | general clinic | hypertensives | age <18 and >75; normotensives; anti-hypertensive medication; diabetes; chronic renal insufficiency; renal transplant active CHD/CVD | 49.8 | | 53 (11) | 100 | 0
Mengden, 1991 (a) | 127 | BP Screening | hypertensives; normotensives | anti-hypertensive medication | 62.2 | | 42.7 (11.2) | | 0
Modesti, 1994 (a) | 139 | general population | no specific population | hypertensives; anti-hypertensive medication | 61.9 | | 38.7 (9.8) | 0
Myers, 1995a (c) | 152 | hypertension clinic | hypertensives; anti-hypertensive medication | can't tell | 42.8 | | | | 100
Men | 65 | | | | 100 | | 55 (1) | | 100
Women | 87 | | | | 0 | | 64 (1) | | 100
Myers, 1995b (a) | 147 | primary care practice | hypertensives; anti-hypertensive medication | age <21 and > 80; dialysis; chronic renal insufficiency; renal transplant; active CHD/CVD | 38.1 | | 64 | 100 | 100
Men | 56 | | | | 100
Women | 91 | | | | 0
Narkiewicz, 1995 (a) | 411 | can't tell | borderline /mild hypertension diastolic 90-99; | age <18 and >45; anti-hypertensive medication; BMI>30% of ideal | 100 | | 33.7 (8.5) | 100 | 0
Nielsen, 1986 (a) | 122 | can't tell | | | | | 47.5
Owens, 1999 (c) | 1350 | hypertension clinic | hypertensives | anti-hypertensive medication | 43.4 | | 50.9 (12.4) | 100 | 569
Palatini, 1998 (c) | 660 | can't tell | age between 18 and 45; white coat hypertensives | anti-hypertensive medication | 74.4 | | 33 (9.0) | 85.6 | 0
Pierdomenico, 1995 (c) | 255 | hypertension clinic | hypertensives | normotensives; anti-hypertensive medication; active CHD/CVD; secondary hypertension; valvular disease; diabetes; renal insufficiency | 51.4 | | 49 (14) | 100 | 0
Sega, 1994 (a) | 1651 | general population | age between 25 and 64
Staessen, 1999 (a) | 808 | can't tell | age >60; hypertensives | chronic renal insufficiency; | 38.5 | | 69.6 (6.2) | | 42.6
Stergiou, 1998a (a) | 189 | hypertension clinic | hypertensives | DBP >120mmHg, SBP >220mmHg; change in medication | 56.6 | | | 100 | 41.8
Stergiou, 1998b (b, c) | 189 | hypertension clinic | hypertensives | DBP>120mmHg, SBP>220mmHg; change in HTN meds | 56.6 | | 52.2 (11.5) | 100 | 41.8
Stergiou, 2000 (b, c) | 133 | hypertension clinic | hypertensives | anti-hypertensive medication; diabetes; dialysis; chronic renal insufficiency; active CHD/CVD; LVH by EKG; clinic BP > 200/115 mmHG | 54.9 | | 48.4 (10.2) | 70.7 | 0
Thijs, 1996 (a) | 477 | Syst-Eur trial | age>59 | active CHD/CVD; secondary hypertension; liver disease, cancer | 38.8 | | | 100
Men | 292 | | | | 100
Women | 185 | | | | 0
Tochikubo, 1999 (c) | 172 | can't tell | age between 29 and 76; hypertensives | normotensives; anti-hypertensive medication; active CHD/CVD; anemia; renal disease; valvular disease | 51.2 | | | | 0
Verdecchia, 1992 (c) | 260 | can't tell | hypertensives | normotensives; anti-hypertensive medication; chronic renal insufficiency; active CHD/CVD | 45.4 | | | 100 | 0
Women | 142 | | | | 0 | | 55.4 | | 0
Men | 118 | | | | 100 | | 54.9 | | 0
Verdecchia, 1995 (c) | 1414 | can't tell | | congestive heart failure; valvular disease | 44.8 | | 50 | 87.4
Verdecchia, 1996 (c) | 83 | can't tell | white coat hypertensives | hypertensives; medication; CHD/CVD; secondary hypertension; concomitant disease | | | 44.3 (12) | 100 | 0
Weisser, 1994 (a) | 503 | general population | no specific population | anti-hypertensive medication; serious illness; arm circumference >35cm | 52.7 | | 46.5 (12.9) | | 0
Men | 265 | | | | 100 | | 46.1 | | 790
Women | 238 | | | | 0 | | 46.9 | | 0
Zachariah, 1988 (a) | 168 | can't tell | hypertensives | normotensives; anti-hypertensive medication | 69.1 | | 51 (9) | 79.2
Zachariah, 1991(a) | 126 | general clinic | normotensives | hypertensives; active CHD/CVD; | 44.4 | | | 0
Zawadzka, 1998 (a, c)) | 410 | can't tell | hypertensives | normotensives; anti-hypertensive medication | | | | 100

Evidence Table 3: Summary of clinic measurement for articles addressing question #1a-c

Study (question) | Device Type | Observer | Position | Measurements (Number)
Study (question) | Device Type | Observer | Position | Per Day | Days | Total
Abe, 1987 (a, b) | mercury | physician | sitting | 1 | 3 | 3
Aylett, 1999 (b) | can't tell | can't tell | can't tell | can't tell
Helmers, 2000 (c) | can't tell | can't tell | sitting | 1 | 3 | 3
Hoegholm, 1999 (c) | multiple devices | physician | sitting | 3
Inden, 1998 (c) | mercury | can't tell | sitting | 2 | 3 | 6
Ironson, 1989 (a) | mercury | can't tell | sitting | 2 | 2 | 4
Jula, 1999 (a) | mercury | nurse | sitting | 2 | 4 | 8
Khoury, 1992 (a) | can't tell | nurse | sitting | can't tell
MacDonald, 1999 (c) | can't tell | nurse | supine | can't tell
Manning, 1999 (c) | mercury | can't tell | combination | 3 | 3 | 9
Martinez, 1999 (c) | mercury | nurse, physician | sitting | 2 | 3 | 6
Martinez, 2001 (c) | mercury | physician | sitting | 2 | 3 | 6
Mengden, 1991 (a) | aneroid | can't tell | can't tell | 1 | 2 | 2
Modesti, 1994 (a) | mercury | physician | sitting | 1 | 2 | 2
Myers, 1995a (c) | mercury | med tech, nurse, physician | combination | 2 | 2 | 4
Myers, 1995b (a) | mercury | nurse | sitting | 3 | 2 | 6
Narkiewicz, 1995 (a) | can't tell | can't tell | supine | 3 | 2 | 6
Nielsen, 1986 (a) | automated | physician | can't tell | 3 | 2 | 6
Owens, 1999 (c) | can't tell | nurse, physician | sitting | 1 | 2 | 2
Palatini, 1998 (c) | can't tell | can't tell | supine | 3 | 2 | 6
Pierdomenico, 1995 (c) | can't tell | can't tell | sitting | 3 | 3 | 9
Staessen, 1999 (a) | can't tell | can't tell | combination | 2 | 3 | 6
Stergiou, 1998a (a) | mercury | physician | sitting | 2 | 2 | 4
Stergiou, 1998b (b, c) | mercury | physician | sitting | 3 | 2 | 6
Thijs, 1996 (a) | can't tell | can't tell | sitting | 2 | 3 | 6
Tochikubo, 1999 (c) | mercury | can't tell | can't tell | 3 | 3 | 9
Verdecchia, 1995 (c) | can't tell | can't tell | can't tell | can't tell
Verdecchia, 1996 (c) | mercury | physician | sitting | 1 | 3 | 3
Weisser, 1994 (a) | automated | physician | sitting | 2 | 2 | 4
Zachariah, 1988 (a) | mercury | med tech | combination | 6 | 2 | 12
Zachariah, 1991 (a) | mercury | med tech | combination | 6 | 2 | 12
Zawadzka, 1991 (a, c)) | can't tell | nurse, physician | can't tell | 1 | 3 | 3

Evidence Table 4: Summary of self measurement for articles addressing question #1a-c

Study | Device | | | Observer | Time of Recordings ^a^ | | | Measurements (Number)
Study | Type | Name | Validated | Observer | morning | afternoon | evening | Per day | Days | Total
Abe, 1987 (a, b) | electronic or automated | can't tell | unknown | can't tell | Y | Y | Y | 2 | 7 | 14
Aylett, 1999 (b) | electronic or automated | Omron 705c | Y | patient | can't tell | can't tell | can't tell | can't tell | | 14
Jula, 1999 (a) | electronic or automated | Omron 705c | Y | patient | Y | N | Y | 4 | 7 | 28
Mengden, 1991 (a) | aneroid | Sysditon | unknown | patient | Y | N | Y | 2 | 6 | 12
Nielsen, 1986 (a) | electronic or automated | TM 101 | unknown | patient | Y | Y | Y | 3 | 7 | 21
Sega, 1994 (a) | electronic or automated | HP 5331 | unknown | patient | Y | N | Y | 1 | 2 | 2
Stergiou, 1998a (a) | electronic or automated | Omron 705c | Y | patient | Y | N | Y | 4 | 6 | 22.8
Stergiou, 1998b (b, c) | electronic or automated | Omron 705c | Y | patient | Y | N | Y | 4 | 6 | 24
Stergiou, 2000 (b, c) | electronic or automated | Omron 705c | Y | can't tell | Y | N | Y | 4 | 5 | 20
Weisser, 1994 (a) | electronic or automated | OM 1 | unknown | patient | Y | N | Y | 2 | 14 | 26.7

a morning = before noon, afternoon = noon to 6:00pm, evening = after 6:00pm

Evidence Table 5: Summary of ambulatory measurement for articles addressing question #1a-c

Study (question) | Device | | | Daytime | | Nighttime
Study (question) | Type | Name | Validated | Definition | Time Interval (mins) | Definition | Time Interval (mins)
Helmers, 2000 (c) | oscillometric | SpaceLabs 90207 | Y | 7:00am -11:00pm | 15 | 11:00pm - 7:00am | 60
Hoegholm, 1999 (c) | oscillometric oscillometric | TM-2420, Model 7 TM-2420, Model 6 | Y Y | 8:00am - 9:59pm | 15 | 12:00am - 5:59am | 30
Inden, 1998 (c) | unknown | Nikon Colin 630 | N | 7:00am -11:30pm | 30 | 11:00pm - 6:30am | 30
Ironson, 1989 (a) | oscillometric | SpaceLabs not specified | unknown | 9:00am - 11:00pm | 20 | can't tell
Jula, 1999 (a) | auscultatory | Accutracker II | N | 6:00pm - 11:00am | 15 | 11:00pm - 6:00am | 30
Khoury, 1992 (a) | oscillometric | SpaceLabs 90207 | Y | 7:00am - 11:00pm | 11 | 11:00pm - 7:00am | 60
MacDonald, 1999 (c) | oscillometric | SpaceLabs 90207 | Y | 8:00am - 10:00pm | 20 | 10:00pm - 8:00pm | 60
Manning, 1999 (c) | unknown | Medilog ABP | N | patient reported | 30 | patient reported | 30
Martinez, 1999 (c) | oscillometric | SpaceLabs 90207 | Y | 10:00am - 8:00pm | 15 | 12:00pm - 6:00am | 15
Martinez, 2001 (c) | oscillometric | SpaceLabs 90207 | Y | 10:00am - 8:00am | 15 | 12:00am - 6:00am | 30
Modesti, 1994 (a) | oscillometric | SpaceLabs 90207 | Y | 7:01am - 10:00pm | 15 | 10:01pm - 7:01am | 15
Myers, 1995a (c) | oscillometric oscillometric unknown | SpaceLabs 90202 SpaceLabs 90207 SpaceLabs 5200 | Y Y unknown | can't tell | can't tell | can't tell | can't tell
Myers, 1995b (a) | oscillometric oscillometric | SpaceLabs 90202 SpaceLabs 90207 | Y Y | can't tell | 15 | not measured
Narkiewicz, 1995 (a) | oscillometric oscillometric | SpaceLabs 90207 TM-2420, Model 7 | Y Y | 6:00am - 11:00pm | 10 | 11:00pm - 6:00am | 30
Owens, 1999 (c) | oscillometric | SpaceLabs 90207 | Y | 9:00am - 9:00pm | 30 | 9:01pm - 12:59am | 30
Palatini, 1998 (c) | oscillometric auscultatory | SpaceLabs 90207 TM 2420, Model 7 | Y Y | 6:00am - 11:00pm | 10 | 11:00pm - 6:00am | 30
Pierdomenico, 1995 (c) | oscillometric oscillometric | SpaceLabs 90202 SpaceLabs 90207 | Y Y | 6:00am - 12:00pm | 15 | 12:00pm - 6:00am | 30
Sega, 1994 (a) | oscillometric | SpaceLabs 90207 | Y | 7:00am - 11:00pm | 20 | 11:00pm - 7:00am | 20
Staessen, 1999 (a) | oscillometric oscillometric | SpaceLabs 90202 SpaceLabs 90207 | Y | 10:00am - 8:00pm | 30 | 12:00am - 6:00am | 30
Stergiou, 1998a (a) | oscillometric | SpaceLabs 90207 | Y | patient reported | 20 | patient reported | 20
Stergiou, 1998b (b, c) | oscillometric | SpaceLabs 90207 | Y | patient reported | 20 | patient reported | 20
Stergiou, 2000 (b, c) | oscillometric | SpaceLabs 90207 | Y | can't tell | 20 | can't tell | 20
Thijs, 1996 (a) | oscillometric oscillometric unknown | SpaceLabs 90202 SpaceLabs 90207 Plus other unspecified | Y Y unknown | 10:00am - 8:00pm | 30 | 12:00am - 6:00am | 30
Tochikubo, 1999 (c) | unknown | TM-2425 | unknown | patient reported | 30 | patient reported | 30
Verdecchia, 1992 (c) | oscillometric oscillometric unknown | SpaceLabs 90202 SpaceLabs 90207 SpaceLabs 5200 | Y Y unknown | 6:00am - 10:00pm | 15 | | 15
Verdecchia, 1995 (c) | oscillometric oscillometric unknown | SpaceLabs 90202 SpaceLabs 90207 SpaceLabs 5200 | Y Y unknown | 6:00am - 10:00pm | 15 | 10:00pm - 6:00am | 15
Verdecchia, 1996 (c) | oscillometric oscillometric | SpaceLabs 90202 SpaceLabs 90207 | Y Y | 6:00am - 10:00pm | 15 | 10:00pm - 6:00am | 15
Zachariah, 1988 (a) | unknown | Pressurometer III | unknown | can't tell | 7.5 | can't tell | 15
Zachariah, 1991 (a) | unknown | Pressurometer | unknown | can't tell | 7.5 | can't tell | 15
Zawadzka, 1998 (a, c) | auscultatory | TM 2420 | unknown | can't tell | 30 | not measured

Evidence Table 6: Distribution of readings between clinic and self-measured blood pressure (question #1a)

Study | N | Mean (SD) Systolic BP | | Systolic Difference | | Mean (SD) Diastolic BP | | Diastolic Difference
Study | N | Clinic | SMBP | Mean (SD) | P-value | Clinic | SMBP | Mean (SD) | P-value
Abe, 1987 | 100 | 165.5 (20.6) | 147.8 (15.9) | 17.7 | <0.001 | 101.2 (10.1) | 94.9 (10.8) | 6.3 | <0.001
Jula, 1999 | 233 | 144.5 (12.6) | 138.9 (13.1) | 5.6 (8.8) | <0.001 | 94.5 (7.4) | 92.9 (8.6) | 1.7 (6.5) | <0.001
Mengden, 1991 | 127 | 131.3 (18.9) | 125.9 (15.5) | 5.4 | <0.01 | 85.6 (13.3) | 84.1 (11) | 1.5 | <0.01
Nielsen, 1986 | 122 | | | 13 | >0.05 | | | 5 | >0.05
Stergiou, 1998b | 189 | 142.9 (16.3) | 137.5 (16.2) | 5.4 | <0.001 | 91.2 (9.9) | 85.9 (9.9) | 5.3 | <0.001
Weisser, 1994 | 503 | 130 (16.5) | 123.1 (14.6) | 6.9 | <0.01 | 82.1 (11.1) | 77.6 (10.7) | 4.5 | <0.01
Women | 238 | 126.4 (17.2) | 118.9 (16.1) | 7.5 | <0.01 | 79.3 (11.2) | 74.4 (11.1) | 4.9 | <0.01
Men | 265 | 133.4 (15.1) | 126.9 (12) | 6.5 | <0.01 | 84.7 (10.3) | 80.5 (9.7) | 4.2 | <0.01

Evidence Table 7: Distribution of readings between clinic blood pressure and ambulatory blood pressure measurement, systolic (question #1a)

Study | N | Mean (SD) mmHG | | | | Difference (SD) from clinic
Study | N | Clinic | Daytime | Nighttime | 24hr | Daytime | P-value | Nighttime | P-value | 24hr | P-value
Ironson, 1989 | 119 | 126 (17.2) | 121 (18.4) | | | 5 | <0.001
Jula, 1999 | 233 | 144.5 (12.6) | 148.3 (13.9) | 125.5 (16.4) | 141.7 (14) | −3.8 (9.9) | <0.001 | 19 | | 2.8
Khoury, 1992 | 131 | 155.4 | | | 138.4 | | | | | 17 | <0.001
Women | 62 | 160 | | | 137.8 | | | | | 22.2 | <0.05 ^a^
Men | 69 | 151.2 | | | 138.8 | | | | | 12.4 | <0.05 ^a^
Age <65 | 92 | 150.9 | | | 135.3 | | | | | 15.6 | <0.05 ^a^
Age >65 | 39 | 164.8 | | | 145 | | | | | 19.8 | <0.05 ^a^
Modesti, 1994 | 139 | 129 (16) | 120 (11) | 107 (12) | 117 (11) | 9 | <0.001 | 22 | <0.001 | 12 | <0.001
Myers, 1995b | 147 | 137 | 132 | | | 14 | <0.001
Narkiewicz, 1995 | 411 | 146.1 (10.4) | 134.9 (11) | 117.7 (11.4) | | 11.2 (12.9)
Staessen, 1999 | 808 | 173.3 (10.8) | 151.4 (16.2) | 134 (18.6) | 145.8 (15.6) | 21.9 | <0.001
Stergiou, 1998b | 189 | 142.9 (16.3) | 136 (14.3) | 119 (13.3) | 129.8 (13.2) | 6.9 | <0.001 | 23.9 | <0.001 | 13.1 | <0.001
Thijs, 1996 | 477 | 174 (12) | 153 | 136 | 148 | 21 | <0.001
Women | 292 | 175 | 153 (17) | 134 (19) | 147 (16) | 22 (8) | <0.05 ^a^
Men | 185 | 174 | 154 (16) | 139 (18) | 149 (15) | 19 (8) | <0.05 ^a^
Zachariah, 1991 | 126 | 118 (13) | | | 125 | | | | | −7(7) | <0.001
Zachariah, 1988 | 168 | 149 (14) | 145 (16) | | 141 (16) | 4 | <0.001 | | | 8 | <0.001
Zawadzka, 1998 | 410 | 168.4 (21.8) | | | | 11.5 (13.4)

a P-value determine by standard error or standard deviation of two groups

Evidence Table 8: Distribution of readings between clinic and ambulatory blood pressure, diastolic (question #1a)

Study | N | Mean (SD) mmHg | | | | Difference (SD) from clinic
Study | N | Clinic | Daytime | Nighttime | 24hr | Daytime | P-value | Nighttime | P-value | 24hr | P-value
Ironson, 1989 | 119 | 83 (12.4) | 80 (14.4) | | | 3 | <0.001
Jula, 1999 | 233 | 94.5 (7.4) | 91.9 (7.8) | 75.6 (8.9) | 87.2 (7.6) | 2.7 (6.8) | <0.001 | 18.9 | | 7.3
Khoury, 1992 | 131 | 93.1 | | | 85.4 | | | | | 7.7 | <0.0001
Women | 62 | 92.9 | | | 83.2 | | | | | | <0.05 ^a^
Men | 69 | 93.2 | | | 87.3 | | | | | | <0.05 ^a^
Age <65 | 92 | 94 | | | 85.4 | | | | | | <0.05 ^a^
Age >65 | 39 | 90.8 | | | 85.4 | | | | | 5.4 | <0.05 ^a^
Modesti, 1994 | 139 | 85 (11) | 75 (8) | 63 (11) | 71 (8) | 10 | <0.001 | 22 | <0.001 | 14 | <0.001
Myers, 1995b | 147 | 78 | 78
Narkiewicz, 1995 | 411 | 95.6 (3.7) | 83.8 (8.2) | 73.4 (8.3) | | 11.8 (8.1)
Staessen, 1999 | 808 | 86 (5.8) | 84.1 (9.8) | 70.2 (10.1) | 79.3 (8.9) | 1.9 | <0.001
Stergiou, 1998b | 189 | 91.2 (9.9) | 86.8 (11.1) | 71.4 (10.1) | 71.4 (10.1) | 4.4 | <0.001 | 19.8 | <0.001 | 10.2 | <0.001
Thijs, 1996 | 477 | 86 (6) | 85 | 71 | 80 | 1 | > 0.05
Women | 292 | 86 | 84 (10) | 69 (11) | 79 (10)
Men | 185 | 86 | 86 (9) | 73 (10) | 81 (8)
Zachariah, 1988 | 168 | 99 (6) | 96 (7) | | 93 (7) | 3 | <0.001 | | | 6 | <0.001
Zachariah, 1991 | 126 | 75 (7) | | | 72 | | | | | 3 (6) | <0.0001
Zawadzka, 1998 | 410 | 106.8 (10.1) | | | | 5.8 (8.5)

a P-value determined by standard error or standard deviation of groups

Evidence Table 9: Distribution of readings between self-measured blood pressure and ambulatory blood pressure measurement, systolic (question #1a)

Study | N | Mean (SD) mmHg | | | | Difference (SD) from self
Study | N | Self | Daytime | Nighttime | 24hr | Daytime | P-value | Nighttime | P-value | 24hr | P-value
Sega, 1994 | 1651 | 119 | | | 118 | | | | | 1 | <0.01
Stergiou, 1998b | 189 | 137.5 (16.2) | 136 (14.3) | 119 (13.3) | 129.8 (13.2) | 1.5 | >0.05 | 18.5 | <0.001 | 7.7 | <0.001
Stergiou, 2000 | 133 | 138.7 (15.6) | 139.3 (12.8) | | | −0.6 (11.8) | >0.05

Evidence Table 10: Distribution between self-measured blood pressure and ambulatory blood pressure measurement, diastolic (question #1a)

Study | N | Mean (SD) mmHg | | | | Difference (SD) from self
Study | N | Self | Daytime | Nighttime | 24hr | Daytime | P-value | Nighttime | P-value | 24hr | P-value
Sega, 1994 | 1651 | 75 | | | 74 | | | | | 1 | <0.01
Stergiou, 1998a | 189 | 85.9 (9.9) | 86.8 (11.1) | 71.4 (10.1) | 81.0 (10.4) | −0.9 (7) | >0.05 | 14.5 | <0.001 | 4.9 | <0.001
Stergiou, 2000 | 133 | 89.3 (8.6) | 91.1 (9.9) | | | −1.8 (6.7) | >0.05

Evidence Table 11: Prevalence of white coat hypertension by self-measured blood pressure (question #1b)

Study | N | Definition of Hypertension | | Prevalence WCH (%)
Study | N | Clinic | SMBP | Prevalence WCH (%)
Abe, 1987 | 100 | Hypertension was defined by 1962 WHO classification | Hypertension was defined by 1962 WHO classification | 17
Aylett, 1999 | 660 | All participants with clinic hypertension (defined as SBP > 160 and DBP > 100 mmHg) | WCH present if mean SMBP < 150 / 85 mmHg | 16.5
Uncontrolled hypertensive | 424 | | | 17
Untreated hypertensive | 236 | | | 27
Stergiou, 1998a | 189 | | WCH present if difference between clinic and mean self SBP > 20 mmHg or self DBP> 10 mmHg | 25.9
Stergiou, 2000 | 133 | All participants with clinic hypertension defined by A) SBP > 140 and DBP > 90 mmHg B) SBP/DBP > 135/85 mmHg | A) WCH present if mean self BP < 140 / 90 mmHg B) WCH present if mean self BP < 135 / 85 mmHg | A) 33 B) 13

Evidence Table 12: Prevalence of white coat hypertension by ambulatory blood pressure (question #1c)

Study | N | Definition of Hypertension | | Prevalence WCH (%)
Study | N | Clinic | ABP | Prevalence WCH (%)
Helmers, 2000 | 194 | All participants with clinic hypertension (defined as DBP > 90 and< 105 mmHg) | WCH present if mean daytime ambulatory DBP < 85 mmHg | 21.6
Men | 128 | | | 14.84
Women | 66 | | | 34.84
Hoeglholm, 1999 | 269 | All participants with clinic hypertension (defined as DBP > 90 mmHg) | WCH present if mean daytime ambulatory BP < 135 / 90 mmHg | 18.1
Men | 269 | | | 11.6
Women | 297 | | | 23.8
Inden, 1998 | 232 | All participants with clinic hypertension (defined as SBP > 140 or DBP > 90 mmHg) | A) WCH present if mean 24-hour ambulatory SBP <135 mmHg and DBP < 85 mmHg B) WCH present if mean daytime ambulatory SBP< 120 mmHg and DBP < 75 mmHg | A) 13 B)19
MacDonald, 1999 | 103 | All participants with clinic hypertension (defined as SBP > 140 to <200 mmHg or DBP > 90 to <120 mmHg) | WCH present if mean daytime ambulatory SBP< 140 mmHg and DBP < 90 mmHg or "if the systolic/diastolic pressure was at least 20/15 mmHg. (Both) lower than the clinic reading". | 36
Men | 55 | | | 20
Women | 48 | | | 54
Manning, 1999. | 186 | All participants with clinic hypertension (defined as SBP > 140/90 mmHg) | WCH present if mean daytime ambulatory SBP < 136/86 mmHg | 23
Men | 95 | | | 10.2
Women | 91 | | | 12.4
Martinez, 1998 | 345 | All participants with clinic hypertension (defined as SBP > 140 and < 179 mmHg or DBP > 90 and 109 mmHg) | A) WCH present if mean daytime (10 am - 8 pm) ambulatory SBP < 135 mmHg and DBP < 85 mmHg B) WCH present if mean daytime (9am - 10 pm) ambulatory SBP <131 / 86 mmHg (women) and < 136/87 mmHg (men) | A) 39 B) 35
Men | 165 | | | A) 31
Women | 180 | | | A) 47
Martinez, 2001 | 223 | All participants with clinic hypertension (defined as SBP > 140 to < 159 or DBP > 90 to < 99 mmHg) | Men: WCH present if mean daytime ambulatory SBP < 135 mmHg and DBP < 86 mmHg Women: WCH present if mean daytime ambulatory SBP <130 mmHg and DBP < 85 mmHg | 32.3
Myers, 1995a | 152 | | A) WCH present if difference between clinic and mean daytime ambulatory SBP > 20 mmHg or ambulatory DBP > 10 mmHg) B) Severe WCH present if difference between clinic mean daytime ambulatory SBP > 40 mmHg or DBP > 20 mmHg) | A) 67.1 B)32.2
Men | 65 | | A. WCH B. Severe WCH | A) 55.4 B) 12.3
Women | 87 | | A. WCH B. Severe WCH | A) 80.5 B) 47.1
Owens, 1999 | 1350 | All participants with clinic hypertension (defined as SBP > 140 mmHg and DBP > 90 mmHg) | WCH present if mean daytime ambulatory BP < 135 / 85 mmHg | 11
Pierdomenico, 1995 | 255 | All participants with clinic hypertension (defined as SBP > 140 or DBP> 90 mmHg) | WCH considered present if: A) 24-hour ambulatory SBP< 135 mmHg and DBP< 85 mmHg B) Daytime ambulatory SBP< 134 mmHg and DBP< 90 mmHg C) Daytime ambulatory SBP<136 mmHg and DBP< 90 mmHg D) Daytime ambulatory SBP < 146 mmHg and DBP < 91 mmHg | A) 21 B) 18.4 C) 19.2 D) 22.7
Stergiou, 1998a | 189 | | WCH present if difference between clinic and mean daytime ambulatory SBP > 20 mmHg or ambulatory DBP> 10 mmHg) | 25.9
Stergiou, 2000 | 133 | All participants with clinic hypertension defined as: A) SBP > 140 mmHg or DBP > 90 mmHg B) BP > 135/85 mmHg | A) WCH present if mean daytime ambulatory BP < 140 / 90 mmHg B) WCH present if mean daytime ambulatory BP < 135 / 85 mmHg | A) 24 B) 11
Tochikubo, 1998 | 172 | All participants with clinic hypertension (defined as SBP > 140 mmHg or DBP > 90 mmHg) | WCH present if mean 24- hour ambulatory SBP< 133 mmHg and DBP < 82 mmHg | 22
Verdecchia, 1992 | 260 | All participants with clinic hypertension (defined as DBP > 90 or SBP> 160 mmHg) | WCH considered present if the mean daytime ambulatory SBP < 134 mmHg and DBP <88 mmHg | 11.9
Men | 118 | | | 11
Women | 142 | | | 12.7
Verdecchia, 1995 | 1414 | All participants with clinic hypertension (defined as SBP > 140 or DBP > 90 mmHg) | Men: WCH present if mean daytime ambulatory SBP< 136 mmHg and DBP < 87 mmHg Women: WCH present if mean daytime ambulatory SBP<131 mmHg and DBP < 86 mmHg | 18.9
Zawadzka, 1998 | 410 | All participants with clinic hypertension (defined as DBP >90 mmHg) | WCH present if mean daytime ambulatory DBP < 90 mmHg | 30.2

Evidence Table 13: Reproducibility of white coat hypertension (WCH) (question #1c)

Study | N | Interval between Assessments | Definition of Hypertension | | Prevalence of WCH^a^
Study | N | Interval between Assessments | Clinic | Ambulatory | Initial N (%) | Repeat N (%)
Palatini, 1998 | 565 | 3 months | Clinic SBP 140-159 mmHg and/or DBP 90-99mmHg | WCH present if ABP: < 130/80mmHg | 90 (100) | 38 (42)
Verdecchia, 1996 | 83 | 2.5 years | Clinic SBP > 140 and/or DBP > 90 mmHg | WHC present if ABP: women < 131/86 mmHg men: < 136/87 mmHg | 83 (100) | 52 (63)

a WCH defined by hypertension by clinic BP, non-hypertension by ambulatory BP

Evidence Table 14: Summary of quality characteristics for articles addressing question #2

Study | Centers | Funding | Adequate Description | | Clinic BP Observer | | | Self BP Instructions Provided | Ambulatory BP Trained | Statistical Variability Reported
Study | Centers | Funding | Eligibility | Baseline Characteristics | Trained | Blinded | Standard Technique | Self BP Instructions Provided | Ambulatory BP Trained | Statistical Variability Reported
Jula, 1999 | single | can't tell | Y | Y | Y | Y | Y | Y | can't tell | Y

Evidence Table 15: Summary of population characteristics for articles addressing question #2

Study | N | Setting | Target Population | Exclusions | Male (%) | Black (%) | Mean Age, years (SD) | HTN (%) | On BP medication (%)
Jula, 1999 | 233 | general clinic | age between 34 and 55; hypertensives | pregnancy; anti-hypertensive medication; diabetes; active CHD/CVD; valvular heart disease | 58.4 | | 46 (4.9) | 100 | 0

Evidence Table 16: Summary of clinic measurements for articles addressing question #2

Study | Device Type | Observer | Position | Measurements (number)
Study | Device Type | Observer | Position | Per Day | Days | Total
Jula, 1999 | mercury | nurse | sitting | 2 | 4 | 8

Evidence Table 17: Summary of self measurement for articles addressing question #2

Study | Device | | | Observer | Time of Recordings^a^ | | | Measurements (Number)
Study | Type | Name | Validated | Observer | Morning | Afternoon | Evening | Per day | Days | Total
Jula, 1999 | electronic or automated | Omron 705c | Y | patient | Y | N | Y | 4 | 7 | 28

a morning = before noon, afternoon = noon to 6:00pm, evening=after 6:00pm

Evidence Table 18: Characteristics of measures of left ventricular mass (question #2)

Study | Left ventricular mass | | Left ventricular hypertrophy
Study | Units | Mean (SD) | Criteria | Prevalence (%)
Jula, 1999 | LV mass by surface area (g/m^2^) | 111 (2.5) | unknown | unknown

Evidence Table 19: Correlation of clinic and self-measured blood pressure with left ventricular mass (question #2)

Study | Systolic BP | | Diastolic BP | | Adjustment factors
Study | Clinic | Self | Clinic | Self | Adjustment factors
Jula, 1999 | 0.4 (<0.001) | 0.47 (<0.001) | 0.37 (<0.001) | 0.44 (<0.001) | unadjusted

Evidence Table 20: Characteristics of albuminuria measurement (question #2)

Study | Measurement | Collection Period | Mean (SD) | Criteria | Prevalence (%)
Jula, 1999 | mg/24hrs | 24 hours | 25.7 (39.3) | NA | NA

Evidence Table 21: Correlation of clinic and self-measured blood pressure with albuminuria (question #2)

Study | Systolic BP | | Diastolic BP | | Adjustment factors
Study | Clinic (P-value) | Self (P-value) | Clinic (P-value) | Self (P-value) | Adjustment factors
Jula, 1999 | 0.34 (<0.001) | 0.32 (<0.001) | 0.25 (<0.001) | 0.28 (<0.001) | unadjusted

Evidence Table 22: Summary of quality characteristics for prospective studies addressing question #2 (question #2b)

Study | Centers | Funding | Adequate description | | Clinic BP Observer | | | Self BP Instructions Provided | Blinded Outcome Assessment | Followup data for >80% | Statistical Variability Reported
Study | Centers | Funding | Eligibility | Baseline Characteristics | Trained | Blinded | Standard Technique | Self BP Instructions Provided | Blinded Outcome Assessment | Followup data for >80% | Statistical Variability Reported
Ohkubo, 1998 | single | govt, other | Y | Y | can't tell | N | Y | Y | N | Y | Y
Sakuma, 1997 | single | govt, other | Y | N | can't tell | N | can't tell | Y | N | Y | Y

Evidence Table 23: Summary of population characteristics for prospective studies addressing question #2 (question #2b)

Study | N | Setting | Target Population | Exclusions | Male (%) | Black (%) | Mean Age, years (SD) | HTN (%) | On BP medication (%)
Ohkubo, 1998 | 1728 | general population in Japan | age >40 | demented; bedridden; hospitalized | 41.7 | | 61 | | 33.7
Sakuma, 1997 | 1256 | general population in Japan | age>40 | demented; bedridden; hospitalized; prior stroke, atrial fibrillation | 40.4 | | 59.1 (11)

Evidence Table 24: Summary of clinic measurement characteristics for prospective studies (question #2b)

Study | Device Type | Observer | Position | Measurements (Number)
Study | Device Type | Observer | Position | Per Day | Days | Total
Ohkubo, 1998 | automated | med tech, nurse | sitting | 2 | 1 | 2
Sakuma, 1997 | automated | nurse, physician | sitting | 2 | 1 | 2

Evidence Table 25: Summary of self measurement characteristics for prospective studies addressing question #2 (question #2b)

Study | Device | | | Observer | Time of Recordings^a^ | | | Measurements (Number)
Study | Type | Name | Validated | Observer | Morning | Afternoon | Evening | Per day | Days | Total
Ohkubo, 1998 | electronic or automated | HEM 401C | unknown | patient | Y | N | N | 1 | 28 | 20.8
Sakuma, 1997 | electronic or automated | HEM 401C | unknown | patient | Y | N | N | 1 | 28 | 23

a morning = before noon, afternoon = noon to 6:00pm, evening = after 6:00pm

Evidence Table 26: Summary of methods in prospective studies (question #2b)

Study | Duration of follow-up Years | N | Outcome of Interest | | | Analyses Adjusted for | Comparison of Prediction
Study | Duration of follow-up Years | N | n | Outcome | Description | Analyses Adjusted for | Comparison of Prediction
Ohkubo ^a^ , 1998 | 6.6 (2.3) | 1728 | 52 | CVD Mortality | Deaths from cerebrovascular disease and cardiovascular disease | Age, Gender, Smoking, Prior CVD, BP medication | Not tested
| | 1728 | 160 | Total Mortality | Total mortality
Sakuma ^a^ , 1997 | 4.4 (2.1) | 1256 | 39 | Stroke | Cerebral hemorrhage, Cerebral infarction, Subarachnoid hemorrhage or Undetermined type of stroke | Age, Gender, Smoking, BP level | Not tested

a Both papers from Ohasama study

Evidence Table 27: Prediction of outcome by clinic blood pressure and self-measured blood pressure (question #2b)

Study | Outcome | Contrast | Clinic Systolic | | Self Systolic | | Clinic Diastolic | | Self Diastolic
Study | Outcome | Contrast | Estimate (RR) | P-value | Estimate (RR) | P-value | Estimate (RR) | P-value | Estimate (RR) | P-value
Ohkubo, 1998 | CVD Mortality | Per mmHg | 1 | 0.97 | 1.021 | 0.048 | 1.005 | 0.704 | 1.013 | 0.414
| Total Mortality | Per mmHg | 1.001 | 0.84 | 1.014 | 0.012 | 1.002 | 0.73 | 1.012 | 0.16
Sakuma, 1997 | Stroke | 2^nd^ VS 1^st^ Quintile | 2.12 ^b^ | NS | 1.03 ^b^ | NS | 2.89 | NS | 0.88 ^b^ | NS
| | 3^rd^ VS 1^st^ Quintile | 1.33 ^b^ | NS | 0.18 ^b^ | NS | 2.79 | NS | 1.06 ^b^ | NS
| | 4^th^ VS 1^st^ Quintile | 0.6 ^b^ | NS | 1.46 ^b^ | NS | 2.7 | NS | 1.19 ^b^ | NS
| | 5^th^ VS 1^st^ Quintile | 3.6 ^b^ | <0.05 | 2.56 ^b^ | NS | 6.12 | <0.05 | 3.12 ^b^ | <0.05

a Both papers from Ohasama study

b Calculated from data in paper

Evidence Table 28: Summary of quality characteristics for self-measured blood pressure trials (question #2d)

Study | Center | Funding | Adequate Description | | | | | Self BP Instruction Provided | Outcome Assessor Blinded^a^ | Between Group P-value Reported
Study | Center | Funding | Eligibility | Sample Size Justification | Randomization | BP Therapy | Outcomes | Self BP Instruction Provided | Outcome Assessor Blinded^a^ | Between Group P-value Reported
Bailey, 1999 | single | can't tell | N | N | N | Y | Y | Y | N | Y
Binstock, 1988 | single | can't tell | N | N | N | N | N | N | N | Y
Carnahan, 1975 | single | can't tell | N | N | N | Y | Y | Y | Y | Y
Earp, 1982 | single | govt | Y | N | N | N | Y | Y | Y | Y
Friedman, 1996 | single | govt | Y | N | Partial | N | Y | N | Y | Y
Johnson, 1978 | single | govt | Partial | N | Y | N | N | Y | Y | Y
Lehnert, 1987 | can't tell | can't tell | Y | N | Y | Y | Y | Y | N | N
Midanik, 1991 | single | other | N | N | N | N | Y | Y | N | N
Rogers, 2001 | single | industry | Y | Y | Y | N | Y | Y | Y | Y
Soghikian, 1992 | can't tell | other | N | N | Partial | N | Y | Y | N | N
Stahl, 1984 | single | govt | Y | N | Y | Y | N | Y | N | N
Vetter, 2000 | multi | industry | Y | N | Partial | Y | Y | Y | N | N

Evidence Table 29: Summary of population characteristics for self-measured blood pressure trials (question #2d)

Study | N | Setting | Target Population | Exclusions | Male (%) | Black (%) | Mean Age, years (SD) | HTN (%) | On BP medication (%)
Bailey, 1999 | 62 | general clinic | inadequately controlled hypertension | unable to record self-BP | 53.2 | | 55.0 | 100 | 93.5
Binstock, 1988 | 112 | can't tell | hypertensives | can't tell | 40 | | | 100
Carnahan, 1975 | 100 | hypertension clinic | hypertensives | can't tell | 98 | | 55.2 | 100 | 0
Earp, 1992 | 218 | general clinic, hypertension clinic | hypertensives; anti-hypertensive medicaton | alcoholism; mental illness | 41 | 77 | 47.4 | 100 | 100
Friedman, 1996 | 267 | general population | age >60 ; hypertensives; anti-hypertensive medication | unable to record self-BP | 22.8 | 10.5 | 76.5
Johnson, 1978 | 140 | general population | age between 34 and 66; hypertensives; anti-hypertensive medication; uncontrolled BP on medication | can't tell | 58.6 | | 53.0 | 100 | 100
Lehnert, 1987 | 189 | rehabilitation center | age between 19 and 61; hypertensives | diabetes; active CHD/CVD; secondary hypertension | 78.3 | | 41.2 | 100 | 63.5
Midanik, 1991 | 204 | general clinic | untreated hypertensives | can't tell | 47.5 | 48.5 | 47.3 | 100 | 0
Rogers, 2001 | 121 | general clinic | hypertensives with elevated BP or symptoms | age <18; pregnancy; secondary hypertension | 49.6 | 9.1 | 61.4 | 100
Soghikian, 1992 | 430 | general clinic | hypertensives | active CHD/CVD | 49.8 | 39.1 | 54.3 | 100 | 85.1
Stahl, 1984 | 396 | screening events | age between 15 and 71; hypertensives | anti-hypertensive medication | 57.9 | 76.2 | 47.5 | 100
Vetter, 2000 | 622 | general clinic | age between 17 and 86; hypertensives; anti-hypertensive medication | proteinuria/albuminuria; active CHD/CVD; contraindication to losartan; hepatic disease | 49.2 | | 57.5 | | 100

Evidence Table 30: Summary of methods for self-measured blood pressure trials (question #2d)

Study | Objective | Duration (months) | Group | N | SMBP Intervention
Study | Objective | Duration (months) | Group | N | Device Type | Device Name | SMBP Frequency | Co-Intervention
Bailey, 1999 | To determine the effects of SMBP on BP control. | 2 | Control | 30
Bailey, 1999 | To determine the effects of SMBP on BP control. | 2 | SMBP | 32 | electronic or automated | Omron HEM 706 | twice daily
Binstock, 1988 | To compare the effects of different compliance techniques with education alone (control group) on BP. | 12 | Control | 32
Binstock, 1988 | To compare the effects of different compliance techniques with education alone (control group) on BP. | 12 | SMBP | 23 | can't tell | can't tell | not discussed
Binstock, 1988 | To compare the effects of different compliance techniques with education alone (control group) on BP. | 12 | Compliance Contract | 15
Binstock, 1988 | To compare the effects of different compliance techniques with education alone (control group) on BP. | 12 | Calender pill count | 30
Binstock, 1988 | To compare the effects of different compliance techniques with education alone (control group) on BP. | 12 | All of the above | 11 | can't tell | can't tell | not discussed
Carnahan, 1975 | To determine the effects of SMBP on BP control. | 6 | Control | | electronic or automated | Ultrasphyg Lumiscope
Carnahan, 1975 | To determine the effects of SMBP on BP control. | 6 | SMBP | | | | twice daily
Earp, 1982 | To determine the effects of social support strategies on BP control. | 24 | Control | 63
Earp, 1982 | To determine the effects of social support strategies on BP control. | 24 | SMBP and social support | 99 | can't tell | can't tell | not discussed | activated significant other
Earp, 1982 | To determine the effects of social support strategies on BP control. | 24 | Home visits | 56
Friedman, 1996 | To determine the effects of a SMBP / telecommunication system (TLC) on BP control. | 6 | Control | 134
Friedman, 1996 | To determine the effects of a SMBP / telecommunication system (TLC) on BP control. | 6 | TLC | 133 | electronic or automated | Omron | weekly | telephone evaluation of medications, adherence, and symptoms
Johnson, 1978 | To determine if SMBP improves BP control and compliance in poorly controlled hypertensives. | 6 | Control | 34
Johnson, 1978 | To determine if SMBP improves BP control and compliance in poorly controlled hypertensives. | 6 | SMBP and Home visit | 35 | can't tell | Taylor Syborn Corporation, Arden, NC | not discussed
Johnson, 1978 | To determine if SMBP improves BP control and compliance in poorly controlled hypertensives. | 6 | SMBP | 34 | | | not discussed
Johnson, 1978 | To determine if SMBP improves BP control and compliance in poorly controlled hypertensives. | 6 | Home visit | 33
Lehnert, 1987 | To determine the effects of a multi-dimensional behavioral training program on BP. | 1.5 | Control | 81 | | | | low salt diet, physical training
Lehnert, 1987 | To determine the effects of a multi-dimensional behavioral training program on BP. | 1.5 | Program | 108 | mercury | | three times daily | low salt diet, physical training, multidimensional behavioral program
Midanik, 1991 | To determine the effects of SMBP on BP control. | 12 | Control | 102
Midanik, 1991 | To determine the effects of SMBP on BP control. | 12 | SMBP | 102 | electronic or automated | Tyco self check digital device | twice weekly | monthly BP reports sent to participants
Rogers, 2001 | To determine if SMBP with telemetric transmission of data reduces BP. | 2 | Control | 61
Rogers, 2001 | To determine if SMBP with telemetric transmission of data reduces BP. | 2 | SMBP | 60 | electronic or automated | 52500, Welch Allyn Inc. | 3 each morning and evening, 3 days per week | weekly reports provided to patients and physicians
Soghikian, 1992 | To determine the effects of SMBP on BP control. | 12 | Control | 215
Soghikian, 1992 | To determine the effects of SMBP on BP control. | 12 | SMBP | 215 | electronic or automated | Tyco self check model 7052-8 | twice weekly | monthly BP reports sent to MD and participant
Stahl, 1984 | To determine whether BP monitoring by self (SMBP) or family reduces BP. | 6 | Control | 173
Stahl, 1984 | To determine whether BP monitoring by self (SMBP) or family reduces BP. | 6 | Family monitoring of BP | 79 | | | not discussed
Stahl, 1984 | To determine whether BP monitoring by self (SMBP) or family reduces BP. | 6 | SMBP | 144 | mercury | | not discussed
Vetter, 2000 | To determine the effects of SMBP on BP control. | 2 | Control | 326
Vetter, 2000 | To determine the effects of SMBP on BP control. | 2 | SMBP | 296 | electronic or automated | Omron HEM 605 | twice daily in morning

Evidence Table 31: Characteristics of outcome measurements in self-measured blood pressure trials (question #2d)

Study | Measure | Device | Position | Measurements (Number)
Study | Measure | Device | Position | Per Day | Days | Total
Bailey, 1999 | clinic | mercury | sitting | can't tell
Binstock, 1988 | clinic | can't tell | can't tell | can't tell
Carnahan, 1975 | clinic | can't tell | sitting | 3 | 1 | 3
Earp, 1982 | clinic | can't tell | can't tell | can't tell
Friedman, 1996 | clinic | can't tell | can't tell | 2 | 1 | 2
Johnson, 1978 | clinic | can't tell | can't tell | can't tell
Lehnert, 1987 | clinic | can't tell | can't tell | 1 | 3 | 3
Midanik, 1991 | clinic | can't tell | can't tell | 2 | 1 | 2
Rogers, 2001 | ambulatory | SpaceLabs 90207 | NA | NA | 1
Soghikian, 1992 | clinic | can't tell | can't tell | 1 | 1 | 1
Stahl, 1984 | clinic | can't tell | can't tell | can't tell
Vetter, 2000 | clinic | can't tell | sitting | 3 | 1 | 3

Evidence Table 32: Results of self-measured blood pressure trials (question #2d)

Study | Group | Systolic BP (mmHg) | | | Diastolic BP (mmHg) | | | Other Findings and Comments
Study | Group | Baseline Mean (SD) | Change from Baseline in intervention groups, net of control | | Baseline Mean (SD) | Change from Baseline in intervention groups, net of control | | Other Findings and Comments
Study | Group | Baseline Mean (SD) | Change | P-value | Baseline Mean (SD) | Change | P-value | Other Findings and Comments
Biley, 1999 | Control | 155 (21.52) | X ^b^ | X ^b^ | 95 (10.76) | X ^b^ | X ^b^ | BP medications were more likely to be unchanged or increased in control group
Biley, 1999 | SMBP | 156 (22.24) | 5 | <0.05 | 93 (11.12) | 2 | NS | BP medications were more likely to be unchanged or increased in control group
Binstock, 1988 | Control | 151 | X ^b^ | X ^b^ | 89 | X ^b^ | X ^b^ | Unclear if significance test pertains to pair wise contrasts or overall comparison to control
Binstock, 1988 | SMBP | 149 | −10 | <0.01 | 90 | −5 | <0.01 | Unclear if significance test pertains to pair wise contrasts or overall comparison to control
Binstock, 1988 | Compliance Contract | 142 | −11 | <0.01 | 88 | −6 | <0.01 | Unclear if significance test pertains to pair wise contrasts or overall comparison to control
Binstock, 1988 | Calender pill count | 156 | −17 | <0.01 | 92 | −10 | <0.01 | Unclear if significance test pertains to pair wise contrasts or overall comparison to control
Binstock, 1988 | All of above | 147 | −10 | <0.01 | 88 | −7 | <0.01 | Unclear if significance test pertains to pair wise contrasts or overall comparison to control
Camhan, 1975 | Control | 156.6 | X ^b^ | X ^b^ | 103.6 | X ^b^ | X ^b^
Camhan, 1975 | SMBP | 152.7 | −7.5 | <0.05 | 101.7 | 0 | NS
Earp, 1982 | Control | | X ^b^ | X ^b^ | | X ^b^ | X ^b^ | BP control (DBP <95mmHg) significantly improved in both intervention groups (75% and 79%) compared to control group (58%) at end of follow-up.
Earp, 1982 | SMBP and social support | | | | | | | BP control (DBP <95mmHg) significantly improved in both intervention groups (75% and 79%) compared to control group (58%) at end of follow-up.
Earp, 1982 | Home visits | | | | | | | BP control (DBP <95mmHg) significantly improved in both intervention groups (75% and 79%) compared to control group (58%) at end of follow-up.
Friedman, 1996 | Control | | X ^b^ | X ^b^ | 84 | X ^b^ | X ^b^ | Improved adherence in TLC group
Friedman, 1996 | TLC | | −4.7 | 0.2 | 86.1 | −4.4 | 0.02 | Improved adherence in TLC group
Johnson, 1978 | Control | | X ^b^ | X ^b^ | 103.2 (10.2) | X ^b^ | X ^b^
Johnson, 1978 | SMBP and Home visit | | | | 104.2 (6.5) | −0.5 | NS
Johnson, 1978 | SMBP | | | | 102.6 (7.2) | −1.3 | NS
Johnson, 1978 | Home visit | | | | 103.9 (6.31) | −0.9 | NS
Lehnert, 1987 | Control | 169.8 | X ^b^ | X ^b^ | 104 | X ^b^ | X ^b^ | Fewer persons on medications and less medication use in active treatment group
Lehnert, 1987 | Program | 168.4 | −0.4 | | 104.6 | 0.5 | | Fewer persons on medications and less medication use in active treatment group
Midanik, 1991 | Control | 144 (16.8) | X ^b^ | X ^b^ | 92.7 (7.7) | X ^b^ | X ^b^ | No difference in percent of participants started on medications
Midanik, 1991 | SMBP | 144.4 (15.7) | −2.4 | NS | 91.3 (9.1) | 0.1 | NS | No difference in percent of participants started on medications
Rogers, 2001 | Control | | X ^b^ | X ^b^ | | X ^b^ | X ^b^ | Similar results by gender. Significant net reduction in mean arterial pressure in African Americans (14.9 mmHg)
Rogers, 2001 | SMBP | | −4.8 ^a^ | 0.047 | | −4.1 ^a^ | 0.01 | Similar results by gender. Significant net reduction in mean arterial pressure in African Americans (14.9 mmHg)
Soghikian, 1992 | Control | 140.2 (17.91) | X ^b^ | X ^b^ | 86.3 (11.02) | X ^b^ | X ^b^ | Reduced HTN costs and visits in SMBP group. Significant BP reduction in men but not in women
Soghikian, 1992 | SMBP | 137.4 (16.96) | −4.5 | <0.05 | 86.1 (8.48) | −1.6 | 0.05 | Reduced HTN costs and visits in SMBP group. Significant BP reduction in men but not in women
Stahl, 1984 | Control | | X ^b^ | X ^b^ | 108.6 | X ^b^ | X ^b^ | Fewer dropouts from family care group
Stahl, 1984 | Family monitoring of BP | | | | 107 | −0.9 | NS | Fewer dropouts from family care group
Stahl, 1984 | SMBP | | | | 109.7 | −1.1 | NS | Fewer dropouts from family care group
Vetter, 2000 | Control | 168.1 (14.44) | X ^b^ | X ^b^ | 102 (5.95) | X ^b^ | X ^b^ | BP control (diastolic BP < 90 mmHg) 66.2% in SMBP vs 59.8% in control (0.05<p<0.10), achieving statistical significance in women (73.2% vs 64.1%, p<0.01) but not in men (59.2% vs 55.3%, p>0.20).
Vetter, 2000 | SMBP | 166.1(14.44) | −0.05 | | 101.9 (6.19) | −1.3 | | BP control (diastolic BP < 90 mmHg) 66.2% in SMBP vs 59.8% in control (0.05<p<0.10), achieving statistical significance in women (73.2% vs 64.1%, p<0.01) but not in men (59.2% vs 55.3%, p>0.20).

a Ambulatory Blood Pressure

b cell has a slash in the print document

Evidence Table 33: Summary of quality characteristics for articles addressing question #3

Study | Center | Funding | Adequate Description | | Clinic BP Observer | | | Ambulatory BP Trained | Statistical Variability Reported
Study | Center | Funding | Eligibility | Baseline Characteristics | Trained | Blinded | Standard Technique | Ambulatory BP Trained | Statistical Variability Reported
Baguet, 2001 | single | can't tell | Y | Y | can't tell | Y | Y | Y | Y
Bauduceau, 1998 | multi | can't tell | Y | Y | can't tell | Y | N | can't tell | Y
Chen, 1995 | multi | govt, other | Y | Y | can't tell | N | can't tell | Y | Y
Cuspidi, 2000 | single | can't tell | Y | Y | can't tell | N | Y | Y | Y
Devereux, 1983 | single | govt, other | Y | Y | can't tell | N | can't tell | Y | Y
Ferrara, 1997 | single | can't tell | Y | Y | can't tell | Y | Y | Y | Y
Gosse, 1993 | single | can't tell | Y | Y | can't tell | N | can't tell | can't tell | Y
Gosse, 1997 | single | can't tell | Y | Y | can't tell | Y | N | N | Y
Hansen, 1992 | single | other | N | Y | can't tell | N | N | Y | Y
Hoegholm, 1994 | multi | other | Y | Y | can't tell | Y | can't tell | can't tell | Y
Hoegholm, 1999 | multi | can't tell | Y | Y | N | Y | N | can't tell | Y
Jula, 1999 | single | can't tell | Y | Y | Y | Y | Y | can't tell | Y
Lemne, 1995 | single | govt, industry | Y | Y | Y | Y | Y | can't tell | Y
Manning, 1999 | single | can't tell | Y | Y | can't tell | Y | Y | Y | Y
Martinez, 1999 | multi | govt, industry | Y | Y | Y | Y | Y | Y | Y
Martinez, 2001 | multi | govt, industry | Y | Y | can't tell | Y | Y | Y | Y
Myers, 1995b | single | can't tell | Y | Y | Y | Y | can't tell | can't tell | Y
Palatini, 1998 | multi | can't tell | Y | Y | can't tell | N | Y | Y | Y
Pierdomenico, 1995 | single | can't tell | Y | Y | can't tell | Y | Y | Y | Y
Pose-Reino, 1996 | single | can't tell | Y | Y | can't tell | Y | can't tell | can't tell | Y
Redon, 1994 | single | industry | Y | Y | can't tell | N | Y | can't tell | Y
Redon, 1996 | can't tell | can't tell | Y | Y | can't tell | N | Y | can't tell | Y
Schulte, 1993 | can't tell | can't tell | N | Y | can't tell | N | can't tell | can't tell | Y
Verdecchia, 1990 | single | can't tell | Y | Y | can't tell | Y | can't tell | can't tell | Y
Verdecchia, 1995 | multi | other | Y | Y | can't tell | N | can't tell | can't tell | Y
Weber, 1994 | single | govt | Y | Y | can't tell | Y | Y | can't tell | Y
Zakopoulos, 1999 | can't tell | can't tell | Y | Y | can't tell | N | can't tell | Y | Y

Evidence Table 34: Summary of population characteristics for articles addressing question #3

Study | N | Setting | Target Population | Exclusions | Male (%) | Black (%) | Mean Age, years (SD) | HTN (%) | On BP medication (%)
Baguet, 2001 | 200 | hypertension clinic | hypertensives | regional wall motion abnormalities on echocardiogram; valvular disease or cardiomyopathy | 62 | | 51 (13) | 100 | 0
Bauduceau, 1998 | 171 | other research study | hypertensives; diabetes | age <18 and >75; anti-hypertensive medication; serum creatinine>1500 ml/L | 54 | | 62 (10) | 100 | 0
Chen, 1995 | 1682 | general population | hypertensives; normotensives | can't tell | | | 54.8 (13.1) | 34.6
Normotensive | 720 | | | | 51 | | 51.3 (13.4) | 0 | 13
Borderline hypertensive | 380 | | | | 54 | | 58.1 (12.2) | 0 | 40
Hypertensive | 582 | | | | 50 | | 57 (12.4) | 100 | 53
Cuspidi, 2000 | 100 | hypertension clinic | hypertensives; anti-hypertensive medication | active CHD/CVD; obesity; cardiac valve disease; conditions preventing ABPM (afib) | 61 | | 56.5 (8.8) | 100 | 100
Devereux, 1983 | 100 | hypertension clinic | hypertensives; normotensives | active CHD/CVD | 81 | | 42.4 | 81 | 0
Ferrara, 1997 | 108 | can't tell | hypertensives; normotensives | anti-hypertensive medication; diabetes; chronic renal insufficiency; active CHD/CVD; liver cirrhosis; chronic lung disease; lactation; oral contraceptive use; no echocardiograph | 63.9 | | 42.3 (10.2) | 70.4 | 0
Gosse, 1993 | 204 | other specialty clinic | hypertensives | anti-hypertensive medication; active CHD/CVD; secondary hypertension | 68.6 | | 50 (11) | 100 | 0
Gosse, 1997 | 181 | hypertension clinic | hypertensives | anti-hypertensive medication; active CHD/CVD; poor quality echocardiograph | 70.7 | | 50 (11) | 100 | 0
Hansen, 1992 | 68 | general population | age <50; Type Idiabetes | pregnancy; anti-hypertensive medication | 70.6 | | 30.5 (10.2) | | 0
Hoegholm, 1994 | 411 | general practitioners; general population | | anti-hypertensive medication; diabetes; dialysis; chronic renal insufficiency; renal transplant | 46.4 | | | 69 | 0
Normotensive | 127 | | | | 50.4 | | 53.4 (15.4) | 0 | 0
Hypertensive | 284 | | | | 44.7 | | | 100 | 0
Hoegholm, 1999 | 566 | general practitioners; general population | hypertensives; normotensives | anti-hypertensive medication; diabetes; active CHD/CVD | 47.5 | | | 74.2 | 0
Jula, 1999 | 233 | general clinic | age between 34 and 55; hypertensives | pregnancy; anti-hypertensive medication; diabetes; active CHD/CVD; valvular heart disease | 58.4 | | 46 (4.9) | 100 | 0
Lemne, 1995 | 138 | general population | males | can't tell | 100 | | | 50
Normotensives | 69 | | | | 100 | | 49.5 (5.7) | 0
Borderline hypertensives | 69 | | | | 100 | | 50 (5.5) | 100
Manning, 1999 | 186 | hypertension clinic | hypertensives | anti-hypertensive medication; | 51.1 | | 46 | 100 | 0
Martinez, 1999 | 345 | general clinic | hypertensives | racial groups; normotensives; anti-hypertensive medication; significant concomitant diseases | 47.8 | 0 | 51.8 (10.6) | 100 | 0
Women | 180 | | | | 0 | 0 | | 100 | 0
Men | 165 | | | | 100 | 0 | | 100 | 0
Martinez, 2001 | 223 | general clinic | hypertensives | age <18 age >75; normotensives; anti-hypertensive medication; diabetes; chronic renal insufficiency; renal transplant; active CHD/CVD | 49.8 | 0 | 53 (11) | 100 | 0
Myers, 1995b | 147 | primary care family physicians | hypertensives; anti-hypertensive medication | age <21 age >80; dialysis;chronic renal insufficiency;renal transplant; active CHD/CVD | 38.1 | | 64 | 100 | 100
Men | 56 | | | | 100 | | | 100 | 100
Women | 91 | | | | 0 | | | 100 | 100
Palatini, 1998 | 1037 | can't tell | age between 18 and 45; hypertensives; normotensives | anti-hypertensive medication | 72 | | 33.3 (8.6) | 90.8 | 0
Pierdomenico, 1995 | 100 | can't tell | no specific population | anti-hypertensive medication; diabetes; chronic renal insufficiency; active CHD/CVD; limited echocardiograhpic | 50 | | 47.8 (10.0) | 75 | 0
Pose-Reino, 1996 | 102 | other specialty clinic | hypertensives; normotensives | anti-hypertensive medication; active CHD/CVD; clinic DBP >104 mmHg | 52.9 | | | 50 | 0
Redon, 1994 | 127 | can't tell | age between 25 and 50; hypertensives; normotensives | anti-hypertensive medication; diabetes; chronic renal insufficiency; GFR< 80ml/min/1.73m^2^ | 64.6 | | 38.9 (73) | | 0
Redon, 1996 | 151 | can't tell | age between 25 and 50; hypertensives; normotensives; | anti-hypertensive medication; diabetes; chronic renal insufficiency; GFR< 80ml/min/1.73m^2^ | 63.6 | | 37 (8) | | 0
Schulte, 1993 | 142 | can't tell | hypertensives; normotensives | unknown | 51.4 | | 49 | 68.3 | 0
Normotensive | 45 | | | | 53.3 | | 46 (8) | 0 | 0
Hypertensive | 97 | | | | 50.5 | | 47.5 (9) | 100 | 0
Verdecchia, 1990 | 235 | can't tell | no specific population | anti-hypertensive medication; active CHD/CVD | | | | 58.3 | 0
Normotensive | 98 | | | | 51 | | 51.9 (14) | 0 | 0
Hypertensive | 137 | | | | 53 | | 52.5 (11) | 100 | 0
Verdecchia, 1995 | 1414 | can't tell | no specific population | congestive heart failure; valvular disease; concomitant disease | 44.8 | | 50 (12) | 87.4 | 0
Weber, 1994 | 259 | hypertension clinic | no specific population | anti-hypertensive medication; diabetes; chronic renal insufficiency; active CHD/CVD; hepatic disorder | 84.6 | | | 66 | 0
Zakopoulos, 1999 | 153 | can't tell | hypertensives | normotensives; anti-hypertensive medication; active CHD/CVD | 54.2 | | | 100 | 0

Evidence Table 35: Summary of clinic measurement characteristics for articles addressing question #3

Study | Device Type | Observer | Position | Measurements (Number)
Study | Device Type | Observer | Position | Per Day | Days | Total
Baguet, 2001 | mercury | can't tell | supine | 1 | 3 | 3
Bauduceau, 1998 | mercury | physician | sitting | 3 | 1 | 3
Chen, 1995 | can't tell | physician | sitting | 2 | 1 | 2
Cuspidi, 2000 | mercury | physician | sitting | 3 | 1 | 3
Devereux, 1983 | can't tell | physician | can't tell | can't tell
Ferrara, 1997 | automated | can't tell | supine | 2 | 3 | 6
Gosse, 1993 | mercury | physician | supine | 3 | 1 | 3
Gosse, 1997 | mercury | physician | supine | 3 | 1 | 3
Hansen, 1992 | mercury random zero | can't tell | sitting | 3 | 1 | 3
Hoegholm, 1994 | multiple devices | can't tell | sitting | can't tell
Hoegholm, 1999 | multiple devices | can't tell | sitting | can't tell
Jula, 1999 | mercury | nurse | sitting | 2 | 4 | 8
Lemne, 1995 | mercury | nurse | can't tell | can't tell
Manning, 1999 | mercury | can't tell | combination | 3 | 3 | 9
Martinez, 1999 | mercury | nurse, physician | sitting | 2 | 3 | 6
Martinez, 2001 | mercury | physician | sitting | 2 | 3 | 6
Myers, 1995b | mercury | nurse | sitting | 3 | 2 | 6
Palatini, 1998 | can't tell | can't tell | supine | 3 | 2 | 6
Pierdomenico, 1995 | can't tell | can't tell | supine | 3 | 1 | 3
Pose-Reino, 1996 | can't tell | can't tell | can't tell | can't tell
Redon, 1994 | mercury | can't tell | sitting | 3 | 1 | 3
Redon, 1996 | mercury | can't tell | sitting | 3 | 3 | 9
Schulte, 1993 | can't tell | can't tell | can't tell | can't tell
Verdecchia, 1990 | mercury random zero | can't tell | supine | can't tell
Verdecchia, 1995 | can't tell | can't tell | can't tell | can't tell
Weber, 1994 | can't tell | can't tell | sitting | 1 | 3 | 3
Zakopoulos, 1999 | can't tell | can't tell | can't tell | 3 | 3 | 9

Evidence Table 36: Summary of ambulatory blood pressure measurement for articles addressing question #3

Study | Device | | | Daytime | | Nighttime
Study | Type | Name | Validated | Definition | Time Interval (mins) | Definition | Time Interval (mins)
Baguet, 2001 | oscillometric | SpaceLabs 90207 | Y | 7:00am - 10:00pm | 15 | 10:00pm - 7:00am | 15
Bauduceau, 1998 | oscillometric | SpaceLabs 90207 | Y | 7:00am - 10:00pm | 15 | 10:00pm - 7:00am | 15
Chen, 1995 | oscillometric | SpaceLabs 90207 | Y | 7:00am - 10:00pm | 20 | 11:00pm - 6:00am | 60
Cuspidi, 2000 | oscillometric | SpaceLabs 90207 | Y | 7:00am - 11:00pm | 15 | 11:00pm - 7:00am | 20
Devereux, 1983 | unknown | Pressurometer II | unknown | patient reported | 15 | patient reported | 15
Ferrara, 1997 | oscillometric | SpaceLabs 90207 | Y | 7:00am - 10:45pm | 15 | 11:00pm - 6:40am | 20
Gosse, 1993 | auscultatory unknown | DIASYS 200 SpaceLabs 5200 | N unknown | 6:00pm - 10:00am | 15 | 10:00pm - 6:00am | can't tell
Gosse, 1997 | auscultatory unknown | DIASYS 200 SpaceLabs 5200 | N unknown | 6:00am - 10pm | 15 | 10:00pm - 6:00pm | can't tell
Hansen, 1992 | oscillometric | SpaceLabs 90202 | Y | 6:00am - 12:00pm | 20 | 12:00pm - 6:00am | 60
Hoegholm, 1994 | unknown | TM-2420 (no model specified) | unknown | 7:00am - 10:59pm | 15 | 11:00pm - 6:59am | 30
Hoegholm, 1999 | oscillometric oscillometric | TM-2420, Model 7 TM-2420, Model 6 | Y Y | 8:00am - 9:59pm | 15 | 12:00am - 5:59am | 30
Jula, 1999 | auscultatory | Accutracker II | N | 6:00pm - 11:00am | 15 | 11:00pm - 6:00am | 30
Lemne, 1995 | auscultatory | Pressurometer IV | unknown | patient reported | 15 | patient reported | 15
Manning, 1999 | auscultatory | Medilog ABP | N | patient reported | 30 | patient reported | 30
Martinez, 1999 | oscillometric | SpaceLabs 90207 | Y | 10:00am - 8:00pm | 15 | 12:00pm - 6:00am | 15
Martinez, 2001 | oscillometric | SpaceLabs 90207 | Y | 10:00am - 8:00am | 15 | 12:00am - 6:00am | 30
Myers, 1995b | oscillometric oscillometric | SpaceLabs 90202 SpaceLabs 90207 | Y Y | can't tell | 15 | not measured | not measured
Palatini, 1997 | oscillometric oscillometric | SpaceLabs 90207 TM-2420, Model 7 | Y Y | 6:00am - 11:00pm | 10 | 11:00pm - 6:00am | 15
Palatini, 1998 | oscillometric oscillometric | SpaceLabs 90207 TM-2420, Model 7 | Y Y | can't tell | 10 | can't tell | 30
Pierdomenico, 1995 | oscillometric | SpaceLabs 90207 | Y | 6:00am - 12:00am | 15 | 12:00am - 6:00am | 30
Pose-Reino, 1996 | auscultatory | Accutracker II | N | 8:00am - 10:00pm | 20 | 10:00pm - 8:00am | 30
Redon, 1994 | oscillometric oscillometric | SpaceLabs 90202 SpaceLabs 90207 | Y Y | 6:00am - 12:00pm | 20 | 12:00pm - 6:00am | 30
Redon, 1996 | oscillometric oscillometric | SpaceLabs 90202 SpaceLabs 90207 | Y Y | 6:00am - 12:00pm | 20 | 12:00pm - 6:00am | 30
Schulte, 1993 | oscillometric | SpaceLabs 90207 | Y | patient reported | 15 | patient reported | 30
Verdecchia, 1990 | unknown | SpaceLabs 5200 | unknown | 6:00am - 10:00pm | 15 | 8:00pm - 6:00am | 15
Verdecchia, 1995 | oscillometric oscillometric unknown | SpaceLabs 90202 SpaceLabs 90207 SpaceLabs 5200 | Y Y unknown | 6:00pm - 10:00pm | 15 | 10:00pm - 6:00am | 15
Weber, 1994 | oscillometric | SpaceLabs 90207 | Y | 6:00am - 10:00pm | 15 | 10:00pm - 6:00am | 15
Zakopoulos, 1999 | oscillometric | SpaceLabs 90207 | Y | 6:00am - 10:00pm | 15 | 10:00pm - 6:00am | 15

Evidence Table 37: Characteristics of measures of left ventricular mass (question #3)

Study | Left ventricular mass | | Left ventricular hypertrophy
Study | Units | Mean (SD) | Criteria | Prevalence (%)
Baguet, 2001 | LV mass by surface area (g/m^2^) | 108 (26) | not applied | unknown
Chen, 1995 | LV mass by surface area (g/m^2^)
Borderline hypertensive | | 92.4 (18.5) | not applied | unknown
Hypertensive | | 99.5 (20.1) | not applied | unknown
Normotensive | | 85.4 (25.3) | not applied | unknown
Cuspidi, 2000 | LV mass by surface area (g/m^2^) | unknown | 125 males 100 females | 28
Devereux, 1983 | LV mass by surface area (g/m^2^) | 104.9 (26.2) | not applied | unknown
Ferrara, 1997 | LV mass by height^2.7^ (g/m^2.7^) | 43.1 (10.2) | not applied | unknown
Gosse, 1993 | LV mass by height (g/m) | 140 | not applied | unknown
Gosse, 1997 | LV mass by surface area (g/m^2^) | 122 (31) | not applied | unknown
Hoegholm, 1999 | unknown (g/m^2^) | unknown | not applied | unknown
Jula, 1999 | LV mass by surface area (g/m^2^) | 111(25) | not applied | unknown
Lemne, 1995 | LV by height^2^ (g/m^2^) | | 134
Borderline hypertensives | | 114 (22) | | 16
Normotensives | | 109 (22) | | 12
Manning, 1999 | LV mass by surface area (g/m^2^) | 119.8 (31) | 132 males 110 females | 36.1
Martinez, 1999 | LV mass by surface area (g/m^2^) | | not applied | unknown
Men | | 124.0 (26.9) | not applied | unknown
Women | | 103.4 (18.8) | not applied | unknown
Myers, 1995b | LV mass by surface area (g/m^2^) | 109 | not applied | unknown
Palatini, 1998 | LV mass by surface area (g/m^2^) | 89.1 | | unknown
Pierdomenico, 1995 | LV by height^2^ (g/m^2^) | 110.8 (10.1) | not applied | unknown
Pose-Reino, 1996 | LV mass by surface area (g/m^2^) | unknown | 134 males 110 females | unknown
Redon, 1996 | LV mass by height (g/m) | 140.6 (44.1) | 140 males 120 females | 34
Schulte, 1993 | LV mass by surface area (g/m^2^) | unknown | 135 males 110 females | unknown
Normotensive | | 93.1(21.4) | not applied | 0
Hypertensive | | 137.2 (28.4) | not applied | 51.5
Verdecchia, 1990 | LV mass by surface area (g/m^2^) | unknown | not applied | unknown
Hypertensive | | unknown | not applied | unknown
Normotensive | | 82.4 (31) | not applied | unknown
Verdecchia, 1995 | LV mass by surface area (g/m^2^) | unknown | not applied | unknown
Weber, 1994 | LV mass by surface area (g/m^2^) | unknown | not applied | unknown
Zakopoulos, 1999 | LV mass by surface area (g/m^2^) | 125.4 (47.2) | not applied | unknown

Evidence Table 38: Correlation of clinic and ambulatory blood pressure with left ventricular mass (question #3)

Study | Correlations with Systolic BP (P-value) | | | | Correlations with Diastolic BP (P-value) | | | | Adjustment factors | Multivariate Model
Study | Clinic | 24 hr | Daytime | Nighttime | Clinic | 24 hr | Daytime | Nighttime | Adjustment factors | Multivariate Model
Baguet, 2001 | 0.34 (<0.001) | 0.37 (<0.001) | 0.35 (<0.001) | 0.37 (<0.001) | 0.25 (<0.001) | 0.28 (<0.001) | 0.23 (<0.001) | 0.29 (<0.001) | unadjusted | Y
Chen, 1995 | 0.34 (<0.01) | 0.43 (<0.01) | 0.42 (<0.01) | 0.41 (<0.01) | 0.2 (<0.01) | 0.32 (<0.01) | 0.33 (<0.01) | 0.29 (<0.01) | unadjusted | Y
Borderline hypertensive | 0.16 (<0.01) | 0.27 (<0.01) | 0.26 (<0.01) | 0.24 (<0.01) | −0.13 (>0.05) | 0.07 (>0.05) | 0.07 (>0.05) | 0.06 (>0.05) | unadjusted | Y
Normotensive | 0.16 (<0.01) | 0.31 (<0.01) | 0.31 (<0.01) | 0.29 (<0.01) | −0.01 (>0.05) | 0.16 (<0.01) | 0.19 (<0.01) | 0.14 (<0.01) | unadjusted | Y
Hypertensive | 0.25 (<0.01) | 0.39 (<0.01) | 0.38 (<0.01) | 0.37 (<0.01) | 0.04 (>0.05) | 0.25 (<0.01) | 0.26 (<0.01) | 0.22 (<0.01) | unadjusted | Y
Cuspidi, 2000 | 0.13 (>0.05) | 0.35 (<0.01) | 0.30 (<0.01) | 0.32 (<0.01) | 0.11 (>0.05) | 0.38 (<0.01) | 0.36 (<0.01) | 0.34 (<0.01) | unadjusted | N
Devereux, 1983 | 0.24 (<0.05) | 0.38 (<0.001) | | 0.10 (>0.05) | 0.20 (<0.05) | 0.31 (<0.01) | | 0.24 (<0.05) | unadjusted | N
Gosse, 1993 | 0.18 (<0.01) | | 0.30 (<0.001) | | 0.2 (<0.01) | | 0.18 (<0.01) | | unadjusted | Y
Gosse, 1997 | 0.24 (<0.01) | 0.39 (<0.001) | | | 0.18 (<0.05) | 0.26 (<0.001) | | | age | Y
Jula, 1999 | 0.4 (<0.001) | 0.44 (<0.001) | 0.46 (<0.001) | 0.35 (<0.001) | 0.37 (<0.001) | 0.37 (<0.001) | 0.37 (<0.001) | 0.32 (<0.001) | unadjusted | Y
Lemne, 1995
Normotesive | 0.03 (>0.05) | 0.28 (<0.05) | 0.22 (>0.05) | | 0.14 (>0.05) | 0.21 (>0.05) | 0.15 (>0.05) | | unadjusted | N
Borderline hypertensive | 0.23 (>0.05) | 0.49 (<0.001) | 0.52 (<0.001) | | 0.02 (>0.05) | 0.16 (>0.05) | 0.16 (>0.05) | | unadjusted | N
Martinez, 1999
Men | 0.26 | 0.18 (>0.05) | 0.13 (>0.05) | 0.11 (>0.05) | 0.02 (>0.05) | 0.14 (>0.05) | 0.09 (>0.05) | 0.09 (>0.05) | unadjusted | N
Women | 0.17 (>0.05) | 0.43 (<0.01) | 0.38 (<0.01) | 0.37 (<0.01) | 0.06 (>0.05) | 0.34 (<0.01) | 0.24 (<0.01) | 0.37 (<0.01) | unadjusted | N
Myers, 1995b | 0.23 (<0.01) | | 0.24 (<0.01) | | 0.02 (>0.05) | | 0.09 (>0.05) | | unadjusted | N
Redon, 1996 | 0.24 (<0.05) | 0.41 (<0.05) | | | 0.19 (>0.05) | 0.3 (<0.05) | | | unadjusted | Y
Schulte, 1993 | 0.52 (<0.001) | 0.55 (<0.001) | 0.56 (<0.001) | 0.5 (<0.001) | 0.46 (<0.001) | 0.51 (<0.001) | 0.52 (<0.001) | 0.43 (<0.001) | unadjusted | N
Normotensive | 0.28 (>0.05) | 0.33 (<0.05) | 0.37 (<0.05) | 0.21 (>0.05) | 0.3 (>0.05) | 0.29 (>0.05) | 0.2 (>0.05) | 0.19 (>0.05) | unadjusted | N
Hypertensive | 0.37 (<0.01) | 0.48 (<0.001) | 0.45 (<0.001) | 0.44 (<0.001) | 0.21 (>0.05) | 0.35 (<0.001) | 0.41 (<0.001) | 0.38 (<0.001) | unadjusted | N
Verdecchia, 1990 | 0.38 (<0.01) | 0.48 (<0.01) | 0.4 (<0.01) | 0.47 (<0.01) | 0.29 (<0.01) | 0.36 (<0.01) | 0.28 (<0.01) | 0.37 (<0.01) | unadjusted | Y
Normotensive | 0.36 (<0.01) | 0.33 (<0.01) | 0.31 (<0.01) | 0.29 (<0.01) | 0.02 (<0.01) | 0.15 (<0.01) | 0.16 (<0.01) | 0.17 (<0.01) | unadjusted | Y
Hypertensive | 0.33 (<0.01) | 0.51 (<0.01) | 0.38 (<0.01) | 0.51 (<0.01) | 0.27 (<0.01) | 0.34 (<0.01) | 0.2 (<0.01) | 0.35 (<0.01) | unadjusted | Y
Zakopoulos, 1999 | 0.33 (<0.001) | 0.35 (<0.001) | | | 0.19 (<0.01) | 0.32 (<0.001) | | | unadjusted | Y

Evidence Table 39: Correlation of left ventricular mass with ambulatory blood pressure defined white coat hypertension (question #3)

Study | Cut-off values for HTN | | Distribution of BP (%) | | | LV mass | | | | Comparison (P-value) | | Adjustment factors | Multivariate Model
Study | Clinic | ABPM | NT | WCH | SH | Units | Mean (SD) | | | WCH vs NT | SH vs WCH | Adjustment factors | Multivariate Model
Study | Clinic | ABPM | NT | WCH | SH | Units | NT | WCH | SH | WCH vs NT | SH vs WCH | Adjustment factors | Multivariate Model
Ferrara, 1997 | SBP > 140 DBP > 90 | SBP > 130 DBP > 85 | 29.6 | 18.5 | 51.9 | g/m^2.7^ | 41.5 (10) | 41.5 (11) | 44.5 (10) | 0 | 3 | unadjusted | N
Hoegholm, 1999 | DBP > 91 | SBP > 135 DBP > 90 | | 13.4 | | g/m^2^ | 98.2 (29.1) | 89.7 (18.9) | 107.5 (28.5) | −8.5 | 17.8 | unadjusted | N
Manning, 1999 | SBP > 140 DBP > 90 | SBP > 137 DBP > 87 | | 22.6 | 77.4 | g/m^2^ | | 102 (23) | 125 (33) | | 23 (<0.001) | unadjusted | N
Martinez, 1999 | SBP > 140 DBP > 90 | SBP > 135 DBP > 85 | | 39.4 | 60.6 | g/m^2^ | | | | NA | 7.6 | age, gender, BMI, duration of HTN | Y
Men | | | | 30.1 | 69.9 | g/m^2^ | | 122.3 (27.7) | 124.8 (26.6) | NA | 2.5 | unadjusted | N
Women | | | | 47.4 | 52.6 | g/m^2^ | | 98.9 (18.9) | 108.2 (18.8) | NA | 9.3 | unadjusted | N
Myers, 1995b | | | | 61.9 | 38.1 | g/m^2^ | | 112 | 108 | NA | −4 (>0.05) | unadjusted | N
Palatini, 1998 | SBP > 140 DBP > 90 | SBP > 135 DBP > 85 | 11.6 | 31.8 | 56.5 | g/m^2^ | 82.1 (1.85) | 89.1 (16.1) | 93.8 (17.2) | 7 (<0.001) | 4.7 (<0.001) | BMI | Y
Pierdomenico, 1995 | SBP > 140 DBP > 90 | SBP > 135 DBP > 85 | 25 | 25 | 50 | g/m^2^ | 93.9 (11) | 97.6 (11.5) | 125.9 (20) | 3.7 | 28.3 (<0.05) | unadjusted | N
Pose-Reino, 1996 | SBP > 140 DBP > 90 | SBP > 135 DBP > 85 | 50 | 26.5 | 23.5 | g/m^2^ | 106 (25) | 132 (46) | 142 (45) | 26 | 10 | unadjusted | Y
Verdecchia, 1995 | SBP > 140 DBP > 90 | | 11.8 | 16.7 | 71.5 | g/m^2^ | 87 (17) | 93 (23) | 112 (31) | 6 | 19 | unadjusted | N
Weber, 1994 | DBP > 90 | DBP > 85 | | 22.4 | | g/m^2^ | 122 | 126.5 | 130 | 4.5 | 8 | unadjusted | N

Evidence Table 40: Characteristics of albuminuria measurement (question #3)

Study | Measurement | Collection Period | Mean (SD) | Micro-albuminuria
Study | Measurement | Collection Period | Mean (SD) | Criteria ^a^ | Prevalence (%)
Bauduceau, 1998 | mg/24hrs | 24 hours | unknown | 30 | 43.3
Hansen, 1992 | mg/24hrs | can't tell | 40.9 (1.9) | 28.8 | 50
Hoegholm, 1994 | mg/mg creatinine | spot | unknown | 0.5 | unknown
Jula, 1999 | mg/24hrs | 24 hours | 25.7 (39.3) | NA | unknown
Martinez, 1999 | mg/24hrs | 8 hours for 3 days | 9.5 | 28.8 | unknown
Martinez, 2001 | mg/24hrs | 8 hours for 3 days | unknown | 28.8 | 7.2
Palatini, 1998 | log (mg/24hrs) | 24 hours | unknown | 30 | unknown
Pierdomenico, 1995 | mg/24hrs | 24 hours | unknown | 30 | unknown
Redon, 1996 | mg/24hrs | 24 hours for 2 days | 25.1 (38.6) | 30 | 24.4
Redon, 1994 | mg/24hrs | 24 hours for 2 days | 30.1 (52.3) | 30 | 28

a criteria same for females and males in each study

Evidence Table 41: Correlations of clinic and ambulatory blood pressure with albuminuria (question #3)

Study | Correlations with Systolic BP (P-value) | | | | Correlations with Diastolic BP (P-value) | | | | Adjustment factors | Multivariate Model
Study | Clinic | 24 hr | Daytime | Nighttime | Clinic | 24 hr | Daytime | Nighttime | Adjustment factors | Multivariate Model
Hansen, 1992 | 0.21 (0.09) | | 0.45 (<0.001) | 0.53 (<0.001) | | | | | unadjusted | Y
Hoegholm, 1994 | | | | | | | | | | Y
Normotensives | 0.23 (<0.01) | | 0.2 | 0.19 (>0.05) | 0.26 (<0.01) | | 0.15 | 0.22 (<0.01) | unadjusted
Hypertensives | 0.11 | | 0.21 (<0.001) | 0.28 (<0.001) | −0.05 | | 0.09 (>0.05) | 0.19 (<0.01) | unadjusted
Jula, 1999 | 0.34 (<0.001) | 0.32 (<0.001) | 0.33 (<0.001) | 0.25 (<0.001) | 0.25 (<0.001) | 0.23 (<0.001) | 0.24 (<0.001) | 0.16 (<0.05) | unadjusted | N
Martinez, 2001 | 0.09 (>0.05) | 0.22 (<0.01) | 0.15 (<0.05) | 0.33 (<0.01) | 0.05 (>0.05) | 0.2 (<0.01) | 0.2 (<0.01) | 0.27 (<0.01) | unadjusted | Y
Redon, 1994 | 0.1 (>0.05) | 0.34 (>0.05) | | | 0.16 (>0.05) | 0.34 (>0.05) | | | unadjusted | Y
Redon, 1996 | 0.31 (<0.05) | 0.37 (<0.05) | | | 0.31 (<0.05) | 0.38 (<0.05) | | | unadjusted | N

Evidence Table 42: Correlation of ambulatory blood pressure defined white coat hypertension with albuminuria (question #3)

Study | Cut-off values for HT | | Distribution of hypertension (%) | | | Units | Mean albuminuria (SD) | | | Comparison (P-value) | | Adjustment factors | Multivariate Model
Study | Clinic | ABP | NT | WCH | SH | Units | NT | WCH | SH | WCH vs NT | SH vs WCH | Adjustment factors | Multivariate Model
Bauduceau, 1998 | DBP > 90 | SBP > 139 DBP> 87 | | 73.7 | 26.3 | mg/24hrs | | 22 | 44 | | 22 (<0.01) | unadjusted | Y
Hoegholm, 1994 | DBP > 90 | DBP > 90 | | 27 | 42 | mg/24hrs creatinine | 20.9 (69.4) | 22 (38.6) | 51.2 (177) | | | unadjusted
Hoegholm, 1999 | DBP > 91 | SBP > 135 DBP > 90 | | 13.4 | 60.7 | log (mg/24hrs creatinine) | −0.161 (0.357) | −0.067 (0.386) | 0.104 (0.466) | (<0.05) | (<0.05) | unadjusted | Y
Martinez, 1999 | SBP > 140 DBP > 90 | SBP > 135 DBP > 85 | | 39.4 | 60.6 | mg/24hrs | | 7.1 | 11.8 | | 4.7 | unadjusted | N
Martinez, 2001 | SBP > 140 DBP > 90 | | | 32.2 | 67.7 | mg/24hrs | | 7.2 (2.9) | 9.6 (2.9) | | 2.4 (<0.05) | unadjusted | Y
Palatini, 1998 | SBP > 140 DBP > 90 | SBP > 135 DBP > 85 | 11.6 | 31.8 | 56.5 | log (mg/24hrs) | | 0.67 (0.48) | 0.76 (0.43) | | | BMI | N
Pierdomenico, 1995 | SBP > 140 DBP > 90 | SBP > 135 DBP > 85 | 25 | 25 | 50 | mg/24hrs | 4.31 (1.1) | 4.45 (1.48) | 15.1 (13.8) | 0.2 (>0.05) | 10.6 (<0.001) | unadjusted | N

Evidence Table 43: Summary of quality characteristics for prospective studies addressing question #3 (question #3b)

Study | Centers | Funding | Adequate description | | Clinic BP Observer | | | Ambulatory BP Trained | Blinded Outcome Assessment | Followup data for 80% | Statistical Variability Reported
Study | Centers | Funding | Eligibility | Baseline Characteristics | Trained | Blinded | Standard Technique | Ambulatory BP Trained | Blinded Outcome Assessment | Followup data for 80% | Statistical Variability Reported
Amar, 2000 | single | can't tell | Y | Y | can't tell | N | Y | Y | N | Y | Y
Fagard, 2000 | multi | govt, industry | N | Y | can't tell | Y | can't tell | can't tell | Y | Y | Y
Gosse, 1997 | single | can't tell | Y | Y | can't tell | N | can't tell | can't tell | N | Y | Y
Nakano, 1999 | single | other | N | Y | can't tell | N | can't tell | can't tell | N | N | Y
Ohkubo, 1997a | single | govt, other | Y | Y | can't tell | N | can't tell | can't tell | Y | Y | Y
Ohkubo, 1997b | single | govt, other | Y | Y | can't tell | N | Y | can't tell | Y | Y | Y
Ohkubo, 2000 | single | govt, other | Y | Y | can't tell | N | Y | can't tell | Y | Y | Y
Perloff, 1989 | single | govt, other | N | Y | can't tell | N | Y | can't tell | N | Y | Y
Redon, 1998 | single | can't tell | Y | Y | can't tell | Y | Y | can't tell | N | Y | Y
Staessen, 1999 | multi | govt, industry, other | Y | Y | can't tell | N | can't tell | can't tell | Y | Y | Y
Suzuki, 2000 | single | can't tell | Y | Y | Y | N | can't tell | can't tell | N | Y | Y
Verdecchia, 1994 | single | can't tell | Y | Y | can't tell | Y | Y | can't tell | Y | Y | Y
Verdecchia, 1998 | single | can't tell | Y | Y | can't tell | N | Y | can't tell | Y | Y | Y
Zweiker, 1994 | single | can't tell | N | Y | can't tell | N | can't tell | Y | N | Y | Y

Evidence Table 44: Summary of population characteristics for prospective studies of ambulatory blood pressure measurement (question #3b)

Study | N | Setting | Target Population | Exclusions | Male (%) | Black (%) | Mean Age, years (SD) | HTN (%) | On BP medication (%)
Amar, 2000 | 57 | other specialty clinic | anti-hypertensive medication;dialysis | orthstatic hypotension; autonomic dysfunction | 52.6 | | 56.8 | 100 | 100
Fagard, 2000 | 695 | Syst-Eur Trial | age >59 ; hypertensives; isolated systolic hypertension | can't tell | 37.6 | | 70 | 100
Gosse, 1997 | 134 | other specialty clinic other research study | age >45 ; hypertensives | diabetes; active CHD/CVD | 56.7 | | 61(11) | 100 | 0
Nakano, 1999 | 257 | Hospital | Type II diabetes | | 63 | | | 51 | 0
Ohkubo, 1997a | 1542 | general population | age >39 | demented; bedridden; hospitalized | 36.6 | | 61.5 | | 30.7
Ohkubo, 1997b | 1542 | general population | age >40 | demented; bedridden; hospitalized | 36.6 | | 61.5 | | 30.7
Ohkubo, 2000 | 1476 | general population | age >40 | demented; bedridden, hospitalized; prior stroke | 40 | | 61 | | 27.4
Perloff, 1989 | 761 | hypertension clinic | no specific population | dialysis; renal transplant | 47.6 | | 43.1 | | 0
Redon, 1998 | 86 | hypertension clinic | hypertensives; poorly controlled HTN on > 3 meds | diabetes; chronic renal insufficiency; secondary hypertension | 29.1 | | 53.3 | 100 | 100
Staessen, 1999 | 265 | Syst-Eur Trial | age >60; hypertensives | chronic renal insufficiency | 38.5 | | 69.6 (6.2) | 100 | 0
Suzuki, 2000 | 134 | general population | elderly | autonomic dysfunction; physical disability | 50 | | 78.5 (7) | 100 | 100
Verdecchia, 1994 | 1392 | general clinic | hypertensives; normotensives | heart failure; valvular; heart disease | 50.3 | 51.3 | | 85.3
Male | 479 | | | | 100 | | 51.72
Female | 480 | | | | 0 | | 54.15
Verdecchia, 1998 | 2010 | general clinic | hypertensives | anti-hypertensive medication; secondary cause of hypertension | 52 | 0 | 52 (12) | 100 | 0
Zweiker, 1994 | 116 | general clinic | hypertensives | can't tell | 42.2 | | 59 (13)

Evidence Table 45: Summary of methods for prospective studies of ambulatory blood pressure measurement (question #3b)

Study | Follow-up-Years mean (SD) | N | Outcomes | | | Analyses Adjusted for | Comparison of Prediction
Study | Follow-up-Years mean (SD) | N | n | Outcome | Description | Analyses Adjusted for | Comparison of Prediction
Amar, 2000 | 2.9 (1.7) | 57 | 10 | CVD Mortality | Ischemic heart disease, Stroke, Aortoiliac disease, Congestive heart failure, Sudden death | Age, Gender, Prior CVD | Not Tested
Fagard, ^a^ 2000 | | 695 | 79 | CVD Morbidity and Mortality | Sudden death, Stroke, MI, Heart failure | Gender, Prior CVD | Not Tested
| | | 29 | Stroke | Neurologic deficit lasting >24 hours or causing death
Gosse, 1997 | 2.5 (0.7) | 134 | 14 | CVD Morbidity and Mortality | Stroke, MI, Angina, Heart failure, Renal failure, Lower limb arterial disease | | ABP better than Clinic BP, by discriminant function analyses
Nakano, 1999 | 4.2 | 257 | 22 | Dialysis | Incident hemodialysis | Age, Gender, Smoking, Blood pressure, Glycemic control, Duration of diabetes, Serum protein, Serum creatinine. | ABP better than Clinic BP, by stepwise regression analyses
Ohkubo, ^b^ 1997a | 5.1 (2) | 1542 | 93 | Total Mortality | Total mortality | Age, Gender, Smoking, Anti hypertensive medications, Prior CVD | Not tested
| | | 37 | CVD Mortality | CVD Mortality
Ohkubo, ^b^ 1997b | 5.1 (2) | 1542 | 93 | Total Mortality | Total mortality | Age, Gender, Smoking, Anti hypertensive medications, Prior CVD | ABP better than Clinic BP, by stepwise regression analyses
| | | 37 | CVD Mortality | CVD Mortality
Ohkubo, ^b^ 2000 | 6.4 (2) | 1476 | 74 | Stroke | Stroke or TIA | Age, Gender, Smoking, Cholesterol, Hematocrit, Prior CVD, Diabetes, BP medication | ABP better than Clinic BP, by stepwise regression analyses
Perloff, 1989 | 5.5 (3.5) | 761 | 120 | CVD Morbidity and Mortality | Cardiac, Cerebral and peripheral vascular diseases, Aortic dissection, Retinal vascular changes, Renal function decline, Heart failure | Age, Gender, LVH, BP medication, Optic fundus. | Incremental Gain of ABP over clinic BP, by residual model
Redon, 1998 | 4 | 86 | 21 | CVD Morbidity and Mortality | MI, Angina, Coronary Revascularization, Stroke, TIA, Sudden death, Aortoiliac occlusive disease, Heart failure, Hypertensive emergencies | Prior CVD | ABP better than Clinic BP, by stepwise regression analyses
Staessen, ^a^ 1999 | 4.4 [median] | 265 | 39 | Total Mortality | Total mortality | Age, Gender, Smoking, Prior CVD | Incremental Gain of ABP over clinic BP, by regression analyses with both variables entered in models
| | | 22 | CVD Mortality | CVD mortality
| | | 54 | CVD Morbidity and Mortality | Fatal and Non fatal heart failure, MI, Sudden death, Stroke
| | | 20 | Stroke | Fatal and non fatal stroke
| | | 35 | Cardiac Morbidity and Mortality | Fatal and non fatal heart failure, MI
Suzuki, 2000 | 4.3 (1.8) | 134 | 34 | CVD Morbidity and Mortality | MI, Angina, Cerebral infarction, Cerebral hemorrhage, TIA, Sudden death, Heart failure, Renal failure | Age, Gender, Smoking, Diabetes, LVH, Prior CVD | ABP better than Clinic BP, by stepwise regression analyses
Verdecchia, ^c^ 1994 | 3.2 | 1392 | 89 | CVD Morbidity and Mortality | MI, Stroke, Sudden death, Heart failure, Stroke, TIA, Coronary revascularization, Angina, Ischemic changes on ECG, Aortoiliac occlusive disease, Retinal artery occlusion, Renal failure | Age, Diabetes, Prior CVD, Pulse Pressure, Clinic DBP, Smoking, Cholesterol, BMI, LVH | Not tested
Verdecchia, ^c^ 1998 | 3.8 (2.4) | 2010 | 36 | CVD Morbidity and Mortality | New onset coronary artery disease, Stroke, TIA, Aortoiliac occlusive disease, Retinal artery occlusion, Heart failure, Renal failure | Age, Gender, Smoking, BMI, Smoking, Cholesterol, BP medications, LVH | ABP better than Clinic BP, by stepwise regression analyses
Zweiker, 1994 | 2.6 | 116 | 4 | Total Mortality | Total mortality | | Not tested
| | | 5 | CVD Morbidity and Mortality | MI, Apoplexy, TIA

a One of two papers from Syst-Eur trial

b One of three papers from Ohasama study

c One of the two papers from PIUMA study

Evidence Table 46: Prediction of outcome by clinic blood pressure and systolic ambulatory blood pressure (question #3b)

Study | Outcome | Contrast | Clinic | | Day Time | | Night Time | | 24 Hour
Study | Outcome | Contrast | Estimate (RR) | P-value | Estimate (RR) | P-value | Estimate (RR) | P-value | Estimate (RR) | P-value
Amar, 2000 | CVD Mortality | Per 10 mmHg | 0.99 | 0.94 | 1.38 | 0.08 | 1.41 | 0.01 | 1.37 | 0.09
Goose, 1997 | CVD Morbidity and Mortality | Per mmHg | | | | | | | 1.03 ^d^ | 0.02
Ohkubo, ^b^ 1997b | Total Mortality | 2^nd^ VS 1^st^ Quintile | 0.95 ^e^ | NS | 0.7 ^e^ | NS | 1.1 ^e^ | NS | 0.59 ^e^ | NS
| | 3^rd^ VS 1^st^ Quintile | 0.96 ^e^ | NS | 0.54 ^e^ | NS | 0.43 ^e^ | NS | 0.49 ^e^ | NS
| | 4^th^ VS 1^st^ Quintile | 0.55 ^e^ | NS | 0.75 ^e^ | NS | 0.66 ^e^ | NS | 0.5 ^e^ | NS
| | 5^th^ VS 1^st^ Quintile | 1.23 ^e^ | NS | 1.08 ^e^ | NS | 1.37 ^e^ | NS | 1.15 ^e^ | NS
Ohkubo, ^b^ 1997b | CVD Mortality | 2^nd^ VS 1^st^ Quintile | 1.09 ^e^ | NS | 0.14 ^e^ | NS | 1.35 ^e^ | NS | 0.34 ^e^ | NS
| | 3^rd^ VS 1^st^ Quintile | 1.63 ^e^ | NS | 0.64 ^e^ | NS | 1.62 ^e^ | NS | 0.39 ^e^ | NS
| | 4^th^ VS 1^st^ Quintile | 0.78 ^e^ | NS | 1.08 ^e^ | NS | 1.68 ^e^ | NS | 0.59 ^e^ | NS
| | 5^th^ VS 1^st^ Quintile | 1.77 ^e^ | NS | 1.26 ^e^ | NS | 4 ^e^ | NS | 1.58 ^e^ | NS
Ohkubo, ^b^ 2000 | Stroke | Per 10 mmHg | 1.02 - 1.06 | NS | 1.41 | 0.0001 | 1.34 | 0.0007 | 1.47 | 0.0001
Perloff, 1998 | CVD Morbidity and Mortality | 140-159 VS <140 mmHg | 2.17^d,e^ | 0.047 | 2.47^d,e^ | <0.001
| | 160-179 VS <140 mmHg | 3.32^d,e^ | 0.001 | 4.37^d,e^ | <0.001
| | >180 VS <140 mmHg | 7.13^d,e^ | <0.001 | 6.13^d,e^ | <0.001
Redon, 1998 | CVD Morbidity and Mortality | Middle VS Lowest Tertile | | | 3.69 | 0.098
| | Highest VS Lowest Tertile | | | 6.42 | 0.017
Staessen, ^a^ 1999 | Total Mortality | Per 10 mmHg | 1.21 | NS | 1.18 | NS | 1.24 | <0.05 | 1.23 | <0.05
| CVD Mortality | Per 10 mmHg | 1.29 | NS | 1.3 | <0.05 | 1.42 | <0.01 | 1.34 | <0.05
| CVD Morbidity and Mortality | Per 10 mmHg | 1.09 | NS | 1.19 | <0.05 | 1.31 | <0.001 | 1.26 | <0.01
| Stroke | Per 10 mmHg | 1.3 | NS | 1.51 | <0.01 | 1.3 | <0.05 | 1.47 | <0.01
| Cardiac Morbidity and Mortality | Per 10 mmHg | 1.05 | NS | 1.07 | NS | 1.27 | <0.05 | 1.14 | NS
Suzuki, 2000 | CVD Morbidity and Mortality | Per 10 mmHg | | NS | | NS | 1.34 | <0.01 | 1.28 | <0.05
Verdecchia, ^c^ 1998 | CVD Morbidity and Mortality | Per 10 mmHg | 1.12 | 0.004 | | | | | 1.23 | 0.005

a One of two papers from Syst-Eur trial

b One of three papers from Ohasama study

c One of the two papers from PIUMA study

d Unadjusted

e Calculated from data in paper

Evidence Table 47: Prediction of outcome by clinic blood pressure and diastolic ambulatory blood pressure (question #3b)

Study | Outcome | Contrast | Clinic | | Day Time | | Night Time | | 24 Hour
Study | Outcome | Contrast | Estimate (RR) | P-value | Estimate (RR) | P-value | Estimate (RR) | P-value | Estimate (RR) | P-value
Amar, 2000 | CVD Mortality | Per 10 mmHg | 0.49 | 0.03 | 1.04 | 0.89 | 1.4 | 0.19 | 0.93 | 0.84
Ohkubo, ^a^ 1997b | Total Mortality | 2^nd^ VS 1^st^ Quintile | 1.07 ^c^ | NS | 0.47 ^c^ | NS | 1.56 ^c^ | NS | 0.69 ^c^ | NS
| | 3^rd^ VS 1^st^ Quintile | 0.92 ^c^ | NS | 0.82 ^c^ | NS | 0.84 ^c^ | NS | 0.73 ^c^ | NS
| | 4^th^ VS 1^st^ Quintile | 0.87 ^c^ | NS | 0.73 ^c^ | NS | 0.68 ^c^ | NS | 0.7 ^c^ | NS
| | 5^th^ VS 1^st^ Quintile | 1.27 ^c^ | NS | 0.98 ^c^ | NS | 1.77 ^c^ | NS | 1.08 ^c^ | NS
Ohkubo, ^a^ 1997b | CVD Morbidity and Mortality | 2^nd^ VS 1^st^ Quintile | 1.34 ^c^ | NS | 0.35 ^c^ | NS | 1.29 ^c^ | NS | 0.63 ^c^ | NS
| | 3^rd^ VS 1^st^ Quintile | 1.87 ^c^ | NS | 1.45 ^c^ | NS | 1.05 ^c^ | NS | 1.3 ^c^ | NS
| | 4^th^ VS 1^st^ Quintile | 1.28 ^c^ | NS | 1.24 ^c^ | NS | 1.05 ^c^ | NS | 1.44 ^c^ | NS
| | 5^th^ VS 1^st^ Quintile | 2.21 ^c^ | NS | 1.61 ^c^ | NS | 3.95 ^c^ | NS | 2.13 ^c^ | NS
Ohkubo, ^a^ 2000 | Stroke | Per 5 mmHg | 1.05 - 1.09 | NS | 1.31 | 0.0004 | 1.24 | 0.0051
Perloff, 1998 | CVD Morbidity and Mortality | 90-99 VS <90 mmHg | 2.78^b,c^ | 0.009 | 1.24^b,c^ | 0.31
| | 100-109 VS <90 mmHg | 2.42^b,c^ | 0.031 | 1.45^b,c^ | 0.12
| | > 110 VS <90 mmHg | 5.61^b,c^ | <0.001 | 2.46^b,c^ | <0.001
Suzuki, 2000 | CVD Morbidity and Mortality | Per 10 mmHg | | NS | | NS | 1.67 | <0.01 | 1.71 | <0.01

a One of three papers from Ohasama study

b Unadjusted

c Calculated from data in paper

Evidence Table 48: Prediction of Outcome by pattern of ambulatory blood pressure (white coat hypertension and dipping status) (question #3b)

Study | Outcome | White Coat Hypertension (WCH) | | | | Non-Dipping
Study | Outcome | Definition | Contrast | Estimate (RR) | P-value | Contrast | Estimate (RR) | P-value
Amar, 2000 | CVD Mortality | | | | | Non Dippers VS Dippers | 4.61 | 0.06
Fagard ^a^ , 2000 | CVD Morbidity and Mortality | clinic SBP 160-219 mmHG daytime ABP < 140 mmHG | WCH VS Sustained HTN | 0.35^d,e^ | 0.002
| Stroke | clinic SBP 160-219 mmHG daytime ABP < 140 mmHG | WCH VS Sustained HTN | 0.23^d,e^ | 0.03
Nakano, 1999 | Dialysis | | | | | Reversed Pattern VS Dippers | 16.2 | <0.05
Ohkubo, ^b^ 1997a | Total Mortality | | | | | Extreme Dipper VS Dippers | 0.65 | 0.29
| | | | | | Non Dippers VS Dippers | 1.35 | 0.27
| | | | | | Inverse Dipper VS Dippers | 2.12 | 0.02
| CVD Mortality | | | | | Extreme Dipper VS Dippers | 0.96 | 0.95
| | | | | | Non Dippers VS Dippers | 2.56 | 0.02
| | | | | | Inverse Dipper VS Dippers | 3.69 | 0.004
Verdecchia, ^c^ 1994 | CVD Morbidity and Mortality | clinic BP > 140/90 mmHG daytime ABP <131/86 mmHG (women) daytime ABP < 136/87 (men) | Normotensive VS Sustained HTN | 0.17 ^e^ | | Non Dippers VS Dippers | 1.69 ^e^
| | clinic BP > 140/90 mmHG daytime ABP <131/86 mmHG (women) daytime ABP < 136/87 (men) | WCH VS Sustained HTN | 0.18 ^e^
| CVD Morbidity and Mortality (Men) | clinic BP > 140/90 mmHG daytime ABP <131/86 mmHG (women) daytime ABP < 136/87 (men) | | | | Non Dippers VS Dippers | 1.04 | 0.91
| CVD Morbidity and Mortality (Women) | clinic BP > 140/90 mmHG daytime ABP <131/86 mmHG (women) daytime ABP < 136/87 (men) | | | | Non Dippers VS Dippers | 6.79 | 0.0002
Verdecchia, ^c^ 1998 | CV Morbidity and Mortality | clinic BP > 140/90 mmHG daytime ABP <131/86 mmHG (women) daytime ABP < 136/87 (men) | WCH VS Sustained HTN | 0.3 | 0.007 | Non Dippers VS Dippers | 1.46 | 0.016
Zweiker, 1994 | CVD Morbidity and Mortality | | | | | Non Dippers VS Dippers | 12 ^d^ | 0.004
| Total Mortality | | | | | Non Dippers VS Dippers | 9 ^d^ | 0.02

a One of two papers from Syst-Eur trial

b One of three papers from Ohasama study

c One of the two papers from PIUMA study

d Unadjusted

e Calculated from data in paper

Evidence Table 49: Summary of quality characteristics in ambulatory blood pressure measurement trials (question #3d)

Study | Centers | Funding | Adequate Description | | | | | Ambulatory BP Trained | Outcome Assessors Blinded | Between Group P-value Reported
Study | Centers | Funding | Eligibility | Sample Size Justification | Randomization | BP Therapy | Outcomes | Ambulatory BP Trained | Outcome Assessors Blinded | Between Group P-value Reported
Schrader, 2000 | multi | can't tell | Y | N | Partial | Y | Y | N | N | Y
Staessen, 1997 | multi | industry | Y | N | Adequate | Y | Y | N | Y | Y

Evidence Table 50: Summary of population characteristics for ambulatory blood pressure measurement trials (question #3d)

Study | N | Setting | Target Population | Exclusions | Male (%) | Black (%) | Mean Age, years (SD) | HTN (%) | On BP medication (%)
Schrader, 2000 | 1298 | general clinic | age between 34 and 66; normotensives | pregnancy; patients in other study; contraindication to ACE inhibitor | 45.7 | | 54.3 | 0 | 0
Staessen, 1997 | 419 | general clinic | age >17; hypertensives | pregnancy; chronic renal insufficiency; active CHD/CVD; severe non-cardiac disease; alcohol or psychiatric disorder; hypertensive retinopathy | 46.1 | | 52.6 | 100 | 0

Evidence Table 51: Summary of methods in ambulatory blood pressure measurement trials (question #3d)

Study | Objective | Duration (months) | Group | N | BP Management Intervention
Schrader, 2000 | To determine whether BP guided by ABPM has a better prognosis and requires less medications then BP guided by clinic measurement. | 56.4 | Control | 647 | Clinic BP measured at 1, 3, 9, 12 months and then annually
Schrader, 2000 | To determine whether BP guided by ABPM has a better prognosis and requires less medications then BP guided by clinic measurement. | 56.4 | ABPM | 651 | Annual ABP measurement and if office BP > 140/90 [SpaceLabs 90207: Every 15 minutes (day) and every 30 min (night)]
Staessen, 1997 | To determine whether BP guided by ABPM would reduce medication use while controlling BP in comparison to BP guided by office measurements. | 6.1 | Control | 206 | BP measured at 1, 2, 4, and 6 months
Staessen, 1997 | To determine whether BP guided by ABPM would reduce medication use while controlling BP in comparison to BP guided by office measurements. | 6.1 | ABPM | 213 | ABP measured at 1, 2, 4, and 6 months [SpaceLabs 90207: Every 15 minutes (day) and every 30 min (night)]

Evidence Table 52: Characteristics of outcome measurements in ambulatory blood pressure measurement trials (question #3d)

Study | Measure | Device | Position | Measurements (Number)
Study | Measure | Device | Position | Per Day | Days | Total
Schrader, 2000 | clinic | can't tell | sitting | 3 | 2 | 6
Staessen, 1997 | clinic | can't tell | sitting | 3 | 1 | 3
| ambulatory | SpaceLabs 90207 | NA | NA | 1 | NA

Evidence Table 53: Effect of ambulatory blood pressure measurement interventions on clinic blood pressure (question #3d)

Study | Group | Systolic Blood Pressure (mmHg) | | | Diastolic Blood Pressure (mmHg) | | | Other Findings and Comments
Study | Group | Baseline Mean (SD) | Change from Baseline in intervention group, net of control | | Baseline Mean (SD) | Change from Baseline in intervention group, net of control | | Other Findings and Comments
Study | Group | Baseline Mean (SD) | Change | P-value | Baseline Mean (SD) | Change | P-value | Other Findings and Comments
Schrader, 2000 | Control | 167.6 (16.9) | | | 99.5 (10) | | | White coat hypertensives excluded after randomization and replaced with other participants in the ABP group but not in the control group. Fewer CVD events and deaths in ABP vs control BP groups (20 vs 35, P=0.04). Similar rates of hypertension control in ABP and control (59.7% VS 53.4%). Similar use of medications in ABP and control group (31.3% vs 31.7%).
Schrader, 2000 | ABP | 165.9 (17.3) | 1 | NS | 100 (10.1) | 0 | NS
Staessen, 1997 | Control | 164.4 (20.3) | | | 104 (9.4) | | | More ABP patients off of medications (26.3% vs 7.3%, P= <0.001). Fewer ABP patients needed multiple medications (27.2% vs 42.7%, P=<0.001). Change in left ventricular mass was similar in ABP and control group (−2 gm vs −6gm, p=0.56) Total costs (monitoring, medications, and physician fee) were similar in both groups.
Staessen, 1997 | ABP | 164.9 (20.3) | 3.3 | 0.06 | 102.9 (8.9) | 1.4 | 0.16

Evidence Table 54: Effect of ambulatory blood pressure measurement interventions on 24 Hour, daytime and nighttime ambulatory blood pressure (question #3d)

Study | Group | Systolic Blood Pressure (mmHg) | | | Diastolic Blood Pressure (mmHg)
Study | Group | Baseline Mean (SD) | Change from Baseline in intervention group, net of control | | Baseline Mean (SD) | Change from Baseline in intervention group, net of control
Study | Group | Baseline Mean (SD) | Change | P-value | Baseline Mean (SD) | Change | P-value
24 Hour ABP
Staessen, 1997 | Control | 143.9 (16.3) | | | 89.7 (11.1)
Staessen, 1997 | ABP | 142.5 (15.5) | 2.8 | 0.02 | 88.5 (10.4) | 1.6 | 0.03
Daytime ABP
Staessen, 1997 | Control | 150.7 (16.4) | | | 95.6 (11.5)
Staessen, 1997 | ABP | 148.9 (15.9) | 2.6 | 0.04 | 93.8 (11.1) | 1.5 | 0.06
Nighttime ABP
Staessen, 1997 | Control | 131.4 (18.5) | | | 79.1 (12.5)
Staessen, 1997 | ABP | 129.9 (17.1) | 3.5 | 0.01 | 78.5 (11.8) | 1.9 | 0.03