# References

1 Littenberg B, Moses L E. Estimating diagnostic accuracy from multiple conflicting reports: a new meta-analytic method. Med Decis Making. Oct-Dec. 1993;13(4):313-21. [pmid: 8246704].
2 Gupta S K, Benstead T J. Symptoms experienced by patients with carpal tunnel syndrome. Can J Neurol Sci. Nov. 1997;24(4):338-42. [pmid: 9398982].
3 Kopell H P, Goodgold J. Clinical and electrodiagnostic features of carpal tunnel syndrome. Arch Phys Med Rehabil. Jul. 1968;49(7):371-5. [pmid: 5658882].
4 United States Department of Labor. Lost-worktime injuries and illnesses: characteristics and resulting time away from work, 1996. [press release online]. Washington (DC): United States Deparment of Labor, Bureau of Labor Statistics; 1998 Apr 23 [cited 1999 Jan 12]. [19 p]. Available:http://stats.bls.gov/oshhome.htm.
5 Brown B A. Internal neurolysis in traumatic peripheral nerve lesions in continuity. Surg Clin North Am. Oct. 1972;52(5):1167-75. [pmid: 5076098].
6 Cullum D E, Molloy C J. Occupation and the carpal tunnel syndrome [published erratum appears in Med J Aust 1994 Dec 5–19;161(11–12):727]. Med J Aust. Nov 7. 1994;161(9):552-4. [pmid: 7968759].
7 Kerwin G, Williams C S, Seiler J G 3d. The pathophysiology of carpal tunnel syndrome. Hand Clin. May. 1996;12(2):243-51. [pmid: 8724576].
8 Graham R A. Carpal tunnel syndrome. A statistical analysis of 214 cases. Orthopedics. 1983;6(10):1283-7.
9 American Society of Plastic and Reconstructive Surgeons (ASPRS). Frequently asked questions: carpal tunnel. [online]. Arlington Heights (IL): American Society of Plastic and Reconstructive Surgeons (ASPRS); [cited 1998 Dec 31]. [2 p]. Available: http://www.plasticsurgery.org/faq/carpal.htm.
10 Kameyama S, Tanaka R, Hasegawa A, Tamura T, Kuroki M. Subclinical carpal tunnel syndrome in acromegaly. Neurol Med Chir (Tokyo). Aug. 1993;33(8):547-51. [pmcid: 358319]. [pmid: 7692327].
11 Demir H, Kirnap M, Utas C, Ersoy A O, Ozugul Y, Aksu M. Carpal tunnel syndrome in hemodialysis patients. Eur J Phys Med Rehabil. 1998;8(6):186-8.
12 Chen C K, Chung C B, Yeh L, Pan H B, Yang C F, Lai P H, Liang H L, Resnick D. Carpal tunnel syndrome caused by tophaceous gout: CT and MR imaging features in 20 patients. AJR Am J Roentgenol. Sep. 2000;175(3):655-9. [pmid: 10954446].
13 Upton A R, McComas A J. The double crush in nerve entrapment syndromes. Lancet. Aug 18. 1973;2(7825):359-62. [pmid: 4124532].
14 Wilbourn A J, Gilliatt R W. Double-crush syndrome: a critical analysis. Neurology. Jul. 1997;49(1):21-9. [pmid: 9222165].
15 Misiunas A, Niepomniszcze H, Ravera B, Faraj G, Faure E. Peripheral neuropathy in subclinical hypothyroidism. Thyroid. Aug. 1995;5(4):283-6. [pmid: 7488869].
16 Perkins AT, Morgenlander JC. Endocrinologic causes of peripheral neuropathy. Pins and needles in a stocking-and-glove pattern and other symptoms. Postgrad Med 1997 Sep;102(3):81–2, 90–2, 102–6.
17 Kraft G H. Carpal tunnel syndrome in patients with peripheral neuropathy: it can be evaluated and treated. Phys Med Rehabil Clin N Am. 1997;8(3):577-596.
18 Vogt T, Mika A, Thomke F, Hopf H C. Evaluation of carpal tunnel syndrome in patients with polyneuropathy. Muscle Nerve. Feb. 1997;20(2):153-7. [pmid: 9040652].
19 Radecki P. Carpal tunnel syndrome: effects of personal factors and associated medical conditions. Phys Med Rehabil Clin N Am. 1997;8(3):419-437.
20 Palmer D H, Hanrahan L P. Social and economic costs of carpal tunnel surgery. Instr Course Lect. 1995;44:167-72. [pmid: 7797856].
21 Dekel S, Papaioannou T, Rushworth G, Coates R. Idiopathic carpal tunnel syndrome caused by carpal stenosis. Br Med J. May 31. 1980;280(6227):1297-9. [pmid: 7388516]. [pmcid: 1601593].
22 American Society of Plastic and Reconstructive Surgeons (ASPRS). Clinical practice guidelines for plastic and maxillofacial surgery services. Arlington Heights (IL): American Society of Plastic and Reconstructive Surgeons (ASPRS); 1993. 43 p. (Clinical Practice Guidelines).
23 Hanrahan L P, Higgins D, Anderson H, Smith M. Wisconsin occupational carpal tunnel syndrome surveillance: the incidence of surgically treated cases. Wis Med J. Dec. 1993;92(12):685-9. [pmid: 8109131].
24 Stevens J C, Sun S, Beard C M, O'Fallon W M, Kurland L T. Carpal tunnel syndrome in Rochester, Minnesota, 1961 to 1980. Neurology. Jan. 1988;38(1):134-8. [pmid: 3336444].
25 Moore KL. Satterfield TS, editor. Clinically oriented anatomy. 3rd ed. Baltimore (MD): Williams & Wilkins; 1992. The upper limb. p. 501–635.
26 Tanaka S, Wild D K, Seligman P J, Behrens V, Cameron L, Putz-Anderson V. The U.S. prevalence of self-reported carpal tunnel syndrome: 1988 National Health Interview Survey data. Am J Public Health. Nov. 1994;84(11):1846-8. [pmid: 7977933]. [pmcid: 1615207].
27 Rempel D, Evanoff B, Amadio P C, de Krom M, Franklin G, Franzblau A, Gray R, Gerr F, Hagberg M, Hales T, Katz J N, Pransky G. Consensus criteria for the classification of carpal tunnel syndrome in epidemiologic studies. Am J Public Health. Oct. 1998;88(10):1447-51. [pmid: 9772842]. [pmcid: 1508472].
28 Glass I, Ring H. Median nerve conduction tests and Phalen's sign in carpal tunnel syndrome. Electromyogr Clin Neurophysiol. Mar. 1995;35(2):107-12. [pmid: 7781571].
29 Gelmers H J. The significance of Tinel's sign in the diagnosis of carpal tunnel syndrome. Acta Neurochir (Wien). 1979;49(34):255-8. [pmcid: 300905]. [pmid: 532731].
30 Szabo R M, Gelberman R H, Dimick M P. Sensibility testing in patients with carpal tunnel syndrome. J Bone Joint Surg Am. Jan. 1984;66(1):60-4. [pmid: 6690444].
31 Gerr F, Letz R. The sensitivity and specificity of tests for carpal tunnel syndrome vary with the comparison subjects. J Hand Surg [Br]. Apr. 1998;23(2):151-5.
32 Rozmaryn L M, Dovelle S, Rothman E R, Gorman K, Olvey K M, Bartko J J. Nerve and tendon gliding exercises and the conservative management of carpal tunnel syndrome. J Hand Ther. Jul-Sep. 1998;11(3):171-9. [pmid: 9730093].
33 Oztas O, Turan B, Bora I, Karakaya M K. Ultrasound therapy effect in carpal tunnel syndrome. Arch Phys Med Rehabil. Dec. 1998;79(12):1540-4. [pmid: 9862296].
34 Walker W C, Metzler M, Cifu D X, Swartz Z. Neutral wrist splinting in carpal tunnel syndrome: a comparison of night-only versus full-time wear instructions. Arch Phys Med Rehabil. Apr. 2000;81(4):424-9. [pmid: 10768530].
35 Chang M H, Chiang H T, Lee S S, Ger L P, Lo Y K. Oral drug of choice in carpal tunnel syndrome. Neurology. Aug. 1998;51(2):390-3. [pmid: 9710008].
36 Girlanda P, Dattola R, Venuto C, Mangiapane R, Nicolosi C, Messina C. Local steroid treatment in idiopathic carpal tunnel syndrome: short-and long-term efficacy. J Neurol. 1993;240(3):187-90. [pmid: 8482993].
37 Roquer J, Cano J F. Carpal tunnel syndrome and hyperthyroidism. A prospective study. Acta Neurol Scand. Aug. 1993;88(2):149-52. [pmid: 8213060].
38 Palumbo C F, Szabo R M, Olmsted S L. The effects of hypothyroidism and thyroid replacement on the development of carpal tunnel syndrome. J Hand Surg [Am]. Jul. 2000;25(4):734-9.
39 Boggins-Magill M K. Carpal tunnel release: scoping out the carpal tunnel. Todays OR Nurse. May-Jun. 1994;16(3):27-33. [pmid: 8009579].
40 Slattery P G. Endoscopic carpal tunnel release. Use of the modified Chow technique in 215 cases. Med J Aust. Feb 7. 1994;160(3):104-7. [pmid: 8295573].
41 Okutsu I, Hamanaka I, Tanabe T, Takatori Y, Ninomiya S. Complete endoscopic carpal canal decompression. Am J Orthop. May. 1996;25(5):365-8. [pmid: 8727087].
42 Chow J C. Endoscopic carpal tunnel release. Two-portal technique. Hand Clin. Nov. 1994;10(4):637-46. [pmid: 7868631].
43 ElZahaar M S. A simplified, modified endoscopic carpal tunnel release (El-Zahaar modification). J Neurol Orthop Med Surg. 1995;16(2):96-100.
44 Worseg A P, Kuzbari R, Korak K, Hocker K, Wiederer C, Tschabitscher M, Holle J. Endoscopic carpal tunnel release using a single-portal system. Br J Plast Surg. Jan. 1996;49(1):1-10. [pmid: 8705095].
45 Brown R A, Gelberman R H, Seiler J G 3d, Abrahamsson S O, Weiland A J, Urbaniak J R, Schoenfeld D A, Furcolo D. Carpal tunnel release. A prospective, randomized assessment of open and endoscopic methods. J Bone Joint Surg Am. Sep. 1993;75A(9):1265-75. [pmid: 8408148].
46 Agee J M, McCarroll H R Jr, Tortosa R D, Berry D A, Szabo R M, Peimer C A. Endoscopic release of the carpal tunnel: a randomized prospective multicenter study. J Hand Surg [Am]. Nov. 1992;17(6):987-95.
47 Netscher D, Steadman A K, Thornby J, Cohen V. Temporal changes in grip and pinch strength after open carpal tunnel release and the effect of ligament reconstruction. J Hand Surg [Am]. Jan. 1998;23(1):48-54.
48 Karlsson M K, Lindau T, Hagberg L. Ligament lengthening compared with simple division of the transverse carpal ligament in the open treatment of carpal tunnel syndrome. Scand J Plast Reconstr Surg Hand Surg. Mar. 1997;31(1):65-9. [pmid: 9075290].
49 Hunter J M. Reconstruction of the transverse carpal ligament to restore median nerve gliding. The rationale of a new technique for revision of recurrent median nerve neuropathy. Hand Clin. May. 1996;12(2):365-78. [pmid: 8724588].
50 Frykman G K, Adams J, Bowen W W. Neurolysis. Orthop Clin North Am. Apr. 1981;12(2):325-42. [pmid: 7243243].
51 Dellon A L. Techniques for successful management of ulnar nerve entrapment at the elbow. Neurosurg Clin N Am. Jan. 1991;2(1):57-73. [pmid: 1821735].
52 Froimson A I, Zahrawi F. Treatment of compression neuropathy of the ulnar nerve at the elbow by epicondylectomy and neurolysis. J Hand Surg [Am]. Jul. 1980;5(4):391-5.
53 Piligian G, Herbert R, Hearns M, Dropkin J, Landsbergis P, Cherniack M. Evaluation and management of chronic work-related musculoskeletal disorders of the distal upper extremity. Am J Ind Med. Jan. 2000;37(1):75-93. [pmid: 10573598].
54 Tackmann W, Vogel P, Kaeser H E, Ettlin T. Sensitivity and localizing significance of motor and sensory electroneurographic parameters in the diagnosis of ulnar nerve lesions at the elbow. A reappraisal. J Neurol. 1984;231(4):204-11. [pmid: 6512575].
55 Kimura I, Ayyar D R, Lippmann S M. Early electrodiagnosis of the ulnar entrapment neuropathy at the elbow. Tohoku J Exp Med. Feb. 1984;142(2):165-72. [pmid: 6326345].
56 Bednar M S, Blair S J, Light T R. Complications of the treatment of cubital tunnel syndrome. Hand Clin. Feb. 1994;10(1):83-92. [pmid: 8188782].
57 Willis BK. Cubital tunnel syndrome. In: Benzel EC, editor. Practical approaches to peripheral nerve surgery. Park Ridge (IL): American Association of Neurosurgical Surgeons; 1992. p. 77–93.
58 Rayan G M. Proximal ulnar nerve compression. Cubital tunnel syndrome. Hand Clin. May. 1992;8(2):325-36. [pmid: 1613040].
59 Folberg C R, Weiss A P, Akelman E. Cubital tunnel syndrome. Part I: Presentation and diagnosis. Orthop Rev. Feb. 1994;23(2):136-44. [pmid: 8196972].
60 Cherniack M G. Epidemiology of occupational disorders of the upper extremity. Occup Med. Jul-Sep. 1996;11(3):513-30. [pmid: 8887382].
61 Richardson J K, Green D F, Jamieson S C, Valentin F C. Gender, body mass and age as risk factors for ulnar mononeuropathy at the elbow. Muscle Nerve. Apr. 2001;24(4):551-4. [pmid: 11268028].
62 Seror P, Nathan P A. Relative frequency of nerve conduction abnormalities at carpal tunnel and cubital tunnel in France and the United States: importance of silent neuropathies and role of ulnar neuropathy after unsuccessful carpal tunnel syndrome release. Ann Chir Main Memb Super. 1993;12(4):281-5. [pmid: 7694630].
63 Fernandez E, Pallini R, Lauretti L, Scogna A, La Marca F. Neurosurgery of the peripheral nervous system: cubital tunnel syndrome. Surg Neurol. Jul. 1998;50(1):83-5. [pmid: 9657498].
64 Heithoff S J. Cubital tunnel syndrome does not require transposition of the ulnar nerve. J Hand Surg [Am]. Sep. 1999;24(5):898-905.
65 Tsai T M, Bonczar M, Tsuruta T, Syed S A. A new operative technique: cubital tunnel decompression with endoscopic assistance. Hand Clin. Feb. 1995;11(1):71-80. [pmid: 7751334].
66 Kuschner S H. Cubital tunnel syndrome. Treatment by medial epicondylectomy. Hand Clin. May. 1996;12(2):411-9. [pmid: 8724593].
67 Plancher K D, McGillicuddy J O, Kleinman W B. Anterior intramuscular transposition of the ulnar nerve. Hand Clin. May. 1996;12(2):435-44. [pmid: 8724595].
68 Osterman A L, Davis C A. Subcutaneous transposition of the ulnar nerve for treatment of cubital tunnel syndrome. Hand Clin. May. 1996;12(2):421-33. [pmid: 8724594].
69 Siegel D B. Submuscular transposition of the ulnar nerve. Hand Clin. May. 1996;12(2):445-8. [pmid: 8724596].
70 Spencer G, Herndon C. Surgical treatment of epicondylitis. J Bone Joint Surg Am. 1953;35A:421-4. [pmid: 13069569].
71 Steinborn M, Heuck A, Jessel C, Bonel H, Reiser M. Magnetic resonance imaging of lateral epicondylitis of the elbow with a 0.2-T dedicated system. Eur Radiol. 1999;9(7):1376-80. [pmid: 10460377].
72 Wright A, Thurnwald P, Smith J. An evaluation of mechanical and thermal hyperalgesia in patients with lateral epicondylalgia. Pain Clinic. 1992;5(4):221-227.
73 Friedman P J. Isokinetic peak torque in women with unilateral cumulative trauma disorders and healthy control subjects. Arch Phys Med Rehabil. Jul. 1998;79(7):816-9. [pmid: 9685097].
74 Bredella M A, Tirman P F, Fritz R C, Feller J F, Wischer T K, Genant H K. MR imaging findings of lateral ulnar collateral ligament abnormalities in patients with lateral epicondylitis. AJR Am J Roentgenol. Nov. 1999;173(5):1379-82. [pmid: 10541124].
75 Kushner S, Reid D C. Manipulation in the treatment of tennis elbow. J Orthop Sports Phys Ther. 1986;7(5):264-272. [pmid: 18802262].
76 Kuorinka I, Forcier L, editors. Work related musculoskeletal disorders (WMSDS). A reference book for prevention. London: Taylor & Francis; 1995. Introduction. p. 1–3.
77 Kraushaar B S, Nirschl R P. Tendinosis of the elbow (tennis elbow). Clinical features and findings of histological, immunohistochemical, and electron microscopy studies. J Bone Joint Surg Am. Feb. 1999;81(2):259-78. [pmid: 10073590].
78 Nirschl R P. Elbow tendinosis/tennis elbow. Clin Sports Med. Oct. 1992;11(4):851-70. [pmid: 1423702].
79 Haker E. Lateral epicondylagia: diagnosis, treatment and evaluation. Crit Rev Phys Rehabil Med. 1993;5:129-54.
80 Hamilton P G. The prevalence of humeral epicondylitis: a survey in general practice. J R Coll Gen Pract. Oct. 1986;36(291):464-5. [pmid: 3440991]. [pmcid: 1960610].
81 Murray-Leslie C F, Wright V. Carpal tunnel syndrome, humeral epicondylitis, and the cervical spine: a study of clinical and dimensional relations. Br Med J. Jun 12. 1976;1(6023):1439-42. [pmid: 953532]. [pmcid: 1640418].
82 Bernard BP, Fine LJ, editors. Musculoskeletal disorders and workplace factors. A critical review of epidemiologic evidence for work-related musculoskeletal disorders of the neck, upper extremity, and low back. U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Institute for Occupational Safety and Health; 1997 Jul. 590 p. Also available: http://www.cdc.gov/niosh/97-141pd.html.
83 Almquist E E, Necking L, Bach A W. Epicondylar resection with anconeus muscle transfer for chronic lateral epicondylitis. J Hand Surg [Am]. Jul. 1998;23(4):723-31.
84 Wilhelm A. Tennis elbow: treatment of resistant cases by denervation. J Hand Surg [Br]. Aug. 1996;21(4):523-33.
85 Berger M R. Painful tendon problems of the hand: trigger thumb, trigger finger and de Quervain's syndrome. Orthop Nurs. Sep-Oct. 1982;1(5):20-3. [pmid: 6923423].
86 Kay N R. Changing pathology or changing perception?. J Hand Surg [Br]. Feb. 2000;25B(1):65-9.
87 Grimes H A. Stenosing tenosynovitis (Dequervain's disease, Trigger thumb, and Trigger finger). J Ark Med Soc. Apr. 1981;77(11):499-500. [pmid: 6455134].
88 Ta K T, Eidelman D, Thomson J G. Patient satisfaction and outcomes of surgery for de Quervain's tenosynovitis. J Hand Surg [Am]. 1999;24(5):1071-1077.
89 King P M, Tuckwell N, Barrett T E. A critical review of functional capacity evaluations. Phys Ther. Aug. 1998;78(8):852-66. [pmid: 9711210].
90 Macdonell R A, Schwartz M S, Swash M. Carpal tunnel syndrome: which finger should be tested? An analysis of sensory conduction in digital branches of the median nerve. Muscle Nerve. Jul. 1990;13(7):601-6. [pmid: 2388658].
91 Hedges LV, Olkin I. Statistical methods for meta-analysis. Boston (MA): Academic Press, Inc.; 1985. 369 p.
92 Hasselblad V, Hedges L V. Meta-analysis of screening and diagnostic tests. Psychol Bull. Jan. 1995;117(1):167-78. [pmid: 7870860].
93 Torgerson WS. Theory and methods of scaling. 6th ed. New York (NY): John Wiley & Sons, Inc.; 1958. The law of categorical judgment. p. 205–46.
94 Shadish WR, Haddock CK. Combining estimates of effect size. In: Cooper H, Hedges LV, editors. The handbook of research synthesis. New York (NY): Russell Sage Foundation; 1994. p. 261–77.
95 Cohen J. Statistical power analysis for the behavioral sciences. 2nd ed. Hillsdale (NJ): Lawrence Erlbaum Associates; 1988. 567 p.
96 Newcombe R G. Interval estimation for the difference between independent proportions: comparison of eleven methods. Stat Med. Apr 30. 1998;17(8):873-90. [pmid: 9595617].
97 Hilburn J W. General principles and use of electrodiagnostic studies in carpal and cubital tunnel syndromes. With special, attention to pitfalls and interpretation. Hand Clin. May. 1996;12(2):205-21. [pmid: 8724574].
98 Rosenbaum R B. The role of imaging in the diagnosis of carpal tunnel syndrome. Invest Radiol. Nov. 1993;28(11):1059-62. [pmid: 8276579].
99 Mesgarzadeh M, Triolo J, Schneck C D. Carpal tunnel syndrome. MR imaging diagnosis. Magn Reson Imaging Clin N Am. May. 1995;3(2):249-64. [pmid: 7553021].
100 Buchberger W. Radiologic imaging of the carpal tunnel. Eur J Radiol. Sep. 1997;25(2):112-7. [pmid: 9283839].
101 De Smet L, Steenwerckx A, Van den Bogaert G, Cnudde P, Fabry G. Value of clinical provocative tests in carpal tunnel syndrome. Acta Orthop Belg. 1995;61(3):177-82. [pmid: 8525813].
102 Tetro A M, Evanoff B A, Hollstien S B, Gelberman R H. A new provocative test for carpal tunnel syndrome. Assessment of wrist flexion and nerve compression. J Bone Joint Surg Br. May. 1998;80(3):493-8. [pmid: 9619944].
103 Para F, Kyral V, Matulova H. Examination of sensory nerve fibers by needle recording in the carpal tunnel syndrome; use of the orthodromic method with special attention to the paresthetic forms. Sb Ved Pr Lek Fak Karlovy Univerzity Hradci Kralove. 1994;37(2):73-80. [pmid: 7784802].
104 Gonzalez del Pino J, Delgado-Martinez A D, Gonzalez Gonzalez I, Lovic A. Value of the carpal compression test in the diagnosis of carpal tunnel syndrome. J Hand Surg [Br]. Feb. 1997;22(1):38-41.
105 Pryse-Phillips W E. Validation of a diagnostic sign in carpal tunnel syndrome. J Neurol Neurosurg Psychiatry. Aug. 1984;47(8):870-2. [pmid: 6470728].
106 Gellman H, Gelberman R H, Tan A M, Botte M J. Carpal tunnel syndrome. An evaluation of the provocative diagnostic tests. J Bone Joint Surg Am. Jun. 1986;68(5):735-7. [pmid: 3722231].
107 Dellon A L, Keller K M. Computer-assisted quantitative sensorimotor testing in patients with carpal and cubital tunnel syndromes. Ann Plast Surg. May. 1997;38(5):493-502. [pmid: 9160131].
108 Weber R A, Schuchmann J A, Albers J H, Ortiz J. A prospective blinded evaluation of nerve conduction velocity versus Pressure-Specified Sensory Testing in carpal tunnel syndrome. Ann Plast Surg. Sep. 2000;45(3):252-7. [pmid: 10987525].
109 Lang E, Claus D, Neundorfer B, Handwerker H O. Parameters of thick and thin nerve-fiber functions as predictors of pain in carpal tunnel syndrome. Pain. Mar. 1995;60(3):295-302. [pmid: 7596625].
110 Molitor P J. A diagnostic test for carpal tunnel syndrome using ultrasound. J Hand Surg [Br]. Feb. 1988;13(1):40-1.
111 Werner R A, Bir C, Armstrong T J. Reverse Phalen's maneuver as an aid in diagnosing carpal tunnel syndrome. Arch Phys Med Rehabil. Jul. 1994;75(7):783-6. [pmid: 8024425].
112 Massy-Westropp N, Grimmer K, Bain G. A systematic review of the clinical diagnostic tests for carpal tunnel syndrome. J Hand Surg [Am]. Jan. 2000;25(1):120-7.
113 Franzblau A, Werner R A, Johnston E, Torrey S. Evaluation of current perception threshold testing as a screening procedure for carpal tunnel syndrome among industrial workers. J Occup Med. Sep. 1994;36(9):1015-21. [pmid: 7823213].
114 King P M. Sensory function assessment. A pilot comparison study of touch pressure threshold with texture and tactile discrimination. J Hand Ther. Jan-Mar. 1997;10(1):24-8. [pmid: 9116804].
115 Tassler P L, Dellon A L. Correlation of measurements of pressure perception using the pressure-specified sensory device with electrodiagnostic testing. J Occup Environ Med. Jul. 1995;37(7):862-6. [pmid: 7552472].
116 Radwin R G, Wertsch J J, Jeng O J, Casanova J. Ridge detection tactility deficits associated with carpal tunnel syndrome. J Occup Med. Jun. 1991;33(6):730-6. [pmid: 1865254].
117 Thonnard J, Saels P, Van den Bergh P, Lejeune T. Effects of chronic median nerve compression at the wrist on sensation and manual skills. Exp Brain Res. Sep. 1999;128(12):61-4. [pmid: 10473740].
118 Gerr F, Letz R, Harris-Abbott D, Hopkins L C. Sensitivity and specificity of vibrometry for detection of carpal tunnel syndrome. J Occup Environ Med. Sep. 1995;37(9):1108-15. [pmid: 8528719].
119 Ikegaya N, Hishida A, Sawada K, Furuhashi M, Maruyama Y, Kumagai H, Kobayashi S, Yamamoto T, Yamazaki K. Ultrasonographic evaluation of the carpal tunnel syndrome in hemodialysis patients. Clin Nephrol. Oct. 1995;44(4):231-7. [pmid: 8575122].
120 Messina C, Dattola R, Girlanda P. Usefulness of antidromic sensory conduction velocity in carpal tunnel syndrome. Acta Neurol (Napoli). Feb. 1980;2(1):43-50. [pmcid: 241447]. [pmid: 7395557].
121 Jordan S E, Greider J L Jr. Autonomic activity in the carpal tunnel syndrome. Orthop Rev. Mar. 1987;16(3):165-9. [pmid: 3453969].
122 Sivri A, Guler-Uysal F. The electroneurophysiological evaluation of rheumatoid arthritis patients. Clin Rheumatol. 1998;17(5):416-8. [pmid: 9805193].
123 Stolp-Smith K A, Pascoe M K, Ogburn P L Jr. Carpal tunnel syndrome in pregnancy: frequency, severity, and prognosis. Arch Phys Med Rehabil. Oct. 1998;79(10):1285-7. [pmid: 9779685].
124 Dlabalova V. Our experience with reoperations for the diagnosis of the carpal tunnel syndrome. Acta Chir Plast. 1995;37(2):50-1. [pmid: 8525751].
125 Lazaro RP. Neuropathic symptoms and musculoskeletal pain in carpal tunnel syndrome: prognostic and therapeutic implications. Surg Neurol 1997 Feb;47(2):115–7; discussion 117–9.
126 Nakamichi K I, Tachibana S. Amyloid deposition in the synovium and ligament in idiopathic carpal tunnel syndrome. Muscle Nerve. Oct. 1996;19(10):1349-51. [pmid: 8808665].
127 Williams T M, Mackinnon S E, Novak C B, McCabe S, Kelly L. Verification of the pressure provocative test in carpal tunnel syndrome. Ann Plast Surg. Jul. 1992;29(1):8-11. [pmid: 1497301].
128 Mossman S S, Blau J N. Tinel's sign and the carpal tunnel syndrome. Br Med J (Clin Res Ed). Mar 14. 1987;294(6573):680. [pmid: 3105686].
129 Westerman R A, Delaney C A. Palmar cold threshold test and median nerve electrophysiology in carpal tunnel compression neuropathy. Clin Exp Neurol. 1991;28:154-67. [pmid: 1821823].
130 Herrick R T, Herrick S K. Thermography in the detection of carpal tunnel syndrome and other compressive neuropathies. J Hand Surg [Am]. Sep. 1987;12A(5 Pt 2):943-9.
131 MacDermid J C, Kramer J F, Woodbury M G, McFarlane R M, Roth J H. Interrater reliability of pinch and grip strength measurements in patients with cumulative trauma disorders. J Hand Ther. Jan-Mar. 1994;7(1):10-4. [pmid: 8012479].
132 Greening J, Lynn B. Vibration sense in the upper limb in patients with repetitive strain injury and a group of at-risk office workers. Int Arch Occup Environ Health. Feb. 1998;71(1):29-34. [pmid: 9523246].
133 Byl N, Wilson F, Merzenich M, Melnick M, Scott P, Oakes A, McKenzie A. Sensory dysfunction associated with repetitive strain injuries of tendinitis and focal hand dystonia: a comparative study. J Orthop Sports Phys Ther. Apr. 1996;23(4):234-44. [pmid: 8775368].
134 Palmer K, Smith G, Kellingray S, Cooper C. Repeatability and validity of an upper limb and neck discomfort questionnaire: the utility of the standardized Nordic questionnaire. Occup Med (Lond). Apr. 1999;49(3):171-5. [pmid: 10451598].
135 Uncini A, Di Muzio A, Cutarella R, Awad J, Gambi D. Orthodromic median and ulnar fourth digit sensory conductions in mild carpal tunnel syndrome. Neurophysiol Clin. Apr. 1990;20(1):53-61. [pmid: 2348811].
136 Atroshi I, Johnsson R. Evaluation of portable nerve conduction testing in the diagnosis of carpal tunnel syndrome. J Hand Surg [Am]. Jul. 1996;21(4):651-4.
137 Hansson S, Nilsson B Y. Median sensory nerve conduction block during wrist flexion in the carpal tunnel syndrome. Electromyogr Clin Neurophysiol. Mar. 1995;35(2):99-105. [pmid: 7781580].
138 Rosen I. Neurophysiological diagnosis of the carpal tunnel syndrome: evaluation of neurographic techniques. Scand J Plast Reconstr Surg Hand Surg. 1993;27(2):95-101. [pmid: 8351503].
139 Marin E L, Vernick S, Friedmann L W. Carpal tunnel syndrome: median nerve stress test. Arch Phys Med Rehabil. May. 1983;64(5):206-8. [pmid: 6847356].
140 Kimura J. The carpal tunnel syndrome: localization of conduction abnormalities within the distal segment of the median nerve. Brain. Sep. 1979;102(3):619-35. [pmid: 497808].
141 Loong S C, Seah C S. A sensitive diagnostic test for carpal tunnel syndrome. Singapore Med J. Oct. 1972;13(5):249-55. [pmid: 4651731].
142 Plaja J. Comparative value of the different electrodiagnostic methods in the carpal tunnel syndrome. Scand J Rehabil Med. 1971;3(3):101-8. [pmid: 5156171].
143 Murthy J M, Meena A K. Carpal tunnel syndrome - electrodiagnostic aspects of fifty seven symptomatic hands. Neurol India. Dec. 1999;47(4):272-5. [pmid: 10625897].
144 Kuntzer T. Carpal tunnel syndrome in 100 patients: sensitivity, specificity of multi-neurophysiological procedures and estimation of axonal loss of motor, sensory and sympathetic median nerve fibers. J Neurol Sci. Dec 20. 1994;127(2):221-9. [pmid: 7707081].
145 Chang C W, Lien I N. Comparison of sensory nerve conduction in the palmar cutaneous branch and first digital branch of the median nerve: a new diagnostic method for carpal tunnel syndrome. Muscle Nerve. Dec. 1991;14(12):1173-6. [pmid: 1766448].
146 Cioni R, Passero S, Paradiso C, Giannini F, Battistini N, Rushworth G. Diagnostic specificity of sensory and motor nerve conduction variables in early detection of carpal tunnel syndrome. J Neurol. May. 1989;236(4):208-13. [pmid: 2760633].
147 Melvin J L, Schuchmann J A, Lanese R R. Diagnostic specificity of motor and sensory nerve conduction variables in the carpal tunnel syndrome. Arch Phys Med Rehabil. Feb. 1973;54(2):69-74. [pmid: 4692637].
148 Loong S C, Seah C S. Comparison of median and ulnar sensory nerve action potentials in the diagnosis of the carpal tunnel syndrome. J Neurol Neurosurg Psychiatry. Dec. 1971;34(6):750-4. [pmid: 5158792].
149 Girlanda P, Quartarone A, Sinicropi S, Pronesti C, Nicolosi C, Macaione V, Picciolo G, Messina C. Electrophysiological studies in mild idiopathic carpal tunnel syndrome. Electroencephalogr Clin Neurophysiol Electromyogr Mot Control. 1998;109(1):44-9.
150 Jackson D A, Clifford J C. Electrodiagnosis of mild carpal tunnel syndrome. Arch Phys Med Rehabil. Mar. 1989;70(3):199-204. [pmid: 2923541].
151 Escobar P L, Goka R S. Carpal tunnel syndrome. Palmar sensory latencies to 3rd digit and wrist. Orthop Rev. 1985;14(10):633-9.
152 Szabo R M, Slater R R Jr, Farver T B, Stanton D B, Sharman W K. The value of diagnostic testing in carpal tunnel syndrome. J Hand Surg [Am]. Jul. 1999;24(4):704-14.
153 Fertl E, Wober C, Zeitlhofer J. The serial use of two provocative tests in the clinical diagnosis of carpal tunel syndrome. Acta Neurol Scand. Nov. 1998;98(5):328-32. [pmid: 9858103].
154 Ghavanini M R, Haghighat M. Carpal tunnel syndrome: reappraisal of five clinical tests. Electromyogr Clin Neurophysiol. Oct-Nov. 1998;38(7):437-41. [pmid: 9809232].
155 Durkan J A. A new diagnostic test for carpal tunnel syndrome [published erratum appears in J Bone Joint Surg Am 1992 Feb;74(2):311]. J Bone Joint Surg Am. Apr. 1991;73(4):535-8. [pmid: 1796937].
156 Seror P. Tinel's sign in the diagnosis of carpal tunnel syndrome. J Hand Surg [Br]. Oct. 1987;12(3):364-5.
157 Stewart J D, Eisen A. Tinel's sign and the carpal tunnel syndrome. Br Med J. Oct 21. 1978;2(6145):1125-6. [pmid: 709262].
158 Seror P. Comparative diagnostic sensitivities of orthodromic or antidromic sensory inching test in mild carpal tunnel syndrome. Arch Phys Med Rehabil. Apr. 2000;81(4):442-6. [pmid: 10768533].
159 Seror P. Orthodromic inching test in mild carpal tunnel syndrome. Muscle Nerve. Sep. 1998;21(9):1206-8. [pmid: 9703449].
160 Uncini A, Di Muzio A, Awad J, Manente G, Tafuro M, Gambi D. Sensitivity of three median-to-ulnar comparative tests in diagnosis of mild carpal tunnel syndrome. Muscle Nerve. Dec. 1993;16(12):1366-73. [pmid: 8232394].
161 Uncini A, Lange D J, Solomon M, Soliven B, Meer J, Lovelace R E. Ring finger testing in carpal tunnel syndrome: a comparative study of diagnostic utility. Muscle Nerve. Sep. 1989;12(9):735-41. [pmid: 2641997].
162 Terzis S, Paschalis C, Metallinos I C, Papapetropoulos T. Early diagnosis of carpal tunnel syndrome: comparison of sensory conduction studies of four fingers. Muscle Nerve. Nov. 1998;21(11):1543-5. [pmid: 9771684].
163 Bronson J, Beck J, Gillet J. Provocative motor nerve conduction testing in presumptive carpal tunnel syndrome unconfirmed by traditional electrodiagnostic testing. J Hand Surg [Am]. Nov. 1997;22(6):1041-6.
164 Murata K, Araki S, Okajima F, Saito Y. Subclinical impairment in the median nerve across the carpal tunnel among female VDT operators. Int Arch Occup Environ Health. 1996;68(2):75-9. [pmid: 8720276].
165 Padua L, Lo Monaco M, Valente E M, Tonali P A. A useful electrophysiologic parameter for diagnosis of carpal tunnel syndrome. Muscle Nerve. Jan. 1996;19(1):48-53. [pmid: 8538669].
166 Young V L, Seaton M K, Feely C A, Arfken C, Edwards D F, Baum C M, Logan S. Detecting cumulative trauma disorders in workers performing repetitive tasks. Am J Ind Med. Mar. 1995;27(3):419-31. [pmid: 7747747].
167 Johnson SL, Evans B. Tracking median nerve conduction as a method of early detection of carpal tunnel syndrome. Proceedings of the Human Factors and Ergonomics Society 37th Annual Meeting. 1993 Oct 11–15; Seattle (WA). Santa Monica (CA): 1993. 759–63 p.
168 Jetzer T C. Use of vibration testing in the early evaluation of workers with carpal tunnel syndrome [published erratum appears in J Occup Med 1991 Jul;33(7):812]. J Occup Med. Feb. 1991;33(2):117-20. [pmid: 2016650].
169 Luchetti R, Schoenhuber R, Alfarano M, Montagna G, Pederzini L, Soragni O. Neurophysiological assessment of the early phases of carpal tunnel syndrome with the inching technique before and during operation. J Hand Surg [Br]. Nov. 1991;16(4):415-9.
170 Charles N, Vial C, Chauplannaz G, Bady B. Clinical validation of antidromic stimulation of the ring finger in early electrodiagnosis of mild carpal tunnel syndrome. Electroencephalogr Clin Neurophysiol. Aug. 1990;76(2):142-7. [pmid: 1697242].
171 Palliyath S K, Holden L. Refractory studies in early detection of carpal tunnel syndrome. Electromyogr Clin Neurophysiol. Aug-Sep. 1990;30(5):307-9. [pmid: 2226276].
172 Wongsam P E, Johnson E W, Weinerman J D. Carpal tunnel syndrome: use of palmar stimulation of sensory fibers. Arch Phys Med Rehabil. Jan. 1983;64(1):16-9. [pmid: 6849628].
173 So Y T, Olney R K, Aminoff M J. Evaluation of thermography in the diagnosis of selected entrapment neuropathies. Neurology. Jan. 1989;39(1):1-5. [pmid: 2909896].
174 Resende L A, Alves R P, Castro H A, Kimaid P A, Fortinguerra C R, Schelp A O. Silent period in carpal tunnel syndrome. Electromyogr Clin Neurophysiol. Jan-Feb. 2000;40(1):31-6. [pmid: 10782355].
175 Loscher W N, Auer-Grumbach M, Trinka E, Ladurner G, Hartung H P. Comparison of second lumbrical and interosseus latencies with standard measures of median nerve function across the carpal tunnel: a prospective study of 450 hands. J Neurol. Jul. 2000;247(7):530-4. [pmid: 10993495].
176 Leavitt S S, Johnston T L, Beyer R D. The process of recovery: patterns in industrial back injury. Part 2: Predicting outcomes from early case data. Ind Med Surg. Dec. 1971;40(9):7-15.
177 Pease W S, Lee H H, Johnson E W. Forearm median nerve conduction velocity in carpal tunnel syndrome. Electromyogr Clin Neurophysiol. Aug-Sep. 1990;30(5):299-302. [pmid: 2226274].
178 Rossi S, Giannini F, Passero S, Paradiso C, Battistini N, Cioni R. Sensory neural conduction of median nerve from digits and palm stimulation in carpal tunnel syndrome. Electroencephalogr Clin Neurophysiol. Oct. 1994;93(5):330-4. [pmid: 7525240].
179 Seror P. The value of special motor and sensory tests for the diagnosis of benign and minor median nerve lesion at the wrist. Am J Phys Med Rehabil. Mar-Apr. 1995;74(2):124-9. [pmid: 7710726].
180 Tzeng S S, Wu Z A, Chu F L. Proximal slowing of nerve conduction velocity in carpal tunnel syndrome. Chung Hua I Hsueh Tsa Chih (Taipei). Mar. 1990;45(3):186-90. [pmid: 2168263].
181 Mondelli M MD, Vecchiarelli B, Rearle F MD, Marsili T, Giannini F MD. Sympathetic skin response before and after surgical release of carpal tunnel syndrome. Muscle Nerve. 2001;24:130-33. [pmid: 11150978].
182 Simovic D, Weinberg D H. Terminal latency index in the carpal tunnel syndrome. Muscle Nerve. Sep. 1997;20(9):1178-80. [pmid: 9270676].
183 Simovic D, Weinberg D H. The median nerve terminal latency index in carpal tunnel syndrome: a clinical case selection study. Muscle Nerve. May. 1999;22(5):573-7. [pmid: 10331355].
184 Resende L A, Adamo A S, Bononi A P, Castro H A, Kimaid P A, Fortinguerra C H, Schelp A O. Test of a new technique for the diagnosis of carpal tunnel syndrome. J Electromyogr Kinesiol. Apr. 2000;10(2):127-33. [pmid: 10699560].
185 Lauritzen M, Liguori R, Trojaborg W. Orthodromic sensory conduction along the ring finger in normal subjects and in patients with a carpal tunnel syndrome. Electroencephalogr Clin Neurophysiol. Feb. 1991;81(1):18-23. [pmid: 1705215].
186 Sener H O, Tascilar N F, Balaban H, Selcuki D. Sympathetic skin response in carpal tunnel syndrome. Clin Neurophysiol. Aug. 2000;111(8):1395-9. [pmid: 10904220].
187 Schwartz M S, Gordon J A, Swash M. Slowed nerve conduction with wrist flexion in carpal tunnel syndrome. Ann Neurol. Jul. 1980;8(1):69-71. [pmid: 7406446].
188 Kakosy T. Tunnel syndromes of the upper extremities in workers using hand-operated vibrating tools. Med Lav. Nov-Dec. 1994;85(6):474-80. [pmid: 7731406].
189 Kimura I, Ayyar D R. The carpal tunnel syndrome: electrophysiological aspects of 639 symptomatic extremities. Electromyogr Clin Neurophysiol. Mar-Apr. 1985;25(23):151-64. [pmid: 3987607].
190 Cherniack M G, Moalli D, Viscolli C. A comparison of traditional electrodiagnostic studies, electroneurometry, and vibrometry in the diagnosis of carpal tunnel syndrome. J Hand Surg [Am]. Jan. 1996;21(1):122-31.
191 Sheean G L, Houser M K, Murray N M. Lumbrical-interosseous latency comparison in the diagnosis of carpal tunnel syndrome. Electroencephalogr Clin Neurophysiol. Dec. 1995;97(6):285-9. [pmid: 8536577].
192 Foresti C, Quadri S, Rasella M, Tironi F, Viscardi M, Ubiali E. Carpal tunnel syndrome: which electrodiagnostic path should we follow? A prospective study of 100 consecutive patients. Electromyogr Clin Neurophysiol. Sep. 1996;36(6):377-84. [pmid: 8891478].
193 Eisen A, Schulzer M, Pant B, MacNeil M, Stewart H, Trueman S, Mak E. Receiver operating characteristic curve analysis in the prediction of carpal tunnel syndrome: a model for reporting electrophysiological data. Muscle Nerve. Jul. 1993;16(7):787-96. [pmid: 8018119].
194 Mills K R. Orthodromic sensory action potentials from palmar stimulation in the diagnosis of carpal tunnel syndrome. J Neurol Neurosurg Psychiatry. Mar. 1985;48(3):250-5. [pmid: 3981194].
195 Kim L Y. Palmar digital nerve stimulation to diagnose carpal tunnel syndrome. Orthop Rev. Jun. 1983;12(6):59-63.
196 Andary M T, Fankhauser M J, Ritson J L, Spiegel N, Hulce V, Yosef M, Stanton D F. Comparison of sensory mid-palm studies to other techniques in carpal tunnel syndrome. Electromyogr Clin Neurophysiol. Jul-Aug. 1996;36(5):279-85. [pmid: 8877320].
197 Gerr FE. Quantitative assessement of carpal tunnel syndrome. Cincinnati (OH): National Institute for Occupational Safety and Health; 1994 Jan 18. 38 p. (Final performance report 5K01OH00098-03).
198 Koris M, Gelberman RH, Duncan K, Boublick M, Smith B. Carpal tunnel syndrome. Evaluation of a quantitative provocational diagnostic test. Clin Orthop 1990 Feb;(251):157–61.
199 Brahme S K, Hodler J, Braun R M, Sebrechts C, Jackson W, Resnick D. Dynamic MR imaging of carpal tunnel syndrome. Skeletal Radiol. Aug. 1997;26(8):482-7. [pmid: 9297753].
200 Bland J D. The value of the history in the diagnosis of carpal tunnel syndrome. J Hand Surg [Br]. Oct. 2000;25B(5):445-450.
201 Rosen B, Lundborg G. A new tactile gnosis instrument in sensibility testing. J Hand Ther. Oct-Dec. 1998;11(4):251-7. [pmid: 9862262].
202 Nathan P A, Keniston R C, Myers L D, Meadows K D, Lockwood R S. Natural history of median nerve sensory conduction in industry: relationship to symptoms and carpal tunnel syndrome in 558 hands over 11 years. Muscle Nerve. Jun. 1998;21(6):711-21. [pmid: 9585324].
203 Nathan P A, Keniston R C, Myers L D, Meadows K D. Longitudinal study of median nerve sensory conduction in industry: relationship to age, gender, hand dominance, occupational hand use, and clinical diagnosis. J Hand Surg [Am]. Sep. 1992;17(5):850-7.
204 Kearns J, Gresch E E, Weichel C Y, Eby P, Pallapothu S R. Pre-and post-employment median nerve latency in pork processing employees. J Occup Environ Med. 2000;42(1):96-100. [pmid: 10652695].
205 Missere M, Caso Maria A, Raffi G B. Evaluation of the impingement of the pronator muscle in occupational carpal tunnel syndrome by electromyographic and ultrasonographic techniques. Arh Hig Rada Toksikol. Dec. 1999;50(4):389-93. [pmid: 10851743].
206 Tan M, Tan U. Correlation of carpal tunnel size and conduction velocity of the sensory median and ulnar nerves of male and female controls and carpet weavers. Percept Mot Skills. Dec. 1998;87(3 Pt 2):1195-201. [pmid: 10052077].
207 Werner R A, Franzblau A, Albers J W, Armstrong T J. Median mononeuropathy among active workers: are there differences between symptomatic and asymptomatic workers?. Am J Ind Med. Apr. 1998;33(4):374-8. [pmid: 9513644].
208 Franzblau A D, Salerno F, Armstrong T J, Werner R A. Test-retest reliability of an upper-extremity discomfort questionnaire in an industrial population. Grant No. R01-OH-02941. Scand J Work Environ Health. AUG. 1997;23(4):299-307. [pmid: 9322821].
209 Jeng O J, Radwin R G, Moore J S, Roberts M, Garrity J M, Oswald T. Preliminary evaluation of a sensory and psychomotor functional test battery for carpal tunnel syndrome: Part 2 - Industrial subjects. Am Ind Hyg Assoc J. Dec. 1997;58(12):885-92. [pmid: 9425650].
210 Werner R A, Franzblau A, Albers J W, Buchele H, Armstrong T J. Use of screening nerve conduction studies for predicting future carpal tunnel syndrome. Occup Environ Med. Feb. 1997;54(2):96-100. [pmid: 9072016].
211 Bingham R C, Rosecrance J C, Cook T M. Prevalence of abnormal median nerve conduction in applicants for industrial jobs. Am J Ind Med. Sep. 1996;30(3):355-61. [pmid: 8876806].
212 Pierre-Jerome C, Bekkelund S I, Mellgren S I, Torbergsen T. Quantitative magnetic resonance imaging and the electrophysiology of the carpal tunnel region in floor cleaners. Scand J Work Environ Health. Apr. 1996;22(2):119-23. [pmid: 8738890].
213 Werner R A, Franzblau A, Johnston E. Comparison of multiple frequency vibrometry testing and sensory nerve conduction measures in screening for carpal tunnel syndrome in an industrial setting. Am J Phys Med Rehabil. Mar-Apr. 1995;74(2):101-6. [pmid: 7710722].
214 Kirschberg G J, Fillingim R, Davis V P, Hogg F. Carpal tunnel syndrome: classic clinical symptoms and electrodiagnostic studies in poultry workers with hand, wrist, and forearm pain. South Med J. Mar. 1994;87(3):328-31. [pmid: 8134852].
215 Nathan P A, Takigawa K, Keniston R C, Meadows K D, Lockwood R S. Slowing of sensory conduction of the median nerve and carpal tunnel syndrome in Japanese and American industrial workers. J Hand Surg [Br]. Feb. 1994;19(1):30-4.
216 Nilsson T, Hagberg M, Burstrom L, Kihlberg S. Impaired nerve conduction in the carpal tunnel of platers and truck assemblers exposed to hand-arm vibration. Scand J Work Environ Health. Jun. 1994;20(3):189-99. [pmid: 7973491].
217 Werner R A, Franzblau A, Johnston E. Quantitative vibrometry and electrophysiological assessment in screening for carpal tunnel syndrome among industrial workers: a comparison. Arch Phys Med Rehabil. Nov. 1994;75(11):1228-32. [pmid: 7979934].
218 Nathan P A, Keniston R C, Meadows K D, Lockwood R S. Predictive value of nerve conduction measurements at the carpal tunnel. Muscle Nerve. Dec. 1993;16(12):1377-82. [pmid: 8232396].
219 Grant K A, Congleton J J, Koppa R J, Lessard C S, Huchingson R D. Use of motor nerve conduction testing and vibration sensitivity testing as screening tools for carpal tunnel syndrome in industry. J Hand Surg [Am]. Jan. 1992;17(1):71-6.
220 Atroshi I, Gummesson C, Johnsson R, Ornstein E, Ranstam J, Rosen I. Prevalence of carpal tunnel syndrome in a general population. JAMA. Jul 14. 1999;282(2):153-8. [pmid: 10411196].
221 Ferry S, Silman A J, Pritchard T, Keenan J, Croft P. The association between different patterns of hand symptoms and objective evidence of median nerve compression: a community-based survey. Arthritis Rheum. Apr. 1998;41(4):720-4. [pmid: 9550482].
222 de Krom M C, Knipschild P G, Kester A D, Spaans F. Efficacy of provocative tests for diagnosis of carpal tunnel syndrome. Lancet. Feb 17. 1990;335(8686):393-5. [pmid: 1968125].
223 Welch R. The Measurement of Physiological Predisposition to Tenosynovitis. Ergonomics. SEP. 1973;16(5):665-8. [pmid: 4772991].
224 Finsen V, Russwurm H. Neurophysiology not required before surgery for typical carpal tunnel syndrome. J Hand Surg [Br]. 2001;26B(1):61-4.
225 Atroshi I, Gummesson C, Johnsson R, Ornstein E, Rosen I. Median nerve latency measurement agreement between portable and conventional methods. J Hand Surg [Br]. Feb. 2000;25(1):73-7.
226 Cuturic M, Palliyath S. Motor unit number estimate (MUNE) testing in male patients with mild to moderate carpal tunnel syndrome. Electromyogr Clin Neurophysiol. Mar. 2000;40(2):67-72. [pmid: 10746180].
227 Montagna P, Liguori R. The motor tinel sign: a useful sign in entrapment neuropathy?. Muscle Nerve. Jun. 2000;23(6):976-8. [pmid: 10842279].
228 Nakamichi K I, Tachibana S. Enlarged median nerve in idiopathic carpal tunnel syndrome. Muscle Nerve. Nov. 2000;23(11):1713-8. [pmid: 11054750].
229 Raudino F. Tethered median nerve stress test in the diagnosis of carpal tunnel syndrome. Electromyogr Clin Neurophysiol. Jan-Feb. 2000;40(1):57-60. [pmid: 10782359].
230 Stalberg E, Stalberg S, Karlsson L. Automatic carpal tunnel syndrome tester. Clin Neurophysiol. May. 2000;111(5):826-32. [pmid: 10802453].
231 Burke D T, Burke M A, Bell R, Stewart G W, Mehdi R S, Kim H J. Subjective swelling: a new sign for carpal tunnel syndrome. Am J Phys Med Rehabil. Nov-Dec. 1999;78(6):504-8. [pmid: 10574164].
232 Duncan I, Sullivan P, Lomas F. Sonography in the diagnosis of carpal tunnel syndrome. AJR Am J Roentgenol. Sep. 1999;173(3):681-4. [pmid: 10470903].
233 Kabiraj M M, al-Rajeh S, al-Tahan A R, Abdulijabbar M, al-Bunyan M. Motor terminal latency index in carpal tunnel syndrome. East Mediterr Health J. Mar. 1999;5(2):262-7. [pmid: 10793802].
234 Lee D, van Holsbeeck M T, Janevski P K, Ganos D L, Ditmars D M, Darian V B. Diagnosis of carpal tunnel syndrome. Ultrasound versus electromyography. Radiol Clin North Am. Jul. 1999;37(4):859-72. [pmid: 10442084].
235 Monagle K, Dai G, Chu A, Burnham R S, Snyder R E. Quantitative MR imaging of carpal tunnel syndrome. AJR Am J Roentgenol. Jun. 1999;172(6):1581-6. [pmid: 10350293].
236 Rudolfer S M, Paliouras G, Peers I S. A comparison of logistic regression to decision tree induction in the diagnosis of carpal tunnel syndrome. Comput Biomed Res. Oct. 1999;32(5):391-414. [pmid: 10529299].
237 Sander H W, Quinto C, Saadeh P B, Chokroverty S. Sensitive median-ulnar motor comparative techniques in carpal tunnel syndrome. Muscle Nerve. Jan. 1999;22(1):88-98. [pmid: 9883861].
238 Wang A K, Raynor E M, Blum A S, Rutkove S B. Heat sensitivity of sensory fibers in carpal tunnel syndrome. Muscle Nerve. Jan. 1999;22(1):37-42. [pmid: 9883855].
239 Aurora S K, Ahmad B K, Aurora T K. Silent period abnormalities in carpal tunnel syndrome. Muscle Nerve. Sep. 1998;21(9):1213-5. [pmid: 9703451].
240 Kabiraj M M, Al Rajeh S, Al Tahan A R, Abduljabbar M, Al Bunyan M, Daif A K, Awada A. Carpel tunnel syndrome: a clinico-electrophysiological study. Medical Science Research. 1998;26(9):631-3.
241 Kleindienst A, Hamm B, Lanksch W R. Carpal tunnel syndrome: staging of median nerve compression by MR imaging. J Magn Reson Imaging. 1998;8(5):1119-1125. [pmid: 9786151].
242 Luchetti R, Schoenhuber R, Nathan P. Correlation of segmental carpal tunnel pressures with changes in hand and wrist positions in patients with carpal tunnel syndrome and controls. J Hand Surg [Br]. Oct. 1998;23(5):598-602.
243 Scelsa S N, Herskovitz S, Bieri P, Berger A R. Median mixed and sensory nerve conduction studies in carpal tunnel syndrome. Electroencephalogr Clin Neurophysiol. Jun. 1998;109(3):268-73. [pmid: 9741794].
244 Smith T. Near-nerve versus surface electrode recordings of sensory nerve conduction in patients with carpal tunnel syndrome. Acta Neurol Scand. Oct. 1998;98(4):280-2. [pmid: 9808279].
245 Wilson J R. Median mixed nerve conduction studies in the forearm: evidence against retrograde demyelination in carpal tunnel syndrome. J Clin Neurophysiol. Nov. 1998;15(6):541-6. [pmid: 9881928].
246 Bak L, Bak S, Gaster P, Mathiesen F, Ellemann K, Bertheussen K, Zeeberg I. MR imaging of the wrist in carpal tunnel syndrome. Acta Radiol. Nov. 1997;38(6):1050-2. [pmid: 9394668].
247 Di Guglielmo G, Torrieri F, Repaci M, Uncini A. Conduction block and segmental velocities in carpal tunnel syndrome. Electroencephalogr Clin Neurophysiol. Aug. 1997;105(4):321-7. [pmid: 9284240].
248 Gunnarsson L G, Amilon A, Hellstrand P, Leissner P, Philipson L. The diagnosis of carpal tunnel syndrome. Sensitivity and specificity of some clinical and electrophysiological tests. J Hand Surg [Br]. Feb. 1997;22(1):34-7.
249 Horch RE, Allmann KH, Laubenberger J, Langer M, Stark GB. Median nerve compression can be detected by magnetic resonance imaging of the carpal tunnel. Neurosurgery 1997 Jul;41(1):76–82; discussion 82–3.
250 Kaneko K, Kawai S, Taguchi T, Fuchigami Y, Shiraishi G. Coexisting peripheral nerve and cervical cord compression. Spine. Mar 15. 1997;22(6):636-40. [pmid: 9089936].
251 Pierre-Jerome C, Bekkelund S I, Mellgren S I, Nordstrom R. Quantitative MRI and electrophysiology of preoperative carpal tunnel syndrome in a female population. Ergonomics. Jun. 1997;40(6):642-9. [pmid: 9174415].
252 Radack D M, Schweitzer M E, Taras J. Carpal tunnel syndrome: are the MR findings a result of population selection bias?. AJR Am J Roentgenol. Dec. 1997;169(6):1649-53. [pmid: 9393185].
253 Rosecrance J C, Cook T M, Bingham R C. Sensory nerve recovery following median nerve provocation in carpal tunnel syndrome. Electromyogr Clin Neurophysiol. Jun-Jul. 1997;37(4):219-29. [pmid: 9208217].
254 Checkosky C M, Bolanowski S J, Cohen J C. Assessment of vibrotactile sensitivity in patients with carpal tunnel syndrome. J Occup Environ Med. Jun. 1996;38(6):593-601. [pmid: 8794958].
255 Ghavanini M R, Kazemi B, Jazayeri M, Khosrawi S. Median-radial sensory latencies comparison as a new test in carpal tunnel syndrome. Electromyogr Clin Neurophysiol. Apr-May. 1996;36(3):171-3. [pmid: 8737938].
256 Kleindienst A, Hamm B, Hildebrandt G, Klug N. Diagnosis and staging of carpal tunnel syndrome: comparison of magnetic resonance imaging and intra-operative findings. Acta Neurochir (Wien). 1996;138(2):228-33. [pmcid: 300905]. [pmid: 8686550].
257 Britz G W, Haynor D R, Kuntz C, Goodkin R, Gitter A, Kliot M. Carpal tunnel syndrome: correlation of magnetic resonance imaging, clinical, electrodiagnostic, and intraoperative findings. Neurosurgery. Dec. 1995;37(6):1097-103. [pmid: 8584150].
258 Golovchinsky V. Relationship between damage of cervical nerve roots or brachial plexus and development of peripheral entrapment syndromes in upper extremities (double crush syndrome). J Neurol Orthop Med Surg. 1995;16(2):61-9.
259 Hamanaka I, Okutsu I, Shimizu K, Takatori Y, Ninomiya S. Evaluation of carpal canal pressure in carpal tunnel syndrome. J Hand Surg [Am]. Sep. 1995;20(5):848-54.
260 Kothari M J, Rutkove S B, Caress J B, Hinchey J, Logigian E L, Preston D C. Comparison of digital sensory studies in patients with carpal tunnel syndrome. Muscle Nerve. Nov. 1995;18(11):1272-6. [pmid: 7565924].
261 Lesser E A, Venkatesh S, Preston D C, Logigian E L. Stimulation distal to the lesion in patients with carpal tunnel syndrome. Muscle Nerve. May. 1995;18(5):503-7. [pmid: 7739637].
262 Nakamichi K, Tachibana S. Restricted motion of the median nerve in carpal tunnel syndrome. J Hand Surg [Br]. Aug. 1995;20(4):460-4.
263 Seradge H, Jia Y C, Owens W. In vivo measurement of carpal tunnel pressure in the functioning hand. J Hand Surg [Am]. Sep. 1995;20(5):855-9.
264 Shafshak T S, el-Hinawy Y M. The anterior interosseous nerve latency in the diagnosis of severe carpal tunnel syndrome with unobtainable median nerve distal conduction. Arch Phys Med Rehabil. May. 1995;76(5):471-5. [pmid: 7741621].
265 Valls-Sole J, Alvarez R, Nunez M. Limited longitudinal sliding of the median nerve in patients with carpal tunnel syndrome. Muscle Nerve. Jul. 1995;18(7):761-7. [pmid: 7783766].
266 Clifford J C, Israels H. Provocative exercise maneuver: its effect on nerve conduction studies in patients with carpal tunnel syndrome. Arch Phys Med Rehabil. Jan. 1994;75(1):8-11. [pmid: 8291968].
267 Durkan J A. The carpal-compression test. An instrumented device for diagnosing carpal tunnel syndrome. Orthop Rev. Jun. 1994;23(6):522-5. [pmid: 8065809].
268 Nakamichi K, Tachibana S. Unilateral carpal tunnel syndrome and space-occupying lesions. J Hand Surg [Br]. Dec. 1993;18(6):748-9.
269 Rodriquez A A, Radwin R G, Jeng O J. Median nerve electrophysiologic parameters and psychomotor performance in carpal tunnel syndrome. Electromyogr Clin Neurophysiol. Jul-Aug. 1993;33(5):311-9. [pmid: 8404568].
270 Rosen I, Stromberg T, Lundborg G. Neurophysiological investigation of hands damaged by vibration: comparison with idiopathic carpal tunnel syndrome. Scand J Plast Reconstr Surg Hand Surg. Sep. 1993;27(3):209-16. [pmid: 8272772].
271 Buchberger W, Judmaier W, Birbamer G, Lener M, Schmidauer C. Carpal tunnel syndrome: diagnosis with high-resolution sonography. AJR Am J Roentgenol. Oct. 1992;159(4):793-8. [pmid: 1529845].
272 Imaoka H, Yorifuji S, Takahashi M, Nakamura Y, Kitaguchi M, Tarui S. Improved inching method for the diagnosis and prognosis of carpal tunnel syndrome. Muscle Nerve. Mar. 1992;15(3):318-24. [pmid: 1557079].
273 Kindstrand E. Antibodies to Borrelia burgdorferi in patients with carpal tunnel syndrome. Acta Neurol Scand. Jul. 1992;86(1):73-5. [pmid: 1519478].
274 Tchou S, Costich J F, Burgess R C, Wexler C E. Thermographic observations in unilateral carpal tunnel syndrome: report of 61 cases. J Hand Surg [Am]. Jul. 1992;17(4):631-7.
275 Buchberger W, Schon G, Strasser K, Jungwirth W. High-resolution ultrasonography of the carpal tunnel. J Ultrasound Med. Oct. 1991;10(10):531-7. [pmid: 1942218].
276 Katz J N, Larson M G, Fossel A H, Liang M H. Validation of a surveillance case definition of carpal tunnel syndrome. Am J Public Health. 1991;81(2):189-193. [pmid: 1990856]. [pmcid: 1404953].
277 Fitz W R, Mysiw W J, Johnson E W. First lumbrical latency and amplitude. Control values and findings in carpal tunnel syndrome. Am J Phys Med Rehabil. Aug. 1990;69(4):198-201. [pmid: 2383380].
278 Gilliatt R W, Meer J. The refractory period of transmission in patients with carpal tunnel syndrome. Muscle Nerve. May. 1990;13(5):445-50. [pmid: 2161081].
279 Merchut M P, Kelly M A, Toleikis S C. Quantitative sensory thresholds in carpal tunnel syndrome. Electromyogr Clin Neurophysiol. Feb-Mar. 1990;30(2):119-24. [pmid: 2155775].
280 Rojviroj S, Sirichativapee W, Kowsuwon W, Wongwiwattananon J, Tamnanthong N, Jeeravipoolvarn P. Pressures in the carpal tunnel. A comparison between patients with carpal tunnel syndrome and normal subjects. J Bone Joint Surg Br. May. 1990;72(3):516-8. [pmid: 2187880].
281 Winn FJ Jr, Putz-Anderson V. Vibration thresholds as a function of age and diagnosis of carpal tunnel syndrome: a preliminary report. Exp Aging Res 1990 Winter;16(4):221–4.
282 Braun R M, Davidson K, Doehr S. Provocative testing in the diagnosis of dynamic carpal tunnel syndrome. J Hand Surg [Am]. Mar. 1989;14(2 Pt 1):195-7.
283 Meyers S, Cros D, Sherry B, Vermeire P. Liquid crystal thermography: quantitative studies of abnormalities in carpal tunnel syndrome. Neurology. Nov. 1989;39(11):1465-9. [pmid: 2812323].
284 Szabo R M, Chidgey L K. Stress carpal tunnel pressures in patients with carpal tunnel syndrome and normal patients. J Hand Surg [Am]. Jul. 1989;14(4):624-7.
285 De Lean J. Transcarpal median sensory conduction: detection of latent abnormalities in mild carpal tunnel syndrome. Can J Neurol Sci. Nov. 1988;15(4):388-93. [pmid: 3208222].
286 Mortier G, Deckers K, Dijs H, Vander Auwera J C. Comparison of the distal motor latency of the ulnar nerve in carpal tunnel syndrome with a control group. Electromyogr Clin Neurophysiol. Mar-Apr. 1988;28(23):75-7. [pmid: 3416807].
287 Pease W S, Cunningham M L, Walsh W E, Johnson E W. Determining neurapraxia in carpal tunnel syndrome. Am J Phys Med Rehabil. Jun. 1988;67(3):117-9. [pmid: 3377889].
288 Carroll G J. Comparison of median and radial nerve sensory latencies in the electrophysiological diagnosis of carpal tunnel syndrome. Electroencephalogr Clin Neurophysiol. Mar. 1987;68(2):101-6. [pmid: 2435526].
289 Jessurun W, Hillen B, Zonneveld F, Huffstadt A J, Beks J W, Overbeek W. Anatomical relations in the carpal tunnel: a computed tomographic study. J Hand Surg [Br]. Feb. 1987;12(1):64-7.
290 Johnson E W, Sipski M, Lammertse T. Median and radial sensory latencies to digit I: normal values and usefulness in carpal tunnel syndrome [published erratum appears in Arch Phys Med Rehabil 1987 Jun;68(6):388]. Arch Phys Med Rehabil. Mar. 1987;68(3):140-1. [pmid: 3827552].
291 Liang C L. CT-scanning study of cross-sectional area of the carpal tunnel in cases of carpal tunnel syndrome. Nippon Seikeigeka Gakkai Zasshi. Oct. 1987;61(10):1033-45. [pmid: 3437172].
292 Macleod W N. Repeater F waves: a comparison of sensitivity with sensory antidromic wrist-to-palm latency and distal motor latency in the diagnosis of carpal tunnel syndrome. Neurology. May. 1987;37(5):773-8. [pmid: 3574675].
293 Borg K, Lindblom U. Increase of vibration threshold during wrist flexion in patients with carpal tunnel syndrome. Pain. Aug. 1986;26(2):211-9. [pmid: 3763234].
294 Borg K, Lindblom U. Provoked changes in vibratory perception threshold versus stationary impairment of sensibility in carpal tunnel syndrom. Acta Neurol Scand. 1984;69(98):218-9. [pmid: 6204498].
295 Satoh K, Nemoto J. Sub-clinical carpal tunnel syndrome: electrophysiological study and natural course. Nihon Univ J Med. 1984;26(2):63-68.
296 Goddard D H, Barnes C G, Berry H, Evans S. Measurement of nerve conduction - a comparison of orthodromic and antidromic methods. Clin Rheumatol. Jun. 1983;2(2):169-74. [pmid: 6678691].
297 Johnson E W, Kukla R D, Wongsam P E, Piedmont A. Sensory latencies to the ring finger: normal values and relation to carpal tunnel syndrome. Arch Phys Med Rehabil. May. 1981;62(5):206-8. [pmid: 7235908].
298 Eisen A, Schomer D, Melmed C. The application of F-wave measurements in the differentiation of proximal and distal upper limb entrapments. Neurology. Jul. 1977;27(7):662-8. [pmid: 559973].
299 Sedal L, McLeod J G, Walsh J C. Ulnar nerve lesions associated with the carpal tunnel syndrome. J Neurol Neurosurg Psychiatry. Feb. 1973;36(1):118-23. [pmid: 4691684].
300 Casey E B, Le Quesne P M. Digital nerve action potentials in healthy subjects, and in carpal tunnel and diabetic patients. J Neurol Neurosurg Psychiatry. Oct. 1972;35(5):612-23. [pmid: 5084132].
301 Buchthal F, Rosenfalck A. Sensory conduction from digit to palm and from palm to wrist in the carpal tunnel syndrome. J Neurol Neurosurg Psychiatry. Jun. 1971;34(3):243-52. [pmid: 5571311].
302 Katz J N, Keller R B, Fossel A H, Punnett L, Bessette L, Simmons B P, Mooney N. Predictors of return to work following carpal tunnel release. Am J Ind Med. 1997;31(1):85-91. [pmid: 8986259].
303 Katz J N, Gelberman R H, Wright E A, Lew R A, Liang M H. Responsiveness of self-reported and objective measures of disease severity in carpal tunnel syndrome. Med Care. Nov. 1994;32(11):1127-33. [pmid: 7967853].
304 Erdmann M W. Endoscopic carpal tunnel decompression. J Hand Surg [Br]. Feb. 1994;19(1):5-13.
305 Straub T A. Endoscopic carpal tunnel release: a prospective analysis of factors associated with unsatisfactory results. Arthroscopy. Apr. 1999;15(3):269-74. [pmid: 10231104].
306 Nygaard O P, Trumpy J H, Mellgren S I. Recovery of sensory function after surgical decompression in carpal tunnel syndrome. Acta Neurol Scand. Oct. 1996;94(4):253-7. [pmid: 8937536].
307 Wheatley M J, Kaul M P. Recurrent carpal tunnel syndrome following endoscopic carpal tunnel release: a preliminary report. Ann Plast Surg. Nov. 1997;39(5):469-71. [pmid: 9374142].
308 Hagberg M, Nystrom A, Zetterlund B. Recovery from symptoms after carpal tunnel syndrome surgery in males in relation to vibration exposure. J Hand Surg [Am]. Jan. 1991;16(1):66-71.
309 Avci S, Sayli U. Carpal tunnel release using a short palmar incision and new knife. J Hand Surg [Br]. Aug. 2000;25B(4):357-60.
310 Khan R, Macey A. Open carpal tunnel release under local anaesthesia: a patient satisfaction survey. Ir Med J. Jan-Feb. 2000;93(1):19. [pmid: 10740368].
311 Mondelli M, Reale F, Sicurelli F, Padua L. Relationship between the self-administered Boston questionnaire and electrophysiological findings in follow-up of surgically-treated carpal tunnel syndrome. Riv Neurobiol. 2000;25 B(2):128-34.
312 Muller L P, Rudig L, Degreif J, Rommens P M. Endoscopic carpal tunnel release: results with special consideration to possible complications. Knee Surg Sports Traumatol Arthrosc. 2000;8(3):166-72. [pmid: 10883429].
313 Porras A F, Alaminos P R, Vinuales J I, Villamanan M A. Value of electrodiagnostic tests in carpal tunnel syndrome. J Hand Surg [Br]. Aug. 2000;25B(4):361-5.
314 Varitimidis S E, Riano F, Vardakas D G, Sotereanos D G. Recurrent compressive neuropathy of the median nerve at the wrist: treatment with autogenous saphenous vein wrapping. J Hand Surg [Br]. Jun. 2000;25B(3):271-5.
315 Alderson M, McGall D. The Alderson-McGall hand function questionnaire for patients with Carpal Tunnel syndrome: a pilot evaluation of a future outcome measure. J Hand Ther. Oct-Dec. 1999;12(4):313-22. [pmid: 10622198].
316 Braun R M, Doehr S, Mosqueda T, Garcia A. The effect of legal representation on functional recovery of the hand in injured workers following carpal tunnel release. J Hand Surg [Am]. Jan. 1999;24(1):53-8.
317 Chen H T, Chen H C, Wei F C. Endoscopic carpal tunnel release. Chang Keng I Hsueh Tsa Chih. Sep. 1999;22(3):386-91. [pmid: 10584409].
318 Erhard L, Ozalp T, Citron N, Foucher G. Carpal tunnel release by the Agee endoscopic technique. Results at 4 year follow-up. J Hand Surg [Br]. Oct. 1999;24(5):583-5.
319 Finsen V, Andersen K, Russwurm H. No advantage from splinting the wrist after open carpal tunnel release. A randomized study of 82 wrists. Acta Orthop Scand. Jun. 1999;70(3):288-92. [pmid: 10429608].
320 Hasegawa K, Hashizume H, Senda M, Kawai A, Inoue H. Evaluation of release surgery for idiopathic carpal tunnel syndrome: endoscopic versus open method. Acta Med Okayama. Aug. 1999;53(4):179-83. [pmid: 10488404].
321 Hirooka T, Hashizume H, Senda M, Nagoshi M, Inoue H, Nagashima H. Adequacy and long-term prognosis of endoscopic carpal tunnel release. Acta Med Okayama. Feb. 1999;53(1):39-44. [pmid: 10096737].
322 Lindau T, Karlsson M K. Complications and outcome in open carpal tunnel release. A 6-year follow-up in 92 patients. Chir Main. 1999;18(2):115-21. [pmid: 10855309].
323 Olney J R, Quenzer D E, Makowsky M. Contested claims in carpal tunnel surgery: outcome study of worker's compensation factors. Iowa Orthop J. 1999;19:111-21. [pmid: 10847525]. [pmcid: 1888621].
324 Senda M, Hashizume H, Terai Y, Inoue H, Nagashima H. Electromyographic evaluation after endoscopic carpal tunnel release in idiopathic carpal tunnel syndrome. J Orthop Sci. 1999;4(3):187-90. [pmid: 10370159].
325 Varitimidis S E, Herndon J H, Sotereanos D G. Failed endoscopic carpal tunnel release. Operative findings and results of open revision surgery. J Hand Surg [Br]. 1999;24 B(4):465-467.
326 Atroshi I, Johnsson R, Sprinchorn A. Self-administered outcome instrument in carpal tunnel syndrome. Reliability, validity and responsiveness evaluated in 102 patients. Acta Orthop Scand. Feb. 1998;69(1):82-8. [pmid: 9524525].
327 Aulisa L, Tamburrelli F, Padua R, Romanini E, Lo Monaco M, Padua L. Carpal tunnel syndrome: indication for surgical treatment based on electrophysiologic study. J Hand Surg [Am]. Jul. 1998;23(4):687-91.
328 Buchhorn T, Cameron E A, Klausmann H G, Erggelet C, Kramer J. The endoscopic treatment of carpal tunnel syndrome as an outpatient procedure. Diagn Ther Endosc. 1998;4(4):183-190. [pmid: 18493471].
329 Choi S J, Ahn D S. Correlation of clinical history and electrodiagnostic abnormalities with outcome after surgery for carpal tunnel syndrome. Plast Reconstr Surg. Dec. 1998;102(7):2374-80. [pmid: 9858172].
330 Davies B W, Pennington G A, Fritz A M. Two-portal endoscopic carpal tunnel release: an outcome analysis of 333 hands. Ann Plast Surg. May. 1998;40(5):542-8. [pmid: 9600444].
331 Lee WP, Strickland JW. Safe carpal tunnel release via a limited palmar incision. Plast Reconstr Surg 1998 Feb;101(2):418–24; discussion 425–6.
332 Nakamichi K, Tachibana S. Histology of the transverse carpal ligament and flexor tenosynovium in idiopathic carpal tunnel syndrome. J Hand Surg [Am]. Nov. 1998;23(6):1015-24.
333 Papageorgiou C D, Georgoulis A D, Makris C A, Moebius U G, Varitimidis S E, Soucacos P N. Difficulties and early results of the endoscopic carpal tunnel release using the modified Chow technique. Knee Surg Sports Traumatol Arthrosc. 1998;6(3):189-93. [pmid: 9704327].
334 Schuind F, Nguyen T, Vancabeke M, Wautrecht J C. Modifications of arterial blood flow to the hand after carpal tunnel release. Acta Orthop Belg. Sep. 1998;64(3):296-300. [pmid: 9828476].
335 Tomaino M M, Plakseychuk A. Identification and preservation of Palmar cutaneous nerves during open carpal tunnel release. J Hand Surg [Br]. Oct. 1998;23(5):607-8.
336 Armstong A P, Flynn J R, Davies D M. Endoscopic carpal tunnel release. A review of 208 consecutive cases. J Hand Surg [Br]. 1997;22 B(4):505-507.
337 Atroshi I, Johnsson R, Ornstein E. Endoscopic carpal tunnel release: prospective assessment of 255 consecutive cases. J Hand Surg [Br]. Feb. 1997;22(1):42-7.
338 Baguneid M S, Sochart D H, Dunlop D, Kenny N W. Carpal tunnel decompression under local anaesthetic and tourniquet control. J Hand Surg [Br]. Jun. 1997;22(3):322-4.
339 Chia J, Pho R W H. Surgical release of carpal tunnel syndrome under local anaesthesia. J Orthop Surg. 1997;5(2):25-28.
340 Citron N D, Bendall S P. Local symptoms after open carpal tunnel release. A randomized prospective trial of two incisions. J Hand Surg [Br]. Jun. 1997;22(3):317-21.
341 Higgs P E, Edwards D F, Martin D S, Weeks P M. Relation of preoperative nerve-conduction values to outcome in workers with surgically treated carpal tunnel syndrome. J Hand Surg [Am]. Mar. 1997;22(2):216-21.
342 Leinberry C F, Hammond N L 3d, Siegfried J W. The role of epineurotomy in the operative treatment of carpal tunnel syndrome. J Bone Joint Surg Am. Apr. 1997;79(4):555-7. [pmid: 9111400].
343 Rosen B, Lundborg G, Abrahamsson S O, Hagberg L, Rosen I. Sensory function after median nerve decompression in carpal tunnel syndrome. Preoperative vs postoperative findings. J Hand Surg [Br]. Oct. 1997;22(5):602-6.
344 Serra J M, Benito J R, Monner J. Carpal tunnel release with short incision. Plast Reconstr Surg. Jan. 1997;99(1):129-35. [pmid: 8982196].
345 Stahl S, Ben-David B, Moscona R A. The effect of local infiltration with morphine before carpal tunnel release. J Bone Joint Surg Am. Apr. 1997;79(4):551-4. [pmid: 9111399].
346 Lewicky R T. Endoscopic carpal tunnel release: the guide tube technique. Arthroscopy. Feb. 1994;10(1):39-49. [pmid: 8166900].
347 Weber R A, Sanders W E. Flexor carpi radialis approach for carpal tunnel release. J Hand Surg [Am]. Jan. 1997;22(1):120-6.
348 Cobb T K, Amadio P C, Leatherwood D F, Schleck C D, Ilstrup D M. Outcome of reoperation for carpal tunnel syndrome. J Hand Surg [Am]. May. 1996;21(3):347-56.
349 Elmaraghy M W, Hurst L N. Single-portal endoscopic carpal tunnel release: agee carpal tunnel release system. Ann Plast Surg. Mar. 1996;36(3):286-91. [pmid: 8659953].
350 Franzini A, Broggi G, Servello D, Dones I, Pluchino M G. Transillumination in minimally invasive surgery for carpal tunnel release. Technical note. J Neurosurg. Dec. 1996;85(6):1184-6. [pmid: 8929518].
351 Gibbs K E, Rand W, Ruby L K. Open vs endoscopic carpal tunnel release. Orthopedics. Dec. 1996;19(12):1025-8. [pmid: 8972520].
352 Glowacki K A, Breen C J, Sachar K, Weiss A P. Electrodiagnostic testing and carpal tunnel release outcome. J Hand Surg [Am]. Jan. 1996;21(1):117-21.
353 Jacobsen M B, Rahme H. A prospective, randomized study with an independent observer comparing open carpal tunnel release with endoscopic carpal tunnel release. J Hand Surg [Br]. Apr. 1996;21(2):202-4.
354 Kluge W, Simpson R G, Nicol A C. Late complications after open carpal tunnel decompression. J Hand Surg [Br]. Apr. 1996;21(2):205-7.
355 Lee H, Jackson TA. Carpal tunnel release through a limited skin incision under direct visualization using a new instrument, the carposcope. Plast Reconstr Surg 1996 Aug;98(2):313–9; discussion 320.
356 McLaughlin M R, Pizzi F J. ‘Sympathy pains’ in carpal tunnel syndrome. Acta Neurochir (Wien). 1996;138(9):1094-8. [pmcid: 300905]. [pmid: 8911546].
357 Nagle D J, Fischer T J, Harris G D, Hastings H, Osterman A L, Palmer A K, Viegas S F, Whipple T L, Foley M. A multicenter prospective review of 640 endoscopic carpal tunnel releases using the transbursal and extrabursal chow techniques. Arthroscopy. Apr. 1996;12(2):139-43. [pmid: 8776988].
358 Padua L, LoMonaco M, Aulisa L, Tamburrelli F, Valente E M, Padua R, Gregori B, Tonali P. Surgical prognosis in carpal tunnel syndrome: usefulness of a preoperative neurophysiological assessment. Acta Neurol Scand. Nov. 1996;94(5):343-6. [pmid: 8947287].
359 Pennino R, Tavin E. Endoscopic-assisted carpal tunnel release: a coupling of endoscopic and open techniques. Ann Plast Surg. May. 1996;36(5):458-61. [pmid: 8743652].
360 Povlsen B, Tegnell I. Incidence and natural history of touch allodynia after open carpal tunnel release. Scand J Plast Reconstr Surg Hand Surg. Sep. 1996;30(3):221-5. [pmid: 8885019].
361 Strickland J W, Idler R S, Lourie G M, Plancher K D. The hypothenar fat pad flap for management of recalcitrant carpal tunnel syndrome. J Hand Surg [Am]. Sep. 1996;21(5):840-8.
362 Wintman BI, Winters SC, Gelberman RH, Katz JN. Carpal tunnel release. Correlations with preoperative symptomatology. Clin Orthop 1996 May;(326):135–45.
363 Abdullah AF, Wolber PH, Ditto EW 3d. Sequelae of carpal tunnel surgery: rationale for the design of a surgical approach. Neurosurgery 1995 Nov;37(5):931–5; discussion 935–6.
364 Bury T F, Akelman E, Weiss A P. Prospective, randomized trial of splinting after carpal tunnel release. Ann Plast Surg. Jul. 1995;35(1):19-22. [pmid: 7574280].
365 Dumontier C, Sokolow C, Leclercq C, Chauvin P. Early results of conventional versus two-portal endoscopic carpal tunnel release. A prospective study. J Hand Surg [Br]. Oct. 1995;20(5):658-62.
366 Futami T. Surgery for bilateral carpal tunnel syndrome. Endoscopic and open release compared in 10 patients. Acta Orthop Scand. Apr. 1995;66(2):153-5. [pmid: 7740946].
367 Gross A S, Louis D S, Carr K A, Weiss S A. Carpal tunnel syndrome: a clinicopathologic study. J Occup Environ Med. Apr. 1995;37(4):437-41. [pmid: 7670899].
368 Hallock G G, Lutz D A. Prospective comparison of minimal incision ‘open’ and two-portal endoscopic carpal tunnel release. Plast Reconstr Surg. Sep. 1995;96(4):941-7. [pmid: 7652069].
369 Katz J N, Fossel K K, Simmons B P, Swartz R A, Fossel A H, Koris M J. Symptoms, functional status, and neuromuscular impairment following carpal tunnel release. J Hand Surg [Am]. Jul. 1995;20(4):549-55.
370 LoVerme P J, Saccone P G. Limited portal with direct-vision carpal tunnel release. Ann Plast Surg. Mar. 1995;34(3):304-8. [pmid: 7598389].
371 Mirza M A, King E T Jr, Tanveer S. Palmar uniportal extrabursal endoscopic carpal tunnel release. Arthroscopy. Feb. 1995;11(1):82-90. [pmid: 7727017].
372 Nancollas M P, Peimer C A, Wheeler D R, Sherwin F S. Long-term results of carpal tunnel release. J Hand Surg [Br]. Aug. 1995;20(4):470-4.
373 Sennwald G R, Benedetti R. The value of one-portal endoscopic carpal tunnel release: a prospective randomized study. Knee Surg Sports Traumatol Arthrosc. 1995;3(2):113-6. [pmid: 7553006].
374 Shinya K, Lanzetta M, Conolly W B. Risk and complications in endoscopic carpal tunnel release. J Hand Surg [Br]. 1995;20 B(2):222-7.
375 al-Qattan M M, Bowen V, Manktelow R T. Factors associated with poor outcome following primary carpal tunnel release in non-diabetic patients. J Hand Surg [Br]. Oct. 1994;19(5):622-5.
376 Foulkes G D, Atkinson R E, Beuchel C, Doyle J R, Singer D I. Outcome following epineurotomy in carpal tunnel syndrome: a prospective, randomized clinical trial. J Hand Surg [Am]. Jul. 1994;19(4):539-47.
377 Katz J N, Gelberman R H, Wright E A, Abrahamsson S O, Lew R A. A preliminary scoring system for assessing the outcome of carpal tunnel release. J Hand Surg [Am]. Jul. 1994;19(4):531-8.
378 Kelly C P, Pulisetti D, Jamieson A M. Early experience with endoscopic carpal tunnel release. J Hand Surg [Br]. Feb. 1994;19(1):18-21.
379 Kerr C D, Gittins M E, Sybert D R. Endoscopic versus open carpal tunnel release: clinical results. Arthroscopy. Jun. 1994;10(3):266-9. [pmid: 8086018].
380 Menon J. Endoscopic carpal tunnel release: preliminary report. Arthroscopy. Feb. 1994;10(1):31-8. [pmid: 8166899].
381 Pascoe M K, Pascoe R D, Tarrant E, Boyle R. Changes in palmar sensory latencies in response to carpal tunnel release. Muscle Nerve. Dec. 1994;17(12):1475-6. [pmid: 7969252].
382 Payne J C, Bergman R S, Ettinger D J. Endoscopic carpal tunnel release. J Am Osteopath Assoc. Apr. 1994;94(4):295-8. [pmid: 8026997].
383 Roth J H, Richards R S, MacLeod M D. Endoscopic carpal tunnel release. Can J Surg. Jun. 1994;37(3):189-93. [pmid: 8199935].
384 Singh I, Khoo K M, Krishnamoorthy S. The carpal tunnel syndrome: clinical evaluation and results of surgical decompression. Ann Acad Med Singapore. Jan. 1994;23(1):94-7. [pmid: 8185280].
385 Skoff H D, Sklar R. Endoscopic median nerve decompression: early experience. Plast Reconstr Surg. Oct. 1994;94(5):691-4. [pmid: 7938293].
386 Strasberg S R, Novak C B, Mackinnon S E, Murray J F. Subjective and employment outcome following secondary carpal tunnel surgery. Ann Plast Surg. May. 1994;32(5):485-9. [pmid: 8060072].
387 Wilson K M. Double incision open technique for carpal tunnel release: an alternative to endoscopic release. J Hand Surg [Am]. Nov. 1994;19(6):907-12.
388 Biyani A, Downes E M. An open twin incision technique of carpal tunnel decompression with reduced incidence of scar tenderness. J Hand Surg [Br]. Jun. 1993;18(3):331-4.
389 Chang B, Dellon A L. Surgical management of recurrent carpal tunnel syndrome. J Hand Surg [Br]. Aug. 1993;18(4):467-70.
390 Feinstein P A. Endoscopic carpal tunnel release in a community-based series. J Hand Surg [Am]. May. 1993;18(3):451-4.
391 Jimenez S, Hardy MA, Horch K, Jabaley M. A study of sensory recovery following carpal tunnel release. J Hand Ther 1993 Apr-Jun;6(2):124–9.
392 Leach W J, Esler C, Scott T D. Grip strength following carpal tunnel decompression. J Hand Surg [Br]. Dec. 1993;18(6):750-2.
393 Levine D W, Simmons B P, Koris M J, Daltroy L H, Hohl G G, Fossel A H, Katz J N. A self-administered questionnaire for the assessment of severity of symptoms and functional status in carpal tunnel syndrome. J Bone Joint Surg Am. Nov. 1993;75(11):1585-92. [pmid: 8245050].
394 Nakamichi K, Tachibana S. The use of ultrasonography in detection of synovitis in carpal tunnel syndrome. J Hand Surg [Br]. Apr. 1993;18(2):176-9.
395 Nathan P A, Meadows K D, Keniston R C. Rehabilitation of carpal tunnel surgery patients using a short surgical incision and an early program of physical therapy. J Hand Surg [Am]. Nov. 1993;18(6):1044-50.
396 Okutsu I, Ninomiya S, Takatori Y, Hamanaka I, Genba K, Ugawa Y, Schonholtz G J, Okumura Y. Results of endoscopic management of carpal tunnel syndrome. Orthop Rev. Jan. 1993;22(1):81-7. [pmid: 8421638].
397 Palmer D H, Paulson J C, Lane-Larsen C L, Peulen V K, Olson J D. Endoscopic carpal tunnel release: a comparison of two techniques with open release. Arthroscopy. 1993;9(5):498-508. [pmid: 8280321].
398 Waegeneers S, Haentjens P, Wylock P. Operative treatment of carpal tunnel syndrome. Acta Orthop Belg. 1993;59(4):367-70. [pmid: 8116368].
399 Nolan W B 3d, Alkaitis D, Glickel S Z, Snow S. Results of treatment of severe carpal tunnel syndrome. J Hand Surg [Am]. Nov. 1992;17(6):1020-3.
400 Pagnanelli DM, Barrer SJ. Bilateral carpal tunnel release at one operation: report of 228 patients. Neurosurgery 1992 Dec;31(6):1030–3; discussion 1033–4.
401 Viegas S F, Pollard A, Kaminksi K. Carpal arch alteration and related clinical status after endoscopic carpal tunnel release. J Hand Surg [Am]. Nov. 1992;17(6):1012-6.
402 Young V L, Logan S E, Fernando B, Grasse P, Seaton M, Young A E. Grip strength before and after carpal tunnel decompression. South Med J. Sep. 1992;85(9):897-900. [pmid: 1523450].
403 Yu G Z, Firrell J C, Tsai T M. Pre-operative factors and treatment outcome following carpal tunnel release. J Hand Surg [Br]. Dec. 1992;17(6):646-50.
404 Flaschka G, Eder H, Mullegger G, Gindl H K. Follow-up results of surgery for carpal tunnel syndrome in local anesthesia. Zentralbl Neurochir. 1991;52(3):123-5. [pmid: 1796671].
405 Foucher G, Malizos C, Sammut D, Braun F M, Michon J. Primary palmaris longus transfer as an opponensplasty in carpal tunnel release. A series of 73 cases. J Hand Surg [Br]. Feb. 1991;16(1):56-60.
406 Jakab E, Ganos D, Cook F W. Transverse carpal ligament reconstruction in surgery for carpal tunnel syndrome: a new technique. J Hand Surg [Am]. Mar. 1991;16(2):202-6.
407 Mackinnon S E, McCabe S, Murray J F, Szalai J P, Kelly L, Novak C, Kin B, Burke G M. Internal neurolysis fails to improve the results of primary carpal tunnel decompression. J Hand Surg [Am]. Mar. 1991;16(2):211-8.
408 Resnick C T, Miller B W. Endoscopic carpal tunnel release using the subligamentous two-portal technique. Contemp Orthop. Mar. 1991;22(3):269-77. [pmid: 10147552].
409 Schuind F, Ventura M, Pasteels J L. Idiopathic carpal tunnel syndrome: histologic study of flexor tendon synovium. J Hand Surg [Am]. May. 1990;15(3):497-503.
410 Gellman H, Kan D, Gee V, Kuschner S H, Botte M J. Analysis of pinch and grip strength after carpal tunnel release. J Hand Surg [Am]. Sep. 1989;14(5):863-4.
411 Okutsu I, Ninomiya S, Takatori Y, Ugawa Y. Endoscopic management of carpal tunnel syndrome. Arthroscopy. 1989;5(1):11-8. [pmid: 2706046].
412 Richman J A, Gelberman R H, Rydevik B L, Hajek P C, Braun R M, Gylys-Morin V M, Berthoty D. Carpal tunnel syndrome: morphologic changes after release of the transverse carpal ligament. J Hand Surg [Am]. Sep. 1989;14(5):852-7.
413 Seiler J G 3d, Milek M A, Carpenter G K, Swiontkowski M F. Intraoperative assessment of median nerve blood flow during carpal tunnel release with laser Doppler flowmetry. J Hand Surg [Am]. Nov. 1989;14(6):986-91.
414 Seradge H, Seradge E. Piso-triquetral pain syndrome after carpal tunnel release. J Hand Surg [Am]. Sep. 1989;14(5):858-62.
415 Gelberman R H, Pfeffer G B, Galbraith R T, Szabo R M, Rydevik B, Dimick M. Results of treatment of severe carpal-tunnel syndrom without internal neurolysis of the median nerve. J Bone Joint Surg Am. Jul 1. 1987;69(6):896-903. [pmid: 3597503].
416 Holmgren H, Rabow L. Internal neurolysis or ligament division only in carpal tunnel syndrome.II A 3 year follow-up with an evaluation of various neurophysiological parameters for diagnosis. Acta Neurochir (Wien). Jan 1. 1987;87(12):44-7. [pmcid: 300905]. [pmid: 3673682].
417 Gartsman G M, Kovach J C, Crouch C C, Noble P C, Bennett J B. Carpal arch alteration after carpal tunnel release. J Hand Surg [Am]. May. 1986;11(3):372-4.
418 Kulick M I, Gordillo G, Javidi T, Kilgore E S Jr, Newmayer W L 3d. Long-term analysis of patients having surgical treatment for carpal tunnel syndrome. J Hand Surg [Am]. Jan. 1986;11(1):59-66.
419 Leblhuber F, Reisecker F, Witzmann A. Carpal tunnel syndrome: neurographical parameters in different stages of median nerve compression. Acta Neurochir (Wien). 1986;81(34):125-7. [pmcid: 300905]. [pmid: 3751695].
420 Shurr D G, Blair W F, Bassett G. Electromyographic changes after carpal tunnel release. J Hand Surg [Am]. Nov. 1986;11(6):876-80.
421 Wadstroem J, Nigst H. Reoperation for carpal tunnel syndrome. A retrospective analysis of forty cases. Ann Chir Main. 1986;5(1):54-8. [pmid: 3963906].
422 Rhoades C E, Mowery C A, Gelberman R H. Results of internal neurolysis of the median nerve for severe carpal-tunnel syndrome. J Bone Joint Surg Am. Feb. 1985;67(2):253-6. [pmid: 3968117].
423 Litchman H M, Silver C M, Simon S D, et al. Carpal tunnel release: efficacy as an ambulatory outpatient procedure done under local anesthesia. Orthop Rev. Mar. 1984;13(3):167-171.
424 Van Rossum J, Kamphuisen H A, Wintzen A R. Management in the carpal tunnel syndrome. Clinical and electromyographical follow-up in 62 patients. Clin Neurol Neurosurg. 1980;82(3):169-76. [pmid: 6260412].
425 Lascar T, Laulan J. Cubital tunnel syndrome: a retrospective review of 53 anterior subcutaneous transpositions. J Hand Surg [Br]. Oct. 2000;25B(5):453-456.
426 Freshwater M F, Arons M S. The effect of various adjuncts on the surgical treatment of carpal tunnel syndrome secondary to chronic tenosynovitis. Plast Reconstr Surg. Jan. 1978;61(1):93-6. [pmid: 339250].
427 Provinciali L, Giattini A, Splendiani G, Logullo F. Usefulness of hand rehabilitation after carpal tunnel surgery. Muscle Nerve. Feb. 2000;23(2):211-6. [pmid: 10639613].
428 Blair W F, Goetz D D, Ross M A, Steyers C M, Chang P. Carpal tunnel release with and without epineurotomy: a comparative prospective trial. J Hand Surg [Am]. Jul. 1996;21(4):655-61.
429 Lowry W E Jr, Follender A B. Interfascicular neurolysis in the severe carpal tunnel syndrome. A prospective, randomized, double-blind, controlled study. Clin Orthop. Feb. 1988;227:251-4. [pmid: 3276422].
430 Lee W P, Plancher K D, Strickland J W. Carpal tunnel release with a small palmar incision. Hand Clin. May. 1996;12(2):271-84. [pmid: 8724579].
431 Clarke A M, Stanley D. Prediction of the outcome 24 hours after carpal tunnel decompression. J Hand Surg [Br]. Apr. 1993;18(2):180-1.
432 Cook A C, Szabo R M, Birkholz S W, King E F. Early mobilization following carpal tunnel release. A prospective randomized study. J Hand Surg [Br]. Apr. 1995;20(2):228-30.
433 Holmgren-Larsson H, Leszniewski W, Linden U, Rabow L, Thorling J. Internal neurolysis or ligament division only in carpal tunnel syndrome - results of a randomized study. Acta Neurochir (Wien). 1985;74(34):118-21. [pmcid: 300905]. [pmid: 3885685].
434 Padua L, Padua R, Aprile I, Pasqualetti P, Tonali P. Multiperspective follow-up of untreated carpal tunnel syndrome: a multicenter study. Neurology. Jun 12. 2001;56(11):1459-66. [pmid: 11402101].
435 Todnem K, Lundemo G. Median nerve recovery in carpal tunnel syndrome. Muscle Nerve. Oct. 2000;23(10):1555-60. [pmid: 11003791].
436 Atherton W G, Faraj A A, Riddick A C, Davis T R. Follow-up after carpal tunnel decompression - general practitioner surgery or hand clinic? A randomized prospective study. J Hand Surg [Br]. Jun. 1999;24(3):296-7.
437 Bruser P, Richter M, Larkin G, Lefering R. The operative treatment of carpal tunnel syndrome and its relevance to endoscopic release. Eur J Plast Surg. 1999;22(23):80-84.
438 Thomas P, James D, Hulbert R, Kassak K M, Meyer J J. Comparative efficacy of conservative medical and chiropractic treatments for carpal tunnel syndrome: a randomized clinical trail. J Manipulative Physiol Ther. 1998;21:317-326. [pmid: 9627862].
439 Ebenbichler G R, Resch K L, Nicolakis P, Wiesinger G F, Uhl F, Ghanem A H, Fialka V. Ultrasound treatment for treating the carpal tunnel syndrome: randomised ‘sham’ controlled trial. BMJ. Mar 7. 1998;316(7133):731-5. [pmcid: 28476]. [pmid: 9529407].
440 Garfinkel M S, Singhal A, Katz W A, Allan D A, Reshetar R, Schumacher H R Jr. Yoga-based intervention for carpal tunnel syndrome: a randomized trial. JAMA. Nov 11. 1998;280(18):1601-3. [pmid: 9820263].
441 Braithwaite B D, Robinson G J, Burge P D. Haemostasis during carpal tunnel release under local anaesthesia: a controlled comparison of a tourniquet and adrenaline infiltration. J Hand Surg [Br]. Apr. 1993;18(2):184-6.
442 Jones S M, Stuart P R, Stothard J. Open carpal tunnel release. Does a vascularized hypothenar fat pad reduce wound tenderness?. J Hand Surg [Br]. Dec. 1997;22(6):758-60.
443 Monge L, De Mattei M, Dani F, Sciarretta A, Carta Q. Effect of treatment with an aldose-reductase inhibitor on symptomatic carpal tunnel syndrome in type 2 diabetes. Diabet Med. Dec. 1995;12(12):1097-101. [pmid: 8750220].
444 Bande S, De Smet L, Fabry G. The results of carpal tunnel release: open versus endoscopic technique. J Hand Surg [Br]. Feb. 1994;19(1):14-7.
445 Spooner G R, Desai H B, Angel J F, Reeder B A, Donat J R. Using pyridoxine to treat carpal tunnel syndrome. Randomized control trial. Can Fam Physician. Oct. 1993;39:2122-7. [pmid: 8219859].
446 Groves E J, Rider B A. A comparison of treatment approaches used after carpal tunnel release surgery. Am J Occup Ther. Jun. 1989;43(6):398-402. [pmid: 2741998].
447 Wolaniuk A, Vadhanavikit S, Folkers K. Electromyographic data differentiate patients with the carpal tunnel syndrome when double blindly treated with pyridoxine and placebo. Res Commun Chem Pathol Pharmacol. Sep. 1983;41(3):501-11. [pmid: 6635331].
448 McDonough J W, Gruenloh T J. A comparison of endoscopic and open carpal tunnel release. Wis Med J. Dec. 1993;92(12):675-7. [pmid: 8043070].
449 Concannon M J, Brownfield M L, Puckett C L. The incidence of recurrence after endoscopic carpal tunnel release. Plast Reconstr Surg. Apr. 2000;105(5):1662-5. [pmid: 10809095].
450 Povlsen B, Tegnell I, Revell M, Adolfsson L. Touch allodynia following endoscopic (single portal) or open decompression for carpal tunnel syndrome. J Hand Surg [Br]. 1997;22 B(3):325-327.
451 Rhoades C E, Mowery C A, Gelberman R H. Results on internal neurolysis of the median nerve for severe carpal-tunnel syndrome. J Bone Joint Surg Am. Feb 1. 1985;67(2):253-6. [pmid: 3968117].
452 Dammers J W, Veering M M, Vermeulen M. Injection with methylprednisolone proximal to the carpal tunnel: randomised double blind trial. BMJ. Oct 2. 1999;319(7214):884-6. [pmcid: 28242]. [pmid: 10506042].
453 Ozdogan H, Yazici H. The efficacy of local steroid injections in idiopathic carpal tunnel syndrome: a double-blind study. Br J Rheumatol. Nov. 1984;23(4):272-5. [pmid: 6487932].
454 O'Gradaigh D, Merry P. Corticosteroid injection for the treatment of carpal tunnel syndrome. Ann Rheum Dis. Nov. 2000;59(11):918-9. [pmid: 11053073]. [pmcid: 1753030].
455 Herskovitz S, Berger A R, Lipton R B. Low-dose, short-term oral prednisone in the treatment of carpal tunnel syndrome. Neurology. Oct. 1995;45(10):1923-5. [pmid: 7477994].
456 Wong S M, Hui A C, Tang A, Ho P C, Hung L K, Wong K S, Kay R, Li E. Local vs systemic corticosteroids in the treatment of carpal tunnel syndrome. Neurology. Jun 12. 2001;56(11):1565-7. [pmid: 11402116].
457 Tal-Akabi A, Rushton A. An investigation to compare the effectiveness of carpal bone mobilisation and neurodynamic mobilisation as methods of treatment for carpal tunnel syndrome. Man Ther. Nov. 2000;5(4):214-222. [pmid: 11052900].
458 Schmitt M, Vergnes P, Canarelli J P, Gaillard S, Daoud S, Dodat H, Lascombes P, Melin Y, Morisson-Lacombe G, Revillon Y. Evaluation of a hydrocolloid dressing. J Wound Care. Oct. 1996;5(9):396-9. [pmid: 8954432].
459 Stransky M, Rubin A, Lava N S, Lazaro R P. Treatment of carpal tunnel syndrome with vitamin B6: a double-blind study. South Med J. Jul. 1989;82(7):841-2. [pmid: 2749352].
460 Shin A Y, Perlman M, Shin P A, Garay A A. Disability outcomes in a worker's compensation population: surgical versus nonsurgical treatment of carpal tunnel syndrome. Am J Orthop. Mar. 2000;29(3):179-84. [pmid: 10746468].
461 Atroshi I, Johnsson R, Ornstein E. Patient satisfaction and return to work after endoscopic carpal tunnel surgery. J Hand Surg [Am]. Jan. 1998;23(1):58-65.
462 Katz J N, Lew R A, Bessette L, Punnett L, Fossel A H, Mooney N, Keller R B. Prevalence and predictors of long-term work disability due to carpal tunnel syndrome. Am J Ind Med. Jun. 1998;33(6):543-50. [pmid: 9582945].
463 DeStefano F, Nordstrom D L, Vierkant R A. Long-term symptom outcomes of carpal tunnel syndrome and its treatment. J Hand Surg [Am]. Mar. 1997;22(2):200-10.
464 Wulfhorst B, Schwanitz H J. Applied health-education in dermatology. Pravent Rehabil. 1996;71(9):680-4.
465 Bloem J J, Pradjarahardja M C, Vuursteen P J. The post-carpal tunnel syndrome. Causes and prevention. Neth J Surg. Apr. 1986;38(2):52-5. [pmid: 3714079].
466 Botte M J, von Schroeder H P, Abrams R A, Gellman H. Recurrent carpal tunnel syndrome. Hand Clin. Nov. 1996;12(4):731-43. [pmid: 8953292].
467 O'Malley M J, Evanoff M, Terrono A L, Millender L H. Factors that determine reexploration treatment of carpal tunnel syndrome. J Hand Surg [Am]. Jul. 1992;17(4):638-41.
468 Kern B C, Brock M, Rudolph K H, Logemann H. The recurrent carpal tunnel syndrome. Zentralbl Neurochir. 1993;54(2):80-3. [pmid: 8368039].
469 Furth H J, Holm M B, James A. Reinjury prevention follow-through for clients with cumulative trauma disorders. Am J Occup Ther. Oct. 1994;48(10):890-8. [pmid: 7825704].
470 Hinderer SR, Hinderer KA. Quantitative methods of evaluation. In: DeLisa JA, Gans BM, editors. Rehabilitation medicine: principles and practice. 2nd ed. Philadelphia (PA): J.B. Lippincott; 1993. p. 96–121.
471 Kirby RL. Impairment, disability, and handicap. In: Rehabilitation medicine: principles and practice. 2nd ed. Philadelphia (PA): JB Lippincott; 1993. p. 40–50.
472 Levack B, Rassmussen G L, Day S, Freeman M A. Range of movement poor index of hip function. Acta Orthop Scand. Feb. 1988;59(1):14-5. [pmid: 3354316].
473 Tinetti M E, Ginter S F. Identifying mobility dysfunctions in elderly patients. Standard neuromuscular examination or direct assessment?. JAMA. Feb 26. 1988;259(8):1190-3. [pmid: 3339820].
474 Gotay CC. Patient-reported assessments versus performance-based tests. In: Quality of life and pharmacoeconomics in clinical trials. 2nd ed. Philadelphia (PA): Lippincott-Raven Publishers; 1996. p. 413–20.
475 Ferry S, Pritchard T, Keenan J, Croft P, Silman A J. Is delayed nerve conduction associated with increased self-reported disability in individuals with hand symptoms? A population based study. J Rheumatol. Aug. 1998;25(8):1616-9. [pmid: 9712109].
476 Pransky G, Feuerstein M, Himmelstein J, Katz J N, Vickers-Lahti M. Measuring functional outcomes in work-related upper extremity disorders. Development and validation of the Upper Extremity Function Scale. J Occup Environ Med. Dec. 1997;39(12):1195-202. [pmid: 9429173].
477 Atroshi I, Johnsson R, Nouhan R, Crain G, McCabe S J. Use of outcome instruments to compare workers' compensation and non-workers' compensation carpal tunnel syndrome. J Hand Surg [Am]. Sep. 1997;22(5):882-8.
478 Ware J E Jr, Sherbourne C D. The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Med Care. Jun. 1992;30(6):473-83. [pmid: 1593914].
479 Pincus T, Summey J A, Soraci S A, Wallston K A, Hummon N P. Assessment of patient satisfaction in activities of daily living using a modified Stanford Health Assessment Questionnaire. Arthritis Rheum. Nov. 1983;26(11):1346-53. [pmid: 6639693].
480 Hunt S M, McEwen J, McKenna S P. Measuring health status: a new tool for clinicians and epidemiologists. J R Coll Gen Pract. Apr. 1985;35(273):185-8. [pmid: 3989783]. [pmcid: 1960139].
481 Sefcovic A D, Tuason E J, Asaad T J, Dawson A M, Lundberg T M, Moreau J E, Dale L M. Symptom severity, functional status, and preventive or palliative measures employed by hand therapists experiencing carpal tunnel syndrome. Work. 2000;14(2):137-44. [pmid: 12441529].
482 Katz J N, Keller R B, Simmons B P, Rogers W D, Bessette L, Fossel A H, Mooney N A. Maine Carpal Tunnel Study: outcomes of operative and nonoperative therapy for carpal tunnel syndrome in a community-based cohort [published erratum appears in J Hand Surg [Am] 1999 Jan;24(1):201]. J Hand Surg [Am]. Jul. 1998;23(4):697-710.
483 Atroshi I, Breidenbach W C, McCabe S J. Assessment of the carpal tunnel outcome instrument in patients with nerve-compression symptoms. J Hand Surg [Am]. Mar. 1997;22(2):222-7.
484 Amadio P C, Silverstein M D, Ilstrup D M, Schleck C D, Jensen L M. Outcome assessment for carpal tunnel surgery: the relative responsiveness of generic, arthritis-specific, disease-specific, and physical examination measures. J Hand Surg [Am]. May. 1996;21(3):338-46.
485 Valle J H, Mathers D M, Ramos-Remus C, Russell A S. Generic health instruments do not comprehensively capture patient perceived improvement in patients with carpal tunnel syndrome. J Rheumatol. 1999;26(5):1163-6. [pmid: 10332984].
486 Atroshi I, Gummesson C, Johnsson R, Sprinchorn A. Symptoms, disability, and quality of life in patients with carpal tunnel syndrome. J Hand Surg [Am]. Mar. 1999;24(2):398-404.
487 Bessette L, Sangha O, Kuntz K M, Keller R B, Lew R A, Fossel A H, Katz J N. Comparative responsiveness of generic versus disease-specific and weighted versus unweighted health status measures in carpal tunnel syndrome. Med Care. Apr. 1998;36(4):491-502. [pmid: 9544589].
488 Katz J N, Punnett L, Simmons B P, Fossel A H, Mooney N, Keller R B. Workers' compensation recipients with carpal tunnel syndrome: the validity of self-reported health measures. Am J Public Health. Jan. 1996;86(1):52-6. [pmid: 8561242]. [pmcid: 1380360].
489 Odusote K, Eisen A. An electrophysiological quantitation of the cubital tunnel syndrome. Can J Neurol Sci. Nov. 1979;6(4):403-10. [pmid: 543982].
490 Eisen A, Danon J. The mild cubital tunnel syndrome. Its natural history and indications for surgical intervention. Neurology. Jul. 1974;24(7):608-13. [pmid: 4858157].
491 Posner M A. Compressive neuropathies of the ulnar nerve at the elbow and wrist. Instr Course Lect. 2000;49:305-17. [pmid: 10829185].
492 MacLean I C. Carpal tunnel syndrome and cubital tunnel syndrome: The electrodiagnostic viewpoint. Med Probl Perform Art. JUN. 1993;8(2):41-5.
493 Okamoto M, Abe M, Shirai H, Ueda N. Diagnostic ultrasonography of the ulnar nerve in cubital tunnel syndrome. J Hand Surg [Br]. Oct. 2000;25B(5):499-502.
494 Rosenberg Z S, Beltran J, Cheung Y, Broker M. MR imaging of the elbow: normal variant and potential diagnostic pitfalls of the trochlear groove and cubital tunnel. AJR Am J Roentgenol. Feb. 1995;164(2):415-8. [pmid: 7839980].
495 Ellemann K, Nielsen K D, Poulsgaard L, Smith T. Vibrotactilometry as a diagnostic tool in ulnar nerve entrapment at the elbow. Scand J Plast Reconstr Surg Hand Surg. Mar. 1999;33(1):93-7. [pmid: 10207971].
496 Merlevede K, Theys P, van Hees J. Diagnosis of ulnar neuropathy: a new approach. Muscle Nerve. Apr. 2000;23(4):478-81. [pmid: 10716756].
497 Chiou H J, Chou Y H, Cheng S P, Hsu C C, Chan R C, Tiu C M, Teng M M, Chang C Y. Cubital tunnel syndrome: diagnosis by high-resolution ultrasonography. J Ultrasound Med. Oct. 1998;17(10):643-8. [pmid: 9771609].
498 Britz GW, Haynor DR, Kuntz C, Goodkin R, Gitter A, Maravilla K, Kliot M. Ulnar nerve entrapment at the elbow: correlation of magnetic resonance imaging, clinical, electrodiagnostic, and intraoperative findings. Neurosurgery 1996 Mar;38(3):458–65; discussion 465.
499 Kingery WS, Park KS, Wu PB, Date ES. Electromyographic motor Tinel's sign in ulnar mononeuropathies at the elbow. Am J Phys Med Rehabil 1995 Nov-Dec;74:419–26.
500 Novak C B, Lee G W, Mackinnon S E, Lay L. Provocative testing for cubital tunnel syndrome. J Hand Surg [Am]. Sep. 1994;19(5):817-20.
501 Uchida Y, Sugioka Y. The value of electrophysiological examination of the flexor carpi ulnaris muscle in the diagnosis of cubital tunnel syndrome. Electromyogr Clin Neurophysiol. Sep. 1993;33(6):369-73. [pmid: 8223337].
502 Robinson D, Aghasi M K, Halperin N. Medial epicondylectomy in cubital tunnel syndrome: an electrodiagnostic study. J Hand Surg [Br]. Jun. 1992;17(3):255-6.
503 Buehler MJ, Thayer DT. The elbow flexion test. A clinical test for the cubital tunnel syndrome. Clin Orthop 1988 Aug;(233):213–6.
504 Ring H, Costeff H, Solzi P. Criteria for preclinical diagnosis of the cubital tunnel syndrome. Electromyogr Clin Neurophysiol 1979 Sep-Oct;19(5):459–66.
505 Artico M, Pastore F S, Nucci F, Giuffre R. 290 surgical procedures for ulnar nerve entrapment at the elbow: physiopathology, clinical experience and results. Acta Neurochir (Wien). 2000;142(3):303-8. [pmcid: 300905]. [pmid: 10819261].
506 Caputo A E, Watson H K. Subcutaneous anterior transposition of the ulnar nerve for failed decompression of cubital tunnel syndrome. J Hand Surg [Am]. May. 2000;25(3):544-51.
507 Greenwald D, Moffitt M, Cooper B. Effective surgical treatment of cubital tunnel syndrome based on provocative clinical testing without electrodiagnostics. Plast Reconstr Surg 1999 Jul;104(1):215–8; quiz 219.
508 Tsai T M, Chen I C, Majd M E, Lim B H. Cubital tunnel release with endoscopic assistance: results of a new technique. J Hand Surg [Am]. Jan. 1999;24(1):21-9.
509 Asami A, Morisawa K, Tsuruta T. Functional outcome of anterior transposition of the vascularized ulnar nerve for cubital tunnel syndrome. J Hand Surg [Br]. Oct. 1998;23(5):613-6.
510 Seradge H, Owen W. Cubital tunnel release with medial epicondylectomy factors influencing the outcome. J Hand Surg [Am]. May. 1998;23(3):483-91.
511 Glowacki KA, Weiss AP. Anterior intramuscular transposition of the ulnar nerve for cubital tunnel syndrome. J Shoulder Elbow Surg 1997 Mar-Apr;6(2):89–96.
512 Nouhan R, Kleinert J M. Ulnar nerve decompression by transposing the nerve and Z-lengthening the flexor-pronator mass: clinical outcome. J Hand Surg [Am]. Jan. 1997;22(1):127-31.
513 Tada H, Hirayama T, Katsuki M, Habaguchi T. Long term results using a modified King's method for cubital tunnel syndrome. Clin Orthop 1997 Mar;(336):107–10.
514 Geutjens G G, Langstaff R J, Smith N J, Jefferson D, Howell C J, Barton N J. Medial epicondylectomy or ulnar-nerve transposition for ulnar neuropathy at the elbow?. J Bone Joint Surg Br. Sep. 1996;78B(5):777-9. [pmid: 8836069].
515 Steiner H H, von Haken M S, Steiner-Milz H G. Entrapment neuropathy at the cubital tunnel: simple decompression is the method of choice. Acta Neurochir (Wien). 1996;138(3):308-13. [pmcid: 300905]. [pmid: 8861700].
516 Messina A, Messina J C. Transposition of the ulnar nerve and its vascular bundle for the entrapment syndrome at the elbow. J Hand Surg [Br]. Oct. 1995;20(5):638-48.
517 Nathan P A, Keniston R C, Meadows K D. Outcome study of ulnar nerve compression at the elbow treated with simple decompression and an early programme of physical therapy. J Hand Surg [Br]. Oct. 1995;20(5):628-37.
518 Pasque C B, Rayan G M. Anterior submuscular transposition of the ulnar nerve for cubital tunnel syndrome. J Hand Surg [Br]. Aug. 1995;20(4):447-53.
519 Manske PR, Johnston R, Pruitt DL, Strecker WB. Ulnar nerve decompression at the cubital tunnel. Clin Orthop 1992 Jan;(274):231–7.
520 Barrios C, Ganoza C, de Pablos J, Canadell J. Posttraumatic ulnar neuropathy versus non-traumatic cubital tunnel syndrome: clinical features and response to surgery. Acta Neurochir (Wien). 1991;110(12):44-8. [pmcid: 300905]. [pmid: 1882718].
521 Froimson AI, Anouchi YS, Seitz WH, Winsberg DD. Ulnar nerve decompression with medial epicondylectomy for neuropathy at the elbow. Clin Orthop 1991 Apr;(265):200–6.
522 Rogers MR, Bergfield TG, Aulicino PL. The failed ulnar nerve transposition. Etiology and treatment. Clin Orthop 1991 Aug;(269):193–200.
523 Heithoff S J, Millender L H, Nalebuff E A, Petruska A J Jr. Medial epicondylectomy for the treatment of ulnar nerve compression at the elbow. J Hand Surg [Am]. Jan. 1990;15(1):22-9.
524 Goldberg B J, Light T R, Blair S J. Ulnar neuropathy at the elbow: results of medial epicondylectomy. J Hand Surg [Am]. Mar. 1989;14(2 Pt 1):182-8.
525 Janes PC, Mann RJ, Farnworth TK. Submuscular transposition of the ulnar nerve. Clin Orthop 1989 Jan;(238):225–32.
526 Kleinman W B, Bishop A T. Anterior intramuscular transposition of the ulnar nerve. J Hand Surg [Am]. Nov. 1989;14(6):972-9.
527 Friedman R J, Cochran T P. Anterior transposition for advanced ulnar neuropathy at the elbow. Surg Neurol. May. 1986;25(5):446-8. [pmid: 3961661].
528 Leffert R D. Anterior submuscular transposition of the ulnar nerves by the Learmonth technique. J Hand Surg [Am]. Mar. 1982;7(2):147-55.
529 Foster R J, Edshage S. Factors related to the outcome of surgically managed compressive ulnar neuropathy at the elbow level. J Hand Surg [Am]. Mar. 1981;6(2):181-92.
530 Chan R C, Paine K W, Varughese G. Ulnar neuropathy at the elbow: comparison of simple decompression and anterior transposition. Neurosurgery. Dec. 1980;7(6):545-50. [pmid: 7207750].
531 Craven P R Jr, Green D P. Cubital tunnel syndrome. Treatment by medial epicondylectomy. J Bone Joint Surg Am. Sep. 1980;62(6):986-9. [pmid: 7430188].
532 Eaton R G, Crowe J F, Parkes J C. Anterior transposition of the ulnar nerve using a non-compressing fasciodermal sling. J Bone Joint Surg Am. Jul. 1980;62(5):820-5. [pmid: 6248560].
533 Miller R G, Hummel E E. The cubital tunnel syndrome: treatment with simple decompression. Ann Neurol. Jun. 1980;7(6):567-9. [pmid: 7436361].
534 Antoniadis G, Richter HP. Pain after surgery for ulnar neuropathy at the elbow: a continuing challenge. Neurosurgery 1997 Sep;41(3):585–9; discussion 589–91.
535 Gabel G T, Amadio P C. Reoperation for failed decompression of the ulnar nerve in the region of the elbow. J Bone Joint Surg Am. Feb. 1990;72(2):213-9. [pmid: 2303507].
536 Torgerson WS. Theory and methods of scaling. New York (NY): John Wiley & Sons, Inc.; 1958. 460 p.
537 Campbell J B, Post K D, Morantz R A. A technique for relief of motor and sensory deficits occurring after anterior ulnar transposition. Technical note. J Neurosurg. Mar. 1974;40(3):405-9. [pmid: 4360492].
538 Mannerfelt L G. Studies on ulnar nerve compression neuropathies with a new computerised instrument - the intrins-o-meter. Scand J Plast Reconstr Surg Hand Surg. Sep. 1997;31(3):251-60. [pmid: 9299687].
539 Bimmler D, Meyer V E. Surgical treatment of the ulnar nerve entrapment neuropathy: submuscular anterior transposition or simple decompression of the ulnar nerve? Long-term results in 79 cases. Ann Chir Main Memb Super. 1996;15(3):148-57. [pmid: 8791977].
540 Martin C E, Schweitzer M E. MR imaging of epicondylitis. Skeletal Radiol. Mar. 1998;27(3):133-8. [pmid: 9554003].
541 Smith R W, Papadopolous E, Mani R, Cawley M I. Abnormal microvascular responses in a lateral epicondylitis. Br J Rheumatol. Dec. 1994;33(12):1166-8. [pmid: 8000748].
542 Binder A, Parr G, Thomas P P, Hazleman B. A clinical and thermographic study of lateral epicondylitis. Br J Rheumatol. May. 1983;22(2):77-81. [pmid: 6682688].
543 Pfahler M, Jessel C, Steinborn M, Refior H J. Magnetic resonance imaging in lateral epicondylitis of the elbow. Arch Orthop Trauma Surg. 1998;118(3):121-5. [pmid: 9932184].
544 Pienimaki T, Vanharanta H. Pain questionnaire, pain drawing and pressure pain thresholds in chronic lateral epicondylitis. Eur J Phys Med Rehabil. 1998;8(1):3-9.
545 De Smet L, Fabry G. Grip force reduction in patients with tennis elbow: influence of elbow position. J Hand Ther 1997 Jul-Sep;10(3):229–31.
546 Pienimaki T, Siira P, Vanharanta H. Muscle function of the hand, wrist and forearm in chronic lateral epicondylitis. Eur J Phys Med Rehabil. 1997;7(6):171-8.
547 Pienimaki T T, Kauranen K, Vanharanta H. Bilaterally decreased motor performance of arms in patients with chronic tennis elbow. Arch Phys Med Rehabil. Oct. 1997;78(10):1092-5. [pmid: 9339158].
548 Potter H G, Hannafin J A, Morwessel R M, DiCarlo E F, O'Brien S J, Altchek D W. Lateral epicondylitis: correlation of MR imaging, surgical, and histopathologic findings. Radiology. Jul. 1995;196(1):43-6. [pmid: 7784585].
549 Benjamin S J, Williams D A, Kalbfleisch J H, Gorman P W, Panus P C. Normalized forces and active range of motion in unilateral radial epicondylalgia (tennis elbow). J Orthop Sports Phys Ther. Nov. 1999;29(11):668-76. [pmid: 10575644].
550 Bauer J A, Murray R D. Electromyographic patterns of individuals suffering from lateral tennis elbow. J Electromyogr Kinesiol. Aug. 1999;9(4):245-52. [pmid: 10437977].
551 Hyland S, Nitschke J, Matyas T A. The extension-adduction test in chronic tennis elbow: soft tissue components and joint biomechanics. Aust J Physiother. 1990;36(3):147-153.
552 Grundberg AB, Dobson JF. Percutaneous release of the common extensor origin for tennis elbow. Clin Orthop 2000 Jul;(376):137–40.
553 Bankes M J, Jessop J H. Day-case simple extensor origin release for tennis elbow. Arch Orthop Trauma Surg. 1998;117(45):250-1. [pmid: 9581253].
554 Organ SW, Nirschl RP, Kraushaar BS, Guidi EJ. Salvage surgery for lateral tennis elbow. Am J Sports Med 1997 Nov-Dec;25(6):746–50.
555 Gabel G T, Morrey B F. Operative treatment of medical epicondylitis. Influence of concomitant ulnar neuropathy at the elbow. J Bone Joint Surg Am. Jul. 1995;77(7):1065-9. [pmid: 7608229].
556 Kurvers H, Verhaar J. The results of operative treatment of medial epicondylitis. J Bone Joint Surg Am. Sep. 1995;77(9):1374-9. [pmid: 7673289].
557 Ollivierre CO, Nirschl RP, Pettrone FA. Resection and repair for medial tennis elbow. A prospective analysis. Am J Sports Med 1995 Mar-Apr;23(2):214–21.
558 Newey M L, Patterson M H. Pain relief following tennis elbow release. J R Coll Surg Edinb. Feb. 1994;39(1):60-1. [pmid: 7515435].
559 Verhaar J, Walenkamp G, Kester A, van Mameren H, van der Linden T. Lateral extensor release for tennis elbow. A prospective long-term follow-up study. J Bone Joint Surg Am. Jul. 1993;75A(7):1034-43. [pmid: 8335663].
560 Wittenberg RH, Schaal S, Muhr G. Surgical treatment of persistent elbow epicondylitis. Clin Orthop 1992 May;(278):73–80.
561 Vangsness C T Jr, Jobe F W. Surgical treatment of medial epicondylitis. Results in 35 elbows. J Bone Joint Surg Br. May. 1991;73(3):409-11. [pmid: 1670439].
562 Tan P K, Lam K S, Tan S K. Results of modified Bosworth's operation for persistent or recurrent tennis elbow. Singapore Med J. Aug. 1989;30(4):359-62. [pmid: 2814538].
563 Goldberg EJ, Abraham E, Siegel I. The surgical treatment of chronic lateral humeral epicondylitis by common extensor release. Clin Orthop 1988 Aug;(233):208–12.
564 Chotigavanich C. Surgical treatment of tennis elbow. J Med Assoc Thai. Jun. 1986;69(6):301-8. [pmid: 3746141].
565 Calvert P T, Allum R L, Macpherson I S, Bentley G. Simple lateral release in treatment of tennis elbow. J R Soc Med. Nov. 1985;78(11):912-5. [pmid: 4067958]. [pmcid: 1289998].
566 Baumgard SH, Schwartz DR. Percutaneous release of the epicondylar muscles for humeral epicondylitis. Am J Sports Med 1982 Jul-Aug;10(4):233–6.
567 O'Neil J, Sarkar K, Uhthoff HK. A retrospective study of surgically treated cases of tennis elbow. Acta Orthop Belg 1980 Mar-Apr;46(2):189–96.
568 Rosen M J, Duffy F P, Miller E H, Kremchek E J. Tennis elbow syndrome: results of the ‘lateral release’ procedure. Ohio State Med J. Feb. 1980;76(2):103-9. [pmid: 7354959].
569 Simunovic Z, Trobonjaca T, Trobonjaca Z. Treatment of medial and lateral epicondylitis - tennis and golfer's elbow - with low level laser therapy: a multicenter double blind, placebo-controlled clinical study on 324 patients. J Clin Laser Med Surg. Jun. 1998;16(3):145-51. [pmid: 9743652].
570 Burton A K. Grip strength and forearm straps in tennis elbow. Br J Sports Med. Mar. 1985;19(1):37-8. [pmid: 3995227].
571 Heyse-Moore G H. Resistant tennis elbow. J Hand Surg [Br]. Feb. 1984;9(1):64-6.
572 Rosenthal M. The application of an extract of human placenta in the treatment of rheumatic affections. Int J Tissue React. 1982;4(2):147-51. [pmid: 6981593].
573 Day B H, Govindasamy N, Patnaik R. Corticosteroid injections in the treatment of tennis elbow. Practitioner. Mar. 1978;220(1317):459-62. [pmid: 347424].
574 Bailey R A, Brock B H. Hydrocortisone in tennis elbow - a controlled series. J R Soc Med. 1957;50:389-90.
575 Molsberger A, Hille E. The analgesic effect of acupuncture in chronic tennis elbow pain. Br J Rheumatol. Dec. 1994;33(12):1162-5. [pmid: 8000747].
576 Haker E, Lundeberg T. Acupuncture treatment in epicondylalgia: a comparative study of two acupuncture techniques. Clin J Pain. Sep. 1990;6(3):221-6. [pmid: 2135016].
577 Wuori J L, Overend T J, Kramer J F, MacDermid J. Strength and pain measures associated with lateral epicondylitis bracing. Arch Phys Med Rehabil. Jul. 1998;79(7):832-7. [pmid: 9685101].
578 Forbes A, Hopper D. The effect of counterforce bracing on grip strength in tennis players with painful elbows. Aust J Physiother. 1990;36(4):259-265.
579 Solveborn S A. Radial epicondylalgia (‘tennis elbow’): treatment with stretching or forearm band. A prospective study with long-term follow-up including range-of-motion measurements. Scand J Med Sci Sports. Aug. 1997;7(4):229-37. [pmid: 9241029].
580 Clements L G, Chow S. Effectiveness of a custom-made below elbow lateral counterforce splint in the treatment of lateral epicondylitis (tennis elbow). Can J Occup Ther. 1993;60(3):137-144.
581 Rompe J D, Hope C, Kullmer K, Heine J, Burger R. Analgesic effect of extracorporeal shock-wave therapy on chronic tennis elbow. J Bone Joint Surg Br. Mar. 1996;78B(2):233-7. [pmid: 8666632].
582 Rompe J D, Hopf C, Kullmer K, Heine J, Burger R, Nafe B. Low-energy extracorporal shock wave therapy for persistent tennis elbow. Int Orthop. 1996;20(1):23-7. [pmid: 8881885].
583 Akermark C, Crone H, Elsasser U, Forsskahl B. Glycosaminoglycan polysulfate injections in lateral humeral epicondylalgia: a placebo-controlled double-blind trial. Int J Sports Med. Apr. 1995;16(3):196-200. [pmid: 7649712].
584 Basford J R, Sheffield C G, Cieslak K R. Laser therapy: a randomized, controlled trial of the effects of low intensity Nd:YAG laser irradiation on lateral epicondylitis. Arch Phys Med Rehabil. Nov. 2000;81(11):1504-10. [pmid: 11083356].
585 Papadopoulos E S, Smith R W, Cawley M I, Mani R. Low-level laser therapy does not aid the management of tennis elbow. Clin Rehabil. 1996;10:9-11.
586 Krasheninnikoff M, Ellitsgaard N, Rogvi-Hansen B, Zeuthen A, Harder K, Larsen R, Gaardbo H. No effect of low power laser in lateral epicondylitis. Scand J Rheumatol. 1994;23(5):260-3. [pmid: 7973480].
587 Vasseljen O Jr, Hoeg N, Kjeldstad B, Johnsson A, Larsen S. Low level laser versus placebo in the treatment of tennis elbow. Scand J Rehabil Med. 1992;24(1):37-42. [pmid: 1604260].
588 Haker E, Lundeberg T. Is low-energy laser treatment effective in lateral epicondylalgia?. J Pain Symptom Manage. May. 1991;6(4):241-6. [pmid: 2030299].
589 Haker E H, Lundeberg T C. Lateral epicondylalgia: report of noneffective midlaser treatment. Arch Phys Med Rehabil. Nov. 1991;72(12):984-8. [pmid: 1953322].
590 Haker E, Lundeberg T. Laser treatment applied to acupuncture points in lateral humeral epicondylalgia. A double-blind study. Pain. Nov. 1990;43(2):243-7. [pmid: 2087335].
591 Vasseljen O. Low-level laser versus traditional physiotherapy in the treatment of tennis elbow. Physiotherapy. 1992;78:329-34.
592 Vicenzino B, Collins D, Wright A. The initial effects of a cervical spine manipulative physiotherapy treatment on the pain and dysfunction of lateral epicondylalgia. Pain. Nov. 1996;68(1):69-74. [pmid: 9252000].
593 Drechsler W I, Knarr J F, Snyder-Mackler L. A comparison of two treatment regimens for lateral epicondylitis: a randomized trial of clinical interventions. J Sport Rehabil. 1997;6(3):226-34.
594 Burton A K. A comparative trial of forearm strap and topical anti-inflammatory as adjuncts to manipulative therapy in tennis elbow. Man Med. 1988;3(4):141-143.
595 Labelle H, Guibert R. Efficacy of diclofenac in lateral epicondylitis of the elbow also treated with immobilization. The University of Montreal Orthopaedic Research Group. Arch Fam Med 1997 May-Jun;6(3):257–62.
596 Adelaar R S, Maddy L, Emroch K S. Diflunisal vs Naproxen in the management of mild to moderate pain associated with epicondylitis. Adv Ther. 1987;4:317-27.
597 Stull P A, Jokl P. Comparison of diflunisal and naproxen in the treatment of tennis elbow. Clin Ther. 1986;9(Suppl C):62-6. [pmid: 3548987].
598 Devereaux MD, Hazleman BL, Thomas PP. Chronic lateral humeral epicondylitis - a double-blind controlled assessment of pulsed electromagnetic field therapy. Clin Exp Rheumatol 1985 Oct-Dec;3(4):333–6.
599 Pienimaki T T, Tarvainen T K, Siira P T, Vanharanta H. Progressive strengthening and stretching exercises and ultrasound for chronic lateral epicondylitis. Physiotherapy. 1996;82(9):522-30.
600 Pienimaki T, Karinen P, Kemila T, Koivukangas P, Vanharanta H. Long-term follow-up of conservatively treated chronic tennis elbow patients. A prospective and retrospective analysis. Scand J Rehabil Med. Sep. 1998;30(3):159-66. [pmid: 9782543].
601 Stahl S, Kaufman T. The efficacy of an injection of steroids for medical epicondylitis. A prospective study of sixty elbows. J Bone Joint Surg Br. 1997;79-A:1648-1652.
602 Solveborn SA, Buch F, Mallmin H, Adalberth G. Cortisone injection with anesthetic additives for radial epicondylalgia (tennis elbow). Clin Orthop 1995 Jul;(316):99–105.
603 Price R, Sinclair H, Heinrich I, Gibson T. Local injection treatment of tennis elbow - hydrocortisone, triamcinolone and lignocaine compared. Br J Rheumatol. 1991;30(1):39-44. [pmid: 1991216].
604 Kivi P. The etiology and conservative treatment of humeral epicondylitis. Scand J Rehabil Med. 1982;15(1):37-41. [pmid: 6828831].
605 Clarke A K, Woodland J. Comparison of two steroid preparations used to treat tennis elbow, using the hypospray. Rheumatol Rehabil. Feb. 1975;14(1):47-9. [pmid: 1091959].
606 Halle J S, Franklin R J, Karalja B L. Comparison of four treatment approaches for lateral epicondylitis of the elbow. J Orthop Sports Phys Ther. 1986;8:62-9. [pmid: 18802239].
607 Verhaar J A, Walenkamp G H, van Mameren H, Kester A D, van der Linden A J. Local corticosteroid injection versus Cyriax-type physiotherapy for tennis elbow. J Bone Joint Surg Br. Jan. 1995;77B(1):128-32.
608 Brattberg G. Acupuncture therapy for tennis elbow. Pain. Jul. 1983;16(3):285-8. [pmid: 6888954].
609 Hay E M, Paterson S M, Lewis M, Hosie G, Croft P. Pragmatic randomised controlled trial of local corticosteroid injection and naproxen for treatment of lateral epicondylitis of elbow in primary care. BMJ. Oct 9. 1999;319(7215):964-8. [pmcid: 28251]. [pmid: 10514160].
610 Saartok T, Eriksson E. Randomized trial of oral naproxen or local injection of betamethasone in lateral epicondylitis of the humerus. Orthopedics. Feb. 1986;9(2):191-4. [pmid: 3515333].
611 Haker E, Lundeberg T. Elbow-band, splintage and steroids in lateral epicondylagia (tennis elbow). Pain Clin. 1993;6:103-12.
612 Johannsen F, Gam A, Hauschild B, Mathiesen B, Jensen L. Rebox: an adjunct in physical medicine?. Arch Phys Med Rehabil. Apr. 1993;74(4):438-40. [pmid: 8466428].
613 Percy E C, Carson J D. The use of DMSO in tennis elbow and rotator cuff tendonitis: a double-blind study. Med Sci Sports Exerc. 1981;13(4):215-9. [pmid: 6456396].
614 Demirtas R N, Oner C. The treatment of lateral epicondylitis by iontophoresis of sodium salicylate and sodium diclofenac. Clin Rehabil. Feb. 1998;12(1):23-9. [pmid: 9549022].
615 Schapira D, Linn S, Scharf Y. A placebo-controlled evaluation of diclofenac diethylamine salt in the treatment of lateral epicondylitis of the elbow. Curr Ther Res Clin Exp. 1991;49(2):162-168.
616 Burnham R, Gregg R, Healy P, Steadward R. The effectiveness of topical diclofenac for lateral epicondylitis. Clin J Sport Med. Apr. 1998;8(2):78-81. [pmid: 9641433].
617 Lundeberg T, Abrahamsson P, Haker E. A comparative study of continuous ultrasound, placebo ultrasound and rest in epicondylalgia. Scand J Rehabil Med. 1988;20(3):99-101. [pmid: 3187466].
618 Binder A, Hodge G, Greenwood A M, Hazleman B L, Page Thomas D P. Is therapeutic ultrasound effective in treating soft tissue lesions?. Br Med J (Clin Res Ed). Feb 16. 1985;290(6467):512-4. [pmid: 3918652].
619 Haker E, Lundeberg T. Pulsed ultrasound treatment in lateral epicondylalgia. Scand J Rehabil Med. 1991;23(3):115-8. [pmid: 1962154].
620 Holdsworth L K, Anderson D M. Effectiveness of ultrasound used with a hydrocortisone coupling medium or epicondylitis clasp to treat lateral epicondylitis: pilot study. Physiotherapy. 1993;79(1):19-25.
621 Stratford P W, Levy D R, Gauldie S, Miseferi D, Levy K. The evaluation of phonophoresis and friction massage as treatments for extensor carpi radialis tendinitis: a randomized controlled trial. Physiother Can. 1989;41:93-9.
622 van der Windt D A, van der Heijden G J, van den Berg S G, ter Riet G, de Winter A F, Bouter L M. Ultrasound therapy for musculoskeletal disorders: a systematic review. Pain. Jun. 1999;81(3):257-71. [pmid: 10431713].
623 Klaiman M D, Shrader J A, Danoff J V, Hicks J E, Pesce W J, Ferland J. Phonophoresis versus ultrasound in the treatment of common musculoskeletal conditions. Med Sci Sports Exerc. Sep. 1998;30(9):1349-55. [pmid: 9741602].
624 Harding WG 3d. Use and misuse of the tennis elbow strap. Phys Sportsmed 1992;20(8):65–8, 71–4.
625 Struijs PA, Smidt N, Arola H, Dijk van CN, Buchbinder R, Assendelft WJ. Orthotic devices for tennis elbow. In: Cochrane Library [Cochrane review online]. Issue 2.Oxford: Update Software;2001. [19 p]. Available: http://www.cochranelibrary.com.
626 Almekinders L C, Temple J D. Etiology, diagnosis, and treatment of tendonitis: an analysis of the literature. Med Sci Sports Exerc. 1998;30(8):1183-90. [pmid: 9710855].
627 NIH Consensus Development Panel on Acupuncture. Acupuncture. JAMA 1998 Nov 4;280(17):1518–24.
628 Seegenschmiedt M H, Keilholz L. Epicondylopathia humeri (EPH) and peritendinitis humeroscapularis (PHS): evaluation of radiation therapy long-term results and literature review. Radiother Oncol. Apr. 1998;47(1):17-28. [pmid: 9632288].
629 Gerberich S G, Priest J D. Treatment for lateral epicondylitis: variables related to recovery. Br J Sports Med. Dec. 1985;19(4):224-7. [pmid: 3879192].
630 Stratford P W, Levy D R, Gowland C. Evaluative properties of measures used to assess patients with lateral epicondylitis at the elbow. Physiother Can. 1993;45(3):160-4.
631 Stratford P, Levy D R, Gauldie S, et al. Extensor carpi radialis tendonitis: a validation of selected outcome measures. Physiother Can. 1987;39(4):250-5.
632 Overend TJ, Wuori-Fearn JL, Kramer JF, MacDermid JC. Reliability of a patient-rated forearm evaluation questionnaire for patients with lateral epicondylitis. J Hand Ther 1999 Jan-Mar;12(1):31–7.
633 Witt J, Pess G, Gelberman R H. Treatment of de Quervain tenosynovitis. A prospective study of the results of injection of steroids and immobilization in a splint. J Bone Joint Surg Am. Feb. 1991;73(2):219-22. [pmid: 1993717].
634 Yuasa K, Kiyoshige Y. Limited surgical treatment of de Quervain's disease: decompression of only the extensor pollicis brevis subcompartment. J Hand Surg [Am]. Sep. 1998;23(5):840-3.
635 Weiss A P, Akelman E, Tabatabai M. Treatment of de Quervain's disease. J Hand Surg [Am]. Jul. 1994;19(4):595-8.
636 Buch-Jaeger N, Stutzmann-Simon S, Jesel M, Foucher G, Schuhl J F. Clinical outcome after surgical carpal tunnel release. Main. 1998;3(3):195-202.
637 Chaudhry V, Clawson L L. Entrapment of motor nerves in motor neuron disease: does double crush occur?. J Neurol Neurosurg Psychiatry. Jan. 1997;62(1):71-6. [pmid: 9010403].
638 Richardson J K, Forman G M, Riley B. An electrophysiological exploration of the double crush hypothesis. Muscle Nerve. 1999;22(1):71-77. [pmid: 9883859].
639 Grundberg A B, Reagan D S. Compression syndromes in reflex sympathetic dystrophy. J Hand Surg [Am]. Jul. 1991;16(4):731-6.
640 Narakas A O. The role of thoracic outlet syndrome in the double crush syndrome. Ann Chir Main Memb Super. 1990;9(5):331-40. [pmid: 1705129].
641 Bursell J P, Little J W, Stiens S A. Electrodiagnosis in spinal cord injured persons with new weakness or sensory loss: central and peripheral etiologies. Arch Phys Med Rehabil. 1999;80(8):904-9. [pmid: 10453766].
642 Chung M S, Gong H S, Baek G H. Prevalence of Raynaud's phenomenon in patients with idiopathic carpal tunnel syndrome. J Bone Joint Surg Br. Nov. 1999;81(6):1017-9. [pmid: 10615978].
643 Baba H, Maezawa Y, Uchida K, Furusawa N, Wada M, Imura S, Kawahara N, Tomita K. Cervical myeloradiculopathy with entrapment neuropathy: a study based on the double-crush concept. Spinal Cord. Jun. 1998;36(6):399-404. [pmid: 9648195].
644 Morgan G, Wilbourn A J. Cervical radiculopathy and distal entrapment neuropathies: Double-crush syndromes?. Neurology. 1998;50(1):78-83. [pmid: 9443461].
645 Guzel R, Sarpel T, Dogan B, Kozanoglu E, Goncu K. Double crush syndrome: presentation of 5 cases. Ann Med Sci. 1997;6(1):57-60.
646 Moore L E, Wiesner S L. Hypnotically-induced vasodilation in the treatment of repetitive strain injuries. Am J Clin Hypn. Oct. 1996;39(2):97-104. [pmid: 8936710].
647 Lanzetta M, Foucher G. Association of Wartenberg's syndrome and De Quervain's disease: a series of 26 cases. Plast Reconstr Surg. Aug. 1995;96(2):408-12. [pmid: 7624415].
648 Nemchausky B A, Ubilluz R M. Upper extremity neuropathies in patients with spinal cord injuries. J Spinal Cord Med. Apr. 1995;18(2):95-7. [pmid: 7640979].
649 Sie I H, Waters R L, Adkins R H, Gellman H. Upper extremity pain in the postrehabilitation spinal cord injured patient. Arch Phys Med Rehabil. Jan. 1992;73(1):44-8. [pmid: 1729973].
650 Gonzalez F, Watson H K. Simultaneous carpal tunnel release and Dupuytren's fasciectomy. J Hand Surg [Br]. May. 1991;16(2):175-8.
651 Wood V E, Biondi J. Double-crush nerve compression in thoracic-outlet syndrome. J Bone Joint Surg Am. Jan. 1990;72(1):85-7. [pmid: 2295677].
652 Kerrigan J J, Bertoni J M, Jaeger S H. Ganglion cysts and carpal tunnel syndrome. J Hand Surg [Am]. 1988;13(5):763-765.
653 Osterman A L. The double crush syndrome. Orthop Clin North Am. Jan. 1988;19(1):147-55. [pmid: 3275922].
654 Eason S Y, Belsole R J, Greene T L. Carpal tunnel release: analysis of suboptimal results. Hand. Oct. 1985;10(3):365-9.
655 Hurst L C, Weissberg D, Carroll R E. The relationship of the double crush to carpal tunnel syndrome (an analysis of 1,000 cases of carpal tunnel syndrome). Hand. Jun. 1985;10(2):202-4. [pmid: 711004].
656 Bryar G E. Multiple nerve entrapments associated with carpal tunnel syndrome. A four year prospective study of 97 surgically treated patients. Int Angiol. 1984;3(2):165-7.
657 Massey E W, Riley T L, Pleet A B. Coexistent carpal tunnel syndrome and cervical radiculopathy (double crush syndrome). South Med J. 1981;74(8):957-959. [pmid: 7268500].
658 Nissenbaum M, Kleinert H E. Treatment considerations in carpal tunnel syndrome with coexistent Dupuytren's disease. J Hand Surg [Am]. Nov. 1980;5(6):544-7.
659 Reinoehl R, Coates J, Russell D, Engst A, et al. The computer dilemma: harming the helpers. Cancer Nurs. 1995;12(12):21-35.
660 Salazar P A, Knapp R K. Preferred and nonpreferred hand skill in performing four industrial tasks. Human Performance. 1996;9(1):65-75.
661 U.S. Census Bureau. Current Population Survey. Washington (DC): U.S. Census Bureau; 2000 Sep 13. Table HINC-01. Selected characteristics of households, by total money income in 1999. p. 10. Also available: http://www.ferret.bls.census.gov/macro/023000/hhinc/new01_001.htm.
662 U.S. Bureau of Labor Statistics. 1998 National occupational employment and wage estimates. Washington (DC): U.S. Bureau of Labor Statistics. 1998 Jan 1. Also available: http://www.stats.bls.gov/oes/national/oes_sale.htm.
663 Current Population Reports, Series P-23, No 28, Series P-60, No. 68. Washington (DC): Poverty and Health Statistics Branch/HHES Division, U.S. Bureau of the Census; 2000 Sep 26. : weighted average poverty thresholds for families of specified size 1959-1999. p. 4. Also available: http://www.census.gov/hhes/poverty/histpov/hstpov1.html. Table 1
664 March Current Population Survey. Washington (DC): Income Statistics Branch/HHES Division, U.S. Census Bureau; 2000 Oct 30. Table H-9: Type of household -- households (all races) by median and mean income 1980 to 1999. p. 5. Also available: http://www.census.gov/hhes/income/histinc/h09.html.