# Results

## Carpal Tunnel Syndrome

### Question #1: What are the most effective methods and approaches for the early identification and diagnosis of carpal tunnel syndrome?

Our response to this question is comprised of a subsection on early diagnosis and a subsection on studies of diagnosis of carpal tunnel syndrome, in general. These two subsections follow our evaluation of the internal validity and generalizability of the available relevant literature. Following these two subsections, is a subsection on screening.

The subsection on early diagnosis is the most direct answer to this question, and in it we examine all articles described by their authors as pertaining to early diagnosis of these conditions. However, there are only a few such articles, and we therefore expand our response to diagnosis in general on the grounds that a “good” diagnostic method may also be a “good” method for making an early diagnosis. Ultimately, though, this reasoning is inferential, and conclusive evidence about whether a “good” diagnostic method is also useful for making an early diagnosis can only be derived by studies that directly address this issue.

The evaluation the diagnostic tests we consider is, as with any such test, greatly complicated by the absence of an independent “gold standard” test for any of the upper extremity disorders we address . ^27^ With no independent reference standard whose results are definitive, clinical trials of diagnostic tests for these disorders generally report differences in test results between a group of patients believed to have the condition and a group believed not to have it. Because determinations of who has and does not have the disorder are imperfect (for example, persons who do not have CTS may have symptoms of another condition that mimics CTS), it is impossible for such studies to draw accurate conclusions on how well any test performs.

The definitions of the groups being compared in these studies can also affect results by introducing spectrum effects to the study population. Criteria for selecting patients withWRUEDs may result in inclusion of only clear-cut cases of the condition, thus excluding mild cases that would be harder to diagnose. Selection criteria for patients without WRUEDs may result in inclusion of only those in ideal health, excluding those with early-stage cases of an upper extremity disorder. Together, these spectrum effects amplify the differences that are found in these studies. Thus, their results may not be applicable to the population most likely to get a test in routine practice: persons in high risk groups or with questionable symptoms.

A variety of diagnostic modalities have been reported in the carpal tunnel syndrome literature, including clinical signs (Table 7), sensory tests (Table 8), nerve conduction studies (Table 9), and imaging tests (Table 10). Furthermore, within each testing modality, there are many specific tests and test variations, and there is little consensus about which tests are useful.

Table 7. Clinical Signs and Symptoms Used to Diagnose CTS

Test | Definition
Closed fist test ^101^ | The patient makes a fist. If the patient feels tingling within one minute, the test is positive.
Combined Phalen's and Durkan's test ^102^ | With the patient's elbow extended, the forearm in supination, and the wrist flexed to 60 degrees, the examiner uses one thumb to apply pressure over the carpal tunnel. If the patient feels tingling or numbness within 30 seconds, the test is positive.
Decreased muscle strength ^103^ | Maximum force exerted by the patient on a measurement device.
Durkan compression test ^104^ | This test is also called the carpal compression test. With the patient's wrist in a neutral position and the forearm supinated, the examiner uses his/her thumbs to compress the wrist at the median nerve. If the patient feels numbness or tingling within 30 seconds, the test is positive.
Flick test ^105^ | The patient is asked: “What do you do with your hands when your symptoms are at their worst?” If the patient shakes or flicks the hands, the test is positive.
Gilliat tourniquet test ^106^ | The examiner inflates a blood pressure monitor on the patient's arm proximal to the elbow. If the patient feels numbness or tingling within one minute, the test is positive.
Grip strength ^107^ | Force measured when patient squeezes a measurement device using the whole hand.
Hypesthesia ^103^ | Also called hypoesthesia. It refers to decreased sensitivity to touch.
Pain on VAS ^108^ | Pain as measured by a visual analog scale in which the patient rates the subjective degree of pain by placing a mark on a graphical bar.
Paresthesia in APB ^109^ | Tingling in the abductor pollicus brevis muscle of the hand.
Phalen's test ^28^ | This test is also called the wrist flexion test. The patient places both elbows on a horizontal surface with the forearms vertical, and allows the wrists to flex by gravity. If the patient feels numbness or tingling within one minute, the test is positive.
Pinch strength ^107^ | Force measured when patient squeezes a measurement device using the thumb and a finger
Symptoms measured systematically ^29^ | Any symptoms of carpal tunnel such as pain, tingling, or numbness, as measured by a questionnaire or a hand diagram.
Symptoms during ultrasound ^110^ | Whether the patient experiences carpal tunnel symptoms when the wrist is stimulated with an ultrasound transducer.
Reverse Phalen's test ^111^ | This test is also called the wrist extension test. The patient extends both wrists and fingers. If the patient feels numbness or tingling within two minutes, the test is positive.
Thenar atrophy ^103^ | The degree of wasting in the thenar muscle of the hand.
Thenar weakness ^31^ | The degree of weakness in the thenar muscle of the hand.
Tinel's test ^29^ | This test is also called Hoffman-Tinel's test. The examiner taps lightly on the medial aspect of the wrist. If the patient feels tingling, the test is positive.

Sources: Massy-Westrop ^112^ and ECRI review of clinical trial articles

Table 8. Sensory tests for Diagnosis of CTS

Test | Definition
Current perception ^113^ | Whether the patient's threshold for perception of electrical current is within normal limits.
Moving two-point discrimination ^107^ | The examiner touches two closely-spaced prongs to patient's fingers and moves them distally. The test is positive if the patient cannot discriminate the prongs when they are 4–6 millimeters apart.
Object identification ^114^ | The patient blindly feels wooden shapes and is asked to identify them.
Pinprick sensation ^109^ | Whether the patient has normal pinprick-induced sensation.
Pressure measurement ^115^ | Whether the patient's threshold for perception of pressure is within normal limits.
Ridge threshold ^116^ | The patient places an index finger on a circular disc that has a small ridge. If the patient's threshold for detection of the ridge is abnormal, the test is positive.
Semmes-Weinstein monofilament ^30^ | This test is also called the von Frey hairs test. The examiner touches the patient with a series of standardized nylon monofilaments, and records the smallest monofilament the patient can detect the presence of.
Static two-point discrimination ^31^ | The examiner touches two closely-spaced prongs to patient's fingers and holds them still. The test is positive if the patient cannot discriminate the prongs when they are 5 millimeters apart.
Temperature measurement ^117^ | Whether the patient's threshold for perception of temperature, heat pain or cold pain is within normal limits.
Tuning fork ^30^ | The examiner hits a metal tuning fork which vibrates, and the patient's threshold for detection of vibration is determined. If the threshold falls outside of normal limits, the test is positive.
Vibrometer ^118^ | An instrument vibrates at varying frequencies, and the patient's threshold for detection of vibration is determined. If the threshold falls outside of normal limits, the test is positive

Sources: Massy-Westrop ^112^ and ECRI review of clinical trial articles

Table 9. Definitions of Nerve Conduction Parameters

Test | Definition
Nerves tested
Median nerve | The central nerve that is believed to be impaired in carpal tunnel syndrome. It innervates the thumb, index, middle, and ring fingers.
Ulnar nerve | The nerve on the medial side of the arm that innervates the ring and little fingers. Some researchers compare median and ulnar nerve conduction tests to diagnose carpal tunnel syndrome.
Radial nerve | The nerve on the lateral side of the arm that innervates the thumb. Some researchers compare median and radial nerve conduction tests to diagnose CTS.
Motor or sensory | Whether the test assesses motor or sensory nerve function.
Orthodromic or antidromic | The relative placement of the stimulating and recording electrodes. If the stimulating electrode is distal to the recording electrode (i.e., the stimulator is further from the torso), the test is orthodromic. Conversely, if the stimulating electrode is proximal to the recording electrode, (i.e., the stimulator is closer to the torso), the test is antidromic. These terms apply to sensory tests but not to motor tests.
Electrode placement sites
Abductor pollicus brevis muscle (APB) | A muscle in the hand that is used to record median motor parameters.
Abductor digiti minimi (ADM) | A muscle in the hand that is used to record ulnar motor parameters.
Parameters Measured
Latency | The time in milliseconds (ms) between stimulation and recording of an electrical impulse.
Onset latency | The time in milliseconds (ms) between stimulation and recording of an electrical impulse when measured to the beginning of the action potential.
Peak latency | The time in milliseconds (ms) between stimulation and recording of an electrical impulse when measured to the largest amplitude of the action potential.
Velocity | Speed of nerve conduction in meters per second (m/s)
Amplitude | Size of the action potential in microvolts (uV)
Presence/absence | Whether the nerve action potential was recordable. In severe cases, some action potentials may not be recordable.
Inching test | A series of nerve conduction tests designed to locate specific areas of nerve slowing. It can be performed orthodromically or antidromically. Electrodes are placed in 9–12 locations which are each a small distance (e.g., 1 cm) apart. By stimulating a fixed site (e.g., the middle finger) and recording at several locations (e.g., 9 evenly-spaced locations along the wrist), researchers can measure the nerve latencies and velocities for each segment along the nerve.

Table 10. Imaging Modalities for the Diagnosis of CTS

Test | Definition
Film | Plain film radiograph (x-ray).
CT | Computed tomography scan. No articles reported use of obsolete (first- or second-generation CT scanners).
MRI | Magnetic resonance imaging scan. No articles reported use of obsolete or prototype MR scanners
Ultrasound | Ultrasonic imaging

Most clinical tests to diagnose CTS (Table 7) involve specific maneuvers that elicit pain, numbness, or tingling in the median-nerve portion of the wrist. For example, in Phalen's test, the patient places both elbows on a horizontal surface with the forearms vertical, and allows the wrists to flex by gravity. If the patient feels numbness or tingling within one minute, the test is positive. ^28^ In Tinel's test, the examiner taps lightly over the median nerve at the wrist. If the patient feels tingling, the test is considered positive. ^29^

Sensory tests for carpal tunnel syndrome (Table 8) typically involve measurement of a patient's threshold for detection of a sensory stimulus. For example, in the Semmes-Weinstein test, the examiner touches the patient with monofilaments, and the test is considered positive if the patient's sensitivity to the monofilaments falls outside normal limits. ^30^ Another example is the two-point discrimination test in which the examiner touches two closely-spaced prongs to the patient's fingers. The test is considered positive if the patient cannot discriminate the prongs when they are 5 millimeters apart. ^31^

Nerve conduction testing for carpal tunnel syndrome can involve several variables (Table 9). Electrodes are placed in two locations along a nerve; the nerve is stimulated from one electrode, and the impulse is recorded from the other electrode. Tests can be performed on either the median nerve, ulnar nerve, or radial nerve, and can assess either motor or sensory function. The placement of electrodes can be either orthodromic (in which stimulating electrodes are placed distal to recording electrodes) or antidromic (in which stimulating electrodes are placed proximal to recording electrodes). Furthermore, many aspects of the nerve impulse can be measured such as latency, amplitude, and velocity.

Some investigators compare two or more nerve conduction tests in an attempt to assist the diagnosis of CTS (e.g., compute a difference between two latencies). We refer to these comparisons as composite nerve conduction tests. One potential advantage of composite nerve conduction tests is that they can compare two measurements in the same individual, thereby controlling for the effect of age on single nerve conduction tests. ^97^

Imaging tests for carpal tunnel syndrome include radiography (conventional film x-ray), computed tomography (CT) scan, magnetic resonance imaging (MRI), and ultrasound. Using these methods, investigators attempt to measure the size of anatomical features such as the carpal tunnel or the median nerve. Radiologists may also look for qualitative signs of CTS, such as bowing of the flexor retinaculum or a flattened shape of the carpal tunnel. ^98^ CTS may also manifest itself through changes in the appearance of the image, such as changes MR signal intensity of the median nerve. One cannot generalize that CTS will always be represented by an increase in signal intensity, because the relative contrast of different tissues is a function of the specific MR pulse sequence used. ^99^ Within a given study, if the same pulse sequence is used, the effect on appearance of normal and abnormal tissue is expected to be consistent.

Many different measurements are possible from a single image. Some of them may be useful in diagnosis of CTS while others are of no use at all. Furthermore, radiologists may take several of these measurements into account when judging an image as positive or negative for CTS. When assessing imaging tests for CTS, one must be specific as to the particular image parameter or combination of parameters being used, and avoid generalization from effectiveness of one imaging measurement to effectiveness of another. Because they were so numerous, we did not tabulate all imaging measurements reported in clinical trial articles, but instead we tabulated the use of each imaging modality (x-ray, CT, MRI, or ultrasound).

Imaging tests, particularly film radiography, may be used to rule out other causes of hand and wrist symptoms, such as fractures or osteoarthritis ^100^ and thus may have a role in differential diagnosis of CTS, even if they are not themselves tests for CTS.

As noted above, the vast majority of CTS diagnostic trials compared groups of patients with known or suspected disorders and groups of healthy normal controls. Therefore it is worth summarizing the difficulties with such studies:

- Potential spectrum bias because the controls are required to be asymptomatic, and subjects with unrelated upper extremity disorders are excluded. In routine practice, the spectrum of negative cases is likely to include patients with abnormalities that might mimic the condition being tested for, thereby reducing test specificity and positive predictive value.
- Potential spectrum bias when severe or obvious cases are selected for in patient inclusion criteria, and patients with mild disorders are excluded. In routine practice, the spectrum of patients with CTS is likely to include mild cases that may not be detected by the diagnostic test, thereby reducing sensitivity and negative predictive value.
- The converse of the above spectrum bias, where inclusion criteria are designed to study patients with mild disorders. Studies of patients with only mild disease will underestimate test performance.
- Potential age bias arising from selection of young hospital or laboratory workers as controls rather than persons of the same ages as CTS sufferers. Where possible, we recorded mean ages of CTS and control groups in each study, and identified studies in which the mean ages of the groups differed by 5.0 years or more.

Potential sex bias arising from different sex distributions in the patient group and the control group. Where possible, we recorded the sex distributions of CTS and control groups in each study, and identified studies in which the percentage of females differed by 20 percentage points or more.

#### Evidence Base

Articles were included in this analysis if they reported counts of positive and negative test results for at least one test, and they included ten or more patients. Having sufficient data from each included study to complete the 2 × 2 diagnostic truth table is important, because sensitivity and specificity must be measured simultaneously, using the same diagnostic threshold. Otherwise, the threshold could be shifted to favor the reported statistic at the expense of the unreported one.

Not all of the articles we examined are addressed in this evidence report. However, data from the articles we did not address are provided in the evidence tables in the appendix. We included articles in these evidence tables, regardless of their level of reporting, if their authors described them as screening studies or studies on “early diagnosis” of CTS.

The evidence tables thus list 205 articles that met our a priori inclusion criteria. We subsequently excluded 16 of them. Each of these excluded articles is listed in Table 11 along with its reason for exclusion. Some articles were excluded for more than one reason, but only the first reason is listed in the table. Therefore, this table cannot be used to determine what percentage of the literature suffered a specific flaw. The reasons for exclusion of each study in the table were each confirmed by a second analyst. In case of disagreement, the study was not excluded.

Table 11. Excluded Studies

Author | Reason for Exclusion
Ikegaya ^119^ | Special patient population (dialysis)
Tackmann ^120^ | No diagnostic data
Jordan ^121^ | Reported only statistical significance of results
Sivri ^122^ | Special patient population (arthritis), only 2 cases of CTS
Stolp-Smith ^123^ | Special patient population (pregnant women), only 5 cases of CTS
Dlabalová ^124^ | All patients post-surgery for CTS
Lazaro ^125^ | All patients post-surgery for CTS
Nakamichi ^126^ | All patients post-surgery for CTS
Williams ^127^ | Discrepancies in reported results; 2 × 2 table could not be accurately reproduced by ECRI.
Mossman ^128^ | Published as letter rather than full paper; 2 × 2 table could not be accurately reproduced by ECRI.
Westerman ^129^ | Discrepancies in reported number of patients, unexplained exclusions of patients.
Herrick ^130^ | Combined results from CTS patients and patients with other conditions.
MacDermid ^131^ | Combined results from CTS patients and patients with other conditions.
Gerrning ^132^ | Combined results from CTS patients and patients with other conditions.
Byl ^133^ | Combined results from CTS patients and patients with other conditions.
Palmer ^134^ | Combined results from CTS patients and patients with other conditions.

After these exclusions, 189 articles remained for analysis, with a total of 38,087 participants in these studies. The majority of studies (110 or 58%) were conducted outside the United States, and almost all of the studies (184 or 97%) were done at a single center.

In order to be included in meta-analyses of diagnostic trial results, articles had to report sufficient data to permit calculation of sensitivity and specificity for the test in question. In other words, counts of positive and negative test results had to be reported, percentages had to be reported with sufficient data on numbers of patients and controls for us to recalculate the 2 × 2 table, or results for each individual patient had to be reported. Patient-level data were reported in 19 of the 189 articles, and counts for at least some patient groups were reported in 131. Only summary statistics (typically group means) were reported in 39 articles. Even though sensitivity and specificity were not reported in these articles, they were included in the analysis because they met other criteria, such as reporting “early diagnosis” of CTS or an intent to evaluate diagnostic tests in a screening population. In 129 of the articles (68%), it was possible to determine sensitivity and specificity for at least one test from the reported data; in 79 of the articles, the authors themselves reported sensitivity and specificity.

#### Internal Validity of Results

To evaluate the quality of this literature base, we determined what proportion of articles reported various details of study methods or results. Reporting of these details is necessary to verify the internal validity and generalizability of study results. Reporting of characteristics affecting the internal validity of the results (the degree to which the reported results reflect the true performance of the test in the conditions of the particular study) is summarized in Table 12; this table includes all 189 articles on CTS diagnosis that were abstracted into the database. Details of the studies eventually included in quantitative analyses are listed in Table 13.

Table 12. Summary of Study Characteristics Affecting Internal Validity

Study characteristic | Number of studies reporting (percentage) | Specifics (percentage)
Whether trial was funded by a for-profit institution | 24 (13%) | For-profit funding: 3 (2%)
| | No for-profit funding: 21 (11%)
Was selection of patients prospective or retrospective? | 75 (40%) | Prospective: 58 (28%)
| | Retrospective: 17 (9%)
Patient inclusion criteria | 185 (98%) | See Table 46
Patient exclusion criteria | 87 (46%) | See Table 46
Was sex distribution of patients reported? | 131 (69%) | ^a^Percentage female: 61.5%
Was the percentage of females in the patient group within 20 percentage points of the control group? | 89 (47%) | Yes: 65 (34%)
| | No, patients were = 20% more female: 21 (11%)
| | No, controls were =20% more female: 3 (2%)
Were patient ages reported? | 123 (65%) | ^a^Mean age 48.1 years
Was the mean patient age within 5 years of the mean control age? | 89 (47%) | Yes: 52 (28%)
| | No, patients were = 5 years older: 36 (19%)
| | No, controls were =5 years older: 1 (1%)
Was duration of patients' condition reported? | 18 (10%) | ^a, b^Mean duration 28.1 months
Were patient comorbidities reported? | 46 (24%) | NA
Was the test operator blinded? | 13 (7%) | Yes: 13 (7%)
Was the test reader blinded? | 23 (12%) | Yes: 23 (12%)
Were there multiple test readers? | 7 (4%) | 2 readers: 4 (2%)
| | 3 readers: 2 (1%)
| | 4 readers: 1 (1%)
What was the method for multiple test readers? | 4 (57% of studies reporting multiple readers) | Independent: 2 (1%)
| | Mean: 1 (1%)
| | Consensus: 1 (1%)
Was the test compared to an independent reference standard? | 38 (20%) | Yes: 38 (20%)
Were all patients given the test and the reference standard? | 28 (15%) | Yes: 28 (15%)

[underlined: Key]:

NA—not applicable

a Calculated on a per-patient basis (i.e., weighted by number of patients in each study reporting this characteristic)

b Studies reporting median duration ^109,^ ^136,^ ^137^ were excluded from calculation.

Table 13. Study Characteristics Affecting Internal Validity of Results

Article | Funded by for-profit institution? | Inclusion criteria reported? | Exclusion criteria reported | Method of diagnosis reported | Patient selection | Comorbidity reported | ^a^Percent female | Possible sex bias | ^a^Mean age | Possible age bias | ^a^Mean duration of condition | Test operator blinded | Test reader blinded | Multiple readers | Method for multiple readers | Independent reference standard | Were patients given both test and reference
Distal Motor Latency: Unspecified Diagnosis Patient Group
Rosén, 1993 ^138^ | NR | Yes | Yes | Yes | NR | NR | 75% | P | 41 | No | NR | NR | NR | NR | NR | No | No
Marin, 1983 ^139^ | NR | Yes | NR | NR | NR | NR | 86% | P | 49 | P | 13 | NR | NR | NR | NR | No | No
Kimura, 1979 ^140^ | NR | Yes | Yes | Yes | NR | NR | 75% | No | 48 | No | NR | NR | NR | NR | NR | No | No
Loong, 1972 ^141^ | NR | Yes | NR | NR | NR | NR | 100% | No | 43.7 | MNR | 12.7 | NR | NR | NR | NR | No | No
Plaja, 1971 ^142^ | NR | NR | Yes | NR | Retrospective | NR | NR | GNR | NR | MNR | NR | NR | NR | NR | NR | No | No
Distal Motor Latency: Symptoms/Presented Patient Groups
Murthy, 1999 ^143^ | NR | Yes | NR | Yes | NR | NR | NR | GNR | NR | ANR | NR | NR | NR | NR | NR | No | No
Atroshi, 1996 ^136^ | No | Yes | NR | NR | Prospective | Yes | 69% | No | 52 | P | 24 | NR | NR | NR | NR | No | No
Kuntzer, 1994 ^144^ | NR | Yes | Yes | NR | Prospective | NR | 80% | P | 51 | P | NR | NR | NR | NR | NR | No | No
Chang, 1991 ^145^ | NR | Yes | Yes | NR | NR | Yes | 79% | GNR | 42.3 | No | NR | NR | NR | NR | NR | No | No
Cioni, 1989 ^146^ | NR | Yes | Yes | NR | NR | NR | 16% | C | 46.4 | P | NR | NR | NR | NR | NR | No | No
Messina, 1980 ^120^ | NR | Yes | NR | NR | NR | NR | NR | GNR | 45.1 | No | NR | NR | NR | NR | NR | No | No
Melvin, 1972 ^147^ | NR | Yes | NR | NR | NR | NR | NR | GNR | NR | ANR | NR | NR | NR | NR | NR | No | No
Loong, 1971 ^148^ | NR | Yes | Yes | NR | NR | Yes | 100% | No | NR | ANR | 7.6 | NR | NR | NR | NR | No | No
Palmar Sensory Latency: Symptoms/Presented Patient Groups
Murthy, 1999 ^143^ | NR | Yes | NR | Yes | NR | NR | NR | GNR | NR | ANR | NR | NR | NR | NR | NR | No | No
Girlanda, 1998 ^149^ | NR | Yes | Yes | NR | NR | Yes | 93% | GNR | 39 | ANR | 48 | NR | NR | NR | NR | No | No
Chang, 1991 ^145^ | NR | Yes | Yes | NR | NR | Yes | 79% | GNR | 42.3 | No | NR | NR | NR | NR | NR | No | No
Jackson, 1989 ^150^ | No | Yes | Yes | NR | NR | Yes | 82% | No | 52.6 | P | NR | NR | NR | NR | NR | No | No
Escobar, 1985 ^151^ | NR | Yes | Yes | NR | NR | Yes | 70% | No | NR | ANR | NR | NR | NR | NR | NR | No | No
Phalen's Maneuver: All Patient Groups
Szabo, 1999 ^152^ | No | Yes | NR | Yes | Prospective | NR | 76% | No | NR | ANR | NR | NR | Yes | NR | NR | No | No
Fertl, 1998 ^153^ | NR | Yes | Yes | Yes | Prospective | NR | 83% | P | 55.5 | P | NR | Yes | Yes | NR | NR | No | No
Gerr, 1998 ^31^ | NR | Yes | Yes | Yes | NR | NR | 72% | No | 46.6 | P | NR | NR | NR | NR | NR | Yes | No
Ghavanini, 1998 ^154^ | NR | Yes | Yes | Yes | Prospective | NR | 81% | No | 40 | No | 15 | NR | NR | NR | NR | No | No
Tetro, 1998 ^102^ | No | Yes | Yes | Yes | Prospective | NR | 64% | No | 49.3 | No | NR | NR | NR | NR | NR | No | No
González del Pino, 1997 ^104^ | NR | Yes | NR | Yes | Prospective | NR | 81% | No | 50 | No | 37.9 | NR | NR | 3 | NR | Yes | Yes
De Smet, 1995 ^101^ | NR | Yes | NR | Yes | NR | NR | 88% | C | 49.2 | C | NR | NR | NR | NR | NR | No | No
Werner, 1994 ^111^ | NR | Yes | NR | Yes | NR | NR | NR | GNR | NR | ANR | NR | NR | NR | NR | NR | No | No
Durkan, 1991 ^155^ | No | Yes | NR | Yes | NR | NR | NR | GNR | 45 | ANR | NR | NR | NR | NR | NR | Yes | Yes
Gellman, 1986 ^106^ | No | Yes | NR | Yes | NR | Yes | 74% | GNR | NR | ANR | NR | NR | NR | NR | NR | Yes | Yes
Tinel's Sign: All Patient Groups
Szabo, 1999 ^152^ | No | Yes | NR | Yes | Prospective | NR | 76% | No | NR | ANR | NR | NR | Yes | NR | NR | No | No
Gerr, 1998 ^31^ | NR | Yes | Yes | Yes | NR | NR | 72% | No | 46.6 | P | NR | NR | NR | NR | NR | Yes | No
Ghavanini, 1998 ^154^ | NR | Yes | Yes | Yes | Prospective | NR | 81% | No | 40 | No | 15 | NR | NR | NR | NR | No | No
Tetro, 1998 ^102^ | No | Yes | Yes | Yes | Prospective | NR | 64% | No | 49.3 | No | NR | NR | NR | NR | NR | No | No
González del Pino, 1997 ^104^ | NR | Yes | NR | Yes | Prospective | NR | 81% | No | 50 | No | 37.9 | NR | NR | 3 | NR | Yes | Yes
De Smet, 1995 ^101^ | NR | Yes | NR | Yes | NR | NR | 88% | C | 49.2 | C | NR | NR | NR | NR | NR | No | No
Durkan, 1991 ^155^ | No | Yes | NR | Yes | NR | NR | 74% | GNR | 45 | ANR | NR | NR | NR | NR | NR | Yes | Yes
Seror, 1987 ^156^ | NR | Yes | Yes | Yes | NR | NR | 79% | No | 56.8 | No | NR | NR | NR | NR | NR | No | No
Gellman, 1986 ^106^ | No | Yes | NR | Yes | NR | Yes | NR | GNR | NR | ANR | NR | NR | NR | NR | NR | Yes | Yes
Gelmers, 1979 ^29^ | NR | Yes | Yes | Yes | NR | NR | 81% | No | 57 | No | NR | NR | NR | NR | NR | Yes | No
Stewart, 1978 ^157^ | NR | Yes | Yes | Yes | NR | Yes | 81% | No | 55 | No | NR | NR | NR | NR | NR | Yes | No

[underlined: Key:]

a Percent female, mean age, and mean duration of condition for CTS patients

Possible sex bias: No—proportion women in epicondylitis group within 20% of proportion of women in control group; P—Patients were more likely to be female; C—Controls were more likely to be female; GNR—Genders not reported for both groups; NC—Study did not contain a separate control group

Possible age bias: No—mean age of epicondylitis group within 5 years of mean age of control group; P—Patients were older than controls; C—Controls were older than patients; ANR—Ages not reported for both groups; NC—Study did not contain a separate control group

Method for multiple test readers: Indep—Independent

The design of most studies raised the possibility of age bias in which patients were markedly older than controls. Some nerve conduction measurements become slower as people age, ^97^ thus if patients are older than controls, the study will overestimate the effectiveness of some nerve conduction tests. For this analysis, we defined age bias as a difference of five years or more between the mean age of patients and the mean age of controls. If a study reported ages of more than one group of carpal tunnel patients or more than one group of controls, we used the ages that implied the least amount of age bias in the study. This conservative approach tends to underestimate the amount of age bias in the studies.

Of 189 carpal tunnel studies we examined, 35 did not include a separate control group and 65 failed to report mean or median ages for one or both groups. That left 89 studies for which we could determine whether there was an age bias. Of these 89 studies, 52 had no age bias according to our definition. In 36 studies, patients were five years or more older than controls, while in one study ^135^ , controls were five years or more older than patients. In only 12 articles were all patient groups within one year of the controls in mean age. This suggests that there is little use of age-matching to ensure that age bias does not affect results, even though it is known that results of some diagnostic tests are affected by age.

Figure 7 plots each study using the mean age of controls on the horizontal axis and the mean age of patients on the vertical axis. The solid diagonal line represents the points at which patients and controls had the same age. The dashed diagonal lines represent the points at which patients and controls were five years apart. The plot shows that patients tended to be older than controls. Whereas patients were older than controls in 76 studies, the reverse was true in only 11 studies (in the remaining two studies, the group means were the same).

Figure 7. Mean Ages of Patient and Control Groups in CTS Diagnostic Studies

A similar analysis was done for possible sex bias. We arbitrarily defined potential sex bias as a difference of 20 or more percentage points in the proportions of females in the patient group and in the control group. As with the age bias analysis, when a study had more than one carpal tunnel group or more than one control group, we used a conservative approach by selecting groups that minimized potential sex bias. This approach will underestimate the amount of potential sex bias.

Of 189 carpal tunnel diagnostic studies recorded in the database, 35 did not contain a separate control group, and 65 did not report the sex distribution for one or both of the CTS and control groups. There were 89 studies for which we could determine whether there was a sex bias. Note that these were not the same 89 studies for which we could determine age bias; 21 studies reported age but not sex, and 21 studies reported sex but not age.

Of these 89 studies, 65 did not meet our definition of possible sex bias. In 21 studies, the percentage of females in the CTS group was 20 or more percentage points higher than the control group. In 3 studies, the percentage of females in the CTS group was 20 or more percentage points lower than in the control group.

Figure 8 plots the sex distribution of each study, using the percentage of females in the control group on the horizontal axis and the percentage of females in patient group on the vertical axis. The plot shows that the percentage of females tended to be higher in patient groups than in control groups. The percentage of females in the patient group was greater than the percentage of females in the control group in 63 of the 89 studies. The reverse was true in only 13 studies. There were 13 studies in which the percentages were equal.

Figure 8. Sex Ratios of Patient and Control Groups in CTS Diagnostic Studies

We defined studies as sex-matched if the proportion of women in each patient groups differed two percentage points or less from the proportion of women in the control group. Using this definition, 20 of the 89 studies (22%) could be called sex-matched. To the extent that sex affects the diagnostic tests for CTS, there is a potential for sex bias in the results. Despite this possible bias, few studies controlled for differing proportions of men and women in their CTS and control groups. These differences, and age differences in patient and control group, are components of the evaluation of diagnostic clinical trial results.

Other study and patient characteristics that potentially affect diagnostic results are just as poorly reported in the clinical trial articles on CTS diagnosis. Patient inclusion criteria were reported in nearly all studies (98%), but exclusion criteria were reported in less than half (48%, Table 12). Lack of reporting does not necessarily mean that studies are free of selection bias. Patients' comorbidities were reported in only 24% of articles even though some may affect test results. Methods for evaluating the diagnostic tests were also rarely reported.

Blinding of test operators and readers to whether a subject was in the CTS or control group was reported in 7–12% of articles, and only 2 of the 29 articles included in our analyses (7%, Table 12). Blinding protects against the potential for intentional or unintentional bias in performing and interpreting the test. Groups of workers in the same hospital or university as the investigators were often used as a convenient source of asymptomatic control subjects. Without blinding, the persons evaluating those subjects would know that familiar persons from around the institution are likely to be controls who do not have CTS, and could consciously or unconsciously bias their findings toward the negative. While some studies may have used blinding without reporting it, one cannot assume that this is so.

Use of multiple readers was not widely reported, and where there were multiple readers reported, only 4 of 7 articles reported how they arrived at conclusions. This could affect the internal validity of the conclusions in studies where multiple readers interpreted each test and then met with each other to resolve their differences in interpretation. This practice can reduce interobserver variability and thus may overestimate the true performance of tests which normally are interpreted by just one person.

#### Generalizability

Reporting statistics on characteristics pertaining to the generalizability of each article's results on them are found in Table 14. Details of the studies in the quantitative analyses are reported in Table 15. Some of these characteristics, like age and sex, can affect both internal validity and generalizability. Even if a study is free of age bias (the ages of the control subjects are similar to the ages of the CTS patients), it is possible that the results may not be generalizable because the ages of the patients in a clinical trial of a test are different from the ages of patients encountered in routine use of the test.

Table 14. Summary of Study Characteristics Affecting Generalizability

Study characteristic | Number of studies reporting (percentage) | Specifics (percentage)
Years in which study was conducted | 39 (21%) | NA
Number of centers | 189 (100%) | Single: 184 (97%)
| | Multiple (<5): 4 (2%)
| | Multiple (>5): 1 (1%)
Country in which study was conducted | 189 (100%) | USA: 79 (42%)
| | Other: 110 (58%)
Patient inclusion criteria | 185 (98%) | See Table 46
Patient exclusion criteria | 87 (46%) | See Table 46
Were patient comorbidities reported? | 46 (24%) | NA
Was sex distribution of patients reported? | 131 (69%) | ^a^Percentage female: 61.5%
Were patient ages reported? | 123 (65%) | ^a^Mean age 48.1 years
Was duration of patients' condition reported? | 18 (10%) | ^a, b^Mean duration 28.1 months
Did all patients have previous conservative treatment? | 1 (1%) | Yes: 1 (1%)
Did any patients have previous surgical treatment? | 6 (3%) | Yes: 6 (3%)
Adequate reporting of study's source of patients | 29 (15%) | NA
Was there a potential selection bias for easy cases? | 58 (31%) | Yes: 58 (31%)
Was there a potential selection bias for hard cases? | 40 (21%) | Yes: 40 (21%)

[underlined: Key:]

NA—not applicable

a Calculated on a per-patient basis (i.e., weighted by number of patients in each study reporting this characteristic)

b Studies reporting median duration ^109,^ ^136,^ ^137^ excluded from calculation

Table 15. Study Characteristics Affecting Generalizability of Results

Article | Years in which trial was conducted | Number of centers | Country where trial was conducted | Are patient comorbidity reported? | Percent female | Mean age | Mean duration of condition | Did all patients have previous conservative treatment? | Did any patients have previous surgical treatment? | Source of patients adequately described and generalizable to broader clinical practice? | Potential selection bias for easy cases? | Potential selection bias for difficult cases?
Distal Motor Latency: Unspecified Diagnosis Patient Group
Rosén, 1993 ^138^ | 1986-1987 | Single | Sweden | No | 75% | 41 | NR | No | No | Yes | No | No
Marin, 1983 ^139^ | NR | Single | USA | No | 86% | 49 | 13 | No | No | No | Yes | No
Kimura, 1979 ^140^ | 1978 | Single | USA | No | 75% | 48 | NR | No | No | No | No | Yes
Loong, 1972 ^141^ | NR | Single | Singapore | No | 100% | 43.7 | 12.7 | No | No | No | No | No
Plaja, 1971 ^142^ | NR | Single | Spain | No | NR | NR | NR | No | No | No | Yes | No
Distal Motor Latency: Symptoms/Presented Patient Groups
Murthy, 1999 ^143^ | NR | Single | India | No | NR | NR | NR | No | No | No | Yes | No
Atroshi, 1996 ^136^ | NR | Single | Sweden | Yes | 69% | 52 | 24 | Yes | No | No | Yes | No
Kuntzer, 1994 ^144^ | NR | Single | Switzerland | No | 80% | 51 | NR | No | No | Yes | No | No
Chang, 1991 ^145^ | NR | Single | Taiwan | Yes | 79% | 42.3 | NR | No | No | No | No | No
Cioni, 1989 ^146^ | NR | Single | Italy | No | 16% | 46.4 | NR | No | No | No | No | No
Messina, 1980 ^120^ | NR | Single | Italy | No | NR | 45.1 | NR | No | No | No | No | No
Melvin, 1972 ^147^ | NR | Single | USA | No | NR | NR | NR | No | No | No | No | No
Loong, 1971 ^148^ | NR | Single | Singapore | Yes | 100% | NR | 7.6 | No | No | No | No | No
Palmar Sensory Latency: Symptoms/Presented Patient Groups
Murthy, 1999 ^143^ | NR | Single | India | No | NR | NR | NR | No | No | No | Yes | No
Girlanda, 1998 ^149^ | NR | Single | Italy | Yes | 93% | 39 | 48 | No | No | No | No | Yes
Chang, 1991 ^145^ | NR | Single | Taiwan | Yes | 79% | 42.3 | NR | No | No | No | No | No
Jackson, 1989 ^150^ | NR | Single | Canada | Yes | 82% | 52.6 | NR | No | No | No | No | No
Escobar, 1985 ^151^ | NR | Single | USA | Yes | 70% | NR | NR | No | No | No | No | No
Phalen's Maneuver: All Patient Groups
Szabo, 1999 ^152^ | 1993-1996 | Single | USA | No | 76% | NR | NR | No | No | No | No | No
Fertl, 1998 ^153^ | 1997 | Single | Austria | No | 83% | 55.5 | NR | No | No | Yes | No | No
Gerr, 1998 ^31^ | NR | Single | USA | No | 72% | 46.6 | NR | No | No | No | No | No
Ghavanini, 1998 ^154^ | NR | Single | Iran | No | 81% | 40 | 15 | No | No | No | No | No
Tetro, 1998 ^102^ | 1995-1997 | Single | USA | No | 64% | 49.3 | NR | No | No | Yes | No | No
González del Pino, 1997 ^104^ | 1992-1995 | Single | Spain | No | 81% | 50 | 37.9 | No | No | No | Yes | No
De Smet, 1995 ^101^ | NR | Single | Belgium | No | 88% | 49.2 | NR | No | No | No | No | No
Werner, 1994 ^111^ | NR | Single | USA | No | NR | NR | NR | No | No | No | No | No
Durkan, 1991 ^155^ | 1987-1990 | Single | USA | No | NR | 45 | NR | No | No | No | No | No
Gellman, 1986 ^106^ | 1982-1984 | Single | USA | Yes | 74% | NR | NR | No | No | No | Yes | No
Tinel's Sign: All Patient Groups
Szabo, 1999 ^152^ | 1993-1996 | Single | USA | No | 76% | NR | NR | No | No | No | No | No
Gerr, 1998 ^31^ | NR | Single | USA | No | 72% | 46.6 | NR | No | No | No | No | No
Ghavanini, 1998 ^154^ | NR | Single | Iran | No | 81% | 40 | 15 | No | No | No | No | No
Tetro, 1998 ^102^ | 1995-1997 | Single | USA | No | 64% | 49.3 | NR | No | No | Yes | No | No
González del Pino, 1997 ^104^ | 1992-1995 | Single | Spain | No | 81% | 50 | 37.9 | No | No | No | Yes | No
De Smet, 1995 ^101^ | NR | Single | Belgium | No | 88% | 49.2 | NR | No | No | No | No | No
Durkan, 1991 ^155^ | 1987-1990 | Single | USA | No | 74% | 45 | NR | No | No | No | No | No
Seror, 1987 ^156^ | NR | Single | France | No | 79% | 56.8 | NR | No | No | No | No | No
Gellman, 1986 ^106^ | 1982-1984 | Single | USA | Yes | NR | NR | NR | No | No | No | Yes | No
Gelmers, 1979 ^29^ | NR | Single | Netherlands | No | 81% | 57 | NR | No | No | No | Yes | No
Stewart, 1978 ^157^ | NR | Single | Canada | Yes | 81% | 55 | NR | No | No | No | Yes | No

[underlined: Key:]

NR—not reported

In this literature, reporting of patient comorbidities was particularly bad. Only 46 of the articles (24%) reported any comorbidities at all. Duration of patients' conditions was reported in only 18 studies (10%) even though this variable is an indicator of condition severity.

Ninety-eight CTS diagnostic articles (52%) reported patient selection criteria that had the potential to bias studies towards including more easy cases (e.g. including only cases of severe CTS) or more difficult cases to diagnose (e.g. including only cases where other diagnostic tests were equivocal). These criteria represent potential for bias but not conclusive proof of bias, thus we did not exclude such studies. Instead, we used potential selection bias in our analyses of homogeneity, by separately analyzing the homogeneity of studies with and without these potential biases. Generalizability of study results is also affected by the possible spectrum bias arising from study designs where patients with known CTS are compared to healthy volunteers, and the absence of a “gold standard” test for diagnosis of CTS.

Incomplete reporting of important study design and patient characteristics prevents one from ruling out selection biases and other confounding factors as the cause of clinical trial results. The quality of this evidence base is not sufficient to permit us to draw reliable conclusions from a single study. Meta-analysis and heterogeneity analysis can be used to try and identify the effects of these study variables on study results.

#### Studies of “Early Diagnosis”

Because there is no broad agreement among clinicians of what constitutes and “early” diagnosis of CTS, we accepted any studies so described by their authors as studies of early identification of the condition.

Eighteen studies proposed tests specifically for the early detection of CTS. Table 16 shows the patient selection criteria used in these studies and the authors' proposed methods for early detection. Eleven of the 18 studies (61%) selected patients who had mild CTS as defined by positive symptoms and normal results on commonly-performed nerve conduction tests. None of these eleven studies, however, agreed on the specific kinds of nerve conduction tests and appropriate thresholds.

Table 16. Articles Self-Described as "Early Diagnosis" of CTS

Article | Patient selection criteria relevant to early detection | Symptoms and normal NCS? | Authors's proposed method for early detection | Sensory NCS?
Seror, 2000 ^158^ | Symptoms, but normal needle examination, normal DML (<4 ms) and normal palm-to-wrist orthodromic SCV (>45 m/s). | | Orthodromic sensory inching test from the middle finger.
Girlanda, 1998 ^149^ | Symptoms, but no weakness, no muscle atrophy, and normal DML (<4 ms). | | Combination of nerve conduction tests:a) Difference between median and ulnar orthodromic SCV from ring finger to wrist, and b) Ratio of orthodromic SCV from middle finger to palm and orthodromic SCV from palm to wrist
Seror, 1998 ^159^ | Symptoms, but normal DML (<4 ms) and normal palm-to-wrist orthodromic SCV (>45 m/s). | | Orthodromic sensory inching test from the middle finger.
Terzis, 1998 ^162^ | Symptoms, but normal DML (<4.2 ms) | | Combination of orthodromic sensory nerve conduction tests from the ring finger.
Bronson, 1997 ^163^ | Symptoms, but normal DML (<4 ms) and normal needle examination. | | Comparison of DMLs using five different wrist positions. | □
Murata, 1996 ^164^ | Workers at risk | □ | Ratio of:a) Antidromic SCV from wrist to index finger, and b) Antidromic SCV from palm to index finger
Padua, 1996 ^165^ | Symptoms, but no signs of severe CTS (e.g., absent SNAP at the wrist). | | Ratio of:a) Orthodromic SCV from middle finger to palm, and b) Orthodromic SCV from palm to wrist
Young, 1995 ^166^ | Workers at risk | □ | Total score on a grading scale that included seven clinical signs, four symptoms, and DML ≥4.45 ms. | □
Johnson, 1993 ^167^ | Workers at risk | □ | Track changes in DML over time | □
Uncini, 1993 ^160^ | Symptoms, but normal DML (<4.2 ms) and normal SCV from index finger to wrist (>45 m/s) | | Difference between: a)Median orthodromic latency between ring finger and wrist, and b)Ulnar orthodromic latency between ring finger and wrist
Jetzer, 1991 ^168^ | Workers at risk | □ | Vibrometry | □
Luchetti, 1991 ^169^ | Symptoms, but normal motor function, sensory function, quantitative sensory examination, cutaneous trophism, DSL (NR), and DML (NR). | | Antidromic inching test to the middle finger
Charles, 1990 ^170^ | Clinical diagnosis of CTS by referring physician, and at least one of the following: a)DML ≥4.5 ms; b) Orthodromic SCV from index finger <45 m/s; c) Difference ≥0.5 ms between median and ulnar sensory antidromic latencies to the ring finger | □ | Difference between: a)Median antidromic latency between ring finger and wrist, and b) Ulnar antidromic latency between ring finger and wrist
Palliyath, 1990 ^171^ | Symptoms, but “very little electrophysiological changes on routine tests for CTS” (p 307). | | Duration of relative refractory period and absolute refractory period. | □
Cioni, 1989 ^146^ | Symptoms | □ | Orthodromic SCV from ring finger to wrist
Jackson, 1989 ^150^ | Symptoms. Patients were stratified into three groups, and one group represented mild CTS as defined by normal NCS (based on four tests) and normal needle examination. | | Combination of two nerve conduction tests: a)Difference between median and radial antidromic sensory latencies from wrist to thumb, and b) Difference between median and ulnar antidromic sensory latencies from wrist to ring finger
Uncini, 1989 ^161^ | Symptoms, but normal DML (≤4.2 ms) and SNAPs were present with normal amplitude. | | Difference between:a) Median orthodromic latency between ring finger and wrist, and b) Ulnar orthodromic latency between ring finger and wrist
Wongsam, 1983 ^172^ | Symptoms suggesting early CTS. | □ | Ratio of:a) Antidromic latency from wrist to middle fingerb) Antidromic latency from palm to middle finger

[underlined: Key:]

DML—Distal motor latency

DSL—Distal sensory latency

ms—Milliseconds

m/s—Meters per second

SCV—Sensory conduction velocity

SNAP—Sensory nerve action potential

NR—Not reported

Thirteen of the 18 studies (72%) proposed sensory nerve conduction test(s) for the early diagnosis of carpal tunnel syndrome. As with the selection criteria, however, there was little agreement regarding test specifics. Two studies by Seror ^158,^ ^159^ each proposed the orthodromic sensory inching test for the early detection of CTS. Two studies by Uncini ^160,^ ^161^ each proposed the difference between median and ulnar orthodromic sensory latencies from the ring finger for the early detection of CTS. None of the other nine studies of sensory nerve conduction proposed the same specific tests or combination of tests. Therefore, studies of the early detection of CTS utilize the same general categories of nerve conduction tests, but there is wide variability in the specific tests employed. Furthermore, there are insufficient studies of any specific test to permit meta-analysis for drawing conclusions on whether it is effective for early identification of CTS. For this reason, we proceed to examine diagnostic tests for carpal tunnel syndrome, in general.

#### “Diagnosis Studies”

Our evaluation of methods for diagnosing CTS is primarily meta-analytic. To identify diagnostic tests of CTS for which meta-analyses were appropriate, we performed several tabulations. These tabulations were restricted to studies that met each of the following three criteria: 1) Study included a carpal tunnel syndrome group; 2) Study included a normal group; 3) Study was not a screening study. There were 138 studies that met all of these criteria.

For each test, we determined the number of studies in each of four patient selection categories that reported the test. Within each of these four categories, we also determined the number of studies for which sensitivity and specificity could be derived (based on information provided in the article). These study counts appear in Table 17 through Table 21. The first number in each cell is the count of all studies in a category, and the second number in each cell is the subset of studies from which we could derive sensitivity and specificity. We coded a study as having derivable sensitivity/specificity if any of the tests in that study had derivable sensitivity and specificity. Because this was not necessarily true for all tests in a study, the table's counts for some tests may slightly overestimate the numbers of studies with derivable sensitivity and specificity.

Table 18. Numbers of Studies Reporting Sensory Tests Across Patient Selection Categories

Legend:
First entry in cell—Total number of articles
Second entry in cell— Number of articles with derivable sensitivity and specificity
Sensory test | Complex objective standard | Simple nerve conduction | Symptoms/ presented | Unspecified diagnosis
Object identification | 0, 0 | 0, 0 | 0, 0 | 1, 0
Pinprick sensation | 0, 0 | 0, 0 | 0, 0 | 1, 1
Pressure measurement | 0, 0 | 0, 0 | 1, 1 | 1, 0
Ridge threshold | 0, 0 | 0, 0 | 0, 0 | 1, 0
Semmes-Weinstein filament | 1, 1 | 0, 0 | 0, 0 | 4, 1
Temperature measurement | 0, 0 | 0, 0 | 1, 1 | 2, 1
Texture discrimination | 0, 0 | 0, 0 | 0, 0 | 1, 0
Tuning fork | 1, 1 | 0, 0 | 1, 1 | 0, 0
Two-point discrimination (moving or static) | 2, 2 | 0, 0 | 2, 2 | 1, 0
Vibrometer | 2, 2 | 0, 0 | 5, 5 | 1, 0

Table 20. Numbers of Studies Reporting Composite Nerve Conduction Tests Across Patient Selection Categories

Legend:
Blank cells—Not reported or not applicable
First entry in cell—Total number of articles
Second entry in cell—Number of articles with derivable sensitivity and specificity
Composite test type | | | | | Patient selection group
Nerve for test 1 | Nerve for test 2 | Motor or sensory | Unit of nerve test | Type composite | Complex objective standard | Simple nerve conduction | Symptoms/ presented | Unspecified diagnosis
Median | Median | Motor | Amplitude | Difference | 0, 0 | 0, 0 | 0, 0 | 1, 0
Median | Median | Motor | Amplitude | Ratio | 1, 1 | 0, 0 | 1, 0 | 0, 0
Median | Median | Motor | Latency | Difference | 0, 0 | 0, 0 | 2, 2 | 2, 2
Median | Median | Motor | Latency | Ratio | 0, 0 | 0, 0 | 0, 0 | 1, 1
Median | Median | Motor | Velocity | Difference | 1, 0 | 0, 0 | 0, 0 | 0, 0
Median | Median | Sensory | Amplitude | Difference | 1, 1 | 0, 0 | 2, 2 | 0, 0
Median | Median | Sensory | Amplitude | Ratio | 1, 1 | 0, 0 | 1, 0 | 1, 1
Median | Median | Sensory | Latency | Difference | 1, 1 | 0, 0 | 6, 5 | 1, 1
Median | Median | Sensory | Latency | Ratio | 0, 0 | 0, 0 | 0, 0 | 1, 1
Median | Median | Sensory | Velocity | Difference | 0, 0 | 0, 0 | 2, 2 | 1, 1
Median | Median | Sensory | Velocity | Ratio | 0, 0 | 0, 0 | 4, 4 | 2, 2
Median | Radial | Sensory | Latency | Difference | 1, 1 | 0, 0 | 3, 3 | 2, 0
Median | Radial | Sensory | Velocity | Difference | 0, 0 | 0, 0 | 0, 0 | 1, 1
Median | Radial | Sensory | Velocity | Ratio | 0, 0 | 0, 0 | 1, 1 | 0, 0
Median | Ulnar | Motor | Latency | Difference | 1, 1 | 2, 2 | 3, 3 | 5, 4
Median | Ulnar | Motor | Other | Difference | 1, 1 | 0, 0 | 0, 0 | 0, 0
Median | Ulnar | Sensory | Amplitude | Ratio | 0, 0 | 0, 0 | 2, 2 | 1, 1
Median | Ulnar | Sensory | Latency | Difference | 1, 1 | 1, 1 | 10, 9 | 5, 3
Median | Ulnar | Sensory | Velocity | Difference | 0, 0 | 0, 0 | 1, 1 | 1, 1
Median | Ulnar | Sensory | Velocity | Ratio | 0, 0 | 0, 0 | 1, 1 | 0, 0
Radial | Median | Sensory | Velocity | Ratio | 0, 0 | 0, 0 | 1, 1 | 0, 0
Radial | Radial | Sensory | Latency | Difference | 0, 0 | 0, 0 | 1, 0 | 0, 0
Ulnar | Median | Sensory | Velocity | Difference | 1, 0 | 0, 0 | 0, 0 | 0, 0
Ulnar | Median | Sensory | Velocity | Ratio | 0, 0 | 0, 0 | 1, 1 | 0, 0
| | | | Other Difference | 3, 1 | 0, 0 | 3, 3 | 1, 1
| | | | Other Ratio | 0, 0 | 0, 0 | 3, 2 | 1, 1
| | | | Other Composite | 5, 4 | 0, 0 | 9, 8 | 4, 2

Table 17. Numbers of Studies Reporting Signs/Symptoms Tests Across Patient Selection Categories

Legend:
First entry in cell—Total number of articles
Second entry in cell—Number of articles with derivable sensitivity and specificity
Sign/symptom | Complex objective standard | Simple nerve conduction | Symptoms/ presented | Unspecified diagnosis
Closed fist test | 0, 0 | 1, 1 | 1, 1 | 0, 0
Combined Phalen's/Durkan test | 1, 1 | 0, 0 | 0, 0 | 0, 0
Decreased muscle strength | 0, 0 | 0, 0 | 1, 1 | 0, 0
Durkan compression | 5, 5 | 1, 1 | 3, 3 | 1, 1
Flick sign | 0, 0 | 0, 0 | 0, 0 | 1, 1
Gilliat tourniquet | 1, 1 | 1, 1 | 1, 1 | 1, 1
Grip strength | 0, 0 | 0, 0 | 0, 0 | 1, 0
Hypesthesia | 0, 0 | 0, 0 | 1, 1 | 0, 0
Pain on VAS | 0, 0 | 0, 0 | 1, 1 | 1, 1
Paresthesia in APB | 0, 0 | 0, 0 | 0, 0 | 1, 1
Phalen's/reverse Phalen's | 7, 7 | 2, 1 | 6, 6 | 3, 3
Pinch strength | 0, 0 | 0, 0 | 0, 0 | 1, 0
Symptoms measured systematically | 3, 3 | 0, 0 | 2, 2 | 1, 0
Symptoms during ultrasound | 0, 0 | 0, 0 | 1, 1 | 0, 0
Thenar atrophy | 0, 0 | 0, 0 | 2, 2 | 0, 0
Thenar weakness | 0, 0 | 0, 0 | 1, 1 | 0, 0
Tinel's | 9, 9 | 2, 1 | 3, 3 | 2, 2

Table 21. Numbers of Articles Reporting Imaging Tests in Patient Selection Categories

Legend:
First entry in cell—Total number of articles
Second entry in cell—Number of articles with derivable sensitivity and specificity
Imaging test | Complex objective standard | Simple nerve conduction | Symptoms/presented | Unspecified diagnosis
CT | 0, 0 | 0, 0 | 0, 0 | 2, 0
MRI | 2, 0 | 2, 0 | 1, 1 | 5, 2
Ultrasound | 1, 0 | 1, 0 | 1, 0 | 3, 3

As an initial criterion for conducting meta-analyses, we required that a minimum of 10 studies that reported a specific test in a specific population had derivable sensitivity and specificity. In other words, the second number in the table cell was required to be 10 or more. We adopted this criterion to ensure that our analysis would focus on the diagnostic tests that are the subject of greatest research interest. When there was a minimum of 10 articles, we proceeded with a meta-analysis even if one or more articles were subsequently excluded because it did not report sensitivity and specificity for the particular test being analyzed (or for other reasons discussed below).

Three combinations of test and patient population (see shaded cells in Table 19) met the a priori analysis criterion of at least 10 articles reporting the test and reporting results in sufficient detail that sensitivity and specificity could be calculated. The table entries on level of reporting are based on the highest level for any test reported in the article, and all tests reported were not necessarily reported at the highest level. This was especially true for studies reporting distal motor latency. It may be the case that some investigators reported only summary data for distal motor latency because it was considered a more of a routine test than other reported tests.

Table 19. Numbers of Studies Reporting Nerve Conduction Tests Across Patient Selection Categories

Legend: Nerve tested: MED-median, RAD-radial, ULN-ulnar, MOT-motor, SEN-sensory
Configuration (not applicable to motor nerve tests): OR-orthodromic, AN-antidromic
Stimulation electrode placement: ELB-elbow, FOR-forearm, WR-wrist, PAL-palm, TH-thumb, IN-index finger, MI-middle finger, RI-ring finger, LI-little finger, APB-abductor policis brevis, ADM-abductor digiti minimi, OTH-other
Recording electrode placement (see D for abbreviations)
Measured parameter: LAT-latency, PRE-presence/absence of signal, AMP-amplitude, VEL-velocity, INCH-inching, OTH-other
Blank cells—Not reported or not applicable
First entry in cell—Total number of articles
Second entry in cell—Number of articles with derivable sensitivity and specificity
Shaded cells—Ten or more articles reporting sensitivity and specificity.
Nerve Conduction Test | | | | | | Patient selection type
Nerve Tested | Nerve Tested | Configuration | Stimulation | Recording | Parameter | Complex objective standard | Simple nerve conduction | Symptoms/ presented | Unspecified diagnosis
| MOT | | | | LAT | 1, 1 | 0, 0 | 0, 0 | 1, 1
| MOT | | WR | OTH | LAT | 0, 0 | 0, 0 | 0, 0 | 1, 1
| SEN | | | | LAT | 1, 1 | 0, 0 | 0, 0 | 1, 1
| SEN | OR | TH | WR | PRE | 0, 0 | 0, 0 | 1, 1 | 0, 0
MED | | | | | OTH | 0, 0 | 0, 0 | 2, 2 | 0, 0
MED | MOT | | | | | 0, 0 | 0, 0 | 0, 0 | 1, 0
MED | MOT | | | | AMP | 0, 0 | 1, 0 | 0, 0 | 0, 0
MED | MOT | | | | LAT | 2, 1 | 1, 0 | 2, 2 | 2, 1
MED | MOT | | | | OTH | 1, 1 | 1, 0 | 2, 1 | 0, 0
MED | MOT | | | | VEL | 0, 0 | 1, 0 | 1, 1 | 1, 0
MED | MOT | | | APB | AMP | 1, 1 | 0, 0 | 0, 0 | 0, 0
MED | MOT | | | APB | LAT | 1, 1 | 0, 0 | 0, 0 | 0, 0
MED | MOT | | ELB | APB | AMP | 1, 0 | 0, 0 | 1, 1 | 1, 1
MED | MOT | | ELB | APB | LAT | 1, 1 | 0, 0 | 0, 0 | 1, 1
MED | MOT | | ELB | APB | OTH | 1, 1 | 0, 0 | 1, 1 | 0, 0
MED | MOT | | ELB | APB | VEL | 1, 0 | 0, 0 | 1, 1 | 2, 2
MED | MOT | | ELB | IN | AMP | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | MOT | | ELB | IN | LAT | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | MOT | | ELB | IN | VEL | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | MOT | | ELB | WR | AMP | 1, 0 | 0, 0 | 0, 0 | 0, 0
MED | MOT | | ELB | WR | LAT | 0, 0 | 0, 0 | 0, 0 | 0, 0
MED | MOT | | ELB | WR | VEL | 2, 1 | 0, 0 | 3, 3 | 1, 1
MED | MOT | | FOR | | VEL | 1, 1 | 0, 0 | 0, 0 | 1, 1
MED | MOT | | FOR | APB | AMP | 1, 1 | 0, 0 | 0, 0 | 0, 0
MED | MOT | | FOR | APB | LAT | 1, 1 | 0, 0 | 0, 0 | 0, 0
MED | MOT | | FOR | APB | VEL | 0, 0 | 0, 0 | 1, 1 | 0, 0
MED | MOT | | FOR | PAL | AMP | 1, 1 | 0, 0 | 0, 0 | 0, 0
MED | MOT | | FOR | PAL | LAT | 1, 1 | 0, 0 | 0, 0 | 0, 0
MED | MOT | | FOR | WR | VEL | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | MOT | | PAL | APB | AMP | 1, 1 | 0, 0 | 1, 0 | 2, 1
MED | MOT | | PAL | APB | LAT | 0, 0 | 0, 0 | 0, 0 | 2, 1
MED | MOT | | PAL | IN | AMP | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | MOT | | PAL | IN | LAT | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | MOT | | PAL | IN | VEL | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | MOT | | WR | | AMP | 0, 0 | 0, 0 | 1, 1 | 0, 0
MED | MOT | | WR | | LAT | 2, 2 | 1, 0 | 1, 1 | 0, 0
MED | MOT | | WR | | PRE | 1, 1 | 0, 0 | 0, 0 | 0, 0
MED | MOT | | WR | | VEL | 1, 1 | 0, 0 | 0, 0 | 0, 0
MED | MOT | | WR | APB | AMP | 2, 1 | 0, 0 | 9, 7 | 9, 6
MED | MOT | | WR | APB | LAT | 4, 4 | 3, 2 | 21, 17 | 24, 21
MED | MOT | | WR | APB | OTH | 2, 1 | 1, 0 | 1, 1 | 2, 2
MED | MOT | | WR | APB | PRE | 0, 0 | 0, 0 | 3, 3 | 1, 1
MED | MOT | | WR | APB | VEL | 0, 0 | 0, 0 | 2, 1 | 5, 5
MED | MOT | | WR | IN | AMP | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | MOT | | WR | IN | LAT | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | MOT | | WR | IN | VEL | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | MOT | | WR | OTH | AMP | 1, 0 | 0, 0 | 1, 1 | 1, 1
MED | MOT | | WR | OTH | LAT | 1, 1 | 1, 1 | 8, 8 | 3, 3
MED | MOT | | WR | OTH | OTH | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | MOT | | WR | OTH | VEL | 1, 0 | 0, 0 | 1, 1 | 0, 0
MED | MOT | | WR | PAL | AMP | 0, 0 | 0, 0 | 1, 1 | 0, 0
MED | MOT | | WR | PAL | LAT | 0, 0 | 0, 0 | 1, 1 | 0, 0
MED | MOT | | WR | PAL | OTH | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | MOT | | WR | PAL | VEL | 0, 0 | 0, 0 | 1, 0 | 0, 0
MED | MOT | | WR | TH | LAT | 0, 0 | 0, 0 | 2, 0 | 0, 0
MED | MOT | | WR | TH | VEL | 0, 0 | 0, 0 | 1, 1 | 0, 0
MED | SEN | | | | | 0, 0 | 0, 0 | 0, 0 | 1, 0
MED | SEN | | | | LAT | 3, 2 | 0, 0 | 0, 0 | 1, 0
MED | SEN | | | | OTH | 0, 0 | 0, 0 | 1, 0 | 1, 0
MED | SEN | | | | VEL | 0, 0 | 1, 0 | 0, 0 | 0, 0
MED | SEN | | WR | | AMP | 1, 1 | 0, 0 | 0, 0 | 0, 0
MED | SEN | | WR | | LAT | 1, 1 | 0, 0 | 0, 0 | 0, 0
MED | SEN | AN | | | AMP | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | AN | | | LAT | 1, 1 | 0, 0 | 1, 1 | 1, 1
MED | SEN | AN | | | VEL | 1, 1 | 0, 0 | 1, 1 | 0, 0
MED | SEN | AN | ELB | IN | AMP | 0, 0 | 0, 0 | 1, 1 | 0, 0
MED | SEN | AN | ELB | IN | OTH | 0, 0 | 0, 0 | 1, 1 | 0, 0
MED | SEN | AN | ELB | MI | VEL | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | AN | ELB | PAL | INCH | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | AN | ELB | WR | VEL | 0, 0 | 0, 0 | 2, 2 | 1, 1
MED | SEN | AN | FOR | IN | LAT | 0, 0 | 0, 0 | 1, 0 | 0, 0
MED | SEN | AN | FOR | RI | LAT | 0, 0 | 0, 0 | 1, 0 | 0, 0
MED | SEN | AN | FOR | TH | LAT | 0, 0 | 0, 0 | 1, 0 | 0, 0
MED | SEN | AN | PAL | IN | AMP | 1, 1 | 0, 0 | 2, 1 | 0, 0
MED | SEN | AN | PAL | IN | LAT | 0, 0 | 0, 0 | 1, 1 | 0, 0
MED | SEN | AN | PAL | IN | PRE | 1, 1 | 0, 0 | 0, 0 | 0, 0
MED | SEN | AN | PAL | IN | VEL | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | AN | PAL | MI | | 0, 0 | 0, 0 | 1, 0 | 0, 0
MED | SEN | AN | PAL | MI | AMP | 0, 0 | 0, 0 | 2, 1 | 0, 0
MED | SEN | AN | PAL | MI | LAT | 0, 0 | 0, 0 | 2, 1 | 0, 0
MED | SEN | AN | PAL | MI | OTH | 0, 0 | 0, 0 | 1, 1 | 0, 0
MED | SEN | AN | PAL | MI | VEL | 0, 0 | 0, 0 | 1, 1 | 2, 2
MED | SEN | AN | WR | | LAT | 0, 0 | 0, 0 | 1, 1 | 0, 0
MED | SEN | AN | WR | IN | AMP | 3, 2 | 0, 0 | 6, 5 | 5, 4
MED | SEN | AN | WR | IN | LAT | 1, 1 | 0, 0 | 11, 9 | 5, 3
MED | SEN | AN | WR | IN | OTH | 2, 1 | 0, 0 | 2, 2 | 0, 0
MED | SEN | AN | WR | IN | PRE | 1, 1 | 0, 0 | 2, 2 | 2, 2
MED | SEN | AN | WR | IN | VEL | 0, 0 | 0, 0 | 3, 2 | 0, 0
MED | SEN | AN | WR | MI | AMP | 0, 0 | 0, 0 | 4, 3 | 0, 0
MED | SEN | AN | WR | MI | INCH | 1, 1 | 0, 0 | 1, 1 | 0, 0
MED | SEN | AN | WR | MI | LAT | 0, 0 | 0, 0 | 2, 1 | 0, 0
MED | SEN | AN | WR | MI | PRE | 0, 0 | 0, 0 | 1, 1 | 0, 0
MED | SEN | AN | WR | MI | VEL | 0, 0 | 0, 0 | 3, 3 | 1, 1
MED | SEN | AN | WR | OTH | VEL | 0, 0 | 0, 0 | 1, 1 | 0, 0
MED | SEN | AN | WR | PAL | AMP | 0, 0 | 0, 0 | 1, 0 | 0, 0
MED | SEN | AN | WR | PAL | LAT | 0, 0 | 1, 0 | 1, 1 | 0, 0
MED | SEN | AN | WR | PAL | VEL | 0, 0 | 0, 0 | 3, 2 | 2, 2
MED | SEN | AN | WR | RI | AMP | 0, 0 | 0, 0 | 1, 0 | 0, 0
MED | SEN | AN | WR | RI | LAT | 0, 0 | 0, 0 | 3, 2 | 3, 2
MED | SEN | AN | WR | RI | VEL | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | AN | WR | TH | AMP | 1, 1 | 0, 0 | 2, 1 | 0, 0
MED | SEN | AN | WR | TH | LAT | 1, 1 | 0, 0 | 3, 2 | 0, 0
MED | SEN | AN | WR | TH | VEL | 0, 0 | 0, 0 | 1, 1 | 1, 1
MED | SEN | OR | | | AMP | 0, 0 | 1, 0 | 0, 0 | 0, 0
MED | SEN | OR | | | LAT | 0, 0 | 1, 0 | 0, 0 | 0, 0
MED | SEN | OR | | WR | AMP | 0, 0 | 0, 0 | 2, 2 | 0, 0
MED | SEN | OR | | WR | LAT | 0, 0 | 0, 0 | 1, 1 | 2, 2
MED | SEN | OR | | WR | VEL | 0, 0 | 0, 0 | 2, 2 | 0, 0
MED | SEN | OR | IN | | AMP | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | IN | | LAT | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | IN | | OTH | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | IN | | VEL | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | IN | PAL | VEL | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | IN | WR | AMP | 4, 3 | 0, 0 | 7, 5 | 2, 2
MED | SEN | OR | IN | WR | LAT | 1, 1 | 0, 0 | 8, 7 | 3, 3
MED | SEN | OR | IN | WR | OTH | 2, 2 | 0, 0 | 2, 1 | 1, 1
MED | SEN | OR | IN | WR | PRE | 1, 1 | 0, 0 | 4, 4 | 0, 0
MED | SEN | OR | IN | WR | VEL | 4, 3 | 1, 1 | 8, 7 | 3, 3
MED | SEN | OR | MI | | AMP | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | MI | | LAT | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | MI | | OTH | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | MI | | VEL | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | MI | MI | AMP | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | MI | MI | VEL | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | MI | PAL | AMP | 1, 0 | 0, 0 | 0, 0 | 0, 0
MED | SEN | OR | MI | PAL | VEL | 1, 0 | 0, 0 | 2, 2 | 0, 0
MED | SEN | OR | MI | WR | AMP | 2, 1 | 0, 0 | 3, 3 | 4, 4
MED | SEN | OR | MI | WR | INCH | 1, 1 | 0, 0 | 0, 0 | 2, 2
MED | SEN | OR | MI | WR | LAT | 0, 0 | 0, 0 | 4, 3 | 0, 0
MED | SEN | OR | MI | WR | OTH | 1, 1 | 0, 0 | 1, 1 | 0, 0
MED | SEN | OR | MI | WR | PRE | 1, 1 | 0, 0 | 2, 2 | 1, 1
MED | SEN | OR | MI | WR | VEL | 3, 2 | 0, 0 | 5, 5 | 5, 5
MED | SEN | OR | OTH | | VEL | 1, 1 | 0, 0 | 0, 0 | 0, 0
MED | SEN | OR | OTH | WR | AMP | 0, 0 | 0, 0 | 1, 1 | 0, 0
MED | SEN | OR | OTH | WR | LAT | 0, 0 | 0, 0 | 2, 2 | 0, 0
MED | SEN | OR | OTH | WR | VEL | 0, 0 | 0, 0 | 2, 2 | 1, 1
MED | SEN | OR | PAL | WR | AMP | 0, 0 | 0, 0 | 2, 2 | 1, 1
MED | SEN | OR | PAL | WR | LAT | 1, 1 | 1, 1 | 11, 11 | 1, 1
MED | SEN | OR | PAL | WR | OTH | 0, 0 | 0, 0 | 1, 1 | 0, 0
MED | SEN | OR | PAL | WR | PRE | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | PAL | WR | VEL | 0, 0 | 0, 0 | 7, 7 | 7, 6
MED | SEN | OR | RI | | AMP | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | RI | | LAT | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | RI | | OTH | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | RI | | VEL | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | RI | WR | AMP | 3, 2 | 0, 0 | 3, 2 | 1, 1
MED | SEN | OR | RI | WR | LAT | 1, 1 | 1, 1 | 4, 3 | 1, 1
MED | SEN | OR | RI | WR | OTH | 1, 1 | 0, 0 | 1, 1 | 0, 0
MED | SEN | OR | RI | WR | PRE | 1, 1 | 0, 0 | 1, 1 | 2, 2
MED | SEN | OR | RI | WR | VEL | 2, 1 | 0, 0 | 3, 3 | 2, 2
MED | SEN | OR | TH | | AMP | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | TH | | LAT | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | TH | | OTH | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | TH | | VEL | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | TH | ELB | PRE | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | TH | MI | VEL | 0, 0 | 0, 0 | 0, 0 | 0, 0
MED | SEN | OR | TH | PAL | VEL | 0, 0 | 0, 0 | 0, 0 | 0, 0
MED | SEN | OR | TH | WR | AMP | 1, 1 | 0, 0 | 3, 3 | 2, 2
MED | SEN | OR | TH | WR | LAT | 0, 0 | 0, 0 | 3, 3 | 0, 0
MED | SEN | OR | TH | WR | OTH | 1, 1 | 0, 0 | 1, 1 | 0, 0
MED | SEN | OR | TH | WR | PRE | 1, 1 | 0, 0 | 1, 1 | 1, 1
MED | SEN | OR | TH | WR | VEL | 1, 1 | 0, 0 | 5, 5 | 2, 2
MED | SEN | OR | WR | ELB | AMP | 2, 1 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | WR | ELB | OTH | 1, 1 | 0, 0 | 0, 0 | 0, 0
MED | SEN | OR | WR | ELB | PRE | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | SEN | OR | WR | ELB | VEL | 2, 1 | 0, 0 | 0, 0 | 1, 1
MED | Transcarpal | | | | AMP | 0, 0 | 0, 0 | 0, 0 | 1, 1
MED | Transcarpal | | | | LAT | 0, 0 | 0, 0 | 0, 0 | 1, 1
RAD | SEN | AN | FOR | TH | LAT | 0, 0 | 0, 0 | 1, 0 | 0, 0
RAD | SEN | AN | WR | TH | AMP | 1, 1 | 0, 0 | 0, 0 | 0, 0
RAD | SEN | AN | WR | TH | LAT | 1, 1 | 0, 0 | 2, 2 | 2, 0
RAD | SEN | AN | WR | TH | VEL | 0, 0 | 0, 0 | 0, 0 | 1, 1
RAD | SEN | OR | TH | WR | AMP | 1, 0 | 0, 0 | 1, 1 | 0, 0
RAD | SEN | OR | TH | WR | LAT | 0, 0 | 0, 0 | 1, 1 | 0, 0
RAD | SEN | OR | TH | WR | PRE | 0, 0 | 0, 0 | 1, 1 | 0, 0
RAD | SEN | OR | TH | WR | VEL | 1, 0 | 0, 0 | 2, 2 | 1, 1
ULN | MOT | | | | LAT | 0, 0 | 0, 0 | 0, 0 | 1, 1
ULN | MOT | | | | OTH | 1, 1 | 0, 0 | 1, 0 | 0, 0
ULN | MOT | | ELB | ADM | LAT | 1, 1 | 0, 0 | 0, 0 | 0, 0
ULN | MOT | | ELB | ADM | OTH | 1, 1 | 0, 0 | 0, 0 | 0, 0
ULN | MOT | | ELB | OTH | AMP | 0, 0 | 0, 0 | 0, 0 | 1, 1
ULN | MOT | | ELB | OTH | PRE | 0, 0 | 0, 0 | 0, 0 | 1, 1
ULN | MOT | | ELB | OTH | VEL | 0, 0 | 0, 0 | 0, 0 | 1, 1
ULN | MOT | | ELB | WR | VEL | 1, 1 | 0, 0 | 1, 1 | 1, 1
ULN | MOT | | WR | | LAT | 1, 1 | 0, 0 | 1, 1 | 0, 0
ULN | MOT | | WR | | VEL | 1, 1 | 0, 0 | 0, 0 | 0, 0
ULN | MOT | | WR | ADM | AMP | 0, 0 | 0, 0 | 1, 0 | 2, 1
ULN | MOT | | WR | ADM | LAT | 2, 2 | 1, 1 | 4, 2 | 5, 4
ULN | MOT | | WR | ADM | OTH | 1, 1 | 0, 0 | 0, 0 | 0, 0
ULN | MOT | | WR | ADM | VEL | 0, 0 | 0, 0 | 1, 0 | 0, 0
ULN | MOT | | WR | APB | LAT | 1, 1 | 0, 0 | 0, 0 | 0, 0
ULN | MOT | | WR | OTH | AMP | 0, 0 | 0, 0 | 1, 1 | 0, 0
ULN | MOT | | WR | OTH | LAT | 0, 0 | 1, 1 | 3, 3 | 4, 3
ULN | MOT | | WR | OTH | PRE | 0, 0 | 0, 0 | 1, 1 | 0, 0
ULN | MOT | | WR | PAL | AMP | 0, 0 | 0, 0 | 1, 1 | 0, 0
ULN | MOT | | WR | PAL | LAT | 0, 0 | 0, 0 | 1, 1 | 0, 0
ULN | SEN | | | | OTH | 0, 0 | 0, 0 | 1, 0 | 0, 0
ULN | SEN | | WR | | AMP | 1, 1 | 0, 0 | 0, 0 | 0, 0
ULN | SEN | | WR | | LAT | 1, 1 | 0, 0 | 0, 0 | 0, 0
ULN | SEN | AN | FOR | LI | LAT | 0, 0 | 0, 0 | 1, 0 | 0, 0
ULN | SEN | AN | FOR | RI | LAT | 0, 0 | 0, 0 | 1, 0 | 0, 0
ULN | SEN | AN | PAL | LI | LAT | 0, 0 | 0, 0 | 1, 1 | 0, 0
ULN | SEN | AN | WR | LI | AMP | 0, 0 | 0, 0 | 2, 2 | 1, 1
ULN | SEN | AN | WR | LI | LAT | 0, 0 | 0, 0 | 2, 2 | 1, 1
ULN | SEN | AN | WR | LI | VEL | 0, 0 | 0, 0 | 3, 3 | 0, 0
ULN | SEN | AN | WR | PAL | LAT | 0, 0 | 0, 0 | 1, 1 | 0, 0
ULN | SEN | AN | WR | RI | LAT | 0, 0 | 0, 0 | 2, 2 | 4, 2
ULN | SEN | AN | WR | RI | VEL | 0, 0 | 0, 0 | 0, 0 | 1, 1
ULN | SEN | OR | LI | WR | AMP | 2, 1 | 0, 0 | 4, 3 | 3, 3
ULN | SEN | OR | LI | WR | LAT | 1, 1 | 0, 0 | 3, 2 | 1, 1
ULN | SEN | OR | LI | WR | OTH | 1, 1 | 0, 0 | 1, 0 | 0, 0
ULN | SEN | OR | LI | WR | PRE | 0, 0 | 0, 0 | 1, 1 | 0, 0
ULN | SEN | OR | LI | WR | VEL | 2, 1 | 0, 0 | 3, 2 | 3, 3
ULN | SEN | OR | OTH | | VEL | 1, 1 | 0, 0 | 0, 0 | 0, 0
ULN | SEN | OR | OTH | WR | VEL | 0, 0 | 0, 0 | 0, 0 | 1, 1
ULN | SEN | OR | PAL | WR | AMP | 0, 0 | 0, 0 | 1, 1 | 0, 0
ULN | SEN | OR | PAL | WR | LAT | 0, 0 | 1, 1 | 6, 6 | 0, 0
ULN | SEN | OR | PAL | WR | VEL | 0, 0 | 0, 0 | 2, 2 | 1, 1
ULN | SEN | OR | RI | WR | AMP | 2, 1 | 0, 0 | 2, 1 | 2, 2
ULN | SEN | OR | RI | WR | LAT | 1, 1 | 1, 1 | 3, 2 | 1, 1
ULN | SEN | OR | RI | WR | PRE | 0, 0 | 0, 0 | 1, 1 | 1, 1
ULN | SEN | OR | RI | WR | VEL | 2, 1 | 0, 0 | 2, 2 | 3, 3
ULN | SEN | OR | WR | ELB | AMP | 1, 1 | 0, 0 | 0, 0 | 0, 0
ULN | SEN | OR | WR | ELB | OTH | 1, 1 | 0, 0 | 0, 0 | 0, 0
ULN | SEN | OR | WR | ELB | VEL | 1, 1 | 0, 0 | 0, 0 | 0, 0

#### Summary ROC Meta-Analysis of Diagnostic Test Results

Ideally, a meta-analysis of a test includes only studies that use the same definition of what is to be diagnosed. However, the absence of a gold standard for defining carpal tunnel syndrome resulted in there being as many different definitions of the condition (and therefore of positive cases) as there were studies. Therefore, we could only combine study results by permitting different authors to use different definitions of CTS. Testing for heterogeneity of results helps reduce, but does not eliminate the possibility that different definitions affected study results.

Distal Motor Latency: Patients with Unspecified Diagnosis of CTS v. Normal Controls

While there were 21 studies of distal motor latency (DML) in patient groups coded as “Unspecified diagnosis” that reported some 2 × 2 tables, only five of those studies ultimately could be included in a meta-analysis. Reasons for the exclusion of the others are shown in Table 22. Seven studies did not report any sensitivity or specificity results for the DML measurements, even though they reported them for other tests. Four studies reported sensitivity but not specificity, while one reported specificity but not sensitivity. These studies were excluded because data from both groups are necessary to ensure the validity of the results and because the summary ROC method requires both sensitivity and specificity for each study. The study by Bronson et al. ^163^ was excluded because DML results were reported for only some of the patients. So et al. ^173^ combined direct measurement of DML with abnormalities in the difference between median and ulnar latency when reporting their results, and we could not isolate results for DML. Charles et al. ^170^ was excluded because authors reported use of a mean + 2 SD threshold for defining abnormal latency, but the actual threshold reported (4.5 msec) did not agree with their reported results for their control subjects (mean + 2 SD = 4.0 msec). Since the number of controls with latency = 4.5 msec was not reported, we could not derive an internally-consistent 2 × 2 table from the article, and had to exclude it from analysis. Resende et al. ^174^ reported patient-level data, but did not report a threshold fordistinguishing normal from abnormal latency. Because there is no agreement on a standard threshold for DML (and there was no way to objectively choose a threshold), we excluded this study.

Table 22. Distal Motor Latency Studies Excluded from Meta-Analysis

Study | Reason for Exclusion
Pease, 1990 ^177^ | Did not report sensitivity and specificity for distal motor latency test
Seror, 1998 ^159^ | Did not report sensitivity and specificity for distal motor latency test
Rossi, 1994 ^178^ | Did not report sensitivity and specificity for distal motor latency test
Seror, 1995 ^179^ | Did not report sensitivity and specificity for distal motor latency test
Lang, 1995 ^109^ | Did not report sensitivity and specificity for distal motor latency test
Tzeng, 1990 ^180^ | Did not report sensitivity and specificity for distal motor latency test
Mondelli, 2001 ^181^ | Did not report sensitivity and specificity for distal motor latency test
Simovic, 1997 ^182^ | Did not report distal motor latency results for control subjects
Simovic, 1999 ^183^ | Did not report distal motor latency results for control subjects
Resende, 2000 ^184^ | Did not report distal motor latency results for control subjects
Lauritzen, 1991 ^185^ | Did not report distal motor latency results for control subjects
Loscher, 2000 ^175^ | Did not report distal motor latency results for CTS patients
Bronson, 1997 ^163^ | Selective reporting of distal motor latency results
So, 1989 ^173^ | Reported combination test of distal motor latency and other nerve conduction measurements
Charles, 1990 ^170^ | Discrepancy in reported threshold
Resende, 2000 ^174^ | No diagnostic threshold reported

Two of the five studies included in the meta-analysis ^140,^ ^175^ did not report counts of normal and abnormal results in the control subjects, but because their thresholds were based on two standard deviations from the mean, we estimated the number of false-positive results by multiplying the number of patients in the control group by the probability that a result would be two or more standard deviations above the mean (0.02275 based on the normal distribution). We also recalculated the results from the study by Rosén ^176^ , which reported a histogram of latency results and did not report a 2 × 2 table for their specified threshold. In the other included articles, there were no discrepancies between the sensitivity and specificity figures reported by the authors and the figures calculated by ECRI and used in the meta-analysis.

Results of each included trial and of the meta-analysis are shown in Table 23 and Figure 9. No statistically significant heterogeneity was found in the results (Q = 0.33, p = 0.99). The results clustered in a small portion of the graph, suggesting there was good agreement among clinicians in how this test is used and how effective it is. The sensitivity and specificity at mean threshold, our best estimate of the effectiveness of the test, was 57.1% sensitivity, 97.9% specificity.

Table 23. Meta-analysis of Distal Motor Latency Results in Trials With Non-specific Diagnosis of Carpal Tunnel Syndrome Groups

Study | TP | FN | FP | TN | Sen. 95% CI | Spec. 95% CI | PPV 95% CI | NPV 95% CI | Prev.
^a^Kimura ^140^ | 105 | 67 | 3 | 119 | 61.0% | 97.5% | 97.2% | 64.0% | 58.5%
| | | | | 53.4% 68.2% | 92.9% 99.2% | 92.0% 99.1% | 56.7% 70.7%
Marin ^139^ | 9 | 5 | 0 | 12 | 64.3% | 100% | 100% | 70.6% | 53.8%
| | | | | 38.3% 83.9% | 75.0% 100% | 69.2% 100% | 46.4% 86.9%
Loong ^141^ | 17 | 10 | 0 | 30 | 63.0% | 100% | 100% | 75.0% | 47.4%
| | | | | 43.9% 78.7% | 88.2% 100% | 81.0% 100% | 59.5% 86.0%
Plaja ^142^ | 16 | 7 | 0 | 20 | 69.6% | 100% | 100% | 74.1% | 53.5%
| | | | | 48.7% 84.6% | 83.3% 100% | 80.0% 100% | 54.9% 87.0%
^b^Rosén ^138^ | 12 | 29 | 0 | 50 | 29.3% | 100% | 100% | 63.3% | 45.1%
| | | | | 17.4% 44.8% | 92.6% 100% | 75.0% 100% | 52.0% 73.3%
Meta-analysis results (mean threshold) | | | | | 57.1% | 97.9%
| | | | | 49.1% 64.8% | 97.1% 98.5%

[underlined: Key:]

TP-true positive, FN-false negative, FP-false positive, TN-true negative

Sen.-sensitivity, Spec-specificity, PPV-positive predictive value, NPV-negative predictive value, Prev.-prevalence of CTS

Confidence intervals on sensitivity, specificity, PPV, NPV calculated by Wilson method ^96^

a Counts for control group (false positive, true negative) estimated by ECRI from threshold reported by authors (mean + 2 SD)

b Results calculated by ECRI from published histogram

Figure 9. Meta-analysis of Distal Motor Latency Results in Trials With Non-specific Diagnosis of Carpal Tunnel Syndrome Groups

The section of the summary ROC curve above sensitivity = 70% is an extrapolation from the actual data. It represents thresholds that are much lower than the thresholds used in the published trials and as such, may not represent an accurate description of clinical events.

Distal Motor Latency: Patients with Symptoms of CTS v. Normal Controls

Seventeen studies met the initial criteria for inclusion in a meta-analysis of DML for distinguishing patients with symptoms of CTS from healthy volunteer controls. As with the meta-analysis on patients with unspecified diagnosis of CTS, there were several articles that did not include sufficient data to permit inclusion in the meta-analysis (Table 24). Four articles were excluded because they did not report the number of CTS patients with normal and abnormal DML, and two articles were excluded because they did not report the corresponding data for control subjects. Two articles were excluded due to selection bias: DML was one of their patient selection criteria. Another article was excluded because of discrepancies in the reported results; ECRI could not verify or recalculate the 2 × 2 table.

Table 24. Distal Motor Latency Articles Excluded From Meta-Analysis

Study | Reason for Exclusion
Jackson, 1989 ^150^ | Did not report sensitivity and specificity for distal motor latency test
Sener, 2000 ^186^ | Did not report sensitivity and specificity for distal motor latency test
Schwartz, 1979 ^187^ | Did not report sensitivity and specificity for distal motor latency test
Escobar, 1985 ^151^ | Did not report sensitivity and specificity for distal motor latency test
Preston, 1992 ^188^ | Did not report distal motor latency results for control subjects
Kimura, 1985 ^189^ | Did not report distal motor latency results for control subjects
Cherniak, 1996 ^190^ | Used distal motor latency for patient selection
Sheean, 1995 ^191^ | Used distal motor latency for patient selection
Foresti, 1996 ^192^ | Discrepancies in reported results

Eight articles remained after those exclusions (see Table 25). Significant heterogeneity in their results was found by the Q statistic (Q = 16.7, p = 0.019), with one obvious outlier (Atroshi et al. ^136^ , standardized residual = –3.68). Excluding that study left the remaining results homogeneous (Q = 3.15, p = 0.79). The meta-analysis was completed both with and without the outlier included, and there was no substantial effect on the results. With the outlier excluded (Figure 10), the sensitivity/specificity at mean threshold was 66.0%/98.3%. Including the outlier changed the results by less than a percentage point: the sensitivity/specificity at mean threshold was 65.0%/97.7%.

Table 25. Meta-analysis of Distal Motor Latency Results in Trials With Patients Presenting with CTS Symptoms

Study | TP | FN | FP | TN | Sen. | Spec. | PPV | NPV | Prev.
| | | | | 95% CI | 95% CI | 95% CI | 95% CI
^a, b^Chang ^145^ | 17 | 26 | 0 | 40 | 39.5% | 100% | 100% | 60.6% | 51.8%
| | | | | 26.1% 54.7% | 90.9% 100% | 81.0% 100% | 48.3% 71.7%
Kuntzer ^144^ | 47 | 53 | 1 | 69 | 47.0% | 98.6% | 97.9% | 56.6% | 58.8%
| | | | | 37.3% 56.9% | 92.1% 99.8% | 88.8% 99.6% | 47.5% 65.2%
^a^Murthy ^143^ 143 | 38 | 19 | 2 | 72 | 66.7% | 97.3% | 95.0% | 79.1% | 43.5%
| | | | | 53.5% 77.7% | 90.5% 99.3% | 83.2% 98.6% | 69.5% 86.3%
Cioni ^146^ | 300 | 75 | 0 | 56 | 80.0% | 100% | 100% | 42.7% | 87.0%
| | | | | 75.6% 83.8% | 93.3% 100% | 98.7% 100% | 34.4% 51.5%
^b^Messina ^120^ | 34 | 6 | 1 | 39 | 85.0% | 97.5% | 97.1% | 86.7% | 50.0%
| | | | | 70.6% 93.0% | 86.8% 99.6% | 85.1% 99.5% | 73.5% 93.8%
Melvin ^147^ | 13 | 4 | 0 | 24 | 76.5% | 100% | 100% | 85.7% | 41.5%
| | | | | 52.2% 90.6% | 85.7% 100% | 76.5% 100% | 68.1% 94.4%
Loong ^148^ | 13 | 9 | 0 | 60 | 59.1% | 100% | 100% | 87.0% | 26.8%
| | | | | 38.4% 77.0% | 93.8% 100% | 76.5% 100% | 76.8% 93.1%
^c^Atroshi ^136^ | 25 | 18 | 8 | 52 | 58.1% | 86.7% | 75.8% | 74.3% | 41.7%
| | | | | 43.0% 71.9% | 75.6% 93.2% | 58.6% 87.3% | 62.7% 83.2%
Meta-analysis results (mean threshold) | | | | | 66.0% | 98.3%
| | | | | 55.7% 75.0% | 97.4% 98.9%

[underlined: Key:]

TP-true positive, FN-false negative, FP-false positive, TN-true negative

Sen.-sensitivity, Spec-specificity, PPV-positive predictive value, NPV-negative predictive value, Prev.-prevalence of CTS

Confidence intervals on sensitivity, specificity, PPV, NPV calculated by Wilson method

a Counts for control group (false positive, true negative) estimated by ECRI from threshold reported by authors (mean + 2 or 2.5 SD)

b Results calculated by ECRI from published graph

c Outlier (excluded from meta-analysis results): see text

Figure 10. Meta-analysis of Distal Motor Latency Results in Trials With Patients Presenting with CTS Symptoms

Note: One outlier ^136^ was excluded (see text).

The results of this meta-analysis are very similar to the results for the meta-analysis of DML with patient groups with unspecified diagnosis of CTS. The results of both meta-analyses suggest that this test has very high specificity, but only moderate sensitivity.

Palmar Sensory Latency: Patients with Symptoms of CTS v. Normal Controls

The cross-tabulation found 11 articles that included palmar sensory latency studies and reported some data in the form of a 2 × 2 table. The articles compared patients who presented with suspected CTS or symptoms of CTS to healthy normal controls. As with the other meta-analyses, several studies could not be included in the meta-analysis (Table 26). Five articles did not report sufficient data to allow us to calculate sensitivity and specificity for this particular test. One used palmar sensory latency as a patient selection criterion and was excluded due to selection bias.

Table 26. Palmar Sensory Latency Articles Excluded from Meta-analysis

Study | Reason for Exclusion
Gerr, 1998 ^31^ | Did not report sensitivity and specificity for palmar sensory latency test
Foresti, 1996 ^192^ | Did not report sensitivity and specificity for palmar sensory latency test
Eisen, 1993 ^193^ | Did not report sensitivity and specificity for palmar sensory latency test
Mills, 1985 ^194^ | Did not report sensitivity and specificity for palmar sensory latency test
Kim, 1983 ^195^ | Did not report sensitivity and specificity for palmar sensory latency test
Andary, 1996 ^196^ | Palmar sensory latency results used as patient selection criterion

After these exclusions, five studies remained in the meta-analysis. There was no statistically significant heterogeneity in their results (Q = 4.87, p = 0.30). The studies and their results are listed in Table 27 and the summary ROC plot is shown in Figure 11.

Table 27. Meta-analysis of Palmar Sensory Latency Results

Study | TP | FN | FP | TN | Sen. 95% CI | Spec. 95% CI | PPV 95% CI | NPV 95% CI | Prev.
^a, b^Chang ^145^ | 26 | 17 | 0 | 40 | 60.5% 45.3% 73.9% | 100% 90.9% 100% | 100% 86.7% 100% | 70.2% 57.1% 80.6% | 51.8%
^c^Jackson ^150^ | 91 | 40 | 1 | 37 | 69.5% 60.9% 76.8% | 97.4% 86.2% 99.5% | 98.9% 93.9% 99.8% | 48.1% 37.0% 59.3% | 77.5%
^a^Murthy ^143^ | 55 | 2 | 2 | 72 | 96.5% 87.8% 99.1% | 97.3% 90.5% 99.3% | 96.5% 87.8% 99.1% | 97.3% 90.5% 99.3% | 43.5%
^a^Escobar ^151^ | 32 | 8 | 2 | 102 | 80.0% 64.9% 89.6% | 98.1% 93.1% 99.5% | 94.1% 80.5% 98.4% | 92.7% 86.1% 96.3% | 27.8%
^c^Girlanda ^149^ | 38 | 37 | 1 | 89 | 50.7% 39.4% 61.9% | 98.9% 93.8% 99.8% | 97.4% 86.5% 99.6% | 70.6% 62.0% 78.0% | 45.5%
Meta-analysis results (mean threshold) | | | | | 75.8% 68.8% 81.6% | 97.7% 96.8% 98.4%

[underlined: Key:]

TP-true positive, FN-false negative, FP-false positive, TN-true negative

Sen.-sensitivity, Spec-specificity, PPV-positive predictive value, NPV-negative predictive value, Prev.-prevalence of CTS Confidence intervals on sensitivity, specificity, PPV, NPV calculated by Wilson method

a Counts for control group (false positive, true negative) estimated by ECRI from threshold reported by authors (mean + 2 or 2.5 SD)

b Results calculated by ECRI from published graph

c Results calculated by ECRI from published percentages

Figure 11. Meta-analysis of Palmar Sensory Latency Results

Like DML, palmar sensory latency has very high specificity. The normal volunteers studied in these trials rarely had abnormal results. This finding, however, does not reveal the test performance on persons with suspected CTS. To address that issue, a computation of sensitivity is required. The sensitivity/specificity at mean threshold was 75.8%/97.7%, and it is clear that the test has some ability to identify persons with symptoms of CTS. Although the summary ROC can be extrapolated to a point where sensitivity and specificity are both quite high (i.e., 96%, 96% respectively), in actual practice it is likely that only specificity is so high. Sensitivity was lower than specificity in all five studies.

Phalen's Maneuver: Combined CTS Groups v. Normal Controls

There were no clinical signs or symptoms for which at least 10 articles reported sensitivity and specificity in a specific patient population. Therefore, we loosened the inclusion criteria by first combining the four patient selection categories, and then requiring a total of 20 or more sensitivity/specificity articles. Because none of the signs and symptoms data met that loosened criterion, we again lowered the threshold to a total of 15 studies or more. Two tests met that criterion: Phalen's maneuver and Tinel's sign. We proceeded to attempt meta-analysis of these data, recognizing that combining patient selection groups could cause heterogeneity of study results that could prevent meta-analysis.

The evidence base on Phalen's maneuver comprised 15 studies. Two of these reported two CTS groups, for a total of 17 entries in the cross-tabulation. For analyzing the two studies with two CTS groups, ^101,^ ^154^ we combined results of all CTS patients. Three articles were excluded because they did not report sufficient data to allow specificity to be calculated. Phalen's maneuver data from the article by Glass and King ^28^ was excluded because results were reported for only 22 of the 159 hands with CTS, and the authors did not report the reason for this. Finally, we determined while abstracting data that two publications by Gerr ^31,^ ^197^ reported the same controls and likely the same patients. Only the later publication ^31^ was included in the analysis. Excluded articles are listed in Table 28.

Table 28. Phalen's Maneuver Articles Excluded from Meta-Analysis

Study | Reason for Exclusion
Koris, 1988 ^198^ | Did not report specificity of Phalen's maneuver
Brahme, 1997 ^199^ | Did not report specificity of Phalen's maneuver
Lang, 1995 ^109^ | Did not report specificity of Phalen's maneuver
Glass, 1995 ^28^ | Reported results for only 22 of 159 affected hands
Gerr, 1994 ^197^ | Duplicate publication

This left a total of 10 articles for meta-analysis (Table 29). We found significant heterogeneity among the studies' results (Q = 71.4, p <0.000001). Six studies selected CTS patients using procedures we categorized as “complex objective standard.” Analyzing this subgroup separately did not eliminate the heterogeneity (Q = 59.4, p <0.000001), nor did excluding the one study ^111^ that used the reverse Phalen maneuver. (Q = 70.8, p <0.000001). There were no obvious outliers to explain the heterogeneity, and grouping studies according to criteria that might affect the validity or generalizability of the results (Table 30) did not reduce heterogeneity to statistically non-significant levels. Thus we could not confidently report a single point as the most likely sensitivity and specificity of the test.

Table 29. Diagnostic Trial Results for Phalen's Maneuver

Study | TP | FN | FP | TN | Sen. 95% CI | Spec. 95% CI | PPV 95% CI | NPV 95% CI | Prev.
De Smet ^101^ | 57 | 9 | 4 | 77 | 86.4% 75.8% 92.7% | 95.1% 87.8% 98.1% | 93.4% 84.1% 97.5% | 89.5% 81.1% 94.5% | 44.9%
Durkan ^155^ | 32 | 14 | 8 | 42 | 69.6% 54.9% 81.1% | 84.0% 71.2% 91.8% | 80.0% 64.9% 89.6% | 75.0% 62.0% 84.6% | 47.9%
Gellman ^106^ | 45 | 18 | 10 | 40 | 71.4% 59.0% 81.3% | 80.0% 66.7% 88.9% | 81.8% 69.4% 89.9% | 69.0% 55.9% 79.6% | 55.8%
^a, b^Gerr ^31^ | 48 | 67 | 4 | 119 | 41.7% 33.0% 51.1% | 96.7% 91.8% 98.8% | 92.3% 81.5% 97.0% | 64.0% 56.7% 70.7% | 48.3%
^b^Ghavanini ^154^ | 34 | 40 | 17 | 41 | 45.9% 34.9% 57.4% | 70.7% 57.7% 81.0% | 66.7% 52.7% 78.2% | 50.6% 39.7% 61.4% | 56.1%
González del Pino ^104^ | 174 | 26 | 20 | 180 | 87.0% 81.5% 91.0% | 90.0% 84.9% 93.5% | 89.7% 84.5% 93.3% | 87.4% 82.0% 91.3% | 50.0%
^a^Szabo ^152^ | 65 | 22 | 5 | 95 | 74.7% 64.4% 82.8% | 95.0% 88.7% 97.9% | 92.9% 84.1% 97.0% | 81.2% 73.0% 87.3% | 46.5%
Tetro ^102^ 1 | 58 | 37 | 16 | 80 | 61.1% 50.8% 70.4% | 83.3% 74.4% 89.6% | 78.4% 67.5% 86.4% | 68.4% 59.3% 76.2% | 49.7%
Fertl ^153^ | 50 | 23 | 3 | 36 | 68.5% 56.9% 78.2% | 92.3% 79.3% 97.4% | 94.3% 84.4% 98.1% | 61.0% 48.0% 72.6% | 65.2%
^c^Werner ^111^ | 17 | 14 | 0 | 20 | 54.8% 37.5% 71.1% | 100% 83.3% 100% | 100% 81.0% 100% | 58.8% 41.9% 73.9% | 60.8%
Meta-analysis results (mean threshold) | | | | | NA | NA

[underlined: Key:]

TP-true positive, FN-false negative, FP-false positive, TN-true negative

Sen.-sensitivity, Spec-specificity, PPV-positive predictive value, NPV-negative predictive value, Prev.-prevalence of CTS Confidence intervals on sensitivity, specificity, PPV, NPV calculated by Wilson method

NA—Results not valid because of excessive heterogenity in study results

a Results calculated by ECRI from published percentages

b Errors in published results corrected by ECRI

c Tested reverse Phalen's maneuver

Table 30. Heterogeneity of Diagnostic Trial Results for Phalen's Maneuver

Group | Q (p-value) for larger group
All articles (N = 10) | 71.4 (p <0.000001)
Patients selected with complex objective standard (N = 6) v. other selection | 59.4 (p <0.000001)
Reverse Phalen's maneuver (N = 1) v. conventional | 70.8 (p <0.000001)
Not funded by for-profit device or drug manufacturer (N = 4) v. not reported | 58.5 (p <0.000001)
Reported both inclusion and exclusion criteria (N = 4) v. reported only inclusion criteria | 20.5 (p = 0.001)
Prospective patient selection (N = 5) v. not reported | 58.7 (p <0.000001)
Comorbidity reported (N = 1) v. not reported | 69.9 (p <0.000001)
Sex ratios of patients, controls within 20% of each other (N = 5) v. possible sex bias | 58.5 (p <0.000001)
Mean ages of patients, controls within 5 years (N = 3) v. possible age bias | 15.4 (p = 0.017)
Duration of condition reported (N = 2) v. not reported | 48.4 (p <0.000001)
Independent reference standard (N = 4) v. no independent reference standard reported | 48.2 (p <0.000001)
Patients given both study test and reference test (N = 3) v. did not do so | 49.3 (p <0.000001)
Studies done in USA (N = 6) v. other countries | 58.1 (p <0.000001)
Potential selection bias for easy cases (N = 4) v. no bias or not reported | 49.3 (p <0.000001)

Q—Q-statistic, with probability that variability in study results [D, logit (sensitivity) + logit (specificity)] is the result of random variability within a homogeneous sample of studies.

The variability of results is shown in Figure 12; sensitivity/specificity covered a large range. We can only conclude that Phalen's maneuver has some ability to distinguish CTS patients from normal controls; the data are too heterogeneous to estimate sensitivity or specificity.

Figure 12. Diagnostic Trial Results for Phalen's Maneuver

Tinel's Sign: Combined CTS Groups v. Normal Controls

The evidence base on Tinel's sign comprised 13 studies; three of these reported two CTS groups, for a total of 16 entries in the cross-tabulation. As mentioned in the meta-analysis of Phalen's maneuver, only the later of the duplicate Gerr publications ^31,^ ^197^ was included in the analysis, and we pooled patient groups in studies with two CTS groups. Two articles were excluded because they did not report specificity. Exclusions are summarized in Table 31

Table 31. Tinel's Sign Articles Excluded from Meta-analysis

Study | Reason for Exclusion
Brahme, 1997 ^199^ | Did not report specificity of Tinel's sign
Lang, 1995 ^109^ | Did not report specificity of Tinel's sign
Gerr, 1994 ^197^ | Duplicate publication

Eleven studies remained for meta-analysis (Table 32). The meta-analysis found significant heterogeneity among the studies' results (Q = 59.1, p <0.000001). All but two studies (De Smet et al. ^101^ and Seror et al. ^156^ ) selected CTS patients using procedures we categorized as “complex objective standard.” Excluding those studies from the analysis did not substantially reduce the heterogeneity (Q = 46.7, p <0.000001).

Table 32. Diagnostic Trial Results for Tinel's Sign

Study | TP | FN | FP | TN | Sen. 95% CI | Spec. 95% CI | PPV 95% CI | NPV 95% CI | Prev.
De Smet ^101^ | 14 | 17 | 0 | 81 | 45.2% 28.9% 62.5% | 100% 95.3% 100% | 100% 77.8% 100% | 82.7% 73.8% 89.0% | 27.7%
Durkan ^155^ | 26 | 20 | 10 | 40 | 56.5% 42.0% 70.0% | 80.0% 66.7% 88.9% | 72.2% 55.7% 84.3% | 66.7% 53.8% 77.5% | 47.9%
Gellman ^106^ | 29 | 37 | 3 | 47 | 43.9% 32.4% 56.2% | 94.0% 83.5% 98.0% | 90.6% 75.4% 96.8% | 56.0% 45.1% 66.3% | 56.9%
Gelmers ^29^ | 20 | 27 | 11 | 32 | 42.6% 29.3% 57.0% | 74.4% 59.4% 85.2% | 64.5% 46.6% 79.1% | 54.2% 41.4% 66.5% | 52.2%
^a, b^Gerr ^31^ | 8 | 50 | 2 | 121 | 13.8% 7.1% 25.2% | 98.4% 94.1% 99.6% | 80.0% 48.4% 94.5% | 70.8% 63.4% 77.2% | 32.0%
Ghavanini ^154^ | 24 | 52 | 9 | 49 | 31.6% 22.1% 42.9% | 84.5% 72.8% 91.7% | 72.7% 55.4% 85.1% | 48.5% 38.8% 58.3% | 56.7%
González del Pino ^104^ | 42 | 87 | 6 | 194 | 32.6% 24.9% 41.2% | 97.0% 93.5% 98.6% | 87.5% 75.0% 94.2% | 69.0% 63.3% 74.3% | 39.2%
^a^Seror ^156^ | 63 | 37 | 18 | 22 | 63.0% 53.0% 72.0% | 55.0% 39.5% 69.6% | 77.8% 67.4% 85.6% | 37.3% 25.9% 50.3% | 71.4%
Stewart ^157^ | 23 | 28 | 15 | 37 | 45.1% 32.0% 58.9% | 71.2% 57.4% 81.8% | 60.5% 44.4% 74.6% | 56.9% 44.6% 68.5% | 49.5%
^a^Szabo ^152^ | 56 | 31 | 1 | 99 | 64.4% 53.7% 73.8% | 99.0% 94.4% 99.8% | 98.2% 90.5% 99.7% | 76.2% 68.0% 82.8% | 46.5%
^a^Tetro ^102^ | 70 | 25 | 9 | 87 | 73.7% 63.8% 81.6% | 90.6% 82.9% 95.1% | 88.6% 79.5% 94.0% | 77.7% 68.9% 84.5% | 49.7%
Meta-analysis results (mean threshold) | | | | | NA | NA

TP-true positive, FN-false negative, FP-false positive, TN-true negative

Sen.-sensitivity, Spec-specificity, PPV-positive predictive value, NPV-negative predictive value, Prev.-prevalence of CTS Confidence intervals on sensitivity, specificity, PPV, NPV calculated by Wilson method

NA—Results not valid because of excessive heterogenity in study results

a Results calculated by ECRI from published percentages

b Errors in published results corrected by ECRI

The heterogeneity is evident in Figure 13. Sensitivity/specificity results are widely dispersed in the graph, and there is no pattern of results that is obvious on inspection. The data suggest that Tinel's sign has some ability to diagnose CTS, but the sensitivity and specificity of the test are uncertain. However, the sensitivity of the test appears to be low.

Figure 13. Diagnostic Trial Results for Tinel's Sign

To see whether other factors, particularly those relating to the validity or generalizability of results, could explain the observed heterogeneity, we repeated the heterogeneity tests for groups defined by reporting criteria in Table 13 and Table 15. The results of those analyses are shown in Table 33. Significant heterogeneity remained regardless of the criteria used to group trials. Therefore none of these criteria are sufficient to explain the heterogeneity that prevents us from meta-analyzing the results.

Table 33. Heterogeneity of Diagnostic Trial Results for Tinel's Sign

Group | Q (p-value) for larger group
All articles (N = 11) | 59.1 (p <0.000001)
Patients selected with complex objective standard (N = 9) v. other selection | 46.1 (p <0.000001)
Not funded by for-profit device or drug manufacturer (N = 5) v. not reported | 10.7 (p = 0.057)
Reported both inclusion and exclusion criteria (N = 6) v. reported only inclusion criteria | 30.2 (p = 0.000013)
Prospective patient selection (N = 4) v. not reported | 16.6 (p = 0.011)
Comorbidity reported (N = 2) v. not reported | 51.4 (p <0.000001)
Mean ages of patients, controls within 5 years (N = 6) v. possible age bias | 37.8 (p <0.000001)
Possible sex bias (N = 3) vs. sex ratios of patients, controls within 20% of each other (N = 8) | 52.8 (p <0.000001)
Duration of condition reported (N = 2) v. not reported | 50.6 (p <0.000001)
Independent reference standard (N = 6) v. no independent reference standard reported | 16.5 (p = 0.005545)
Patients given both study test and reference test (N = 3) v. did not do so | 51.6 (p <0.000001)
Studies done in USA (N = 5) v. other countries | 22.3 (p = 0.000454)
Potential selection bias for easy cases (N = 4) v. no bias or not reported | 41.9 (p <0.000001)

Q—Q-statistic, with probability that variability in study results [D, logit (sensitivity) + logit (specificity)] is the result of random variability within a homogeneous sample of studies.

#### Articles on Carpal Tunnel Syndrome Screening

Screening tests are intended to identify persons at risk of developing a condition in the future, not those who already have the condition. Because there is no agreement on what constitutes screening for CTS, we accepted any studies so described by their authors as screening studies. There were 28 articles described by their authors as screening studies. Two (Bland ^200^ and Rosen ^201^ ) were excluded from this analysis because they required all participants to be symptomatic. Two ^202,^ ^203^ were sequential reports on the same study. Therefore, 25 studies (Table 34) were included in the analysis of screening of carpal tunnel syndrome. Twenty-two of the studies screened workers at risk, and the remaining three studies screened the general population; the table is stratified according to these two categories.

Table 34. Articles Described as Screening Studies

Article | N | Population | Symptoms | Positive NCS | Symptoms & Positive NCS
Workers-at-risk screening studies for carpal tunnel syndrome
Kearns, 2000 ^204^ | 45 | Pork processors | NR | NR | NR
Missere, 1999 ^205^ | 45 | Meat manufacturers | NR | ^a^ 28.9% | NR
Nathan, 1998 ^202^ | 283 | Steel mill workers, food processors, electronics workers, and plastics workers | 12.9% | 43.0% | 8.2%
Tan, 1998 ^206^ | 64 | Carpet weavers | NR | NR | NR
Werner, 1998 ^207^ | 119 | Automobile parts manufacturers | NR | 27% | ^b^ 20.2%
| 98 | Furniture manufacturers | NR | 26% | ^b^ 10.2%
| 77 | Paper containers manufacturers | NR | 34% | ^b^ 14.3%
| 64 | Automobile parts manufacturers | NR | 30% | ^b^ 17.2%
| 164 | Clerical insurance workers | NR | 15% | ^b^ 11.0%
| 202 | Spark plugs manufacturers | NR | 28% | ^b^ 9.4%
Franzblau, 1997 ^208^ | 148 | Automobile parts manufacturers | 41% | NR | NR
Jeng, 1997 ^209^ | 27 | Food processors | 48.8% | 34.1% | 22.0%
Werner, 1997 ^210^ | 59 | Manufacturing workers and clerical workers | 11.1% | 45.4% | 5.6%
Bingham, 1996 ^211^ | 1021 | Applicants for jobs in meat packers, plastics assemblers, food processors, furniture manufacturers, or grocery warehousing workers | ^c^ 6.0% | ^a^ 17.4% | ^c^ 1.8%
Murata, 1996 ^164^ | 27 | Data entry operators | NR | 37% | NR
Pierre-Jerome, 1996 ^212^ | 24 | Floor cleaners | NR | NR | NR
Werner, 1995 ^213^ | 167 | Automobile parts manufacturers | 19.8% | 24.6% | 9.0%
Young, 1995 ^166^ | 157 | Poultry processors | 70%b | 31% | NR
Franzblau, 1994 ^113^ | 84 | Automobile parts manufacturers | 21.4% | 19.3% | 8.40%
Kirschberg, 1994 ^214^ | 112 | Poultry processors | 22.3% | 29.5% | 17.0%
Nathan, 1994 ^215^ | 101 | Japanese furniture factory workers | ^a, b^4.5% | ^b^17.8% | ^b^2.0%
| 316 | Steel mill workers, food processors, electronics workers, and plastics workers | ^a, b^23.4% | ^b^22.0% | ^b^8.3%
Nilsson, 1994 ^216^ | 61 | Office workers | NR | 33% | NR
| 58 | Truck assemblers | NR | 40% | NR
| 56 | Platers | NR | 55% | NR
Werner, 1994 ^217^ | 130 | Automobile parts manufacturers | 27.7% | ^d^ 20.2% | NR
Johnson, 1993 ^167^ | 184 | Poultry processors | ^a, b^ 37.3% | ^a, b^ 19.2% | ^a, b^ 6.0%
Nathan, 1993 ^218^ | 737 | Steel mill workers, meat/food processors, electronics workers, plastics workers, aluminum reduction workers, and cable plant workers. | ^a, b^51.0% | ^a, b^ 33.6% | ^a, b^19.8%
Grant, 1992 ^219^ | 63 | Manufacturing plant workers | ^a^ 25.4% | NR | NR
Jetzer, 1991 ^168^ | 39 | Computer assemblers | NR | NR | NR
| 100 | Meat processors | NR | NR | NR
| 284 | Keyboard operators | NR | NR | NR
General population screening studies for carpal tunnel syndrome
Atroshi, 1999 ^220^ | 2466 | General population | 14.4% | ^c^ 22.3% | ^c^ 6.6%
Ferry, 1998 ^221^ | 648 | General population | 18.5% | 17.4% | 7.7%
DeKrom, 1990 ^222^ | 500 | General population | 13.8% | NR | ^c^ 7.8%

[underlined: Key]

NR-Not reported

NCS-Nerve conduction studies

a Based on hands instead of participants

b Calculated by ECRI based on information reported in the article

c Estimated by ECRI based on information reported in the article

d Prevalence of positive NCS in the study by Werner ^217^ was based on 129 participants .

The reported methods of diagnosis in the 28 screening studies appear in Table 35. The most common diagnostic criteria were symptoms (12 studies, 43%) and the difference between median and ulnar sensory tests (9 studies, 32%). Thirteen studies (46%) used both clinical criteria and nerve conduction criteria, three studies (11%) used nerve conduction criteria only, and no studies used clinical criteria only. The table demonstrates the variability in authors' methods for screening for CTS. As with the diagnostic articles on CTS, we tabulated the number of screening articles reporting use of each particular test (Table 36, Table 37, Table 38, Table 39, Table 40). In no case were there sufficient articles reporting a particular test to meet our a priori criteria for meta-analyzing their data.

Table 35. Definitions of CTS Reported in Screening Articles

Author, Year | Clinical findings | | | Nerve conduction studies | | | | | | Comments
| SYM | CLN | OTH CLN | DML | DSL | PAL | SEN DIF | MOT DIF | OTH NCS
Bland, 2000 ^200^ | □ | □ | □ | | □ | □ | □ | □ | | If tests equivocal, authors measured sensory potential or inching test
Kearns, 2000 ^204^ | □ | □ | □ | □ | □ | □ | □ | □ | □ | NR
Atroshi, 1999 ^220^ | | | □ | □ | □ | □ | | □ | □
Missere, 1999 ^205^ | □ | □ | □ | □ | □ | □ | □ | □
Ferry, 1998 ^221^ | □ | □ | □ | □ | □ | □ | □ | □ | □ | NR
Nathan, 1998 ^202^ | | □ | □ | □ | | | □ | □
Rosen, 1998 ^201^ | □ | □ | □ | □ | □ | □ | □ | □ | □ | NR
Tan, 1998 ^206^ | □ | □ | □ | □ | □ | □ | □ | □ | □ | NR
Werner, 1998 ^207^ | | □ | □ | □ | □ | □ | | □ | □
Franzblau, 1997 ^208^ | □ | □ | □ | □ | □ | □ | □ | □ | □ | NR
Jeng, 1997 ^209^ | | □ | □ | | | □ | | □ | □
Werner, 1997 ^210^ | | □ | □ | □ | □ | □ | | □ | □
Bingham, 1996 ^211^ | □ | □ | □ | □ | □ | □ | □ | □ | □ | NR
Murata, 1996 ^164^ | □ | □ | □ | □ | □ | □ | □ | □ | □ | NR
Pierre-Jerome, 1996 ^212^ | □ | □ | □ | □ | □ | □ | □ | □ | □ | NR
Werner, 1995 ^213^ | | □ | □ | □ | □ | □ | | □ | □
Young, 1995 ^166^ | □ | □ | □ | □ | □ | □ | □ | □ | □ | NR
Franzblau, 1994 ^113^ | | □ | □ | □ | □ | □ | | □ | □
Kirschberg, 1994 ^214^ | | | | | □ | | | □
Nathan, 1994 ^215^ | | □ | □ | □ | | | □ | □
Nilsson, 1994 ^216^ | □ | □ | □ | □ | □ | □ | □ | □ | □ | NR
Werner, 1994 ^217^ | □ | □ | □ | □ | □ | □ | □ | □ | □ | NR
Johnson, 1993 ^167^ | □ | □ | □ | □ | □ | □ | □ | □ | □ | NR
Nathan, 1993 ^218^ | | □ | □ | □ | | | □ | □
Grant, 1992 ^219^ | □ | □ | □ | | | □ | | | ?
Jetzer, 1991 ^168^ | | □ | □ | □ | □ | □ | □ | □ | □ | Or positive NCS (tests not reported)
DeKrom, 1990 ^222^ | | □ | □ | | □ | □ | | □ | □
Welch, 1973 ^223^ | □ | □ | □ | □ | □ | □ | □ | □ | □ | NR
Totals | 12 | 2 | 1 | 5 | 5 | 4 | 9 | 1 | 6

[underlined: Key]

SYM—Were positive symptoms included in the author's method of diagnosis?

CLN—Was a positive clinical exam included in the author's method of diagnosis?

OTH CLN—Were other clinical findings included in the author's method of diagnosis?

DML—Was distal motor latency included in the author's method of diagnosis?

DSL—Was distal sensory latency included in the author's method of diagnosis?

PAL—Was palmar sensory latency included in the author's method of diagnosis?

SEN DIF—Was the difference between median and ulnar sensory studies included in the author's method of diagnosis?

MOT DIF—Was the difference between median and ulnar motor studies included in the author's method of diagnosis?

OTH NCS—Were other nerve conduction studies included in the author's method of diagnosis?

NR—Method of diagnosis was not reported

Table 36. Signs and Symptoms Reported in Screening Articles

Legend:
First entry in cell—Total number of articles
Second entry in cell—Number of articles with derivable sensitivity and specificity
Sign/symptom | Number of articles reporting
Clinical exam and history | 1, 0
Durkan compression | 1, 1
Flick sign | 1, 1
Flick: Does shaking alleviate night symptoms? | 1, 1
Gilliat tourniquet | 1, 1
Grip strength | 2, 0
Hypalgesia | 1, 0
Hyperpathia | 1, 0
Lateral pinch strength | 1, 0
Luthy's test | 1, 1
Night symptoms | 1, 1
Opponens pollicus weakness | 1, 1
Phalen's/reverse Phalen's | 3, 2
Right or left hand worse? Or bilateral? | 1, 1
Signs | 1, 0
Symptoms measured systematically | 15, 7
Symptoms | 2, 0
Symptoms and signs | 1, 0
Thenar atrophy | 1, 1
Thenar weakness | 1, 1
Three-point pinch strength | 1, 0
Tinel's | 3, 2
When are symptoms worse? | 1, 1
Which fingers are worst affected? | 1, 1

Table 37. Sensory Tests Reported in Screening Articles

Legend:
First entry in cell—Total number of articles
Second entry in cell—Number of articles with derivable sensitivity and specificity
Sensory test | Number of articles reporting
Current perception | 1, 1
Gap detection test | 1, 1
Semmes-Weinstein monofilament | 1, 0
Tactile discrimination | 1, 1
Vibrometer | 6, 3

Table 38. Nerve Conduction Tests Reported in Screening Articles

Legend:
Nerve tested: MED-median, RAD-radial, ULN-ulnar
Nerve tested: MOT-motor, SEN-Sensory
Configuration (not applicable to motor nerve tests: OR-orthodromic, AN-antidromic
Stimulation/measurement sites: ELB-elbow, FOR-forearm, WR-wrist, PAL-palm, IN-index finger, MI-middle finger, RI-ring finger, LI-little finger, APB-abductor policis brevis, ADM -abductor digiti minimi, OTH-other
Measured parameter: LAT-latency, AMP-amplitude, VEL-velocity, INCH-inching, OTH-other
Blank cells—characteristic not reported
First entry in cell—Total number of articles
Second entry in cell—Number of articles with derivable sensitivity and specificity
Numeric entries—Total number of articles, articles from which sensitivity and specificity can be calculated
Nerve tested | | Configuration | Stimulation site | Measurement site | Parameter measured | Number of articles reporting
MED | MOT | | | | LAT | 2, 0
MED | MOT | | FOR | APB | LAT | 1, 1
MED | MOT | | WR | APB | LAT | 4, 2
MED | MOT | | WR | APB | VEL | 1, 1
MED | MOT | | WR | OTH | AMP | 1, 0
MED | MOT | | WR | OTH | LAT | 3, 2
MED | MOT | | WR | OTH | VEL | 1, 0
MED | SEN | | | | AMP | 1, 0
MED | SEN | | | | LAT | 4, 0
MED | SEN | | | | OTH | 1, 1
MED | SEN | AN | | | LAT | 1, 1
MED | SEN | AN | PAL | IN | VEL | 1, 1
MED | SEN | AN | PAL | MI | AMP | 1, 1
MED | SEN | AN | PAL | MI | VEL | 1, 1
MED | SEN | AN | WR | IN | AMP | 2, 2
MED | SEN | AN | WR | IN | LAT | 5, 3
MED | SEN | AN | WR | IN | VEL | 1, 1
MED | SEN | AN | WR | MI | AMP | 1, 1
MED | SEN | AN | WR | MI | INCH | 3, 1
MED | SEN | AN | WR | MI | VEL | 1, 1
MED | SEN | AN | WR | OTH | LAT | 3, 1
MED | SEN | AN | WR | PAL | VEL | 2, 2
MED | SEN | AN | WR | RI | LAT | 1, 1
MED | SEN | OR | IN | WR | LAT | 1, 1
MED | SEN | OR | IN | WR | VEL | 1, 0
MED | SEN | OR | PAL | WR | LAT | 5, 2
MED | SEN | OR | WR | ELB | VEL | 1, 1
ULN | MOT | | | | LAT | 1, 0
ULN | MOT | | WR | ADM | LAT | 1, 0
ULN | SEN | | | | LAT | 2, 0
ULN | SEN | AN | | | LAT | 1, 1
ULN | SEN | AN | WR | LI | AMP | 2, 2
ULN | SEN | AN | WR | LI | LAT | 4, 2
ULN | SEN | AN | WR | RI | LAT | 1, 1
ULN | SEN | OR | LI | WR | LAT | 1, 0
ULN | SEN | OR | LI | WR | VEL | 1, 0
ULN | SEN | OR | PAL | WR | LAT | 3, 2

Table 39. Composite Nerve Conduction Tests Reported in Screening Articles

Legend:
Nerves: MED—median, ULN—Ulnar
Measured parameter: LAT-latency, VEL-velocity
First entry in cell—Total number of articles
Second entry in cell—Number of articles with derivable sensitivity and specificity
First nerve | Second nerve | Motor or Sensory | Parameter Measured | Combination | Number of articles reporting
MED | MED | SEN | VEL | Ratio | 1, 1
MED | ULN | MOT | LAT | Difference | 2, 0
MED | ULN | SEN | LAT | Difference | 11, 6
ULN | MED | SEN | LAT | Difference | 1, 0
| | | | Other composite | 7, 3

Table 40. Imaging Tests Reported in Screening Articles

Legend:
First entry in cell—Total number of articles
Second entry in cell—Number of articles with derivable sensitivity and specificity
Imaging modality | Number of articles reporting
CT | 1, 0
MRI | 1, 0
Ultrasound | 1, 1

The presence of symptoms and the presence of a positive nerve conduction test appeared to be independent of each other in the screening studies. Figure 14 plots the prevalence of symptoms on the horizontal axis and the prevalence of positive nerve conduction tests on the vertical axis. We could only plot the 15 studies that reported both variables. The correlation between symptoms and nerve conduction was 0.21 (r^2^ = 0.04) and was not statistically different from zero. Because two of the 15 studies screened a general population, we recomputed the correlation after removing these two studies. The correlation was 0.16 (r^2^ = 0.02) and was not statistically different from zero. The weak association between symptoms and abnormal nerve conduction suggests that a high incidence of CTS symptoms in workers at risk does not necessarily imply that those same workers will have a high incidence of abnormal nerve conduction.

Figure 14. Association of Symptoms with Positive NCS Findings in Screening Studies

Lack of agreement on what constitutes carpal tunnel syndrome is another obstacle to analyzing these studies. Table 41 lists all the different criteria used to define true cases of CTS in the screening articles. In 13 of the 28 articles (46%), the criteria were not reported at all. The majority of articles that did report criteria (80%) considered both nerve conduction and symptoms; the others used nerve conduction only. In some cases, it was not clearly reported how the elements of the diagnosis were to be combined: whether any sign of CTS would be considered diagnostic for the condition or whether all the criteria must be met.

Table 41. Definitions of CTS Reported in Screening Articles

Article | Method of diagnosis used to determine patient condition
Bland, 2000 ^200^ | Median and ulnar sensory conduction (velocity?), DML to APB. Sensory potential or segmental study of conduction used if previous tests equivocal. Threshold 2.5 SD from the mean.
Kearns, 2000 ^204^ | Not reported
Atroshi, 1999 ^220^ | Two definitions: 1) Symptoms and positive clinical exam. Symptoms were pain, numbness and/or tingling in 2 or more of the first 4 fingers at least twice weekly during the preceding 4 weeks, as stated on a questionnaire. Clinical exam required the presence of nocturnal and/or activity-related numbness and/or tingling involving the palmar aspects of at least 2 of the first 4 fingers. The presence of median nerve sensory and/or motor deficit was supportive of the diagnosis but not necessary. 2) Symptoms and positive clinical exam and positive nerve conduction. Included the same definitions as above, and in addition required a difference of 0.8 ms or more between the median sensory latency (middle finger to wrist) and the ulnar sensory latency (little finger to wrist).
Missere, 1999 ^205^ | SCV <42.5 m/s as measured by the nerve conduction inching test.
Ferry, 1998 ^221^ | Not reported
Nathan, 1998 ^202^ | Symptoms and abnormal nerve conduction. Symptoms defined as positive when the patient has either one of two sets of symptoms: 1) Two or more specific CTS symptoms such as numbness, tingling, nocturnal awakening occurring at least twice per month in the median nerve distribution. 2) One specific CTS symptoms and two or more nonspecific symptoms such as pain, tightness, clumsiness occurring at least twice per month in the median nerve distribution. NCS was defined as abnormal when a patient had any of the following three abnormalities: 1) Maximum latency difference = 0.4 ms in the orthodromic inching test. 2) Antidromic wrist-to-digit sensory latency >3.6 ms. 3) Orthodromic palm to wrist sensory latency >2.2 ms
Rosen, 1998 ^201^ | Not reported
Tan, 1998 ^206^ | Not reported
Werner, 1998 ^207^ | Nerve conduction abnormality defined as a difference >0.5 ms between median and ulnar antidromic sensory latencies to index and little fingers, respectively. Symptom abnormality defined as numbness, tingling, burning, or pain in the wrist, fingers, or hand.
Franzblau, 1997 ^208^ | Not reported
Jeng, 1997 ^209^ | Two definitions: One required both symptoms and abnormal conduction, and the other required either symptoms or abnormal nerve conduction :Symptoms: tingling, numbness, pain, perceived weakness, and clumsiness.Nerve conduction was abnormal on any of the following three tests: 1) DML >4.5 ms. 2) Antidromic sensory latency from index finger >3.7 ms. 3) Difference between median palm-to-wrist latency and ulnar palm-to-wrist latency >0.5 ms.
Werner, 1997 ^210^ | Difference between median and ulnar sensory latency >0.5 ms, and symptoms.
Bingham, 1996 ^211^ | Not reported
Murata, 1996 ^164^ | Not reported
Pierre-Jerome, 1996 ^212^ | Not reported
Werner, 1995 ^213^ | Symptoms and abnormal NCS. Positive symptoms were defined as any of the following: numbness, tingling, buning, pain, or nocturnal paresthesia in the hand. Abnormal CTS was defined as a difference greater than 0.5 ms between the median and ulnar sensory antidromic latencies.
Young, 1995 ^166^ | Not reported
Franzblau, 1994 ^113^ | Symptoms and abnormal nerve conduction. Positive symptoms was defined as having both 1) numbness, tingling, burning, or pain in the fingers, hand, wrist, or forearm and 2) nocturnal occurrence of above symptoms. Abnormal nerve conduction was defined as a difference >0.5 between median sensory antidromic wrist-to-index latency and ipsilateral ulnar sensory antidromic wrist-to-little-finger latency.
Kirschberg, 1994 ^214^ | Clinical CTS: One or more of the following 7 findings: 1) nocturnal paresthesia of the hand, relieved by shaking; 2) sensory symptoms in the specific distribution of the median nerve; 3) specific median nerve sensory loss; 4) positive Phalen's sign; 5) Positive Tinel's sign; 6) Thenar atrophy; 7) Thenar weakness. Electrodiagnostic CTS (using Mayo Clinic criteria) involved any of the following 4 findings: 1) Median DML >4.6 ms; 2) Median palmar sensory latency >2.2 ms; 3) Difference >0.2 ms between median and ulnar palmar latencies; 4) Difference >1.8 ms between median and ulnar latencies.
Nathan, 1994 ^215^ | Symptoms and abnormal nerve conduction. Symptoms defined as positive when the patient has either one of two sets of symptoms: 1) Two or more specific CTS symptoms such as numbness, tingling, nocturnal awakening occurring at least twice per month in the median nerve distribution 2) One specific CTS symptom and two or more nonspecific symptoms such as pain, tightness, clumsiness occurring at least twice per month in the median nerve distribution. NCS was defined as abnormal when a patient had any of the following three abnormalities: 1) Maximum latency difference = 0.4 ms in the orthodromic inching test. 2) Antidromic wrist-to-digit sensory latency >3.6 ms 3) Orthodromic palm to wrist sensory latency >2.2 ms
Nilsson, 1994 ^216^ | Not reported
Werner, 1994 ^217^ | Not reported
Johnson, 1993 ^167^ | Not reported
Nathan, 1993 ^218^ | Symptoms and abnormal nerve conduction. Symptoms defined as positive when the patient has either one of two sets of symptoms: 1) Two or more specific CTS symptoms such as numbness, tingling, nocturnal awakening occurring at least twice per month in the median nerve distribution 2) One specific CTS symptoms and two or more nonspecific symptoms such as pain, tightness, clumsiness occurring at least twice per month in the median nerve distributionNCS was defined as abnormal when a patient had any of the following three abnormalities: 1) Maximum latency difference = 0.4 ms in the orthodromic inching test. 2) Antidromic wrist-to-digit sensory latency >3.6 ms 3) Orthodromic palm to wrist sensory latency >2.2 ms
Grant, 1992 ^219^ | Median DML >4.5 ms or median DSL >3.5 ms or median-ulnar DML difference >1.2 ms or median-ulnar DSL difference >0.5 ms
Jetzer, 1991 ^168^ | Symptoms and either positive EMG or recent prior carpal tunnel surgery.
DeKrom, 1990 ^222^ | Nocturnal paresthesia at least twice a week and either DML >4.5 ms or a difference >0.4 ms between median and ulnar antidromic latencies to the ring finger.
Welch, 1973 ^223^ | Not reported

The ideal study design for evaluating screening tests for WRUEDs would first test a group of at-risk persons, and then perform followup for a period of time to determine whether symptoms develop. Only six articles in our evidence base reported this kind of trial, and two reported on the same trial. The bulk of the “screening” literature was made up of articles intended to diagnose CTS in screening populations (asymptomatic workers presumed to be at risk for CTS). The five longitudinal studies of screening populations are listed in Table 42. The evidence base is small enough that each study will be discussed individually in this report.

Table 42. Screening Articles Reporting Longitudinal Results

Article | N | Population | Selection | Followup
Kearns, 2000 ^204^ | 45 | Porkprocessors | Starting employment | 42–83 days, mean 64
Nathan, 1998 ^202^ ^203^ ^218^ | 283 | Various manufacturing and clerical | Randomly-selected workers | 11 years
Werner, 1997 ^210^ | NR, though over 700 | Various manufacturing and clerical | NCS positive workers and matched controls | 10 to 24 months
Johnson, 1993 ^167^ | 184 | Meat processors | Mostly new employees | Not reported, but few followed more than 3 months

Kearns ^204^ measured nerve conduction in new workers at a pork processing plant. Tests were done before the workers started employment and after two months' employment, though the actual time of the followup test ranged from 42 days to 83 days. Only the nerve conduction tests were done; no symptoms were reported and the authors cautioned that the study was not intended to identify workers who developed CTS. Therefore, this study cannot be used to base conclusions of nerve conduction measurement as a screening test for CTS.

Nathan et al. performed the longest longitudinal study on nerve conduction measurements: 11 years. Two articles ^202,^ ^203^ reported on the same group of subjects: 471 workers from a variety of manufacturing and clerical jobs. Their initial testing was in 1984, with subsequent testing in 1989 (316 subjects followed) ^203^ and 1994-95 (283 subjects) ^202^ . Both inching tests and sensory latency measurements were reported in the latest article, though several other nerve conduction tests were also done.

The first followup article reports that there was a statistically significant association between slowing of nerve conduction in 1984 and CTS symptoms in 1989, but did not report sufficient data to allow us to verify these findings or determine the sensitivity and specificity of the test. There were sufficient data of this type reported from the 1994-95 followup to calculate sensitivity and specificity of one nerve conduction test: the “maximum latency difference” test, which is a variation of the inching test. We reanalyzed this data: the resulting sensitivities and specificities at different threshold values are shown in Table 43 and an ROC curve fitted to the data using the logit regression method is shown in Figure 15. While it is clear that this test had a significant ability to predict future CTS in this screening population, this is just one of several nerve conduction tests done in this study, and the possibility of a chance result cannot be discounted. Independent confirmation of this finding would be necessary for us to conclude that this is an effective predictive test. Reanalysis of the unpublished results from this study could verify whether or not other nerve conduction tests also predict future CTS, and could help clinicians decide which test is most effective.

Table 44. Carpal Tunnel Syndrome-Study Design

Article | SGN | SEN | NCS | CMP | IMG | OTH | Centers | CTS groups | CTS pts. | Neg. groups | Neg. subjects | Prospective or retrospective | Level of reporting | Could sensitivity & specificity be determined?
Finsen, 2001 ^224^ | | □ | □ | | □ | □ | Single | 1 | 68 | 0 | 0 | Prospective | Counts | No: thresholds not reported
Mondelli, 2001 ^181^ | □ | □ | | □ | □ | | Single | 1 | 20 | 1 | 19 | Not reported | Counts | Calculated by ECRI
Atroshi, 2000 ^225^ | □ | □ | | □ | □ | □ | Single | 1 | 262 | 1 | 125 | Prospective | Summary | No: only summary statistics reported
Bland, 2000 ^200^ | | □ | □ | □ | □ | | Single | 1 | 8223 | 1 | 3533 | Retrospective | Counts | Reported by authors
Cuturic, 2000 ^226^ | □ | □ | | □ | □ | | Single | 1 | 19 | 1 | 16 | Prospective | Patient level | Calculated by ECRI
Kearns, 2000 ^204^ | □ | □ | | | □ | □ | Single | 1 | 45 | 0 | 0 | Prospective | Summary | No: only summary statistics reported
Loscher, 2000 ^175^ | □ | □ | | | □ | □ | Single | 2 | NR | 1 | 87 | Prospective | Counts | Reported by authors
Montagna, 2000 ^227^ | □ | □ | □ | □ | □ | | Single | 1 | 30 | 1 | 15 | Not reported | Counts | Reported by authors
Nakamichi, 2000 ^228^ | □ | □ | | □ | | □ | Single | 1 | 125 | 1 | 200 | Not reported | Summary | No: only summary statistics reported
Raudino, 2000 ^229^ | | □ | □ | □ | □ | □ | Single | 1 | 83 | 0 | 0 | Not reported | Counts | Reported by authors
Resende, 2000 ^184^ | □ | □ | | | □ | □ | Single | 1 | 32 | 1 | 20 | Not reported | Patient level | Calculated by ECRI
Resende, 2000 ^174^ | □ | □ | | □ | □ | □ | Single | 1 | 20 | 1 | 20 | Not reported | Patient level | Calculated by ECRI
Sener, 2000 ^186^ | | □ | | □ | □ | | Single | 1 | 31 | 1 | 21 | Not reported | Counts | Calculated by ECRI
Seror, 2000 ^158^ | □ | □ | | | □ | □ | Single | 1 | 20 | 1 | 20 | Not reported | Counts | Reported by authors
Stalberg, 2000 ^230^ | □ | □ | □ | | □ | □ | Single | 1 | 136 | 1 | 32 | Not reported | Counts | Reported by authors
Weber, 2000 ^108^ | | | □ | | □ | □ | Single | 1 | 53 | 1 | 26 | Not reported | Counts | Reported by authors
Atroshi, 1999 ^220^ | | □ | | | □ | □ | Single | 1 | 2466 | 0 | 0 | Prospective | Counts | No: only one patient group
Burke, 1999 ^231^ | | □ | | | □ | □ | Multiple (<5) | 1 | 186 | 0 | 0 | Prospective | Counts | Calculated by ECRI
Duncan, 1999 ^232^ | □ | □ | □ | □ | | □ | Single | 1 | 68 | 1 | 36 | Prospective | Counts | Reported by authors
Kabiraj, 1999 ^233^ | □ | □ | | | □ | □ | Single | 1 | 31 | 1 | 38 | Not reported | Counts | Calculated by ECRI
Lee, 1999 ^234^ | □ | □ | □ | □ | | □ | Single | 1 | 50 | 1 | 28 | Prospective | Counts | Reported by authors
Missere, 1999 ^205^ | □ | □ | | □ | | □ | Single | 1 | 45 | 0 | 0 | Not reported | Counts | Reported by authors
Mongale, 1999 ^235^ | □ | □ | □ | □ | | □ | Single | 1 | 8 | 2 | 16 | Not reported | Summary | No: only summary statistics reported
Murthy, 1999 ^143^ | □ | □ | | | □ | | Single | 1 | 84 | 1 | 37 | Not reported | Counts | Reported by authors
Rudolfer, 1999 ^236^ | □ | □ | □ | | □ | □ | Single | 1 | 937 | 0 | 0 | Retrospective | Counts | Calculated by ECRI
Sander, 1999 ^237^ | □ | □ | | | □ | | Single | 1 | 59 | 1 | 34 | Prospective | Counts | Reported by authors
Simovic, 1999 ^183^ | □ | □ | | | □ | □ | Single | 2 | 66 | 1 | 19 | Prospective | Counts | Reported by authors
Szabo, 1999 ^152^ | | | | □ | □ | | Single | 1 | 50 | 2 | 100 | Prospective | Counts | Reported by authors
Thonnard, 1999 ^117^ | □ | | | | □ | | Single | 1 | 11 | 1 | 10 | Prospective | Summary | No: only summary statistics reported
Wang, 1999 ^238^ | □ | □ | | | □ | □ | Single | 1 | 12 | 1 | 12 | Prospective | Summary | No: only summary statistics reported
Aurora, 1998 ^239^ | □ | □ | | □ | □ | □ | Single | 1 | 19 | 1 | 20 | Not reported | Summary | No: only summary statistics reported
Ferry, 1998 ^221^ | | □ | | | □ | □ | Single | 1 | 648 | 0 | 0 | Prospective | Counts | Reported by authors
Fertl, 1998 ^153^ | | □ | | □ | □ | | Single | 1 | 47 | 1 | 20 | Prospective | Counts | Reported by authors
Gerr, 1998 ^31^ | | | | | □ | | Single | 1 | 60 | 1 | 59 | Not reported | Counts | Reported by authors
Ghavanini, 1998 ^154^ | | | | □ | □ | □ | Single | 1 | 74 | 1 | 58 | Prospective | Counts | Reported by authors
Girlanda, 1998 ^149^ | | □ | | | □ | □ | Single | 1 | 41 | 1 | 45 | Not reported | Counts | Reported by authors
Kabiraj, 1998 ^240^ | □ | □ | | | □ | □ | Single | 1 | 72 | 1 | 65 | Retrospective | Summary | No: only summary statistics reported
Kleindienst, 1998 ^241^ | □ | □ | □ | □ | | □ | Single | 1 | 77 | 1 | 18 | Prospective | Summary | No: only summary statistics reported
Luchetti, 1998 ^242^ | □ | □ | □ | □ | □ | | Single | 1 | 39 | 1 | 12 | Not reported | Summary | No: only summary statistics reported
Nathan, 1998 ^202^ | | □ | | | □ | □ | Single | 1 | 283 | 0 | 0 | Prospective | Counts | No: only one patient group
Rosen, 1998 ^201^ | □ | | □ | □ | □ | □ | Single | 2 | 34 | 1 | 60 | Prospective | Counts | Reported by authors
Scelsa, 1998 ^243^ | □ | □ | | □ | □ | □ | Single | 2 | 63 | 1 | 25 | Prospective | Counts | Reported by authors
Seror, 1998 ^159^ | □ | □ | | □ | □ | □ | Single | 1 | 85 | 1 | 80 | Not reported | Counts | Reported by authors
Smith, 1998 ^244^ | □ | □ | | □ | □ | □ | Single | 1 | 82 | 0 | 0 | Prospective | Counts | Calculated by ECRI
Tan, 1998 ^206^ | □ | □ | | □ | | □ | Single | 1 | 64 | 1 | 56 | Not reported | Summary | No: only summary statistics reported
Terzis, 1998 ^162^ | □ | □ | | □ | □ | □ | Single | 1 | 72 | 1 | 43 | Not reported | Counts | Reported by authors
Tetro, 1998 ^102^ | | | | □ | □ | | Single | 1 | 64 | 1 | 50 | Prospective | Counts | Reported by authors
Werner, 1998 ^207^ | | □ | | | □ | □ | Multiple (>5) | 1 | 727 | 0 | 0 | Prospective | Counts | No: only one patient group
Wilson, 1998 ^245^ | □ | □ | | | □ | □ | Single | 1 | 23 | 1 | 14 | Not reported | Summary | No: only summary statistics reported
Bak, 1997 ^246^ | □ | □ | □ | | | □ | Single | 1 | 20 | 0 | 0 | Prospective | Counts | No: no control group
Brahme, 1997 ^199^ | | □ | □ | □ | | □ | Single | 1 | 20 | 1 | 15 | Prospective | Counts | Reported by authors
Bronson, 1997 ^163^ | □ | □ | | | □ | □ | Single | 1 | 22 | 1 | 16 | Prospective | Patient level | Calculated by ECRI
Del Pino, 1997 ^104^ | | □ | □ | □ | □ | □ | Single | 1 | 180 | 1 | 100 | Prospective | Counts | Reported by authors
Dellon, 1997 ^107^ | | | □ | □ | □ | □ | Single | 1 | 72 | 2 | 94 | Not reported | Counts | No: inconsistent thresholds
Franzblau, 1997 ^208^ | | □ | □ | □ | □ | □ | Single | 1 | 148 | 0 | 0 | Prospective | Summary | No: only summary statistics reported
Guglielmo, 1997 ^247^ | □ | □ | | | □ | □ | Single | 1 | 198 | 1 | 69 | Prospective | Summary | No: only summary statistics reported
Gunnarsson, 1997 ^248^ | | □ | | | □ | □ | Single | 1 | 100 | 0 | 0 | Prospective | Counts | Reported by authors
Horch, 1997 ^249^ | □ | □ | □ | □ | | □ | Single | 1 | 19 | 1 | 17 | Not reported | Summary | No: only summary statistics reported
Jeng, 1997 ^209^ | | | | | □ | | Single | 1 | 27 | 0 | 0 | Prospective | Counts | Reported by authors
Kaneko, 1997 ^250^ | □ | □ | | | □ | □ | Single | 1 | 15 | 3 | 66 | Not reported | Summary | No: only summary statistics reported
King, 1997 ^114^ | □ | | □ | □ | □ | □ | Single | 1 | 29 | 1 | 100 | Not reported | Summary | No: only summary statistics reported
Pierre-Jerome, 1997 ^251^ | □ | □ | | □ | | □ | Single | 1 | 27 | 1 | 28 | Prospective | Summary | No: only summary statistics reported
Radack, 1997 ^252^ | □ | □ | □ | □ | | □ | Single | 1 | 161 | 1 | NR | Retrospective | Counts | Reported by authors
Rosecrance, 1997 ^253^ | □ | □ | □ | | □ | | Single | 1 | 28 | 1 | 25 | Not reported | Summary | No: only summary statistics reported
Simovic, 1997 ^182^ | □ | □ | | | □ | □ | Single | 1 | 107 | 1 | 15 | Retrospective | Counts | Reported by authors
Werner, 1997 ^210^ | □ | □ | | | □ | □ | Single | 2 | 108 | 0 | 0 | Retrospective | Counts | No: incomplete reporting
Andary, 1996 ^196^ | □ | □ | | | □ | □ | Single | 1 | 81 | 1 | 17 | Prospective | Counts | Reported by authors
Atroshi, 1996 ^136^ | □ | □ | | □ | □ | □ | Single | 1 | 36 | 2 | 60 | Prospective | Counts | Reported by authors
Bingham, 1996 ^211^ | | □ | | | □ | □ | Single | 1 | 1021 | 0 | 0 | Prospective | Counts | No: only one patient group
Checkosky, 1996 ^254^ | □ | | □ | □ | □ | □ | Single | 1 | 24 | 1 | 20 | Not reported | Patient level | Reported by authors
Cherniak, 1996 ^190^ | □ | | | | □ | | Single | 1 | 49 | 1 | 10 | Not reported | Counts | Reported by authors
Foresti, 1996 ^192^ | □ | □ | | | □ | □ | Single | 1 | 100 | 1 | 25 | Prospective | Counts | Reported by authors
Ghavanini, 1996 ^255^ | □ | □ | | | □ | □ | Single | 1 | 50 | 1 | 50 | Not reported | Summary | No: only summary statistics reported
Kleindienst, 1996 ^256^ | □ | □ | □ | □ | | □ | Single | 1 | 55 | 1 | 18 | Not reported | Counts | Reported by authors
Murata, 1996 ^164^ | | □ | | | □ | □ | Single | 1 | 27 | 1 | 19 | Not reported | Counts | Calculated by ECRI
Padua, 1996 ^165^ | □ | □ | | | □ | | Single | 1 | 43 | 1 | 36 | Not reported | Counts | Reported by authors
Pierre-Jerome, 1996 ^212^ | | □ | | □ | | □ | Single | 1 | 24 | 1 | 19 | Prospective | Summary | No: only summary statistics reported
Britz, 1995 ^257^ | | □ | | | | | Single | 1 | 32 | 1 | 5 | Prospective | Patient level | No: results not reported for controls
De Smet, 1995 ^101^ | | □ | □ | □ | □ | □ | Single | 2 | 50 | 2 | 55 | Not reported | Counts | Reported by authors
Gerr, 1995 ^118^ | □ | | □ | □ | □ | □ | Single | 2 | 60 | 1 | 59 | Not reported | Counts | Reported by authors
Glass, 1995 ^28^ | | □ | | □ | □ | □ | Single | 1 | 82 | 1 | 24 | Not reported | Counts | Calculated by ECRI
Golovchinsky, 1995 ^258^ | □ | □ | | | □ | | Single | 1 | 571 | 0 | 0 | Retrospective | Counts | Reported by authors
Hamanaka, 1995 ^259^ | □ | □ | | | □ | | Single | 2 | 647 | 1 | 31 | Retrospective | Counts | Calculated by ECRI
Hansson, 1995 ^137^ | □ | □ | | | □ | □ | Single | 2 | 30 | 1 | 10 | Not reported | Counts | Reported by authors
Kothari, 1995 ^260^ | □ | □ | | □ | □ | □ | Single | 1 | 59 | 1 | 30 | Not reported | Summary | No: only summary statistics reported
Lang, 1995 ^109^ | | | | □ | □ | | Single | 1 | 23 | 1 | 16 | Prospective | Counts | Reported by authors
Lesser, 1995 ^261^ | □ | □ | | | □ | | Single | 1 | 45 | 1 | 20 | Not reported | Counts | Reported by authors
Nakamichi, 1995 ^262^ | □ | □ | □ | □ | | □ | Single | 1 | 15 | 1 | 15 | Not reported | Patient level | Calculated by ECRI
Seradge, 1995 ^263^ | □ | □ | □ | □ | □ | | Single | 1 | 72 | 1 | 21 | Not reported | Summary | No: only summary statistics reported
Seror, 1995 ^179^ | □ | □ | | | □ | □ | Single | 3 | 75 | 1 | 40 | Not reported | Counts | Reported by authors
Shafshak, 1995 ^264^ | □ | □ | | □ | □ | | Single | 2 | 36 | 2 | 36 | Not reported | Counts | No: no diagnostic results reported
Sheean, 1995 ^191^ | □ | □ | | | □ | □ | Single | 1 | 49 | 1 | NR | Not reported | Counts | Calculated by ECRI
Tassler, 1995 ^115^ | □ | | □ | | □ | □ | Single | 1 | 14 | 1 | 13 | Retrospective | Counts | Reported by authors
Valls-Sole, 1995 ^265^ | □ | □ | | | □ | □ | Single | 1 | 18 | 1 | 15 | Prospective | Summary | No: only summary statistics reported
Werner, 1995 ^213^ | | | | | □ | □ | Single | 1 | 167 | 0 | 0 | Not reported | Counts | Reported by authors
Young, 1995 ^166^ | | | | □ | □ | □ | Single | 1 | 157 | 0 | 0 | Prospective | Counts | No: only one patient group
Clifford, 1994 ^266^ | □ | □ | | | □ | □ | Single | 1 | 20 | 1 | 10 | Not reported | Summary | No: only summary statistics reported
Durkan, 1994 ^267^ | | □ | □ | □ | □ | □ | Single | 1 | 30 | 1 | 25 | Not reported | Counts | Calculated by ECRI
Franzblau, 1994 ^113^ | | | | | □ | □ | Single | 1 | 83 | 0 | 0 | Prospective | Counts | Reported by authors
Gerr, 1994 ^197^ | | | □ | □ | □ | □ | Single | 2 | NR | 1 | NR | Not reported | Counts | Reported by authors
Kirschberg, 1994 ^214^ | | □ | | | □ | □ | Single | 1 | 112 | 0 | 0 | Retrospective | Counts | No: only one patient group
Kuntzer, 1994 ^144^ | □ | □ | | | □ | | Single | 1 | 100 | 1 | 70 | Prospective | Counts | Reported by authors
Nathan, 1994 ^215^ | | □ | | | □ | □ | Multiple (<5) | 2 | 417 | 0 | 0 | Retrospective | Counts | No: no control subjects
Nilsson, 1994 ^216^ | □ | □ | | □ | □ | □ | Single | 3 | 175 | 0 | 0 | Prospective | Counts | Reported by authors
Para, 1994 ^103^ | | □ | | | □ | | Single | 2 | 51 | 1 | 12 | Not reported | Counts | Reported by authors
Rossi, 1994 ^178^ | □ | □ | | | □ | □ | Single | 1 | 62 | 1 | 27 | Not reported | Counts | Reported by authors
Werner, 1994 ^217^ | | | | | □ | □ | Single | 1 | 130 | 0 | 0 | Prospective | Counts | Calculated by ECRI
Werner, 1994 ^111^ | | □ | | | □ | □ | Single | 1 | 31 | 1 | 20 | Not reported | Counts | Calculated by ECRI
Eisen, 1993 ^193^ | □ | □ | | | □ | □ | Single | 1 | NR | 1 | NR | Not reported | Counts | Reported by authors
Johnson, 1993 ^167^ | | □ | | □ | □ | □ | Single | 1 | 184 | 0 | 0 | Prospective | Summary | No: only summary statistics reported
Nakamichi, 1993 ^268^ | □ | □ | □ | □ | | □ | Single | 1 | 128 | 0 | 0 | Not reported | Counts | No: only one patient group
Nathan, 1993 ^218^ | | □ | | | □ | □ | Single | 2 | 1125 | 1 | 45 | Prospective | Counts | Reported by authors
Rodriquez, 1993 ^269^ | □ | □ | | □ | □ | | Single | 1 | 10 | 1 | 8 | Prospective | Patient level | Calculated by ECRI
Rosen, 1993 ^270^ | □ | | | □ | □ | □ | Single | 2 | 62 | 2 | 71 | Not reported | Counts | Calculated by ECRI
Rosén, 1993 ^138^ | □ | □ | | | □ | □ | Single | 1 | 28 | 3 | 86 | Not reported | Counts | Calculated by ECRI
Uncini, 1993 ^160^ | □ | □ | | | □ | □ | Single | 1 | 70 | 1 | 47 | Not reported | Counts | Reported by authors
Buchberger, 1992 ^271^ | □ | □ | □ | □ | | □ | Multiple (<5) | 1 | 18 | 1 | NR | Not reported | Counts | Reported by authors
Grant, 1992 ^219^ | □ | | | □ | □ | □ | Single | 1 | 22 | 1 | 47 | Not reported | Counts | Calculated by ECRI
Imaoka, 1992 ^272^ | □ | □ | | □ | □ | □ | Single | 1 | 42 | 1 | 32 | Not reported | Counts | Calculated by ECRI
Kindstrand, 1992 ^273^ | □ | □ | □ | □ | □ | | Single | 1 | 94 | 1 | 127 | Prospective | Patient level | Calculated by ECRI
Preston, 1992 ^188^ | □ | □ | | | □ | □ | Single | 1 | 8 | 1 | NR | Not reported | Counts | Calculated by ECRI
Tchou, 1992 ^274^ | □ | □ | □ | □ | □ | | Single | 1 | 61 | 1 | 40 | Not reported | Patient level | Reported by authors
Buchberger, 1991 ^275^ | □ | □ | □ | □ | | □ | Single | 1 | 25 | 1 | 14 | Not reported | Summary | No: only summary statistics reported
Chang, 1991 ^145^ | □ | □ | | | □ | □ | Single | 1 | 43 | 1 | 40 | Not reported | Counts | Calculated by ECRI
Durkan, 1991 ^155^ | | □ | □ | □ | □ | □ | Single | 1 | 31 | 1 | 50 | Not reported | Counts | Reported by authors
Jetzer, 1991 ^168^ | | | □ | □ | □ | | Single | 3 | 323 | 1 | 284 | Prospective | Counts | No: no control subjects
Katz, 1991 ^276^ | | | | | □ | | Single | 1 | 78 | 0 | 0 | Not reported | Counts | Reported by authors
Lauritzen, 1991 ^185^ | □ | □ | | | □ | | Single | 1 | 38 | 1 | 23 | Not reported | Counts | Calculated by ECRI
Luchetti, 1991 ^169^ | | □ | | | □ | □ | Single | 1 | 14 | 0 | 0 | Retrospective | Patient level | No: only one patient group
Radwin, 1991 ^116^ | □ | | □ | □ | □ | □ | Single | 1 | 12 | 1 | 15 | Not reported | Patient level | No: no diagnostic threshols used
Charles, 1990 ^170^ | □ | □ | | | □ | □ | Single | 1 | 158 | 2 | 90 | Not reported | Counts | Reported by authors
De Krom, 1990 ^222^ | | □ | | | □ | □ | Single | 1 | 50 | 0 | 0 | Prospective | Counts | Calculated by ECRI
Fitz, 1990 ^277^ | □ | □ | | | □ | □ | Single | 1 | 36 | 1 | 44 | Not reported | Counts | Calculated by ECRI
Gilliatt, 1990 ^278^ | □ | □ | | | □ | □ | Single | 1 | 10 | 1 | 15 | Not reported | Counts | Calculated by ECRI
MacDonell, 1990 ^90^ | □ | □ | | □ | □ | □ | Single | 1 | 34 | 1 | 12 | Not reported | Counts | Reported by authors
Merchut, 1990 ^279^ | □ | | | □ | □ | □ | Single | 1 | 23 | 1 | 54 | Not reported | Counts | Reported by authors
Palliyath, 1990 ^171^ | □ | □ | | □ | □ | □ | Single | 1 | 10 | 1 | 11 | Not reported | Summary | No: only summary statistics reported
Pease, 1990 ^177^ | □ | □ | | □ | □ | □ | Single | 1 | 21 | 1 | 16 | Not reported | Counts | Calculated by ECRI
Rojviroj, 1990 ^280^ | □ | | □ | □ | □ | □ | Single | 1 | 33 | 1 | 16 | Prospective | Counts | Reported by authors
Tzeng, 1990 ^180^ | □ | □ | | □ | □ | □ | Single | 1 | 84 | 1 | 50 | Not reported | Counts | Calculated by ECRI
Uncini, 1990 ^135^ | □ | □ | | | □ | □ | Single | 1 | 35 | 1 | 39 | Not reported | Summary | No: only summary statistics reported
Winn, 1990 ^281^ | □ | | □ | □ | □ | □ | Single | 2 | 61 | 0 | 0 | Prospective | Summary | No: only summary statistics reported
Braun, 1989 ^282^ | | | □ | □ | □ | □ | Single | 1 | 40 | 0 | 0 | Not reported | Counts | No: no diagnostic thresholds reported
Cioni, 1989 ^146^ | □ | □ | | | □ | □ | Single | 1 | 307 | 1 | 54 | Not reported | Counts | Reported by authors
Jackson, 1989 ^150^ | □ | □ | | | □ | | Single | 1 | 123 | 1 | 38 | Not reported | Counts | Reported by authors
Meyers, 1989 ^283^ | □ | □ | □ | □ | □ | | Single | 1 | 14 | 1 | 19 | Not reported | Counts | Calculated by ECRI
So, 1989 ^173^ | □ | □ | | □ | □ | | Single | 1 | 22 | 2 | 35 | Not reported | Counts | Reported by authors
Szabo, 1989 ^284^ | □ | | □ | □ | □ | □ | Single | 1 | 22 | 0 | 0 | Not reported | Summary | No: only summary statistics reported
Uncini, 1989 ^161^ | □ | □ | | | □ | □ | Single | 1 | 32 | 1 | 33 | Not reported | Summary | No: only summary statistics reported
De Léan, 1988 ^285^ | □ | □ | | □ | □ | □ | Single | 1 | 150 | 0 | 0 | Not reported | Counts | Calculated by ECRI
Koris, 1988 ^198^ | | | □ | □ | □ | □ | Single | 1 | 21 | 1 | 15 | Prospective | Counts | Reported by authors
Molitor, 1988 ^110^ | | □ | □ | □ | □ | | Single | 1 | 19 | 1 | NR | Not reported | Counts | Calculated by ECRI
Mortier, 1988 ^286^ | □ | □ | | | □ | □ | Single | 1 | 116 | 1 | 102 | Retrospective | Counts | Reported by authors
Pease, 1988 ^287^ | □ | □ | | | □ | □ | Single | 1 | 25 | 1 | 23 | Not reported | Summary | No: only summary statistics reported
Carroll, 1987 ^288^ | □ | □ | | | □ | □ | Single | 1 | 101 | 1 | 50 | Not reported | Counts | Reported by authors
Jessurun, 1987 ^289^ | □ | □ | □ | □ | | □ | Multiple (<5) | 1 | 24 | 1 | 10 | Not reported | Summary | No: only summary statistics reported
Johnson, 1987 ^290^ | □ | □ | | | □ | □ | Single | 1 | 20 | 1 | 78 | Not reported | Counts | Calculated by ECRI
Liang, 1987 ^291^ | □ | □ | □ | □ | | □ | Single | 1 | 68 | 2 | 139 | Not reported | Summary | No: only summary statistics reported
Macleod, 1987 ^292^ | | □ | | □ | □ | □ | Single | 1 | 111 | 1 | 125 | Not reported | Summary | No: only summary statistics reported
Seror, 1987 ^156^ | | □ | □ | □ | □ | □ | Single | 1 | 62 | 1 | 20 | Not reported | Counts | Reported by authors
Borg, 1986 ^293^ | | | | □ | □ | □ | Single | 1 | 22 | 0 | 0 | Not reported | Counts | Calculated by ECRI
Gellman, 1986 ^106^ | | □ | | | □ | □ | Single | 1 | NR | 2 | NR | Not reported | Counts | Reported by authors
Escobar, 1985 ^151^ | □ | □ | | □ | □ | □ | Single | 1 | 23 | 1 | 55 | Not reported | Counts | Calculated by ECRI
Kimura, 1985 ^189^ | □ | □ | | | □ | | Single | 1 | 438 | 1 | 148 | Not reported | Counts | Reported by authors
Mills, 1985 ^194^ | □ | □ | | | □ | □ | Single | 1 | 47 | 2 | 49 | Not reported | Counts | Calculated by ECRI
Borg, 1984 ^294^ | □ | | □ | □ | □ | □ | Single | 3 | 45 | 0 | 0 | Prospective | Patient level | Calculated by ECRI
Pryse-Phillips, 1984 ^105^ | | □ | □ | □ | □ | □ | Single | 1 | 212 | 4 | 184 | Retrospective | Counts | Reported by authors
Satoh, 1984 ^295^ | | □ | | □ | □ | □ | Single | 1 | 14 | 0 | 0 | Retrospective | Patient level | No: only one patient group
Szabo, 1984 ^30^ | | | □ | □ | □ | □ | Single | 1 | 20 | 0 | 0 | Prospective | Counts | No: only one patient group
Goddard, 1983 ^296^ | □ | □ | | □ | □ | □ | Single | 1 | 24 | 1 | 49 | Not reported | Counts | Calculated by ECRI
Kim, 1983 ^195^ | □ | □ | | | □ | □ | Single | 1 | 39 | 1 | 33 | Not reported | Counts | Reported by authors
Marin, 1983 ^139^ | □ | □ | | | □ | □ | Single | 1 | 14 | 1 | 12 | Not reported | Counts | Calculated by ECRI
Wongsam, 1983 ^172^ | □ | □ | | □ | □ | □ | Single | 1 | 15 | 2 | 56 | Not reported | Summary | No: only summary statistics reported
Johnson, 1981 ^297^ | □ | □ | | | □ | □ | Single | 1 | 18 | 1 | 37 | Not reported | Summary | No: only summary statistics reported
Dekel, 1980 ^21^ | □ | □ | □ | □ | | □ | Single | 1 | 26 | 1 | 33 | Prospective | Patient level | No: could not extract 2 × 2 counts from graph
Messina, 1980 ^120^ | □ | □ | | | □ | □ | Single | 1 | 40 | 1 | 40 | Not reported | Counts | Reported by authors
Gelmers, 1979 ^29^ | | □ | | | □ | □ | Single | 1 | 47 | 1 | 43 | Not reported | Counts | Reported by authors
Kimura, 1979 ^140^ | □ | □ | | | □ | □ | Single | 1 | 105 | 1 | 61 | Not reported | Counts | Calculated by ECRI
Schwartz, 1979 ^187^ | □ | □ | | | □ | □ | Single | 1 | 20 | 1 | 10 | Not reported | Counts | Calculated by ECRI
Stewart, 1978 ^157^ | | □ | □ | □ | □ | □ | Single | 1 | 37 | 1 | 38 | Not reported | Counts | Reported by authors
Eisen, 1977 ^298^ | □ | □ | | | □ | □ | Single | 1 | 30 | 3 | 101 | Not reported | Patient level | Calculated by ECRI
Sedal, 1973 ^299^ | □ | □ | | □ | □ | □ | Single | 1 | 214 | 1 | 34 | Retrospective | Counts | Reported by authors
Welch, 1973 ^223^ | □ | | □ | □ | □ | □ | Single | 1 | 428 | 1 | 111 | Not reported | Summary | No: only summary statistics reported
Casey, 1972 ^300^ | □ | □ | | □ | □ | □ | Single | 1 | 16 | 2 | 112 | Not reported | Patient level | Calculated by ECRI
Loong, 1972 ^141^ | □ | □ | | | □ | □ | Single | 1 | 18 | 1 | 30 | Not reported | Patient level | Calculated by ECRI
Melvin, 1972 ^147^ | □ | □ | | □ | □ | □ | Single | 1 | 17 | 1 | 24 | Not reported | Counts | Calculated by ECRI
Buchthal, 1971 ^301^ | □ | □ | | □ | □ | | Single | 1 | 22 | 1 | 10 | Not reported | Counts | Calculated by ECRI
Loong, 1971 ^148^ | □ | □ | | | □ | □ | Single | 1 | 15 | 1 | 30 | Not reported | Patient level | Calculated by ECRI
Plaja, 1971 ^142^ | □ | □ | | □ | □ | | Single | 1 | 56 | 1 | 20 | Retrospective | Counts | Reported by authors

Table 45. Carpal Tunnel Syndrome-Patient Groups

Article | Disorder type | Patient selection | N patients | % female | Mean age | Age of youngest | Age of oldest | Duration of condition before treatment (months) | Shortest duration (months) | Longest duration (months) | Are patient comorbidities reported?
Finsen, 2001 ^224^ | CTS | Unspecified diagnosis | 68 | 74 | 48 | 21 | 86 | | | | Yes
Mondelli, 2001 ^181^ | Normal | Healthy volunteers | 19 | NR | 51.9 | 31 | 72 | | | | No
Mondelli, 2001 ^181^ | CTS | Unspecified diagnosis | 20 | 80 | 52.8 | 35 | 75 | | | | No
Atroshi, 2000 ^225^ | CTS | Symptoms/ presented | 262 | 57 | 52 | | | | | | No
Atroshi, 2000 ^225^ | Normal | Healthy volunteers | 125 | 55 | 51 | | | | | | No
Bland, 2000 ^200^ | CTS | Complex objective standard | 4690 | 65 | 57 | | | | | | No
Bland, 2000 ^200^ | CTS | Symptoms/ presented | 8223 | 66 | 53 | 10 | 98 | | | | No
Bland, 2000 ^200^ | Normal | Other | 3533 | 67 | 49 | | | | | | No
Cuturic, 2000 ^226^ | CTS | Unspecified diagnosis | 19 | 0 | 43 | 29 | 62 | | | | No
Cuturic, 2000 ^226^ | Normal | Healthy volunteers | 16 | 0 | 41 | 26 | 58 | | | | No
Kearns, 2000 ^204^ | CTS | Workers at risk | 45 | 4 | | | | | | | Yes
Loscher, 2000 ^175^ | Normal | Healthy volunteers | 87 | NR | 47 | 15 | 86 | | | | No
Loscher, 2000 ^175^ | CTS | Unspecified diagnosis | | NR | | | | | | | No
Loscher, 2000 ^175^ | CTS | Other | | NR | | | | | | | No
Montagna, 2000 ^227^ | Cubital tunnel syndrome | Unspecified diagnosis | 10 | NR | | | | | | | No
Montagna, 2000 ^227^ | Normal | Healthy volunteers | 15 | NR | | | | | | | No
Montagna, 2000 ^227^ | CTS | Unspecified diagnosis | 30 | NR | | | | | | | No
Nakamichi, 2000 ^228^ | CTS | Simple nerve conduction | 125 | 100 | 56 | 40 | 70 | | | | No
Nakamichi, 2000 ^228^ | Normal | Healthy volunteers | 200 | NR | 57 | 40 | 70 | | | | No
Raudino, 2000 ^229^ | CTS | Complex objective standard | 83 | 82 | 48.9 | 19 | 82 | 26.9 | 1 | 180 | Yes
Resende, 2000 ^174^ | CTS | Unspecified diagnosis | 20 | NR | | | | | | | No
Resende, 2000 ^174^ | Normal | Healthy volunteers | 20 | NR | | 21 | 55 | | | | No
Resende, 2000 ^184^ | Normal | Healthy volunteers | 20 | 100 | 36 | 20 | 54 | | | | No
Resende, 2000 ^184^ | CTS | Unspecified diagnosis | 32 | 100 | 44 | 25 | 59 | | | | No
Sener, 2000 ^186^ | CTS | Symptoms/ presented | 31 | NR | 46 | 26 | 70 | | | | Yes
Sener, 2000 ^186^ | Normal | Healthy volunteers | 21 | NR | 38 | 18 | 60 | | | | Yes
Seror, 2000 ^158^ | Normal | Healthy volunteers | 20 | 75 | 43 | 20 | 67 | | | | No
Seror, 2000 ^158^ | CTS | Complex objective standard | 20 | 75 | 47 | 32 | 76 | | | | No
Stalberg, 2000 ^230^ | CTS | Symptoms/ presented | 136 | NR | | | | | | | No
Stalberg, 2000 ^230^ | Normal | Healthy volunteers | 32 | NR | | 21 | 62 | | | | No
Weber, 2000 ^108^ | CTS | Symptoms/ presented | 53 | 79 | 45 | | | | | | No
Weber, 2000 ^108^ | Normal | Healthy volunteers | 26 | 85 | 37 | | | | | | No
Burke, 1999 ^231^ | CTS | Symptoms/ presented | 186 | NR | | | | | | | No
Atroshi, 1999 ^220^ | Normal | Other | 2466 | NR | | | | | | | No
Duncan, 1999 ^232^ | CTS | Complex objective standard | 68 | 74 | 54 | | | | | | Yes
Duncan, 1999 ^232^ | CTS | Complex objective standard | | NR | | | | | | | Yes
Duncan, 1999 ^232^ | Normal | Healthy volunteers | 36 | 64 | 44 | | | | | | Yes
Kabiraj, 1999 ^233^ | Normal | Healthy volunteers | 38 | 50 | | 20 | 79 | | | | No
Kabiraj, 1999 ^233^ | CTS | Complex objective standard | 31 | 68 | | 28 | 85 | | | | No
Lee, 1999 ^234^ | Normal | Healthy volunteers | 28 | 54 | | 22 | 47 | | | | No
Lee, 1999 ^234^ | CTS | Unspecified diagnosis | 50 | 74 | | 32 | 81 | | | | No
Missere, 1999 ^205^ | CTS | Workers at risk | 45 | 0 | 37.7 | | | | | | No
Mongale, 1999 ^235^ | Normal | Healthy volunteers | 9 | 100 | 39 | 26 | 50 | | | | No
Mongale, 1999 ^235^ | Normal | Healthy volunteers | 7 | 0 | 39 | 27 | 58 | | | | No
Mongale, 1999 ^235^ | CTS | Unspecified diagnosis | 8 | 100 | 43 | 24 | 54 | | | | No
Murthy, 1999 ^143^ | CTS | Symptoms/ presented | 84 | NR | | | | | | | No
Murthy, 1999 ^143^ | Normal | Healthy volunteers | 37 | NR | | | | | | | No
Rudolfer, 1999 ^236^ | CTS | Symptoms/ presented | 937 | NR | | | | | | | No
Sander, 1999 ^237^ | Normal | Healthy volunteers | 34 | NR | 41 | 26 | 71 | | | | No
Sander, 1999 ^237^ | CTS | Complex objective standard | 59 | NR | 49 | 29 | 73 | | | | No
Simovic, 1999 ^183^ | CTS | Other | 12 | NR | | | | | | | Yes
Simovic, 1999 ^183^ | Normal | Healthy volunteers | 19 | 63 | 40 | 25 | 68 | | | | Yes
Simovic, 1999 ^183^ | CTS | Unspecified diagnosis | 54 | NR | | | | | | | Yes
Szabo, 1999 ^152^ | Normal | Healthy volunteers | 50 | 66 | | 18 | 59 | | | | No
Szabo, 1999 ^152^ | CTS | Complex objective standard | 50 | 76 | | 20 | 73 | | 2 | 240 | No
Szabo, 1999 ^152^ | Unrelated disease | Other | 50 | 80 | | 28 | 72 | | 0 | 180 | No
Thonnard, 1999 ^117^ | CTS | Unspecified diagnosis | 11 | 73 | 52 | | | | | | No
Thonnard, 1999 ^117^ | Normal | Healthy volunteers | 11 | 73 | 53 | | | | | | No
Wang, 1999 ^238^ | CTS | Complex objective standard | 12 | 92 | 46 | 30 | 65 | | | | No
Wang, 1999 ^238^ | Normal | Healthy volunteers | 12 | 42 | 37 | 28 | 59 | | | | No
Aurora, 1998 ^239^ | CTS | Symptoms/ presented | 19 | NR | 52.8 | | | | | | No
Aurora, 1998 ^239^ | Normal | Healthy volunteers | 20 | NR | 32.9 | | | | | | No
Ferry, 1998 ^221^ | Normal | Other | 648 | 56 | 46.9 | | | | | | No
Fertl, 1998 ^153^ | Normal | Healthy volunteers | 20 | 60 | 42 | 25 | 77 | | | | No
Fertl, 1998 ^153^ | CTS | Symptoms/ presented | 47 | 83 | 55.5 | 21 | 78 | | | | No
Gerr, 1998 ^31^ | Normal | Healthy volunteers | 59 | 69 | 38.2 | | | | | | No
Gerr, 1998 ^31^ | CTS | Symptoms/ presented | 60 | 72 | 46.6 | | | | | | No
Ghavanini, 1998 ^154^ | CTS | Complex objective standard | 26 | 100 | 37 | 20 | 50 | 9 | 1 | 36 | No
Ghavanini, 1998 ^154^ | CTS | Symptoms/ presented | 74 | 81 | 40 | 20 | 50 | 15 | 1 | 60 | No
Ghavanini, 1998 ^154^ | Normal | Healthy volunteers | 58 | 76 | 36.7 | 20 | 50 | | | | No
Ghavanini, 1998 ^154^ | CTS | Complex objective standard | 26 | 69 | 41 | 20 | 50 | 19.4 | 1 | 48 | No
Ghavanini, 1998 ^154^ | CTS | Complex objective standard | 22 | 73 | 42 | 30 | 50 | 19 | 4 | 60 | No
Girlanda, 1998 ^149^ | CTS | Symptoms/ presented | 41 | 93 | 39 | 24 | 65 | 48 | 1 | 180 | Yes
Girlanda, 1998 ^149^ | Normal | Healthy volunteers | 45 | NR | | | | | | | Yes
Kabiraj, 1998 ^240^ | CTS | Symptoms/ presented | 72 | NR | | | | | | | No
Kabiraj, 1998 ^240^ | Normal | Healthy volunteers | 65 | 45 | 39.8 | 20 | 75 | | | | No
Kleindienst, 1998 ^241^ | CTS | Complex objective standard | | NR | | | | | | | No
Kleindienst, 1998 ^241^ | CTS | Other | | NR | | | | | | | No
Kleindienst, 1998 ^241^ | CTS | Complex objective standard | | NR | | | | | | | No
Kleindienst, 1998 ^241^ | CTS | Other | | NR | | | | | | | No
Kleindienst, 1998 ^241^ | Normal | Healthy volunteers | 18 | 83 | 51 | 43 | 59 | | | | No
Kleindienst, 1998 ^241^ | CTS | Complex objective standard | | NR | | | | | | | No
Kleindienst, 1998 ^241^ | CTS | Unspecified diagnosis | 77 | 82 | 54 | 22 | 79 | | | | No
Luchetti, 1998 ^242^ | CTS | Unspecified diagnosis | 39 | 79 | 31 | 26 | 45 | | | | No
Luchetti, 1998 ^242^ | Normal | Healthy volunteers | 12 | 83 | 27 | 24 | 36 | | | | No
Nathan, 1998 ^202^ | CTS | Workers at risk | 283 | 45 | 35.2 | | | | | | No
Rosen, 1998 ^201^ | Normal | Healthy volunteers | 60 | NR | | | | | | | No
Rosen, 1998 ^201^ | CTS | Workers at risk | 20 | 5 | 46 | 26 | 65 | | | | No
Rosen, 1998 ^201^ | CTS | Unspecified diagnosis | 14 | 100 | 53 | 33 | 78 | | | | No
Scelsa, 1998 ^243^ | CTS | Other | 21 | 48 | 46 | 10 | 69 | | | | No
Scelsa, 1998 ^243^ | CTS | Unspecified diagnosis | 42 | 76 | 50 | 25 | 85 | | | | No
Scelsa, 1998 ^243^ | Normal | Healthy volunteers | 25 | 44 | 42 | 23 | 63 | | | | No
Seror, 1998 ^159^ | CTS | Unspecified diagnosis | 85 | 74 | 46 | 25 | 83 | | | | No
Seror, 1998 ^159^ | Normal | Healthy volunteers | 80 | 64 | 42 | 22 | 68 | | | | No
Smith, 1998 ^244^ | CTS | Symptoms/ presented | 82 | 61 | 44 | 17 | 88 | 14 | 1 | 120 | No
Tan, 1998 ^206^ | CTS | Workers at risk | 64 | 63 | | 22 | 28 | | | | No
Tan, 1998 ^206^ | Normal | Healthy volunteers | 56 | 57 | | 21 | 29 | | | | No
Terzis, 1998 ^162^ | CTS | Unspecified diagnosis | 72 | 92 | 49.6 | | | | | | No
Terzis, 1998 ^162^ | Normal | Healthy volunteers | 43 | 84 | 48.3 | | | | | | No
Tetro, 1998 ^102^ | Normal | Healthy volunteers | 50 | 74 | 46.9 | 22 | 79 | | | | No
Tetro, 1998 ^102^ | CTS | Complex objective standard | 64 | 64 | 49.3 | 21 | 83 | | | | No
Werner, 1998 ^207^ | CTS | Workers at risk | 727 | 54 | 42 | 25 | 69 | | | | Yes
Wilson, 1998 ^245^ | Normal | Healthy volunteers | 14 | NR | 52 | 33 | 76 | | | | No
Wilson, 1998 ^245^ | CTS | Complex objective standard | 23 | NR | 59 | 24 | 76 | | | | No
Bak, 1997 ^246^ | CTS | Symptoms/ presented | 20 | 55 | | | | | | | Yes
Brahme, 1997 ^199^ | CTS | Unspecified diagnosis | 20 | 90 | 37 | 21 | 61 | | | | No
Brahme, 1997 ^199^ | Normal | Healthy volunteers | 15 | 47 | 35 | 22 | 60 | | | | No
Bronson, 1997 ^163^ | Normal | Other | 16 | 56 | 29.5 | 21 | 44 | | | | Yes
Bronson, 1997 ^163^ | CTS | Unspecified diagnosis | 22 | 73 | 34.4 | 21 | 59 | | | | Yes
Del Pino, 1997 ^104^ | Normal | Healthy volunteers | 100 | 78 | 49 | 37 | 67 | | | | No
Del Pino, 1997 ^104^ | CTS | Complex objective standard | 180 | 81 | 50 | 16 | 84 | 37.9 | 1 | 216 | No
Dellon, 1997 ^107^ | CTS | Unspecified diagnosis | 72 | NR | | | | | | | Yes
Dellon, 1997 ^107^ | Cubital tunnel syndrome | Unspecified diagnosis | 42 | NR | | | | | | | Yes
Dellon, 1997 ^107^ | Normal | Other | 52 | 62 | | | | | | | Yes
Franzblau, 1997 ^208^ | CTS | Workers at risk | 148 | 57 | 44.2 | | | | | | Yes
Guglielmo, 1997 ^247^ | CTS | Symptoms/ presented | 198 | 60 | 46 | 13 | 84 | | | | No
Guglielmo, 1997 ^247^ | Normal | Healthy volunteers | 69 | 57 | 40.3 | 20 | 86 | | | | No
Gunnarsson, 1997 ^248^ | CTS | Symptoms/ presented | 100 | NR | | | | | | | No
Horch, 1997 ^249^ | Normal | Healthy volunteers | 17 | 71 | 43.4 | 24 | 58 | | | | No
Horch, 1997 ^249^ | CTS | Simple nerve conduction | 19 | 63 | 49.7 | 25 | 67 | | | | No
Jeng, 1997 ^209^ | CTS | Workers at risk | 27 | 52 | 40.2 | 23 | 57 | | | | No
Kaneko, 1997 ^250^ | CTS | Unspecified diagnosis | 15 | 87 | | 40 | 54 | | | | Yes
Kaneko, 1997 ^250^ | Normal | Healthy volunteers | 46 | 22 | | 25 | 45 | | | | Yes
Kaneko, 1997 ^250^ | Cubital tunnel syndrome | Unspecified diagnosis | 10 | 20 | | 45 | 56 | | | | Yes
Kaneko, 1997 ^250^ | Combined WRUEDs | Unspecified diagnosis | 10 | 50 | | 40 | 62 | | | | Yes
King, 1997 ^114^ | CTS | Unspecified diagnosis | 29 | 62 | | | | | | | No
King, 1997 ^114^ | Normal | Healthy volunteers | 100 | 50 | | | | | | | No
Pierre-Jerome, 1997 ^251^ | Normal | Healthy volunteers | 28 | 100 | 45.1 | 26 | 67 | | | | No
Pierre-Jerome, 1997 ^251^ | CTS | Simple nerve conduction | 27 | 100 | 51.9 | 16 | 78 | 36 | 12 | 72 | No
Radack, 1997 ^252^ | CTS | Complex objective standard | | NR | | | | | | | No
Radack, 1997 ^252^ | Normal | Unrelated disease | | NR | | | | | | | No
Radack, 1997 ^252^ | CTS | Symptoms/ presented | 161 | 53 | 37.4 | 13 | 86 | | | | No
Rosecrance, 1997 ^253^ | CTS | Complex objective standard | 20 | 70 | 41.5 | | | ^a^32 | | | No
Rosecrance, 1997 ^253^ | CTS | Complex objective standard | 10 | 60 | 39.9 | | | ^a^14 | | | No
Rosecrance, 1997 ^253^ | Normal | Healthy volunteers | 25 | 28 | 38.8 | | | | | | No
Rosecrance, 1997 ^253^ | CTS | Complex objective standard | 28 | NR | | | | | | | No
Simovic, 1997 ^182^ | Normal | Healthy volunteers | 15 | NR | | 18 | 70 | | | | No
Simovic, 1997 ^182^ | CTS | Unspecified diagnosis | 107 | 61 | 51 | 19 | 86 | | | | No
Werner, 1997 ^210^ | CTS | Workers at risk | 59 | 64 | 40.1 | | | | | | No
Werner, 1997 ^210^ | Normal | Simple nerve conduction | 49 | 67 | 41.7 | | | | | | No
Andary, 1996 ^196^ | Normal | Healthy volunteers | 17 | NR | 36 | | | | | | No
Andary, 1996 ^196^ | CTS | Symptoms/ presented | 81 | NR | 42 | | | | | | No
Atroshi, 1996 ^136^ | Normal | Healthy volunteers | 30 | 57 | 36 | 25 | 62 | | | | Yes
Atroshi, 1996 ^136^ | CTS | Symptoms/ presented | 36 | 69 | 52 | 20 | 87 | ^a^24 | 1 | 120 | Yes
Atroshi, 1996 ^136^ | Normal | Healthy volunteers | 30 | 70 | 40 | 19 | 65 | | | | Yes
Bingham, 1996 ^211^ | CTS | Workers at risk | 1021 | 29 | 30.1 | 17 | 60 | | | | No
Checkosky, 1996 ^254^ | Normal | Healthy volunteers | 10 | 70 | | 25 | 44 | | | | No
Checkosky, 1996 ^254^ | Normal | Healthy volunteers | 20 | 75 | | 25 | 67 | | | | No
Checkosky, 1996 ^254^ | CTS | Symptoms/ presented | 12 | 83 | | 45 | 70 | | | | No
Checkosky, 1996 ^254^ | CTS | Symptoms/ presented | 24 | 79 | 46.7 | 27 | 70 | | | | No
Checkosky, 1996 ^254^ | Normal | Healthy volunteers | 10 | 80 | | 46 | 67 | | | | No
Checkosky, 1996 ^254^ | CTS | Symptoms/ presented | 12 | 75 | | 27 | 45 | | | | No
Cherniak, 1996 ^190^ | Normal | Healthy volunteers | 10 | 70 | 37.1 | 26 | 52 | | | | No
Cherniak, 1996 ^190^ | CTS | Symptoms/ presented | 49 | 33 | 43 | 19 | 71 | | | | No
Foresti, 1996 ^192^ | Normal | Healthy volunteers | 25 | 28 | 42 | 18 | 69 | | | | Yes
Foresti, 1996 ^192^ | CTS | Symptoms/ presented | 100 | 25 | 49 | 27 | 78 | | | | Yes
Ghavanini, 1996 ^255^ | CTS | Unspecified diagnosis | 50 | 82 | 38.6 | 27 | 59 | | | | Yes
Ghavanini, 1996 ^255^ | Normal | Healthy volunteers | 50 | 78 | 28.7 | 20 | 42 | | | | Yes
Kleindienst, 1996 ^256^ | CTS | Other | 55 | 82 | 54 | | | | | | No
Kleindienst, 1996 ^256^ | Normal | Healthy volunteers | 18 | 83 | 51 | | | | | | No
Murata, 1996 ^164^ | Normal | Healthy volunteers | 19 | 100 | 24 | 19 | 31 | | | | Yes
Murata, 1996 ^164^ | CTS | Workers at risk | 27 | 100 | 25 | 19 | 37 | | | | Yes
Padua, 1996 ^165^ | Normal | Healthy volunteers | 36 | 69 | 43.7 | 19 | 79 | | | | No
Padua, 1996 ^165^ | CTS | Symptoms/ presented | 43 | 72 | 45.2 | 23 | 80 | 27 | 2 | 48 | No
Pierre-Jerome, 1996 ^212^ | CTS | Workers at risk | 24 | 100 | 44 | 26 | 59 | | | | Yes
Pierre-Jerome, 1996 ^212^ | Normal | Other | 19 | 100 | 39.5 | 25 | 44 | | | | Yes
Britz, 1995 ^257^ | CTS | Unspecified diagnosis | 32 | NR | | | | | | | No
Britz, 1995 ^257^ | Normal | Healthy volunteers | 0 | NR | | | | | | | No
De Smet, 1995 ^101^ | CTS | Simple nerve conduction | 10 | 70 | 42.8 | 22 | 53 | | | | No
De Smet, 1995 ^101^ | Normal | Healthy volunteers | 46 | 100 | 51 | 34 | 76 | | | | No
De Smet, 1995 ^101^ | Normal | Other | 9 | 100 | | | | | | | No
De Smet, 1995 ^101^ | CTS | Symptoms/ presented | 40 | 93 | 50.8 | 23 | 77 | | | | No
Gerr, 1995 ^118^ | Symptomatic /normal NCS | Complex objective standard | 30 | 60 | 43.9 | | | | | | No
Gerr, 1995 ^118^ | CTS | Complex objective standard | 30 | 83 | 50.1 | | | | | | No
Gerr, 1995 ^118^ | Normal | Healthy volunteers | 59 | 69 | 38.2 | | | | | | No
Glass, 1995 ^28^ | CTS | Symptoms/ presented | 82 | 77 | | 23 | 69 | | | | No
Glass, 1995 ^28^ | Normal | Contralateral arm | 26 | NR | | | | | | | No
Glass, 1995 ^28^ | Normal | Healthy volunteers | 24 | 58 | | 24 | 69 | | | | No
Golovchinsky, 1995 ^258^ | Combined WRUEDs | Unspecified diagnosis | 571 | 49 | 45.2 | 22 | 86 | | | | No
Hamanaka, 1995 ^259^ | CTS | Unrelated disease | 31 | 39 | 37.9 | 18 | 67 | | | | Yes
Hamanaka, 1995 ^259^ | CTS | Unspecified diagnosis | 647 | 61 | 53.9 | 21 | 87 | | | | Yes
Hansson, 1995 ^137^ | CTS | Symptoms/ presented | 20 | 95 | 45 | 31 | 60 | ^a^9 | 2 | 120 | Yes
Hansson, 1995 ^137^ | Normal | Healthy volunteers | 10 | 90 | 45 | 26 | 65 | ^a^9 | 2 | 120 | Yes
Hansson, 1995 ^137^ | CTS | Complex objective standard | 10 | 100 | 57 | 41 | 79 | ^a^9 | 2 | 120 | Yes
Kothari, 1995 ^260^ | CTS | Symptoms/ presented | 59 | 75 | 50 | 22 | 91 | | | | No
Kothari, 1995 ^260^ | Normal | Healthy volunteers | 30 | 70 | 36 | 21 | 70 | | | | No
Lang, 1995 ^109^ | CTS | Unspecified diagnosis | 23 | 78 | 51.4 | | | ^a^36 | 12 | 420 | No
Lang, 1995 ^109^ | Normal | Healthy volunteers | 16 | 63 | 55 | | | | | | No
Lesser, 1995 ^261^ | Normal | Healthy volunteers | 20 | 40 | 36 | 22 | 50 | | | | No
Lesser, 1995 ^261^ | CTS | Complex objective standard | 45 | 73 | 52 | 27 | 79 | | | | No
Nakamichi, 1995 ^262^ | CTS | Unspecified diagnosis | 15 | 100 | 53.9 | 50 | 58 | | | | Yes
Nakamichi, 1995 ^262^ | Normal | Healthy volunteers | 15 | 100 | 54.4 | 50 | 58 | | | | Yes
Seradge, 1995 ^263^ | CTS | Unspecified diagnosis | 72 | 75 | 45.6 | 18 | 80 | | | | No
Seradge, 1995 ^263^ | Normal | Unrelated disease | 21 | 52 | | 20 | 74 | | | | No
Seror, 1995 ^179^ | Normal | Healthy volunteers | 40 | 70 | 53 | | | | | | No
Seror, 1995 ^179^ | CTS | Unspecified diagnosis | 25 | 80 | 56 | | | | | | No
Seror, 1995 ^179^ | CTS | Unspecified diagnosis | 25 | 84 | 52 | | | | | | No
Seror, 1995 ^179^ | CTS | Unspecified diagnosis | 25 | 84 | 55 | | | | | | No
Shafshak, 1995 ^264^ | CTS | Complex objective standard | 25 | 52 | | 22 | 40 | | | | Yes
Shafshak, 1995 ^264^ | Other | Other | 11 | 27 | | 23 | 51 | | | | Yes
Shafshak, 1995 ^264^ | Normal | Healthy volunteers | 25 | 52 | 42 | 18 | 57 | | | | Yes
Shafshak, 1995 ^264^ | CTS | Unspecified diagnosis | 11 | 100 | | 27 | 53 | | | | Yes
Sheean, 1995 ^191^ | CTS | Symptoms/ presented | 49 | 71 | 56.2 | 29 | 84 | | | | No
Sheean, 1995 ^191^ | Normal | Healthy volunteers | | NR | | 22 | 59 | | | | No
Tassler, 1995 ^115^ | Cubital tunnel syndrome | Unspecified diagnosis | 13 | NR | | | | | | | Yes
Tassler, 1995 ^115^ | CTS | Unspecified diagnosis | 14 | NR | | | | | | | Yes
Valls-Sole, 1995 ^265^ | CTS | Complex objective standard | 18 | 100 | | 34 | 53 | | 6 | 144 | No
Valls-Sole, 1995 ^265^ | Normal | Healthy volunteers | 15 | 87 | | 25 | 51 | | | | No
Werner, 1995 ^213^ | CTS | Workers at risk | 167 | NR | | | | | | | No
Young, 1995 ^166^ | CTS | Workers at risk | 157 | 82 | 39.9 | 20 | 64 | | | | No
Clifford, 1994 ^266^ | CTS | Symptoms/ presented | 20 | 100 | 43.1 | | | | | | No
Clifford, 1994 ^266^ | Normal | Healthy volunteers | 10 | NR | 26.7 | | | | | | No
Durkan, 1994 ^267^ | CTS | Unspecified diagnosis | 30 | 43 | 52 | 21 | 88 | | | | No
Durkan, 1994 ^267^ | Normal | Healthy volunteers | 25 | NR | | | | | | | No
Franzblau, 1994 ^113^ | CTS | Workers at risk | 83 | 53 | 33.8 | | | | | | No
Gerr, 1994 ^197^ | Normal | Healthy volunteers | | NR | 38 | | | | | | No
Gerr, 1994 ^197^ | CTS | Complex objective standard | | NR | 43 | | | | | | No
Gerr, 1994 ^197^ | CTS | Complex objective standard | | NR | 50 | | | | | | No
Kirschberg, 1994 ^214^ | CTS | Workers at risk | 112 | 85 | 33.3 | | | | | | No
Kuntzer, 1994 ^144^ | Normal | Healthy volunteers | 70 | 60 | 43 | 25 | 70 | | | | No
Kuntzer, 1994 ^144^ | CTS | Symptoms/ presented | 100 | 80 | 51 | 26 | 85 | | | | No
Nathan, 1994 ^215^ | CTS | Workers at risk | 316 | 47 | 40.4 | | | | | | No
Nathan, 1994 ^215^ | CTS | Workers at risk | 101 | 26 | 38.6 | | | | | | No
Nilsson, 1994 ^216^ | CTS | Workers at risk | 58 | 0 | 24.6 | | | | | | No
Nilsson, 1994 ^216^ | CTS | Workers at risk | 61 | 0 | 37.4 | | | | | | No
Nilsson, 1994 ^216^ | CTS | Workers at risk | 56 | 0 | 32.4 | | | | | | No
Para, 1994 ^103^ | CTS | Symptoms/ presented | 24 | 71 | 51.6 | 26 | 62 | | | | No
Para, 1994 ^103^ | CTS | Symptoms/ presented | 27 | 70 | 48.6 | 28 | 60 | | | | No
Para, 1994 ^103^ | Normal | Healthy volunteers | 12 | 58 | 36.6 | 17 | 55 | | | | No
Rossi, 1994 ^178^ | CTS | Unspecified diagnosis | 62 | 84 | 49.4 | 22 | 63 | | | | No
Rossi, 1994 ^178^ | Normal | Healthy volunteers | 27 | 67 | 44.6 | 22 | 62 | | | | No
Werner, 1994 ^217^ | CTS | Workers at risk | 130 | 56 | 34 | | | | | | No
Werner, 1994 ^111^ | CTS | Symptoms/ presented | 31 | NR | | | | | | | No
Werner, 1994 ^111^ | Normal | Healthy volunteers | 20 | NR | | | | | | | No
Eisen, 1993 ^193^ | CTS | Symptoms/ presented | | NR | | | | | | | Yes
Eisen, 1993 ^193^ | Normal | Healthy volunteers | | NR | | | | | | | Yes
Johnson, 1993 ^167^ | CTS | Workers at risk | 184 | NR | | | | | | | No
Nakamichi, 1993 ^268^ | CTS | Unspecified diagnosis | 128 | 74 | 54 | 33 | 86 | | | | No
Nathan, 1993 ^218^ | Normal | Healthy volunteers | 45 | 47 | 19.8 | | | | | | No
Nathan, 1993 ^218^ | CTS | Workers at risk | 388 | 63 | 39.4 | | | | | | No
Nathan, 1993 ^218^ | CTS | Workers at risk | 737 | 28 | 42.4 | | | | | | No
Rodriquez, 1993 ^269^ | Normal | Healthy volunteers | 8 | 38 | 40.3 | 23 | 82 | | | | No
Rodriquez, 1993 ^269^ | CTS | Unspecified diagnosis | 10 | 80 | 43.8 | 22 | 83 | | | | No
Rosen, 1993 ^270^ | Normal | Healthy volunteers | 21 | 48 | 33.6 | 20 | 50 | | | | No
Rosen, 1993 ^270^ | Normal | Healthy volunteers | 50 | 0 | 41.5 | 27 | 63 | | | | No
Rosen, 1993 ^270^ | CTS | Symptoms/ presented | 47 | 0 | 42.8 | 23 | 63 | | | | No
Rosen, 1993 ^270^ | CTS | Symptoms/ presented | 15 | 80 | 37.9 | 26 | 53 | | | | No
Rosén, 1993 ^138^ | Normal | Healthy volunteers | 15 | 60 | 34 | 21 | 46 | | | | No
Rosén, 1993 ^138^ | Normal | Other | 50 | 0 | 41.5 | 27 | 63 | | | | No
Rosén, 1993 ^138^ | CTS | Unspecified diagnosis | 28 | 75 | 41 | 26 | 77 | | | | No
Rosén, 1993 ^138^ | Normal | Healthy volunteers | 21 | 48 | 33.6 | 20 | 50 | | | | No
Uncini, 1993 ^160^ | Normal | Healthy volunteers | 47 | 72 | 44.7 | 18 | 78 | | | | No
Uncini, 1993 ^160^ | CTS | Simple nerve conduction | 70 | 86 | 49.3 | 26 | 78 | | | | No
Buchberger, 1992 ^271^ | Normal | Healthy volunteers | | NR | | | | | | | No
Buchberger, 1992 ^271^ | CTS | Unspecified diagnosis | 18 | 78 | 57 | 23 | 82 | | | | No
Grant, 1992 ^219^ | CTS | Complex objective standard | 22 | NR | | 22 | 71 | | | | Yes
Grant, 1992 ^219^ | Normal | Healthy volunteers | 47 | 100 | | 16 | 65 | | | | Yes
Grant, 1992 ^219^ | CTS | Workers at risk | | NR | | | | | | | Yes
Grant, 1992 ^219^ | CTS | Symptoms/ presented | | NR | | | | | | | Yes
Imaoka, 1992 ^272^ | CTS | Unspecified diagnosis | 42 | 79 | 50.3 | 20 | 76 | | | | Yes
Imaoka, 1992 ^272^ | Normal | Healthy volunteers | 32 | 59 | 49.2 | 24 | 76 | | | | Yes
Kindstrand, 1992 ^273^ | Normal | Other | 127 | 65 | 47.5 | 15 | 84 | | | | Yes
Kindstrand, 1992 ^273^ | CTS | Complex objective standard | 94 | 73 | 50 | 19 | 95 | | 1 | 121 | Yes
Preston, 1992 ^188^ | Normal | Healthy volunteers | | NR | 31 | 18 | 50 | | | | Yes
Preston, 1992 ^188^ | CTS | Other | 8 | NR | | | | | | | Yes
Preston, 1992 ^188^ | CTS | Symptoms/ presented | | NR | 49 | 21 | 98 | | | | Yes
Tchou, 1992 ^274^ | CTS | Unspecified diagnosis | 61 | NR | | | | | | | No
Tchou, 1992 ^274^ | Normal | Healthy volunteers | 40 | 50 | | 22 | 45 | | | | No
Buchberger, 1991 ^275^ | Normal | Healthy volunteers | 14 | 64 | | | | | | | No
Buchberger, 1991 ^275^ | CTS | Symptoms/ presented | 25 | 68 | 61 | 38 | 85 | | | | No
Chang, 1991 ^145^ | Normal | Healthy volunteers | 40 | NR | 38.6 | 22 | 60 | | | | Yes
Chang, 1991 ^145^ | CTS | Symptoms/ presented | 43 | 79 | 42.3 | 25 | 64 | | | | Yes
Durkan, 1991 ^155^ | CTS | Complex objective standard | 31 | 74 | 45 | 22 | 79 | | | | No
Durkan, 1991 ^155^ | Normal | Healthy volunteers | 50 | NR | | | | | | | No
Jetzer, 1991 ^168^ | CTS | Workers at risk | 100 | NR | | | | | | | No
Jetzer, 1991 ^168^ | CTS | Workers at risk | 284 | NR | | | | | | | No
Jetzer, 1991 ^168^ | CTS | Workers at risk | 39 | NR | | | | | | | No
Jetzer, 1991 ^168^ | Normal | Healthy volunteers | 284 | NR | | | | | | | No
Katz, 1991 ^276^ | CTS | Symptoms/ presented | 78 | 63 | 43.4 | | | | | | Yes
Lauritzen, 1991 ^185^ | CTS | Unspecified diagnosis | 38 | 68 | 53 | | | | | | Yes
Lauritzen, 1991 ^185^ | Normal | Healthy volunteers | 23 | NR | | | | | | | Yes
Luchetti, 1991 ^169^ | CTS | Unspecified diagnosis | 14 | 93 | 41 | 21 | 64 | 31.3 | 2 | 120 | Yes
Radwin, 1991 ^116^ | CTS | Unspecified diagnosis | 12 | 58 | | 29 | 60 | | | | No
Radwin, 1991 ^116^ | Normal | Healthy volunteers | 15 | NR | 34.5 | 25 | 67 | | | | No
Charles, 1990 ^170^ | Other | Other | 30 | 60 | 45.5 | 25 | 63 | | | | Yes
Charles, 1990 ^170^ | Normal | Healthy volunteers | 60 | 80 | 45 | 23 | 76 | | | | Yes
Charles, 1990 ^170^ | CTS | Unspecified diagnosis | 158 | 84 | 47.1 | 20 | 64 | | | | Yes
De Krom, 1990 ^222^ | Normal | Other | 50 | 86 | | | | | | | No
Fitz, 1990 ^277^ | Normal | Healthy volunteers | 44 | NR | 30 | 22 | 66 | | | | No
Fitz, 1990 ^277^ | CTS | Complex objective standard | 36 | NR | 52 | 25 | 88 | | | | No
Gilliatt, 1990 ^278^ | CTS | Unspecified diagnosis | 10 | NR | 44 | | | | | | No
Gilliatt, 1990 ^278^ | Normal | Healthy volunteers | 15 | NR | 42 | | | | | | No
MacDonell, 1990 ^90^ | CTS | Complex objective standard | 34 | NR | 44 | 29 | 67 | | | | No
MacDonell, 1990 ^90^ | Normal | Healthy volunteers | 12 | NR | 41 | 26 | 61 | | | | No
Merchut, 1990 ^279^ | Normal | Healthy volunteers | 54 | NR | 53 | | | | | | No
Merchut, 1990 ^279^ | CTS | Symptoms/ presented | 23 | 87 | 53 | 25 | 74 | | | | No
Palliyath, 1990 ^171^ | Normal | Healthy volunteers | 11 | NR | 31 | | | | | | No
Palliyath, 1990 ^171^ | CTS | Unspecified diagnosis | 10 | NR | 42 | 30 | 50 | | | | No
Pease, 1990 ^177^ | Normal | Healthy volunteers | 16 | NR | | 21 | 63 | | | | No
Pease, 1990 ^177^ | CTS | Unspecified diagnosis | 21 | NR | | | | | | | No
Rojviroj, 1990 ^280^ | CTS | Complex objective standard | 33 | 76 | 46.5 | 19 | 67 | 19 | 1 | 120 | No
Rojviroj, 1990 ^280^ | Normal | Healthy volunteers | 16 | 25 | | | | | | | No
Tzeng, 1990 ^180^ | CTS | Unspecified diagnosis | 84 | 70 | 48 | 21 | 67 | | | | No
Tzeng, 1990 ^180^ | Normal | Healthy volunteers | 50 | 56 | 46 | 20 | 65 | | | | No
Uncini, 1990 ^135^ | Normal | Healthy volunteers | 39 | NR | 54 | 16 | 81 | | | | No
Uncini, 1990 ^135^ | CTS | Complex objective standard | 35 | 80 | 49 | 28 | 68 | | | 8 | No
Winn, 1990 ^281^ | CTS | Other | 34 | NR | | | | | | | No
Winn, 1990 ^281^ | CTS | Symptoms/ presented | 27 | NR | | | | | | | No
Braun, 1989 ^282^ | CTS | Symptoms/ presented | 40 | 80 | 38 | | | | | | Yes
Cioni, 1989 ^146^ | Normal | Healthy volunteers | 54 | 65 | 38.3 | 18 | 68 | | | | No
Cioni, 1989 ^146^ | CTS | Symptoms/ presented | 307 | 16 | 46.4 | 20 | 72 | | | | No
Jackson, 1989 ^150^ | CTS | Symptoms/ presented | 123 | 82 | 52.6 | 21 | 85 | | | | Yes
Jackson, 1989 ^150^ | Normal | Healthy volunteers | 38 | 76 | 42.2 | 21 | 66 | | | | Yes
Meyers, 1989 ^283^ | Normal | Healthy volunteers | 19 | 53 | 36 | 22 | 60 | | | | No
Meyers, 1989 ^283^ | CTS | Unspecified diagnosis | 14 | 64 | 51 | 36 | 68 | | | | No
So, 1989 ^173^ | Normal | Healthy volunteers | 20 | NR | | | | | | | No
So, 1989 ^173^ | Cubital tunnel syndrome | Unspecified diagnosis | 15 | NR | | | | | | | No
So, 1989 ^173^ | CTS | Unspecified diagnosis | 22 | NR | | | | | | | No
Szabo, 1989 ^284^ | CTS | Unspecified diagnosis | 22 | 73 | 51 | 24 | 79 | 29 | 7 | 120 | Yes
Uncini, 1989 ^161^ | CTS | Symptoms/ presented | 32 | NR | | | | | | | No
Uncini, 1989 ^161^ | Normal | Healthy volunteers | 33 | 55 | | 16 | 81 | | | | No
De Léan, 1988 ^285^ | CTS | Simple signs/symptoms | 150 | 73 | 47.6 | 18 | 84 | 31 | 1 | 144 | Yes
Koris, 1988 ^198^ | CTS | Unspecified diagnosis | 21 | 86 | 60 | 28 | 85 | | 1 | 120 | Yes
Koris, 1988 ^198^ | Normal | Healthy volunteers | 15 | NR | | 28 | 40 | | | | Yes
Molitor, 1988 ^110^ | CTS | Symptoms/ presented | 19 | NR | | | | | | | No
Molitor, 1988 ^110^ | Normal | Healthy volunteers | | NR | 49 | 23 | 79 | | | | No
Mortier, 1988 ^286^ | CTS | Simple nerve conduction | 116 | 67 | 49.2 | 20 | 82 | | | | No
Mortier, 1988 ^286^ | Normal | Healthy volunteers | 102 | 67 | 47.5 | 22 | 86 | | | | No
Pease, 1988 ^287^ | Normal | Healthy volunteers | 23 | NR | | 21 | 62 | | | | No
Pease, 1988 ^287^ | CTS | Unspecified diagnosis | 25 | NR | | | | | | | No
Carroll, 1987 ^288^ | CTS | Symptoms/ presented | 101 | 76 | 44.8 | 22 | 82 | | | | No
Carroll, 1987 ^288^ | Normal | Healthy volunteers | 50 | 48 | 46.7 | 16 | 82 | | | | No
Jessurun, 1987 ^289^ | Normal | Healthy volunteers | 10 | 50 | | | | | | | No
Jessurun, 1987 ^289^ | CTS | Unspecified diagnosis | 24 | 88 | | | | | | | No
Johnson, 1987 ^290^ | Normal | Healthy volunteers | 78 | NR | | 20 | 79 | | | | Yes
Johnson, 1987 ^290^ | CTS | Complex objective standard | 20 | NR | | | | | | | Yes
Liang, 1987 ^291^ | CTS | Other | 10 | 100 | | | | | | | No
Liang, 1987 ^291^ | CTS | Unspecified diagnosis | 68 | 79 | 50 | 24 | 73 | | | | No
Liang, 1987 ^291^ | Normal | Contralateral arm | 39 | 67 | | | | | | | No
Liang, 1987 ^291^ | Normal | Healthy volunteers | 100 | 50 | 45 | 20 | 69 | | | | No
Liang, 1987 ^291^ | CTS | Other | 28 | 82 | | | | | | | No
Liang, 1987 ^291^ | CTS | Other | 20 | 90 | | | | | | | No
Liang, 1987 ^291^ | CTS | Other | 20 | 65 | | | | | | | No
Liang, 1987 ^291^ | CTS | Other | 58 | 76 | | | | | | | No
Macleod, 1987 ^292^ | CTS | Simple nerve conduction | 111 | NR | | | | | | | No
Macleod, 1987 ^292^ | Normal | Healthy volunteers | 26 | 58 | 39 | 17 | 63 | | | | No
Macleod, 1987 ^292^ | Normal | Healthy volunteers | 125 | 52 | 41 | 17 | 82 | | | | No
Seror, 1987 ^156^ | CTS | Symptoms/ presented | 62 | 79 | 56.8 | 29 | 85 | | | | No
Seror, 1987 ^156^ | Normal | Healthy volunteers | 20 | 75 | 55.7 | 34 | 79 | | | | No
Borg, 1986 ^293^ | CTS | Symptoms/ presented | 22 | 82 | 45.5 | | | 33 | | | No
Gellman, 1986 ^106^ | CTS | Complex objective standard | | NR | | | | | | | Yes
Gellman, 1986 ^106^ | Normal | Healthy volunteers | | NR | | | | | | | Yes
Gellman, 1986 ^106^ | Other | Other | | NR | | | | | | | Yes
Escobar, 1985 ^151^ | CTS | Symptoms/ presented | 23 | 70 | | 22 | 55 | | | | Yes
Escobar, 1985 ^151^ | Normal | Healthy volunteers | 55 | 64 | | 20 | 70 | | | | Yes
Kimura, 1985 ^189^ | Normal | Healthy volunteers | 148 | 54 | 47.6 | 20 | 81 | | | | No
Kimura, 1985 ^189^ | CTS | Symptoms/ presented | 438 | 65 | 51.4 | 18 | 85 | | | | No
Mills, 1985 ^194^ | CTS | Symptoms/ presented | 47 | 77 | | 29 | 74 | | 0 | 60 | No
Mills, 1985 ^194^ | Normal | Healthy volunteers | 29 | 45 | | 19 | 63 | | | | No
Mills, 1985 ^194^ | Normal | Other | 20 | 50 | | 19 | 75 | | | | No
Borg, 1984 ^294^ | CTS | Unspecified diagnosis | 21 | NR | | | | | | | No
Borg, 1984 ^294^ | CTS | Other | 12 | NR | | | | | | | No
Borg, 1984 ^294^ | CTS | Unspecified diagnosis | 12 | NR | | | | | | | No
Pryse-Phillips, 1984 ^105^ | Other | Complex objective standard | 44 | NR | | | | | | | No
Pryse-Phillips, 1984 ^105^ | Cubital tunnel syndrome | Complex objective standard | 67 | NR | | | | | | | No
Pryse-Phillips, 1984 ^105^ | CTS | Complex objective standard | 212 | NR | | | | | | | No
Pryse-Phillips, 1984 ^105^ | Other | Complex objective standard | 41 | NR | | | | | | | No
Pryse-Phillips, 1984 ^105^ | Other | Complex objective standard | 32 | NR | | | | | | | No
Satoh, 1984 ^295^ | CTS | Complex objective standard | 14 | 100 | | | | | | | No
Szabo, 1984 ^30^ | CTS | Unspecified diagnosis | 20 | 50 | | 32 | 81 | | 2 | 180 | No
Goddard, 1983 ^296^ | CTS | Unspecified diagnosis | 24 | NR | | | | | | | No
Goddard, 1983 ^296^ | Normal | Healthy volunteers | 49 | NR | | | | | | | No
Kim, 1983 ^195^ | Normal | Healthy volunteers | 33 | NR | 41.3 | 20 | 68 | | | | No
Kim, 1983 ^195^ | CTS | Symptoms/ presented | 39 | NR | | | | | | | No
Marin, 1983 ^139^ | CTS | Unspecified diagnosis | 14 | 86 | 49 | 23 | 79 | 13 | 1 | 24 | No
Marin, 1983 ^139^ | Normal | Healthy volunteers | 12 | 42 | 30 | 22 | 48 | | | | No
Wongsam, 1983 ^172^ | DM with peripheral neuropathy | Unrelated disease | 6 | NR | | | | | | | No
Wongsam, 1983 ^172^ | CTS | Symptoms/ presented | 15 | NR | | | | | | | No
Wongsam, 1983 ^172^ | Normal | Healthy volunteers | 50 | 56 | | 20 | 68 | | | | No
Johnson, 1981 ^297^ | CTS | Unspecified diagnosis | 18 | NR | | | | | | | No
Johnson, 1981 ^297^ | Normal | Healthy volunteers | 37 | 49 | | | | | | | No
Dekel, 1980 ^21^ | Normal | Healthy volunteers | 33 | 58 | 40.3 | | | | | | No
Dekel, 1980 ^21^ | CTS | Unspecified diagnosis | 26 | 100 | | | | | | | No
Messina, 1980 ^120^ | CTS | Symptoms/ presented | 40 | NR | 45.1 | 19 | 67 | | | | No
Messina, 1980 ^120^ | Normal | Healthy volunteers | 40 | NR | 47.5 | | | | | | No
Gelmers, 1979 ^29^ | Normal | Healthy volunteers | 43 | 79 | 54 | 26 | 74 | | | | No
Gelmers, 1979 ^29^ | CTS | Complex objective standard | 47 | 81 | 57 | 29 | 78 | | | | No
Kimura, 1979 ^140^ | CTS | Unspecified diagnosis | 105 | 70 | 48 | 20 | 78 | | | | No
Kimura, 1979 ^140^ | Normal | Unrelated disease | 61 | 57 | 43 | 15 | 50 | | | | No
Schwartz, 1979 ^187^ | CTS | Symptoms/ presented | 20 | 85 | 52 | 27 | 77 | | | | No
Schwartz, 1979 ^187^ | Normal | Healthy volunteers | 10 | 100 | | 20 | 28 | | | | No
Stewart, 1978 ^157^ | CTS | Complex objective standard | 37 | 81 | 55 | 36 | 84 | | | | Yes
Stewart, 1978 ^157^ | Normal | Healthy volunteers | 38 | 79 | 53 | 30 | 84 | | | | Yes
Eisen, 1977 ^298^ | Cubital tunnel syndrome | Complex objective standard | 18 | NR | 51.7 | 26 | 65 | | | | No
Eisen, 1977 ^298^ | Normal | Healthy volunteers | 60 | NR | 41.5 | 11 | 74 | | | | No
Eisen, 1977 ^298^ | Combined WRUEDs | Other | 23 | NR | 50 | 7 | 68 | | | | No
Eisen, 1977 ^298^ | CTS | Complex objective standard | 30 | NR | 56.1 | 21 | 76 | | | | No
Sedal, 1973 ^299^ | Normal | Healthy volunteers | 34 | NR | 47 | 18 | 77 | | | | Yes
Sedal, 1973 ^299^ | CTS | Complex objective standard | 214 | 56 | 54 | 19 | 87 | | | | Yes
Welch, 1973 ^223^ | Other | Other | 111 | NR | | | | | | | No
Welch, 1973 ^223^ | Combined WRUEDs | Workers at risk | 428 | 81 | | | | | | | No
Casey, 1972 ^300^ | CTS | Unspecified diagnosis | 16 | 94 | 55.9 | 35 | 70 | | | | Yes
Casey, 1972 ^300^ | Other | Other | 18 | 33 | 53.5 | 30 | 77 | 178 | 72 | 444 | Yes
Casey, 1972 ^300^ | Normal | Healthy volunteers | 94 | NR | 51 | 20 | 80 | | | | Yes
Loong, 1972 ^141^ | Normal | Healthy volunteers | 30 | 100 | | 30 | 60 | | | | No
Loong, 1972 ^141^ | CTS | Unspecified diagnosis | 18 | 100 | 43.7 | 31 | 60 | 12.7 | 1 | 48 | No
Melvin, 1972 ^147^ | CTS | Symptoms/ presented | 17 | NR | | | | | | | No
Melvin, 1972 ^147^ | Normal | Healthy volunteers | 24 | NR | | | | | | | No
Buchthal, 1971 ^301^ | Normal | Healthy volunteers | 10 | 50 | | 32 | 57 | | | | No
Buchthal, 1971 ^301^ | CTS | Other | 22 | 73 | | 29 | 67 | | | 360 | No
Loong, 1971 ^148^ | Normal | Healthy volunteers | 30 | 100 | | 30 | 60 | | | | Yes
Loong, 1971 ^148^ | CTS | Symptoms/ presented | 15 | 100 | | 31 | 60 | 7.6 | 1 | 24 | Yes
Plaja, 1971 ^142^ | Normal | Healthy volunteers | 20 | NR | | | | | | | No
Plaja, 1971 ^142^ | CTS | Unspecified diagnosis | 56 | NR | | | | | | | No

a Reported median age instead of mean age

CTS—Carpal tunnel syndrome

DM—Diabetes mellitus

Table 46. Carpal Tunnel Syndrome-Reported Inclusion and Exclusion Criteria

Article | Reported Patient Inclusion Criteria | Reported Patient Exclusion Criteria
Finsen, 2001 ^224^ | Positive clinical diagnosis of carpal tunnel syndrome | Patients for whom the clinical diagnosis was considered equivocal. If more than one hand was treated, only the first was included.
Mondelli, 2001 ^181^ | Idiopathic CTS with reduction of distal conduction velocity of the median nerve. Unilateral CTS. | None reported
Atroshi, 2000 ^225^ | Respondents to a random survey who reported numbness and/or tingling in at least two radial fingers at least twice a week for previous four weeks | Previous CTS surgery, resolution of symptoms, symptoms not consistent with CTS, unwilling to take test
Bland, 2000 ^200^ | All patients in county referred for NCS with suspected CTS, also patients with other referrals who then had a positive NCS | None (authors report 100% inclusion)
Cuturic, 2000 ^226^ | Sensory symptoms and abnormal NCS, limited to mild or moderate disease | Certain EMG abnormalities (authors do not specify that these were in fact exclusion criteria--just that no patients had them)
Kearns, 2000 ^204^ | Pork processing employees who had worked for at least 2 months. | Pre-existing CTS or diabetes.
Loscher, 2000 ^175^ | Referred to the laboratory for neurophysiological assessment of median nerve | Traumatic nerve lesions
Montagna, 2000 ^227^ | Diagnosed with carpal tunnel syndrome or cubital tunnel syndrome. | None reported
Nakamichi, 2000 ^228^ | DML >4.2 ms and SCV >45 m/s | None reported
Raudino, 2000 ^229^ | Referred to lab. All were complaining of discomfort, paresthesias, or weakness in the territory of the median nerve occurring especially at night or after repetitive actions and relieved by changes in posture or shaking hands. Abnormal nerve conduction test as defined by one of the following three abnormalities: 1) DML >4 ms; 2) antidromic DSL to index finger >3 ms; wrist-to-palm sensory latency >1.8 ms for patients <45 years old or >2 ms for patients older than 45. | Metabolic diseases, radiculopathies, polyneuropathies, concomitant pathologies.
Resende, 2000 ^184^ | Clinical diagnosis of carpal tunnel syndrome and abnormal conventional motor and sensory conduction studies | None reported
Resende, 2000 ^174^ | Diagnosed with carpal tunnel syndrome by clinical and electrophysiological methods with conventional techniques. Normal bilateral sensory conduction studies of the ulnar nerve. | None reported
Sener, 2000 ^186^ | Symptoms and clinical signs suggesting carpal tunnel syndrome. | Peripheral nerve dysfunction or peripheral neuropathy other than CTS
Seror, 2000 ^158^ | Diagnosis of mild CTS | None reported
Stalberg, 2000 ^230^ | Patients referred to the lab with the presumptive diagnosis of carpal tunnel syndrome. | None reported
Weber, 2000 ^108^ | Suspected of having carpal tunnel syndrome. | None reported
Atroshi, 1999 ^220^ | Randomly selected from the population of Sweden. | Did not respond to mailed questionnaire, did not attend clinical exam, previous carpal tunnel surgery, declined nerve conduction testing, neurologic disease
Burke, 1999 ^231^ | Referred for splinting | None reported
Duncan, 1999 ^232^ | Positive NCS (decreased median SCV or prolonged DML) or two physicians agreeing that the symptoms and history are consistent with CTS. Did not give specific criteria for either. | Previous surgery or anatomic variation in the median nerve
Kabiraj, 1999 ^233^ | DML >4.02 m/sec [sic] (mean + 2 SD), MCV <47.57 m/s (mean -2 SD), CMAP decreased by 1 SD, prolonged or absent median sensory action potential. Painful paresthesia with night worsening, appropriate distribution, thenar weakness, positive Tinel, positive Phalen. | None reported
Lee, 1999 ^234^ | Clinical diagnosis of CTS. | None reported
Missere, 1999 ^205^ | Male workers in a meat processing plant | None reported
Mongale, 1999 ^235^ | Diagnosed with carpal tunnel syndrome via NCS. | None reported
Murthy, 1999 ^143^ | Referred for electrodiagnostic evaluation for paresthesia | None reported
Rudolfer, 1999 ^236^ | Patients in database referred to electromyographer. | Non-CTS abnormality.
Sander, 1999 ^237^ | Both clinical and electrophysiological diagnosis of carpal tunnel. 1) Clinical: Two or more of the following primary symptoms in a median nerve distribution: numbness, tingling, clumsiness, or nocturnal symptom exacerbation. If only one of these symptoms was present, two of the following secondary symptoms were required: burning/cold, tightness, sore/ache/discomfort, or puffiness. 2)Electrodiagnostic confirmation: one of the following three abnormalities: A) an absent median palm-wrist mixed nerve action potential latency. B) a median palm-wrist mixed nerve action potential latency >1.7ms, C) if this same latency exceed the ipsilateral ulnar palm-wrist latency by more than 0.3ms. | Carpal tunnel patients: excluded if a history or physical exam suggestive of a neuromuscular disorder other than carpal tunnel syndrome.
Simovic, 1999 ^183^ | Referred to laboratory with hand or arm complaints including but not limited to numbness, tingling, or pain | Diabetes or the clinical or electrophysiological suggestion of a concomitant peripheral nerve disorder
Szabo, 1999 ^152^ | Diagnosed CTS | None reported
Thonnard, 1999 ^117^ | Severe CTS: small or absent sensory amplitude, DSL and DML >5 ms, and evidence of denervation in APB | Other (non-CTS) electrodiagnostic abnormalities
Wang, 1999 ^238^ | Symptoms and at least 2 of the following 5 NCS criteria: 1) DML >4.2 ms 2) DSL to index >3.5 ms 3) Difference between median and ulnar mixed nerve latencies = 0.4 ms 4) Difference between median and ulnar sensory latency to ring finger = 0.5 ms 5) Difference between median motor latency to 2nd lumbrical and ulnar motor latency to first palmar interosseous = 0.5 ms | Additional neuromuscular disease, polyneuropathy, cervical radiculopathy, severe CTS, atypical histories.
Aurora, 1998 ^239^ | Referred to lab with clinically definite carpal tunnel syndrome. | None reported
Ferry, 1998 ^221^ | All participants were registered to receive primary care at a local general practice. | None reported
Fertl, 1998 ^153^ | Referred with pain | Polyneuropathy, ulnar nerve lesion, radiculopathy, arthropathy
Gerr, 1998 ^31^ | Any patient 18–70 years old with symptoms of pain, weakness, numbness, or tingling in the cutaneous distribution of the median nerve | Electrophysiological tests positive for a disorder other than CTS.
Ghavanini, 1998 ^154^ | Symptoms of CTS | Conditions other than CTS
Girlanda, 1998 ^149^ | Symptomatic hands with clinical evidence of idiopathic CTS. Examples of symptoms: nocturnal or activity-related pain and paresthesia in the hand, Phalen's, hypaesthesia limited to the distribution of the median nerve. Mild CTS required: No weakness or muscle atrophy present, DML in all patients was never slower than 4.0 ms which represented 2.5 SD below mean of controls in this laboratory. | Known causes of entrapment neuropathies or systemic diseases. Cervical radiculopathy, brachial plexopathy, thoracic outlet syndrome, multi-polyneuropathies.
Kabiraj, 1998 ^240^ | Patients had the following symptoms and signs: history of pain, numbness, paresthesia, nocturnal awakening due to pain and weakness with or without atrophy, decreased sensations, Tinel's signs and wrist flexion Phalen's signs | Evidence of peripheral neuropathy other than median nerve dysfunction
Kleindienst, 1998 ^241^ | Clinical diagnosis of CTS | None reported
Luchetti, 1998 ^242^ | Idiopathic CTS, defined as night pain and/or paresthesia, and median nerve sensory deficits. Motor deficits not required. | Diabetes, uremia, polyneuropathy, history of wrist trauma
Nathan, 1998 ^202^ | Industrial workers in four industries: steel mill workers, food processors, electronics workers, and plastics workers. | Previous carpal tunnel release surgery.
Rosen, 1998 ^201^ | Carpal tunnel patients: Clinically diagnosed. Vibration-exposure patients Symptomatic, with exposure to hand-held vibrating tools. | None reported
Scelsa, 1998 ^243^ | Clinically definite CTS as defined by: symptoms of numbness, paresthesia or pain in median nerve distribution and at least one of the following: hand clumsiness, nocturnal hand symptoms, sensory loss, weakness on exam in an appropriate median nerve distribution. Normal ulnar sensory and motor conduction studies | Cervical radicular pain or objective signs of cervical radiculopathy, or clinical evidence of polyneuropathy, or electrophysiological evidence of ulnar neuropathy
Seror, 1998 ^159^ | Intermittent symptoms of burning, tingling, and paresthesia in the radial digits especially at night or upon awakening. Also patients had normal classical electrodiagnostic tests, i.e., DML to APB <4ms and palm-to-wrist orthodromic sensory conduction velocity >45m/s | None reported
Smith, 1998 ^244^ | Referred with suspected CTS | None reported
Tan, 1998 ^206^ | Working as carpet weaver | None reported
Terzis, 1998 ^162^ | CTS patients: Median distal motor latency required to be less than 4.2 ms. 18 months after the study, confirmation of CTS by sensory nerve latency on either digit 2 or digit 3 of >3ms. | Any history of peripheral nerve problems. Any other pathology, screened out by ulnar nerve and palmar stimulation studies
Tetro, 1998 ^102^ | CTS symptoms including median distribution of pain and paresthesia. Positive NCS including abnormal DML or DSL or DML 1.0 ms more than contralateral or DSL 0.5 ms more than contralateral | Proximal entrapment symptoms, thoracic outlet syndrome, acute CTS, paralysis, negative NCS (n = 7)
Werner, 1998 ^207^ | Workers were selected to be representative of a range of jobs typically found in contemporary manufacturing and clerical sites. | None reported
Wilson, 1998 ^245^ | Presence of carpal tunnel syndrome | History of significant hand trauma, or peripheral neuropathy, or radiculopathy, or Martin-Gruber anastomosis
Bak, 1997 ^246^ | Suspected CTS | Diabetes, severe renal disease, pregnancy within the last year, previously treated CTS, contraindications to MRI, polyneuropathy.
Brahme, 1997 ^199^ | Diagnosed by hand surgeon with work-related dynamic carpal tunnel syndrome (indicating that symptoms only occurred during repetitive motion). | None reported
Bronson, 1997 ^163^ | Patients: Pre-surgery, DML <4 ms, normal needle EMG of APB. Included in this group based on traditional clinical indications, as judged by physicians. Controls: positive Tinel's sign, but no symptoms. Negative on standard sensory and motor nerve conduction tests. | Diabetes, rheumatoid arthritis, hypothyroidism, cervical spine disease, pregnancy, cervical radiculopathy.
Del Pino, 1997 ^104^ | All of the following three criteria for diagnosis of CTS: 1) Symptoms of CTS, consisting of pain predominantly at night, paresthesias and dysaesthesias, numbness, sensory deficit in the territory of the median nerve, and weakness of the APB; 2) Abnormal sensitivity in the median nerve distribution compared to the ulnar territory of the same hand and/or cutaneous territory of the contralateral median nerve in cases of unilateral involvement; 3) Complete relief of pain and paresthesias within 15 days of open surgical release of the carpal tunnel. | None reported
Dellon, 1997 ^107^ | Already diagnosed with either carpal tunnel syndrome or cubital tunnel syndrome. Diagnosis was based on the clinical history and physical examination, which included positive provocative testing, positive Tinel's sign at the wrist or elbow, abnormal tuning fork perception. | Cervical radiculopathy, diabetes, thoracic outlet syndrome, thyroid disease, collagen vascular disease, using narcotics or antidepressants.
Franzblau, 1997 ^208^ | At least 6 months' tenure in jobs at a spark plug manufacturing plant | None reported
Guglielmo, 1997 ^247^ | Typical signs and symptoms of carpal tunnel syndrome (based on American Academy of Neurology Quality Standards Subcommittee) | None reported
Gunnarsson, 1997 ^248^ | Referred to lab with suspected CTS | Neuropathies
Horch, 1997 ^249^ | Surgical candidates with symptoms of CTS and median motor latency >4 ms | None reported
Jeng, 1997 ^209^ | Volunteers from food processing plant. | History of peripheral neuropathy, fractures, severe burns, arthritis, diabetes, carpal tunnel surgery
Kaneko, 1997 ^250^ | Group 01: Coexisting entrapment neuropathy and cervical cord compression demonstrated by MRI. | None reported
| Group 02: Diagnosed with carpal tunnel syndrome.
| Group 03: Diagnosed with cubital tunnel syndrome.
| Group 04: Control group, no subjective symptoms or neurologic findings associated with peripheral or central lesions.
King, 1997 ^114^ | CTS as confirmed by EMG or NCS. New referrals. | None reported
Pierre-Jerome, 1997 ^251^ | Typical signs and symptoms, DML >4.5 ms or sensory velocity <45 m/s | Previous surgery, comorbidity with “somatic connective tissue diseases” (radiculopathy?), alcoholism
Radack, 1997 ^252^ | All wrist MRI examinations, regardless of indication | None
Rosecrance, 1997 ^253^ | Recent (within two weeks) numbness and tingling, or one of those plus any two of: burning/cold, tightness, pain, symptoms worsening at night. Must have involved median nerve distribution (thumb to medial aspect of ring finger). | Disorders with similar presentation to CTS.
Simovic, 1997 ^182^ | 1) Referral to laboratory for possible carpal tunnel syndrome; and 2) Completion of a median motor study including distal and proximal stimulation, sensory antidromic median conduction to the index finger, and mixed nerve median and ulnar conduction studies with palmar stimulation | 1) Clinical symptoms or signs of other peripheral nerve disorders of the same limb. 2) Diabetes mellitus 3) Insufficient chart data
Werner, 1997 ^210^ | DSL prolonged by 0.5 ms or more, but asymptomatic | None reported
Andary, 1996 ^196^ | Referred to lab because of pain or numbness in the hand and wrist with histories and physical exam consistent with the possible diagnosis of CTS. Median antidromic sensory latency to index finger was required to be <4.0 ms to rule out “clear cut” CTS. Other nerve conduction tests (unspecified), however, were required to be positive. | None reported
Atroshi, 1996 ^136^ | Symptoms and signs consistent with carpal tunnel syndrome. Unsuccessful prior nonoperative treatment. | None reported
Bingham, 1996 ^211^ | All new applicants who had been offered jobs at meat packing, plastics assembly, food processing, furniture manufacturing, or grocery warehousing in a 17 county area in the southeastern US over an 18 month period. Applicants had worked for an average of 4.4 years in various settings. | None reported
Checkosky, 1996 ^254^ | Physician-diagnosed CTS | None reported
Cherniak, 1996 ^190^ | Referred to lab. | None reported
Foresti, 1996 ^192^ | Patients with suspected carpal tunnel referred to the laboratory | Other pathologies potentially causing polyneuropathy such as diabetes, iperuremia, acromegaly, etc.
Ghavanini, 1996 ^255^ | Paresthesia or numbness in fingers, and nocturnal hand pain or paresthesia, and excessive hand sweating or coldness, and positive Tinel sign or Phalen sign. | Diabetes, rheumatoid arthritis, thyroid dysfunction, history of trauma to neck or hands, cervical spondylosis, pregnancy, hand edema, obesity
Kleindienst, 1996 ^256^ | Pre-operative | None reported
Murata, 1996 ^164^ | Data entry operators. | None of the patients complained of nocturnal awakening with paresthesia or pain in hands, none had positive Tinel's sign or positive Phalen's sign. Also excluded prior pregnancy, occupational exposure to neurotoxic substances, endocrine disorders, neurological disorders, diabetes, acromegaly, myxedema, lupus, amyloidosis, rheumatoid arthritis, alcoholic dependency, hand injury, forearm injury.
Padua, 1996 ^165^ | Paresthesia, pain, hypotrophy of thenar eminence | Other neuropathies or signs of severe CTS (i.e., absence of SNAP at wrist).
Pierre-Jerome, 1996 ^212^ | Cleaners: Worked for at least three consecutive years and at least 19 hours a week. | Systemic diseases and psychiatric disorders including alcoholism.
Britz, 1995 ^257^ | select group of patients who had been clinically diagnosed as having CTS | None reported
De Smet, 1995 ^101^ | Presented as surgical candidate | None reported
Gerr, 1995 ^118^ | Age 18–70 with any hand symptoms | None reported
Glass, 1995 ^28^ | CTS symptoms | None reported
Golovchinsky, 1995 ^258^ | Referred to lab with complaints of neck pain and/or pain, numbness, or weakness in upper extremities. | Obvious injuries of the wrist, diabetes, hypothyroidism, renal failure.
Hamanaka, 1995 ^259^ | Clinical diagnosis of CTS based on symptoms, sensory disturbance of the median nerve distribution area, Tinel's sign, Phalen's sign, manual muscle testing, and APB atrophy. Carpal canal pressure in resting position >15 mm Hg or carpal canal pressure in power active flex >135 mmHg. | None reported
Hansson, 1995 ^137^ | Typical history (defined by sensory or motor symptoms like intermittent paresthesias, numbness, pain and weakness in the domain of the median nerve) | Diabetes, polyneuropathy, or rheumatic disease
Kothari, 1995 ^260^ | Clinical diagnosis of CTS, including arm or wrist pain, paresthesia or other median distribution symptoms, weakness, Tinel's, or Phalen's and positive NCS | Signs or symptoms of neuropathy
Lang, 1995 ^109^ | 1) CTS-typical signs and symptoms; 2) DML >4.5 ms or orthodromic SCV palm-to-wrist <45 m/s 3) planned surgical treatment | Previous surgery on the same hand
Lesser, 1995 ^261^ | Typical signs and symptoms of carpal tunnel syndrome, AND one or more of the following: 1)median distal motor latency >4.4ms, 2)median sensory antidromic latency to peak >3.5ms, 3)median sensory palm to wrist latency at least 0.4ms longer than that latency for the analogous segment of the ulnar nerve. | Peripheral neuropathy or multiple mononeuropathy
Nakamichi, 1995 ^262^ | Clinical and electrophysiological diagnosis of bilateral CTS. Clinical evaluation included the presence of typical sensory symptoms, Phalen's test, two-point discrimination, muscle testing, and thenar atrophy. Electrophysiological criteria were either DML >4.2 ms or SCV <45 m/s. | Rheumatoid arthritis, chronic renal failure under hemodialysis, endocrine or metabolic disorders including diabetes, gout, amyloidosis, or hypothyroidism, Colles fracture, ganglion, calcium deposition, and osteoarthritis.
Seradge, 1995 ^263^ | None reported | None reported
Seror, 1995 ^179^ | Referred to lab based on a clinical diagnosis of carpal tunnel syndrome: Intermitted paresthesia, numbness, tingling, or hypoesthesia in the median nerve distribution, with nocturnal aggravation, with or without pain in the hand, wrist, and forearm, and rarely for thenar muscle atrophy. | None reported
Shafshak, 1995 ^264^ | Group 001: Positive Phalen's, positive Tinel's, DSL >4 ms, DML >4.7 ms, but normal ulnar nerve conduction studies Group 002: Definite polyneuropathy, DML >4.7 ms, slowed MCV at the forearm. Group 003: Severe unilateral CTS based on clinical findings, and unobtainable DML and DSL, but normal ulnar nerve conduction. | None reported
Sheean, 1995 ^191^ | Referred to lab based on suspected CTS. | None reported
Tassler, 1995 ^115^ | Symptomatic patients who had been diagnosed, had not been cured by nonoperative methods, and later received surgery for the condition. | Diabetes, alcoholism, other toxicity.
Valls-Sole, 1995 ^265^ | Referred to lab, and all of the following:1) Slowing of MCV in wrist to palm and normal DML to thenar and normal CV elbow to wrist2) Normal CMAP amplitude from wrist or elbow stimulation3) Slow median SCV from palm to wrist, but no reduced SNAP amplitude4) Normal ulnar SCV5) No significant limitation of joint movement because of pain, skin or joint diseases or fat. | None reported
Werner, 1995 ^213^ | Employees at an automobile parts manufacturing plant and a furniture assembly plant in southern Michigan. | None reported
Young, 1995 ^166^ | Workers at a poultry processing plant. | None reported
Clifford, 1994 ^266^ | Referred to lab from family physicians, rheumatologists, and neurologists. Symptoms of CTS (e.g. pain, numbness, tingling). Screening history and physical exam to ensure the referring diagnosis of CTS was warranted. | Peripheral neuropathy, or obvious entrapment other than the median nerve.
Durkan, 1994 ^267^ | Symptoms of CTS, particularly in median nerve distribution | None reported
Franzblau, 1994 ^113^ | Full-time employees of an automobile parts manufacturing plant which had reported problems with upper extremity cumulative trauma disorders. | None reported
Gerr, 1994 ^197^ | Referred to lab, age 18–70 with symptoms of pain, weakness, numbness, or tingling that involved either hand. | None reported
Kirschberg, 1994 ^214^ | Employees in repetitive jobs in the poultry industry who were referred to a neurologist with pain, numbness, or tingling. | None reported
Kuntzer, 1994 ^144^ | If patient reported a combination of hand and arm symptoms suggestive of CTS, with numbness, tingling, pins and needles, “sleeping” of the hands and fingers, nocturnal symptoms or clumsiness, weakness, puffiness, swelling, tightness, joint pain or aching of the hand or fingers. | Patients: Two were excluded due to absent distal reflexes in the lower extremities. Controls: Two were excluded due to presence of symptoms of CTS, or pregnancy.
Nathan, 1994 ^215^ | Japanese furniture factory workers. American workers from four industries. | None reported
Nilsson, 1994 ^216^ | Currently working as a platers, truck assembler, or office worker. Male, age <54, randomly selected from larger groups for participation in the study. Platers were required to be currently exposed to vibration, and were selected for nerve conduction based on consecutive cases. | None reported
Para, 1994 ^103^ | Paresthetic CTS: Has CTS, has normal distal motor latency. Slight CTS: Has CTS, has abnormal distal motor latency. Controls: no current or past subjective complaints about upper extremities and an entirely normal neurological exam. | None reported
Rossi, 1994 ^178^ | History and symptoms typical of idiopathic CTS. Reduction of median nerve SCV in one or more of the digit-wrist segments studied, with normal values of ulnar and radial nerve sensory conduction. | Working at manual jobs. None had signs or history of cervical radiculopathy or peripheral neuropathy.
Werner, 1994 ^217^ | Employees at an automobile parts manufacturing plant that had reported a significant problem with CTS. Consent to testing. | Significant exposures to vibration or low temperature.
Werner, 1994 ^111^ | Referred for evaluation of CTS, must have median nerve symptoms | None reported
Eisen, 1993 ^193^ | One of three groups: 1) Clinical for CTS. Symptoms and clinical signs. Examinations included Tinel's and Phalen's, but these were not required for diagnosis of CTS; 2) Historical for CTS. Symptoms: pain, sensory discomfort, or numbness in the hand, nocturnal awakening because of hand pain, clumsiness and loss of dexterity; 3) Uncertain. Vague complaints without nocturnal awakening and no loss of hand dexterity, and normal neurological exam. | 1) Clinical or electrophysiological evidence of other upper limb neuropathy such as proximal median neuropathy, ulnar neuropathy, or cervical radiculopathy. 2) Historical or clinical evidence of systemic disease such as diabetes or alcoholism. 3) Prior treatment with a wrist splint or carpal tunnel surgical release. 4) Inability to obtain a median CMAP elicited by stimulating the median nerve at the wrist or inability to obtain median or ulnar SNAPs by palmar stimulation
Johnson, 1993 ^167^ | Employees at one of six poultry processing plants. | None reported
Nakamichi, 1993 ^268^ | Diagnosed with carpal tunnel syndrome based on clinical signs and NCS tests. Clinical evaluation included the presence of typical sensory symptoms, Phalen's and Tinel's tests, sensory testing by 2-point discrimination on the middle finger, muscle testing, and thenar atrophy. NCS was abnormal if either DML >4.2 ms or SCV <45 m/s. | None reported
Nathan, 1993 ^218^ | Industrial workers from six industries: steel mill, meat/food processing, electronics, plastics, aluminum reduction, and cable plant. Workers' compensation patients had upper extremity complaints, primarily related to suspected CTS. | None reported
Rodriquez, 1993 ^269^ | History and physical, and abnormal NCS | Peripheral neuropathy, cervical radiculopathy, other entrapments
Rosen, 1993 ^270^ | Workers: Complaints of numbness and paresthesia and sometimes pain after long term exposure to vibrating tools. Carpal tunnel syndrome patients: Diagnosed with carpal tunnel syndrome, symptoms typical of CTS (numbness and paresthesia of radial fingers aggravated at night ), not exposed to vibration | None reported
Rosén, 1993 ^138^ | Referred for diagnosis of suspected CTS. All had numbness and paresthesia that worsened at night | Any other explanation for symptoms, such as radiculopathy or polyneuropathy
Uncini, 1993 ^160^ | Clinical signs and symptoms suggestive of CTS, DML <4.2 ms (normal), SCV index-to-wrist >45 m/s (normal). | None reported
Buchberger, 1992 ^271^ | Patients with carpal tunnel syndrome. All had pain and sensory impairment in the distribution of the median nerve. All had prolonged DML (unspecified threshold). | None reported
Grant, 1992 ^219^ | Symptomatic: tingling, numbness, or decreased sensation in at least two fingers. Diagnosed: symptoms plus abnormal NCS | Arthritis, broken bones in hand/wrist, Raynaud's syndrome, previous wrist surgery, diabetes, kidney or metabolic disorders, heart or other circulatory disorders, pregnancy, use of OCs or hormones, history of heavy alcohol or tobacco use
Imaoka, 1992 ^272^ | Any sensory disorder in the median nerve region, and either nocturnal acroparesthesia or positive Phalen's sign. | Marked atrophy of APB, peripheral nerve disorders, diabetes, or other polyneuropathies.
Kindstrand, 1992 ^273^ | NCS-confirmed CTS | None reported
Preston, 1992 ^188^ | Symptoms of CTS, “proven to have electrophysiologic CTS by standard nerve conduction criteria.” Plus eight patients with possible CTS (symptomatic, but normal standard median studies, and at least one additional abnormal test) | None reported
Tchou, 1992 ^274^ | Referred to lab with symptoms and clinically diagnosed CTS, and confirmation of diagnosis via established criteria for nerve conduction studies. Developed symptoms within three months preceding examination. | None reported
Buchberger, 1991 ^275^ | Symptoms of CTS. | Unrelieved or recurrent CTS after surgical treatment.
Chang, 1991 ^145^ | History of carpal tunnel syndrome, with intermittent paresthesia occurring spontaneously at night or after repetitive use of the affected hand | Diabetes
Durkan, 1991 ^155^ | Suspected carpal tunnel syndrome based on pain, numbness, and paresthesias in the distribution of the median nerve. Either abnormal motor latency or sensory latency. | None reported
Jetzer, 1991 ^168^ | One of four different groups: computer assemblers, meat processors, keyboard workers, controls. | None reported
Katz, 1991 ^276^ | Pain or paresthesia in the upper extremity who were referred to the lab, and whose symptoms were caused by work. | Patients whose symptoms were not caused by work.
Lauritzen, 1991 ^185^ | Symptoms and signs compatible with CTS, and slowing of SCV along the median nerve from digit 1 or 3,or both, to the wrist, and prolonged DML from wrist to APB. | None reported
Luchetti, 1991 ^169^ | Nocturnal paresthesia in the median nerve territory. Normal motor function, sensory function, quantitative sensory examination, cutaneous trophism, distal sensory latency, distal motor latency. | Polyneuropathy, metabolic diseases with involvement of peripheral nerves.
Radwin, 1991 ^116^ | Diagnosis of CTS. Sensory complaints including tingling or numbness in the thumb, index, or middle finger and nocturnal exacerbation of the paresthesias. Either positive Tinel's sign, positive Phalen's sign, or positive Semmes-Weinstein monofilaments test. | Polyneuropathy, evidence of Raynaud's phenomenon.
Charles, 1990 ^170^ | For carpal tunnel syndrome patients: Clinical diagnosis of CTS by referring physician, and at least one of the following: 1) DML = 4.5 ms; 2) median orthodromic sensory nerve conduction in the second finger <45 m/s; 3) difference between median and ulnar orthodromic distal sensory latencies in the ring finger = 0.5ms. | For controls: Diabetes, peripheral neuropathy, no symptoms suggestive of CTS For the cervical spondylitic radiculopathy group: hand paresthesia mainly in the second and third fingers
DeKrom, 1990 ^222^ | Randomly selected from the general population of Maastricht (The Netherlands) and surrounding villages. | None reported
Fitz, 1990 ^277^ | APB motor latency = 4.2 ms, or digit 1 radial sensory latency = 3.1 ms, or median sensory latency = 3.2 ms or difference = 0.5 ms or similar abnormalities on digit 3 | None reported
Gilliatt, 1990 ^278^ | Patients had carpal tunnel syndrome | None reported
MacDonell, 1990 ^90^ | Patients had at least two of five criteria: 1) DML >4.2ms; 2) SNAP amplitude <10μV;3) SNAP conduction velocity <40m/s; 4) SNAP amplitude less than that of the ipsilateral ulnar nerve at the wrist; 5) median motor or sensory latencies at the wrist more than 0.5 ms longer than opposite hand | Normal ulnar nerve motor and sensory conduction studies in both arms
Merchut, 1990 ^279^ | Symptomatic CTS referred to the lab. Electrophysiological confirmation via at least one of four NCS tests: 1) Prolonged sensory latency; 2) Prolonged DML; 3) Slowed median SCV; 4) prolonged difference between median sensory latency from ring finger and ulnar sensory latency from ring finger. | Excluded if any clinical signs, symptoms, or EMG findings suggested the possibility of another cause of paresthesia or numbness in their hands such as polyneuropathy, radiculopathy, or CNS lesion.
Palliyath, 1990 ^171^ | Symptoms of CTS, but little change on routine NCS | None reported
Pease, 1990 ^177^ | Symptoms and abnormal nerve conduction testing (vague). | Abnormalities or radial or ulnar nerves. Abnormal EMG of any muscle except the thenar muscles.
Rojviroj, 1990 ^280^ | Symptoms, positive Phalen's and positive Tinel's, and carpal tunnel was confirmed by DSL >3.5 ms or DML >4.5 ms or both. | None reported
Tzeng, 1990 ^180^ | Diagnosed by both clinical and electromyographic findings | None reported
Uncini, 1990 ^135^ | Typical CTS symptoms but normal DML and normal or borderline SCV | None reported
Winn, 1990 ^281^ | Responded to ad on bulletin board | None reported
Braun, 1989 ^282^ | Symptoms of dynamic carpal tunnel syndrome. | Evidence of long-standing fixed compression neuropathy or with contributory diseases such as rheumatoid arthritis. Thenar atrophy or profound fixed anesthesia.
Cioni, 1989 ^146^ | Signs and symptoms suggestive of carpal tunnel syndrome. Referred to laboratory for electrophysiological confirmation of carpal tunnel syndrome. | History or physical evidence of peripheral neuropathy or cervical radiculopathy.
Jackson, 1989 ^150^ | Referred to the lab for symptoms of CTS. | Peripheral neuropathy, or obvious entrapment other than median nerve.
Meyers, 1989 ^283^ | History and physical consistent with CTS, characteristic electrophysiologic abnormalities | None reported
So, 1989 ^173^ | Patients were selected from referrals to the lab. Carpal tunnel syndrome: Confident clinical diagnosis based on history of pain and paresthesias in the hand and fingers, and physical findings that localized the pathology to the median nerve, e.g. sensory alteration or weakness in a median nerve distribution, Tinel's, or Phalen's. | None reported
| Cubital tunnel syndrome: Confident clinical diagnosis based on paresthesias or numbness in an ulnar nerve distribution, usually accompanied by weakness in ulnar-innervated muscles. In those patients without weakness on examination, the diagnosis of ulnar neuropathy at the elbow was not made unless there was percussion sensitivity at the cubital tunnel or the ulnar groove, or exacerbation of symptoms with elbow flexion.
Szabo, 1989 ^284^ | CTS patients about to have carpal tunnel release surgery. Clinical and electrophysiological evidence of CTS. Electrophysiological evidence based on either DML >4.5 ms or DSL >3.5 ms. | None reported
Uncini, 1989 ^161^ | Symptoms and signs of carpal tunnel syndrome | Severe carpal tunnel (DML >4.2 ms or SNAPs were absent or SNAPs were very low amplitude)
De Léan, 1988 ^285^ | Paresthesia in median nerve distribution, regardless of Tinel's or Phalen's signs | Polyneuropathy, medicolegal cases, workers' comp
Koris, 1988 ^198^ | Accepted signs and symptoms including paresthesia, but did not have to be limited to the median nerve distribution | None reported
Molitor, 1988 ^110^ | Referred to lab for the diagnosis of carpal tunnel. | None reported
Mortier, 1988 ^286^ | Prolonged distal motor latency of median nerve or prolonged distal sensory latency of median nerve | Generalized peripheral neuropathy, other peripheral entrapment neuropathies, cervical radiculopathy.
Pease, 1988 ^287^ | Diagnosed with CTS based on clinical and electrodiagnostic findings | None reported
Carroll, 1987 ^288^ | Referred to lab, symptoms suggestive of CTS | Abnormal ulnar sensory amplitude or latency.
Jessurun, 1987 ^289^ | Suffering from primary CTS | None reported
Johnson, 1987 ^290^ | Antidromic DSL to middle finger >4 ms and DML >4.3 ms. | None reported
Liang, 1987 ^291^ | None reported | None reported
Macleod, 1987 ^292^ | Symptomatic NCS confirmed with abnormal sensory latency | Signs of other neurologic disorder
Seror, 1987 ^156^ | Pathological wrists | Radicular signs
Borg, 1986 ^293^ | Referred to lab with suspicion of CTS. Patients had digital paresthesias. | None reported
Gellman, 1986 ^106^ | Carpal tunnel group syndrome: Three requirements: 1) Symptoms indicative of median-nerve compression in the carpal canal; 2) Either positive Semmes-Weinstein test or positive two-point discrimination test; 3) Positive nerve conduction results as indicated by any of four abnormalities: A) DML >4.5 ms B) DML on symptomatic hand more than 1 ms slower than DML on asymptomatic hand C) Sensory latency >3.5 ms D) Sensory latency on symptomatic hand more than one millisecond slower than on asymptomatic hand. | None reported
| Diverse lesion group: Abnormal results on clinical sensibility testing other than carpal tunnel syndrome
Escobar, 1985 ^151^ | Patients: Referred to lab for evaluation of numbness, tingling, weakness, and/or pain in the hand or arm. Controls: DSL <3.7 ms. | Endocrine disorders or peripheral nerve disease.
Kimura, 1985 ^189^ | Referred to lab with frank clinical signs and symptoms suggestive of CTS | Other disease that predispose toward peripheral neuropathy.
Mills, 1985 ^194^ | Tentative diagnosis of CTS | None reported
Borg, 1984 ^294^ | Patients with CTS. Some patients' conditions had been neurophysiologically confirmed (undefined). | None reported
Pryse-Phillips, 1984 ^105^ | Group 01: Carpal tunnel syndrome: Symptoms of paresthesia, numbness and/or weakness in the hand in digits I–II or I–V, with or without hand and arm pain, usually with nocturnal or early morning accentuation, ± clinical signs of thenar motor or median nerve territory sensory deficit. DML >4.5 ms or a difference of 1 ms between right and left or 1.5 median/ulnar difference. Median SNAP amplitude <ulnar or <10 μV or latency to onset >3.5 ms. Group 02: Cubital tunnel syndrome: Symptoms of hand weakness, ± digit V (IV) hypoesthesia, not extending into palm: and/or electrical signs of interosseous or hypothenar wasting, with proportionate weakness. Eisen score (undefined) greater than 5/10. Group 03: Other median nerve pathologies: Digital neuropathy affecting digits I–III or arm pain/paresthesia without nocturnal predominance, or clinically apparent weakness of long forearm flexors, ± palmar hypoesthesia. EMG evidence of acute/chronic denervation in forearm flexor muscles, ± delay in motor conduction across the point above the wrist with absence of electrical evidence of median nerve compression at the carpal tunnel. Group 04: Thoracic outlet syndrome. Group 05: Cervical radiculopathy | Carpal tunnel syndrome: Martin-Gruber anastomosis, other median nerve pathologies: cases of anterior interosseous syndrome
Satoh, 1984 ^295^ | No symptoms, normal ulnar sensory and motor conduction and one of three nerve conduction abnormalities: 1) orthodromic SCV digit-to-palm <42 m/s; 2) terminal latency >4.2 ms; 3) absent SNAP and absent CMAP. | None reported
Szabo, 1984 ^30^ | Patients with objectively proved abnormalities of median nerve conduction who had carpal tunnel release surgery. | None reported
Goddard, 1983 ^296^ | Diagnosed with CTS and referred to the department | None reported
Kim, 1983 ^195^ | Signs and symptoms highly suggestive of CTS but with borderline or normal DSL. | None reported
Marin, 1983 ^139^ | Patients had previously undergone routine NCS studies for carpal tunnel syndrome | None reported
Wongsam, 1983 ^172^ | Symptoms suggesting early CTS | None reported
Johnson, 1981 ^297^ | Diagnosed CTS: history and NCS | None reported
Dekel, 1980 ^21^ | Diagnosed with carpal tunnel using history, clinical exam, and nerve conduction studies. | Any of the recognized diseases associated with carpal tunnel syndrome.
Messina, 1980 ^120^ | Signs and symptoms suggestive of CTS | None reported
Gelmers, 1979 ^29^ | Diagnosis of carpal tunnel based on three findings: 1) Acroparesthesia in the distribution of the median nerve; 2) Thenar muscle wasting or weakness or failure to detect an action potential of the thenar muscles by needle electromyography; 3) Prolongation of distal latency of the median nerve to more than 4.7 ms, or a difference in distal latency of more than 1 ms between symptomatic and asymptomatic hands, even though both latencies were within normal limits | Signs of generalized neuropathy
Kimura, 1979 ^140^ | Clinical impression (history and symptoms, not NCS), relatively mild symptoms | Polyneuropathy
Schwartz, 1979 ^187^ | Referred to lab based on sensory symptoms in a median distribution. | Generalized neuropathy
Stewart, 1978 ^157^ | In addition to ipsilateral ulnar sensory amplitude = 8.5 μV and ulnar sensory latency <2.8 ms, three or more of the following were required: 1) Sensory signs in the distribution of the median nerve.; 2) Thenar wasting or weakness; 3) DML >4.5 ms; 4) sensory onset latency >2.7 ms; 5) Sensory amplitude <8.6 μV | Diabetes, peripheral neuropathy. CTS secondary to trauma or other localized or generalized disease.
Eisen, 1977 ^298^ | Carpal tunnel patients: Sensory symptoms limited to one or both hands, normal ulnar sensory latency (<2.8 ms), normal ulnar sensory amplitude (>8.4 μV), and at least three of the following five criteria: 1) Sensory signs restricted to median distribution; 2) Weakness or wasting of the APB muscle; 3) Median DML >4.5 ms; 4) Median DSL >2.7 ms; 5) Median SNAP amplitude <8.6 μV or median SNAP duration >2.4 ms. | Subjects were excluded from the control group if there was neuromuscular disease, diabetes, alcoholism, peripheral neuropathy, or systemic dysfunction.
| Cubital tunnel patients: Sensory symptoms limited to one or both hands, normal median sensory latency (<2.7 ms), normal median sensory amplitude (>8.6 μV), and at least three of the following six criteria: 1) Sensory signs restricted to ulnar distribution; 2) Weakness or wasting of the ulnarinnervated muscles of the hand; 3) Ulnar DML >4.0 ms; 4) Ulnar proximal motor latency (stimulation just above the elbow) >8.9 ms; 5) Ulnar DSL >2.8 ms; 6) Ulnar SNAP amplitude <8.4 μV or ulnar SNAP duration >2.1 ms.
| Patients with proximal lesions: Sensory symptoms limited to one or both hands, but did not meet criteria for either carpal tunnel or cubital tunnel.
Sedal, 1973 ^299^ | Presented as idiopathic carpal tunnel. | Excluded if CTS was an incidental finding in the investigation of a generalized peripheral neuropathy, OR if they had diabetes or alcoholism or chronic renal disease, or if there was clinical evidence of either radial or nerve lesions
Welch, 1973 ^223^ | Workers at a factory employed on repetition work producing domestic appliances. The other group consisted of job applicants who had not yet started work. | None reported
Casey, 1972 ^300^ | Carpal tunnel syndrome: Classical symptoms. Also 10 of the 16 patients had hypalgesia in the fingers of the involved hand supplied by the median nerve. Abnormal (or at the lower limit of normal) median SNAP recorded at the wrist after digital stimulation. Diabetics: Reflex changes and distal sensory abnormalities in the lower limbs, consisting of pain and paresthesia with sensory loss. In addition, 10 of the 18 diabetics had sensory changes in the upper limbs | None reported
Loong, 1972 ^141^ | Clinical diagnosis of CTS with typical history of intermittent paresthesia at night or after use. | None reported
Melvin, 1972 ^147^ | Referred to the laboratory as possible cases of carpal tunnel syndrome. | None reported
Buchthal, 1971 ^301^ | None reported | Normal ulnar SCV and latency to ADM to exclude generalized neuropathy
Loong, 1971 ^148^ | Referred to lab with clinical diagnosis of carpal tunnel syndrome. Typical history of the syndrome with intermittent paresthesia occurring spontaneously at night or after use of the affected hand. | Diabetes
Plaja, 1971 ^142^ | None reported | “We excluded misleading diagnosis by controlling at the same time different levels and nerve trunks.”

Table 43. Prediction of Future CTS by Maximum Latency Difference

MLD result | Future CTS | No CTS | Threshold | Sensitivity | Specificity | PPV | NPV
<0.28 ms | 3 | 129 | 0.28 ms | 90.9% 76.1% 96.9% | 29.9% 25.7% 34.5% | 9.0% 6.4% 12.7% | 97.7% 93.4% 99.2%
0.28–0.35 ms | 11 | 211 | 0.36 ms | 57.6% 40.5% 73.0% | 78.9% 74.7% 82.5% | 17.3% 11.2% 25.6% | 96.0% 93.4% 97.7%
0.36–0.43 ms | 7 | 56 | 0.44ms | 36.4% 22.0% 53.7% | 91.9% 88.8% 94.1% | 25.5% 15.1% 39.8% | 95.0% 92.4% 96.7%
0.44–0.51 ms | 5 | 20 | 0.52 ms | 21.2% 10.5% 38.1% | 96.5% 94.3% 97.9% | 31.8% 16.1% 53.1% | 94.1% 91.5% 96.0%
>0.51 ms | 7 | 15

Data from Nathan et al., 1998 ^202^

Future CTS—Patients developed CTS during the 11-year followup periof

No CTS—Patients did not develop CTS during followup period.

Figure 15. Prediction of Future CTS by Maximum Latency Difference

Data from Nathan et al. ^202^

#### Conclusions

The evidence base on most individual diagnostic tests for carpal tunnel syndrome is small, even though the total number of articles on CTS diagnosis is large (Table 19). This is because there are so many different tests that have been reported. Nerve conduction tests are most frequently reported in the literature, but there is great diversity in their methods, and one cannot conclude that one of these tests is effective based on clinical trial results for another test.

The most frequently reported nerve conduction tests were distal motor latency and palmar sensory latency. There were sufficient clinical trial articles available for us to meta-analyze their results and obtain estimates of their sensitivity sensitivities and specificites. For both tests, clinicians chose thresholds that yielded high specificity (a low incidence of false-positive results). ECRI's meta-analyses of distal motor latency studies found the sensitivity of the test to be 57% to 66% and the specificity to be 98%. The meta-analysis of palmar sensory latency studies found a sensitivity of 76% and a specificity of 98%.

Because all of the trials in these analyses used healthy asymptomatic persons as controls, the results of these analyses may overestimate the specificity of nerve conduction measurements in typical practice, where the test would be used on workers believed to be at risk for CTS or persons suspected of having CTS. There are not enough data to permit us to test the hypothesis that high specificity may be an effect of selection criteria for the control groups creating a control population unrepresentative of the population the test would be used on in routine practice: patients with suspected CTS.

Clinical signs and symptoms are also used in the diagnosis of CTS. The evidence base on these tests was smaller than the evidence base on nerve conduction measurement. Like nerve conduction tests, there were many different signs and symptoms reported in the literature, and one cannot infer a test's effectiveness based on the effectiveness of other tests. We attempted to use our meta-analysis techniques to obtain summary values for the sensitivity and specificity of Tinel's sign and Phalen's maneuver. In both cases, there was heterogeneity in the published results that could not be explained by differences in patient selection or by single outlier studies. Therefore, we did not calculate summary measurements for sensitivity or specificity. The sensitivity of Phalen's maneuver was lower than its specificity, and two trials reported sensitivity of 80% to 90%. All of the studies of Tinel's sign found that its sensitivity was lower than its specificity, and none found a sensitivity of 75 percent or greater. There was too much heterogeneity in the results for us to conclude that one test was superior to the other, or to compare these tests to nerve conduction testing.

Regarding sensory tests, composite nerve conduction tests, and imaging tests, there was insufficient evidence for us to perform meta-analyses of clinical trial results.

Analysis of tests for CTS screening and for early diagnosis of CTS is hampered by the lack of agreement by investigators on what those terms mean. We identified 28 articles described by their authors as “screening” studies, but only five of these studies provided longitudinal data. Most employed cross-sectional designs in which the authors evaluated the ability of other tests to identify subjects with abnormal nerve conduction.

One well-designed study by Nathan et al ^202^ suggests that nerve conduction measurement may be able to identify some workers at risk of developing CTS in the future. By itself, this evidence is not sufficient for us to conclude that nerve conduction screening for CTS is effective, but there could be sufficient unpublished results from this study to confirm the findings of the one reported test.

### Question #2: What are the specific indications for surgery for carpal tunnel syndrome?

Published evidence does not directly address the specific indications for surgery for carpal tunnel syndrome. Therefore, we describe the reported characteristics of patients who have received surgery for carpal tunnel syndrome in published studies. The extent to which these patients represent typical surgical candidates is not certain. Patients included in published studies of a procedure are frequently a subset of patients who are candidates for that procedure. They may represent an unusual group of interest, or a group thought most likely to benefit from the procedure. Therefore, the data presented here, while informative, may not accurately reflect the overall patient population. It does, however, represent the best data available, and is the most comprehensive description of those carpal tunnel syndrome patient characteristics who receive surgery that has yet been compiled.

#### Evidence Base

To answer this question, we examined 141 studies (controlled trials and case series) describing a total of 15,993 patients.

#### Age

Patients who received surgery for carpal tunnel syndrome were predominantly of middle age. The mean of mean ages from the 124 studies that reported this information was 50.5 years, with a standard deviation of 5.7. Ages of individual patients ranged from 17 to 100 years. Mean ages and ranges from individual studies are given in Table 47, and are depicted in Figure 16. The vertical line in Figure 16 represents the mean age for all studies.

Table 47. Age and sex of patients receiving surgery for carpal tunnel syndrome

Trial | Number of patients | Number of males | Number of females | Percent female | Age reported as mean or median? | Age | Age of youngest patient | Age of oldest patient
Finsen, 2001 ^224^ | 79 | 18 | 61 | 77.2% | Median | 48 | 21 | 86
Mondelli, 2001 ^181^ | 28 | 4 | 24 | 85.7% | Mean | 52.8 | 35 | 75
Avci, 2000 ^309^ | 25 | 1 | 24 | 96.0% | Mean | 43 | 21 | 72
Khan, 2000 ^310^ | 44 | 11 | 33 | 75.0% | Mean | 55 | 29 | 88
Mondelli, 2000 ^311^ | 110 | 13 | 97 | 88.2% | Mean | 56 | 20 | 82
Muller, 2000 ^312^ | 148 | 28 | 120 | 81.1% | Mean | 51.8 | NR^a^ | NR
Porras, 2000 ^313^ | 85 | 8 | 77 | 90.6% | Mean | 52 | 18 | 81
Vartimidis, 2000 ^314^ | 15 | 6 | 9 | 60.0% | Mean | 52 | 28 | 75
Alderson, 1999 ^315^ | 26 | 5 | 21 | 80.8% | Mean | 44.4 | 22 | 79
Braun, 1999 ^316^ | 225 | 36 | 189 | 84.0% | Mean | 41.0 | NR | NR
Chen, 1999 ^317^ | 948 | 212 | 736 | 77.6% | Mean | 48 | 21 | 79
Erhard, 1999 ^318^ | 124 | 15 | 109 | 87.9% | Mean | 54.3 | 19 | 84
Finsen, 1999 ^319^ | 82 | 22 | 60 | 73.2% | Mean | 49.4 | 21 | 86
Hasegawa, 1999 ^320^ | 82 | 0 | 82 | 100.0 | Mean | 54.1 | NR | NR
Hirooka, 1999 ^321^ | 37 | 4 | 33 | 89.2% | Mean | 58 | 40 | 78
Lindau, 1999 ^322^ | 140 | 17 | 123 | 87.9% | Mean | 55.4 | NR | NR
Olney, 1999 ^323^ | 211 | 46 | 165 | 78.2% | Mean | 44.8 | NR | NR
Senda, 1999 ^324^ | 26 | 1 | 25 | 96.2% | Mean | 56.8 | 19 | 93
Straub, 1999 ^305^ | 67 | 47 | 20 | 29.9% | Median | 40 | 19 | 70
Vartimidis, 1999 ^325^ | 22 | 8 | 14 | 63.6% | Mean | 52 | 21 | 77
Atroshi, 1998 ^326^ | 103 | 35 | 68 | 66.0% | Mean | 52 | 21 | 88
Aulisa, 1998 ^327^ | 45 | 8 | 37 | 82.2% | Mean | 47 | 26 | 68
Buckhorn 1998 ^328^ | 50 | 21 | 29 | 58.0% | Mean | 51.3 | 27 | 61
Choi, 1998 ^329^ | 154 | 6 | 148 | 96.1% | Mean | 52 | 30 | 82
Davies, 1998 ^330^ | 239 | NR | NR | NR | Mean | 43.5 | 20 | 82
Lee, 1998 ^331^ | 525 | 134 | 391 | 74.5% | Mean | 50.7 | 21 | 88
Nakamichi, 1998 ^332^ | 130 | 16 | 114 | 87.7% | Mean | 58 | 35 | 85
Papageorgiou, 1998 ^333^ | 76 | 18 | 58 | 76.3% | Mean | 48 | NR | NR
Schuind. 1998 ^334^ | 13 | 6 | 7 | 53.8% | Mean | 47 | 45 | 77
Tomaino, 1998 ^335^ | 29 | 6 | 23 | 79.3% | Mean | 52 | 28 | 82
Armstrong, 1997 ^336^ | 176 | 35 | 141 | 80.1% | Mean | 50.5 | 30 | 86
Atroshi, 1997 ^337^ | 204 | 56 | 148 | 72.5% | Mean | 49.3 | 19 | 94
Baguneid, 1997 ^338^ | 75 | 11 | 64 | 85.3% | Mean | 56 | 24 | 85
Chia, 1997 ^339^ | 62 | 13 | 49 | 79.0% | Mean | 47.7 | 29 | 73
Citron, 1997 ^340^ | 47 | 8 | 39 | 83.0% | Mean | 52.1 | 26 | 80
Higgs, 1997 ^341^ | 93 | 30 | 63 | 67.7% | Mean | 43 | 23 | 69
Karlsson, 1997 ^48^ | 74 | 15 | 59 | 79.7% | Median | 54.5 | 24 | 88
Katz, 1997 ^302^ | 135 | 42 | 93 | 68.9% | NR | NR | NR | NR
Leinberry, 1997 ^342^ | 44 | 18 | 26 | 59.1% | Mean | 64.9 | 38 | 100
Rosen, 1997 ^343^ | 102 | 18 | 84 | 82.4% | Mean | 51.0 | 24 | 82
Serra, 1997 ^344^ | 112 | 16 | 96 | 85.7% | Mean | 47 | 31 | 70
Stahl, 1997 ^345^ | 50 | 16 | 34 | 68.0% | Mean | 49.5 | NR | NR
Tucci, 1997 ^346^ | 27 | 6 | 21 | 77.8% | Mean | 48.6 | NR | NR
Weber, 1997 ^347^ | 74 | 26 | 48 | 64.9% | Median | 41.4 | 26 | 80
Wheatly, 1997 ^307^ | 126 | 114 | 12 | 9.5% | NR | NR | NR | NR
Cobb, 1996 ^348^ | 235 | 44 | 191 | 81.3% | Mean | 51 | 20 | 79
Elmaraghy. 1996 ^349^ | 69 | 21 | 48 | 69.6% | Mean | 51 | 24 | 97
Franzini, 1996 ^350^ | 50 | 11 | 39 | 78.0% | Mean | 52 | 32 | 60
Gibbs, 1996 ^351^ | 46 | 16 | 30 | 65.2% | Mean | 56.2 | 31 | 86
Glowacki, 1996 ^352^ | 167 | 35 | 132 | 79.0% | Mean | 42 | 17 | 84
Jacobsen, 1996 ^353^ | 32 | 9 | 23 | 71.9% | Mean | 44.9 | 24 | 59
Kluge. 1996 ^354^ | 66 | 18 | 48 | 72.7% | Mean | 51 | 36 | 93
Lee, 1996 ^355^ | 275 | 76 | 199 | 72.4% | Mean | 50.7 | 21 | 88
Mclaughlin, 1996 ^356^ | 102 | 26 | 76 | 74.5% | Mean | 52 | NR | NR
Nagle, 1996 ^357^ | 506 | 134 | 372 | 73.5% | Mean | 48 | 13 | 91
Nygaard, 1996 ^306^ | 29 | 7 | 22 | 75.9% | Mean | 53 | 32 | 75
Okutsu, 1996 ^41^ | 43 | 2 | 41 | 95.3% | Mean | 55.1 | 31 | 87
Padua, 1996 ^358^ | 33 | 7 | 26 | 78.8% | Mean | 47.2 | NR | NR
Pennino, 1996 ^359^ | 124 | NR | NR | NR | Mean | 55 | 28 | 92
Povlsen, 1996 ^360^ | 51 | 23 | 28 | 54.9% | NR | NR | NR | NR
Strickland, 1996 ^361^ | 62 | 16 | 46 | 74.2% | Mean | 52 | 22 | 88
Wintman, 1996 ^362^ | 50 | NR | NR | NR | Mean | 54 | 25 | 83
Worseg, 1996 ^44^ | 126 | 38 | 88 | 69.8% | Mean | 56.0 | 35 | 90
Abdullah, 1995 ^363^ | 100 | 19 | 81 | 81.0% | Mean | 41.4 | 19 | 79
Bury, 1995 ^364^ | 43 | 4 | 39 | 90.7% | Mean | 52.3 | NR | NR
Dumontier, 1995 ^365^ | 96 | 11 | 85 | 88.5% | Mean | 41.1 | 29 | 53
El-Zahaar, 1995 ^43^ | 41 | 12 | 29 | 70.7% | Mean | 53 | 39 | 61
Futami, 1995 ^366^ | 10 | 1 | 9 | 90.0% | Mean | 51 | NR | NR
Gross, 1995 ^367^ | 44 | 16 | 28 | 63.6% | Mean | 44.2 | NR | NR
Hallock, 1995 ^368^ | 100 | 26 | 74 | 74.0% | Mean | 59 | NR | NR
Katz, 1995 ^369^ | 50 | 6 | 44 | 88.0% | Mean | 51.4 | NR | NR
Lang, 1995 ^109^ | 23 | 5 | 18 | 78.3% | Mean | 53 | 25 | 84
LoVerme, 1995 ^370^ | 42 | 4 | 38 | 90.5% | Mean | 29 | NR | NR
Mirza, 1995 ^371^ | 236 | 74 | 162 | 68.6% | Mean | 44 | 17 | 79
Nancollas, 1995 ^372^ | 93 | 17 | 76 | 81.7% | Mean | 52.5 | NR | NR
Sennwald, 1995 ^373^ | 47 | 12 | 35 | 74.5% | Mean | 54 | 22 | 88
Shinya, 1995 ^374^ | 88 | 16 | 72 | 81.8% | Mean | 49 | 20 | 82
Al-Qattan, 1994 ^375^ | 112 | 28 | 84 | 75.0% | Mean | 54 | 25 | 83
Chow, 1994 ^42^ | 815 | 289 | 526 | 64.5% | NR | NR | NR | NR
Erdmann, 1994 ^304^ | 96 | 26 | 70 | 72.9% | Mean | 53.4 | NR | NR
Foulkes, 1994 ^376^ | 33 | 16 | 17 | 51.5% | Mean | 45.4 | NR | NR
Katz, 1994 ^377^ | 104 | 31 | 73 | 70.2% | Mean | 55 | 25 | 87
Kelly, 1994 ^378^ | 69 | 16 | 53 | 76.8% | Mean | 50 | 21 | 79
Kerr, 1994 ^379^ | 85 | 37 | 48 | 56.5% | Mean | 44.8 | 19 | 82
Menon, 1994 ^380^ | 87 | 28 | 59 | 67.8% | Mean | 48.3 | 21 | 76
Pascoe, 1994 ^381^ | 28 | 12 | 16 | 57.1% | Mean | 55 | 32 | 82
Payne, 1994 ^382^ | 16 | 6 | 10 | 62.5% | NR | NR | NR | NR
Roth. 1994 ^383^ | 94 | 35 | 59 | 62.8% | Mean | 52.4 | 25 | 91
Singh, 1994 ^384^ | 357 | 56 | 301 | 84.3% | NR | NR | NR | NR
Skoff, 1994 ^385^ | 1994 | NR | NR | NR | Mean | 56.0 | 24 | 84
Slattery, 1994 ^40^ | 215 | 69 | 146 | 67.9% | Mean | 41 | 17 | 84
Strasberg, 1994 ^386^ | 45 | 16 | 29 | 64.4% | Mean | 50.6 | NR | NR
Wolson, 1994 ^387^ | 30 | 10 | 20 | 66.7% | Mean | 47 | 14 | 71
Biyani, 1993 ^388^ | 56 | 7 | 49 | 87.5% | Mean | 65.4 | 44 | 81
Brown, 1993 ^45^ | 145 | 46 | 99 | 68.3% | Mean | 55 | 25 | 87
Chang, 1993 ^389^ | 30 | 6 | 24 | 80.0% | Mean | 46.2 | 31 | 77
Feinstein, 1993 ^390^ | 55 | 21 | 34 | 61.8% | Mean | 45 | 21 | 79
Jiminez, 1993 ^391^ | 24 | 6 | 18 | 75.0% | Mean | 46 | NR | NR
Leach, 1993 ^392^ | 25 | 11 | 14 | 56.0% | Mean | 43 | 25 | 80
Levine, 1993 ^393^ | 39 | 17 | 22 | 56.4% | Median | 57 | 19 | 88
Nakamichi, 1993 ^394^ | 41 | 8 | 33 | 80.5% | Mean | 54 | 33 | 86
Nathan, 1993 ^395^ | 238 | 80 | 158 | 66.4% | Mean | 41 | 15 | 79
Okutsu, 1993 ^396^ | 27 | 0 | 27 | 100.0% | Mean | 55.9 | 33 | 87
Palmer, 1993 ^397^ | 173 | 73 | 100 | 57.8% | Mean | 44.9 | 20 | 83
Waegeneers, 1993 ^398^ | 76 | 21 | 55 | 72.4% | Mean | 54 | 21 | 82
Nolan, 1992 ^399^ | 22 | 7 | 15 | 68.2% | Mean | 70 | 52 | 86
Pagnanelli, 1992 ^400^ | 228 | 65 | 163 | 71.5% | Mean | 55.2 | NR | NR
Viegas, 1992 ^401^ | 71 | 17 | 54 | 76.1% | Mean | 48 | 23 | 79
Young, 1992 ^402^ | 21 | NR | NR | NR | Mean | 49 | 22 | 72
Yu, 1992 ^403^ | 53 | 22 | 31 | 58.5% | Median | 46 | 20 | 83
Flaschka, 1991 ^404^ | 99 | 18 | 81 | 81.8% | Mean | 56.4 | 22 | 82
Foucher, 1991 ^405^ | 83 | 17 | 66 | 79.5% | Mean | 59.6 | 46 | 77
Hagberg, 1991 ^308^ | 41 | 41 | 0 | 0.0% | Mean | 42.0 | NR | NR
Jakab, 1991 ^406^ | 73 | 25 | 48 | 65.8% | Mean | 52 | 27 | 88
Mackimmon, 1991 ^407^ | 59 | 11 | 48 | 81.4% | Mean | 58.5 | 20 | 91
Resnick, 1991 ^408^ | 65 | 17 | 48 | 73.8% | Mean | 46.2 | 23 | 81
Schuind, 1990 ^409^ | 21 | 2 | 19 | 90.5% | Mean | 49 | 32 | 81
Gellman, 1989 ^410^ | 21 | 2 | 19 | 90.5% | Mean | 51.5 | 30 | 65
Okutsu, 1989 ^411^ | 45 | 15 | 30 | 66.7% | Mean | 51.1 | 29 | 73
Richman, 1989 ^412^ | 12 | 6 | 6 | 50.0% | NR | NR | NR | NR
Seiler, 1989 ^413^ | 10 | 2 | 8 | 80.0% | Mean | 43.6 | 23 | 65
Seradge, 1989 ^414^ | 500 | 218 | 282 | 56.4% | Median | 41 | 19 | 87
Szabo, 1989 ^284^ | 22 | 6 | 16 | 72.7% | Mean | 51 | 24 | 79
Gelberman, 1987 ^415^ | 29 | 17 | 12 | 41.4% | Mean | 55 | 28 | 84
Holmgren, 1987 ^416^ | 48 | 15 | 33 | 68.8% | Mean | 50 | 21 | 80
Gartsman, 1986 ^417^ | 50 | 14 | 36 | 72.0% | NR | NR | NR | NR
Kulick, 1986 ^418^ | 167 | 30 | 137 | 82.0% | Mean | 55.5 | 21 | 92
Leblhuber , 1986 ^419^ | 47 | 10 | 37 | 78.7% | Mean | 50.2 | 19 | 81
Shurr, 1986 ^420^ | 36 | 8 | 28 | 77.8% | Mean | 44.6 | NR | NR
Wadstroem, 1986 ^421^ | 36 | 10 | 26 | 72.2% | Mean | 50 | 32 | 80
Rhodes, 1985 ^422^ | 32 | 21 | 11 | 34.4% | Mean | 63 | 37 | 90
Litchman, 1984 ^423^ | 135 | 28 | 107 | 79.3% | Mean | 54 | 20 | 84
van Rossum, 1980 ^424^ | 37 | 6 | 31 | 83.8% | NR | NR | NR | NR

a Not reported

Figure 16. Distribution of patient ages in studies of surgical treatment for carpal tunnel syndrome

The solid vertical line denotes the mean age for all studies

Very few studies (4%) reported that patients were excluded on the basis of age. Two studies excluded patients under the age of 18, ^302,^ ^303^ and one excluded patients under 16. ^304^ In contrast, one excluded patients over the age of seventy, ^305^ and another excluded patients over 75. ^306^

#### Sex

Patients receiving surgery for carpal tunnel syndrome were more likely to be female than male, as can be seen in Figure 17. One hundred twenty eight studies provided sufficient information to calculate the male-to-female patient ratio. The average study reported that 73% of patients were female, with a standard deviation of 0.2. Patients in two studies were 100% female, and 100% male in one study. Numbers of male and female patients in individual studies are reported in Table 47.

Figure 17. Sex distribution in surgical trials of surgical treatment for carpal tunnel syndrome

No study reported sex to be a criterion for exclusion or inclusion. However, both studies in which men were the majority recruited their patients from male-majority populations. One recruited exclusively from a veteran's hospital population, ^307^ and one recruited patients who worked with heavy, vibrating machinery. ^308^ These patients do not represent typical carpal tunnel syndrome patients.

#### Signs and Symptoms

Signs and symptoms of carpal tunnel syndrome among patients receiving surgery for carpal tunnel syndrome were incompletely reported. This is illustrated by Figure 18, which depicts the percentage of studies reporting the number of patients with an individual sign or symptom. This percentage never exceeds 15% of all studies. Rather than report the number of patients with a given sign or symptom, the common practice among studies of carpal tunnel syndrome is to report that patients had one or more symptoms from a given list. Some studies that included patients with bilateral carpal tunnel syndrome report symptoms per affected hand rather than per patient, reflecting the fact that the same patient can have different symptoms in each hand. The number and percent of patients reporting each sign or symptom is given in Table 48. These data are summarized in Figure 19. “Error” bars in Figure 19 represent the range of percentages reported by individual studies. Because so few (always less than 15%) studies reported this information, the extent to which the available data reflect the signs and symptoms of typical patients receiving surgery cannot be determined.

Table 48. Symptoms of patients treated with surgery for carpal tunnel syndrome

Study | Number of patients (or hands) | Sign or symptom | Number of patients with sign or symptom | Percent of patients (or hands)
McLaughlin, 1996 ^356^ | 102 | Burning | 70 | 68.6%
Mirza, 1995 ^371^ | 56 | Burning | 6 | 10.7%
Finsen, 2001 ^224^ | 79 | Clumsiness | 42 | 53.2%
Atroshi, 1997 ^337^ | 255 Hands | Clumsiness | 155 | 60.8%
Cobb, 1996 ^348^ | 235 | Clumsiness | 81 | 34.5%
Lee, 1996 ^355^ | 275 Hands | Clumsiness | 207 | 75.3%
Lascar, 2000 ^425^ | 71 | Clumsiness | 6 | 8.5%
Porras, 2000 ^313^ | 85 | Durkan/carpal compression test | 50 | 58.8%
Finsen, 2001 ^224^ | 79 | Night symptoms | 56 | 70.9%
Straub, 1999 ^305^ | 100 Hands | Night symptoms | 93 | 93.0%
Aulisa, 1998 ^327^ | 45 | Night symptoms | 44 | 97.8%
Buchhorn, 1998 ^328^ | 50 | Night symptoms | 50 | 100.0%
Atroshi, 1997 ^337^ | 255 Hands | Night symptoms | 237 | 92.9%
Cobb, 1996 ^348^ | 235 | Night symptoms | 71 | 30.2%
Elmaraghy, 1996 ^349^ | 69 | Night symptoms | 56 | 81.2%
Glowacki, 1996 ^352^ | 167 | Night symptoms | 114 | 68.3%
Kluge, 1996 ^354^ | 66 | Night symptoms | 50 | 75.8%
Lee, 1996 ^355^ | 275 Hands | Night symptoms | 226 | 82.2%
McLaughlin, 1996 ^356^ | 102 | Night symptoms | 78 | 76.5%
Nygaard, 1996 ^306^ | 29 | Night symptoms | 20 | 69.0%
Strickland, 1996 ^361^ | 58 | Night symptoms | 58 | 100%
Worseg, 1996 ^44^ | 126 | Night symptoms | 111 | 88.1%
Singh, 1994 ^384^ | 357 | Night symptoms | 104 | 29.1%
Palmer, 1993 ^397^ | 173 | Night symptoms | 148 | 85.5%
Pagnanelli, 1992 ^400^ | 456 Hands | Night symptoms | 424 | 93.0%
Resnick, 1991 ^408^ | 75 Hands | Night symptoms | 66 | 88.0%
Freshwater, 1978 ^426^ | 22 | Night symptoms | 22 | 100%
Provinciali, 2000 ^427^ | 100 | Numbness | 62 | 62.0%
Vartimidis, 2000 ^314^ | 15 | Numbness | 15 | 100.0%
Straub, 1999 ^305^ | 100 Hands | Numbness | 71 | 71.0%
Aulisa, 1998 ^327^ | 45 | Numbness | 7 | 15.6%
Armstrong, 1997 ^336^ | 208 Hands | Numbness | 160 | 76.9%
Atroshi, 1997 ^337^ | 255 Hands | Numbness | 178 | 69.8%
Blair, 1996 ^428^ | 75 | Numbness | 71 | 94.7%
Cobb, 1996 ^348^ | 235 | Numbness | 88 | 37.4%
Elmarghy, 1996 ^349^ | 69 | Numbness | 68 | 98.6%
Kluge, 1996 ^354^ | 66 | Numbness | 35 | 53.0%
Lee, 1996 ^355^ | 275 Hands | Numbness | 240 | 87.3%
McLaughlin, 1996 ^356^ | 102 | Numbness | 71 | 69.6%
Futami, 1995 ^366^ | 10 | Numbness | 10 | 100%
LoVerme, 1995 ^370^ | 42 | Numbness | 28 | 66.7%
Mirza, 1995 ^371^ | 56 | Numbness | 53 | 94.6%
Singh, 1994 ^384^ | 357 | Numbness | 283 | 79.3%
Strasberg, 1994 ^386^ | 45 | Numbness | 45 | 100.0%
Waegeneers, 1993 ^398^ | 100 Hands | Numbness | 28 | 28.0%
Pagnanelli, 1992 ^400^ | 456 Hands | Numbness | 264 | 57.9%
Wadstroem, 1986 ^421^ | 36 | Numbness | 25 | 69.4%
Freshwater, 1978 ^426^ | 11 | Numbness | 11 | 100%
Provinciali, 2000 ^427^ | 100 | Pain | 80 | 80.0%
Vartimidis, 2000 ^314^ | 15 | Pain | 15 | 100%
Armstrong, 1997 ^336^ | 208 Hands | Pain | 185 | 88.9%
Atroshi, 1997 ^337^ | 255 Hands | Pain | 198 | 77.6%
Blair, 1996 ^428^ | 75 | Pain | 67 | 89.3%
Cobb, 1996 ^348^ | 131 | Pain | 80 | 61.1%
Elmaraghy, 1996 ^349^ | 69 | Pain | 59 | 85.5%
Lee, 1996 ^355^ | 275 Hands | Pain | 232 | 84.4%
Mirza, 1995 ^371^ | 56 | Pain | 46 | 82.1%
Strasberg, 1994 ^386^ | 45 | Pain | 39 | 86.7%
Waegeneers. 1993 ^398^ | 100 Hands | Pain | 96 | 96.0%
Nolan, 1992 ^399^ | 22 | Pain | 11 | 50.0%
Richman, 1989 ^412^ | 12 | Pain | 10 | 83.3%
Lowry, 1988 ^429^ | 50 | Pain | 47 | 94.0%
Freshwater, 1978 ^426^ | 22 | Pain | 6 | 27.3%
Nygaard, 1996 ^306^ | 29 | Paresis | 8 | 27.6%
Provinciali, 2000 ^427^ | 100 | Paresthesias | 82 | 82.0%
Straub, 1999 ^305^ | 100 Hands | Paresthesias | 100 | 100%
Buchholm, 1998 ^328^ | 50 | Paresthesias | 49 | 98.0%
Armstrong, 1997 ^336^ | 208 Hands | Paresthesias | 195 | 93.8%
Atroshi, 1997 ^337^ | 255 Hands | Paresthesias | 242 | 94.9%
Cobb, 1996 ^348^ | 235 | Paresthesias | 82 | 34.9%
Elmaraghy, 1996 ^349^ | 69 | Paresthesias | 59 | 85.5%
Kluge, 1996 ^354^ | 66 | Paresthesias | 3 | 4.5%
Lee, 1996 ^355^ | 275 Hands | Paresthesias | 233 | 84.7%
Worseg, 1996 ^44^ | 126 | Paresthesias | 120 | 95.2%
Mirza, 1995 ^371^ | 56 | Paresthesias | 56 | 100%
Palmer, 1993 ^397^ | 173 | Paresthesias | 171 | 98.8%
Waegeneers, 1993 ^398^ | 100 Hands | Paresthesias | 99 | 99.0%
Pagnanelli, 1992 ^400^ | 456 Hands | Paresthesias | 424 | 93.0%
Wadstroem, 1986 ^421^ | 36 | Paresthesias | 32 | 88.9%
Finsen, 2001 ^224^ | 79 | Phalen's sign | 58 | 73.4%
Porras, 2000 ^313^ | 85 | Phalen's sign | 64 | 75.3%
Straub, 1999 ^305^ | 100 Hands | Phalen's sign | 87 | 87.0%
Aulisa, 1998 ^327^ | 45 | Phalen's sign | 32 | 71.1%
Atroshi, 1997 ^337^ | 255 Hands | Phalen's sign | 214 | 83.9%
Serra, 1997 ^344^ | 112 | Phalen's sign | 98 | 87.5%
Glowacki, 1996 ^352^ | 167 | Phalen's sign | 115 | 68.9%
McLaughlin, 1996 ^356^ | 102 | Phalen's sign | 90 | 88.2%
Nygaard, 1996 ^306^ | 29 | Phalen's sign | 22 | 75.9%
Strickland, 1996 ^361^ | 62 | Phalen's sign | 45 | 72.6%
Worseg, 1996 ^44^ | 126 | Phalen's sign | 74 | 58.7%
Bury, 1995 ^364^ | 43 | Phalen's sign | 43 | 100.0%
Futami, 1995 ^366^ | 10 | Phalen's sign | 10 | 100.0%
Lang, 1995 ^109^ | 23 | Phalen's sign | 19 | 82.6%
Erdmann. 1994 ^304^ | 96 | Phalen's sign | 80 | 83.3%
Payne, 1994 ^382^ | 16 | Phalen's sign | 16 | 100.0%
Roth, 1994 ^383^ | 94 | Phalen's sign | 94 | 100.0%
Palmer, 1993 ^397^ | 211 Hands | Phalen's sign | 196 | 92.9%
Waegemeers, 1993 ^398^ | 100 Hands | Phalen's sign | 84 | 84.0%
Resnick, 1991 ^408^ | 75 Hands | Phalen's sign | 69 | 92.0%
Richman, 1989 ^412^ | 12 | Phalen's sign | 10 | 83.3%
Freshwater, 1978 ^426^ | 22 | Phalen's sign | 17 | 77.3%
Armstrong, 1997 ^336^ | 208 Hands | Stiffness | 174 | 83.7%
Lascar, 2000 ^425^ | 71 | Stiffness | 7 | 9.9%
Aulisa, 1998 ^327^ | 45 | Swelling | 27 | 60.0%
Mirza, 1995 ^371^ | 280 | Swelling | 3 | 1.1%
Freshwater, 1978 ^426^ | 22 | Swelling | 0 | 0.0%
Strickland, 1996 ^361^ | 58 | Tenderness | 54 | 93.1%
Pagnanelli, 1992 ^400^ | 456 Hands | Tenderness | 18 | 3.9%
Porras, 2000 ^313^ | 85 | Thenar atrophy | 15 | 17.6%
Aulisa, 1998 ^327^ | 45 | Thenar atrophy | 3 | 6.7%
Buchhorn, 1998 ^328^ | 50 | Thenar atrophy | 11 | 22.0%
Atroshi, 1997 ^337^ | 255 Hands | Thenar atrophy | 36 | 14.1%
Serra, 1997 ^344^ | 112 | Thenar atrophy | 16 | 14.3%
McLaughlin, 1996 ^356^ | 102 | Thenar atrophy | 16 | 15.7%
Nygaard, 1996 ^306^ | 29 | Thenar atrophy | 8 | 27.6%
LoVerme, 1995 ^370^ | 42 | Thenar atrophy | 8 | 19.0%
Singh, 1994 ^384^ | 357 | Thenar atrophy | 110 | 30.8%
Waegeneers, 1993 ^398^ | 100 Hands | Thenar atrophy | 8 | 8.0%
Nolan, 1992 ^399^ | 22 | Thenar atrophy | 11 | 50.0%
Pagnanelli, 1992 ^400^ | 456 Hands | Thenar atrophy | 112 | 24.6%
Foucher, 1991 ^405^ | 83 | Thenar atrophy | 83 | 100.0%
Mackimmon, 1991 ^407^ | 59 | Thenar atrophy | 41 | 69.5%
Resnick, 1991 ^408^ | 75 Hands | Thenar atrophy | 12 | 16.0%
Richman, 1989 ^412^ | 12 | Thenar atrophy | 3 | 25.0%
Gelberman, 1987 ^415^ | 61 | Thenar atrophy | 38 | 62.3%
Kulick, 1986 ^418^ | 167 | Thenar atrophy | 20 | 12.0%
Leblhuber, 1986 ^419^ | 55 Hands | Thenar atrophy | 14 | 25.5%
Wadstroem, 1986 ^421^ | 36 | Thenar atrophy | 17 | 47.2%
Freshwater, 1978 ^426^ | 22 | Thenar atrophy | 2 | 9.1%
Finsen, 2001 ^224^ | 79 | Tinel's sign | 46 | 58.2%
Porras, 2000 ^313^ | 85 | Tinel's sign | 51 | 60.0%
Straub, 1999 ^305^ | 100 Hands | Tinel's sign | 73 | 73.0%
Buchhorn, 1998 ^328^ | 50 | Tinel's sign | 46 | 92.0%
Atroshi, 1997 ^337^ | 255 Hands | Tinel's sign | 176 | 69.0%
Serra, 1997 ^344^ | 112 | Tinel's sign | 5 | 4.5%
Glowacki, 1996 ^352^ | 96 | Tinel's sign | 66 | 68.8%
McLaughlin, 1996 ^356^ | 102 | Tinel's sign | 69 | 67.6%
Nygaard, 1996 ^306^ | 29 | Tinel's sign | 9 | 31.0%
Strickland, 1996 ^361^ | 62 | Tinel's sign | 45 | 72.6%
Worsegm 1996 ^44^ | 126 | Tinel's sign | 100 | 79.4%
Futami, 1995 ^366^ | 10 | Tinel's sign | 10 | 100.0%
Lang, 1995 ^109^ | 23 | Tinel's sign | 7 | 30.4%
Erdmann, 1994 ^304^ | 96 | Tinel's sign | 74 | 77.1%
Roth, 1994 ^383^ | 94 | Tinel's sign | 94 | 100.0%
Palmer, 1993 ^397^ | 211 | Tinel's sign | 181 | 85.8%
Waegeneers, 1993 ^398^ | 100 Hands | Tinel's sign | 77 | 77.0%
Resnick, 1991 ^408^ | 75 Hands | Tinel's sign | 57 | 76.0%
Richman, 1989 ^412^ | 12 | Tinel's sign | 7 | 58.3%
Freshwater, 1978 ^426^ | 22 | Tinel's sign | 15 | 68.2%
Provinciali, 2000 ^427^ | 100 | Weakness | 75 | 75.0%
Straub, 1999 ^305^ | 100 Hands | Weakness | 63 | 63.0%
Aulisa, 1998 ^327^ | 45 | Weakness | 9 | 20.0%
Armstrong, 1997 ^336^ | 208 Hands | Weakness | 156 | 75.0%
Atroshi, 1997 ^337^ | 255 Hands | Weakness | 79 | 31.0%
Cobb, 1996 ^348^ | 235 | Weakness | 97 | 41.3%
Elmaraghy, 1996 ^349^ | 69 | Weakness | 35 | 50.7%
Kluge, 1996 ^354^ | 66 | Weakness | 5 | 7.6%
Lee, 1996 ^355^ | 275 Hands | Weakness | 220 | 80.0%
McLaughlin, 1996 ^356^ | 102 | Weakness | 17 | 16.7%
Singh, 1994 ^384^ | 357 | Weakness | 120 | 33.6%
Strasberg, 1994 ^386^ | 45 | Weakness | 42 | 93.3%
Palmer, 1993 ^397^ | 173 | Weakness | 152 | 87.9%
Waegeneers, 1993 ^398^ | 100 Hands | Weakness | 43 | 43.0%
Pagnanelli, 1992 ^400^ | 456 Hands | Weakness | 210 | 46.1%
Richman, 1989 ^412^ | 12 | Weakness | 7 | 58.3%
Kulick, 1986 ^418^ | 167 | Weakness | 20 | 12.0%
Freshwater, 1978 ^426^ | 22 | Weakness | 17 | 77.3%

Figure 18. Reporting of symptoms in studies of surgical treatment for carpal tunnel syndrome

Figure 19. Symptoms of patients with carpal tunnel syndrome

Eight studies excluded patients with thenar atrophy, while four included only patients with thenar atrophy. Seven studies required their patients to have Tinel's sign, Phalen's sign or both, and an indeterminate number included tests for these signs as part of their diagnostic procedure. The exact number of such studies can not be determined because some describe their patients as having “signs and symptoms of carpal tunnel syndrome” without providing further description or enumeration. The extent to which use of these criteria influence the overall description of the typical patient with carpal tunnel syndrome cannot be determined, because it is unclear whether or to what extent criteria for surgery may differ from criteria for study inclusion.

The duration of symptoms prior to surgery was reported by 35 studies (24% of total). These are listed in Table 49. The mean of means among these 35 studies was 29.9 months, with a standard deviation of 16.5 and a range of zero to 480 months. The means and ranges of individual studies are depicted in Figure 20. The vertical line in Figure 20 represents the mean of means.

Table 49. Duration of symptoms among patients treated with surgery for carpal tunnel syndrome

Trial | N | Is duration of condition reported as Mean or Median? | Duration of condition before treatment (months) | Shortest period of duration before treatment (months) | Longest period of duration before treatment (months)
Porras, 2000 ^313^ | 85 | Mean | 39 | 6 | 300
Straub, 1999 ^305^ | 67 | Median | 24 | 3 | 300
Buchhorn, 1998 ^328^ | 50 | Mean | 43 | Not reported | Not reported
Lee, 1998 ^331^ | 525 | Mean | 40.1 | 2 | 480
Atroshi, 1997 ^337^ | 204 | Mean | 24 | 1 | 240
Karlsson, 1997 ^48^ | 74 | Median | 6 | 1 | 60
Leinberry, 1997 ^342^ | 44 | Mean | 31.8 | 3 | 168
Wheatly, 1997 ^307^ | 126 | Mean | 90 | 10 | 120
Gibbs, 1996 ^351^ | 46 | Mean | 57.0 | 1 | 360
Glowacki, 1996 ^352^ | 96 | Mean | 17.8 | Not reported | Not reported
Lee, 1996 ^430^ | 525 | Mean | 40.1 | 2 | 480
Nagle, 1996 ^357^ | 506 | Mean | 31 | 1 | 420
Wintman, 1996 ^362^ | 50 | Mean | 28 | 3 | 173
Worseg, 1996 ^44^ | 126 | Mean | 23.4 | Not reported | Not reported
Mirza, 1995 ^371^ | 236 | Mean | 23 | Not reported | Not reported
Nancollas, 1995 ^372^ | 93 | Mean | 26.5 | 1 | 300
Sennwald, 1995 ^373^ | 47 | Mean | 9.2 | Not reported | Not reported
Erdmann, 1994 ^304^ | 96 | Mean | 24.1 | Not reported | Not reported
Roth, 1994 ^383^ | 94 | Mean | 46.8 | 4 | 300
Brown, 1993 ^45^ | 145 | Mean | 25 | 2 | 120
Clarke, 1993 ^431^ | 37 | Mean | 37 | 2 | 300
Levine, 1993 ^393^ | 39 | Median | 18 | 3 | 58
Palmer, 1993 ^397^ | 173 | Mean | 35.6 | Not reported | Not reported
Pagnanelli, 1992 ^400^ | 228 | Mean | 45.6 | 3 | 360
Yu, 1992 ^403^ | 53 | Median | 6 | 0 | 72
Flaschka, 1991 ^404^ | 99 | Mean | 24 | 1 | 180
Hagberg, 1991 ^308^ | 41 | Mean | 43.6 | Not reported | Not reported
Jakab, 1991 ^406^ | 73 | Mean | 48 | 2 | 516
Resnick, 1991 ^408^ | 65 | Mean | 16.8 | 1 | 204
Richman, 1989 ^412^ | 12 | Mean | 28 | 5 | 72
Szabo, 1989 ^284^ | 22 | Mean | 29 | 7 | 120
Kulick, 1986 ^418^ | 167 | Mean | 30 | 0 | 348
Shurr, 1986 ^420^ | 36 | Mean | 12 | Not reported | Not reported
Freshwater, 1978 ^426^ | 11 | Mean | 12 | 3 | 120

Figure 20. Duration of symptoms in studies of surgery for carpal tunnel syndrome

Solid vertical line denotes the mean duration of symptoms

#### Neuroelectrical characteristics

Of the 145 studies that reported on surgery for carpal tunnel syndrome and met inclusion criteria, 83 stated that electrodiagnostic tests were part of their inclusion criteria, but did not provide any further information as to the nature of these tests. An additional 26 did not provide any diagnostic information. Eleven studies did not include electrodiagnostic studies in their description of their diagnostic and inclusion criteria, and two specifically stated that electrodiagnostics were not part of their diagnostic protocol. Electrodiagnostic criteria in the remaining studies are reported in Table 50. Because the majority of studies excluded some patients based on their neuroelectrical characteristics without providing information as to which patients were excluded or why, the impact of these exclusion criteria on the characteristics of the patients described in these studies cannot be determined.

Table 50. Electrodiagnostic criteria among patients treated with surgery for carpal tunnel syndrome

Trial | Electrodiagnostic criteria
Hasegawa, 1999 ^320^ | Patients with grade I (mild) symptoms were accepted for surgery if they also had distal motor latency >7.1ms or distal motor latency >5.2ms and 3 months of failed conservative treatment
Hirooka, 1999 ^321^ | Patients with grade 1 (mild) symptoms received surgery only if they had a distal motor latency of at least 7.0 ms.
Aulisa, 1998 ^327^ | Patients fit into one of the following categories:
| Mild: Sensory conduction velocity, first digit to wrist <42m/s, third digit to wrist <44m/s
| Moderate: Sensory conduction velocity as in mild, plus median distal motor latency >4ms
| Severe: Absent sensory or motor median response.
Jacobsen, 1996 ^353^ | Patients fit into one of the following categories:
| Slight CTS: >3 sensory responses delayed 2–4 standard deviations (SD).
| Intermediate CTS: All sensory responses delayed >3SD+decreased sensory amplitudes.
| Pronounced CTS: Several or all sensory responses lacking and rest are delayed >4SD with low amplitudes, motor delay >4SD with low amplitude or no motor response.
| The “normal” values to which these diagnostics were compared, and the size of a standard deviation were not reported.
Cook, 1995 ^432^ | Distal motor latency >4.5 ms and/or sensory antidromic latency >3.5 ms.
Lang, 1995 ^109^ | Either distal motor latency >4.5 ms or orthodromic sensory conduction velocity palm-to-wrist <45 m/s
Foulkes, 1994 ^376^ | Distal sensory latency of at least 3.6ms or motor latency of 4.4ms were considered supportive of diagnosis.
Pascoe, 1994 ^381^ | Difference between median and palmar sensory latency of more than 0.4ms
Brown, 1993 ^45^ | Electrophysiological confirmation was established when distal motor latency was 4.5 ms or there was a difference of 1 ms or more between the affected and unaffected hand or sensory latency was more than 3.5 ms or there was a difference of more than 0.5 ms between the affected and unaffected hand.
Nakamichi, 1993 ^394^ | Distal motor latency >4.2ms or sensory nerve conduction velocity <45ms
Hagberg, 1991 ^308^ | A positive phalen test or distal motor latency of at least 4.5
Schuind, 1990 ^409^ | Distal motor latency >4ms or distal sensory latency >3.5ms
Richman, 1989 ^412^ | Distal motor latency >4.5ms or distal sensory latency >3.5ms
Szabo, 1989 ^284^ | Distal motor latency >4.5 ms or distal sensory latency >3.5 ms.
Lowry, 1998 ^429^ | Distal antidromic sensory latency >5ms or unobtainable at 13cm.
Holmgren-Larssen, 1985 ^433^ | Sensory nerve conduction velocity <50 ms and distal latency >4.5 ms.
Rhoades, 1985 ^422^ | Fibrillations in the abductor pollicis or opponens pollicis muscles detectable by EMG.
Van Rossum, 1980 ^424^ | Distal motor latency >4.5 ms
Freshwater, 1978 ^426^ | No patients had normal motor latency (4.5ms or less), but this was not stated to have been an inclusion criterion.

#### Employment Characteristics

Of the 145 studies describing patients receiving surgery for carpal tunnel syndrome that met inclusion criteria, only 20 (14%) reported data on the types of employment of their patients. The occupations of patients receiving surgery for carpal tunnel syndrome and the percent of patients in each study possessing that occupation are given in Table 51.

Table 51. Reported occupations of patients receiving surgery for carpal tunnel syndrome

Study | Occupation | Number of Patients | Number of patients with occupation | Percent of patients with occupation
Mirza, 1995 ^371^ | Blue Collar | 56 | 9 | 16.1%
Olney, 1999 ^323^ | Clerical | 211 | 89 | 42.2%
Weber, 1997 ^347^ | Clerical | 74 | 29 | 39.2%
Cobb, 1996 ^348^ | Clerical | 235 | 38 | 16.2%
Mirza, 1995 ^371^ | Clerical | 56 | 6 | 10.7%
Kelly, 1994 ^378^ | Clerical | 69 | 10 | 14.5%
Palmer, 1993 ^397^ | Clerical | 173 | 35 | 20.2%
Pagnanelli, 1992 ^400^ | Clerical | 228 | 71 | 31.1%
Dumontier, 1995 ^365^ | Clerical, unoccupied or retired | 96 | 47 | 49.0%
Wintman, 1996 ^362^ | Disabled | 50 | 1 | 2.0%
Worseg, 1996 ^44^ | Employee | 126 | 19 | 15.1%
Buchhorn, 1998 ^328^ | Employee- average work | 50 | 21 | 42.0%
Olney, 1999 ^323^ | Factory | 211 | 30 | 14.2%
Nagle, 1996 ^357^ | Heavy work | 506 | 27 | 5.3%
Yu, 1992 ^403^ | Heavy work | 53 | 23 | 43.4%
Porras, 2000 ^313^ | High manual activity | 85 | 14 | 16.5%
Kelly, 1994 ^378^ | High manual activity | 69 | 7 | 10.1%
Cobb, 1996 ^348^ | Homemaker | 235 | 19 | 8.1%
Wintman, 1996 ^362^ | Homemaker | 50 | 12 | 24.0%
Worseg, 1996 ^44^ | Homemaker | 126 | 8 | 6.3%
Mirza, 1995 ^371^ | Homemaker | 56 | 5 | 8.9%
Chow, 1994 ^42^ | Homemaker | 815 | 63 | 7.7%
Kelly, 1994 ^378^ | Homemaker | 69 | 14 | 20.3%
Yu, 1992 ^403^ | Homemaker | 53 | 3 | 5.7%
Palmer, 1993 ^397^ | Industrial | 173 | 90 | 52.0%
Katz, 1997 ^302^ | Laborer/machine operator | 135 | 25 | 18.5%
Nagle, 1996 ^357^ | Light work | 506 | 72 | 14.2%
Buchhorn, 1998 ^328^ | Light work | 50 | 16 | 32.0%
Yu, 1992 ^403^ | Light work | 53 | 8 | 15.1%
Wintman, 1996 ^362^ | Light labor with repetitive tasks or clerical work | 50 | 15 | 30.0%
Nagle, 1996 ^357^ | Light-repetitive work | 506 | 42 | 8.3%
Porras, 2000 ^313^ | Low manual activity | 85 | 37 | 43.5%
Kelly, 1994 ^378^ | Low manual activity | 69 | 21 | 30.4%
Katz, 1997 ^302^ | Management | 135 | 22 | 16.3%
Weber, 1997 ^347^ | Management | 74 | 14 | 18.9%
Lindau, 1999 ^322^ | Manual Worker | 140 | 29 | 20.7%
Buchhorn, 1998 ^328^ | Manual Worker | 50 | 8 | 16.0%
Weber, 1997 ^347^ | Manual Worker | 74 | 25 | 33.8%
Cobb, 1996 ^348^ | Manual Worker | 235 | 60 | 25.5%
Dumontier, 1995 ^365^ | Manual Worker | 96 | 45 | 46.9%
Erhard, 1999 ^318^ | Manual worker- heavy lifting | 124 | 12 | 9.7%
Olney, 1999 ^323^ | Manual worker- heavy lifting | 211 | 40 | 19.0%
Buchhorn, 1998 ^328^ | Manual worker- heavy lifting | 50 | 5 | 10.0%
Wintman, 1996 ^362^ | Manual worker- heavy lifting | 50 | 5 | 10.0%
Chow, 1994 ^42^ | Manual worker- heavy lifting | 815 | 322 | 39.5%
Pagnanelli, 1992 ^400^ | Manual worker- heavy lifting | 228 | 60 | 26.3%
Erhard, 1999 ^318^ | Manual worker- light lifting | 124 | 12 | 9.7%
Chow, 1994 ^42^ | Manual worker- light lifting | 815 | 215 | 26.4%
Pagnanelli, 1992 ^400^ | Manual worker- light lifting | 228 | 97 | 42.5%
Olney, 1999 ^323^ | Meat packing | 211 | 15 | 7.1%
Palmer, 1993 ^397^ | Medical | 173 | 7 | 4.0%
Porras, 2000 ^313^ | Medium manual activity | 85 | 35 | 41.2%
Nagle, 1996 ^357^ | Medium work | 506 | 46 | 9.1%
Yu, 1992 ^403^ | Medium strenuous work | 53 | 13 | 24.5%
Lindau, 1999 ^322^ | Nonmanual worker | 140 | 41 | 29.3%
Chow, 1994 ^42^ | Other | 815 | 68 | 8.3%
Katz, 1997 ^302^ | Other | 135 | 81 | 60.0%
Cobb, 1996 ^348^ | Other | 235 | 14 | 6.0%
Worseg, 1996 ^44^ | Other | 126 | 3 | 2.4%
Kelly, 1994 ^378^ | Other | 69 | 1 | 1.4%
Palmer, 1993 ^397^ | Other | 173 | 15 | 8.7%
Wintman, 1996 ^362^ | Professional | 50 | 6 | 12.0%
Mirza, 1995 ^371^ | Professional | 56 | 11 | 19.6%
Palmer, 1993 ^397^ | Professional | 173 | 16 | 9.2%
Palmer, 1993 ^397^ | Education | 173 | 8 | 4.6%
Lindau, 1999 ^322^ | Retired | 140 | 21 | 15.0%
Weber, 1997 ^347^ | Retired | 74 | 6 | 8.1%
Wintman, 1996 ^362^ | Retired | 50 | 7 | 14.0%
Worseg, 1996 ^44^ | Retired | 126 | 60 | 47.6%
Hallock, 1995 ^368^ | Retired | 100 | 15 | 15.0%
Mirza, 1995 ^371^ | Retired | 56 | 5 | 8.9%
Strasberg, 1994 ^386^ | Retired | 45 | 4 | 8.9%
Yu, 1992 ^403^ | Retired | 53 | 6 | 11.3%
Palmer, 1993 ^397^ | Retired or Homemaker | 173 | 40 | 23.1%
Olney, 1999 ^323^ | Retired or light employment | 211 | 57 | 27.0%
Chow, 1994 ^42^ | Retired or unemployed | 815 | 147 | 18.0%
Kelly, 1994 ^378^ | Retired or unemployed | 69 | 16 | 23.2%
Erhard, 1999 ^318^ | Sedentary | 124 | 18 | 14.5%
Nagle, 1996 ^357^ | Sedentary | 506 | 69 | 13.6%
Strasberg, 1994 ^386^ | Student | 45 | 2 | 4.4%
Wintman, 1996 ^362^ | Unemployed | 50 | 4 | 8.0%
Worseg, 1996 ^44^ | Unemployed | 126 | 19 | 15.1%
Strasberg, 1994 ^386^ | Unemployed | 45 | 28 | 62.2%
Worseg, 1996 ^44^ | Worker | 126 | 17 | 13.5%

No consistent categorization was used in these studies. The distinction between groups may be unclear. For example, the study by Worseg, et al. distinguished between “Workers” and “Employees”. ^44^ The difference between the two groups was not described. As a result, it is difficult to make generalizations about typical characteristics of patients with carpal tunnel syndrome. The number of studies reporting each occupational category is given in Figure 21, and the percent of patients with each occupation among studies reporting that occupation is given in Figure 22.

Figure 21. Number of studies reporting occupations of patients receiving surgery for carpal tunnel syndrome

Figure 22. Percent of patients with reported occupations receiving surgery for carpal tunnel syndrome

#### Comorbidities

The number of patients with comorbidities is incompletely reported in published studies of surgical treatment for carpal tunnel syndrome, as can be seen in Figure 23. The number of studies reporting the presence of a given comorbidity never exceeds 20% of the available studies. Further confounding analysis is the fact that many studies excluded patients with comorbidities, and not all studies reported a precise list of excluded comorbidities. Because comorbidities are underreported and because patients with them are frequently excluded, it is difficult to draw conclusions about the presence of comorbidities among patients receiving surgery for carpal tunnel syndrome or how these comorbidities affect whether a patient is a candidate for surgery.

Figure 23. Percent of studies reporting and excluding comorbidities

#### Conclusions

Patients who have undergone surgery for carpal tunnel syndrome are predominantly middle aged and female. Because of underreporting, no firm evidence-based conclusions can be drawn regarding the signs, symptoms, neuroelectrical characteristics and comorbidities of these patients.

### Question #3: What are the relative benefits and harms of various surgical and nonsurgical interventions for persons with carpal tunnel syndrome?

#### Evidence Base

In addressing this question, we consider only data from controlled trials. Controls are needed to account for changes that can occur over time that are not due to treatment. These changes could be caused by rest, changes in patient activity, or other factors. CTS is often a progressive disease, but remissions occur, even in untreated patients. ^434^

As described in the methodology section of this evidence report, we only evaluate patient-oriented outcomes. These are the outcomes of primary interest to the patient. They include pain, functional activity, quality of life, return to work, and global measures of treatment outcome such as patient satisfaction and overall relief of symptoms. Functional activity includes the measures of functional ability as well as measures of activities of daily living (ADL), including time to return to ADL. Outcomes that are not directly experienced by the patient, such as change in nerve conduction velocity, are not assessed. Surrogate outcomes, such as two-point discrimination or grip strength, are important only to the extent that they correlate with patient-oriented outcomes. Because no measures of correlation between changes in surrogate outcomes and changes in patient-oriented outcomes have been published, we did not analyze surrogate outcomes.

To determine the benefits and harms of various treatments for carpal tunnel syndrome, we retrieved 58 controlled trials. Seventeen of these were excluded for reasons stated in Table 52, leaving 41 studies to be assessed. Four (10%) of these trials were multicenter, 27 (66%) were randomized, and 34 (83%) were prospective. Sixteen (39%) of the studies were double or single blinded and 16 (39%) either used intent-to treat analysis to account for patients lost to followup or had no reported loss to followup.

Table 52. Excluded trials

Study | Reason for Exclusion
Todnem, 2000 ^435^ | Retrospective comparison of operated and nonoperated patients. Groups were significantly different in several electrodiagnostic parameters prior to surgery.
Atherton, 1999 ^436^ | Did not report any patient characteristics or patient-oriented outcomes.
Brüser, 1999 ^437^ | A single study comparing two very similar treatments.
Davis, 1998 ^438^ | Utilized a combination of treatments, rendering it impossible to determine the effect of a single treatment.
Ebenbichler, 1998 ^439^ | There were significant differences between groups at baseline. Although patients were described as having bilateral carpal tunnel syndrome, five patients in the treated group and seven in the placebo group had no wrist complaints.
Garfinkel, 1998 ^440^ | The treatment received by the control group was not standardized and was not described.
Netscher, 1998 ^47^ | Did not report any patient-oriented outcomes.
Rozmaryn, 1998 ^32^ | Patients received an assortment of nonstandardized treatments in addition to the experimental treatment.
Braithwaite, 1997 ^441^ | Compares minor variations in surgical technique. No patient-oriented outcome measures were reported other than perioperative pain. No patient characteristics were reported.
Jones, 1997 ^442^ | A single study comparing two very similar treatments.
Monge, 1995 ^443^ | No patient-oriented outcomes were reported for the controls; only for treated patients. Reported no information on the source of control data or the comparability of controls and treated patients.
Bande, 1994 ^444^ | Groups were not comparable. Patients with comorbidities (e.g. synovitis, diabetes, rheumatoid arthritis) were all placed in the open release group. There was no indication as to how many such patients were included.
Biyani, 1993 ^388^ | A single study comparing two very similar treatments.
Nathan, 1993 ^395^ | A single study comparing two very similar treatments.
Spooner, 1993 ^445^ | Did not report any patient-oriented outcomes.
Groves, 1989 ^446^ | Compared outcomes at two separate clinics. There was no indication that the patient populations treated by the two clinics were comparable. This study had no internal validity.
Wolaniuk, 1983 ^447^ | Did not report any patient-oriented outcomes.
Ellis, 1979 ^447^ | Describes a double-blind crossover study of a single patient.

No published trials compared surgery to no treatment or placebo, making it difficult to determine, in strict scientific terms, whether surgery benefits patients. Although absence of evidence is not evidence of absence of efficacy, the lack of trials that incorporate these controls complicates evaluation of the effectiveness of surgery. However, differences between the effects of various surgical treatments can in some cases be assessed. The existence of differences in effect size between treatments may itself constitute evidence that some treatments are, to some extent, effective.

The 41 studies are divided below into groups of studies comparing similar treatments. Internal validity and generalizability are discussed separately for each group of studies. The former term describes the potential for bias in the studies. Randomization and blinding help to eliminate potential sources of bias, providing stronger evidence that any observed differences between groups are the result of differences in treatment. Patient attrition and threats to statistical validity may also affect internal validity.

Generalizability refers to the extent to which the results of a trial may be applied to the overall population of candidates for treatment. If the patients described in a trial are unusual or specialized, the generalizability of the trial is limited. The results of a study that includes only elderly patients, for example, may not be generalizable to a population of younger patients.

### What are the relative benefits and harms of open and endoscopic carpal tunnel release for persons with carpal tunnel syndrome?

Seventeen published controlled trials addressing this question met inclusion criteria. These trials described a total of 2,598 patients.

#### Internal validity

Six of these trials were randomized; two of which were blinded. One RCT was incompletely randomized, as some patients with bilateral CTS requested endoscopic release for their second procedure after undergoing endoscopic release in the initial hand. ^46^ Blinding of patients and posttreatment examiners in trials of surgical treatments is often impractical, if not impossible. In the two blinded studies, only raters and not patients were blinded. In addition to the prospective trials, there were four retrospective comparisons between patient groups. Patient attrition ranged from zero to more than 80%. No studies with patient attrition performed intent-to-treat analyses performed. In at least two reports, investigators had a financial stake in the results of their studies. Neither of these studies were blinded. Study characteristics affecting internal validity are listed in Table 53.

Table 53. Internal validity of studies comparing open and endoscopic carpal tunnel release

Study | Number of patients | Percent of patients with bilateral procedures | Number of centers | Funded by a for-profit stakeholder? | Study design | Blinding | Total Patient Attrition (all patient groups) | Intent to treat analysis?
Concannon, 2000 ^449^ | 191 | NR^a^ | Single | Not reported | Retro | No | 0 | Yes
Chen, 1999 ^317^ | 948 | At least 34.8%^b^ | Single | Not reported | Retro | No | 24 | No
Hasegawa, 1999 ^320^ | 82 | 2.4% | Single | Not reported | Retro | No | 0 | Yes
Povlsen, 1997 ^450^ | 120 | 0% | Multiple (<5) | Not reported | CT | No | 4 | No
Gibbs, 1996 ^351^ | 46 | 23.9% | Single | Not reported | Retro | No | 3 | No
Jacobsen, 1996 ^353^ | 29 | 10.3% | Single | Not reported | RCT | Rater | 0 | Yes
Worseg, 1996 ^44^ | 126 | 0% | Single | Not reported | CT | No | 0 | Yes
Dumontier, 1995 ^365^ | 103 | 0% | Single | Not reported | RCT | No | 83 | No
Futami, 1995 ^366^ | 10 | 100% | Single | Not reported | CT | No | 0 | Yes
Hallock, 1995 ^368^ | 96 | 37% | Single | Not reported | CT | No | 0 | No^c^
Sennwald, 1995 ^373^ | 47 | 0% | Single | Not reported | RCT | No | 0 | Yes
Erdmann, 1994 ^304^ | 71 | 47.9% | Single | Not reported | RCT | No | 0 | Yes
Kerr, 1994 ^379^ | 157 | At least 17.4%^b^ | Single | Not reported | CT | No | 13 | No
Brown, 1993 ^45^ | 151 | 13.2% | Multiple (<5) | No | RCT | Rater | 22 | No
McDonough, 1993 ^448^ | 88 | 23.5% | Single | Yes | Retro | No | 7 | No
Palmer, 1993 ^397^ | 211 | 29.4% | Single | No | CT | No | 0 | Yes
Agee, 1992 ^46^ | 122 | 20.5% | Multiple (>5) | Yes | RCT | No | NR | No

a This report describes the results of 191 procedures. The number of patients was not reported.

b The number of bilateral procedures among those patients who underwent open procedures was not reported.

c Four patients whose endoscopic procedures were, for various technical reasons, converted to open procedures, are included in the Open group.

Randomization is necessary to ensure that patients in the different groups of a study are as similar as possible. One particularly important feature of randomization is that important but unknown patient characteristics are equally distributed among groups. Finally, randomization reduces the chance of bias being introduced as a result of the personal preferences or expectations of the patient or the physician. Similarly, lack of blinding can introduce bias.

Patient attrition may skew the results of a study in the direction of seeming more favorable toward a treatment, because patients who are dissatisfied with their treatment may be less likely to return for followup examinations. Wherever possible, we have recalculated data from studies with patient attrition. In doing so, we apply the conservative assumption that treatment failed for all patients lost to followup. If statistical significance is obtained under this assumption, one can be more confident that the effect of patient attrition is not severe enough to overturn a statistically significant result.

An additional threat to internal validity common in studies of carpal tunnel syndrome is the presence of bilateral procedures. Carpal tunnel syndrome often occurs in both hands, leading some researchers to report outcome data per procedure rather than per patient. Using procedures rather than patients as the unit of analysis violates statistical assumptions of independence between and within groups and compromises the statistical validity of the study if more than one procedure is performed on a single patient. Four studies included patients with bilateral procedures, but did not violate assumptions of independence between groups because all patients had the same procedure in each hand. ^351,^ ^368,^ ^379,^ ^448^ An additional study implied, but did not explicitly state, that no patient underwent both open and endoscopic release. ^317^ Two studies included patients with bilateral procedures, but analyzed their data using the Wilcoxon rank-sum test, which does not assume independence between groups. ^304,^ ^353^ The study by Sennwald also analyzed some data by this method, but did not specify which comparisons utilized this test. ^373^ In all cases, assumptions of independence within groups were violated.

Violating the assumption of independence within groups leads to underestimation of standard errors and spurious statistically significant results (Type I errors). Four studies had no bilateral procedures and therefore did not violate the independence assumption. Among the remaining studies, the extent of the violation depends on the percentage of patients with bilateral procedures. The more bilateral patients, the more severe the violation. To guage the severity of this violation, we note the percentage of patients on whom bilateral procedures were performed for each study. Four of the studies (Chen, Gibbs, Futami and Erdman) had a fairly high percentage of patients who received bilateral procedures (>30%), and are particularly prone to statistical biases in their results.

The power of a statistical test to detect differences between groups is also an internal validity issue. However, statistical power is different for each outcome. Therefore, power is addressed as part of the discussion of each outcome, below.

#### Generalizability

The average age of patients in the 13 studies that provided this information is 49.0 years. Mean ages ranged from 44 to 56 years, while individual ages ranged from 19 to 90 years. The majority of patients (56% to 100%) were female. This is consistent with available epidemiological data on carpal tunnel syndrome, ^22,^ ^25^ as well as with data on surgical patients compiled in answer to question 2 of this evidence report. This indicates that the results of these studies are broadly generalizable to the overall carpal tunnel population. These and other patient characteristics are listed in Table 54.

Table 54. Generalizability of studies comparing open and endoscopic carpal tunnel release

Study | Number of patients | Mean age and range | % Female | Mean Duration (Months) of condition and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Excluded severe disease? | Excluded mild disease?
Concannon, 2000 ^449^ | 191 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | No | No
Chen, 1999 ^317^ | 948 | 48 (21–79) | 78.5 | NR | 0.6 | 2.4 | 0 | NR | 0 | 0.3 | 0 | Yes | No
Hasegawa, 1999 ^320^ | 82 | 54.1 | 100 | NR | NR | NR | NR | NR | NR | NR | NR | No | Yes
Povlsen, 1997 ^450^ | 120 | NR | NR | NR | NR | NR | NR | NR | 0 | NR | NR | No | No
Gibbs, 1996 ^351^ | 46 | 56.2 (31–86) | 89.1 | 57.0 (1–360) | 0 | 0 | NR | 0 | NR | NR | NR | No | No
Jacobsen, 1996 ^353^ | 29 | (24–59) | NR | NR | NR | NR | NR | NR | NR | NR | NR | Yes | Yes
Worseg, 1996 ^44^ | 126 | 56.0 (35–90) | 69.8 | 23.4 | NR | 0 | NR | NR | 0 | NR | NR | Yes | Yes
Dumontier, 1995 ^365^ | 103 | 52.3 | 82.5 | NR | NR | NR | NR | NR | NR | NR | NR | No | No
Futami, 1995 ^366^ | 10 | 53 (39–61) | 90.0 | NR | NR | NR | NR | NR | NR | NR | NR | No | Yes
Hallock, 1995 ^368^ | 96 | 44.2 | 77.1 | NR | NR | NR | 0 | NR | NR | NR | NR | No | No
Sennwald, 1995 ^373^ | 47 | 52.5 | 80.9 | 9.2 | 0 | 0 | NR | NR | NR | NR | NR | No | Yes
Erdmann, 1994 ^304^ | 71 | 53.4 | 98.6 | 27.3 | 2.8 | 28.2 | 0 | NR | NR | NR | NR | Yes | No
Kerr, 1994 ^379^ | 157 | 44.8 (19–82) | 56.5 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Brown, 1993 ^45^ | 151 | 55 (25–87) | 65.6 | 25 (2–120) | NR | 0 | NR | NR | 0 | 0 | NR | No | No
McDonough, 1993 ^448^ | 88 | 46.0 (21–79) | 62.5 | 35.6 | NR | NR | NR | NR | NR | NR | NR | No | Yes
Palmer, 1993 ^397^ | 211 | 44.9 (20–83) | 65.4 | 35.7 | 1.4 | 0 | NR | NR | NR | NR | NR | No | Yes
Agee, 1992 ^46^ | 122 | NR | NR | NR | 0 | 0 | 0 | NR | 0 | NR | 0 | Yes | Yes

The presence of various comorbidities associated with CTS is incompletely reported in these studies. Some studies excluded patients with some comorbidities, indicated in Table 54 by a zero under that comorbidity. This somewhat limits the generalizability of these studies, as comorbidities are not exclusion criteria for surgery. An exception is rheumatoid arthritis, which can sometimes interfere with endoscopic carpal tunnel release. Five studies excluded patients with severe CTS. While this exclusion may limit our ability to generalize to other severe CTS patients, it may render the results more generalizable to average patients. Eight studies excluded patients with mild CTS. The effect of this exclusion on generalizability is unknown, because we do not know whether the criteria applied were unique to these studies or if they are normally applied to surgical candidates in general clinical practice.

Patient employment characteristics (Table 55) are incompletely reported in these studies. Therefore, the extent to which the employment characteristics of these patients may be generalized to the overall CTS patient population cannot be determined from the information available.

Table 55. Patient employment characteristics in studies comparing open and endoscopic carpal tunnel release

Study | Number of patients | % Patients employed | % Patients receiving workers' compensation | % Patients retired | % Patients Homemakers | Reported occupations
Concannon, 2000 ^449^ | 191 | Not reported | 44.0 | Not reported | Not reported | Not reported
Chen, 1999 ^317^ | 948 | Not reported | Not reported | Not reported | Not reported | Not reported
Hasegawa, 1999 ^320^ | 82 | Not reported | Not reported | Not reported | Not reported | Not reported
Povlsen, 1997 ^450^ | 120 | Not reported | Not reported | Not reported | Not reported | Not reported
Gibbs, 1996 ^351^ | 46 | 84.8 | 15.2 | Not reported | Not reported | 16 Retired, homemaker or unemployed
Jacobsen, 1996 ^353^ | 29 | 100 | 0 | 0 | 0 | Not reported
Worseg, 1996 ^44^ | 126 | 31.0 | 87.3 | 47.6 | 6.3 | 19 Employee
| | | | | | 17 Worker
| | | | | | 60 Retired
| | | | | | 19 Unemployed
| | | | | | 8 Homemaker
| | | | | | 3 Other
Dumontier, 1995 ^365^ | 103 | 89.3 | Not reported | Not reported | Not reported | 45 Manual workers
| | | | | | 47 Clerical, unoccupied or retired
Futami, 1995 ^366^ | 10 | Not reported | Not reported | Not reported | Not reported | Not reported
Hallock, 1995 ^368^ | 96 | Not reported | 54.2 | 15.6 | Not reported | Not reported
Sennwald, 1995 ^373^ | 47 | Not reported | Not reported | Not reported | Not reported | Not reported
Erdmann, 1994 ^304^ | 71 | Not reported | Not reported | Not reported | Not reported | Not reported
Kerr, 1994 ^379^ | 157 | Not reported | Not reported | Not reported | Not reported | Not reported
Brown, 1993 ^45^ | 151 | 53.6 | 4.6 | Not reported | Not reported | 41 Professional, management or business
| | | | | | 29 Clerical or technical support
| | | | | | 11 Manual labor
McDonough, 1993 ^448^ | 88 | Not reported | 27.3 | Not reported | Not reported | Not reported
Palmer, 1993 ^397^ | 211 | 73.9 | 57.8 | Not reported | Not reported | 8 Education
| | | | | | 90 Industrial
| | | | | | 7 Medical
| | | | | | 16 Professional
| | | | | | 35 Clerical
| | | | | | 40 Retired or Homemaker
| | | | | | 15 Other
Agee, 1992 ^46^ | 122 | Not reported | Not reported | Not reported | Not reported | Not reported

#### Results

##### Global outcome

A global outcome is any score that attempts to encompass the overall success or failure of the treatment. It may be a numerical rating of overall symptom relief or patient satisfaction, a categorical rating such as excellent, good, fair or poor, or a dichotomous rating such as the answer to the question “Would you undergo this procedure again?.” Such outcomes were reported in seven controlled trials, two of which were randomized and two of which were retrospective. The results are presented in Table 56.

Table 56. Global outcome in patients treated with open or endoscopic carpal tunnel release

Study | Number of Patients | Global Outcome | Statistical Significance of Difference Between Groups
Hasegawa et al., 1999 ^320^ | | Global outcome rating at 12 Months | Not significantly different by chi square test conducted by ECRI, p=0.57
| 40 Open | 28 Excellent
| | 8 Good
| | 3 Fair
| | 1 Poor
| 42 Endoscopic | 29 Excellent
| | 13 Good
| | 1 Fair
| | 1 Poor
Gibbs et al., 1996 ^351^ | | Mean change in symptom severity score 3–33 Months | Not significantly different by t-test conducted by ECRI, p = 0.86
| 43 Open | -12.5±5.6
| 14 Endoscopic (Hands) | -12.2±5.3
Worseg et al., 1996 ^44^ | | Mean symptom rating, verbal scale | Scores were not significantly different between groups at any time point (p >0.05, Wilcoxon rank sum test)
| 62 Open | This outcome was reported using a 3-dimensional graph, making it difficult to estimate values.
| 64 Endoscopic
Futami 1995 ^366^ | | Weeks until relief of symptoms | Not reported
| 10 Open | 2.5 Weeks
| 10 Endoscopic (Hands of 10 patients) | 2.4 Weeks
Hallock 1995 ^368^ | | Number of hands with complete relief of symptoms (Time not reported) | Not significantly different by chi square test conducted by ECRI, p=0.46
| 71 Open | 63
| 66 Endoscopic (Hands) | 61
Erdmann, 1994 ^304^ | | Days until relief of symptoms | Not significantly different by Mann-Whitney test. The p value determining significance was not reported.
| 52 Open | 1.75 Days
| 53 Endoscopic | 1.1 Days
Brown, 1993 ^45^ | | Mean patient satisfaction rating, 0–100 | Not significantly different by t-test conducted by ECRI, p = 0.15
| 82 Open | 84 Days: 84±26
| 78 Endoscopic (Hands) | 84 Days: 89±18

Five studies reported sufficient data for an effect size to be calculated. This number was sufficient for us to perform a meta-analysis. In this analysis, a positive effect size indicates that the study favors endoscopic release over open release, and a negative effect size indicates the converse. The results of the meta-analysis of the five studies are summarized in Table 57.

Table 57. Results of meta-analysis of the effect of open or endoscopic treatment on global outcome

Author | Year | N | Effect Size | 95% CI | p-value | Standardized Residual | Outlier by Std Resid?
Hasegawa ^320^ | 1999 | 82 | 0.362 | -0.07–0.80 | 0.105 | 0.83 | No
Gibbs ^351^ | 1996 | 57 | -0.054 | -0.66–0.55 | 0.862 | -0.84 | No
Worseg ^44^ | 1996 | 126 | 0.12^a^ | -0.23–0.41. | 0.502 | -0.49 | No
Hallock ^368^ | 1995 | 137 | 0.240 | -0.41–0.89 | 0.466 | 0.15 | No
Brown ^45^ | 1993 | 160 | 0.222 | -0.09–0.53 | 0.163 | -0.22 | No
Summary Effect Size | | | | 95% CI | p-value | Q Statistic | p of Q
Fixed Effects Model | 0.19 | | | 0.01–0.38 | 0.041 | 1.44 | 0.838

a Estimated from published data by assuming that the p-value of the Wilcoxon test was 0.5

The combined fixed effect size from the meta-analysis is modest (d = 0.19), but statistically significant. The individual and combined effect sizes are illustrated in Figure 24. The magnitude of the effect size is further illustrated in Figure 25 which demonstrates that there is a high degree (85.7%) of overlap in the global outcome scores of the two treatment groups.

Figure 24. Results of meta-analysis of effect of treatment on global outcome

Figure 25. Degree of overlap between outcomes

Four of the five studies were neither randomized nor blinded. Two were retrospective. Although there is a trend in favor of endoscopic release, the suboptimal quality of the studies incorporated into this analysis means that these results are suggestive rather than definitive. In addition, the difference is not robust. The incorporation of a single study showing no difference between groups into the meta-analysis would render the overall effect size nonsignificant. On the other hand, the two studies reporting global outcomes that were not incorporated into the meta-analysis all found slightly more favorable results in the endoscopic groups. Addition of these studies would likely reduce the impact of a “no-effect” study on the summary effect size. Therefore, our analysis suggests that although there may be a difference in the global outcome of patients who receive open surgery and those who receive endoscopic surgery, any such difference is small, and its exact value is uncertain.

##### Return to work

Return to work was reported in 12 controlled trials, six of which were randomized and two of which were retrospective. Only two studies reported sufficient data for an effect size to be calculated. Results from such a small fraction (16.7%) of the available studies do not constitute a sufficient sampling of the available information. For this reason, we did not perform a meta-analysis on these data. The results of the trials are given in Table 58. Data are reported as means plus or minus standard deviations (when available) unless otherwise stated.

Table 58. Time to return to work in patients treated with open or endoscopic surgery

Study | n (units) | Time Until Return to Work | Statistical Significance of Difference Between Groups
Gibbs, 1996 ^351^ | | Time at which 50% of patients had returned to work | Groups were not significantly different by log rank test , p = 0.63
| Open | 4 Days (Range 1->1003)^a^
| Endoscopic | 14 Days Range (1–91)
| Total N = 28 Group n not reported
Jacobsen, 1996 ^353^ | 16 Open | Open 18.94±10.25 Days (Range 0–42) | Groups not significantly different, p>0.05, Fisher Exact test
| 16 Endoscopic (Hands) | Endoscopic 17.06±9.11 Days (Range 0–31)
Dumontier, 1995 ^365^ | | Percent of patients returning to work within: | Groups were not significantly different at any time by chi square test.
| Open | 2 Weeks: 29%; 1 Month: 70%; 3 Months: 89%^b^ | At 1 month, p = 0.13. p-values were not reported for the other two time points.
| Endoscopic | 2 Weeks: 30%; 1 Month 45%; 3 Months 70%
| Numbers of patients not reported
Futami, 1995 ^366^ | Open 3 | 7 Weeks | Not reported
| Endoscopic 3 | 6 Weeks
Hallock, 1995 ^368^ | Open 39 | 46.3±36.9 Days | Groups were not significantly different, p = 0.373. The test used was not reported.
| Endoscopic 25 | 39.8±19.3 Days
Sennwald, 1995 ^373^ | 22 Open | 41.95±13.18 Days^d^ | Groups were significantly different by t-test calculated by ECRI, p = 0.000001
| 25 Endoscopic | 24.13±7.69 Days
| (Patients)
Erdmann, 1994 ^304^ | 23 Open (Patients) | 39 Days Open | Groups were significantly different, p <0.005 unpaired Mann-Whitney U test
| 27 Open (Hands)^e^
| 23 Endoscopic (Patients) | 14 Days Endoscopic
| 28 Endoscopic (Hands)
Kerr, 1994 ^379^ | 72 Open | Patients treated endoscopically returned to work 10.6 days sooner than those treated openly. | Groups were significantly different by paired t-test (p = 0.0015)
| 72 Endoscopic
Brown, 1993 ^45^ | 85 Open | Median 28 Days Open^a^ | Groups were statistically significant, p <0.05, log-rank test
| 84 Endoscopic(Hands) | Median 14 Days Endoscopic
McDonough, 1993 ^448^ | 28 Open | 50.4 Days (Range 11–103) | Not reported
| 27 Endoscopic (Patients) | 28.5 Days (Range 4–67)
Palmer, 1993 ^397^ | Open | 44.1±37.3 | Open was significantly different from the other two groups by t-test, p <0.05
| Endoscopic-Agee method | 20.7±12.8
| Endoscopic- Chow method | 27.9±16.9
| n not reported
Agee, 1992 ^46^ | 30 Open | Median 46.5 Days^a^ | Statistically significant difference between groups, p <0.01, survival analysis version of the Wilcoxon test
| 49 Endoscopic (Patients) | Median 25 Days

a Calculated by Kaplan-Meier survival analysis

b Percentages estimated from a published chart. They cannot be converted to numbers of patients because it is unclear whether they are percentages of all patients or of patients employed prior to surgery.

c Some patients in each group did not return to work. The numbers reported therefore do not constitute an accurate representation of time to return to work.

d Estimated by ECRI from a published chart.

e Unclear whether data is reported per patient or per treated hand. Therefore, we did not calculate an effect size for this study.

Table 59 summarizes return to work data by indicating whether patients treated with endoscopic or open carpal tunnel release had a faster reported return to work, and whether that difference was statistically significant. As can be seen in Table 59 and Figure 26, only one trial found that patients receiving open release returned to work faster than those receiving endoscopic release, and that difference was not statistically significant. Examination of the study designs, patient and employment characteristics (Table 53, Table 54, and Table 55) does not suggest a reason why this study found a trend opposite that observed in the other studies. In contrast, 11 trials found that endoscopic release led to faster return to work. This difference was statistically significant in six trials.

Table 59. Summary of effect of treatment type on return to work

Study | Which Procedure Yielded Faster Return to Work? | Was the Difference Statistically Significant? | Power (Minimum percent difference detectable)^a^ | Effect Size (95% Confidence Interval)^a^
Gibbs, 1996 ^351^ | Open | No | Not calculable | Not calculable
Jacobsen, 1996 ^353^ | Endoscopic | No | 25% | 0.19 (-0.51 – 0.88)
Dumontier, 1995 ^365^ | Endoscopic at 2 weeks | No | Not calculable | Not calculable
| Open at 1 month and 3 months
Futami, 1995 ^366^ | Endoscopic | No | Not calculable | Not calculable
Hallock, 1995 ^368^ | Endoscopic | No | 32.6% | Not calculable
Sennwald, 1995 ^373^ | Endoscopic | Yes | 15.1% | 1.65 (0.99 –2.31)
Erdmann, 1994 ^304^ | Endoscopic | Yes | Not calculable | Not calculable
Kerr, 1994 ^379^ | Endoscopic | Yes | Not calculable | Not calculable
Brown, 1993 ^45^ | Endoscopic | Yes | Not calculable | Not calculable
McDonough, 1993 ^448^ | Endoscopic | Not reported | Not calculable | Not calculable
Palmer, 1993 ^397^ | Endoscopic | Yes | Not calculable | Not calculable
Agee, 1992 ^46^ | Endoscopic | Yes | Not calculable | Not calculable

a Calculated by ECRI

Figure 26. Summary of effect of treatment on return to work

An open bar denotes an RCT, a striped bar a CT, and a filled bar a retrospective trial.

NR indicates that the authors did not report the number of patients for whom this outcome was recorded.

Table 59 also indicates the power of each study to detect differences between groups. In all three of the studies for which power could be calculated, there was insufficient power to detect small (less than 10%) differences between groups. Two of the studies that did not detect a significant effect lacked the power to detect moderate (less than 25%) differences. The addition of more patients to these studies might have increased the statistical power to detect differences between groups enough so that the detected differences would have become statistically significant.

Effect sizes (Hedges' d) could be calculated for only two studies. These are given in Table 59 and Figure 27.

Figure 27. Calculable effect sizes for effect of treatment type on return to work

Because no meta-analysis could be conducted on the available studies, we base our conclusions on a semi-quantitative analysis. Data from 11 of 12 trials suggest that patients undergoing endoscopic surgery show a tendency toward faster return to work than patients who have open surgery. However, because no quantitative analysis was possible, no reliable conclusions can be drawn as to how much faster they may return.

##### Time to return to activities of daily living

This outcome was reported in five controlled studies, three of which were randomized. Data from these studies are presented in Table 60. Unless otherwise stated, data are presented as mean times to return to activities of daily living (ADLs). Only one study reported sufficient data for a valid effect size to be calculated. Therefore, no meta-analysis could be performed. Instead, Table 61 summarizes trends in the data available from the controlled trials.

Table 60. Time to return to activities of daily living in patients treated with open or endoscopic surgery

Study | Number of Patients | Time to Return to Activities of Daily Living | Statistical Significance of Difference Between Groups
Gibbs, 1996 ^351^ | | Time until 50% of patients had returned to ADL^a^ | Groups not significantly different by log-rank test
| 43 Open | 21 Days (Range 1->911)
| 14 Endoscopic | 21 Days (Range 7->425)
Futami, 1995 ^366^ | 10 Open^b^ | 41 Days (Range 28–51) | Groups significantly different by t-test, p <0.01
| 10 Endoscopic | 12 Days (Range 4–18)
Erdmann, 1994 ^304^ | 23 Open (Patients) | | Groups significantly different (p <0.005, Mann-Whitney test)
| 27 Open (Hands) | 39 Days
| 23 Endoscopic (Patients)^c^ | 14 Days
| 28 Endoscopic (Hands)
Brown, 1993 ^45^ | 21 Days, N = 149 Hands Group n not reported^d^ | Number of patients (hands) with no impairment of ADL
| Open | 3 (5) | Groups were not significantly different by Kaplan-Meier survivorship analysis
| Endoscopic | 8 (8)
| 42 Days, N = 147 Hands
| Open | (12) | Groups were not significantly different by Kaplan-Meier survivorship analysis
| Endoscopic | (14)
| 84 Days, N = 160 Hands
| 82 Open | 28 (29) | Groups were notsignificantly different by Kaplan-Meier survivorship analysis. However, they were significantly different by chi square test conducted by ECRI, p = 0.019
| 78 Endoscopic | 39 (42)
Agee, 1992 ^46^ | 63 Open | Median 13 Days, estimated by Kaplan-Meier | Groups not significantly different according to a survival analysis version of the Wilcoxon test.
| 81 Endoscopic
| (Hands) | Median 9 Days, estimated by Kaplan-Meier

a Calculated by Kaplan-Meier survival analysis

b 20 hands in 10 patients

c Unclear whether means were calculated as per patient or per hand.

d Sum of group ns calculated by ECRI from published data did not match reported total Ns.

Table 61. Summary of effect of treatment (open or endoscopic) on time to return to ADLs

Study | Which Procedure Yielded Faster Return to Daily Activities? | Was the Difference Statistically Significant? | Power (Minimum percent difference detectable^a^ | Effect Size (95% Confidence Interval)^a^
Gibbs, 1996 ^351^ | Both groups were equal | No | Not calculable | Not calculable
Futami, 1995 ^366^ | Endoscopic | Yes | Not calculable | Not calculable
Erdmann, 1994 ^304^ | Endoscopic | Yes | Not calculable | Not calculable
Brown, 1993 ^45^ | Endoscopic | 21 days: | 21 days: Not calculable | 21 Days: Not calculable
| | 42 days: No | 42 days: Not calculable | 42 days: Not calculable
| | 84 days: Yes | 84 days: 18.3% | 84 days: 0.42 (0.065–0.77)
Agee, 1992 ^46^ | Endoscopic | No | Not calculable | Not calculable

a : Calculated by ECRI

Four trials found a faster return to daily activities in the group treated with endoscopic release. Three of these found the difference to be statistically significant. A chi square test conducted by ECRI found that in the study by Brown, the difference between groups at 84 days was statistically significant despite the fact that it was reported as insignificant. ^45^ The effect size calculated from the same data was significantly different from zero. The study that did not favor endoscopic release was the only retrospective study. It found that both groups returned to daily activities in the same amount of time. This is illustrated in Figure 28.

Figure 28. Summary of effect of treatment on returns to ADLs

Open bars represent RCTs, striped bars CTs, and dark bars retrospective trials.

The amount of time required for return to ADLs varies among studies. Futami reported that all patients treated with endoscopic release returned to daily activities “with full use of the hand” within 18 days, while Brown reported that only a fraction of endoscopic patients (11%) returned to ADLs within 21 days. Gibbs reported that half of the patients in the endoscopic group returned to work in 21 days, while Agee reported a median of 9 days. The reasons for these differences are unknown.

As was the case for return to work, the data show a trend toward faster return to daily activities for patients treated with endoscopic carpal tunnel release than with open surgery. However, because one cannot perform a meta-analysis on the data, the magnitude of the difference cannot be precisely determined.

##### Pain

In this question, we address pain as a symptom of carpal tunnel syndrome, distinct from postsurgical pain, scar tenderness or pillar pain. This outcome was reported in four controlled trials, two of which were randomized. Again, because effect sizes could be calculated for only two studies, we did not perform a meta-analysis. Therefore, we examine the data for trends. Data describing the relative effect of open and endoscopic treatment on pain are presented in Table 62.

Table 62. Symptomatic pain in patients treated with open or endoscopic carpal tunnel release

Study | Number of Hands | Pain | Statistical Significance of Difference Between Groups
Gibbs, 1996 ^351^ | | Pain rating | Groups not significantly different before or after treatment by t-test, p = 0.78 and 0.21 respectively.
| 43 Open | Preop:: 3.3±1.0
| | 18.9 Months: 1.2 ±0.52
| 14 Endoscopic | Preop: 3.3±0.87
| | 16 Months: 1.5±0.96
Erdmann, 1994 ^304^ | | Mean VAS, 0–10 Scale^a^ | Groups significantly different at 1 week only (Mann-Whitney test, p <0.05)
| 52 Open | Preop: 5.6; 1 Week: 3.9
| | 1 Year: 0.95
| 53 Endoscopic | Preop, 5.7; 1 Week: 2.4
| | 1 Year: 0.1
Palmer, 1993 ^397^ | | Percent of patients^b^ reporting nocturnal pain | Groups not significantly different at any time point by chi square test, p >0.05
| 42 Patients, 49 Hands Open | Preop: 88.7%
| | 2 Weeks: 23.3%
| | 6 Months: 25.0%
| 70 Patients, 90 Hands Endoscopic (Agee method) | Preop: 80.0%
| | 2 Weeks: 16.7%
| | 6 Months: 12.5%
| 62 Patients, 72 Hands Endoscopic (Chow method) | Preop: 89.8%
| | 2 Weeks: 21.7%
| | 6 Months: 28.9%
Agee, 1992 ^46^ | | Percent of patients^b^ with symptomatic pain | Not reported
| 65 Open | Preop: 89; 1 Week: 59
| | 26 Weeks: 27
| 82 Endoscopic | Preop: 85; 1 Week: 43
| | 26 Weeks: 25

a : Estimated by ECRI from a published chart

b : The report states that outcomes are reported as percent of patients. However, as some patients had a different procedure in each hand, it is likely that the outcome is actually percent of hands. Thus, the true n is unclear.

To address this outcome, we perform three separate analyses. First, we assess differences between patient groups prior to treatment. If there are differences in pain prior to treatment, this may influence whether there are differences after treatment. In randomized controlled trials, the process of randomization is used to eliminate this concern.

The second analysis we performed is a comparison of short-term results. This is because the rationale behind endoscopic treatment is that it is less invasive, leading to faster recovery. Whether this also means faster relief of symptoms has not been determined. For this analysis, we are defining short-term results to be those obtained one month or less after surgery. Finally, in our third analysis, we evaluated long-term (longer than one month) results.

Data relevant to these three analyses are summarized in Table 63. There were no statistically significant differences between groups before treatment. All three studies reporting pain at early (1 month or less) times after treatment found less pain in the endoscopic groups, with one RCT finding a statistically significant difference. At later time points, all but the one retrospective study found less pain in the endoscopic groups. However, none of the differences were statistically significant.

Table 63. Summary of effect of treatment (open or endoscopic) on pain

Study | Which Procedure Had Less Pain? | Was the Difference Stastically Significant? | Power (Minimum percent difference detectable 80% of the time)^a^ | Effect Size (95% Confidence Interval)^a^
Gibbs, 1996 ^351^ | Preop: No difference | Preop: No | Preop: 17.5% | Preop: 0.0 (-0.60–0.60)
| Early: Not reported | Early: Not reported | Early: Not reported | Early: Not reported
| Late: Open | Late: No | Late: 40.0% | Late: -0.45 (-1.06–0.15)
Erdmann, 1994 ^304^ | Preop: Open | Preop: No | Not calculable | Preop: Not calculable
| Early: Endoscopic | Early: Yes | | Early: 0.39 (0.00–0.77)^b^
| Late: Endpscopic | Late: No | | Late: Not calculable
Palmer, 1993 ^397^ | Preop: Endoscopic | Preop: No | Not calculable | Not calculable
| Early: Endoscopic | Early: No
| Late: Endoscopic | Late: No
Agee, 1992 ^46^ | Preop: Endoscopic | Preop: Not reported | Not calculable | Not calculable
| Early: Endoscopic | Early: Not reported
| Late: Endoscopic | Late: Not reported

a : Calculated by ECRI

b : Calculated by ECRI based on the conservative assumption that p = 0.049)

The statistically nonsignificant results may indicate that these studies were too small (i.e., underpowered to detect differences. Only Gibbs provided sufficient data for power to be calculable. After treatment, the study only had the power to detect large (>40%) differences between groups. If the true difference between groups is less than this, the study is uninformative. However, the two calculable post-treatment effect sizes are not large (See Figure 31), suggesting that low power is not exclusively responsible for these non-significant results.

Figure 31. Calculable effect sizes for pain

An open bar indicates an RCT and a dark bar a retrospective study.

The data show a trend toward greater pain relief for patients treated with endoscopic carpal tunnel release at both early and later times after surgery (See Figure 29, Figure 30, and Figure 31). However, there is some circumstantial evidence to suggest that the effect is not large at both early and late followup times. At early followup times, only one of three studies found a statistically significant effect, despite all three studies being of reasonable size (>100 patients). At later followup times, no studies found a statistically significant effect. Similarly, the only calculable effect size from a prospective trial (an RCT) was not large. Thus, while the precise effect size cannot be calculated, evidence suggests it is small.

Figure 29. Summary of the effect of treatment on pain at early time points

An open bar indicates an RCT, striped bar a CT. The study by Gibbs does not appear beacause it did not report early time ponts.

Figure 30. Summary of the effect of treatment on pain at late time points

An open bar indicates an RCT, striped bar a CT, and dark bar a retrospective study.

##### Function

Function refers to the ability of the patient to perform various tasks and activities with their affected limb(s). It is measured using any of a number of tests.

Only one nonrandomized controlled trial, that by Worseg, reported a measure of function. This outcome is described in Table 64 and summarized in Table 65. Worseg's global function was the mean of the difficulty ratings (scale of 1–5) of eight individual activities (writing, buttoning clothes, holding a book, gripping a telephone, opening jars, household chores, carrying a grocery bag, and bathing and dressing).

Table 64. Function in patients treated with open or endoscopic carpal tunnel release

Study | Number of Patients | Function | Statistical Significance of Difference Between Groups
Worseg et al., 1996 ^44^ | | Mean of function scores^a^ | Between group differences were significant at 1 Week only (p <0.05, Wilcoxon rank sum test).
| Open 62 | Preop: 3.14 ; 1 Week: 3.33; 24 Weeks: 1.29
| Endoscopic 64 | Preop: 3.16 ; 1 Week: 2.29; 24 Weeks: 1.20

a : Lower score indicates superior function

Table 65. Summary of the effect of treatment on function

Study | Which Procedure Had Superior Function at Followup? | Was the Difference Stastically Significant? | Power (Minimum percent difference detectable)^a^ | Effect Size (95% Confidence Interval)^a^
Worseg, 1996 ^44^ | Endoscopic | At 1 week only | Not calculable | Preop: 0.12 (-0.23 – 0.47)^b^
| | | | 1 Week: 0.35 (0.00 – 0.70)
| | | | 24 Weeks: 0.12 (-0.23 – 0.47)

a : Calculated by ECRI

b : Calculated by ECRI based on the conservative assumption that p = 0.49 at one week and p = 0.50 at the other time points.

The endoscopic group experienced superior function one week after surgery, but there were no statistically significant differences in the long term. This is consistent with the idea that the less invasive treatment leads to more rapid recovery. Because, however, function was examined in only one study (which was not randomized), it is difficult to draw firm evidence-based conclusions about the relative effects of open and endoscopic surgery on function.

##### Quality of Life

No studies reported this outcome.

##### Harms

Analysis of differences in incidence of adverse events between endoscopic and open surgery is hindered by incomplete reporting. Figure 32 shows the percent of studies reporting each adverse effect. Only one complication, transient sensory disturbance, was reported by more than half of the studies. It is not possible to determine whether in the remaining studies complications did not occur or were not reported in the remaining studies. Six studies did not report any complications. A complete listing of reported complications may be found in Evidence Table 12.

Figure 32. Studies reporting minor complications

The following analysis is based on the assumption that major, severe complications are more likely to be reported than minor ones. This analysis is therefore limited to reports of the accidental severing of a nerve, tendon or blood vessel. This type of injury requires repair and is presumably serious enough to warrant mention. Incidence of accidental laceration is reported in Table 66.

Table 66. Blood vessel, nerve and tendon lacerations during open and endoscopic carpal tunnel release

Study | Procedures | Endoscopic Lacerations | Open Lacerations
Chen, 1999 ^317^ | Open 64 | 1 Motor nerve | 0
| Endo 1214
Povlsen, 1997 ^450^ | Open 50 | 0 | 0
| Endo 50
Jacobsen, 1996 ^353^ | Open 16 | 0 | 0
| Endo 16
Worseg, 1996 ^44^ | Open 62 | 1 Transection of the superficial palmar arch | 0
| Endo 64
Dumontier, 1995 ^365^ | Open 40 | 1 Ulnar artery injury | 0
| Endo 56
Sennwald, 1995 ^373^ | Open 22 | 0 | 0
| Endo 25
Erdmann, 1994 ^304^ | Open 52 | 0 | 1 Palmar cutaneous nerve
| Endo 53
Brown, 1993 ^45^ | Open 85 | 1 Superficial palmar arch | 0
| Endo 84
McDonough, 1993 ^448^ | Open 50 | 1 Digital tendon | 0
| Endo 50
Palmer, 1993 ^397^ | Open 49 | 0 | 0
| Endo (Agee) 90
| Endo (Chow) 72
Total | | 1774 Procedures | 490 Procedures
| | 5 Lacerations | 1 Laceration

Incomplete transection of the carpal ligament is a technical failure that can lead to recurring or continuing symptoms of carpal tunnel syndrome and may require reoperation. The number of incomplete transections reported in studies comparing open and endoscopic carpal tunnel release are presented in Table 67.

Table 67. Incomplete transections of the carpal ligament

Study | Procedures | Endoscopic Incomplete Transections | Open Incomplete Transections
Concannon et al., 2000 ^449^ | Open 103 | 5 | 0
| Endo 88
Sennwald and Benedetti, 1995 ^373^ | Open 22 | 0 | 0
| Endo 25
Erdmann, 1994 ^304^ | Open 52 | 1 | 0
| Endo 53
McDonough et al., 1993 ^448^ | Open 50 | 1 | 0
| Endo 50
Palmer et al., 1993 ^397^ | Open 49 | 1 Agee | 0
| Endo (Agee) 90
| Endo (Chow) 72 | 1 Chow
Total | | 378 Procedures | 276 Procedures
| | 9 Incomplete transections | 0 Incomplete transections

Ten studies reporting on 490 open releases reported one nerve injury. Among 1,774 Endoscopic releases, there were five nerve, tendon or blood vessel lacerations. The difference between groups was not statistically significant by a chi square test (p=0.767) conducted by ECRI.

An incomplete transection of the carpal ligament is unlikely when performing open release, because the ligament is fully visualized. Since the rate of incomplete release is essentially zero when performing open release, the rate for endoscopic release (9 incomplete transections in 378 procedures) is higher. Endoscopic release may therefore have a higher reoperation rate than open release.

#### Conclusions

Endoscopic release allows faster return to work and to activities of daily living. In addition, it leads to superior global outcome and reduced pain. However, the effects on pain and global outcome may be small. Presently available data do not allow one to reach firm evidence-based conclusions about the relative effect of open and endoscopic surgery on function. Because of incomplete transection of the transverse carpal ligament, endoscopic release has a higher rate of reoperation. Although there is insufficient data to draw firm conclusions, endoscopic release may also have a higher complication rate.

### What are the relative benefits and harms of open carpal tunnel release with and without neurolysis for persons with carpal tunnel syndrome?

Eight published studies comparing open carpal tunnel release with carpal tunnel release combined with neurolysis met the inclusion criteria. These studies enrolled a total of 494 cases. One of these, the study by Gelberman et al., ^415^ compared their data to an earlier case series, that of Rhodes et al. ^451^ Therefore, the study of Rhodes et al. may be considered an historical control for the study by Gelberman et al. Six of the remaining trials are prospective, randomized controlled trials. Four are single- or double-blinded. One is double-blinded, but not randomized. ^426^ Long-term outcomes for one study are reported in a separate publication. ^416,^ ^433^

#### Internal validity

Factors affecting internal validity of controlled trials of neurolysis are described in Table 68. Three studies had no attrition, and the remaining five had attrition ranging from 6% to 50%. None of the studies with patient attrition reported results on an intent-to-treat basis. Wherever possible, we compensated for attrition using the conservative assumption that treatment had failed for all patients not accounted for. All but one of the studies violated statistical assumptions of independence by including patients with bilateral CTS. ^433^ The impact of this violation in terms of the number of times an erroneous conclusion of statistical significance was drawn is unknown, but it does affect one's confidence in the results of our analyses.

Table 68. Internal validity of studies comparing open carpal tunnel release with and without neurolysis

Study | Number of patients | Percent of patients with bilateral procedures | Number of centers | Funded by a for-profit stakeholder? | Study design | Blinding | Total Patient Attrition (all patient groups) | Intent to treat analysis?
Leinberry, 1997 ^342^ | 44 | 13.6% | Single | No | RCT | Rater | 0 | Yes
Blair, 1996 ^428^ | 117 | 36.0% | Single | No | RCT | Rater | 42 | No
Foulkes, 1994 ^376^ | 46 | 8.7% | Single | No | RCT | Rater | 23 | No
Mackinnon, 1991 ^407^ | 59 | 6.8% | Single | No | RCT | Double | 20 | No
Lowry, 1988 ^429^ | 50 | 22.0% | Single | Not reported | RCT | Double | 3 | No
Gelberman, 1987 ^415^ | 61 | 13.1% | Multiple (<5) | No | Retro | No | 0 | Yes
Holmgren-Larsson, 1985 ^433^ | 48 | 0.0% | Single | Not reported | RCT | No | 7 | No
Holmgren, 1987 ^416^
Freshwater, 1978 ^426^ | 22 | 18.2% | Single | Not reported | CT | Double | 0 | Yes

#### Generalizability

The average age of the patients in the five studies reporting mean ages was 55.7, with a range of 20–100. This is consistent with the reported epidemiology of CTS as well as with the ages observed under question 2 of this evidence report. Two of the studies included somewhat fewer than 50% female patients, but this percentage is not so low that it would greatly limit the generalizability of the data reported. These and other patient characteristics are listed in Table 69.

Table 69. Generalizability of studies comparing open carpal tunnel release with and without neurolysis

Study | Number of patients | Mean age and range | % Female | Mean Duration (Months) of condition and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Excluded severe disease? | Excluded mild disease?
Leinberry, 1997 ^342^ | 44 | 65 (38–100) | 59.1 | 31.8 (1–360) | 6.8 | NR | NR | NR | NR | NR | NR | No | Yes
Blair, 1996 ^428^ | 86 | 49 (23–82) | 72.1 | NR | NR | NR | NR | 0 | 0 | NR | NR | No | Yes
Foulkes, 1994 ^376^ | 46 | NR | 37.0 | NR | NR | NR | NR | NR | NR | 0 | NR | No | Yes
Mackinnon, 1991 ^407^ | 79 | 58.5 (20–91) | 60.8 | NR | 0 | NR | 0 | 0 | 0 | NR | NR | No | Yes
Lowry, 1988 ^429^ | 50 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | No | Yes
Gelberman, 1987 ^415^ | 61 | 59.2 (28–90) | 37.7 | NR | NR | NR | NR | NR | NR | NR | NR | No | Yes
Holmgren, 1987 ^416^ | 48 | 50 (21–80) | 68.8 | NR | NR | NR | NR | NR | NR | NR | NR | No | Yes
Holmgren-Larsson, 1985 ^433^ | 48 | 50 (21–80) | 68.8 | NR | NR | NR | NR | NR | NR | NR | NR | No | Yes
Freshwater, 1978 ^426^ | 22 | NR; (32–74) | NR | 12 (3–120) | NR | 0 | NR | NR | NR | NR | NR | NR | NR

Except in cases where patients with comorbidities were excluded (noted in Table 69 by a zero under the comorbidity), patient comorbidities were not described in these studies. Similarly, employment characteristics are not described, as can be seen in Table 70. No conclusions about the generalizability of these results to the general CTS population is possible.

Table 70. Patient employment characteristics in studies comparing open carpal tunnel release with and without neurolysis

Study | Number of patients | % Patients employed | % Patients receiving workers' compensation | % Patients retired | % Patients Homemakers | Reported occupations
Leinberry, 1997 ^342^ | 44 | Not reported | Not reported | Not reported | Not reported | Not reported
Blair, 1996 ^428^ | 86 | Not reported | Not reported | Not reported | Not reported | Not reported
Foulkes, 1994 ^376^ | 46 | Not reported | Not reported | Not reported | Not reported | Not reported
Mackinnon, 1991 ^407^ | 79 | Not reported | 12.7 | Not reported | Not reported | Not reported
Lowry, 1988 ^429^ | 50 | Not reported | Not reported | Not reported | Not reported | Not reported
Gelberman, 1987 ^415^ | 61 | Not reported | Not reported | Not reported | Not reported | Not reported
Holmgren, 1987 ^416^ | 48 | Not reported | Not reported | Not reported | Not reported | Not reported
Holmgren-Larsson, 1985 ^433^ | 48 | Not reported | Not reported | Not reported | Not reported | Not reported
Freshwater, 1978 ^426^ | 22 | Not reported | Not reported | Not reported | Not reported | Not reported

One study (Leinberry, et al.) included only patients with severe disease. ^342^ It may therefore be inappropriate to combine the study by Leinberry with the remaining studies, and this study may not be generalizable to the CTS population at large. All but one of the studies excluded patients with mild disease. ^426^ The extent to which this criterion differs from criteria for surgical candidates in ordinary clinical practice is not known. Therefore, the impact of this exclusion on generalizability is not known.

#### Results

##### Global outcome

This outcome was reported by all eight controlled trials, six of which were randomized and one of which was retrospective. Of the six randomized trials, five were blinded. Data from these trials are summarized in Table 71. The study by Blair employed three different measures of global outcome. ^428^ We did not consider patient perceptions about symptom relief because these authors presented their results in a manner that is difficult to quantify. For example, they reported that some patients experience permanent partial relief while others experienced temporary total relief. It is difficult to determine which of these outcomes the patients considered superior.

Table 71. Effect of neurolysis on global outcome

Study | Number of Patients | Global Outcome | Statistical Significance of Difference Between Groups
Leinberry, 1997 ^342^ | | Number of hands with no symptoms | Not significantly different, test not reported
| Open Release 25 | 12 Months: 15
| Release and Neurolysis 25 | 12 Months: 14
| (Hands)
Blair, 1996 ^428^ | | Patients stating they would have surgery again | Not reported
| Open Release 27 | 26
| Release and Neurolysis 48 | 46
| (Hands) | Patient perceptions about relief of symptoms
| Open Release 27 | Permanent total: 13
| | Permanent partial: 12
| | Temporary total: 2
| Release and Neurolysis 48 | Permanent total: 31
| | Permanent partial:15
| | Temporary total: 2
| | Patient satisfaction
| Open Release 27 | Happy/very happy: 19
| | Satisfied, with reservations: 8
| | Disappointed/very disappointed: 0
| Release and Neurolysis 48 | Happy/very happy: 35
| | Satisfied, with reservations: 9
| | Disappointed/very disappointed: 4
Foulkes, 1994 ^376^ | | Improvement at 29 Months | Not reported
| Open Release 8 | Normal 2
| | Improved 6
| | Unimproved 0
| Release and Neurolysis 15 | Normal 5
| | Improved 9
| | Unimproved 1
| Recalculated: | Recalculated: | Not reported
| Open Release 10^a^ | Normal 2
| | Improved 6
| | Unimproved 2
| Release and Neurolysis 26 | Normal 5
| | Improved 9
| | Unimproved 12
| (Hands)
| | Symptom severity score
| Open Release 8 | Preop: 2.5; 29 Months: 0.4
| | Recalculated to account for patient attrition:
| Open Release 10 | Preop: 2.5; 29 Months: 0.82
| Release and Neurolysis 15 | Preop 2.9; 29 Months: 0.3
| | Recalculated to account for patient attrition:
| Release and Neurolysis 26 | Preop: 2.9; 29 Months: 1.4
| (Hands)
Mackinnon 1991 ^407^ | | Symptom rating at 12 months. | Not reported
| Open Release 32 | Relief of all or most symptoms 28
| | Unimproved 4
| | Worse 0
| Release and neurolysis 31 | Relief of all or most symptoms 25
| | Unimproved 5
| | Worse 1
| (Hands)
Lowry, 1988 ^429^ | | 3 Months | Not reported
| Open Release 23 | Excellent 7
| | Good 8
| | Fair 6
| | Poor 2
| Release and Neurolysis 24 | Excellent 4
| | Good 12
| | Fair 7
| | Poor 1
| | Recalculated^b^:
| Open Release 25 | Excellent 7
| | Good 8
| | Fair 6
| | Poor 4
| Release and Neurolysis 25 | Excellent 4
| | Good 12
| | Fair 7
| | Poor 2
Gelberman, 1987 ^415^ ; | | Number of patients with complete resolution of signs and symptoms | Significantly different (p <0.05, chi square)
Rhodes, 1985 ^451^ | Open Release: 29 | Complete resolution: 18
| | Mean followup time: 16 Months
| Release and Neurolysis 32 | Complete resolution: 10
| | Mean followup time: 18 Months
Holmgren-Larsson, et al. 1985 ^433^ | 48 Patients; Number in each group not reported. | Percent of patients reporting themselves symptom-free at 6 months | Not reported
| Open Release | 89%
| Release and Neurolysis | 89%
Holmgren, 1987 ^416^ | | 3–4 Years:
| Open Release 20 | Totally restituted: 12
| | Improved: 4
| | Dead: 1
| | Did not respond: 3
| Release and Neurolysis 23 | Totally restituted: 18
| | Improved: 3
| | Dead: 1
| | Did not respond: 1
Freshwater, 1978 ^426^ | | Number of patients with no symptoms at 2 years | Not significantly different by chi square test conducted by ECRI, p = 0.64
| Open Release 12 | 11
| Release and Neurolysis 14 | 12

a : Two hands were lost to followup in the open release group and eleven in the neurolysis group. These hands were conservatively assumed to be unimproved. The significant loss to followup, as well as the fact that loss was not evenly distributed between groups, may render these data unreliable. This recalculation does not account for the additional 13 patients (14 hands) who were lost to followup for whom the group assignment was not reported.

b : Recalculated to account for patient attrition using the conservative assumption that treatment had failed for the two patients missing from the open release group and the one patient missing from the release and neurolysis group.

Of the remaining two outcomes in the report by Blair et al., both could be used to calculate an effect size. The number of patients stating they would have surgery again gave an effect size of d = 0.067, while the number of patients happy or satisfied with their treatment led to an effect size of d = 0.94. It is unclear which of these is the more accurate measure of global effect. We chose to use the smaller effect size in our meta-analysis. This conservative approach, which is biased against finding a significant effect, adds credibility to the resulting significant effect.

The report by Foulkes ^376^ provided two measures of global outcome, only one of which could be used to calculate an effect size. We were able to compensate for 13 of the 27 hands lost to followup by using the conservative assumption that they were unimproved at followup. The remaining 14 hands could not be accounted for because their group assignment was not reported. Similarly, the 42 hands not reported in the study by Blair and twenty in the study by Mackinnon could not be accounted for because their group assignment was not reported.

The report by Holmgren et al. is a long-term followup of Holmgren-Larsson et al. that does not account for five patients (10.4%) who did not return for followup examinations. ^416,^ ^433^ Because the original report by Holmgren-Larsson did not report the number of patients assigned to each group, the group assignments of these five patients is not known. Thus, these patients cannot be accounted for when calculating effect sizes. The two patients known to have died were not included in our calculations. Three patients were not accounted for in the study by Lowry. Two of them were in the no neurolysis group and one in the neurolysis group. We accounted for them using the conservative assumption that treatment had failed for all of them.

Eight studies provided sufficient data for meta-analysis. The results may be found in Table 72. The calculated effect sizes are not heterogenous (Q = 5.20; p = 0.64) and the overall effect size is significantly different from zero (d = 0.27, 95% C.I. = 0.003–0.537; p = 0.047). The lack of heterogeneity suggests that although the study by Leinberry incorporated patients who may have had more severe CTS than those in the other studies, ^342^ its results were not derived from a different population than the results of other studies. It was therefore statistically valid to combine this study with the others for meta-analysis. The effect sizes of the individual studies as well as the overall effect size, and their 95% confidence intervals are depicted graphically in Figure 33. Although the difference between groups is statistically significant, there is still considerable (80.6%) overlap between the global outcome scores of the two groups, as can be seen in Figure 34.

Table 72. Results of conservative meta-analysis of global outcome among patients treated with neurolysis for carpal tunnel syndrome

Author | Year | N | Effect Size | 95% CI | p-value | Standardized Residual | Outlier by Std Residual?
Leinberry, ^342^ | 1997 | 50 | 0.089 | -0.53–0.78 | 0.778 | -0.64 | No
Blair, ^428^ | 1996 | 75 | 0.067 | -1.28–1.42 | 0.923 | -0.30 | No
Foulkes, ^376^ | 1994 | 36 | 0.432 | -0.30–1.17 | 0.250 | 0.46 | No
Mackinnon, ^407^ | 1991 | 63 | 0.282 | -0.48–1.04 | 0.465 | 0.03 | No
Lowry, ^429^ | 1988 | 50 | 0.140 | -0.41–0.70 | 0.615 | -0.52 | No
Gelberman, ^415^ | 1987 | 61 | 0.697 | 0.11–1.28 | 0.019 | 1.61 | No
Holmgren, ^416^ | 1987 | 41 | -0.741 | -2.04–0.56 | 0.263 | -1.56 | No
Freshwater, ^426^ | 1978 | 26 | 0.324 | -1.08–1.72 | 0.650 | 0.08 | No
| | | Fixed effects model:
| | | Overall Effect Size | 95% CI | p-value of E.S. | Q | p-value of Q
| | | 0.27 | 0.003–0.537 | 0.047 | 5.20 | 0.636

Figure 33. Results of meta-analysis of the effect of neurolysis on global outcome

Figure 34. Overlap between effects of neurolysis and no neurolysis

One difficulty in interpreting this meta-analysis comes from the large rate of patient attrition. Of the 494 cases treated in these studies, results were not reported for 99. Two of these had died, and an additional 16 could be accounted for by assuming that treatment had failed for them. This leaves a total of 81 (16.4%) patients unaccounted for. The existence of a large number of treated patients whose outcomes are not known may undermine the confidence with which these results are interpreted.

For three of the studies in this meta-analysis, more than one effect size could be calculated depending on the assumptions made about the data. In all cases, we chose the most conservative assumption. However, because of the distribution of patients between groups, the most conservative assumption did not always lead to the smallest possible effect size. In the study by Foulkes, there were 11 patients missing from the neurolysis group and only two from the no neurolysis group. Assuming that treatment had failed for all of these patients leads to a larger effect size (favoring no neurolysis) than either applying the anti-conservative assumption that treatment had succeeded for these patients or not attempting to account for missing patients at all. Thus, application of this assumption may have lead to an erroneous result. The effect of making conservative or anticonservative assumptions, or of not attempting to account for missing patients by recalculating data is summarized in Table 73.

Table 74. Effects of assumptions about individual studies on the overall effect size

Study | | | Is the overall effect size significantly different from zero?
Blair | Foulkes | Lowry
Conservative | Conservative | Conservative | Yes
Conservative | No Recalculation | No Recalculation | No
Conservative | Anti-conservative | Anti-conservative | No
Anti-conservative | Conservative | Conservative | Yes
Anti-conservative | No Recalculation | No Recalculation | Yes
Anti-conservative | Anti-conservative | Anti-conservative | Yes

Table 73. Effect sizes of individual studies according to the assumptions used to calculate them

Study | Assumption used to calculate Hedges' d
| Conservative | No Recalculation | Anti-conservative
Blair ^428^ | 0.067 (-1.28–1.42) | N/A^a^ | 0.94 (-0.70–2.57)
Foulkes ^376^ | 0.43 (-0.30–1.17) | 0.30 (-1.53–2.13) | 0.11 (-1.69–1.92)
Lowry ^429^ | 0.14 (-0.41–0.70) | 0.28 (-0.30–0.85) | 0.37 (-0.19–0.93)
Overall Effect Size | 0.27 (0.003–0.537) | 0.29 (0.01–0.97)^b^ | 0.31 (0.03–0.59)
| | 0.28 (-0.01–0.57)^c^

a : N/A; Not applicable. Data from this study were not recalculated.

b : If the anticonservative effect size from the study by Blair is used.

c : If the conservative effect size from the study by Blair is used.

As can be seen in Table 73, consistently applying either the conservative or the anti-conservative assumptions to the data leads to a statistically significant effect. Anti-conservative in this instance means assuming that treatment was successful for all missing patients, and using the larger of the two effect sizes calculable from the data of Blair. The fact that the results significantly favor no neurolysis regardless of whether conservative or anticonservative assumptions are applied strengthens our confidence in the results of our analysis.

When the data from the studies by Foulkes and Lowry were not recalculated to account for missing patients, the meta-analytic summary statistic was statistically significant only when the larger effect size from the study by Blair was used. This later meta-analysis, however, was only marginally nonsignificant (p = 0.052), and could be overturned by future studies. This result, however, does not establish that there is a benefit derived from performing neurolysis. To the contrary, if the true effect size is nonsignificant, this indicates that there is no effect of neurolysis on global outcome. The lack of a statistically significant effect of neurolysis does not arise because we included non-randomized and non-blinded studies in our meta-analysis. Removal of such studies again yielded a non-significant meta-analytic summary statistic (d = 0.18, 95% CI –0.7–0.42, p=0.154.

The results of our conservative meta-analysis suggest that in a typical case of carpal tunnel syndrome, there is no benefit from performing neurolysis along with surgical release of the carpal tunnel. When statistical assumptions are consistently applied while performing meta-analysis, results suggest that patients report superior global effect of surgery when neurolysis is not performed. The results of this meta-analysis become statistically nonsignificant when analysis is restricted to the results of blinded RCTs. Removal of studies, however, reduces the statistical power of the meta-analysis, and it may be this loss of power, rather than any bias in the non-blinded studies that causes the analysis to become non-significant. That there is no marked bias in these studies is suggested by the lack of heterogeneity, which, in turn, indicates that all eight studies in the meta-analysis measure the same population parameter. There is insufficient evidence to reach an evidence-based conclusion about whether neurolysis is of benefit in atypical cases, such as when there is marked scarring or neural adhesion.

##### Return to work

Two controlled trials, one of which was randomized, reported some information describing return to work. Both included patients who received bilateral procedures, and one had high (36%) attrition. Results are presented in Table 75 and summarized in Table 76. Neither study reported the number of patients who were working or on sick leave prior to treatment, so the number of patients returning to work could not be determined. As can be seen in Table 76 and Figure 35, both studies favor release without neurolysis, with the difference achieving statistical significance in one study. Because of incomplete reporting, no meta-analysis or power analysis was possible.

Table 75. Effect of neurolysis on return to work

Study | Number of Patients | Time to Return to Work | Statistical Significance of Difference Between Groups
Foulkes, 1994 ^376^ | Open Release | Median 53 Days (Range 1–180) | Not significantly different, statistical test not reported.
| Release and Neurolysis | Median 59 Days (Range 14–120)
| N not reported
Freshwater, 1978 ^426^ | N not reported | Stated only that patients receiving open release without neurolysis returned to work more quickly than those who received neurolysis. | This difference was statistically significant by the Mann-Whitney U test (p <0.01).

Table 76. Summary of the effect of neurolysis on return to work

Study | Which Procedure Had Faster Return to Work? | Was the Difference Stastically Significant? | Power (Minimum percent difference detectable) | Effect Size (95% Confidence Interval)
Foulkes, 1994 ^376^ | No neurolysis | No | Not calculable | Not calculable
Freshwater, 1978 ^426^ | No neurolysis | Yes | Not calculable | Not calculable

Figure 35. Summary of the effect of neurolysis on return to work

An open bar indicates an RCT, while a striped bar indicates a CT.

##### Return to Activities of Daily Living

No studies reported this outcome.

##### Pain

Three controlled trials, two of which were randomized, compared pain in patients who received surgery with and without neurolysis. Results are presented in Table 77. The study by Freshwater and Arons found no statistically significant differences between groups in incidence of night pain and tenderness. ^426^ Too few patients (6, or 23%) had wrist pain prior to treatment for any statistical analysis of differences in pain between groups to be made. The study by Blair shows a trend toward superior results from neurolysis, but the difference between groups is not significant (chi square test conducted by ECRI, p = 0.106). Given the 36% loss to followup in the study, as discussed above, its results are not conclusive. If only the more successful candidates returned for followup, this would bias the results. Holmgren-Larssen et al. ^433^ found that the patients treated with neurolysis had a resurgence in pain at 6-month followup, while the patients with no neurolysis did not. The statistical significance of this trend cannot be determined, however, because they did not report the number of patients in each group.

Table 77. Effect of neurolysis on carpal tunnel pain

Study | Number of Hands | Pain | Statistical Significance of Difference Between Groups
Blair, 1996 ^428^ | Open Release 27 | Preop: 25 had pain | Not significantly different by chi square test conducted by ECRI, p = 0.11
| | Unimproved: 0
| | Improved: 8 (32%)
| | No Pain: 17 (68%)
| | Preop: 42 had pain
| Release and Neurolysis 48
| | Unimproved: 1 (2.4%)
| (Hands) | Improved: 5 (12%)
| | No Pain: 36 (86%)
Holmgren-Larsson, 1985 ^433^ | 48 Hands total; number in each group not reported | Percent of patients reporting pain | Not reported
| Open release
| Preop. | 78
| 3–4 Weeks | 0
| 6 Months | 0
| Release and neurolysis
| Preop. | 85
| 3–4 Weeks | 4
| 6 Months | 13
Freshwater, 1978 ^426^ | | Patients with wrist pain: | Not significantly different by chi square test conducted by ECRI, p = 0.91
| Open Release 12 | Preop: 2; Postop: 1
| Release and Neurolysis 14 | Preop 4; Postop: 1
| | Patients with night-waking pain and tenderness: | Not significantly different by chi square test conducted by ECRI, p = 0.97
| Open Release 12 | Preop: 12; Postop: 0
| Release and Neurolysis 14 | Preop: 14; Postop: 0

These results are summarized in Table 78 and Figure 36. Calculable effect sizes are presented in Figure 37. The available data are of insufficient quality and quantity to allow one to reach n evidence-based conclusion about whether there is a difference in symptomatic pain resulting from performing or not performing neurolysis.

Table 78. Summary of the effect of neurolysis on pain

Study | Which Procedure led to less pain? | Was the Difference Stastically Significant? | Power (Minimum percent difference detectable)^a^ | Effect Size (95% Confidence Interval)^a^
Blair, 1996 ^428^ | Neurolysis | No | 28% | -0.57 (-1.23–0.10)
Holmgren-Larsson, 1985 ^433^ | No Neurolysis | No | Not calculable | Not calculable
Freshwater, 1978 ^426^ | No difference | No | Not calculable | 0.08 (-2.12–2.28)

a : Calculated by ECRI

Figure 36. Summary of effect of neurolysis on pain

An open bar indicates an RCT, a striped bar indicates a CT.

Figure 37. Size of effect (Hedges' d) of neurolysis on pain

##### Function

Two randomized controlled trials of carpal tunnel release with or without neurolysis reported measures of function. Both included patients treated for bilateral CTS, and both had high (36%-50%) rates of attrition. Their results can be found in Table 79. Foulkes et al. asked patients to rate their hand function on a scale of 0–100, while Blair et al. reported the number of patients having difficulty in three specific activities. As can be seen in Table 80 and Figure 38, neither study found a statistically significant difference between groups, and no clear trends can be observed favoring one group or the other. Differences between groups are small, and, in the case of Blair, would have to be large (at least 44%) before the study would have the statistical power to find them significant.

Table 79. Effect of neurolysis on hand function

Study | Number of Patients | Function | Statistical Significance of Difference Between Groups
Blair et al., 1996 ^428^ | | Patients having difficulty: | There were no significant differences between groups before or after treatment (test not reported)
| | Screwing Lids:
| Open Release 27 | Preop: 25 (92.5%)
| | 24 Months: 11 (40.7%)
| Release and Neurolysis 48 | Preop: 41 (85.4%)
| | 24 Months: 15 (31.3%)
| | Picking up small objects
| Open Release 27 | Preop: 18 (66.7%)
| | 24 Months: 10 (37.0%)
| Release and Neurolysis 48 | Preop: 27 (56.3%)
| | 24 Months: 9 (18.8%)
| | Lifting:
| Open Release 27 | Preop: 15 (55.6%)
| | 24 Months: 7 (25.9%)
| Release and Neurolysis 48 | Preop: 25 (52.1%)
| | 24 Months: 9 (18.8%)
| (Hands)
Foulkes et al., 1994 ^376^ | | Function rating (0–100) | Not reported
| Open Release 8 | Preop: 41
| | 29 Months: 89
| 10 | Recalculated^a^: 79.4
| Release and Neurolysis 15 | Preop: 34
| | 29 Months: 88
| 26 | Recalculated: 65.2

a : Recalculated by ECRI according to intent to treat principles by making the conservative assumption that the two patients lost to followup in the open release group had function ratings of 41 at 29 months, and the 11 lost to followup in the neurolysis group had function ratings of 34.

Table 80. Summary of effect of neurolysis on hand function

Study | Which Procedure led to superior function? | Was the Difference Stastically Significant? | Power (Minimum percent difference detectable)^a^ | Effect Size (95% Confidence Interval)
Blair, 1996 ^428^ | Neurolysis | No | Screwing Lids: 62% | Not calculable
| | | Picking up objects: 57%
| | | Lifting: 44%
Foulkes, 1994 ^376^ | Open release | Not reported | Not calculable | Not calculable

a : Calculated by ECRI

Figure 38. Summary of effect of neurolysis on hand function

##### Quality of Life

No studies reported on this outcome.

##### Harms

Only two randomized controlled trials reported on complications and adverse effects among patients receiving neurolysis. One of these had 50% attrition. ^376^ These trials are listed below in Table 81. One controlled trial and one retrospective trial reported that there were no complications. ^415,^ ^426^ There are insufficient data to allow one to reach an evidence-based conclusion.

Table 81. Complications in controlled trials of neurolysis for patients with carpal tunnel syndrome

Study | Group n | Complication | Number of patients reporting
Foulkes, 1994 ^376^ | No Neurolysis 8 Hands | Infection | 0
| Neurolysis 15 Hands | Infection | 2
Lowry, 1988 ^429^ | No Neurolysis 23 | Persistent incisional pain | 3
| | Hand swelling | 0
| | Causalgia | 1
| Neurolysis 24 | Persistent incisional pain | 4
| | Hand swelling | 1
| | Causalgia | 0

#### Conclusion

The available evidence suggest there is little or no benefit from performing neurolysis along with surgical release of the carpal tunnel. Meta-analysis of global outcomes demonstrates a benefit from not performing neurolysis that was not apparent from examination of the individual studies. Available return to work data also shows a trend toward an advantage of not performing neurolysis. There are insufficient data to allow one to reach an evidence-based conclusion, on the effect of neurolysis on pain or function. The possibility remains that neurolysis may be helpful is special cases, such as in the presence of marked scarring or neural adhesion, but no available evidence specifically documents the benefits and harms of neurolysis among such patients.

### What are the relative benefits and harms of steroid injection into the carpal tunnel for persons with carpal tunnel syndrome?

Four prospective, randomized controlled trials describing 261 patients reported on the effect of steroid injections into the carpal tunnel.

#### Internal Validity

Three studies of steroid injections were double-blinded, ^36,^ ^452,^ ^453^ and one was unblinded. ^427^ Three studies assessed only one hand per patient, while Girlanda et al. assessed 53 hands in 32 patients. ^36^ This study therefore violated the statistical principle of independence between subjects. All four studies had no attrition and full compliance. Data on study internal validity may be found in Table 82.

Table 82. Internal validity of studies of steroid injection for carpal tunnel syndrome

Study | Number of patients | Percent of patients with bilateral CTS | Number of centers | Funded by a for-profit stakeholder? | Study design | Blinding | Total Patient Attrition (all patient groups) | Intent to treat analysis? | % Compliance
O'Gradaigh, 2000 ^454^ | 123 | 0% | Single | Not reported | RCT | No | 0 | Yes | 100
Dammers, 1999 ^452^ | 60 | 0% | Single | No | RCT | Double | 0 | Yes | 100
Girlanda, 1993 ^36^ | 32 | 65.6% | Single | Not reported | RCT | Double | 0 | Yes | 100
Ozdogan, 1984 ^453^ | 37 | 0% | Single | Not reported | RCT | Double | 0 | Yes | 100

#### Generalizability

None of the studies reported patient comorbidities, except when some comorbidities were excluded, as indicated by a zero in Table 83. Dammers, et al. excluded patients with mild disease. ^452^ Results in this study may therefore be different from results in others. None of the studies provided information about patient employment characteristics.

Table 83. Generalizability of studies of steroid injection for carpal tunnel syndrome

Study | Number of patients | Mean age and range | % Female | Mean Duration (Months) of condition and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Excluded severe disease? | Excluded mild disease?
O'Gradaigh, 2000 ^454^ | 123 | NR | NR | NR | NR | NR | 0 | NR | NR | NR | NR | No | No
Dammers, 1999 ^452^ | 60 | 52 | 83.3 | 29 | NR | NR | NR | NR | NR | NR | NR | No | Yes
Girlanda, 1993 ^36^ | 32 | 45.5 | 81.3 | 53.5 (1–240) | 0 | 0 | NR | 0 | 0 | NR | 0 | No | No
Ozdogan, 1984 ^453^ | 37 | 47.0 | 100 | 45.6 | 0 | 0 | 0 | NR | NR | NR | 0 | No | No

##### Global outcome

One study compared steroid injection with no treatment, ^454^ two compared steroid injection with placebo (saline or lidocaine), ^36,^ ^452^ and one compared carpal tunnel injection with intramuscular injection. ^453^ Two therefore controlled for a possible placebo effect, while one is considered a comparison of treatments, as intramuscular steroid injection may exert an effect.

The results of the four trials may be found in Table 84. Because effect sizes could only be calculated for three studies, we did not perform a meta-analysis. After treatment, global outcomes were significantly higher in all treated groups (as compared to untreated) in the study by O'Gradaigh et al., but were not significantly different from each other at 6 weeks or 6 months (chi square tests conducted by ECRI). The difference from untreated remained statistically significant after applying the Bonfferoni correction for multiple statistical tests (critical p = 0.004).

Table 84. Effect of steroid injection on global outcome

Study | Number of Patients | | Global Outcome | Statistical Significance of Difference Between Groups
O'Gradaigh, 2000 ^454^ | | | Patients showing improvement of symptoms | Treatments were superior to controls at either time point by chi square test, p <0.05
| | | 6 Weeks: | Treatments were not significantly different from each other at either time point by chi square test, p>0.05.
| No Injection | 20 | 1 (5.0%)
| 20 mg Triamcinolone | 18 | 13 (72.2%)
| 25 mg Hydrocortisone | 32 | 21 (65.6%)
| 100 mg Hydrocortisone | 53 | 34 (64.1%)
| | | 6 Months:
| No Injection | 20 | 0 (0%)
| 20 mg Triamcinolone | 18 | 8 (44.4%)
| 25 mg Hydrocortisone | 32 | 14 (43.8%)
| 100 mg Hydrocortisone | 53 | 17 (32.1%)
Dammers, 1999 ^452^ | | | Patients with No symptoms or minor symptoms | Treatments were significantly different at both time points (p = 0.000011 and 0.0002 respectively, chi square test conducted by ECRI)
| | | 1 Month
| Placebo (10 mg Lignocaine) | 30 | 6 (20.0%)
| 10 mg Lignocaine and 40 mg Methylprednisone | 30 | 23 (76.7%)
| | | 12 Months
| Placebo (10 mg Lignocaine) | 30 | 2 (6.7%)
| 10 mg Lignocaine and 40 mg Methylprednisone | 30 | 15 (50.0%)
Girlanda, et al., 1993 ^36^ | | | Mean symptom score (0–10) | Not reported
| | | Pretreatment:
| Placebo (Saline) | 26 | 9
| 15 mg Methylprednisone | 27 | 8
| | | 1 Week
| Placebo (Saline) | 26 | 7
| 15 mg Methylprednisone | 27 | 3
| | | 2 Months
| Placebo (Saline) | 26 | 8
| 15 mg Methylprednisone | 27 | 1.5
Ozdogan and Yazici, 1984 ^453^ | | | Pretreatment::
| | | | Groups were not significantly different, p = 0.83, chi square test conducted by ECRI
| 1.5mg Betamethasone in the deltoid muscle | 19 | Severe 13
| | | Moderate 4
| | | Minimal 2
| | | No Symptoms 0
| 1.5mg Betamethasone in the carpal tunnel | 18 | Severe 11
| | | Moderate 6
| | | Minimal 1
| | | No Symptoms 0
| | | 1 Week:
| | | | Groups were not significantly different, p = 0.25, chi square test conducted by ECRI.
| 1.5mg Betamethasone in the deltoid muscle | 19 | Severe 5
| | | Moderate 2
| | | Minimal 8
| | | No Symptoms 4
| 1.5mg Betamethasone in the carpal tunnel | 18 | Severe 2
| | | Moderate 3
| | | Minimal 8
| | | No Symptoms 5
| | | 1 Month:
| | | | Groups were significantly different, p = 0.009, chi square test conducted by ECRI
| 1.5mg Betamethasone in the deltoid muscle | 19 | Severe 8
| | | Moderate 8
| | | Minimal 2
| | | No Symptoms 1
| 1.5mg Betamethasone in the carpal tunnel 18 | 18 | Severe 6
| | | Moderate 3
| | | Minimal 0
| | | No Symptoms 9

Similarly, Dammers found that treated groups were significantly different from placebo groups at both time points reported, ^452^ while Girlanda reported global scores favoring steroid injection over placebo, but did not report on the statistical significance of this difference. The results of the four trials are summarized in Table 85 and Figure 39.

Table 85. Summary of effect of steroid injection on global outcome

Study | Which Procedure led to Superior Global Outcome? | Was the Difference Stastically Significant? | Power (Minimum percent difference detectable)^a^ | Effect Size (95% Confidence Interval)^a^
O'Gradaigh, 2000 ^454^ | Injection | Yes | 20 mg Triamcinolone 22% | 20 mg Triamcinolone
| | | | 6 Weeks: 2.11 (0.86 – 3.35)
| | | | 6 Months: 1.89 (0.27 – 3.52)
| | | 25 mg Hydrocortisone 18% | 25 mg Hydrocortisone
| | | | 6 Weeks: 1.95 (0.77 – 3.13)
| | | | 6 Months: 1.88 (0.29 – 3.48)
| | | 100 mg Hydrocortisone 17% | 100 mg Hydrocortisone
| | | | 6 Weeks: 1.92 (0.77 – 3.07)
| | | | 6 Months: 1.62 (0.05 – 3.20)
Dammers, 1999 ^452^ | Injection | Yes | 16% | 1 Month: 1.40 (0.720–02.08)
| | | | 12 Months: 1.44 (0.55 – 2.32)
Girlanda, 1993 ^36^ | Injection | Not reported | Not calculable | Not calculable
Ozdogan, 1984 ^453^ | Injection | At 1 month only | Not calculable | 1 Week: 0.25(-0.39 – 0.90)
| | | | 1 Month: 0.28 (-0.37 – 0.40)

a : Calculated by ECRI

Figure 39. Summary of effect of injection on global outcome

Both studies that reported longer followup times (>6 months) found that the effect of steroid injection declined over time. The period of relief that can be expected by the average patient cannot be determined from the available data.

The differences in effect sizes between studies may be explained by the differences in the groups to which steroid injection into the carpal tunnel is being compared. The largest effect sizes, ranging from 1.62 to 2.11, are found in the study by O'Gradaigh, who compared steroid injection to no treatment. The next largest (1.40–1.44) are in the study by Dammers, who compared steroid injection to placebo injection. If the placebo exerted a placebo effect, the difference between groups, and thus the effect size, would be smaller than that found in a study comparing treated and untreated groups. The smallest effect sizes (0.25–0.28) are found in the study by Ozdogan, who compaired steroid injection into the carpal tunnel with another active treatment, intramuscular steroid injection. Ozdogan thus tests not whether steroid injection into the carpal tunnel is effective, but whether it exerts an effect superior to that of intramuscular injection.

##### Return to Work

No studies reported this outcome.

##### Return to Activities of Daily Living

No studies reported this outcome.

##### Pain

No studies reported this outcome.

##### Function

No studies reported this outcome.

##### Quality of Life

No studies reported this outcome.

##### Harms

No side effects or complications were described by any of the reports. This does not necessarily indicate that there were no such occurrences. Only Dammers et al. specifically stated that there were no side effects. ^452^

#### Conclusions

The results of these four studies indicate that injection of steroid into the carpal tunnel yields superior global outcomes than no treatment or placebo. Although the short-term (1 week) effect of carpal tunnel injection was not superior to intramuscular injection in the trial by Ozdogan and Yazici, the effects of injection may last longer. ^453^ Carpal tunnel injection was significantly better than intramuscular injection at a longer (1 month) followup time. Because no further time points were reported, we are unable to determine whether this difference persists beyond this time.

There are no data available that indicate whether any type of steroid may be superior to any other, or whether any particular dose is optimum. Although it is clear that the effects of steroid injection wear off after time, there is no information indicating the expected duration of relief for the average patient, or whether any patients can expect to experience permanent relief.

### What are the relative benefits and harms of oral medications for persons with carpal tunnel syndrome?

Oral medications, including steroids, nonsteroidal anti-inflammatory drugs (NSAIDs) and diuretics have been used to treat carpal tunnel syndrome.

#### Internal Validity

Two prospective, double-blinded randomized controlled trials describing 109 patients reported the effects of oral medications on carpal tunnel syndrome. ^35,^ ^455^ Study characteristics affecting internal validity are listed in Table 86.

Table 86. Internal validity of studies of oral medication for carpal tunnel syndrome

Study | Number of patients | Percent of patients with bilateral CTS | Number of centers | Funded by a for-profit stakeholder? | Study design | Blinding | Total Patient Attrition (all patient groups) | Intent to treat analysis? | % Compliance
Chang, 1998 ^35^ | 91 | 0% | Single | Not reported | RCT | Double | 18 | No | NR
Herskovitz, 1995 ^455^ | 18 | 0% | Single | Not reported | RCT | Double | 3 | No | NR

All results were reported per patient, rather than per hand. Therefore, there was no violation of the statistical assumption of independence. Both reports described only patients who completed the treatment. There was a 20% attrition before final followup in the study by Chang, including 7 patients who underwent carpal tunnel surgery during the course of the study. The study by Herskovitz reported a 16.7% attrition rate, including two patients from the prednisone group and one from the placebo group. This attrition may have resulted in an increase in the apparent effectiveness of the drugs, as patients who are unsatisfied with their treatment may have been more likely to drop out of the study. The seven patients described by Chang et al. who underwent surgery were clearly unsatisfied with the results of their medication. Neither trial provided a measure of patient compliance. Therefore it is unknown whether or how often the patients took their medication.

#### Generalizability

Patients were middle-aged (mean 46.3 years) and predominantly female (58%-80%). Both excluded patients with mild and severe CTS. Herskovitz included patients with diabetes and arthritis, while these patients were excluded from the study by Chang. This exclusion limits both the generalizability of the study and the extent to which the results of the two studies can be compared and combined. Patient characteristics from the two studies are presented in Table 87. Neither study described patient employment characteristics.

Table 87. Generalizability of studies of oral medication for carpal tunnel syndrome

Study | Number of patients | Mean age and range | % Female | Mean Duration (Months) of condition and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Excluded severe disease? | Excluded mild disease?
Chang, 1998 ^35^ | 91 | 45.7 | 58.2 | NR | 0 | 0 | NR | NR | 0 | 0 | NR | Yes | Yes
Herskovitz, 1995 ^455^ | 18 | 49.6 | 80.0 | 20.6 | 6.6 | 6.6 | NR | 0 | 0 | NR | NR | Yes | Yes

One trial compared oral prednisone with placebo, ^455^ while the other compared prednisolone, tenoxicam, trichlormethiazide and placebo. ^35^ These drugs and dosages are described in Table 88. The two studies tested different drugs. However, both report the effects of an anti-inflammatory steroid, and these results are to some extent comparable.

Table 88. Oral drugs used to treat carpal tunnel syndrome in controlled studies

Drug | Dose | Description
Prednisone | 20mg/day for 1 week, then 10mg/day for 1 week | An anti-inflammatory steroid
Prednisolone | 20mg/day for 2 weeks, then 10mg/day for 2 weeks | An anti-inflammatory steroid
Tenoxicam | 20mg/day for 4 weeks | A nonsteroidal anti-inflammatory drug (NSAID)
Trichlormethiazide | 2mg/day for 4 weeks | A diuretic, used to reduce swelling and lower carpal tunnel pressure

#### Results

##### Global outcome

Both studies reported global symptom scores. This was the mean of five symptom severity ratings on a scale of zero to ten. The symptoms rated were pain, numbness, paresthesia, weakness/clumsiness and nocturnal awakening. These data are summarized in Table 89. As can be seen in Table 90 and Figure 40, both reports found statistically significant decreases in symptom scores among patients treated with steroids compared to placebo controls. However, Herskovitz et al. reported that symptoms returned after the cessation of treatment. In neither study did symptom scores approach zero, indicating that although there was some relief, symptoms were still present. Chang et al. reported a 64% mean decrease in global symptom scores, while Herskovitz et al reported a 68% decrease. Neither paper indicated whether the patients were satisfied with their level of symptom relief.

Table 89. Effect of oral medications on global outcome of carpal tunnel syndrome

Study | Number of Patients | Global Outcome | Statistical Significance of Difference Between Groups
Chang, et al., 1998 ^35^ | | Mean global symptom score^a^
| Placebo 16 | Baseline: 22.9±5.9 | Symptom reduction among patients receiving steroid was significantly greater at 2 weeks than among patients in the other three groups (F = 7.37, p = 0.0002)
| | 2 Weeks: 21.6±6.4
| | 4 Weeks: 20.8±6.6
| Diuretic 16 | Baseline: 26.0±3.8 | Symptom reduction among patients receiving steroid was significantly greater at 4 weeks than among patients in the other three groups (F = 10.7, p = 0.0001)
| | 2 Weeks: 22.3±5.5
| | 4 Weeks: 21.6±6.3
| NSAID 18 | Baseline: 29.7±8.4 | NSAID and diuretic groups were not significantly different from placebo at either time point.
| | 2 Weeks: 24.7±8.6
| | 4 Weeks: 24.0±9.7
| Steroid 23 (Prednisolone) | Baseline: 27.9±6.9
| | 2 Weeks: 15.0±6.8
| | 4 Weeks: 10.0±7.5
| Recalculated^b^ | Recalculated^b^
| Placebo 23 | Baseline: 22.9
| | 2 Weeks: 22.0
| | 4 Weeks: 21.4
| Steroid 26 | Baseline: 27.9
| | 2 Weeks: 16.5
| | 4 Weeks: 12.1
Herskovitz, et al., 1995 ^455^ | | Mean global symptom score^a^
| Placebo 9 | Baseline: 23 | Groups were significantly different only at 2 weeks (p <0.05, t-test)
| | 2 Weeks: 19
| | 4 Weeks: 17
| | 8 Weeks: 16.5
| Steroid 6 | Baseline: 25
| (Prednisone) | 2 Weeks: 8
| | 4 Weeks: 11
| | 8 Weeks: 20
| Recalculated^b^ | Recalculated^b^
| Placebo 10 | Baseline: 23
| | 2 Weeks: 19.4
| | 4 Weeks: 17.6
| | 8 Weeks: 17.2
| Steroid 8 | Baseline: 25
| | 2 Weeks: 12.3
| | 4 Weeks: 14.5
| | 8 Weeks: 21.3
| | Number of patients reporting improvement in symptoms: | Numbers were the same for all time points, and were significantly different between groups (p = 0.02, test not reported)
| Placebo 9 | 3 | Improvement rates were no longer statistically significant if the two patients from the steroid group and one from the placebo group who were not reported on were assumed not to have improved, p = 0.058 by chi square test conducted by ECRI.
| Steroid 6 (Prednisone) | 6

a : The sum of severity ratings (scale 0–10) for 5 symptoms: pain, numbness, paresthesia, weakness/clumsiness, and nocturnal wakening

b : Recalculated to account for patient attrition using the conservative assumption that patients for whom no data was provided had scores equal to the mean baseline score for that group.

Table 90. Summary of effect of oral medications on global outcome of carpal tunnel syndrome

Study | Which Medication led to Superior Global Outcome? | Was the Difference Stastically Significant? | Power (Minimum percent difference detectable)^a^ | Effect Size (95% Confidence Interval)^a^
Chang, 1998^35^ | Steroid | Yes | Diuretic | Diuretic
| | | 2 Weeks: 20.0% | 2 Weeks: -0.11 (-0.81 – 0.58)
| | | 4 Weeks: 22.4% | 4 Weeks: -0.12 (-0.81 – 0.57)
| | | NSAID | NSAID
| | | 2 Weeks: 24.6% | 2 Weeks: -0.40 (-1.08 – 0.28)
| | | 4 Weeks: 27.9% | 4 Weeks: -0.37 (-1.05 – 0.31)
| | | Steroid | Steroid
| | | 2 Weeks: 20.2% | 2 Weeks: 0.97 (0.30 – 1.65)
| | | 4 Weeks: 22.4% | 4 Weeks: 1.48 (0.76 – 2.20)
Herskovitz, 1995^455^ | Steroid | Yes | Global Symptom Score | Global Symptom Score
| | | Not calculable | 2 Weeks: 1.08 (-0.03 – 2.18)^b^
| | | Number of Patients Improved | Number of Patients Improved
| | | 49% | 1.65 (-0.09 – 3.39)

a : Calculated by ECRI

b : Estimated by ECRI based on the conservative assumption that p = 0.049.

figure 40. Summary of effect of oral steroids on global outcome

When the data were recalculated to account for patient attrition, the steroid groups in both studies still showed a greater than 50% reduction in global symptom scores. However, because we are unable to accurately estimate the standard deviations around the recalculated means, we are unable to determine whether the difference remains statistically significant. The number of patients reporting symptom relief in the report by Herskovitz is not statistically significantly different between groups once we attempted to compensate for patient attrition by assuming that patients for whom there was no data did not improve.

In the study by Chang, neither the diuretic nor the NSAID caused statistically significant symptom relief compared to placebo control. However, a single small trial with high loss to followup is not sufficient proof that these agents have no effect. Moreover, only a single dosage of each drug was tested. There are no published data on the effectiveness of these agents at other dosages. The power of the study by Chang was sufficient to detect medium-sized (20–30%) differences between groups. The differences between placebo and steroid were greater than this, while the differences between the other groups and placebo were too small to be statistically significant with the available power.

The study by Herskovitz had fewer patients than the study by Chang. Although the statistical power of this study to detect differences in global symptom score could not be calculated, it was likely lower than that of Chang. The study by Herskovitz had the power to detect only a large (49%) difference between number of improved patients in each group. Because of this low power and high attrition, we are unable to determine whether oral steroids lead to a statistically significant improvement in global outcome.

##### Return to Work

Neither study reported this outcome.

##### Return to Activities of Daily Living

Neither study reported this outcome.

##### Pain

Because the study by Chang did not report this outcome, only the effect of oral steroids can be considered. Herskovitz et al. reported that improvement in pain scores was significantly greater in the steroid group than the control (p = 0.07, 0.03 and 0.008 at 2, 4, and 8 weeks, respectively by t-test). Because the raw were not reported, no analysis is possible. Although the differences may be statistically significant, without information regarding their magnitude (effect size), we are unable to determine whether they are clinically significant. Further, the results of a single small trial are insufficient evidence for conclusions to be drawn.

##### Function

Neither study reported this outcome.

##### Quality of Life

Neither study reported this outcome.

##### Harms

Chang et al. reported the number of patients experiencing nausea and epigastric pain, while Herskovitz et al. reported the number experiencing any perceived effect. These results are presented in Table 91. In both studies, numbers of patients reporting side effects were not significantly different between treated groups and placebo groups by chi square test conducted by ECRI (p >0.3). However, there are too few studies to allow one to reach a firm evidence-based conclusion about the side effects experienced by patients with carpal tunnel syndrome who are given oral medications.

Table 91. Side effects of oral medications for carpal tunnel syndrome

Study | Group | Complication | Number of patients experiencing complication
Chang, et al., 1998 ^35^ | Placebo 16 | Nausea | 1
| | Epigastric pain | 2
| Diuretic 16 | Nausea | 0
| | Epigastric pain | 2
| NSAID 18 | Nausea | 3
| | Epigastric pain | 3
| Steroid 23(Prednisolone) | Nausea | 3
| | Epigastric pain | 2
Herskovitz, et al., 1995 ^455^ | Placebo 9 | Nausea/abdominal discomfort, constipation, insomnia, headache, dysuria, and burning nostrils | 3
| Prednisone 6 | Nausea/abdominal discomfort, constipation, dysgeusia, mild hypoglycemia | 3

#### Conclusions

Two double-blinded randomized controlled trials suggest that oral steroids may lead to a reduction in symptoms of CTS. A single published randomized controlled trial indicates that oral tenoxicam and trichlormethiazide do not reduce the symptoms of CTS under the dosing regimens described. The effects of oral steroids are short-lived and may not be sufficient for patient satisfaction. There are no published controlled trials describing the effects of higher doses or longer treatment regimens.

### What are the relative benefits and harms of oral and locally injected corticosteroids for persons with carpal tunnel syndrome?

A single randomized, double-blinded trial of 60 patients compared oral steroids with a single injection of steroid into the carpal tunnel. Patients in the steroid injection group received a single injection of 15mg methylprednisolone acetate directly into the carpal tunel and instructed to take placebo pills daily for 10 days. The oral steroid group received an injection of saline into the carpal tunnel, and took 25 mg of prednisolone daily for 10 days.

#### Internal Validity

Factors affecting internal validity are listed in Table 92. Although 14 patients had bilateral CTS, all results are reported per patient, rather than per effected hand. Therefore, there is no violation of the statistical assumption of independence. Whether patients with bilateral CTS received injections into both wrists was not reported. The effect of bilateral CTS on a patient's global symptom score (the only outcome measure reported) is not known. Patients with bilateral CTS may rate themselves as having more severe CTS than patients with only one arm affected. Bilateral patients were evenly distributed between groups by chi square test conducted by ECRI (p = 0.54). There was no patient attrition. Therefore, there was no violation of the intent-to-treat principle. However, the rate at which patients complied with instructions and took their oral medications was not reported.

Table 92. Internal validity of the study comparing oral and injected steroids

Study | Number of patients | Percent bilateral patients | Number of centers | Funded by a for-profit stakeholder? | Study design | Blinding | Total Patient Attrition (all patient groups) | Intent to treat analysis? | % Compliance
Wong, 2001 ^456^ | 60 | 23.3% | Single | Not Reported | RCT | Double | 0 | Yes | NR

#### Generalizability

Patient age and sex was consistent with the overall population of CTS patients as described in the introduction under Epidemiology. However, this study excluded patients with comorbidities, those with severe disease, and those with mild disease. These exclusions may limit the generalizability of the results of this study. Patient characteristics affecting generalizability are listed in Table 93.

Table 93. Generalizability of the study comparing oral and injected steroids for carpal tunnel syndrome

Study | Number of patients | Mean age and range | % Female | Mean Duration (Months) of condition and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Excluded severe disease? | Excluded mild disease?
Wong, 2001 ^456^ | 60 | 49 | 88.3% | NR | 0 | 0 | 0 | 0 | 0 | 0 | 0 | Yes | Yes

#### Results

##### Global Outcome

The outcome measure was global symptom score, the sum of ratings (0 to 10) of pain, numbness, paresthesia, weakness/clumsiness and nocturnal awakening. These scores are given in Table 94, and the results are summarized in Table 95. This outcome was statistically significantly different between groups at 8 weeks and 12 weeks. The difference between groups at two weeks was smaller than the study had the power to detect.

Table 94. Relative effect of steroid injection and oral steroids on global outcome of CTS

Study | Number of Patients | Global Symptom Score | Statistical Significance of Difference Between Groups
Wong, 2001 ^456^ | Injection 30 | | Groups were significantly different at 8 weeks and 12 weeks by t-test conducted by ECRI
| Pretreatment | 25.00±6.41
| 2 Weeks | 13.57±7.47
| 8 Weeks | 13.67±8.27
| 12 Weeks | 14.30±8.42
| Oral 30
| Pretreatment | 25.73±8.31 | p = 0.705
| 2 Weeks | 17.77±9.98 | p = 0.070
| 8 Weeks | 20.83±8.73 | p = 0.0019
| 12 Weeks | 21.40±9.64 | p = 0.0036

Table 95. Summary of the relative effect of steroid injection and oral steroids on global outcome of CTS

Study | Which Procedure led to Superior Global Outcome? | Was the Difference Statiscally Significant? | Power (Minimum percent difference detectable)^a^ | Effect Size (95% Confidence Interval)^a^
Wong, 2001 ^456^ | 2 Weeks: Injection | No | 21% | 0.47 (-0.09–1.03)
| 8 Weeks: Injection | Yes | 21% | 0.831. (0.25–1.41)
| 12 Weeks: Injection | Yes | 22% | 0.77 (0.20–1.35)

a : Calculated by ECRI

##### Return to Work

This study did not report this outcome.

##### Return to Activities of Daily Living

This study did not report this outcome.

##### Pain

This study did not report this outcome.

##### Function

This study did not report this outcome.

##### Quality of Life

This study did not report this outcome.

##### Harms

Harms reported among the two groups are given in Table 96. Steroid and placebo injection led to injection pain in two patients each. All other side effects were reported to have been experienced by the oral steroid group only. The difference in occurrence of side effects between groups was statistically significant by chi square test conducted by ECRI (p = 0.0195).

Table 96. Reported harms of injected and oral steroids

Study | Group | Complication | Number of patients experiencing complication
Wong, 2001 ^456^ | Injected 30 | Injection pain | 2
| | Increased appetite | 0
| | Bloating | 0
| | Insomnia | 0
| Oral 30 | Injection pain | 2
| | Increased appetite | 3
| | Bloating | 2
| | Insomnia | 2

#### Conclusions

Although only a single study, this study had high internal validity, providing evidence that, under the conditions of the experiment, steroid injection leads to greater reduction of symptoms with fewer side effects than oral steroid. The experiment is short-term (12 weeks) and does not address the issue of whether the effect of injection remains effective at longer time points. Further, it does not address whether continued treatment with oral steroids leads to further benefits or harms to the patient.

### What are the relative benefits and harms of physical therapy for persons with carpal tunnel syndrome?

Two randomized controlled trials describing 121 patients reported on the effects of various forms of physical therapy. Tal-Akabi and Rushton compared groups receiving nerve mobilization, groups receiving bone mobilization and a no-treatment control group. ^457^ Provinciali et al. compared a program of physical therapy including strengthening exercises, massage, gliding exercises and sensory re-training to instruction in a program of home-based strengthening exercises. ^427^

#### Internal Validity

The study by Provinciali was rater-blinded, while the other was unblinded. Trial characteristics affecting internal validity are listed in Table 97. Neither study had any reported attrition, and neither reported on patient compliance.

Table 97. Internal validity of studies of physical therapy for carpal tunnel syndrome

Study | Number of patients | Number of centers | Funded by a for-profit stakeholder? | Study design | Blinding | Total Patient Attrition (all patient groups) | Intent to treat analysis? | % Compliance
Provinciali, 2000 ^427^ | 100 | Single | Not reported | RCT | Rater | 0 | Yes | NR
Tal-Akabi, 2000 ^457^ | 21 | Not Reported | Not reported | RCT | No | 0 | Yes | NR

#### Generalizeability

In both studies, patients were predominantly middle-aged (mean 54.8 years) and female (67%-82%), as reported in Table 98. This is consistent with the overall population with CTS as described in the introduction under Epidemiology. Tal-Akabi excluded patients with comorbidities, while Provincialli did not report comorbidities. Both studies excluded patients with mild disease. This may limit generalizability, as patients with mild disease are more likely to receive noninvasive treatments such as physical therapy than patients with severe disease, who may be candidates for surgery. Neither study reported patient employment characteristics.

Table 98. Generalizability of studies of physical therapy for carpal tunnel syndrome

Study | Number of patients | Mean age and range | % Female | Mean Duration (Months) of condition and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Excluded severe disease? | Excluded mild disease?
Provincialli, 2000 ^427^ | 100 | 56.45 (24–86) | 82.0 | NR | NR | NR | NR | NR | NR | NR | NR | No | Yes
Tal-Akabi, 2000 ^457^ | 21 | 47.1 (29–85) | 66.6 | 27.6 (12–36) | 0 | 0 | 0 | 0 | 0 | 0 | NR | No | Yes

#### Results

##### Global Outcome

Global outcome was assessed in the study by Tal-Akabi and Rushton as the number of patients who did or did not go on to receive surgery after treatment. All patients had been drawn from a waiting list for surgery, which may eliminate factors such as economic status that might have influenced the patients' willingness to undergo surgery. Results are presented in Table 99, and summarized in Table 100. Outcomes of the two treated groups were not significantly different from each other (p = 0.51 by chi square test conducted by ECRI), but both the neurodynamic and carpal bone mobilization groups had significantly fewer patients going on to surgery than control (p = 0.03 and 0.008, respectively). Although differences between the treated groups and the control group were large enough to be statistically significant, the study lacks the statistical power required to demonstrate significant differences between-treatment groups. With only seven patients per group, a statistically significant effect can be detected only when there is at least a 50% difference between groups.

Table 99. Global outcome of physical therapy for carpal tunnel syndrome

Study | Number of Patients | Global Outcome | Statistical Significance of Difference Between Groups
Tal-Akabi and Rushton, 2000 ^457^ | | Global Score (Number of patients going on to receive surgery) | The two treated groups were not significantly different from each other (p = 0.51 by chi square test conducted by ECRI); both were significantly different from control (p = 0.03 and 0.008, respectively).
| Neurodynamic mobilization 7 | 2
| Carpal Bone mobilization 7 | 1
| No treatment (Control) 7 | 6

Table 100. Summary of Global outcome of physical therapy for carpal tunnel syndrome

Study | Which Procedure led to Superior Global Outcome? | Was the Difference Stastically Significant? | Power (Minimum percent difference detectable)^a^ | Effect Size (95% Confidence Interval)^a^
Tal-Akabi, 2000 ^457^ | Carpal bone mobilization | Yes | 50% | Neurodynamic mobilization
| | | | 1.40 (-0.08 – 2.87)
| | | | Carpal bone mobilization
| | | | 1.85 (0.20 – 3.50)
| | | | Difference between-treatment groups
| | | | 0.45 (-1.42–1.93)

a : Calculated by ECRI

##### Return to work

A single study reported time to return to work. Provincialli et al. reported that patients receiving physical therapy returned to work earlier than patients assigned to home exercise. ^427^ As can be seen in Table 101, the difference was statistically significant, but the number of patients for whom this measurement was taken was not reported. Further, it is unclear exactly what was measured. These numbers are described both as time to return to daily activities and time to return to work. These ambiguities render it difficult to draw conclusions from these data.

Table 101. Time to return to work after physical therapy for carpal tunnel syndrome

Study | Number of Patients | Days until Return to Activities of Daily Living | Statistical Significance of Difference Between Groups
Provincialli et al., 2000 ^427^ | Physical Therapy | 32.16±10.72 | Difference was statistically significant by ANOVA (p <0.006)
| Home Exercise | 42.55±13.39
| Number of patients is unknown because patients receiving workers' compensation were excluded. The number of such patients was not reported.

##### Return to Activities of Daily Living

This outcome was not reported by either study.

##### Pain

Both studies reported pain scores. Tal-Akabi and Rushton also reported pain relief scores. These data are given in Table 102. Provincialli et al. found no statistically significant difference between the program of physical therapy and home exercise instructions. Tal-Akabi and Rushton found that one treatment, carpal bone mobilization, but not the other treatment, neurodynamic modulation, led to pain scores statistically significantly lower than those in the control group (p = 0.003 and 0.35 respectively). The two treatment groups were not significantly different from each other (p = 0.18). The study lacked the statistical power to detect the difference between these groups. Only large between-group differences (>50%) could be detected in this study, as can be seen in Table 103. While the differences between carpal bone mobilization and control are large enough to be detected, other between-group differences are not. The fact that carpal bone mobilization led to a statistically significant effect while neurodynamic mobilization did not suggests, but does not prove, that carpal bone manipulation is the superior treatment for pain. Further study is necessary to test the differences between these therapies.

Table 102. Effects of nerve and bone mobilization on pain from carpal tunnel syndrome

Study | Number of Patients | Pain | Statistical Significance of Difference Between Groups
Provinciali, 2000 ^427^ | Physical Therapy 50 | Sum of patients' pain ratings (scale not reported) | Groups were not significantly different by chi square test (p >0.001; p-level required for significance adjusted by Provinciali using the Bonferroni correction related to 40 comparisons)
| Pretreatment | 149
| 1 Month | 55
| 2 Months | 50
| Home Exercise 50
| Pretreatment | 145
| 1 Month | 54
| 2 Months | 50
Tal-Akabi, 2000 ^457^ | | Pain (VAS, 0–10) | After treatment, the carpal bone mobilization group was significantly different from control by t-test conducted by ECRI (p = 0.003), but the neurodynamic mobilization group was not significantly different from control (p = 0.35) or from carpal bone mobilization (p = 0.18)
| Neurodynamic mobilization 7 | Baseline 2.42±1.51
| | 3 Weeks 1.57±1.4
| Carpal Bone mobilization 7 | Baseline 2.29±0.95
| | 3 Weeks 0.71±0.76
| No treatment (Control) 7 | Baseline 2.0±1.29
| | 3 Weeks 2.14±0.69
| Neurodynamic mobilization 7 | Pain Relief Rating 3.14±1.35 | Not significantly different between the two treated groups (p = 0.38), but both the neurodynamic mobilization group and the carpal bone mobilization group were significantly different from control (p = 0.00005 and 0.0000002, respectively)
| Carpal Bone mobilization 7 | 3.71±0.95
| No treatment (Control) 7 | 0±0

Table 103. Summary of effects of nerve and bone mobilization on pain from carpal tunnel syndrome

Study | Which Procedure led to Less Pain? | Was the Difference Stastically Significant? | Power (Minimum percent difference detectable)^a^ | Effect Size (95% Confidence Interval)^a^
Provinciali, 2000 ^427^ | No difference | No | Not calculable | Not calculable
Tal-Akabi, 2000 ^457^ | Carpal bone mobilization | Yes | | VAS
| | | Neurodynamic mobilization: 60% | Neurodynamic mobilization 0.48 (-0.62 – 1.58)
| | | Carpal bone mobilization: 54% | Carpal bone mobilization 1.84 (0.59 – 3.10)
| | | | Pain Relief Rating
| | | | Neurodynamic mobilization 3.08 (1.53 – 4.63)
| | | | Carpal bone mobilization 5.17 (2.99 – 7.35)

a : Calculated by ECRI

Although pain ratings in the VAS group were not significantly different from control after treatment, differences between pain relief scores were statistically significant. It is unclear which is the superior measure of pain.

#### Function

In the study by Provincialli, function was measured using a nine-hole peg test. Function scores were not significantly different between groups at any time point. ^427^ In the study by Tal-Akabi and Rushton, functional scores were based on the impairment rating of the patient's most impaired activity. ^457^ Thus, a lower score indicates superior function. These scores were not significantly different before treatment. Results are presented in Table 104. After treatment, functional scores in the carpal bone mobilization group were significantly lower than those of the control group (p = 0.01), while those of the neurodynamic mobilization group were not (p = 0.09). The two treatment groups were not significantly different from each other (p = 0.57). As presented in Table 105, the study only had the power to detect large (>50%) differences between groups. Only the difference between carpal bone mobilization and control was large enough to be found statistically significant.

Table 104. Effect of physical therapy on function

Study | Number of Patients | Function | Statistical Significance of Difference Between Groups
Provinciali et al. 2000, ^427^ | Physical Therapy 50 | Time (units not stated) to complete nine-hole peg test
| Pretreatment | 22.35±5.14 | Groups were not significantly different by t- test (p >0.001; p-level required for significance adjusted by Provinciali using the Bonnferoni correction related to 40 comparisons
| 12 Days | 23.8^a^
| 1 Month | 20.5
| 2 Months | 19.5
| Home Exercise 50
| Pretreatment | 22.38±3.23
| 12 Days | 20.5
| 1 Month | 20.5
| 2 Months | 19
Tal-Akabi and Rushton, 2000 ^457^ | | Function Score (Range 0–4) | After treatment, carpal bone mobilization group was significantly different from control group (p = 0.01) neurodynamic mobilization group was not (p = 0.09). The two treatment groups were not significantly different from each other (p = 0.57). t-tests conducted by ECRI.
| Neurodynamic mobilization 7 | Baseline 2.0±1.41
| | 3 Weeks 1.14±1.35
| Carpal Bone mobilization 7 | Baseline 2.0±1.41
| | 3 Weeks 0.71±0.76
| No treatment (Control) 7 | Baseline 2.42±1.27
| | 3 Weeks 2.42±1.27

a : Estimated by ECRI from a published chart

Table 105. Summary of the effect of physical therapy on function

Study | Which Procedure led to Superior Function? | Was the Difference Stastically Significant? | Power (Minimum percent difference detectable)^a^ | Effect Size (95% Confidence Interval)^a^
Provinciali, 2000 ^427^ | No difference | No | Not calculable | Not calculable
Tal-Akabi, 2000 ^457^ | Carpal bone mobilization | Yes | Neurodynamic mobilization 63% | Neurodynamic mobilization 0.91 (-0.21 – 2.19)
| | | Carpal bone mobilization 50% | Carpal bone mobilization 1.53 (0.34 – 2.72)

a : Calculated by ECRI

##### Quality of Life

This outcome was not reported by either study.

##### Harms

No harms were reported by either study.

#### Conclusions

Manual therapy may have some use in the treatment of carpal tunnel syndrome. A single study suggests that carpal bone mobilization provides pain relief, improves function, and delays or eliminates the need for surgery among patients with carpal tunnel syndrome. ^457^ Results from neurodynamic mobilization show a similar trend, but because of a lack of statistical power one cannot conclude that this trend is real. For the same reason, differences in effectiveness between these two treatment groups cannot be determined. The study was not placebo-controlled and was not blinded. The observed effects may have been influenced by a placebo effect or rater bias.

A larger, more statistically powerful study found no difference between the effects of a physical therapy program and home exercise instructions on pain or function. However, patients receiving physical therapy returned to work faster than those instructed to exercise at home.

Although these studies indicate a trend toward physical therapy having an effect on carpal tunnel syndrome, they are too small and inconclusive for one to reach a firm evidence-based conclusion.

### What are the relative benefits and harms of ultrasound for persons with carpal tunnel syndrome?

One patient-blinded randomized controlled trial describing 18 patients reported on the effects of ultrasound. ^33^ This study compared two different levels of intensity of ultrasound to placebo.

#### Internal Validity

Factors affecting the internal validity of this study are listed in Table 106. The data are reported in terms of the number of hands, rather than number of patients, and among the 18 patients, 30 hands were treated. This violates statistical assumptions of independence.

Table 106. Internal validity of the study of ultrasound for carpal tunnel syndrome

Study | Number of patients | Percent bilateral patients | Number of centers | Funded by a for-profit stakeholder? | Study design | Blinding | Total Patient Attrition (all patient groups) | Intent to treat analysis? | % Compliance
Oztas, 1998 ^33^ | 18 | 66.7% | Single | No | RCT | Patient | 0 | Yes | NR

#### Generalizability

As can be seen in Table 107, the 18 patients were middle-aged (range 37–66), and all were female. Patients with comorbidities were excluded, as were patients with very mild or severe CTS. These exclusions may limit the generalizability of the trial's results, especially given the fact that only a single trial has been published.

Table 107. Generalizability of the study of ultrasound for carpal tunnel syndrome

Study | Number of patients | Mean age and range | % Female | Mean Duration (Months) of condition and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Excluded severe disease? | Excluded mild disease?
Oztas, 1998 ^33^ | 18 | 51.6 (37–66) | 100 | 84 (6–240) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | Yes | Yes

#### Results

Because this is a single trial describing only two outcomes, we discuss the results together. Return to work, return to ADLs, function, quality of life and harms were not described. The results of the trial are presented in Table 108 and summarized in Table 109. There were no differences between groups. Moreover, the sham-treated group showed a statistically significant effect of treatment for both pain and global outcome. ^33^ This may indicate that some patients were incorrectly diagnosed, that patients were receiving additional treatments that were exerting an effect, or they were experiencing a placebo effect.

Table 108. Effects of ultrasound on carpal tunnel syndrome

Study | Number of Hands^a^ | Outcome | Statistical Significance of Difference Between Groups
Oztas, et al., 1998 ^33^ | | Pain (VAS, 0–10)
| 1.5 W/cm^2^ 10 | Baseline 6.10±2.50 | All posttreatment scores were significantly different from baseline (p <0.05, t-test). There were no significant differences between groups (p >0.05, 1-way ANOVA).
| | Posttreatment^2^ 2.90±1.69
| 0.8 W/cm^2^ 10 | Baseline 7.10±2.38
| | Posttreatment 3.60±1.90
| 0 W/cm^2^ (Placebo) 10 | Baseline 7.90±1.80
| | Posttreatment 4.00±2.40
| | Global Outcome (Mean of a categorical symptom rating, 0–3 scale)
| 1.5 W/cm^2^ 10 | Baseline 2.30±0.68
| | Posttreatment 1.40±0.52
| 0.8 W/cm^2^ 10 | Baseline 2.60±0.70
| | Posttreatment 1.70±0.82
| 0 W/cm^2^ (Placebo) 10 | Baseline 2.60±0.69
| | Posttreatment 1.40±0.97

a : Eighteen patients with a total of 30 affected hands were treated.

b : Followup time was five days after two weeks of treatment

Table 109. Summary of effects of ultrasound on carpal tunnel syndrome

Study | Which Procedure led to Superior Outcome? | Was the Difference Stastically Significant? | Power (Minimum percent difference detectable)^a^ | Effect Size (95% Confidence Interval)^a^
Oztas, 1998 ^33^ | No differences | No | Pain | Pain
| | | | 1.5 W/cm^2^ 0.51 (-0.38 – 1.40)
| | | 49%
| | | | 0.8 W/cm^2^ 0.18 (-0.70 – 1.06)
| | | Global Outcome | Global Outcome
| | | | 1.5 W/cm^2^ 0 (-0.88 – 0.88)
| | | 52%
| | | | 0.8 W/cm^2^ -0.32 (-1.20 – 0.56)

a : Calculated by ECRI

Pain scores, but not global outcome ratings, were lower in the group treated with 1.5 W/cm^2^ ultrasound than in the control group. However, the difference was not statistically significant. The study had the statistical power to detect only large (49–52%) differences between groups. It is unknown whether a more powerful study would have found the difference between groups to be statistically significant.

Interpretation of these results is further complicated by the fact that VAS scores were higher in the placebo-treated group prior to treatment than in either of the treated groups. This may indicate that the randomization procedure in this study was ineffective. The decrease in both VAS and global symptom score after treatment was also greater among placebo-treated hands than among hands receiving ultrasound. This may have been simply because the higher initial scores allowed greater room for improvement, or the improvement may have been the result of regression to the mean.

#### Conclusions

Only one study meeting inclusion criteria addresses the use of ultrasound for carpal tunnel syndrome. Because of this, and because its design and analysis difficulties, one cannot reach a firm evidence-based conclusion.

### What are the relative benefits and harms of full-time and nighttime-only splint use for persons with carpal tunnel syndrome?

A single unblinded randomized trial of 21 patients compared the effects of nighttime-only and full-time splint use. ^34^

#### Internal Validity

Study characteristics related to internal validity are presented in Table 110. This study reported a 20% loss to followup. Of those patients who returned for followup, there was considerable noncompliance. Only 85% of the nighttime-only group reported complete or nearly complete nighttime splint use. Twenty-three percent of this group also reported some daytime use, despite instructions to wear the splint only at night. Complete or nearly-complete daytime use was reported by only 27% of patients instructed to wear the splints full-time. Nearly 43% of the patients had bilateral CTS, and results were reported per hand rather than per patient. This, combined with the loss to followup and noncompliance issues, raises serious doubts as to the reliability of the results of this study.

Table 110. Internal validity of the study of full-time and nighttime-only splint use for carpal tunnel syndrome

Study | Number of patients | Percent of bilateral patients | Number of centers | Funded by a for-profit stakeholder? | Study design | Blinding | Total Patient Attrition (all patient groups) | Intent to treat analysis? | % Compliance
Walker, 2000 ^34^ | 21 | 42.9% | Single | Not reported | RCT | No | 4 | No | 14

#### Generalizability

Patients were middle age (mean 60 years) and predominantly male. This distinguishes them from the majority of CTS patients, who are usually female. Patient characteristics are listed in Table 111. No information about comorbidities or employment characteristics was reported, except that 57.1% of patients were employed (Table 112).

Table 111. Generalizability of the study of full-time and nighttime-only splint use for carpal tunnel syndrome

Study | Number of patients | Mean age and range | % Female | Mean Duration (Months) of condition and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Excluded severe disease? | Excluded mild disease?
Walker, 2000 ^34^ | 21 | 60 | 3.0 | 28.5 | NR | NR | NR | NR | NR | NR | NR | No | Yes

Table 112. Patient employment characteristics in the study of full-time and nighttime-only splint use for carpal tunnel syndrome

Study | Number of patients | % Patients employed | % Patients receiving workers' compensation | % Patients retired | % Patients Homemakers | Reported occupations
Walker, 2000 ^34^ | 21 | 57.1 | Not reported | Not reported | Not reported | Not reported

#### Results

Because there is only a single study reporting two outcomes, we discuss the results together. No results were described for return to work, return to ADLs, pain, quality of life or harms. Reported results can be found in Table 113. There were no statistically significant differences between groups in global outcome or functional ability, as can be seen in Table 114. However, the study lacked the statistical power to detect small differences between groups. Only medium (28%-33%) or larger differences would have been statistically significant.

Table 113. Results of comparison between full-time and part-time splint wear for carpal tunnel syndrome

Study | Number of Hands | Outcome | Statistical Significance of Difference Between Groups
Walker et al., 2000 ^34^ | | Global outcome (Symptom severity) | Change from pre to post was not significantly different between groups by t-test. p-values were not reported.
| Nighttime-only 13
| Pretest | 2.89±0.96
| Posttest | 2.30±0.93
| Full-time 11
| Pretest | 2.79±0.69
| Posttest | 2.09±0.62
| | Functional (Levine) score | Change from pre to post was not significantly different between groups by t-test. p-values were not reported.
| Nighttime-only 13
| Pretest | 2.75±1.01
| Posttest | 2.14±0.87
| Full-time 11
| Pretest | 2.27±1.03
| Posttest | 1.93±0.77

Table 114. Summary of comparison between full-time and part-time splint wear for carpal tunnel syndrome

Study | Which Procedure led to Superior Outcome? | Was the Difference Stastically Significant? | Power (Minimum percent difference detectable)^a^ | Effect Size (95% Confidence Interval)^a^
Walker et al., 2000 ^34^ | Full-time use | No | Global outcome 29% | Global outcome 0.25 (-0.55 – 1.06)
| | | Functional (Levine) score 33% | Functional (Levine) score 0.25 (-0.56 – 1.05)

a : Calculated by ECRI

#### Conclusions

Splint use was addressed only by a single trial that had design difficulties. Because of this, one cannot reach an evidence-based conclusion about splint use.

### What are the relative benefits and harms of open carpal tunnel release with ligament reconstruction for persons with carpal tunnel syndrome?

One non-blinded, retrospective controlled trial reported on the effects of ligament lengthening or reconstruction. ^48^

#### Internal Validity

The study did not include patients with bilateral CTS, meaning that there were no violations of the assumption of statistical independence. There was no attrition. Therefore intent-to-treat principles were followed. Study characteristics related to internal validity are listed in Table 115.

Table 115. Internal validity of studies of open carpal tunnel release with and without ligament reconstruction

Study | Number of patients | Percent of bilateral patients | Number of centers | Funded by a for-profit stakeholder? | Study design | Blinding | Total Patient Attrition (all patient groups) | Intent to treat analysis?
Karlsson, 1997 ^48^ | 74 | 0% | Single | Not reported | Retro | No | 0 | Yes

#### Generalizability

Patients were predominantly female and the reported range of ages (24–88 years) is broadly similar to that of the overall CTS population. The trial did not describe patient comorbidities or employment characteristics. ^48^ Patient characteristics are presented in Table 116.

Table 116. Generalizability of studies of open carpal tunnel release with and without ligament reconstruction

Study | Number of patients | Mean age and range | % Female | Mean Duration (Months) of condition and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Excluded severe disease? | Excluded mild disease?
Karlsson, 1997 ^48^ | 74 | NR; (24–88) | 59.6 | [Median) 6 (1–60) | NR | NR | NR | NR | NR | NR | NR | No | No

#### Results

Time to return to work among patients treated with open release or ligament reconstruction is reported in Table 117. No other patient-oriented outcomes were reported.

Table 117. Effect of ligament reconstruction on time to return to work

Study | Number of Patients | Weeks until Return to Work | Statistical Significance of Difference Between Groups
Karlsson et al., 1997 ^48^ | Open release 50 | 4.5 (Range 1–12) | Groups were significantly different (p <0.01, t-test.).
| Release and reconstruction 24 | 6.0 (Range 3–24)

Patients who received ligament reconstruction were statistically significantly slower to return to work than those who received open release without ligament reconstruction. The effect size was statistically significantly different from zero (d = 0.65, 95% C.I. = 0.15 – 1.15).

#### Conclusions

The results of one study suggest that suboptimal outcomes are obtained when patients receive ligament reconstruction. However, this trial was neither randomized nor blinded, so one cannot draw firm evidence-based conclusions from it.

### What are the relative benefits and harms of open carpal tunnel release with early or late mobilization for persons with carpal tunnel syndrome?

Three prospective, randomized controlled trials describing 171 patients compared early and late mobilization (removal of cast or splint) after open carpal tunnel release.

#### Internal Validity

None of these trials were blinded. Study characteristics related to internal validity are presented in Table 118. Only one study had patient attrition, and two reported results of bilateral patients as per hand rather than per patient. One study had a high (92.7%) rate of compliance, while the other two did not report compliance.

Table 118. Internal validity of studies of splinting after carpal tunnel release

Study | Number of patients | Percent bilateral patients | Number of centers | Funded by a for-profit stakeholder? | Study design | Blinding | Total Patient Attrition (all patient groups) | Intent to treat analysis? | % Compliance
Finsen, 1999 ^319^ | 74 | 10.8% | Single | Not reported | RCT | No | 0 | Yes | 92.7
Bury, 1995 ^364^ | 47 | 7.5% | Single | Not reported | RCT | No | 7 | No | NR
Cook, 1995 ^432^ | 50 | 0% | Single | Not reported | RCT | No | 0 | Yes | NA

#### Generalizability

Patient characteristics are reported in Table 119. The studies by Finsen and Bury included predominantly female, middle-aged patients, while Cook did not report these characteristics. The studies differed in their inclusion/exclusion criteria, with Bury et al excluding patients with mild carpal tunnel syndrome, ^458^ Cook et al. excluding both the most mild and the most severe cases, ^432^ and Finsen et al. not excluding according to severity. ^319^ Finsen and Cook excluded patients with comorbidities, while Bury included patients with other nerve impingement conditions. These differences may make it less valid to compare or combine the results of these studies.

Table 119. Generalizability of studies of splinting after carpal tunnel release

Study | Number of patients | Mean age and range | % Female | Mean Duration (Months) of condition and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Excluded severe disease? | Excluded mild disease?
Finsen, 1999 ^319^ | 74 | 54.7 (21–86) | 81.1 | NR | 0 | 0 | 0 | 0 | 0 | 0 | 0 | No | No
Bury, 1995 ^364^ | 47 | 41.4 (19–79) | 83.0 | 13 (5–36) | NR | NR | NR | 7 | NR | NR | NR | No | Yes
Cook, 1995 ^432^ | 50 | NR | NR | NR | 0 | NR | 0 | NR | 0 | 0 | 0 | Yes | Yes

Employment characteristics were under-reported in all three studies, as can be seen in Table 120.

Table 120. Patient employment characteristics in studies of splinting after carpal tunnel release

Study | Number of patients | % Patients employed | % Patients receiving workers' compensation | % Patients retired | % Patients Homemakers | Reported occupations
Finsen, 1999 ^319^ | 74 | 63.5 | Not reported | Not reported | Not reported | Not reported
Bury, 1995 ^364^ | 47 | Not reported | Not reported | Not reported | Not reported | Not reported
Cook, 1995 ^432^ | 50 | Not reported | 16.0 | Not reported | Not reported | Not reported

#### Results

##### Global Outcome

Effects of splinting after surgery on global outcome can be seen in Table 121. In the study by Bury et al., the number of patients said to be cured does not equal the number said to be symptom-free. ^364^ The reason for this discrepancy is not clear. Results are summarized in Table 122 and Figure 41. Both Bury and Cook found that superior global outcomes were obtained in the absence of splinting, with the difference statistically significant only in the study by Cook.

Table 121. Effect of splinting after surgery on global outcome

Study | Number of Patients | Global Outcome | Statistical Significance of Difference Between Groups
Bury et al., 1995 ^364^ | | Global score (Scale not reported) | Not reported
| No splint 17 | 8.0
| 2 week splint 26 | 8.1
| | Number of patients symptom-free | Not significantly different by chi square test conducted by ECRI, p = 0.85.
| No splint 17 | 9
| 2 week splint 26 | 13
| | Categorical rating | Not significantly different by chi square test conducted by ECRI, p = 0.68.
| No splint 17 | Cured: 8
| | Improved: 9 | Not significantly different when data is collapsed into a dichotomous outcome (number cured or improved) by chi square test conducted by ECRI, p = 0.15
| | Unchanged: 0
| | Worse: 0
| 2 week splint 26 | Cured: 12
| | Improved: 11
| | Unchanged: 1
| | Worse: 2
Cook et al., 1995 ^432^ | | 14 Days:
| No splint 25 | Excellent 9
| | Good 9
| | Fair 7 | Significantly different by chi square test conducted by ECRI, p = 0.018.
| 2 week splint 25 | Excellent 1
| | Good 14
| | Fair 10
| | 1 Month:
| No splint 25 | Excellent 12 | Significantly different by Chi square test conducted by ECRI, p = 0.007.
| | Good 10
| | Fair 3
| 2 week splint 25 | Excellent 2
| | Good 18
| | Fair 5

Table 122. Summary of effect of splinting after surgery on global outcome

Study | Which Procedure led to Superior Global Outcome? | Was the Difference Stastically Significant? | Power (Minimum percent difference detectable)^a^ | Effect Size (95% Confidence Interval)^a^
Bury, 1995 ^364^ | No Splint | No | Number symptom-free 28% | Number symptom-free 0.06 (-0.61 – 0.72)
| | | Categorical rating^b^ 29% | Categorical rating^b^ 0.89 (-0.78–2.56)
Cook, 1995 ^432^ | No Splint | Yes | Not calculable | 14 Days 0.38 (-0.18–0.94)
| | | | 1 Month 0.86 (0.28–1.44)

a : Calculated by ECRI

b : Calculated by ECRI by collapsing the categorical rating into a dichotomous one: number cured or improved.

Figure 41. Effect of splinting after surgery on global outcome

##### Return to work

All three trials reported on return to work. These results are presented in Table 123. As can be seen in Table 124 and Figure 42, two studies show a trend toward favoring no splint, with the difference becoming statistically significant in the study by Cook. In contrast, the study by Finsen shows no difference between groups.

Table 123. Effect of splinting after surgery on return to work

Study | Number of Patients | Return to work | Statistical Significance of Difference Between Groups
Finsen, 1999 ^319^ | | Median time to return to work | Not reported
| No splint 28 | 6 Weeks (95% CI 5–6 Weeks)
| 4 week splint 19 | 6 Weeks (95% CI 4–7 Weeks)
Bury, 1995 ^364^ | | Number^a^ of patients who had not returned to work at last followup (Mean 5.7 Months) | Not significantly different by chi-square test conducted by ECRI, p = 0.23
| No splint 17 | 2
| 2 week splint 26 | 7
Cook, 1995 ^432^ | | Time to return to work | Significantly different by t-test (Light duty p = 0.01; Full duty p = 0.005)
| No splint 25 | Light duty: 15 Days
| | Full duty: 17 Days
| 2 week splint 25 | Light duty: 24 Days
| | Full duty: 27 Days

a : Calculated by ECRI from a published percentage

Table 124. Summary of effect of splinting after surgery on return to work

Study | Which Procedure led to Superior Outcome? | Was the Difference Stastically Significant? | Power (Minimum percent difference detectable)^a^ | Effect Size (95% Confidence Interval)^a^
Finsen, 1999 ^319^ | No difference | No | Not calculable | Not calculable
Bury, 1995 ^364^ | No Splint | No | 24% | 0.55 (-0.39 – 1.49)
Cook, 1995 ^432^ | No Splint | Yes | Not calculable | Light duty: 0.75 (0.17 – 1.32)
| | | | Full duty: 0.82 (0.24–1.40)

Figure 42. Effect of splinting after carpal tunnel surgery on return to work

##### Return to Activities of Daily Living

One study of 50 patients reported on time to return to activities of daily living. The results are presented in Table 125. These results show a statistically significant advantage to not splinting. ^432^ The effect size is significantly different from zero (d = 1.06, 95%C.I. 0.47 – 1.65).

Table 125. Effect of splinting after surgery on time to return to activities of daily living

Study | Number of Patients | Return to Activities of Daily Living | Statistical Significance of Difference Between Groups
Cook, 1995 ^432^ | | Time to return to activities of daily living | Significantly different by t-test, p = 0.0004.
| No splint 25 | 6 Days
| 2 week splint 25 | 12 Days

##### Pain

Two studies reported on pain. The results are presented in Table 126. Finsen et al. found no statistically significant differences between groups. ^319^ Cook et al. found statistically significant differences between groups at 2 weeks and 4 weeks. These differences were stated to be no longer significant at 3 and 6 months, but no data were reported. In this study, it is unclear whether the pain described after treatment is pain from carpal tunnel syndrome, pain resulting from surgery, or both. As can be seen in Table 127 and Figure 43, the results of the two studies show opposite trends, and as noted above, it is unclear whether the patients in these two studies are comparable.

Table 126. Effect of splinting after surgery on pain

Study | Number of Patients | Pain | Statistical Significance of Difference Between Groups
Finsen, et al., 1999 ^319^ | | Median VAS (0–100) | Not significantly different (p >0.05; test not reported)
| No splint 45
| Preop | 56 (Range 46–65)
| 2 Weeks | 6 (Range 4–17)
| 6 Months | 3 (Range 2–8)
| 4 week splint 37
| Preop | 51 (Range 38–57)
| 2 Weeks | 5 (Range 2–11)
| 6 Months | 2 (Range 0–4)
Cook et al., 1995 ^432^ | | Verbal Scale (1–10) | Significantly different at both time points (p = 0.001 and 0.01 respectively by t-test)
| No splint 25
| 14 Days | 0.9
| 1 Month | 0.5
| 2 week slpint 25
| 14 Days | 2.4
| 1 Month | 1.5

Table 127. Summary of effect of splinting after surgery on pain

Study | Which Procedure led to Superior Outcome? | Was the Difference Stastically Significant? | Power (Minimum percent difference detectable)^a^ | Effect Size (95% Confidence Interval)^a^
Finsen, et al., 1999 ^319^ | Splinting | No | Not calculable | Not calculable
Cook et al., 1995 ^432^ | No Splint | Yes | Not calculable | 14 Days: 0.98 (0.39 – 1.56)
| | | | 1 Month: 0.75 (0.17 – 1.32)

a : Calculated by ECRI

Figure 43. Summary of effect of splinting after surgery on pain

##### Harms

All three studies reported harms, but as listed in Table 128, none reported the same harms. Although all reported harms occurred in the unsplinted group, both the numbers of patients and the numbers of harms are too small to demonstrate significant differences between groups. No evidence-based conclusions can be drawn as to whether splinting after surgery prevents complications.

Table 128. Reported harms in studies of splinting after carpal tunnel surgery

Study | Patients per group | Complication | Number reporting
Finsen, 1999 ^319^ | No splint 45 | Superficial Hematoma | 1
| | Wound discharge | 1
| 2 Week splint 36 | Superficial Hematoma | 0
| | Wound discharge | 0
Bury, 1995 ^364^ | No splint 17 | Persistent symptoms requiring reoperation | 1
| 2 week splint 26 | Persistent symptoms requiring reoperation | 0
Cook, 1995 ^432^ | No splint 25 | Reported that there were no wound complications or bowstringing tendons | 0
| 2 week splint 25

#### Conclusions

The three studies examining whether there was an advantage to splinting after carpal tunnel surgery have yielded fairly consistent results within each study. Cook, et al found a statistically significant advantage to not splinting for reduced pain, faster return to work and daily activities, and superior global outcome. ^432^ Bury also found that not splinting led to better global outcome and faster return to work, but neither of these effects was statistically significant. ^364^ This study lacked the statistical power to detect small (<20%) differences between groups. In contrast, Finsen et al. found a small and statistically nonsignificant trend advantage for the effect of splinting on pain, while times to return to work were the same for both groups. The reasons for the differences between studies is not readily apparent from an examination of the study or patient characteristics. There may be conditions under which splints offer an advantage and conditions under which they do not. Further studies are necessary before a conclusion may be reached.

### What are the relative benefits and harms of vitamin B therapy for persons with carpal tunnel syndrome?

One trial of 17 patients examining the effect of vitamin B_6_ therapy on carpal tunnel syndrome met exclusion criteria. ^459^

#### Internal Validity

This was a small (n = 15) randomized controlled trial. There was 13% attrition, and compliance was not reported. Study characteristics affecting internal validity are listed in Table 129.

Table 129. Internal validity of studies of vitamin B therapy for carpal tunnel syndrome

Study | Number of patients | Number of centers | Funded by a for-profit stakeholder? | Study design | Blinding | Total Patient Attrition (all patient groups) | Intent to treat analysis? | % Compliance
Stransky, 1989 ^459^ | 15 | Single | Not reported | RCT | Double | 2 | No | NR

#### Generalizability

This study did not report patient characteristics except that patients with mild disease were excluded, so no discussion of its generalizability is possible.

#### Results

This trial reported a single patient-oriented outcome (global outcome expressed as number of patients improved after treatment). A summary of the effect of vitamin B_6_ therapy in this study is shown in Table 131. There was no statistically significant difference in percent of patients improved between-treatment groups. This study had few patients and very low power. Only large (46–48%) differences between groups were would have been statistically significant.

Table 130. Generalizability of studies of vitamin B therapy for carpal tunnel syndrome

Study | Number of patients | Mean age and range | % Female | Mean Duration (Months) of condition and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Excluded severe disease? | Excluded mild disease?
Stransky, 1989 ^459^ | 15 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | No | Yes

Table 132. Summary of effect of vitamin B therapy on symptoms of carpal tunnel syndrome

Study | Which Treatment led to Superior Global Outcome? | Was the Difference Stastically Significant? | Power (Minimum percent difference detectable)^a^ | Effect Size (95% Confidence Interval)^a^
Stransky et al. 1989 ^459^ | Placebo | No | Vitamine vs. Placebo 46% | Vitamine vs. Placebo -0.55 (-1.86 – 0.75)
| | | Vitamine vs. No treatment 48% | Vitamine vs. No treatment -0.42 (-1.76 – 0.91)

a : Calculated by ECRI

Table 131. Global outcome in patients treated with vitamin B therapy

Study | N (units) | Global outcome - number (%) patients improved | Statistical significance of difference between groups
Stransky et al. 1989 ^459^ | Vitamin B_6_ 6 | 3 (50) | Vitamin B_6_ was not significantly different from placebo or control by chi-square test conducted by ECRI (p = 0.30 and 0.42, respectively)
| Placebo 5 | 4 (80)
| Untreated Control 4 | 3 (75)

#### Conclusions

Although the low power of the study prevents any solid conclusion from being drawn, the trend toward a greater percentage of improved patients in the placebo group does not support the therapeutic effectiveness of Vitamin B_6_.

### Question #4: Is there a relationship between specific clinical findings and specific treatment outcomes among patients with carpal tunnel syndrome?

In addressing this question, we consider whether published literature suggests that there are clinical findings that predict positive or negative outcomes after treatment for carpal tunnel syndrome. The studies we considered all attempted to identify predictors by using regression techniques or by comparing outcomes in different groups of patients with different pre-treatment clinical findings.

#### Excluded studies

As discussed in the Methods section, we retrieved articles identified by our literature searches according to certain a priori criteria. However, not all of the retrieved studies met our more specific inclusion criteria for this question. These latter studies, and the reason we did not consider them for this question are shown in Table 133.

Table 133. Excluded studies

Author | Reason for exclusion
Walker (2000) ^34^ | Stratified study that did not examine any correlations that were also examined by at least two other studies
Hasegawa (1999) ^34^ | Stratified study that did not examine any correlations that were also examined by at least two other studies
Olney (1999) ^323^ | Stratified study that did not examine any correlations that were also examined by at least two other studies
Rosen (1997) ^343^ | Stratified study that did not examine any correlations that were also examined by at least two other studies
LoMonaco (1996) ^358^ | Stratified study that did not examine any correlations that were also examined by at least two other studies
Padua (1996) ^358^ | Stratified study that did not examine any correlations that were also examined by at least two other studies
Wintman (1996) ^362^ | Stratified study with no clinical finding/outcome comparisons reported by at least three studies
Chang and Dellon (1993) ^389^ | Stratified study that did not examine any correlations that were also examined by at least two other studies

#### Evidence base

After these exclusions, there remained 12 studies with a total of 1723 patients.

#### Study quality

The evaluation of the quality of literature for this question differs from quality evaluations of studies of treatments. This is because, for the present question, the RCT is not necessarily the “gold standard”. Case series data, if appropriately analyzed, can also yield valid information. Consequently, the method of data analysis plays a prominent role when considering the quality of the studies relevant to this question.

One valid way to analyze these data is to use multiple regression techniques. These techniques allow construction of a regression equation (or model) consisting of one or more predictor variables. The advantage of multiple regression is that the predictive ability of any given variable is adjusted for any other predictor variables in the equation.

Another valid way to analyze these data involves stratifying patients along some clinical variable. For example, in a stratified study one might compare the outcomes of patients with severe disease to those with mild disease. In a stratified study, the predictive ability of the variable of interest is not adjusted for any other predictor variables. Therefore, the magnitude of a variable's ability to predict future outcomes may be misestimated in stratified studies. For this reason, one can consider the results of stratified studies to be somewhat less reliable than those studies that employed regression techniques. However, an important advantage of stratified studies is that studies that have stratified patients into two groups have more statistical power than studies that used regression analysis.

Another aspect of study quality pertinent to the present question is whether the study was performed prospectively or retrospectively. Patients in retrospective studies may not be representative of the population of patients with carpal tunnel syndrome. This means that the generalizability of the results of retrospective studies is unknown. It also means that the patients in retrospective studies may be more homogeneous than the population of patients with carpal tunnel syndrome. If this were the case, then the magnitude of a clinical finding's ability to predict future outcome would be misestimated. In the extreme case, the artificial homogeneity of patients in a retrospective study could lead to “range restriction”. This, in turn, could lead to the inability to detect important predictors of outcome. For these reasons, one can consider the results of prospective studies as stronger than those of retrospective studies.

Table 134 shows relevant quality characteristics of studies that met the inclusion criteria for this question.

Table 134. Study quality

Author/year | Prospective? | Methods used to identify predictor variables
Finsen and Russwurm (2001) ^224^ | Yes | Stratification
Shin (2000) ^460^ | No | Multiple logistic regression
Straub (1999) ^305^ | Yes | Stratification
Atroshi (1998) ^461^ | Yes | Multiple linear regression
Choi and Ahn (1998) ^329^ | No | Stratification
Katz (1998) ^462^ | Yes | Multiple logistic regression
Higgs (1997) ^341^ | No | Stratification
Glowacki (1996) ^352^ | No | Stratification
Jacobsen and Rahme (1996) ^353^ | Yes | Multiple regression^a^
Al-Qattan (1994) ^375^ | No | Stratification
Nathan (1993) ^395^ | Partly^b^ | Multiple regression
Yu (1992) ^403^ | No | Stratification

a Independent analysis of individual patient data conducted by ECRI

b Patients entering the study after a certain date were studied prospectively; patients who had treatment prior to that date were studies retrospectively.

#### Results

Table 135 shows the relationship of specific clinical findings to treatment outcomes in those studies that used regression to identify predictor variables. In the table, clinical variables are indicated by boldface type. There are five such studies with a total of 932 patients. Also presented in this table are non-clinical variables (e.g. age, gender) to show all of the variables used in each multiple regression.

Table 135. Relationship between specific clinical findings and treatment outcomes among patients with Carpal Tunnel Syndrome (Multiple regression analysis)

Author | N | Treatment | Outcomes | Variables examined by at least two studies (significant correlation with outcome?) | | | | | | | | | Unique study variables
| | | | Age | Gender | Treatment | Hand dominance | Insurance type | Employment status | Two-point discrimination^d^ | Electrodiagnostic test | Grip strength
Shin (2000) ^460^ | 210 | Conservative treatments | Odds of obtaining employment disability | NS | NS | NS | - | - | - | - | Sig | - | Mechanism of injury (NS)
| | Surgery^a^
Atroshi (1998) ^461^ | 140 | Surgery^b^ | Global outcome (patient dissatisfaction) | Sig | NS | - | NS | - | NS | NS | Sig | NS | Vibration exposure (sig), ADL score (NS), thenar atrophy (NS), pinch strength (NS), tinel sign (NS), phalen sign (NS)
Katz (1998) ^462^ | 315 | Surgery and conservative treatments (not described) | Work absence (18 months after treatment) | NS | NS | NS | - | NS^e^ | NS | - | - | NS | Occupation (NS), baseline function (sig), function at 6 months (sig), hired attorney (sig), work absence at enrollment (NS), work absence at 6 months (sig), mental health status (NS), physical and clerical self-reported exposure scales
Jacobsen and Rahme (1996) ^353^ | 29 (32 hands) | Surgery^c^ | Number of sick days after surgery | NS | NS | NS | NS | - | - | NS | Sig | - | None
Nathan (1993) ^395^ | 238 | Surgery^a^ | Return to work | NS | NS | - | NS | Sig | NS | - | NS | - | Laterality (NS), year of study (NS), referral source (NS), incision length (NS), occupational hand use (NS), diabetes (NS), rheumatoid arthritis (NS), number and density of hand therapy sessions/ week (NS)

a Open release

b Unilateral endoscopic release

c Open and endoscopic release

d Variables in boldface represent clinical findings

d In a related publication, surgical patients alone were analyzed and insurance type significantly correlated with work absence 6 months post-surgery. ^302^

NS - Not significant

No study that employed regression analysis reported statistically significant correlations between two-point discrimination or grip strength and any outcomes. However, three out of four studies that examined the “predictability” of electrodiagnostic tests reported statistically significant correlations between electrodiagnostic test results and various outcomes. Two of the studies that found a statistically significant relationship were prospective.

The outcomes predicted by electrodiagnostic test results in the three “significant” studies were odds of obtaining disability payment, patient satisfaction with surgery, and number of sick leave days. Odds of obtaining disability payment were higher in patients diagnosed with CTS (mild, moderate, or severe) compared to those with normal electrodiagnostic findings. ^460^ Another study found patient satisfaction with surgery was lower among patients with a better electrodiagnostic test (distal motor latency) before surgery. ^461^ Analysis of individual patient data from a third study revealed that number of sick leave days was higher among patients with a pre-surgical electrodiagnostic test indicating slight or intermediate CTS as opposed to pronounced CTS. ^353^ In the fourth study, the relationship between electrodiagnostic test results and return to work was not statistically significant. ^395^ Electrodiagnostic test result was the only variable shown to predict treatment outcome in more than one of the studies that employed multiple regression.

We attempted to confirm the relationship between electrodiagnostic test results and patient outcomes by examining the results of studies that stratified according to the electrodiagnostic test results (Table 136). There were seven such studies, two of which were prospective. All studies evaluated surgical procedures. Six (85.7%) of the studies did not find a statistically significant relationship between electrodiagnostic test results and global outcomes. The remaining study (which was retrospective) found that patients with normal/near normal nerve deficit before treatment had a significantly better global outcome after treatment.

Table 136. Stratified studies (global outcome)

Study | N | Treatment | Golbal outcome measure | Stratification variable
| | | | Electrodiagnostic nerve deficit
Finsen and Russworm (2001) ^224^ | 79 | Surgery (open release) | VAS for pain and discomfort | NS
Straub (1999) ^305^ | 100 | Surgery (endoscopic release) | Satisfactory/unsatisfactory result | NS (but trend toward more success in abnormal sensory/ normal motor nerve conduction group)
Choi and Ahn (1998) ^329^ | 154 | Surgery (open release) | Patient satisfaction (poor, fair, good, or excellent) | NS
Higgs (1997) | 93 | Surgery (open release) | Improved/not improved | Sig (normal/near normal)
Glowacki (1996) ^352^ | 167 | Surgery (open release) | Symptoms resolved, improved, or same or worse | NS
Al-Qattan (1994) ^375^ | 112 | Surgery (open release) | Satisfactory/poor outcome | NS
Yu (1992) ^403^ | 53 | Surgery (open release) | Good/fair/poor result | NS

NS - Not signficant

#### Conclusions

Studies that searched for relationships between clinical findings and treatment outcomes did so by using multiple regression analysis or stratified patient groups. Among studies that used regression analysis, the only clinical finding variable shown by more than one study to significantly predict treatment outcomes was electrodiagnostic testing. This finding was statistically significant in three of the four studies that examined it. The outcomes predicted by these three studies were patient satisfaction with surgery, odds of obtaining disability payment, and number of sick days after surgery. Odds of obtaining disability payment were higher in patients diagnosed with CTS (mild, moderate, or severe) compared to those with normal electrodiagnostic findings. Another study found patient satisfaction with surgery was lower among patients with a better electrodiagnostic test results (distal motor latency) before surgery. Analysis of individual patient data from a third study revealed that number of sick leave days was higher among patients with a pre-surgical electrodiagnostic test indicating slight or intermediate CTS as opposed to pronounced CTS. The fourth study of electrodiagnostic tests found no statistically significant relationship between electrodiagnostic test results and return to work. This apparent lack of consistency of results could indicate that, although the relationship between electrodiagnostic tests and treatment outcomes is statistically significant, it may not be substantial. The possibility that this relationship is small is supported by the results of stratified studies that examined the relationship between electrodiagnostic test results and global outcomes. Six of seven studies did not find a statistically significant relationship.

### Question #5: Is there a relationship between duration of symptoms and specific treatment outcomes among patients with carpal tunnel syndrome?

In addressing this question, we consider whether published literature suggests that duration of symptoms predicts positive or negative outcomes after treatment for carpal tunnel syndrome. The studies we considered all attempted to identify predictors by using regression techniques or by comparing outcomes in different groups of patients with different duration of symptoms.

#### Excluded studies

As discussed in the Methods section, we retrieved articles identified by our literature searches according to certain a priori criteria. However, not all of the retrieved studies met our more specific inclusion criteria for this question. These latter studies, and the reason we did not consider them for this question are shown in Table 137.

Table 137. Excluded studies

Author | Reason for exclusion
Wintman (1996) ^362^ | Stratified study with no duration of symptoms/outcome comparisons reported by at least three studies

#### Evidence base

After this exclusion, there remained six studies with 984 patients.

#### Study quality

The criteria used to evaluate study quality were identical to those described for Question 4. One prospective study and one retrospective study conducted a multiple regression analysis, while four studies performed stratifications

(Table 138). Only one of the four stratified studies was prospective in design.

Table 138. Study quality

Author/year | Prospective? | Methods used to identify predictor variables
Straub (1999) ^305^ | Yes | Stratification
Atroshi (1998) ^461^ | Yes | Multiple linear regression
Choi and Ahn (1998) ^329^ | No | Stratification
DeStefano (1997) ^463^ | No | Multivariable proportional hazards regression
Al-Qattan (1994) ^375^ | No | Stratification
Yu (1992) ^403^ | No | Stratification

#### Results

Table 139 shows the relationship between duration of symptoms and treatment outcomes in the only study that used regression to adjust for the effects of other predictor variables. All other variables used in this regression are also presented in the table. Atroshi et al. (1998) found that duration of symptoms was not a statistically significant predictor of patient dissatisfaction at three or six months following surgery. ^461^ The range of duration of symptoms was not reported in this study. DeStefano et al. (1997) found that duration of symptoms was a statistically significant predictor of symptom resolution among surgical patients (symptom duration <3 years correlated with greater likelihood of symptom resolution) but not among non-surgical patients. ^463^ They did not report the specific range of duration of symptoms, except that it ranged from <2 months to >3 years.

Table 139. Relationship between duration of symptoms and treatment outcomes among patients with Carpal Tunnel Syndrome

Author | N | Treatment | Outcomes | Duration of symptoms - significance (duration associated with better outcome) | Other variables examined
Atroshi (1998) ^461^ | 140 | Surgery (unilateral endoscopic release) | Global outcome (patient dissatisfaction) | NS | Age (sig), sex (NS), hand dominance (NS), unemployment (NS), vibration exposure (sig), ADL score (NS), DML (sig), surgeon (NS), subjective weakness (NS), type of work (NS), type of symptoms (NS), Tinel sign (NS), Phalen's test results (NS), thenar atrophy (NS), two-point discrimination (NS), grip strength (NS), pinch strength (NS)
DeStefano (1997) ^463^ | 425 | Non-surgical (oral meds, oral steroids, steroid injections, splints) | Global outcome (symptom resolution) | NS (non-surgical patients) | Age (NS), sex (NS), carpal tunnel syndrome category (NS), hand involved (NS), arthritis (NS), pregnancy (NS), injury (NS), diabetes or hypothyroidism (sig for surgical patients)
| | Surgical (carpal tunnel release) | | Sig (surgical patients, <3 years)

We searched further for a relationship between duration of symptoms and patient outcomes by examining the results of studies that stratified according to duration of symptoms (Table 140). There were four such studies, one of which was prospective. All studies evaluated the effects of surgical procedures, and all contained patients with a duration of symptoms ranging from weeks to years. Three out of four studies found no statistically significant relationship between duration of symptoms and global outcomes. The fourth study found a statistically significant correlation between shorter duration of symptoms and improved global outcome.

Table 140. Stratified studies (global outcome)

Study | N | Treatment | Global outcome measure | Duration of symptoms - significance (duration associated with better outcome)
Straub (1999) ^305^ | 100 | Surgery (endoscopic release) | Satisfactory/unsatisfactory result | NS
Choi and Ahn (1998) ^329^ | 154 | Surgery (open release) | Patient satisfaction (poor, fair, good, or excellent) | Sig (shorter duration, <3 months)
Al-Qattan (1994) ^375^ | 112 | Surgery (open release) | Satisfactory/poor outcome | NS
Yu (1992) ^403^ | 53 | Surgery (open release) | Good/fair/poor result | NS, but trend toward more success in ≥6 month group

NS - Not signficant

#### Conclusions

The majority of available evidence is less than optimal because it consists primarily of retrospective studies. The highest quality study (prospective with multiple regression analysis) suggested that there was no statistically significant correlation between duration of symptoms and global outcome after surgery. One prospective and two retrospective stratified studies found similar results. Two retrospective studies (one performing multiple regressions, one stratified) found a statistically significant relationship between shorter duration of symptoms and symptom resolution or patient satisfaction after surgery. The retrospective nature of these trials could have created bias that influenced these findings. An additional high quality prospective study is needed before firm conclusions can be reached.

### Question #6: Is there a relationship between factors such as patients' age, gender, socioeconomic status and/or racial or ethnic grouping and specific treatment outcomes among patients with carpal tunnel syndrome?

In addressing this question, we consider whether published literature suggests that there are demographic variables that predict positive or negative outcomes after treatment for carpal tunnel syndrome. The studies we considered all attempted to identify predictors by using regression techniques or by comparing outcomes in different groups of patients with different pre-treatment demographic characteristics.

#### Excluded studies

As discussed in the Methods section, we retrieved articles identified by our literature searches according to certain a priori criteria. However, not all of the retrieved studies met our more specific inclusion criteria for this question. These latter studies, and the reason we did not consider them for this question are shown in Table 141.

Table 141. Excluded studies

Author | Reason for exclusion
Walker (2000) ^34^ | Stratified study with no demographic variables/outcome comparisons reported by at least three studies
Braun (1999) ^316^ | Stratified study with no demographic variables/outcome comparisons reported by at least three studies
Hasegawa (1999) ^34^ | Stratified study with no demographic variables/outcome comparisons reported by at least three studies
Higgs (1997) ^341^ | Stratified study with no demographic variables/outcome comparisons reported by at least three studies
Rosen (1997) ^343^ | Stratified study with no demographic variables/outcome comparisons reported by at least three studies
Padua (1996) ^358^ | Stratified study with no demographic variables/outcome comparisons reported by at least three studies
Wintman (1996) ^362^ | Stratified study with no demographic variables/outcome comparisons reported by at least three studies
Nancollas (1995) ^464^ | Stratified study with no demographic variables/outcome comparisons reported by at least three studies
Chang and Dellon (1993) ^389^ | Stratified study with no demographic variables/outcome comparisons reported by at least three studies
Feinstein (1993) ^390^ | Data presentation did not allow determination of correlation
Hagberg (1991) ^308^ | Stratified study with no demographic variables/outcome comparisons reported by at least three studies

#### Evidence base

After these exclusions, there remained 22 studies with a total of 3616 patients.

#### Study quality

The criteria used to evaluate study quality were identical to those described for Question 4 of our section on carpal tunnel syndrome. Table 142 shows the 22 included studies and the relevant study design and quality characteristics. Six studies used multiple regression and 16 used stratifications to identify correlations between demographic variables and treatment outcomes. Of the six studies utilizing regression, three were prospective, one was partially prospective, and two were retrospective. Of the 16 stratified studies, eight were prospective.

Table 142. Study quality

Author/year | Prospective? | Methods used to identify predictor variables
Shin (2000) ^460^ | No | Multiple logistic regression
Olney (1999) ^323^ | No | Stratification
Straub (1999) ^305^ | Yes | Stratification
Atroshi (1998) ^461^ | Yes | Multiple linear regression
Davies (1998) ^330^ | No | Stratification
Katz (1998) ^462^ | Yes | Multiple logistic regression
DeStefano (1997) ^463^ | No | Multivariable proportional hazards regression
Elmaraghy and Hurst (1996) ^349^ | Yes | Stratification
Glowacki (1996) ^352^ | No | Stratification
Jacobsen and Rahme (1996) ^353^ | Yes | Multiple regression
Lee and Jackson (1996) ^355^ | No | Stratification
Nagle (1996) ^357^ | Yes | Stratification
Strickland (1996) ^361^ | No | Stratification
Wintman (1996) ^362^ | Yes | Stratification
Hallock and Lutz (1995) ^368^ | Yes | Stratification
Mirza (1995) ^371^ | Unknown | Stratification
Al-Qattan (1994) ^375^ | No | Stratification
Roth (1994) ^383^ | Yes | Stratification
Nathan (1993) ^395^ | Partly^a^ | Multiple regression
Palmer (1993) ^397^ | Yes | Stratification
Agee (1992) ^46^ | Yes | Stratification
Yu (1992) ^403^ | No | Stratification

WC - Workers' compensation

b Patients entering the study after a certain date were studied prospectively; patients who had treatment prior to that date were studies retrospectively

#### Results

Table 143 shows the relationship of specific demographic variables to treatment outcomes in those studies that used regression to identify predictor variables (demographic variables are shown in bold type). There are six such studies with a total of 1357 patients. Also presented in this table are non-demographic variables (e.g. grip strength) to show all of the variables used in each multiple regression.

Table 143. Relationship between demographic factors and treatment outcomes among patients with Carpal Tunnel Syndrome (multiple regression analysis)

Author | N | Treatment | Outcomes | Variables examined by at least two studies (significant correlation with outcome?) | | | | | | | | | Unique study variables
| | | | Age^d^ | Gender | Treatment | Hand dominance | Insurance type | Employment status | Two-point discrimination | Electrodiagnostic test | Grip strength
Shin (2000) ^460^ | 210 | Conservative treatments | Odds of obtaining employment disability | NS | NS | NS | - | - | - | - | Sig | - | Mechanism of injury (NS)
| | Surgery^a^
Atroshi (1998) ^461^ | 140 | Surgery^b^ | Global outcome (patient dissatisfaction) | Sig | NS | - | NS | - | NS | NS | Sig | NS | Vibration exposure (sig), ADL score (NS), thenar atrophy (NS), pinch strength (NS), tinel sign (NS), phalen sign (NS)
Katz (1998) ^462^ ^302^ | 315 | Surgery and conservative treatments (not described) | Work absence (18 months after treatment) | NS | NS | NS | - | NS (all patients)^e^ | NS | NS | - | NS | Occupation (NS), baseline function (sig), function at 6 months (sig), hired attorney (sig), work absence at enrollment (NS), work absence at 6 months (sig), mental health status (NS), physical and clerical self-reported exposure scales
| | | | | | | | Sig (surgery patients)
DeStefano (1997) ^463^ | 425 | Conservative treatments | Global outcome (symptom resolution) | NS | NS | Sig | NS | - | - | Sig (surgical patients only) | - | - | -
| | Surgery (carpal tunnel release)
Jacobsen^e^ and Rahme (1996) ^353^ | 29 (32 hands) | Surgery^c^ | Number of sick days after surgery | NS | NS | NS | NS | - | - | NS | Sig | - | None
Nathan (1993) ^395^ | 238 | Surgery^a^ | Return to work | NS | NS | - | NS | Sig | NS | - | NS | - | Laterality (NS), year of study (NS), referral source (NS), incision length (NS), occupational hand use (NS), diabetes (NS), rheumatoid arthritis (NS), number and density of hand therapy sessions/ week (NS)

a Open release

b Unilateral endoscopic release

c Open and endoscopic release

d Variables in boldface represent demographic characteristics

e In a related publication, surgical patients alone were analyzed and insurance type significantly correlated with work absence 6 months post-surgery. ^302^

e Multiple regression performed independently by ECRI from individual patient data presented in this study

NS - Not significant

Gender, employment status, and hand dominance did not correlate significantly with any treatment outcomes in any of these studies. Two studies found that insurance type (workers' compensation vs non-workers' compensation) correlated significantly with treatment outcomes (work absence and return to work) after surgical treatment. ^302,^ ^395^ One of these studies was a subgroup analysis derived from a larger study that analyzed surgical and non-surgical patients together. ^462^ When data from these patients were combined, the correlation between insurance type and treatment outcome was not statistically significant. Although one out of five studies found age to be significantly correlated with patient satisfaction, ^461^ the reported odds ratio was close to 1. Two studies evaluated diabetes as a potential predictor variable. One retrospective study found it to have a statistically significant relationship with symptom resolution, but only among surgical patients. ^463^ The other study (partly retrospective, partly prospective) found no statistically significant relationship between diabetes and return to work among surgical patients. ^395^

Table 144 and Table 145 summarize the results of studies that conducted stratification and outcome comparisons (e.g. stratification by age, evaluated by patient satisfaction) that were reported by at least three studies. The only two outcomes reported by at least three studies were global outcome (Table 144) and return to work (Table 144), and the only stratifications reported by at least three studies were insurance type and job category. All of these studies evaluated the effectiveness of various surgical procedures.

Table 144. Stratified studies (global outcome)

Study | N | Treatment | Global outcome measure | Stratification variable
| | | | Workers' compensation (WC) status | Job category
Straub (1999) ^305^ | 100 | Surgery (endoscopic release) | Satisfactory/unsatisfactory result | NS (but trend toward more success in non-WC group) | NS
Davies (1998) ^330^ | 239 | Surgery (endoscopic release) | Patient satisfaction/dissatisfaction | Sig (non-WC) | -
Glowacki (1996) ^352^ | 167 | Surgery (open release) | Symptoms resolved, improved, or same or worse | Sig (non-WC) | -
Al-Qattan (1994) ^375^ | 112 | Surgery (open release) | Satisfactory/poor outcome | Sig (non-WC) | Sig (not physically strenuous)
Yu (1992) ^403^ | 53 | Surgery (open release) | Good/fair/poor result | - | Sig (not physically strenuous)

NS - Not significant

Table 145. Stratified studies (return to work)

Study | N | Treatment | Stratification variable
| | | Workers' compensation (WC) status
Olney (1999) ^323^ | 211 | Surgery (open or endoscopic release) | Sig (non-WC and non-contested WC)
Davies (1998) ^330^ | 239 | Surgery (endoscopic release) | Sig (non-WC)
Elmaraghy and Hurst (1996) ^349^ | 75 | Surgery (endoscopic release) | Sig (non-WC)
Lee and Jackson (1996) ^355^ | 237 | Surgery (limited incision release using carposcope) | Sig (non-WC)
Nagle (1996) ^357^ | 291 | Surgery (endoscopic release) | Sig (non-WC)
Strickland (1996) ^361^ | 62 | Surgery (hypothenar fat pad flap for patients who received unsuccessful open release) | NS, except for manual labor subgroup (non-WC)
Hallock and Lutz (1995) ^368^ | 96 | Surgery (open or endoscopic release) | Sig (non-WC)
Mirza (1995) ^371^ | 236 | Surgery (endoscopic release) | Sig (non-WC)
Roth (1994) ^383^ | 95 | Surgery (endoscopic release) | Sig (non-WC)
Palmer (1993) ^397^ | 163 | Surgery (open or endoscopic release) | Sig (non-WC)
Agee (1992) ^46^ | 122 | Surgery (open or endoscopic release) | Sig (non-WC)

NS - Not significant

Of the four stratified studies that attempted to correlate workers' compensation status with global outcomes, three found that non-workers' compensation patients had significantly better global outcomes after treatment. ^330,^ ^352,^ ^375^ These were the three largest studies that examined this relationship, but all were retrospective. The remaining study, which was prospective but slightly smaller, found a non-significant trend toward a better global outcome in the non-workers' compensation group. ^305^ Of three studies that attempted to correlate job category with global outcomes, two (one of which was prospective) found that patients with jobs that were not physically strenuous had significantly better global outcomes after treatment. ^375,^ ^403^ The remaining study found no statistically significant difference among job categories as measured by global outcome. ^305^

Of studies that examined return to work as an outcome measure, 11 studies stratified patients by workers' compensation status, and 10 (six of which were prospective) found a significantly quicker return to work after treatment in the non-workers' compensation group. The remaining study showed a significantly quicker return to work among non-workers' compensation patients only in the subgroup of manual workers. ^361^

#### Conclusions

The available evidence suggests that patients who are not receiving workers' compensation tend to return to work faster than those receiving such compensation. This is suggested by one of two “multiple regression” studies of this relationship and by a combination of 10 prospective and retrospective stratified studies. Some evidence also suggests that patients who are not receiving workers' compensation have better global outcomes, but this evidence is derived exclusively from retrospective studies. Therefore, these latter findings require confirmation. In any event, one cannot ascribe causal relationships to these correlations.

Available evidence suggests that there is no strong relationship between gender, employment status, or hand dominance and return to work or global outcomes. There is insufficient evidence to arrive at a firm evidence-based conclusion on the relationship between type of work, diabetes, or age and patient outcomes.

### Question #7: What are the surgical and nonsurgical costs or charges for treatment of carpal tunnel syndrome?

According to the Medicare Provider Analysis and Review (MEDPAR) database, which covers hospital inpatient services, average total charges per patient for the DRG (diagnosis-related group) of carpal tunnel release are $8,185.24 (calculated by dividing total charges by number of discharges). This DRG includes open and endoscopic release. The Median Costs for Hospital Outpatient Services Dataset contains median costs for services that are reimbursed under Medicare for the hospital outpatient prospective payment system. The reported median cost for endoscopic release of the transverse carpal ligament is $849.84 (cost of open release was not reported by this database). The reported median cost for application of a short arm static splint is $72.69.

### Question #8: For persons who have had surgery for carpal tunnel syndrome, what are the most effective methods for preventing the recurrence of symptoms, and how does this vary depending on subject characteristics or other underlying health problems?

This question distinguishes symptom recurrence from continued symptoms after treatment. The latter may be caused by incomplete sectioning of the transverse carpal ligament, damage to the median nerve during the operation, initial misdiagnosis of carpal tunnel syndrome, or the presence of additional compressive nerve injuries. ^465–467^ Recurrence of carpal tunnel syndrome after initial relief of symptoms may be caused by compression of the medial nerve due to fibrosis, hematoma, neuroma, scarring, or re-injury. ^465,^ ^466,^ ^468^

Techniques that have been recommended to prevent recurrence include changing work habits, use of ergonomic equipment, and other forms of occupational therapy. ^469^ Careful surgical technique to prevent excessive scarring, ^468^ and physical therapy to prevent formation of adhesions may also have some utility. ^32,^ ^466^ However, no controlled trials have been published that report on the efficacy or effectiveness of any technique for the prevention of recurrence of carpal tunnel syndrome. Controlled trials are necessary so that incidence of recurrence among patients for whom measures have been taken to prevent recurrence may be compared with recurrence among patients for whom no such measures have been taken, drawn from the same population. Controls enable one to distinguish treatment effects from effects due to population differences, changes in behavior, and/or medications (including over-the-counter drugs, and other, unknown factors that may influence recurrence rates. In the absence of controlled trials, no analysis may be performed and no evidence-based conclusions may be drawn.

### Question #9: What instruments, if any, can accurately assess functional limitations in an individual with carpal tunnel syndrome?

Instruments have been developed that allow patients to self-report their degree of functional impairment. Self-administered questionnaires require few personnel to adminster and are a low-cost way to collect information, especially of data for which the patient's self-report is the only possible source. However, such instruments tend to suffer from certain biases caused by basic human psychological tendencies. These biases are listed in Table 146. The effect of these biases on the results of assessment instruments can be reduced by careful instrument design, but never completely eliminated. Because these biases can distort the results of assessment instruments, each assessment instrument must be evaluated as to its usefulness and accuracy.

Table 146. Potential biases in assessment instruments^a^

Bias | Definition
Yea-saying | The tendency to always agree with yes-no questions.
End aversion | The tendency to use middle values rather than the end points of analog scales
Question framing | The tendency for the wording of a question to affect the response.
Motivation to seem better | Patients want to subconsciously please their health-care providers by responding to treatment and are embarrassed to complain about problems.
Motivation to seem worse | Can occur if patients will lose services or benefits if they improve.
Response shifts | The tendency of patients to modify their internal standards of evaluation so that their current level of functioning is seen as normal.
Memory failure | Difficulty in remembering past function may influence assessment of current function.
Leading the patient | The tendency of the questionnaire itself to change the way the patient assesses functioning.

a Adapted from Gotay 1996 ^474^

Evaluating the usefulness and accuracy of functional assessment instruments is difficult because there is no “gold standard” against which to compare the results. However, these instruments can be evaluated according to three key components: internal reliability, test-retest reliability, and validity of results. If there is a treatment available for the disorder causing the functional impairment, instruments are also evaluated as to their ability to respond to changes in function caused by treatment. ^470^

Internal reliability, or internal consistency, refers to the degree to which scores on subsections of the test correlate with scores from other subsections. For example, if a subject has significant functional impairment in the use of the hands, it is likely that the subject will score as impaired on questions about both work activities and home activities.

Test-retest reliability means that the score of a test depends solely on the impairments of the individual taking the test, not on factors such as the time of day the test is administered, or who is administering the test. Test-retest reliability is usually measured by having the subject take the test several times under different conditions.

Evaluating the validity of an assessment instrument can be difficult. Content validity, which refers to whether the test questions reflect the functions required to perform the task(s) in question, is largely a theoretical concept and cannot be directly measured. ^89^ Concurrent validity refers to the way a test's scores correlate with other measurements of what the test is purported to assess. ^89^ However, findings on clinical examinations often do not correlate well with functional impairment and thus can be problematic when used to validate functional assessment instruments. ^471–473^ Predictive validity refers to a test's ability to reflect future performance, i.e., if a subject's scores predict little functional impairment and the subject soon returns to full work, the test may be said to have predictive validity. ^89^

We define an instrument that can accurately assess functional limitations in an individual with carpal tunnel syndrome as one that has been shown to have: test-retest reliability, internal reliability, concurrent validity, predictive validity, and responds to treatment.

#### Evidence base

Eight studies met the inclusion criteria (see the section Inclusion Criteria). They are listed in Table 147. The functional assessment instruments evaluated by the studies that met the inclusion criteria are listed in Table 148.

Table 147. Trials of functional assessment instruments that met the inclusion criteria

Study | Instruments evaluated^a^ | N subjects | Outcome measurements
Vaile 1999 ^475^ | NHP, SF-36, mSHAQ, V-VAS | 27 | Response to treatment
Alderson 1999 ^315^ | AMHFQ | 26 | Validity
| | | Test-retest reliability
Atroshi 1998 ^326^ | SF-36 and CTS-I | 102 | Test-test comparison
| | | Test-retest reliability
| | | Response to treatment
Pransky 1997 ^476^ | UEF | 165 | Validity
| | | Test-test comparison
Atroshi 1997 ^477^ | SF-36 and CTS-I | 277 | Validity
Katz 1994 ^377^ | Global score | 104 | Validity
Katz 1994 ^303^ | CTS-I and K-ADL | 74 | Response to treatment
Levine 1993 ^393^ | CTS-I | 67 | Validity
| | | Test-retest reliability
| | | Response to treatment

a The full names of the instruments and descriptions of the instruments are given in

Table 148. Instruments evaluated to measure functional limitations associated with carpal tunnel syndrome

Instrument | Abbreviation | First described by | Scoring system | Subjects covered | Extent of use^a^
Alderson-McGall Hand Function Questionnaire | AMHFQ | Alderson and McGall 1999 ^318^ | Functional difficulty categories | Common tasks performed with the hands | Not widely used
Calculated Global Score | Global Score | Katz 1994 ^377^ | VAS | Grip strength, numbness, pain, parethesia | Not widely used
Carpal Tunnel Syndrome Instrument | CTS-I | Levine 1993 ^393^ | Functional difficulty categories/symptom severity categories | Eight ADL, and severity of symptoms | Widely used
Katz Activities of Daily Living | K-ADL | Katz 1994 ^303^ | Functional difficulty categories | Ten ADL | Not widely used
Medical Outcomes Study 36-Item Short-Form Health Survey | SF-36 | Ware 1992 ^478^ | Categories | Impact of health on physical activities, social activities, activities of daily living, pain, psychological distress, emotional health, and energy | Extensively used
Modified Stanford Health Assessment Questionnaire | mSHAQ | ^479^ | Categories | ADL | Widely used
Nottingham Health Profile | NHP | Hunt 1985 ^480^ | Categories | Pain, energy, emotional reactions, sleep problems, social isolation, physical mobility, employment, hobbies, sex life, personal relationships, and holiday | Widely used
Upper Extremity Function Scale | UEF | Pransky 1997 ^476^ | Functional difficulty categories | Eight ADL | Not widely used
Vaile Visual Analog Scales | V-VAS | Vaile 1999 ^475^ | VAS | Impact of CTS on well being, discomfort, activities | Not widely used

a Extent of use was determined by searching Medline for manuscripts that used the assessment instrument. Not widely used = 3 or fewer studies. Widely used= four to ten studies. Extensively used= more than ten studies.

#### Study quality

##### Internal validity

Studies evaluating instruments need not include a separate control group, because each patient acts as his/her own control. The patient's score on the assessment instrument can be directly compared to the patient's score on the parameter against which the test is being measured. All of the studies included in this section are single-arm prospective cohort studies. Factors relating to the quality of the studies are shown in Table 149. Five of the eight studies administered and scored the instruments with evaluators who were blinded to the identity, history, and other test scores of the patients. Studies that did not use blinded evaluators may have been subject to bias.

Table 149. Details of study design

Study | Number of patients | Number of centers | Funded by a for-profit agency? | Study design | Prospective | Blinding | % Attrition | Intent to treat analysis | % Compliance
Vaile 1999 ^475^ | 27 | 2 | NR | Cohort | Yes | No | 0 | Yes | NA
Alderson 1999 ^315^ | 26 | 1 | NR | Cohort | Yes | Rater | 34 | No | NA
Atroshi 1998 ^326^ | 102 | 1 | No | Cohort | Yes | Rater | 0 | Yes | NA
Pransky 1997 ^476^ | 165 | 1 | No | Cohort | Yes | No | 44.8 | No | NA
Atroshi 1997 ^477^ | 277 | 3 | No | Cohort | Yes | No | 23.4 | No | NA
Katz 1994 ^377^ | 104 | 4 | No | Cohort | Yes | Rater | 0 | Yes | NA
Katz 1994 ^303^ | 74 | 4 | NR | Cohort | Yes | Rater | NR | No | NA
Levine 1993 ^393^ | 67 | 2 | No | Cohort | Yes | Rater | 0 | No | NA

##### Generalizability

It is important for studies that evaluate assessment instruments to enroll patients who are representative of the population of interest. Information about patients enrolled in the studies addressing this question are shown in Table 150. All eight studies recruited populations that appear to be “typical” of patients presenting with carpal tunnel syndrome as has been established by epidemiology studies (See the Introduction). The patient groups are predominantly female and middle aged. Few of the studies reported on the presence of co-morbid conditions that may have contributed to functional limitations. The occupations and employment status of the patients are shown in Table 151. The two studies by Katz recuited patients from the same large randomized controlled trial, a trial that was comparing different methods of surgically treating carpal tunnel syndrome.

Table 150. Study generalizability: patient characteristics

Study | Number of patients | Mean age and range | % female | Duration of conditon mean and range months | % Patients with diabetes | % Patients with arthritis | % Patients with prevous relevant injuries | % Patients with other relevant nerve impingement conditons | % Patients with peripheral neruopathy | % Patients pregnant | % Patients on kidney dialysis | Did the study exclude patients with severe disease? | Did the study exclude patients with mild disease?
Vaile 1999 ^475^ | 27 | 57 (29–84) | 81.4 | NR | NR | 55.5 | NR | NR | NR | NR | NR | No | No
Alderson 1999 ^315^ | 26 | 44.4 (22–79) | 70.5 | (3–48) | NR | 0 | NR | NR | NR | NR | NR | No | No
Atroshi 1998 ^326^ | 102 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Pransky 1997 ^476^ | 165 | 46 (19–65) | 67 | NR | NR | NR | NR | NR | NR | NR | NR | No | No
Atroshi 1997 ^477^ | 277 | 46.6 (13–91) | 77.8 | NR | NR | NR | NR | NR | NR | NR | NR | No | No
Katz 1994 ^377^ | 104 | 55 (25–87) | 70 | NR | NR | NR | NR | NR | NR | NR | NR | No | No
Katz 1994 ^303^ | 74 | 55 (25–87) | 70 | NR | NR | 0 | NR | 0 | 0 | 0 | NR | No | No
Levine 1993 ^393^ | 67 | 57 (19–88) | 75 | 18 (3–58) | NR | NR | NR | NR | NR | NR | NR | NR | No

Table 151. Generalizability: employment status and occupations

Study | Number of patients | % Patients employed | % Patients on Workers Compensation | % Patients retired | % Patients homemakers | Reported Occupations
Vaile 1999 ^475^ | 27 | NR | 0 | NR | NR | NR
Alderson 1999 ^315^ | 26 | NR | 35 | NR | 5.6% | Business-17.6%
| | | | | | Sciences-5.9%
| | | | | | Health-11.8%
| | | | | | Education-5.9%
| | | | | | Recreation-5.9%
| | | | | | Sales-11.8%
| | | | | | Trades and Transport-5.9%
| | | | | | Industry-5.9%
| | | | | | Manufacturing-23.5%
Atroshi 1998 ^326^ | 102 | NR | NR | NR | NR | NR
Pransky 1997 ^476^ | 165 | 89 | 10 | NR | NR | NR
Atroshi 1997 ^477^ | 277 | NR | 28.8 | NR | NR | NR
Katz 1994 ^377^ | 104 | NR | 8 | NR | NR | NR
Katz 1994 ^303^ | 74 | NR | 8 | NR | NR | NR
Levine 1993 ^393^ | 67 | NR | 13 | NR | NR | NR

#### Results

##### Test-retest reliability

Two studies have reported that two tests, the CTS-I and the AMFHQ, give similar results when administered twice to the same subject. The correlation coefficients describing the test-retest reliability are shown in Table 152.

Table 152. Results of test-retest reliability tests

Study | Number of patients | Tests evaluated | Time between test administrations | Type of statistical comparison being made | Was the instrument reliable?
Alderson 1999 ^315^ | 26 | AMFHQ | NR | Intraclass correlation coefficient Reported to be consistent | Yes
Atroshi 1998 ^326^ | 22 | CTS-I | 24 hours | Correlation coefficient r = 0.71 | Yes
Levine 1993 ^393^ | 67 | CTS-I | 24 hours | Pearson's correlation coefficient r = 0.93 | Yes

##### Internal reliability

None of the studies reported on this aspect of instrument evaluation.

##### Response to treatment

Four studies have reported the ability of six different assessment instruments to respond to changes in subjects treated for carpal tunnel syndrome. For the purposes of answering this question, studies that analyzed the test scores of patients who were successfully treated separately from those patients who failed treatment are superior. If the test scores of patients who failed treatment are included with those who were successfully treated, the results will be biased towards finding that the assessment instrument cannot detect a response to treatment. None of the studies separately analyzed data from successfully treated patients and data from unsuccessfully treated patients. The studies by Vaile 1999 and Katz 1995 included only patients who had been successfully treated. The results of the response to treatment evaluations are summarized in Table 153.

Table 153. Results of response to treatment tests

Study | Number of patients | Test evaluated | Treatment | Time of testing months | Effect size hedges' d (95% CI)^a^ | Was the instrument responsive to treatment?
Vaile 1999 ^475^ | 27 | mSHAQ | Injection of corticosteroids | 0 | 0.31 (-0.23 to 0.85) | No
| | | | 1
| | SF-36 | Injection of corticosteroids | 0 | -0.29 (-0.82 to 0.24) | No
| | | | 1
| | NHP | Injection of corticosteroids | 0 | 0.38 (-0.16 to 0.91) | No
| | | | 1
| | V-VAS | Injection of corticosteroids | 0 | 1.58 (0.97 to 2.19) | Yes
| | | | 1
Atroshi 1998 ^326^ | 102 | CTS-I | Carpal tunnel release surgery | 0 | 0.78 (0.50 to 1.07) | Yes
| | | | 3
| 48 | SF-36 | Carpal tunnel release surgery | 0 | -0.052 (-0.45 to 0.35) | No
| | | | 3
Katz 1994 ^303^ | 43 | CTS-I | Carpal tunnel release surgery | 0 | 1.08 (0.63 to 1.53) | Yes
| | | | 3
| 55 | K-ADL | Carpal tunnel release surgery | 0 | 1.32 (0.91 to 1.73) | Yes
| | | | 3
Levine 1993 ^393^ | 38 | CTS-I | Carpal tunnel release surgery | 0 | 0.97 (0.50 to 1.45) | Yes
| | | | 14 mean

a calculated by ECRI

Because there are three or fewer studies evaluating each test, we did not perform a meta-analysis. We scored an instrument as being responsive to treatment if there was a statistically significant difference in the effect sizes determined from the pre-treatment and post-treatment scores. By this criterion, the mSHAQ and NHP were not responsive to treatment, while the V-VAS and the K-ADL were responsive to treatment. Three studies evaluated the CTS-I; all three found the instrument to be responsive to treatment. Two studies reported that the SF-36 was not responsive to treatment.

In summary, the more general instruments were not found to be responsive to treatment for carpal tunnel syndrome (NHP, SF-36, mSHAQ). Instruments designed to evaluate carpal tunnel syndrome were found to respond to treatment for carpal tunnel syndrome (CTS-I, K-ADL, V-VAS).

##### Validity

The validity tests performed on the instruments evaluated are summarized in Table 154. The validity tests can be separated into two groups: those measuring predicitive validity, and those measuring concurrent validity.

Table 154. Results of validity tests

Study | Number of patients | Test evaluated | Type of statistical comparison being made | Validated against | Was the instrument valid by this measurement?
Alderson 1999 ^315^ | 26 | AMHFQ | Pearson's correlation coefficient | pinch strength r = 0.295 | Yes, but the r value is low
| | | | grip strength r = 0.3867 | Yes, but the r value is low
| | | | two-point discrimination r = -0.127 | No
Atroshi 1997 ^477^ | 102 | SF-36 | ANOVA | On workers comp. vs. not on workers comp. p = 0.5 | No
| | CTS-I | ANOVA | On workers comp. vs. not on workers comp p = 0.07 | No
Pransky 1997 ^476^ | 165 | UEF | Difference between two means with t-test | working vs. not working p <0.001 | Yes
| | | | normal Phalen's test vs. abnormal Phalen's test p <0.05 | Yes
| | | Pearson's correlation coefficient | nerve conduction speed test p >0.05 | No
| | | | pinch strength p <0.001 | Yes
| | | | grip strength p <0.001 | Yes
Katz 1994 ^377^ | 104 | Global score | Pearson's correlation coefficient | time to return to work- treated with open release surgery r = 0.67 | Yes
| | | | time to return to work- treated with endoscopic release surgery r = 0.2 | Yes, but the r value is low
Levine 1993 ^393^ | 67 | CTS-I | Spearmann's correlation coefficient | Semmes-Weinstein monofilament testing r = 0.24 | Yes, but the r value is low
| | | | two-point discrimination test r = 0.42 | Yes
| | | | pinch strength r = 0.60 | Yes
| | | | grip strength r = 0.50 | Yes
| | | | median nerve sensory conduction velocity r = 0.12 | No

###### Predictive validity

Atroshi 1997 compared the test scores of those receiving Workers' Compensation to the scores of those not receiving Workers' Compensation. Atroshi 1997 found no statistically significant differences between the two groups in their scores on either the SF-36 or the CTS-I. Workers' Compensation is paid to only those with injuries so severe that they cannot work. Thus, the results of this study suggest that either the SF-36 and the CTS-I are not valid tests for functional limitations, or that Workers' Compensation is not a valid measure of the severity of functional limitations. Due to a lack of reported data, we were unable to verify that the study by Atroshi 1997 had sufficient statistical power to be able to detect a statistical significance between the two groups if one had existed.

Pransky 1997 compared test scores on the UEF of those working and those not working. However, instead of calculating the correlation between the individual scores and work status, Pransky 1997 compared the mean scores of the two groups of patients. There was a statistically significant difference between the means of the two groups for both a mixed population of upper extremity disorders and a population with carpal tunnel syndrome. Comparing the means suggests that the UEF can discriminate between subjects who are working and not working, but provides little information as to whether an individual score on the test can be used to predict an individual's ability to work.

Katz 1994 tested individuals shortly after surgery for carpal tunnel syndrome and found a statistically significant correlation between the Global Score and time to return to work for those treated with open tunnel release surgery, but not for those treated with endoscopic tunnel release surgery. This finding can be explained by the fact that one of the measurements that contributes to the Global Score is the amount of pain the individual experiences at the site of surgery. Thus it is likely that the Global Score is not a particularly valid measurement of functional limitations related to the WRUEDs.

In summary, none of the instruments have been reported to have predictive validity as measured by the ability to work. None of the instruments were evaluated as to predictive validity as measured by the ability to perform activities of daily living.

###### Concurrent validity

The clinical examination results used to validate the instruments consist of measurements of hand grip strength, and measurements of hand sensory function or nerve conduction speed. One study per test has reported a weak correlation (see Table 154 for the values of the correlation coefficients) between scores on the AMHFQ, the UEF, and the CTS-I and hand grip strength. This suggests that all three tests may have concurrent validity as measured by hand grip strength.

Alderson 1999 reported no statistically significant correlation between scores on the AMHFQ and measurements of hand sensory capability. Levine 1993 reported a weak correlation between hand sensory capability and scores on the CTS-I. Pransky 1997 and Levine 1993 reported no statistically significant correlation between nerve conduction speed tests and scores on the UEF and CTS-I. These results indicate that the instruments cannot be used to predict sensory/nerve function.

In summary, the AMHFQ, the UEF, and the CTS-I may all be concurrently valid as measured by hand grip strength, but not of hand sensory ability.

##### Test-test comparisons

One study compared the scores of the same patients on different tests (Table 155). Atroshi 1998 compared the CTS-I and the SF-36 tests on patients with carpal tunnel syndrome. Before treatment of the carpal tunnel syndrome, the test scores correlated fairly well, but the correlation dropped after treatment. This change may be attributed to the finding, discussed previously, that the CTS-I instrument is responsive to treatment while the SF-36 is not.

Table 155. Results of test-test comparisons

Study | Tests being compared | Type of statistical comparison being made | Value of comparison r | Were the tests consistent?
Atroshi 1998 ^326^ | CTS-I and SF-36, pre-treatment | Spearmann's correlation coefficient | 0.62 | Yes
| CTS-I and SF-36, post-treatment | Spearmann's correlation coefficient | 0.56 | Yes

#### Conclusion

Eight studies evaluated the ability of nine different instruments as ways to measure functional limitations of patients with carpal tunnel syndrome. Of the available instruments, only two were evaluated by more than one trial. The two instruments that were evaluated by three and four trials, respectively, were the SF-36 and the Levine CTS-I.

It can be tentatively concluded that the SF-36 is not a useful instrument for assessing functional limitations in individuals with carpal tunnel syndrome. The SF-36 was reported to not be responsive to treatment and to not be able to predict ability to work.

It can be tentatively concluded that the Levine CTS-I may be a useful instrument for assessing functional limitations in individuals with carpal tunnel syndrome. This instrument was reported to be responsive to treatment, and to have concurrent validity as measured by grip and pinch strength. However, the Levine CTS-I was not evaluated by the studies included in the answer to this question for internal reliability, or prediction of the ability to perform activities of daily living. In addition, the Levine CTS-I has been reported by one study to not be able to predict ability to work.

It is difficult to reach an evidence-based conclusion as to the usefulness of the other instruments evaluated in this report due to the limited evidence base.

### Question #10: What are the functional limitations for an individual with carpal tunnel syndrome before treatment?

This question inquires about the functional limitations of an individual before they have received conservative or surgical treatment for carpal tunnel syndrome. In addressing it, our objective is to catalogue these limitations, and not to address the effectiveness of these treatments. We address the effectiveness of conservative and surgical treatments in Question 3.

The available literature governs our approach to the present question. Hence, we address functional status rather than functional limitations, because no published studies specifically addressed the latter. In addition, the only available data operationally defines functional status in terms of scores on certain written tests. Hence, we also address functional status in these terms. The validity and reliability of these written tests is discussed in Question 9. Study inclusion criteria are described under Methods (section ).

#### Excluded studies

As discussed in the Methods section, we retrieved articles identified by our literature searches according to certain a priori criteria. However, not all of the retrieved studies met our more specific inclusion criteria for this question. These latter studies, and the reason we did not consider them for this question are shown in Table 156.

Table 156. Excluded studies

Author | Reason for exclusion
Sefcovic (2000) ^481^ | Some patients had prior treatment (including surgery), some did not, but all were analyzed together.
Davis (1998) ^438^ | Used CTOA-I scale that has not been validated against accepted functional scales for carpal tunnel syndrome

There were also nine studies wherein functional status was reported for patients prior to receiving surgical treatment. ^44,^ ^311,^ ^313,^ ^326,^ ^428,^ ^476,^ ^482–484^ These patients generally had received prior conservative treatment that had been ineffective at relieving symptoms (or had not provided enough relief). Because patients who eventually receive surgery may have more severe pre-treatment symptoms than non-surgical patients, these nine studies do not address the question and are not considered further.

#### Evidence Base

Two studies (with a total of 51 patients) remained that addressed this question after the above exclusions.

#### Internal validity

Aspects of study quality that are most relevant to the present question are shown in Table 157. Because we are cataloging functional status rather than using it to compare treatments, randomization and the use of control groups are not of paramount importance here. Therefore, Table 157 does not depict these aspects of study design. However, the following variables are particularly important: attrition rates, whether the trial was prospective, and whether the raters of functional status (in this case the patients) were blinded to the treatment the patient received.

Table 157. Internal validity

Author | Number of patients | Number of centers | Funded by a for-profit agency? | Prospective | Blinding | % Attrition | Intent to treat analysis | % Compliance
Walker (2000) ^34^ | 21 | 1 | No | Yes | No | 19.0 | No | 92
Vaile (1999) ^485^ | 30 | 2 | NR | Yes | No | 0 | Yes | NR

NR - Not reported

One study reported no patient attrition, the other reported an attrition rate of 19 percent. This latter study did not perform an intent-to-treat analysis. ^34^ Both studies were prospective, but neither employed blinding. Because it is difficult to blind patients to the treatment received, we are considering unblinded studies to be of acceptable quality for this question.

#### Generalizability

Selected patient characteristics are presented in Table 158. Both studies reported mean patient age and percentage of female patients. For the remaining categories, one study reported combidities, ^485^ and neither study reported duration of symptoms or selection of patients based on severity of disease. In one study (Walker et al., 2000), the percent of female patients was much lower than that found in a typical population of carpal tunnel patients. This study examined a population of Veteran's Administration patients, of which men comprise an overwhelming majority. ^34^ Although Vaile et al. (1999) did not report a mean age, the range suggests that the mean age is probably consistent with epidemiologic studies (see Introduction section, carpal tunnel syndrome, subheading epidemiology, as well as Question two for CTS).

Table 158. Patient characteristics

Author | Number of patients | Mean age (range) | % female | Duration of condition mean and range (months) | % Patients with diabetes | % Patients with arthritis | % Patients with prevous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Did the study exclude patients with severe disease? | Did the study exclude patients with mild disease?
Walker (2000) ^34^ | 21 | 60 (44–81) | 4.8 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Vaile (1999) ^485^ | 30 | (29–84) | 81.5 | NR | NR | 55.6 | NR | 7.4 | NR | NR | NR | NR | NR

NR - Not reported

Only one study reported any information relating to patient employment or occupation. Vaile et al. (1999) reported that there were no patients receiving workers' compensation (Table 159). ^485^ Because there were only two studies, and they incompletely presented information on occupation-related variables, one cannot determine how generalizable these studies are to the greater population of patients with carpal tunnel syndrome.

Table 159. Patient occupation

Author | Number of patients | % Patients employed | % Patients on Workers Compensation | % Patients retired | % Patients homemakers | Reported Occupations
Walker (2000) ^34^ | 21 | NR | NR | NR | NR | NR
Vaile (1999) ^485^ | 30 | NR | 0 | NR | NR | NR

NR - Not reported

#### Results

Table 160 shows the reported functional status of patients with carpal tunnel syndrome who had no prior treatment. Since each study used a different scale to measure functional status, the scores are not directly comparable. The two studies suggested that untreated patients on average score in the middle range (the 30–65% level) of functional status scales, suggesting mild to moderate difficulty with functional activities. ^34,^ ^485^

Table 160. Studies with patients who had no prior treatment

Study | N | Future treatment | Scale | Range of scale | Overall mean pre-treatment functional status score | % of maximum score
Walker (2000) ^34^ | 21 | Non-surgical (splints) | CTS-I | 1–5 | Splint (night only): 2.75 (1.01) | 43.8
| | | | | Splint (full-time): 2.27 (1.03) | 31.8
Vaile (1999) ^485^ | 30 | Non-surgical (steroid injections) | Vaile | 0–100 | 64.2 (24.0) | 64.2
| | | VAS

CTS-I - Carpal Tunnel Syndrome Instrument

VAS - Visual Analog Scale

#### Conclusions

There is some evidence to suggest that most untreated patients with carpal tunnel syndrome have mild to moderate functional difficulties before treatment. However, this evidence is derived from only two studies comprised of a total of 51 patients. This is too few patients and too few studies to allow one to reach a firm evidence-based conclusion.

### Question #11: What are the functional limitations of an individual with carpal tunnel syndrome after treatment?

This question inquires about the functional limitations of an individual after they have received conservative or surgical treatment for carpal tunnel syndrome. Our objective is as described in Question 10 for carpal tunnel syndrome. As also discussed in Question 10, our approach is governed by the available literature. We refer the reader to that question for additional details.

#### Excluded studies

As discussed in the Methods section, we retrieved articles identified by our literature searches according to certain a priori criteria. However, not all of the retrieved studies met our more specific inclusion criteria for this question. Table 161 shows these latter studies and the reason we did not consider them for this question.

Table 161. Excluded studies

Author | Reason for exclusion
Provinciali (2000) ^427^ | Used Jebsen-Taylor test to measure functional limitation. The test is not validated for carpal tunnel syndrome
Atroshi (1999) ^486^ | Study group overlaps with Atroshi et al. ^326^
Bessette (1998) ^487^ | Used SF-36 scale that is not accurate for carpal tunnel syndrome (see Question 9 for carpal tunnel syndrome)
Davis (1998) ^438^ | Used CTOA-I scale that has not been validated against accepted functional scales for carpal tunnel syndrome
Katz (1998) ^462^ | Study group contains an unspecified number of the same patients evaluated in Katz et al. ^482^
Atroshi (1997) ^483^ | Lack of information about treatment status of the study group
Katz (1996) ^488^ | Study group contains an unspecified number of the same patients evaluated in Katz et al. ^482^
Katz (1994) ^303^ | Biased post-hoc selection of patients for analysis

#### Evidence base

Twelve studies (with a total of 1567 patients) that addressed this question remained after the above exclusions.

#### Internal Validity

Aspects of study quality that are most relevant to the present question are shown in Table 162. Because we are cataloging functional status rather than using it to compare treatment, randomization and the use of control groups are not of paramount importance here. Therefore, Table 162 does not depict these aspects of study design. However, the following variables are particularly important: attrition rates, whether the trial was prospective, and whether the raters of functional status (in this case the patients) were blinded to the treatment the patient received.

Table 162. Study quality

Author | Number of patients | Number of centers | Funded by a for-profit agency? | Prospective | Blinding | % Attrition | Intent to treat analysis | % Compliance
Mondelli (2000) ^311^ | 110 | 1 | No | NR | No | 15.5 | No | NA
Porras (2000) ^313^ | 85 | 1 | NR | Yes | No | 0 | Yes | NA
Walker (2000) ^34^ | 21 | 1 | No | Yes | No | 19.0 | No | 92
Vaile (1999) ^485^ | 30 | 2 | NR | Yes | No | 0 | Yes | NR
Atroshi (1998) ^326^ | 111 | 1 | No | Yes | No | 8.1 | No | NA
Katz (1998) ^482^ | 429 | 26 | No | Yes | No | 21 (6 months) | No | NR
| | | | | | 28 (18 months)
| | | | | | 31 (30 months)
Atroshi (1997) ^477^ | 277 | 1 | No | NA | NA | 24 | No | NR
Pransky (1997) ^476^ | 165 | 1 | No | Yes | No | 13 | No | NR
| | | | | | 37 (18 months)
Amadio (1996) ^484^ | 22 | 1 | No | Yes | No | 0 | Yes | NA
Blair (1996) ^428^ | 86 | 1 | No | Yes | Single (partly) | 11.8 | No | NA
Worseg (1996) ^44^ | 126 | 1 | No | Yes | No | 0 | Yes | NA
Levine (1993) ^393^ | 105 | 1 | No | Yes (partly) | No | Not clear | Yes | NR

NR -Not reported

None of the studies that reported attrition performed an intent-to-treat analysis. Four studies reported an attrition rate that exceeded 20 percent. This is sufficient attrition to cast doubt on the internal validity of the studies. Nine of 12 studies were prospective. In another study, some, but not all, patients were prospectively enrolled. No studies employed blinding of patients to the treatment they received. Because it is difficult to blind patients to the treatment received (especially surgical treatments), we are considering unblinded studies to be of acceptable quality for this question.

#### Generalizability

Selected patient characteristics are presented in Table 163. Ten of 12 studies (83.3%) reported mean patient age and all studies reported percentage of female patients. The mean ages of patients in surgical studies (53.4 years) was similar to that reported in epidemiological studies (see Introduction section, subheading epidemiology) and the average obtained from the 124 surgical studies (50.5 years) that were evaluated for any question in this document (see Question 2). The percentage of female patients in surgical studies was generally similar to that observed when compared to all surgical studies. The non-surgical study by Walker et al. (2000) reported a low percentage of females (4.8%) compared to the typical carpal tunnel population. ^34^ This study examined Veterans Administration patients, a population that is overwhelmingly male.

Table 163. Patient characteristics

Author | Number of patients | Mean age (range) | % female | Duration of condition mean and range (months) | % Patients with diabetes | % Patients with arthritis | % Patients with prevous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Did the study exclude patients with severe disease? | Did the study exclude patients with mild disease?
Mondelli (2000) ^311^ | 110 | 56 (20–82) | 86.0 | NR | 5.4 | 0 | 4.3 | NR | 1.1 | NR | 0 | NR | NR
Porras (2000) ^313^ | 85 | 52 (18–81) | 90.6 | 39 (6–300) | NR | NR | NR | NR | NR | NR | NR | NR | NR
Walker (2000) ^34^ | 21 | 60 (44–81) | 4.8 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Vaile (1999) ^485^ | 30 | (29–84) | 81.5 | NR | NR | 55.6 | NR | 7.4 | NR | NR | NR | NR | NR
Atroshi (1998) ^326^ | 111 | 52 (21–88) | 65.7 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Katz (1998) ^482^ | 429 | NR | 74.2 | NR | NR | NR | NR | NR | NR | 0 | NR | NR | NR
Atroshi (1997) ^477^ | 277 | WC: 41 (25–62) | 77.8 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
| | Non-WC: 49 (13–91)
Pransky (1997) ^476^ | 165 | 46 (22–80) | 67 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Amadio (1996) ^484^ | 22 | 60 (33–80) | 59.1 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Blair (1996) ^428^ | 86 | 49 (23–82) | 82.7 | NR | NR | NR | NR | NR | 0 | NR | NR | NR | NR
Worseg (1996) ^44^ | 126 | 56 (35–90) | 69.8 | 23.4 | NR | NR | NR | NR | 0 | NR | NR | NR | NR
Levine (1993) ^393^ | 105 | 58 (19–88) | 74.3 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR

NR -Not reported

For the remaining categories, two studies reported duration of symptoms, zero to three studies reported specific comorbidities, and no studies reported selection of patients based on severity of disease.

Few studies reported information on patient employment or occupation (Table 164). Two of 12 studies (16.7%) reported percentage of patients employed, six of 12 (50%) reported percentage on workers' compensation, two of 12 (16.7%) reported specific patient occupations, and only one study (8.3%) reported percentage of patients retired or homemakers. There is not enough information in epidemiological studies to determine the relative generalizability of these studies regarding patient occupation. Likewise, there were too few studies in the larger group of 124 surgical studies that reported this type of information to determine generalizability.

Table 164. Patient occupation

Author | Number of patients | % Patients employed | % Patients on Workers Compensation | % Patients retired | % Patients homemakers | Reported Occupations
Mondelli (2000) ^311^ | 110 | NR | NR | NR | NR | NR
Porras (2000) ^313^ | 85 | NR | NR | NR | NR | Homemaker, low functional demand, cleaners, keyboard workers, heavy work, assembly line
Walker (2000) ^34^ | 21 | NR | NR | NR | NR | NR
Vaile (1999) ^485^ | 30 | NR | 0 | NR | NR | NR
Atroshi (1998) ^326^ | 111 | NR | NR | NR | NR | NR
Katz (1998) ^482^ | 429 | NR | 38.2 | NR | NR | NR
Atroshi (1997) ^477^ | 277 | NR | 28.8 | NR | NR | NR
Pransky (1997) ^476^ | 165 | 89 | 10 | NR | NR | NR
Amadio (1996) ^484^ | 22 | 63.6 | 0.9 | NR | NR | NR
Blair (1996) ^428^ | 86 | NR | NR | NR | NR | NR
Worseg (1996) ^44^ | 126 | NR | NR | 47.6 | 6.3 | Retired, employee, worker, unemployed, homemaker, other
Levine (1993) ^393^ | 105 | NR | 12.4 | NR | NR | NR

NR -Not reported

#### Results

Table 165 shows the results of the two nonsurgical studies of post-treatment functional limitations in patients with carpal tunnel syndrome. Since these studies used different scales to measure functional status, their scores are not directly comparable. Both studies suggested that after nonsurgical treatment, patients score, on average, in the lower range (the 20–30% level) of functional status scales. ^34,^ ^485^ However, it is unclear whether the results of these two studies are generalizable to the larger patient population.

Table 165. Studies with patients who had no prior treatment

Study | N | Treatment | Scale | Range of scale | Overall mean post-treatment functional status score (± SD) | % of maximum score
Walker (2000) ^34^ | 21 | Non-surgical (splints) | CTS-I | 1–5 | Splint (night only): 2.14 (0.87) | 28.5
| | | | | Splint (full-time): 1.93 (0.77) | 23.3
Vaile (1999) ^485^ | 30 | Non-surgical (steroid injections) | Vaile | 0–100 | 23.8 (26.2) | 23.8
| | | VAS

CTS-I - Carpal Tunnel Syndrome Instrument

VAS - Visual Analog Scale

Table 166 shows the results of the two surgical studies that reported individual functional activity mean scores using the CTS-I scale. Lower scores on this scale indicate less functional limitation. Table 167 shows the number of patients for each level of the scale in the surgical study of Atroshi et al. (1998). ^326^

Table 166. Studies with post-treatment functional limitation data for patients with carpal tunnel syndrome (individual functional activities - mean scores from CTS-I)

Study | N | Treatment | Range of scale | Writing | Holding a book | Buttoning clothes | Gripping the telephone | Opening jars | Performing household chores | Carrying a grocery bag | Bathing and dressing
Atroshi (1998) ^326^ | 111 | Endoscopic release | 1–5 | 1.5 | 1.7 | 1.7 | 1.5 | 2.1 | 1.7 | 2.1 | 1.3
Worseg (1996) ^44^ | 126 | Endoscopic release | 1–5 | 1.0 (0.2)^a^ | 1.0 (0.1) | 1.0 (0.1) | 1.0 (0.1) | 1.6 (0.7) | 1.4 (0.8) | 1.4 (0.8) | 1.2 (0.4)
| | Open release | | 1.0 (0.2) | 1.0 (0.2) | 1.2 (0.4) | 1.1 (0.2) | 1.9 (0.8) | 1.2 (0.4) | 1.7 (0.8) | 1.2 (0.4)

a Numbers in parentheses indicate standard deviations

Table 167. Studies with post-treatment functional limitation data for patients with carpal tunnel syndrome (individual functional activities - number of patients)

Study | N | Score | Number of patients in each CTS-I Functional Status category (%)
| | | Writing | Holding a book | Buttoning clothes | Gripping the telephone | Opening jars | Performing household chores | Carrying a grocery bag | Bathing and dressing
Atroshi (1998) ^326^ | 111 | 1 | 69 (70.4) | 59 (60.2) | 59 (59.6) | 69 (72.6) | 42 (42.4) | 56 (56.6) | 41 (42.3) | 77 (77)
| | 2 | 17 (17.3) | 21 (21.4) | 19 (19.2) | 12 (12.6) | 26 (26.3) | 21 (21.2) | 25 (25.8) | 18 (18)
| | 3 | 6 (6.1) | 9 (9.2) | 15 (15.2) | 7 (7.4) | 13 (13.1) | 16 (16.2) | 16 (16.5) | 3 (3)
| | 4 | 6(6.1) | 9 (9.2) | 2 (2.0) | 4 (4.2) | 14 (14.1) | 4 (4.0) | 12 (12. 4) | 2 (2)
| | 5 | 0 (0) | 0 (0) | 4 (4.0) | 3 (3.2) | 4 (4.0) | 1 (1.0) | 3 (3.1) | 0 (0)

Table 168 shows the results of a third surgical study, performed by Blair et al. ^428^ Although these latter authors did not use a specific scale, they did report the number of patients who had difficulty with specific functional activities. Both of these studies suggest that patients have relatively mild functional limitations following surgery, and the study by Blair et al. suggests that the majority of patients do not have any noticeable difficulty with certain functional activities after surgery.

Table 168. Studies with post-treatment functional limitation data for patients with carpal tunnel syndrome (individual functional activities - number of patients)

Study | Treatment | Difficulty | Self-described difficulty in performing selected activities of daily living after carpal tunnel release (% of patients)
| | | Screwing lids | Picking up small objects | Lifting
Blair (1996) ^428^ | Open release plus epineurotomy (n = 48) | Yes | 15 (31.3) | 9 (18.8) | 9 (18.8)
| | No | 33 (68.8) | 39 (81.3) | 39 (81.3)
| Open release without epineurotomy (n = 27) | Yes | 11 (40.7) | 10 (37.0) | 7 (25.9)
| | No | 16 (59.3) | 17 (63.0) | 20 (74.1)

Seven studies reported overall mean functional activity scores on the CTS-I scale prior to surgery (Table 169). Four out of seven studies did not describe the surgical procedure, so no evidence-based conclusions can be reached concerning functional limitations after specific surgical procedures. However, one can make some broad conclusions about functional limitations after surgical procedures as a group. These studies suggested that most patients report no-to-moderate difficulty with functional activities (mean 1.4–2.6 on CTS-I) after surgery. Although there were no statistically significant posttreatment differences between specific patient groups, in two studies there was a trend toward more difficulty with functional activities among patients receiving workers' compensation.

Table 170. Studies with post-treatment functional limitation data for patients with carpal tunnel syndrome (summary function score on UEFS)

Study | N | Treatment | Study Design | Range of scale | Followup time | Overall summary post-treatment functional status score (SD) | % of maximum score
Pransky (1997) ^476^ | 108 | Surgical or non-surgical (not described) | Prospective case series | 1–10 | Mean: 18 months | 25.4 (18.1)* | 17.1
| | | | | | Note: this study also had a case series of mixed upper extremity disorders (UEDs)

Table 169. Studies with post-treatment functional limitation data for patients with carpal tunnel syndrome (mean function score on CTS-I)

Study | N | Treatment | Study Design | Range of scale | Followup time | Overall mean post-treatment functional status score (SD) | % of maximum score
Mondelli (2000) ^311^ | 110 | Surgical (open release) | Prospective case series | 1–5 | 1 month | 2.0 (0.7) | 25
| | | | | 6 months | 1.5 (0.6) | 12.5
Porras (2000) ^313^ | 85 | Surgical (open release) | Prospective case series | 1–5 | 6 months | 1.4 (range 1–4.2) | 10
Atroshi (1998) ^326^ | 111 | Surgical (endoscopic release) | Prospective case series | 1–5 | 3 months | 1.7 (range 1.6–1.9) | 17.5
Katz (1998) ^482^ | 429 | Surgical (n = 270, procedures not described) | Prospective case series (stratified) | 1–5 | 6 months | Surgical patients: >55 years: 1.7 (0.9) | 17.5
| | Non-surgical (n = 125) | | | | ≤55 years, WC non-recipient:: 1.6 (0.7) | 15
| | (34 patients who crossed over to surgery were not evaluated) | | | | ≤55 years, WC recipient: 2.1 (0.9) | 27.5
| | | | | | Non-surgical patients: >55 years: 2.6 (0.8) | 40
| | | | | | ≤55 years, WC non-recipient:: 1.9 (0.9) | 22.5
| | | | | | ≤55 years, WC recipient: 2.2 (0.7) | 30
| | | | | 18 months | Surgical patients: >55 years: 1.6 (0.7) | 15
| | | | | | ≤55 years, WC non-recipient: 1.6 (0.7) | 15
| | | | | | ≤55 years, WC recipient: 2.2 (0.9) | 30
| | | | | | Non-surgical patients: >55 years: 2.3 (0.9) | 32.5
| | | | | | ≤55 years, WC non-recipient:: 2.0 (1.0) | 25
| | | | | | ≤55 years, WC recipient: 2.4 (0.7) | 35
| | | | | 30 months | Surgical patients: >55 years: 1.6 (0.9) | 15
| | | | | | ≤55 years, WC non-recipient: 1.6 (0.7) | 15
| | | | | | ≤55 years, WC recipient: 2.2 (1.0) | 30
| | | | | | Non-surgical patients: >55 years: 2.2 (0.8) | 30
| | | | | | ≤55 years, WC non-recipient:: 2.0 (0.9) | 25
| | | | | | ≤55 years, WC recipient: 2.2 (0.8) | 30
Atroshi (1997) ^477^ | 277 | Surgical or non-surgical (or both) (procedures not described) | Cross-sectional study | 1–5 | 6–20 months | WC patients: 2.5 (95% CI: 2.2–2.7) | 37.5
| | | | | | Non-WC patients: 2.2 (2.0–2.4) | 30
Amadio (1996) ^484^ | 22 | Surgical (not described) | Prospective case series | 1–5 | 3 months | 1.77 (0.68) | 19.3
Levine (1993) ^393^ | 67 | Surgical or non-surgical (not described) | Prospective case series | 1–5 | 3 months | Prospective: 2.1 (1.1) | 27.5
| 38 | Surgical (not described) | Retrospective case series | | Median: 14 months | Retrospective: 2.0 (1.1) | 25

WC - Workers' Compensation

The utility of functional status scales would be enhanced if they could be shown to predict work-related outcomes. The relevance of the CTS-I scale in relating functional limitation to work-related outcomes was examined by the Maine Carpal Tunnel Study (Katz et al.). ^462^ Results of this study suggest that patients with functional difficulty at six months after treatment have greater odds of being absent from work at 18 months post-treatment (odds ratio 3.3, 95% CI 1.5–6.9, p = 0.002). This odds ratio, as determined by logistic regression was per one unit change on the CTS-I scale. However, the available data were insufficient to allow an estimation of the percentage of patients with a particular score who were absent from work.

#### Conclusions

Although studies of non-surgical therapies suggested that most patients experience only mild difficulty with functional activities after treatment, it is unclear whether the results of these two studies are generalizable to the larger patient population. Studies with surgical outcomes suggested that most patients report no-to-moderate difficulty with functional activities (mean 1.4–2.6 on CTS-I) after surgery. Although there were no statistically significant differences between specific patient groups, in two studies there was a trend toward more difficulty with functional activities among workers' compensation patients. Decreased functional ability on the CTS-I scale shows a strong correlation with work absence. The available data are insufficient to determine a cutoff point on measuring scales above which patients are unable to work.

## Cubital Tunnel Syndrome

### Question #1: What are the appropriate methods and approaches for the early identification and diagnosis of cubital tunnel syndrome?

#### Evidence Base

Articles were included in this analysis if they reported data that could be used for evaluation of the test in diagnosing cubital tunnel syndrome, and they included ten or more patients.

Twenty-two articles met the initial inclusion criteria. Two (Table 171) were subsequently excluded because they contained no diagnostic data. The remaining 20 articles reported on a total of at least 557 cubital tunnel syndrome patients and at least 448 controls. These figures are approximate because Odusote et al. did not report the number of patients or controls in their study ^489^ and Eisen et al. did not report the number of controls in their 1974 article. ^490^ Three of the articles (15%) reported on multi-center trials; the rest were conducted at single centers. Half of the articles were from the United States, and half were from other countries.

Table 171. Excluded Studies

Author | Reason for Exclusion
Okamoto, 2000 ^493^ | No diagnostic data
Rosenberg, 1995 ^494^ | No diagnostic data

Two articles (10%) reported only summary data for groups of patients (i.e., mean test results for cubital tunnel syndrome group and for control group). Four articles (20%) reported patient-level data either in tables or in charts from which counts of patients with positive and negative test results could be made. The remaining 14 articles reported those counts directly, but only nine articles (45% of total) reported sufficient information on both cubital tunnel syndrome patients and normal controls to permit both sensitivity and specificity to be determined. Details on data reporting levels and other characteristics of each study are found in Table 181 through Table 183.

Table 182. Cubital Tunnel Syndrome-Patient Groups

Article | Disorder type | Patient selection | Number of patients | Percent female | Mean age | Age of youngest | Age of oldest | Duration of condition before treatment (mths) | Shortest duration (months) | Longest duration (months) | Patient comorbidities reported?
Montagna, 2000 ^227^ | Carpal tunnel syndrome | Unspecified diagnosis | 30 | NR | | | | | | | No
Montagna, 2000 ^227^ | Cubital tunnel syndrome | Unspecified diagnosis | 10 | NR | | | | | | | No
Montagna, 2000 ^227^ | Normal | Healthy volunteers | 15 | NR | | | | | | | No
Ellemann, 1999 ^495^ | Cubital tunnel syndrome | Symptoms/ presented | 39 | 54 | 46 | 21 | 72 | | | | Yes
Merlevede, 1999 ^496^ | Other | Other | 24 | NR | | | | | | | Yes
Merlevede, 1999 ^496^ | Normal | Healthy volunteers | 60 | 63 | 33.6 | 13 | 61 | | | | Yes
Merlevede, 1999 ^496^ | Cubital tunnel syndrome | Simple nerve conduction | 10 | NR | | | | | | | Yes
Chiou, 1998 ^497^ | Cubital tunnel syndrome | Symptoms/ presented | 14 | 43 | 50 | 21 | 80 | | | | No
Chiou, 1998 ^497^ | Normal | Healthy volunteers | 10 | 50 | 45 | 30 | 60 | | | | No
Dellon, 1997 ^107^ | Normal | Other | 52 | 62 | | | | | | | Yes
Dellon, 1997 ^107^ | Carpal tunnel syndrome | Unspecified diagnosis | 72 | NR | | | | | | | Yes
Dellon, 1997 ^107^ | Cubital tunnel syndrome | Unspecified diagnosis | 42 | NR | | | | | | | Yes
Kaneko, 1997 ^250^ | Carpal tunnel syndrome | Unspecified diagnosis | 15 | 87 | | 40 | 54 | | | | Yes
Kaneko, 1997 ^250^ | Cubital tunnel syndrome | Unspecified diagnosis | 10 | 20 | | 45 | 56 | | | | Yes
Kaneko, 1997 ^250^ | Normal | Healthy volunteers | 46 | 22 | | 25 | 45 | | | | Yes
Kaneko, 1997 ^250^ | Combined WRUEDs | Unspecified diagnosis | 10 | 50 | | 40 | 62 | | | | Yes
Britz, 1996 ^498^ | Cubital tunnel syndrome | Symptoms/ presented | 27 | 11 | 51 | 31 | 69 | | | | No
Britz, 1996 ^498^ | Normal | Healthy volunteers | 10 | NR | | | | | | | No
Kingery, 1995 ^499^ | Cubital tunnel syndrome | Symptoms/ presented | 42 | NR | 51 | 32 | 72 | | | | No
Kingery, 1995 ^499^ | Other | Other | 40 | NR | 47 | 28 | 76 | | | | No
Tassler, 1995 ^115^ | Carpal tunnel syndrome | Unspecified diagnosis | 14 | NR | | | | | | | Yes
Tassler, 1995 ^115^ | Cubital tunnel syndrome | Unspecified diagnosis | 13 | NR | | | | | | | Yes
Novak, 1994 ^500^ | Normal | Healthy volunteers | 33 | 39 | 41 | 23 | 59 | | | | No
Novak, 1994 ^500^ | Cubital tunnel syndrome | Simple nerve conduction | 32 | 41 | 46 | 24 | 81 | | | | No
Uchida, 1993 ^501^ | Cubital tunnel syndrome | Unspecified diagnosis | 60 | 23 | 48.6 | 17 | 74 | | | | Yes
Robinson, 1992 ^502^ | Cubital tunnel syndrome | Unspecified diagnosis | 22 | 55 | | 18 | 65 | 7.5 | 16 | | No
So, 1989 ^173^ | Normal | Healthy volunteers | 20 | NR | | | | | | | No
So, 1989 ^173^ | Carpal tunnel syndrome | Unspecified diagnosis | 22 | NR | | | | | | | No
So, 1989 ^173^ | Cubital tunnel syndrome | Unspecified diagnosis | 15 | NR | | | | | | | No
Buehler, 1986 ^503^ | Cubital tunnel syndrome | Unspecified diagnosis | 13 | NR | | | | | | | Yes
Kimura, 1984 ^55^ | Normal | Healthy volunteers | 25 | 40 | 40.8 | 20 | 66 | | | | No
Kimura, 1984 ^55^ | Cubital tunnel syndrome | Symptoms/ presented | 44 | 32 | 41.6 | 18 | 64 | | | | No
Tackmann, 1984 ^54^ | Normal | Healthy volunteers | 52 | NR | a-39 | 20 | 69 | | | | No
Tackmann, 1984 ^54^ | Cubital tunnel syndrome | Symptoms/ presented | 103 | NR | a-43 | 12 | 76 | | 0 | 72 | No
Odusote, 1979 ^489^ | Other | Other | 230 | NR | 48.8 | 17 | 88 | | | | Yes
Odusote, 1979 ^489^ | Cubital tunnel syndrome | Symptoms/ presented | NR | NR | 56.1 | 21 | 83 | 34.4 | 1 | 636 | Yes
Odusote, 1979 ^489^ | Cubital tunnel syndrome | Symptoms/ presented | NR | NR | 49.8 | 30 | 78 | 9.6 | 0 | 108 | Yes
Odusote, 1979 ^489^ | Cubital tunnel syndrome | Symptoms/ presented | NR | NR | 49.2 | 16 | 70 | 11.2 | 0 | 108 | Yes
Odusote, 1979 ^489^ | Cubital tunnel syndrome | Symptoms/ presented | NR | NR | 45.6 | 22 | 77 | 16.4 | 0 | 120 | Yes
Ring, 1979 ^504^ | Cubital tunnel syndrome | Workers at risk | 32 | 6 | 40.6 | | | | | | No
Ring, 1979 ^504^ | Normal | Healthy volunteers | 50 | 48 | 27.2 | | | | | | No
Eisen, 1977 ^298^ | Normal | Healthy volunteers | 60 | NR | 41.5 | 11 | 74 | | | | No
Eisen, 1977 ^298^ | Carpal tunnel syndrome | Complex objective standard | 30 | NR | 56.1 | 21 | 76 | | | | No
Eisen, 1977 ^298^ | Combined WRUEDs | Other | 23 | NR | 50 | 7 | 68 | | | | No
Eisen, 1977 ^298^ | Cubital tunnel syndrome | Complex objective standard | 18 | NR | 51.7 | 26 | 65 | | | | No
Eisen, 1974 ^490^ | Normal | Healthy volunteers | NR | NR | 43.7 | 19 | 78 | | | | No
Eisen, 1974 ^490^ | Cubital tunnel syndrome | Symptoms/ presented | 30 | 50 | 42.9 | 17 | 66 | | | | No

a —Study reported median age rather than mean age

Table 180. Cubital Tunnel Syndrome-Test Types Reported

Article | Signs/Symptoms | Sensory Tests | Nerve Conduction | Composite Nerve Conduction | Imaging | Other
Montagna, 2000 ^227^ | □ | □ | □ | □ | □
Ellemann, 1999 ^495^ | □ | | □ | | □ | □
Merlevede, 1999 ^496^ | □ | □ | | | □ | □
Chiou, 1998 ^497^ | □ | □ | □ | □ | | □
Dellon, 1997 ^107^ | | | □ | □ | □ | □
Kaneko, 1997 ^250^ | □ | □ | | | □ | □
Britz, 1996 ^498^ | | □ | □
Kingery, 1995 ^499^ | | □ | | | □
Tassler, 1995 ^115^ | □ | | □ | | □ | □
Novak, 1994 ^500^ | | □ | □ | □ | □ | □
Uchida, 1993 ^501^ | □ | □ | | □ | □ | □
Robinson, 1992 ^502^ | | | □ | □ | □ | □
So, 1989 ^173^ | □ | □ | | □ | □
Buehler, 1986 ^503^ | | □ | □ | □ | □ | □
Kimura, 1984 ^55^ | □ | □ | | | □
Tackmann, 1984 ^54^ | □ | □ | | | □ | □
Odusote, 1979 ^489^ | □ | □ | | | □
Ring, 1979 ^504^ | | □ | | | □ | □
Eisen, 1977 ^298^ | □ | □ | | | □ | □
Eisen, 1974 ^490^ | □ | □ | | | □ | □

Table 181. Cubital Tunnel Syndrome-Study Design

Article | Centers | Cubital tunnel groups | Cubital tunnel patients | Negative groups | Negative subjects | Prospective or retrospective design | Level of reporting | Could sensitivity and specificity be determined?
Montagna, 2000 ^227^ | Single | 1 | 10 | 1 | 15 | NR | Counts | Reported by authors
Ellemann, 1999 ^495^ | Multiple (<5) | 1 | 39 | 0 | 0 | NR | Patient level | Reported by authors (note: normed to contralateral hand)
Merlevede, 1999 ^496^ | Single | 1 | 10 | 1 | 60 | NR | Patient level | Calculated by ECRI
Chiou, 1998 ^497^ | Single | 1 | 14 | 1 | 10 | NR | Summary | No: only summary statistics reported
Dellon, 1997 ^107^ | Single | 1 | 42 | 1 | 52 | NR | Counts | Control data not reported
Kaneko, 1997 ^250^ | Single | 1 | 10 | 1 | 46 | NR | Summary | No: only summary statistics reported
Britz, 1996 ^498^ | Multiple (<5) | 1 | 27 | 1 | 10 | Prospective | Patient level | Reported by authors
Kingery, 1995 ^499^ | Single | 1 | 42 | 1 | 40 | NR | Counts | Reported by authors
Tassler, 1995 ^115^ | Single | 1 | 13 | 1 | 14 | Retrospective | Counts | Reported by authors
Novak, 1994 ^500^ | Single | 1 | 32 | 1 | 33 | NR | Counts | Reported by authors
Uchida, 1993 ^501^ | Single | 1 | 60 | 0 | 0 | Retrospective | Counts | No: no control group
Robinson, 1992 ^502^ | Single | 1 | 22 | 0 | 0 | Retrospective | Counts | No: no control group
So, 1989 ^173^ | Single | 1 | 15 | 1 | 20 | NR | Counts | Reported by authors
Buehler, 1986 ^503^ | Single | 1 | 13 | 0 | 0 | NR | Counts | No: no control group
Kimura, 1984 ^55^ | Single | 1 | 44 | 1 | 25 | NR | Counts | Control data not reported
Tackmann, 1984 ^54^ | Single | 1 | 103 | 1 | 52 | NR | Counts | Control data not reported
Odusote, 1979 ^489^ | Single | 4 | 237 | 1 | 230 | NR | Counts | Reported by authors
Ring, 1979 ^504^ | Multiple (<5) | 1 | 32 | 1 | 50 | Prospective | Counts | Control data not reported
Eisen, 1977 ^298^ | Single | 1 | 18 | 1 | 60 | NR | Patient level | Calculated by ECRI
Eisen, 1974 ^490^ | Single | 1 | 30 | 1 | 48 limbs | Prospective | Counts | Control data not reported

Table 183. Cubital Tunnel Syndrome - Inclusion and Exclusion Criteria

Article | Reported Patient Inclusion Criteria | Reported Patient Exclusion Criteria
Montagna, 2000 ^227^ | Diagnosed with carpal tunnel or cubital tunnel. | None reported
Ellemann, 1999 ^495^ | Admitted for surgical treatment for symptoms consistent with sulcus compression in the ulnar nerve at the elbow: weakness of the small hand muscles innervated by the ulnar nerve, sensory disturbances, paresthesia, and tingling or pain in the ulnar, palmar side of the hand or little finger. | Exposure to vibration within the previous 24 hours, systemic illness, possible secondary neuropathies, polyneuropathy.
Merlevede, 1999 ^496^ | Cubital tunnel patients: Obvious ulnar neuropathy at the elbow. Motor or sensory deficit, and either 1) partial/complete motor conduction block across the elbow, or 2) MCV across the elbow <50 m/s. Other patients: Other neurological disorders but no symptoms of ulnar neuropathy. | None reported
Chiou, 1998 ^497^ | Complaints of aching pain and numbness over the medial elbow, ulnar side of the forearm, and ring and little fingers. | None reported
Dellon, 1997 ^107^ | Already diagnosed with either carpal tunnel or cubital tunnel. Diagnosis was based on the clinical history and physical examination, which included positive provocative testing, positive Tinel's sign at the wrist or elbow, abnormal tuning fork perception. | Cervical radiculopathy, diabetes, thoracic outlet syndrome, thyroid disease, collagen vascular disease, using narcotics or antidepressants.
Kaneko, 1997 ^250^ | Group 01: Coexisting entrapment neuropathy and cervical cord compression demonstrated by MRI. Group 02: Diagnosed with carpal tunnel. Group 03: Diagnosed with cubital tunnel. Group 04: Control group, no subjective symptoms or neurologic findings associated with peripheral or central lesions. | None reported
Britz, 1996 ^498^ | History and physical exam consistent with cubital tunnel syndrome. Symptoms included numbness and paresthesias of the ring and little fingers and weakness and clumsiness of the hand. | None reported
Kingery, 1995 ^499^ | Chronic paresthesias in the ulnar distribution | Carpal tunnel, brachial plexopathy, cervical radiculopathy, polyneuropathy.
Tassler, 1995 ^115^ | Symptomatic patients who had been diagnosed, had not been cured by nonoperative methods, and later received surgery for the condition. | Diabetes, alcoholism, other toxicity.
Novak, 1994 ^500^ | Patients diagnosed with cubital tunnel based on symptoms and nerve conduction tests. Symptoms included complaints of paresthesia and numbness in the ulnar nerve distribution. Nerve conduction criteria was conduction velocity across the elbow <50 m/s and a decrease of 15% at the elbow. | Previous surgery, or brachial plexus decompression.
Uchida, 1993 ^501^ | Signs and/or symptoms of high ulnar nerve palsy, and MCV across the elbow <48 m/s. | Radiculopathy, other signs and symptoms.
Robinson, 1992 ^502^ | Pre-operatively evaluated patients with cubital tunnel syndrome. Clinical diagnosis as well as positive nerve conduction for cubital tunnel based on a reduction to two-third of normal. | Intrinsic atrophy
So, 1989 ^173^ | Patients were selected from referrals to the lab. Carpal tunnel: Confident clinical diagnosis based on history of pain and paresthesias in the hand and fingers, and physical findings that localized the pathology to the median nerve, e.g. sensory alteration or weakness in a median nerve distribution, Tinel's, or Phalen's. Cubital tunnel: Confident clinical diagnosis based on paresthesias or numbness in an ulnar nerve distribution, usually accompanied by weakness in ulnar-innervated muscles. In those patients without weakness on examination, the diagnosis of ulnar neuropathy at the elbow was not made unless there was percussion sensitivity at the cubital tunnel or the ulnar groove, or exacerbation of symptoms with elbow flexion. | None reported
Buehler, 1986 ^503^ | History and clinical findings consistent with cubital tunnel, confirmed by nerve conduction tests. | Generalized neuropathy, cervical disc disease, arthritis, elbow trauma.
Kimura, 1984 ^55^ | Patients with frank clinical signs and symptoms suggestive of cubital tunnel syndrome. | History of trauma, clinical or x-ray evidence of joint deformity or disease that predisposed to peripheral neuropathy.
Tackmann, 1984 ^54^ | Referred to lab with a clinical diagnosis of cubital tunnel syndrome. | None reported
Odusote, 1979 ^489^ | Symptomatic cubital tunnel syndrome. | Ulnar nerve lesion at the wrist, brachial plexus lesion, thoracic outlet syndrome, disease of the cervical roots, anterior horn cell disease, generalized polyneuropathy, familial multiple entrapment neuropathy, exposure to neurotoxins.
Ring, 1979 ^504^ | Sample of diamond polishers referred by their union for study participation. Not known to have major illness or ulnar nerve damage at the time of referral. | None reported
Eisen, 1977 ^298^ | Carpal tunnel patients: Sensory symptoms limited to one or both hands, normal ulnar sensory latency (<2.8 ms), normal ulnar sensory amplitude (>8.4 uV), and at least three of the following five criteria: 1) Sensory signs restricted to median distribution; 2) Weakness or wasting of the APB muscle; 3) Median DML >4.5 ms; 4) Median DSL >2.7 ms; 5) Median SNAP amplitude <8.6 uV or median SNAP duration >2.4 ms. Cubital tunnel patients: Sensory symptoms limited to one or both hands, normal median sensory latency (<2.7 ms), normal median sensory amplitude (>8.6 uV), and at least three of the following six criteria: 1) Sensory signs restricted to ulnar distribution; 2) Weakness or wasting of the ulnar-innervated muscles of the hand; 3) Ulnar DML >4.0 ms; 4) Ulnar proximal motor latency (stimulation just above the elbow) >8.9 ms; 5) Ulnar DSL >2.8 ms; 6) Ulnar SNAP amplitude <8.4 uV or ulnar SNAP duration >2.1 ms. Patients with proximal lesions: Sensory symptoms limited to one or both hands, but did not meet criteria for either carpal tunnel or cubital tunnel. | Subjects were excluded from the control group if there was neuromuscular disease, diabetes, alcoholism, peripheral neuropathy, or systemic dysfunction.
Eisen, 1974 ^490^ | Referred to lab because of subjective complaints of numbness and tingling limited to the ring and little fingers, and present for three or more weeks. | Definite muscle wasting or weakness, cervical disk disease, thoracic outlet syndrome, carpal tunnel, ulnar compression at the wrist, evidence for generalized neuropathy.

#### Internal Validity of Results

Table 172 details aspects of study design and reporting that bear on the internal validity of the results: whether the published results truly reflect the diagnostic effectiveness of the test as used in the trial. The quality of reporting of these characteristics is summarized in Table 173. Only two articles reported that the person interpreting the test was blinded to patients' group assignment, and only one reported that the person performing the test was blinded. Blinding helps assure that test results were free of intentional or unintentional biases. The numbers of men and women in the cubital tunnel syndrome and control groups were not reported in 11 of the 20 articles (55%). Without reporting of these figures, one cannot be sure that the results of these studies were free of sex bias. Likewise, seven articles (35%) failed to report ages of patients and controls, even though some of the tests are known to be affected by age.

Table 172. Study Design: Characteristics Affecting Internal Validity

Article | Funded by for-profit institution? | Inclusion criteria reported? | Exclusion criteria reported | Method of diagnosis reported | Patient selection | Comorbidity reported | Sex reported | Possible sex bias | Ages reported | Possible age bias | Duration of condition reported | Test operator blinded | Test reader blinded | Multiple readers | Method for multiple readers | Independent reference standard | Were patients given both test and reference
Montagna, 2000 ^227^ | NR | Yes | NR | NR | NR | NR | NR | GNR | NR | ANR | NR | NR | NR | NR | NR | No | No
Ellemann, 1999 ^495^ | NR | Yes | Yes | NR | NR | Yes | Yes | NC | Yes | NC | NR | NR | NR | NR | NR | No | No
Merlevede, 1999 ^496^ | NR | Yes | NR | Yes | NR | Yes | NR | GNR | NR | ANR | NR | NR | NR | NR | NR | No | No
Chiou, 1998 ^497^ | NR | Yes | NR | Yes | NR | NR | Yes | No | Yes | P | NR | NR | NR | 2 | NR | Yes | Yes
Dellon, 1997 ^107^ | Yes | Yes | Yes | Yes | NR | Yes | NR | GNR | NR | ANR | NR | NR | NR | NR | NR | Yes | Yes
Kaneko, 1997 ^250^ | NR | Yes | NR | Yes | NR | Yes | Yes | P | NR | ANR | NR | NR | NR | NR | NR | No | No
Britz, 1996 ^498^ | NR | Yes | NR | NR | Prospective | NR | Yes | GNR | Yes | ANR | NR | NR | Yes | NR | NR | No | No
Kingery, 1995 ^499^ | NR | Yes | Yes | Yes | NR | NR | NR | GNR | Yes | No | NR | NR | NR | NR | NR | No | No
Tassler, 1995 ^115^ | Yes | Yes | Yes | NR | Retrospective | Yes | NR | GNR | NR | ANR | NR | Yes | NR | NR | NR | Yes | Yes
Novak, 1994 ^500^ | No | Yes | Yes | Yes | NR | NR | Yes | No | Yes | P | NR | NR | NR | NR | NR | Yes | Yes
Uchida, 1993 ^501^ | NR | Yes | Yes | Yes | Retrospective | Yes | Yes | NC | Yes | NC | NR | NR | NR | NR | NR | No | No
Robinson, 1992 ^502^ | NR | Yes | Yes | Yes | Retrospective | NR | Yes | NC | NR | NC | Yes | NR | NR | NR | NR | No | No
So, 1989 ^173^ | NR | Yes | NR | Yes | NR | NR | NR | GNR | NR | ANR | NR | NR | Yes | NR | NR | Yes | No
Buehler, 1986 ^503^ | NR | Yes | Yes | Yes | NR | Yes | Yes | NC | NR | NC | NR | NR | NR | NR | NR | No | No
Kimura, 1984 ^55^ | NR | Yes | Yes | NR | NR | NR | Yes | No | Yes | No | NR | NR | NR | NR | NR | No | No
Tackmann, 1984 ^54^ | NR | Yes | NR | NR | NR | NR | NR | GNR | Yes | No | NR | NR | NR | NR | NR | No | No
Odusote, 1979 ^489^ | NR | Yes | Yes | NR | NR | Yes | NR | GNR | Yes | No | Yes | NR | NR | NR | NR | Yes | Yes
Ring, 1979 ^504^ | NR | Yes | NR | NR | Prospective | NR | Yes | C | Yes | P | NR | NR | NR | NR | NR | No | No
Eisen, 1977 ^298^ | NR | Yes | Yes | Yes | NR | NR | NR | GNR | Yes | P | NR | NR | NR | NR | NR | No | No
Eisen, 1974 ^490^ | NR | Yes | Yes | Yes | Prospective | NR | Yes | GNR | Yes | No | NR | NR | NR | NR | NR | No | No

[underlined: Key] :

Possible sex bias: No—proportion women in epicondylitis group within 20% of proportion of women in control group; P—Patients were more likely to be female; C—Controls were more likely to be female; GNR—Genders not reported for both groups; NC—Study did not contain a separate control group

Possible age bias: No—mean age of epicondylitis group within 5 years of mean age of control group; P—Patients were older than controls; C—Controls were older than patients; ANR—Ages not reported for both groups; NC—Study did not contain a separate control group

Method for multiple test readers: Indep—Independent

NR—Not reported

Table 173. Summary of Characteristics Affecting Internal Validity

Study characteristic | Number of studies reporting | Details
Whether trial was funded by a for-profit institution | 3 (15%) | For-profit funding: 2 (10%)
| | No such funding: 1 (5%)
Patient inclusion criteria | 20 (100%) | See Table 183
Patient exclusion criteria | 12 (60%) | See Table 183
Method of diagnosis | 12 (60%) | Clinical and NCS: 7 (35%)
| | NCS only: 3 (15%)
| | Clinical only: 2 (10%)
Was selection of patients prospective or retrospective? | 6 (30%) | Prospective: 3 (15%)
| | Retrospective: 3 (15%)
Were patient comorbidities reported? | 8 (40%) | Various
Was the sex distribution of patients reported? | 11 (55%) | ^a^Percentage female: 31.6%
Was the percentage of females in the patient group within 20 percentage points of the control group? | 5 (25%) | Yes: 4 (20%)
| | No, patients were = 20% more female: 0
| | No, control group was =20% more female: 1 (5%)
Were patient ages reported? | 12 (60%) | ^a, b^Mean age: 46.6
Was the mean patient age within 5 years of the mean control age? | 9 (45%) | Yes: 5 (25%)
| | No, patients were = 5 years older: 4 (20%)
Was the duration of patients' condition reported? | 1 (5%) | ^a^Mean duration: 7.5 months
Was the test operator blinded? | 1 (5%) | Yes: 1 (5%)
Was the test reader blinded? | 2 (10%) | Yes: 2 (10%)
Were there multiple test readers? | 1 (5%) | 2 readers: 1 (5%)
What was the method for multiple test readers? | 0 | NA
Was the test compared to an independent reference standard? | 6 (30%) | Yes: 6 (30%)
Were all patients given the test and the reference standard? | 6 (30%) | Yes: 5 (25%)
| | No: 1 (5%)

[underlined: Key:]

NA-not applicable

a Calculated on a per-patient basis (i.e., weighted by number of patients in each study reporting this characteristic)

b Calculation excludes study reporting median age ^54^ and study that failed to report the number of patients ^489^

#### Generalizability of Results

Table 174 lists study characteristics that might affect the generalizability of results from the patient population in the study to the patient population. The quality of reporting of these characteristics is summarized in Table 175. Many studies did not report important patient characteristics such as sex and previous treatment. Without this information, one cannot determine whether diagnostic results were affected by these variables, or whether the results were representative of test performance in routine practice.

Table 174. Study Design: Characteristics Affecting Generalizability of Results

Article | Years in which trial was conducted | Number of centers | Country where trial was conducted | Inclusion criteria reported? | Exclusion criteria reported | Patient comorbidity reported? | Sex reported | Ages reported | Duration of condition reported | Did all patients have previous conservative treatment? | Did any patients have previous surgical treatment? | Source of patients adequately described and generalizable to broader clinical practice? | Potential selection bias for easy cases? | Potential selection bias for difficult cases?
Montagna, 2000 ^227^ | NR | Single | Italy | Yes | NR | No | NR | NR | NR | No | No | No | Yes | No
Ellemann, 1999 ^495^ | NR | Multiple (<5) | Denmark | Yes | Yes | Yes | Yes | Yes | NR | No | No | No | Yes | No
Merlevede, 1999 ^496^ | NR | Single | Belgium | Yes | NR | Yes | NR | NR | NR | No | No | No | Yes | Yes
Chiou, 1998 ^497^ | NR | Single | Taiwan | Yes | NR | No | Yes | Yes | NR | No | No | No | No | No
Dellon, 1997 ^107^ | 1993 | Single | USA | Yes | Yes | Yes | NR | NR | NR | No | No | No | Yes | No
Kaneko, 1997 ^250^ | NR | Single | Japan | Yes | NR | Yes | Yes | NR | NR | No | No | No | Yes | No
Britz, 1996 ^498^ | NR | Multiple (<5) | USA | Yes | NR | No | Yes | Yes | NR | No | Yes | No | No | No
Kingery, 1995 ^499^ | NR | Single | USA | Yes | Yes | No | NR | Yes | NR | No | No | No | No | Yes
Tassler, 1995 ^115^ | 1993-1994 | Single | USA | Yes | Yes | Yes | NR | NR | NR | No | No | No | Yes | No
Novak, 1994 ^500^ | NR | Single | USA | Yes | Yes | No | Yes | Yes | NR | No | No | No | No | No
Uchida, 1993 ^501^ | 1985-1992 | Single | Japan | Yes | Yes | Yes | Yes | Yes | NR | No | No | No | No | No
Robinson, 1992 ^502^ | 1984-1988 | Single | Israel | Yes | Yes | No | Yes | NR | Yes | No | No | No | Yes | No
So, 1989 ^173^ | NR | Single | USA | Yes | NR | No | NR | NR | NR | No | No | Yes | No | No
Buehler, 1986 ^503^ | NR | Single | USA | Yes | Yes | Yes | Yes | NR | NR | No | No | No | Yes | No
Kimura, 1984 ^55^ | NR | Single | USA | Yes | Yes | No | Yes | Yes | NR | No | No | No | No | No
Tackmann, 1984 ^54^ | NR | Single | Germany | Yes | NR | No | NR | Yes | NR | No | No | No | No | No
Odusote, 1979 ^489^ | NR | Single | USA | Yes | Yes | Yes | NR | Yes | Yes | No | No | No | Yes | Yes
Ring, 1979 ^504^ | NR | Multiple (<5) | Israel | Yes | NR | No | Yes | Yes | NR | No | No | No | No | No
Eisen, 1977 ^298^ | NR | Single | Canada | Yes | Yes | No | NR | Yes | NR | No | No | No | No | Yes
Eisen, 1974 ^490^ | NR | Single | USA | Yes | Yes | No | Yes | Yes | NR | No | No | No | No | No

[underlined: Key:]

NR—not reported

Table 175. Summary of Characteristics Affecting Generalizability

Study characteristic | Number of studies reporting | Details
Years in which study was conducted | 4 (20%) | 1984-1988: 1 (5%)
| | 1985-1992: 1 (5%)
| | 1993: 1 (5%)
| | 1993-1994: 1 (5%)
Number of centers in which trial was conducted | 20 (100%) | Single: 17 (85%)
| | Multiple (<5): 3 (15%)
Country(s) where trial was performed | 20 (100%) | USA: 10 (50%)
| | Other: 10 (50%)
Patient inclusion criteria | 20 (100%) | See Table 183
Patient exclusion criteria | 12 (60%) | See Table 183
Were patient comorbidities reported? | 8 (40%) | Various
Was the sex distribution of patients reported? | 11 (55%) | ^a^Percentage female: 31.6%
Were patient ages reported? | 12 (60%) | ^a, b^Mean age: 46.6 years
Was the duration of patients' condition reported? | 1 (5%) | ^a^Mean duration: 7.5 months
Did all patients have previous conservative treatment? | 0 | NA
Did any patients have previous surgical treatment? | 1 (5%) | Yes: 1 (5%)
Adequate reporting of study' source of patients | 1 (5%) | Yes: 1 (5%)
Was there a potential selection bias for easy cases? | 9 (45%) | Yes: 9 (45%)
Was there a potential selection bias for hard cases? | 4 (20%) | Yes: 4 (20%)

[underlined: Key:]

NA-not applicable

a Calculated on a per-patient basis (i.e., weighted by number of patients in each study reporting this characteristic)

b Calculation excludes study reporting median age ^54^ and study that failed to report the number of patients ^489^

The overall quality of articles in this evidence base is low. Important variables that could affect the validity or generalizability of results from these studies were not reported. Though this lack of reporting is not evidence of bias in the studies, it limits the confidence one can have in any conclusions drawn from them.

A tabulation of patient selection and types of controls appears in Table 176. See Table 174 for the definition of these categories. Only three studies (15%) used objective criteria to define their cubital tunnel syndrome patient group, while eight (40%) diagnosed patients with unspecified methods. Eleven articles (55%) compared the cubital tunnel syndrome patients to healthy normal volunteers; this comparison may cause spectrum bias in the results because these control subjects may be less likely than patients referred for cubital tunnel syndrome testing to have other conditions that could cause false-positive test results.

Table 176. Patient and Control Group Selection in Cubital Tunnel Syndrome Diagnostic Articles

Control Selection | Patient selection | | | | | Total
| Complex objective standard | Simple nerve conduction | Symptoms/ presented | Unspecified diagnosis | Workers at risk
Healthy control group and asymptomatic arms of patients | 0 | 0 | 1 | 0 | 0 | 1
Healthy control group | 1 | 2 | 4 | 3 | 1 | 11
Other control group | 0 | 0 | 2 | 2 | 0 | 4
Asymptomatic arm as control | 0 | 0 | 1 | 0 | 0 | 1
No controls | 0 | 0 | 0 | 3 | 0 | 3
Total | 1 | 2 | 8 | 8 | 1 | 20

The poor quality of the literature, particularly in reporting of study characteristics that demonstrate that study results are free of bias and generalizable to the diagnosis of cubital tunnel syndrome in routine practice, argues against trying to draw evidence-based conclusions from the results of a single study. If there is sufficient data on a particular test, meta-analytic techniques can be used to see if any of these variables affected study results.

#### Results

Table 177 tabulates reported tests (by type of test: there are different tests in each category) and patient selection categories in the 20 articles. There were no tests for which at least 10 articles reported sensitivity and specificity, not just for any one category of patient selection, but even for all categories combined. Therefore, we did not perform any meta-analyses of diagnostic tests for cubital tunnel syndrome.

Table 177. Cubital Tunnel Syndrome Tests and Patient Groups

Legend:
Numeric entries in each cell— Total number of articles, articles from which sensitivity and specificity can be calculated
Test type | Patient selection
| Complex objective standard | Simple objective standard | Symptoms/ presented | Unspecified diagnosis | Workers at risk
Composite nerve conduction | 1, 1 | 1, 1 | 7, 4 | 2, 1 | 1, 0
Imaging | 0, 0 | 0, 0 | 2, 1 | 0, 0 | 0, 0
Nerve conduction | 1, 1 | 1, 1 | 5, 2 | 3, 1 | 1, 0
Sensory | 0, 0 | 0, 0 | 1, 1 | 3, 1 | 0, 0
Signs/Symptoms | 0, 0 | 1, 1 | 2, 2 | 3, 0 | 1, 0
Other | 0, 0 | 0, 0 | 4, 3 | 2, 2 | 0, 0

See Table 3 CODING OF PATIENT INCLUSION—METHODS SECTION for the definition of these groups

The reported methods for defining cubital tunnel syndrome in the 20 included studies appear in Table 178. The most common criteria were symptoms (7 studies, 35%) and motor nerve conduction velocity across the elbow (6 studies, 30%). Seven studies (35%) used both clinical criteria and nerve conduction criteria, three studies (15%) used nerve conduction criteria only, and two studies (10%) used clinical criteria only. The table demonstrates the variability in authors' definitions of cubital tunnel syndrome. The lack of agreement on what constitutes cubital tunnel syndrome hinders assessing tests for diagnosing the condition.

Table 178. Definitions of Cubital Tunnel Syndrome Used in Reported Clinical Trials

Article | Clinical findings | | | Nerve conduction studies | | | Comments
| SYM | CLN | OTH CLN | MCV ELB | OTH MOT | SEN
Montagna, 2000 ^227^ | □ | □ | □ | □ | □ | □ | NR
Ellemann, 1999 ^495^ | □ | □ | □ | □ | □ | □ | NR
Merlevede, 1999 ^496^ | | □ | □ | | | □
Chiou, 1998 ^497^ | □ | □ | □ | □ | □ | □ | NCS (tests not reported)
Dellon, 1997 ^107^ | □ | | | □ | □ | □
Kaneko, 1997 ^250^ | □ | □ | □ | | □ | □
Britz, 1996 ^498^ | □ | □ | □ | □ | □ | □ | NR
Kingery, 1995 ^499^ | | □ | □
Tassler, 1995 ^115^ | □ | □ | □ | □ | □ | □ | NR
Novak, 1994 ^500^ | | □ | □ | | □ | □
Uchida, 1993 ^501^ | | | □ | | □ | □
Robinson, 1992 ^502^ | □ | | □ | □ | □ | □ | NCS (tests not reported)
So, 1989 ^173^ | | | | □ | □ | □
Buehler, 1986 ^503^ | □ | □ | □ | □
Kimura, 1984 ^55^ | □ | □ | □ | □ | □ | □ | NR
Tackmann, 1984 ^54^ | □ | □ | □ | □ | □ | □ | NR
Odusote, 1979 ^489^ | □ | □ | □ | □ | □ | □ | NR
Ring, 1979 ^504^ | □ | □ | □ | □ | □ | □ | NR
Eisen, 1977 ^298^ | | □ | | □
Eisen, 1974 ^490^ | | □ | □
Totals (20 articles) | 7 | 4 | 3 | 6 | 5 | 4

[underlined: Key]:

SYM- Were positive symptoms included in the author's method of diagnosis?

CLN- Was a positive clinical exam included in the author's method of diagnosis?

OTH CLN- Were other clinical findings included in the author's method of diagnosis?

MCV ELB- Was ulnar motor nerve conduction velocity across the elbow included in the author's method of diagnosis?

OTH MOT- Were other motor conduction studies included in the author's method of diagnosis?

SEN- Were sensory conduction studies included in the author's method of diagnosis?

NR - Method of diagnosis was not reported

Because there was little agreement in the clinical trial articles on appropriate diagnostic methods for cubital tunnel syndrome, we also examined review articles, to see if they identified any standard approaches to diagnosis. The four articles that reviewed cubital tunnel diagnosis ^57,^ ^97,^ ^491,^ ^492^ listed typical symptoms of the condition, but did not recommend specific diagnostic strategies (i.e., which test to use first). They disagreed on the value of clinical signs like Tinel's sign. The only characteristic of cubital tunnel syndrome mentioned in all four articles was abnormal ulnar motor nerve conduction velocity at the elbow. Piligian ^53^ came closest to recommending a diagnostic strategy, suggesting that cubital tunnel syndrome be diagnosed using both symptoms (paresthesia of the fourth and fifth fingers and pain in the medial aspect of the elbow) and nerve conduction tests (reduced ulnar motor nerve conduction velocity at the elbow). There was not sufficient evidence in the reported clinical trials of these tests for us to meta-analyze their results and determine how effective they are.

Because ulnar motor nerve conduction velocity at the elbow was described as a characteristic of cubital tunnel syndrome in all four review articles we examined, and no tests for cubital tunnel syndrome met our a priori meta-analysis criteria, we abstracted sensitivity and specificity data from the three articles in which this was possible (the article by So et al. ^173^ was excluded because no specificity data was reported for the nerve conduction tests). The results reported in those three articles are presented in Table 179 and Figure 44. All three studies reported high specificity but low sensitivity.

Table 179. Clinical Trial Results: Ulnar Motor Nerve Conduction Velocity at the Elbow for Diagnosis of Cubital Tunnel Syndrome

Study | TP | FN | FP | TN | Sensitivity (95% CI) | Specificity (95% CI) | PPV (95% CI) | NPV (95% CI) | Prevalence
^a^Odusote, 1979 ^489^ | 72 | 181 | 10 | 229 | 28.5% 23.2% 34.4% | 95.8% 92.4% 97.7% | 87.8% 78.8% 93.3% | 55.9% 50.9% 60.7% | 51.4%
^b^Eisen, 1977 ^298^ | 12 | 6 | 0 | 60 | 66.7% 43.3% 84.0% | 100% 93.8% 100% | 100% 75.0% 100% | 90.9% 81.3% 95.8% | 23.1%
^a, b^Kingery, 1995 ^499^ | 16 | 34 | 2 | 68 | 32.0% 20.6% 46.1% | 97.1% 90.0% 99.2% | 88.9% 66.7% 97.0% | 66.7% 56.9% 75.2% | 41.7%

Insufficient data for meta-analysis

a Data reported on a per-arm basis, rather than per-patient.

b Counts for control group (false positive, true negative) estimated by ECRI from threshold reported by authors

Figure 44. Clinical Trial Results: Ulnar Motor Nerve Conduction Velocity at the Elbow for Diagnosis of Cubital Tunnel Syndrome

#### Conclusions

All of the articles on diagnosis of cubital tunnel syndrome suffered from poor reporting of study methods and patient characteristics, so one cannot be assured that the results of any individual study were unaffected by bias. There were no diagnostic tests for cubital tunnel syndrome for which 10 or more articles reported sensitivity and specificity. Therefore, we could not perform meta-analyses to see if results were affected by differences in patient characteristics and study design. One test, ulnar motor nerve conduction velocity at the elbow, was mentioned by reviewers, and three studies reported high specificity and low sensitivity for this test. Due to the small number of studies, however, one cannot draw quantitative conclusions about the effectiveness of the test. There are insufficient data to permit evidence-based conclusions about the effectiveness of this or any other tests for cubital tunnel syndrome.

### Question #2. What are the specific indications for surgery for cubital tunnel syndrome?

There is no published information available that directly addressed the question of specific indications for surgery for cubital tunnel syndrome. Therefore, this section will present the characteristics of patients who have received surgery as described in published studies. Because patients enrolled in clinical trials may differ from the general population of patients encountered in general practice, these data may not accurately reflect the general population of patients who have received surgery, and may be of limited utility when selecting candidates for surgery in the future. However, the present analysis is the most comprehensive guide available.

#### Evidence Base

For this question, we examined controlled trials and case series that described patients being surgically treated for cubital tunnel syndrome. We identified thirty-two such studies that included a total of 1,820 patients.

#### Patient demographics

Table 184 shows the mean age, age range, and gender composition of the patient groups included in the trials. Thirty-one of the 32 studies (96.9%) reported information about the ages of the patients, and 29 of the studies (90.6%) reported information about the gender composition of the patient groups. The mean ages and age range are shown in Figure 45. In general, patients surgically treated for cubital tunnel syndrome were middle aged (a mean of 46.4 years of age), but ages ranged from under ten years old to almost 90 years of age. The percentages of women in the patient groups are shown in Figure 46. The patients were predominantly male (62%). None of the studies reported that patients were excluded/included on the basis of either age or gender.

Table 184. Ages and gender composition of patient groups receiving surgery for cubital tunnel syndrome

Study | Number of patients | Number of males | Number of females | Percent female | Age reported as mean or median? | Age | Age of youngest patient | Age of oldest patient
Artico 2000 ^505^ | 236 | 140 | 96 | 40.7 | Mean | 42.5 | 17 | 69
Caputo 2000 ^506^ | 20 | 13 | 7 | 35.0 | Mean | 47 | 24 | 70
Lascar 2000 ^425^ | 71 | 59 | 12 | 16.9 | Mean | 50 | 18 | 83
Greenwald 1999 ^507^ | 31 | 29 | 2 | 6.5 | Mean | 60 | 37 | 79
Tsai 1999 ^508^ | 76 | 29 | 47 | 61.8 | Median | 42 | 21 | 81
Asami 1998 ^509^ | 35 | 25 | 10 | 28.5 | Mean | 54.4 | 15 | 80
Seradge 1998 ^510^ | 160 | 99 | 61 | 38.1 | Mean | 43 | 14 | 81
Glowacki 1997 ^511^ | 40 | 17 | 23 | 57.5 | Mean | 40 | 17 | 67
Nouhan 1997 ^512^ | 31 | 18 | 13 | 41.9 | Mean | 46 | 27 | 67
Tada 1997 ^513^ | 50 | 44 | 6 | 12.0 | Mean | 58 | 20 | 72
Geutjens 1996 ^514^ | 52 | NR | NR | NR | Mean | 58 | 36 | 85
Steiner 1996 ^515^ | 41 | 29 | 12 | 29.3 | Mean | 46 | NR | NR
Messina 1995 ^516^ | 30 | 22 | 8 | 26.7 | Mean | 54 | 23 | 79
Nathan 1995 ^517^ | 164 | 74 | 90 | 54.8 | Mean | 41.9 | NR | NR
Pasque 1995 ^518^ | 64 | 40 | 24 | 37.5 | Mean | 42 | 5 | 75
Manske 1992 ^519^ | 26 | 15 | 11 | 42.3 | Mean | 40 | 22 | 73
Barrios 1991 ^520^ | 53 | 37 | 16 | 30.2 | Mean | 42 | 12 | 70
Froimson 1991 ^521^ | 34 | 6 | 28 | 82.4 | Mean | 47 | NR | NR
Rogers 1991 ^522^ | 14 | 8 | 6 | 42.9 | Mean | 36 | 16 | 59
Heithoff 1990 ^523^ | 39 | 22 | 17 | 43.6 | Mean | 41.8 | 16 | 74
Goldberg 1989 ^524^ | 46 | 22 | 24 | 52.2 | Mean | 47 | 23 | 69
Janes 1989 ^525^ | 30 | 26 | 4 | 13.3 | Mean | 51 | 27 | 69
Kleinman 1989 ^26^ | 47 | 26 | 21 | 44.7 | Mean | 45 | 17 | 69
Friedman 1986 ^527^ | 22 | 22 | 0 | 0.0 | Mean | 52.1 | NR | NR
Leffert 1982 ^528^ | 38 | NR | NR | NR | Mean | 32.9 | 14 | 73
Foster 1981 ^529^ | 48 | 29 | 19 | 50.0 | Mean | 51.2 | NR | NR
Chan 1980 ^530^ | 235 | 214 | 21 | 43.7 | Mean | 54.5 | 10 | 86
Craven 1980 ^531^ | 30 | 26 | 4 | 13.3 | Mean | 53 | 25 | 77
Eaton 1980 ^532^ | 16 | 12 | 4 | 13.3 | Mean | 36 | 18 | 75
Froimson 1980 ^52^ | 29 | 27 | 2 | 12.5 | Mean | 43 | 13 | 65
Miller 1980 ^533^ | 12 | 0 | 12 | 48.3 | Mean | 51 | 26 | 65

Figure 45. Mean ages and ranges of ages of patients treated surgically for cubital tunnel syndrome

The vertical line indicates the mean age

Figure 46. Gender composition of patient groups treated surgically for cubital tunnel syndrome

The vertical line indicates the mean % of females

#### Signs and symptoms

The signs and symptoms of patients before surgical treatment for cubital tunnel syndrome are listed in Table 185. The number of studies reporting on the proportion of patients in the study group having each sign and symptom are listed in Table 186 and shown in Figure 47. The mean percentage of patients reported to have each sign and symptom, and the range of reported percentages, are shown in Figure 48. In addition to the clinical signs and symptoms, some studies reported on the conduction velocity of the ulnar nerve. Nine of the 32 studies simply reported that all of the patients treated with surgery had “abnormal” nerve conduction velocities. One of the 32 studies reported that 31% of the patients had “abnormal” nerve conduction velocities. The definition of abnormal varied from study to study, and often no definition was supplied. Five of the 32 studies did not measure the nerve conduction velocity of the ulnar nerve before treating the patients with surgery. In 17 of the 32 studies it was not clear from the reported information whether nerve conduction velocities were measured.

Table 185. Signs and symptoms of patients treated with surgery for cubital tunnel syndrome

Study | Number of Patients | Sign or symptom | Number of patients with sign or symptom | Percent of Patients
Artico 2000 ^505^ | 236 | Pain | 104 | 44.1
Lascar 2000 ^425^ | 71 | Pain | 13 | 18.3
Messina 1995 ^516^ | 30 | Pain | 30 | 100.0
Nathan 1995 ^517^ | 164 | Pain | 78 | 47.6
Manske 1992 ^519^ | 26 | Pain | 26 | 100.0
Rogers 1991 ^522^ | 14 | Pain | 14 | 100.0
Goldberg 1989 ^524^ | 46 | Pain | 15 | 32.6
Foster 1981 ^529^ | 48 | Pain | 31 | 64.5
Chan 1980 ^530^ | 235 | Pain | 102 | 43.4
Eaton 1980 ^532^ | 16 | Pain | 14 | 87.5
Miller 1980 ^533^ | 12 | Pain | 7 | 58.3
Lascar 2000 ^425^ | 71 | Tinel's sign | 45 | 63.4
Greenwald 1999 ^507^ | 31 | Tinel's sign | 24 | 77.4
Seradge 1998 ^510^ | 160 | Tinel's sign | 160 | 100.0
Nouhan 1997 ^512^ | 33 | Tinel's sign | 30 | 90.9
Nathan 1995 ^517^ | 164 | Tinel's sign | 43 | 26.2
Rogers 1991 ^522^ | 14 | Tinel's sign | 14 | 100.0
Goldberg 1989 ^524^ | 46 | Tinel's sign | 37 | 80.4
Foster 1981 ^529^ | 48 | Tinel's sign | 27 | 56.2
Chan 1980 ^530^ | 235 | Tinel's sign | 48 | 20.4
Eaton 1980 ^532^ | 16 | Tinel's sign | 11 | 68.8
Lascar 2000 ^425^ | 71 | Numbness | 23 | 32.4
Steiner 1996 ^515^ | 41 | Numbness | 24 | 58.5
Goldberg 1989 ^524^ | 46 | Numbness | 30 | 65.2
Foster 1981 ^529^ | 48 | Numbness | 41 | 85.4
Chan 1980 ^530^ | 235 | Numbness | 113 | 48.0
Eaton 1980 ^532^ | 16 | Numbness | 4 | 25.0
Miller 1980 ^533^ | 12 | Numbness | 12 | 100
Artico 2000 ^505^ | 236 | Paresthesias | 219 | 92.8
Greenwald 1999 ^507^ | 31 | Paresthesias | 24 | 77.4
Steiner 1996 ^515^ | 41 | Paresthesias | 14 | 34.1
Foster 1981 ^529^ | 48 | Paresthesias | 42 | 87.5
Chan 1980 ^530^ | 235 | Paresthesias | 200 | 85.1
Craven 1980 ^531^ | 30 | Paresthesias | 20 | 66.7
Eaton 1980 ^532^ | 16 | Paresthesias | 9 | 56.3
Artico 2000 ^505^ | 236 | Wasting of the intrinsic muscles | 156 | 66.1
Seradge 1998 ^510^ | 160 | Wasting of the intrinsic muscles | 11 | 6.9
Steiner 1996 ^515^ | 41 | Wasting of the intrinsic muscles | 30 | 73.2
Nathan 1995 ^517^ | 164 | Wasting of the intrinsic muscles | 5 | 3.0
Goldberg 1989 ^524^ | 46 | Wasting of the intrinsic muscles | 15 | 32.6
Foster 1981 ^529^ | 48 | Wasting of the intrinsic muscles | 10 | 20.8
Chan 1980 ^530^ | 235 | Wasting of the intrinsic muscles | 200 | 85.1
Artico 2000 ^505^ | 236 | Weakness | 156 | 66.1
Lascar 2000 ^425^ | 71 | Weakness | 31 | 43.7
Steiner 1996 ^515^ | 41 | Weakness | 36 | 87.8
Nathan 1995 ^517^ | 164 | Weakness | 3 | 1.8
Foster 1981 ^529^ | 48 | Weakness | 30 | 62.5
Eaton 1980 ^532^ | 16 | Weakness | 4 | 25.0
Miller 1980 ^533^ | 12 | Weakness | 12 | 100.0
Chan 1980 ^530^ | 235 | Hypalgesia/hypesthesia | 216 | 91.9
Miller 1980 ^533^ | 12 | Hypalgesia/hypesthesia | 12 | 100.0
Chan 1980 ^530^ | 235 | Tenderness | 95 | 40.4
Eaton 1980 ^532^ | 16 | Tenderness | 13 | 81.3
Messina 1995 ^516^ | 30 | Weakness of grip | 30 | 100
Chan 1980 ^530^ | 235 | Weakness of grip | 187 | 79.6
Chan 1980 ^530^ | 235 | Claw hand deformity | 20 | 8.5
Lascar 2000 ^425^ | 71 | Clumsiness | 6 | 8.5
Foster 1981 ^529^ | 48 | Dysthesia | 39 | 87
Eaton 1980 ^532^ | 16 | Palpable nerve subluxation | 3 | 18.8
Eaton 1980 ^532^ | 16 | Restricted range of motion | 5 | 31.3
Lascar 2000 ^425^ | 71 | Stiffness | 7 | 9.9
Nathan 1995 ^517^ | 164 | Ulnar nerve subluxation | 4 | 2.4
Craven 1980 ^531^ | 30 | Wartenberg sign | 18 | 60.0
Chan 1980 ^530^ | 235 | Wasting and weakness of the flexor muscles | 37 | 15.7
Chan 1980 ^530^ | 235 | Weakness of the intrinsic muscles | 200 | 85.1

Table 186. Reporting of signs and symptoms by studies of surgery to treat cubital tunnel syndrome

Sign or symptom | Number of studies reporting
Pain | 11
Tinel's sign | 10
Numbness | 7
Paresthesias | 7
Wasting of the intrinsic muscles | 7
Weakness | 7
Hypalgesia/hypesthesia | 2
Tenderness | 2
Weakness of grip | 2
Claw hand deformity | 1
Clumsiness | 1
Dysthesia | 1
Palpable nerve subluxation | 1
Restricted range of motion | 1
Stiffness | 1
Ulnar nerve subluxation | 1
Wartenberg sign | 1
Wasting and weakness of the flexor muscles | 1
Weakness of the intrinsic muscles | 1
Moving 2-point discrimination | 0
Night symptoms | 0
Paresis | 0
Semmes-Weinstein monofilament testing | 0
Static 2-point discrimination | 0
Swelling | 0
Symptoms with ADLs | 0

Figure 47. Percentage of studies reporting on the proportion of patients with each sign and symptom

Figure 48. Mean percentage and range of percentages of patients reported to have each sign and symptom

Fifteen of the 32 studies reported how long the patients had had symptoms before being treated with surgery. The reported mean durations and ranges are shown in Figure 49. On average, patients had symptoms for 10 to 24 months before treatment.

Figure 49. Mean and range of duration of symptoms before treatment

Because fewer than 40% of the studies reported information about whether their patients had any specific signs and symptoms or other characteristics, the extent to which the available data reflects the typical cubital tunnel syndrome patient cannot be determined.

#### Occupations and work history

Of the 32 studies describing patients receiving surgery for cubital tunnel syndrome only one study reported the specific occupations of its patient group. Six studies reported on the percentages of patients receiving Workers' Compensation. One study reported on the percentage of patients able to work, and one study reported on the percentage of patients not able to work. Because so few studies reported data pertaining to the occupations and work history of their patient groups, it is difficult to make generalizable statements.

#### Comorbidities

The number of patients with comorbidities is incompletely reported in published studies of surgical treatment for cubital tunnel syndrome, as can be seen in Figure 50. The number of studies reporting the presence of a given comorbidity never exceeds 35% of the available studies. Further complicating analysis is the fact that some studies exclude patients with comorbidities. Because comorbidities are both underreported and patients with them may be excluded from clinical trials, it is difficult to reach conclusions about the presence of comorbidities among patients receiving surgery for cubital tunnel syndrome or the impact of comorbidities on whether a patient is a candidate for surgery.

Figure 50. Percentage of studies reporting and excluding comorbidities

#### Conclusions

Thirty-two studies of patients who received surgery for cubital tunnel syndrome were identified. Due to a lack of reported data, few trends or characteristics of patients who received surgery could be identified. The mean age of patients who received surgery for cubital tunnel syndrome was 46 years. The patients were slightly more likely to be male (62% male), and on average had symptoms 10 to 24 months before receiving surgical treatment.

### Question#3. What are the relative benefits and harms of surgery for persons with cubital tunnel syndrome?

The scope of our answer to this question is determined by the scope of the published literature. The relevant literature consists of one study that compares anterior transposition to decompression surgery, one study that compares anterior transposition to epicondylectomy, and one study that compares variants of anterior transposition (see the Introduction for a description of these surgical procedures). Therefore, one can only address the relative benefits and harms of these surgical procedures. There are no published studies that compared surgery to placebo or untreated groups. Because of this, the absolute benefit of surgery cannot be determined; only the relative benefits of different types of surgery can be inferred.

#### Evidence base

We considered only controlled trials that evaluated treatments for patients with cubital tunnel syndrome for this section of the report. Six studies were retrieved. Three did not meet the inclusion criteria (See the Inclusion criteria section) and were excluded. These three studies and their reasons for exclusion are listed in Table 187. The remaining three studies, which included a total of 301 patients, were included in the answer to this question. The outcomes reported by these studies are listed in Table 187.

Table 187. Excluded studies

Study | Reason for exclusion
Tsai 1995 ^65^ | Reports on patients who are reported on elsewhere. ^508^
Antoniadis 1997 ^534^ | Reports on only a subset of the patients entered into the trial.
Gabel 1990 ^535^ | Reports on only a subset of the patients entered into the trial.

#### Quality of the literature

##### Internal validity

Details of the study designs relevant to the internal validity of the trials are shown in Table 188. Two of the three trials did not randomly assign patients to treatment groups. If patients are not randomly assigned to groups, there may be important differences between these groups that could contribute to any observed differences in outcomes.

Table 188. Internal validity

Study | Number of patients | Number of centers | Funded by a for-profit agency? | Study design | Blinding | % Attrition | Intent to treat analysis | % Compliance
Asami 1998 ^509^ | 35 | 1 | NR | CT | No | 0 | Yes | NA
Geutjens 1996 ^514^ | 52 | 1 | No | RCT | Rater | 17.3 | No; corrected for | NA
Chan 1980 ^530^ | 214 | 1 | NR | Retro | No | 6.5 | No | NA

CT = controlled trial

RCT = randomized controlled trial

Retro = retrospective

NA = not applicable

NR = not reported

One of the three trials was prospective and one trial was retrospective. The third trial may have also been retrospective, but the study design was not explicitly described in the published article. Retrospective studies are more prone to bias than are prospective studies because the former are necessarily performed on a select group of patients.

One of the three trials used physicians blinded to the type of treatment to evaluate the patients. The other two trials did not employ any type of blinding. Lack of blinding of the patient to the type of treatment, in particular when using subjective outcome measures, can alter measurements of treatment effect because patients might unconsciously rate their condition differently in order to please the clinician. ^474^ However, the nature of the surgical treatments used in these trials precludes blinding of the patients so we did not consider this a study weakness. We did consider lack of blinding of the evaluating physician to be a weakness. This is because if the evaluating physician is aware of the treatment given, it is possible that he/she may unconsciously bias the patient's responses by giving leading instructions. ^474^

Two of the trials did not analyze their data according to the intent-to-treat principle. Ignoring attrition when analyzing the data can create a bias in the results. Where possible, we have tried to compensate for this by attempting to gauge the maximum possible effect of not following this principle. Thus, we assumed that all patients who were not followed until the end of the study received unsuccessful treatment. This is a highly conservative assumption. However, if statistical significance is obtained under this assumption, one can be more confident that the magnitude of this design weakness is not large enough to overturn the results of a statistically significant trial. For the trial by Geutjens 1996, we were able to re-calculate the data in an intent-to-treat fashion. We were not able to do this for the trial by Chan 1980 because the data were presented in terms of numbers of arms, but the initial total number of arms was not reported, and the attrition data was in terms of numbers of patients.

Both Chan 1980 and Asami 1999 reported data in terms of the number of arms treated, not the number of patients treated. The validity of this approach cannot be determined. It violates the assumption of independence that underlie the statistical tests. This typically leads to underestimation of standard errors and spurious statistically significant results (Type I errors). For the purposes of this analysis, we have ignored the assumption of independence. In the study by Chan 1980, there were only 35 bilateral cases out of 235 cases in total (14.8%), and in the study by Asami 1998 there were only 6 bilateral cases out of 41 cases in total (14.6%). Therefore, the violation of the assumption of independence in these studies may be relatively inconsequential.

##### Generalizability

Characteristics of the patient groups enrolled in the three trials are shown in Table 189. Studies of the epidemiology of cubital tunnel syndrome, and our analysis of patients enrolled in clinical trials of surgery to treat cubital tunnel syndrome (see the answer to Question #2), have found that patients are typically in their forties and fifties, and are more likely to be male than female. The patients enrolled in these three trials fit this profile: the mean ages of the patients in all three trials were in the late fifties, with a range of 15 to 85. The patients were predominantly male. Thus, the results of the trials can be generalized to patients other than those enrolled in the trials.

Table 189. Generalizability information: patient characteristics

Study | Number of patients | Mean age and range | % female | Duration of conditon mean and range | % Patients with diabetes | % Patients with arthritis | % Patients with prevous relevant injuries | % Patients with other relevant nerve impingement conditons | % Patients with peripheral neruopathy | % Patients pregnant | % Patients on kidney dialysis | Did the study exclude patients with severe disease? | Did the study exclude patients with mild disease?
Asami 1998 ^509^ | 35 | 55 (15–80) | 28.5 | NR | NR | NR | NR | NR | NR | NR | NR | No | No
Geutjens 1996 ^514^ | 52 | 58 (36–85) | NR | NR | NR | 0 | NR | NR | NR | NR | NR | No | No
Chan 1980 ^530^ | 214 | 54.5 (10–86) | 23.4 | 1.6 (1–456) | 2.3 | 10.7 | NR | NR | NR | NR | NR | No | No

NR = not reported

None of the studies reported any information as to the employment status, work history, or occupations of the patients.

##### Conclusions

All three trials appear to be generalizable. The trial by Geutjens 1996 appears to be well-designed. However, the other two trials have weaknesses in design (not randomized, not blinded, retrospective) that may introduce bias into the results and weaken the conclusions drawn from the data.

#### Results

##### Success of Treatment

Three trials of a total of 301 patients reported on the relative success of different surgical techniques. The studies all used patient-rated categorical questionnaires to determine the success of the treatment. The reported results are shown in Table 190.

Table 190. Results of global assessment

Study | Number of patients | Global assessment patient-reported categories | Statistical significance of difference between groups
Geutjens 1996 ^514^ | 26 medial epicondylectomy | At 54 months | chi-squared test^a^
| | Epicondylectomy- 12 excellent, 8 better, 4 same, 1 worse | p = 0.022587
| 26 anterior transposition | Transposition- 6 excellent, 6 better, 5 same, 3 worse
Asami 1998 ^509^ | 8 transposition without extrinsic vessels | In terms of number of arms: | chi-squared test
| | At 70 months mean (range 12–147) Without vessels- 3 excellent, 3 better, 4 same | p <0.05
| 27 transposition with extrinsic vessels | With vessels- 16 excellent, 12 better, 3 same
Chan. 1980 ^530^ | 101 decompression | In terms of number of arms: At 22 months | chi-squared test^a^
| | Decompression- 34 excellent, 60 better, 18 same, 3 worse | p = 0.879^b^
| 99 anterior transposition | Transposition- 22 excellent, 77 better, 19 same, 2 worse

a calculated by ECRI

b the authors reported that an undescribed statistical test showed that the difference between the groups was statistically significant.

Because no studies compared the same therapies, no meta-analysis could be performed. We calculated p-values and effect sizes (Hedges' d) for each study by collapsing the scales into dichotomous outcomes (excellent-better vs. same-worse). For the study by Asami 1999, we calculated the effect size (Hedges' d) using a method described by Torgersen. ^536^ For the trial by Geutjens 1996, we calculated the effect sizes and the p-value using a conservative method to account for the attrition as discussed in the section on study quality. We were unable to correct for attrition in our analysis of the data from the trial by Chan 1980 as explained in the section on study quality. The results of the studies are summarized in Table 191.

Table 192. Pain results

Study | Number of patients | Reported pain | Statistical significance of difference between groups
Geutjens 1996 ^514^ | 26 medial epicondylectomy | At 54 months, on a 0–5 point pain scale, epicondylectomy- Mean 0 SD 0 | Test not reported P<0.05
| 26 anterior transposition | Transposition- Mean 0.45 SD 0.86
Asami 1998 ^509^ | 8 transposition without extrinsic vessels | At 70 months mean (range 12–147) | chi-squared test P<0.05
| | Without- 8 (80%) arms pain-free
| 27 transposition with extrinsic vessels | With-29 (93.5%) arms pain free
Chan 1980 ^530^ | 101 decompression | At 22 months, Decompression-28 (27.7%) arms pain free | chi-squared test p <0.000010
| 99 anterior transposition | Transposition-58 (58.6%) arms pain-free

a calculated by ECRI

Table 191. Success of surgical treatment for cubital tunnel syndrome

Study | Number of patients | Time of follow-up | Which treatment was more successful? | Was the difference statistically significant? | Minimal difference between groups the study had statistical power to detect | Effect size Hedges' d (95% CI)^a^
Geutjens 1996 ^514^ | 26 medial epicondylectomy | 54 months | Medial epicondylectomy, | Yes | NA | 0.74 (0.08 to 1.40)
| 26 anterior transposition
Asami 1998 ^509^ | 8 transposition without extrinsic vessels | 70 months | Transposition with preservation of extrinsic vessels | Yes | NA | -0.66 (-1.38 to 0.07)
| 27 transposition with extrinsic vessels
Chan 1980 ^530^ | 101 decompression | 22 months | Decompression | No | 9% | 0.21 (-0.05 to 0.47)
| 99 anterior transposition

a calculated by ECRI

Asami 1998 found that transposition with preservation of extrinsic vessels led to statistically significantly better global outcomes than transposition without preservation of extrinsic vessels, but the calculated effect size did not reach statistical significance. This apparent discrepancy can be attributed to the fact that tests of statistical significance depend upon two factors, an effect size and the number of patients. Thus, a trial with a very small, statistically non-significant effect size can be found to be statistically significant simply by increasing the number of patients.

The success of treatment with anterior transposition as compared to the other types of surgery evaluated (decompression and medial epicondylectomy) is summarized in Figure 51 and Figure 52. Figure 51 displays the p-values of the statistical tests, while Figure 52 shows the effect sizes we calculated. The data from the study by Guetjens 1996 indicates that patients treated with epicondylectomy have statistically significantly improved outcomes compared to patients treated with anterior transposition. The difference between the two groups in the study by Chan 1980 did not reach statistical significance. The study had sufficient statistical power to have detected a relatively small difference between the groups, so it appears that this lack of a statistically significant difference is truly the result of a small or absent difference between the groups, and not due to low statistical power.

Figure 51. Success of surgical treatment: statistical tests comparing anterior transposition to other types of surgery

Figure 52. Success of surgical treatment: effect sizes of different types of surgery compared to anterior transposition

##### Work Status

None of the trials reported on this outcome.

##### Pain

Three trials of a total of 301 patients reported on the relative success of different surgical techniques in treating the pain of cubital tunnel syndrome. One of the studies had patients rate their pain after treatment on a five-point scale. The other two studies asked the patients whether their pain had been relieved. These two studies reported their data in terms of the number of arms, not the number of patients. The extent to which this affects the validity of the statistical analysis may be small, as was discussed in the section on Study quality. The reported data and effect sizes are summarized in Table 193. We could not compensate for attrition in either study due to the nature of the reported data. The effect of surgical treatment on pain is summarized in Table 193. The results of the statistical tests are shown graphically in Figure 53. The effect sizes we calculated are shown in Figure 54.

Table 193. Effect of treatments on pain

Study | Number of patients | Time of follow-up | Which treatment was more successful in relieving pain? | Was the difference statistically significant? | Effect size Hedges' d (95% CI)^a^
Geutjens 1996 ^514^ | 26 medial epicondylectomy | 54 months | Medial epicondylectomy | Yes | 0.73 (0.17 to 1.29)
| 26 anterior transposition
Asami 1998 ^509^ | 8 transposition without extrinsic vessels | 70 months | Transposition with preservation of extrinsic vessels | Yes | -0.70 (-1.86 to 0.47)
| 27 transposition with extrinsic vessels
Chan 1980 ^530^ | 101 decompression | 22 months | Anterior transposition | Yes | -0.68 (-1.00 to -0.35)
| 99 anterior transposition

a calculated by ECRI

Figure 53. Effect of surgery on pain: statistical tests of anterior transposition vs. other types of surgery

Figure 54. Effect of surgery on pain: effect sizes of anterior transposition vs. other types of surgery

Transposition with preservation of the extrinsic vessels was found to relieve pain to a greater extent than without the extrinsic vessels, but the effect size of this result did not reach statistical significance. The data from the study by Geutjens 1996 indicates that patients treated with epicondylectomy had a greater relief of pain than did patients treated with anterior transposition. The data from the study by Chan 1980 suggests that patients treated with anterior transposition had a greater relief of pain than did patients treated with decompression.

##### Function and activities

None of the studies reported patient-oriented outcomes addressing the ability of the patient to function and resume normal activities.

##### Quality of life

None of the studies reported on this outcome.

##### Morbidity and Complications

None of the included studies reported on this outcome. However, various authors have reported complications that may occur with certain types of surgery. These complications are listed in Table 194. The frequencies with which these complications may occur cannot be determined.

Table 194. Complications reported to occur after surgery for cubital tunnel syndrome

Type of surgery | Complications reported
Decompression | Subluxation of the ulnar nerve ^56^
Medial epicondylectomy | Elbow instability ^63^
| Trauma and damage to ulnar nerve ^66^
Anterior transposition | Compression of the ulnar nerve at a new site ^64^
| Extensive scar formation ^67^
| Subluxation of the ulnar nerve ^64^
| Injury to the flexor carpi ulnaris motor branches ^56^
| Injury to the ulnar nerve ^56^ ^537^ ^64^
| Disruption of blood flow to the ulnar nerve ^64^
| Formation of adhesions that limit elbow mobiltiy ^56^

#### Conclusions

One randomized controlled trial of 52 patients found that medial epicondylectomy was superior to anterior transposition in relieving pain and in improving global outcome scores. Although this study had a relatively high attrition rate, our calculations suggest that this did not influence the conclusions of the study. The results of this study are suggestive, but it is problematic to arrive at a strong evidence-based conclusion from the results of only one trial. Therefore, replication of this study is desirable.

The other two trials, one comparing decompression to anterior transposition and the other comparing anterior transposition with and without preservation of extrinsic vessels, have design weaknesses that could influence interpretation of their results. Because of their design weaknesses the results of these trials cannot be considered definitive in the absence of further study.

There are insufficient data available to definitively determine the rates of surgical complications for any of the described surgical procedures.

### Question #4. Is there a relationship between specific clinical findings and specific treatment outcomes among patients with cubital tunnel syndrome?

In addressing this question, we considered whether published literature suggests that there are specific clinical findings that predict positive or negative outcomes after treatment for cubital tunnel syndrome. The studies we considered all attempted to identify predictors by using regression techniques or by comparing outcomes in different groups of patients with different pre-treatment clinical findings. Correlations between patient characteristics and outcomes are considered in the answer to Question 6, and correlations between duration of symptoms and outcomes are considered in the answer to Question 5.

#### Excluded studies

Table 195 shows studies that were retrieved to address this question but did not meet the inclusion criteria.

Table 195. Excluded studies

Study | Reason for exclusion
Glowacki 1997 ^511^ | Stratified study that did not examine any correlations that were also examined by at least two other studies
Pasque 1995 ^518^ | Stratified study that did not examine any correlations that were also examined by at least two other studies
Friedman 1986 ^527^ | Stratified study that did not examine any correlations that were also examined by at least two other studies

#### Evidence Base

We examined eleven studies describing a total of 544 patients.

#### Study quality

The evaluation of the quality of the literature for this question differs from quality evaluations of studies of treatments. This is because for the question at hand the randomized controlled trial is not necessarily the most informative study design. Single-arm case series, if appropriately analyzed, can yield valid information for the purposes of addressing this question. However, the method of data analysis, not the study design, is an important consideration when considering the quality of the studies relevant to this question. We emphasize the results of studies that employ multiple regression techniques rather than stratification. We also consider whether a study was prospective or retrospective. We refer the reader to Question 4 Carpal Tunnel Syndrome for a more complete discussion of these issues.

Table 196 shows relevant quality characteristics of studies that met the inclusion criteria for this question.

Table 196. Study quality

Study | Prospective? | Methods used to identify predictor variables
Tada 1997 ^513^ | Yes | Multiple regression
Froimson 1991 ^52^ 1980 ^521^ | No | Stratification
Caputo 2000 ^506^ | Yes | Multiple regression^a^
Lascar 2000 ^425^ | No | Stratification
Nouhan 1997 ^512^ | No | Stratification
Kleinman 1989 ^526^ | Yes | Stratification
Tsai 1999 ^508^ | Yes | Stratification
Nathan 1995 ^517^ | No | Multiple regression
Manske 1992 ^519^ | Yes | Multiple regression^a^
Miller 1980 ^533^ | Yes | Multiple regression^a^
Foster 1981 ^529^ | No | Multiple regression^a^

a performed by ECRI

#### Results

The relationship of specific clinical findings to treatment outcomes in those studies that used regression to identify predictor variables are shown in Table 197. There are six such studies of a total of 278 patients. Also presented in Table 197 are all of the variables used in each multiple regression, including non-clinical outcome variables that do not address this question directly. The variables that do address this question are indicated in bold in the table.

Table 197. Relationship between specific clinical findings and treatment outcomes among patients with cubital tunnel syndrome (multiple regression analysis)

Study | N | Type of surgical treatment | Outcomes | Variables examined by at least two studies is there a significant correlation with the outcome? | | | | | | Unique study variables
| | | | Age | Gender | Duration of symptoms before treatment | Severity of symptoms | Nerve conduction velocity | Etiology
Tada 1997 ^513^ | 40 | Epicondylectomy | Global outcome (success of surgery) | NS | - | NS | Sig. | - | - | Range of motion (NS)
Caputo 2000 ^506^ | 20 | Anterior transposition | Global outcome (success of surgery) | NS | NS | NS | NS | - | Sig. | Workers' compensation (NS), muscle atrophy (NS)
Nathan 1995 ^517^ | 131 | Decompression | Global outcome (success of surgery) | NR | NR | NR | NR | Sig. | NR | Normal 2-point discrimination (Sig.)
Manske 1992 ^519^ | 27 | Decompression | Global outcome (success of surgery) | - | - | NS | - | NS | Sig.
Miller 1980 ^533^ | 12 | Mixture of types | Pain relief | - | - | NS | - | NS | -
Foster 1981 ^529^ | 48 | Mixture of types | Global outcome (success of surgery) | Sig. | NS | NS | NS | - | -

Bolded text indicates variables that directly address the current question. NR indicates that the study did not report what variables it included in the mulltiple regression equation

One out of three studies found a statistically significant correlation between less severe pre-treatment symptoms and a higher score on global outcome. One of three studies of nerve conduction velocity found a statistically significant correlation between the presence of normal nerve conduction velocity before treatment and a higher score on global outcome.

We investigated these relationships further by examining the results of studies that stratified their patients according to severity of symptoms or nerve conduction velocity (see Table 198). Three of four studies of symptom severity found a statistically significant correlation between less severe symptoms and a higher score on global outcome. Neither of the studies that stratified by nerve conduction velocity found a statistically significant correlation between this variable and a higher score on global outcome.

Table 198. Stratified studies (success of surgical treatment)

Study | Type of surgery | N patients | Stratification variable
| | | Severity of symptoms | Nerve conduction velocity
Froimson 1991 and 1980 ^52^ ^521^ | Epicondylectomy | 66 | Sig. | -
Lascar 2000 ^425^ | Anterior transposition | 53 | Sig. | NS
Nouhan 1997 ^512^ | Anterior transposition | 31 | NS | -
Kleinman 1989 ^526^ | Anterior transposition | 40 | - | NS
Tsai 1999 ^508^ | Decompression | 76 | Sig. | -

One explanation for why some studies found a statistically significant relationship between pretreatment symptom severity and posttreatment global outcome scores and others did not is that the studies that found a statistically significant correlation tended to have more patients than did studies that did not (Figure 55). This suggests that the smaller studies lacked the statistical power to find significance. Thus, it can be tentatively concluded that patients presenting with milder symptoms tend to have better outcomes after surgery, regardless of the type of surgery, than do patients presenting with more severe symptoms.

Figure 55. Studies reporting no significant correlation between the severity of symptoms and success of treatment may be underpowered

Similar considerations may explain why not all studies found a significant correlation between nerve conduction velocity and outcomes. The one study that reported a statistically significant correlation was much larger than the other studies that found no statistically significant correlation (Figure 56). It is possible that the other studies did not find a statistically significant correlation because of their small size ^1^ . However, because only one study found a significant relationship between nerve conduction velocity and global outcome scores, it is difficult to reach a definitive evidence-based conclusion about the relationship between the two variables.

1 A quantitative analysis of the statistical power of each study could not be performed due to incomplete reporting of data.

Figure 56. Studies reporting no significant correlation between nerve conduction velocity and success of treatment may be underpowered

Squares denote studies that performed multiple regressions. Diamonds denote studies that used stratification.

#### Conclusions

The only clinical finding variable shown by more than one study to significantly predict treatment outcomes was severity of symptoms. This correlation was statistically significant in four out of seven studies that examined it. The studies that did not find a statistically significant correlation may have been underpowered. Therefore, currently available evidence tentatively suggests that there is a correlation between having less severe symptoms and having a higher global outcome score after surgical treatment for cubital tunnel syndrome. There are insufficient data to reach evidence-based conclusions about the relationships between other clinical findings and treatment outcomes.

### Question #5. Is there a relationship between duration of symptoms and specific treatment outcomes among patients with cubital tunnel syndrome?

In addressing this question, we considered whether published literature suggests that there are specific treatment outcomes that can be predicted by duration of symptoms before treatment for cubital tunnel syndrome. The studies we considered all attempted to identify predictors by using regression techniques or by comparing outcomes in different groups of patients with different pre-treatment clinical findings.

#### Evidence Base

We identified fourteen studies of 843 patients that addressed this question. All retrieved studies met the inclusion criteria.

#### Study quality

The evaluation of the quality of the literature for this question differs from quality evaluations of studies of treatments. This is because for the question at hand the randomized controlled trial is not necessarily the most informative study design. Single-arm case series, if appropriately analyzed, can yield valid information for the purposes of addressing this question. However, the method of data analysis, not the study design, is an important consideration when considering the quality of the studies relevant to this question. We emphasize the results of studies that employ multiple regression techniques rather than stratification. We also consider whether a study was prospective or retrospective. We refer the reader to Question 4 Carpal Tunnel Syndrome for a more complete discussion of these issues.

Table 199 shows relevant quality characteristics of studies that met the inclusion criteria for this question.

Table 199. Study quality

Study | Prospective? | Methods used to identify predictor variables
Seradge 1998 ^510^ | No | Stratification
Tada 1997 ^513^ | Yes | Multiple regression
Caputo 2000 ^506^ | Yes | Multiple regression^a^
Glowacki 1997 ^511^ | Yes | Stratification
Pasque 1995 ^518^ | No | Stratification
Barrios 1991 ^520^ | Yes | Stratification
Kleinman 1989 ^526^ | Yes | Stratification
Friedman 1986 ^527^ | Yes | Stratification
Manske 1992 ^519^ | Yes | Multiple regression^a^
Miller 1980 ^533^ | Yes | Multiple regression^a^
Mannerfelt 1997 ^538^ | Yes | Multiple regression^a^
Bimmler 1996 ^539^ | Yes | Stratification
Chan 1980 ^530^ | No | Stratification
Foster 1981 ^529^ | No | Multiple regression^a^

a performed by ECRI

#### Results

The relationship between patient outcomes and duration of symptoms before treatment in those studies that used regression to identify predictor variables are shown in Table 200. There are six such studies of a total of 195 patients. Also presented in Table 200 are all of the variables used in each multiple regression. None of these studies reported that there was a statistically significant correlation between the duration of symptoms before treatment and treatment outcomes.

Table 200. Relationship between duration of symptoms and treatment outcomes among patients with cubital tunnel syndrome (multiple regression analysis)

Study | N | Type of surgical treatment | Outcomes | Mean duration of symptoms (range) | Statistical significance | Other variables examined
Tada 1997 ^513^ | 40 | Epicondylectomy | Global outcome (success of surgery) | 22 months (1–180 months) | NS | Age (NS), severity of symptoms (Sig), range of motion (NS)
Caputo 2000 ^506^ | 20 | Anterior transposition | Global outcome (success of surgery) | 12.6 months (1–72 months) | NS | Age (NS), gender (NS), severity of symptoms (NS), etiology (Sig), workers' compensation (NS), muscle atrophy (NS)
Mannerfelt 1997 ^538^ | 48 | Mixed types | Global outcome (success of surgery) | 14.6 months (2–73 months) | NS | Age (NS), Gender (NS)
Manske 1992 ^519^ | 27 | Decompression | Global outcome (success of surgery) | 10.5 months (3–36 months) | NS | Nerve conduction velocity (NS), etiology (Sig)
Miller 1980 ^533^ | 12 | Mixture of types | Pain relief | 19.2 months (4–48 months) | NS | Nerve conduction velocity (NS)
Foster 1981 ^529^ | 48 | Mixture of types | Global outcome (success of surgery) | 23.5 months (0.3–240 months) | NS | Age (Sig), gender (NS), severity of symptoms (NS)

In order to extend these data, we examined the results of the studies that stratified according to duration of symptoms (Table 201). Six out of eight of these studies found the same result, namely that there was no statistically significant correlation between duration of symptoms before treatment and global outcome score. There was no consistent relationship between the size of the study and the statistical significance of its findings. Likewise, there was no consistent relationship between whether the study was prospective and the statistically significance of its findings.

Table 201. Stratified studies (success of treatment)

Study | Type of surgery | N | Mean duration of symptoms (range) | Statistical significance (duration associated with better outcome)
Seradge 1998 ^510^ | Epicondylectomy | 160 | 8 months (2–57 months) | NS
Glowacki 1997 ^511^ | Anterior transposition | 45 | 5.5 months (0.75–72 months) | Sig (Shorter duration, ≤2.5 months)
Pasque 1995 ^518^ | Anterior transposition | 48 | 25 months (2–241 months) | NS
Barrios 1991 ^520^ | Anterior transposition | 19 | 14 months | Sig (Shorter duration, <12 months)
Kleinman 1989 ^526^ | Anterior transposition | 40 | Reported only for separate subgroups | NS
Friedman 1986 ^527^ | Anterior transposition | 22 | 11.3 months (3–36 months) | NS
Bimmler 1996 ^539^ | Surgery, mixed types | 79 | NR | NS
Chan 1980 ^530^ | Surgery, mixed types | 235 | 18.6 months (<1–456 months) | NS

#### Conclusions

Fourteen studies of three different types of surgical treatment reported on the relationship between duration of symptoms and outcomes. Six studies analyzed their results using multiple regression, but all did not find a statistically significant relationship between duration of symptoms and outcomes. Eight studies stratified patients according to symptom duration. Five of these latter studies, including the two largest ones, also did not find a statistically significant relationship. Consequently, currently available evidence does not suggest a clear-cut relationship between the duration of symptoms before treatment and the success of surgery. There are insufficient data available to reach evidence-based conclusions about the relationship between symptom duration and other treatment outcomes.

### Question #6. Is there a relationship between patient characteristics and specific treatment outcomes among patients with cubital tunnel syndrome?

In addressing this question, we considered whether published literature suggests that there are specific clinical findings that predict positive or negative outcomes after treatment for cubital tunnel syndrome. The studies we considered all attempted to identify predictors by using regression techniques or by comparing outcomes in different groups of patients with different pre-treatment clinical findings.

#### Excluded studies

Table 202 shows studies that were retrieved to address this question but did not meet the inclusion criteria.

Table 202. Excluded studies

Study | Reason for exclusion
Nathan 1995 ^517^ | Stratified study with no patient characteristics-outcome comparisions reported by at least three studies
Miller 1980 ^533^ | Stratified study with no patient characteristics-outcome comparisions reported by at least three studies

#### Evidence Base

Subsequent to these exclusions, we examined fifteen studies of 942 patients that addressed this question.

#### Study quality

The evaluation of the quality of the literature for this question differs from quality evaluations of studies of treatments. This is because for the question at hand the randomized controlled trial is not necessarily the most informative study design. Single-arm case series, if appropriately analyzed, can yield valid information for the purposes of addressing this question. However, the method of data analysis, not the study design, is an important consideration when considering the quality of the studies relevant to this question. We emphasize the results of studies that employ multiple regression techniques rather than stratification. We also consider whether a study was prospective or retrospective. We refer the reader to Question 4 Carpal Tunnel Syndrome for a more complete discussion of these issues.

Table 203 shows relevant quality characteristics of studies that met the inclusion criteria for this question.

Table 203. Study quality

Study | Prospective? | Methods used to identify predictor variables
Seradge 1998 ^510^ | No | Stratification
Tada 1997 ^513^ | Yes | Multiple regression
Goldberg 1989 ^524^ | No | Stratification
Caputo 2000 ^506^ | Yes | Multiple regression^a^
Lascar 2000 ^425^ | No | Stratification
Glowacki 1997 ^511^ | Yes | Stratification
Nouhan 1997 ^512^ | No | Stratification
Pasque 1995 ^518^ | No | Stratification
Kleinman 1989 ^526^ | Yes | Stratification
Friedman 1986 ^527^ | Yes | Stratification
Manske 1992 ^519^ | Yes | Multiple regression^a^
Mannerfelt 1997 ^538^ | Yes | Multiple regression^a^
Bimmler 1996 ^539^ | Yes | Stratification
Chan 1980 ^530^ | No | Stratification
Foster 1981 ^529^ | No | Multiple regression^a^

a performed by ECRI

#### Results

The relationship of specific patient characteristics to treatment outcomes in those studies that used regression to identify predictor variables are shown in Table 204. There are five such studies of a total of 183 patients. Also presented in Table 204 are all of the variables used in each multiple regression.

Table 204. Relationship between patient characteristics and treatment outcomes among patients with cubital tunnel syndrome (multiple regression analysis)

Study | N | Type of surgical treatment | Outcome | Variable examined by at least two studies is there a significant correlation with the outcome? | | | | | | Unique study variables
| | | | Age | Gender | Duration of symptoms before treatment | Severity of symptoms | Nerve conduction velocity | Etiology
Tada 1997 ^513^ | 40 | Epicondylectomy | Global outcome (success of surgery) | NS | - | NS | Sig. | - | - | Range of motion (NS)
Caputo 2000 ^506^ | 20 | Anterior transposition | Global outcome (success of surgery) | NS | NS | NS | NS | - | Sig. | Workers' compensation (NS), muscle atrophy (NS)
Mannerfelt 1997 ^538^ | 48 | Mixed types | Global outcome (success of surgery) | NS | NS | NS | - | - | -
Manske 1992 ^519^ | 27 | Decompression | Global outcome (success of surgery) | - | - | NS | - | NS | Sig.
Foster 1981 ^529^ | 48 | Mixture of types | Global outcome (success of surgery) | Sig. | NS | NS | NS | - | -

Bolded text indicates variables that address the curent question

One out of four studies of age found a statistically significant correlation between age and patient outcomes. This study (Foster 1981) was the only retrospective multiple regression study. None of the three studies that examined the relationship between gender and patient outcomes found a statistically significant correlation. Both studies that looked for a relationship between traumatic causes of cubital tunnel syndrome and higher scores on global outcomes after treatment found a statistically significant relationship. One study reported that there was no statistically significant relationship between workers' compensation status and patient outcomes.

We further investigated these possible relationships further by examining the results of studies that stratified their patients according to patient characteristics (see Table 205). Six out of nine studies of age found no statistically significant relationship between this variable and patient outcomes. In these studies, there was no apparent relationship between study size or whether the study was prospective and whether it obtained statistical significance. None of the three studies that looked at the relationship between sex and global outcomes found a statistically significant correlation. Four out of five studies that looked for a relationship between workers' compensation status and patient outcomes found no statistically significant correlation. Three out of three studies reported no statistically significant relationship between etiology and patient outcomes.

Table 205. Relationship between patient characteristics and success of surgical treatment of cubital tunnel syndrome- stratified studies

Study | Treatment | N patients | Age | Sex | Workers' compensation | Etiology
Seradge 1998 ^510^ | Epicondylectomy | 160 | <41 and >50 | - | - | -
Goldberg 1989 ^524^ | Epicondylectomy | 46 | NS | NS | NS | NS
Lascar 2000 ^425^ | Anterior transposition | 53 | Younger | - | - | -
Glowacki 1997 ^511^ | Anterior transposition | 45 | Younger | - | NS | -
Nouhan 1997 ^512^ | Anterior transposition | 31 | - | - | NS | -
Pasque 1995 ^518^ | Anterior transposition | 48 | NS | NS | NS | NS
Kleinman 1989 ^526^ | Anterior transposition | 40 | NS | - | Not on workers' compensation | -
Friedman 1986 ^527^ | Anterior transposition | 22 | NS | - | - | NS
Bimmler 1996 ^539^ | Surgery, mixed types | 79 | NS | - | - | -
Chan 1980 ^530^ | Surgery, mixed types | 235 | NS | NS | - | -

#### Conclusions

Seventeen studies were identified that addressed the relationship between various patient characteristics and specific treatment outcomes. The available data do not suggest a substantial correlation between the age, sex, or workers' compensation status of the patient and the success of surgery. Two studies that used multiple regression found that patients whose cubital tunnel syndrome is caused by an acute trauma have better global outcomes after surgical treatment than patients with cubital tunnel syndrome from other causes. However, three studies that stratified by etiology found no statistically significant relationship between cause and patient outcomes. The studies that used multiple regression techniques are of better quality than the stratified studies; thus, current data suggest that there may be a correlation between etiology and patient outcomes, but this cannot be regarded as definitive.

### Question #7: What are the surgical and nonsurgical costs or charges for treatment of cubital tunnel syndrome?

According to Medicare Provider Analysis and Review (MEDPAR), average total charges per patient for the DRG (diagnosis-related group) of major shoulder/elbow procedures with comorbidities or complications are $9,008.94 (calculated by dividing total charges by number of discharges). For the DRG shoulder, elbow or forearm procedures, except major joint procedures, without comorbidities or complications, average total charges per patient are $7729.16. For the DRG peripheral and cranial nerve and other nerve procedures without complications or comorbidities, the average total per patient charges are $14,357.65 (with complications or comorbidities the charges are $24,288). These DRGs may include procedures that are used to treat disorders other than cubital tunnel syndrome. The Median Costs for Hospital Outpatient Services Dataset contains median costs for services that are reimbursed under Medicare for the hospital outpatient prospective payment system. The reported median cost for a decompression fasciotomy of the forearm and/or wrist is $603.85. The reported median cost for application of a long-arm splint is $80.48.

### Question #8. For persons who have had surgery to treat cubital tunnel syndrome, what are the appropriate methods for preventing the recurrence of symptoms, and how does this vary depending on subject characteristics or other underlying health problems?

No studies were identified that addressed this question.

### Question #9: What instruments, if any, can accurately assess functional limitations in an individual with cubital tunnel syndrome?

No trials were identified that evaluated instruments to assess functional limitations in patients with cubital tunnel syndrome.

### Question #10: What are the functional limitations for an individual with cubital tunnel syndrome before treatment?

There were no studies that addressed this question.

### Question #11: What are the functional limitations of an individual with cubital tunnel syndrome after treatment?

There were no studies that addressed this question.

## Epicondylitis

### Question #1: What are the appropriate methods and approaches for the early identification and diagnosis of epicondylitis?

#### Evidence Base

Articles were included for this question if they reported data that could be used for evaluation of the test in diagnosing epicondylitis, and they included ten or more patients.

Sixteen studies met the initial inclusion criteria. Six of those studies were excluded because they selected only patients who had had unsuccessful treatment for their condition (see Table 206). This is likely to engender a spectrum bias in the results, because such patients may have more severe conditions. Furthermore, the patient inclusion criteria for these trials imply that they were not intended to evaluate the diagnostic tests used, and that the diagnostic information provided was only incidental.

Table 206. Excluded Articles

Article | Reason for Exclusion
Pfaler, 1999 ^543^ | All patients previously treated
Pienimaki, 1998 ^544^ | All patients previously treated
De Smet, 1997 ^545^ | All patients previously treated
Pienimaki, 1997 ^546^ | All patients previously treated
Pienimaki, 1997 ^547^ | All patients previously treated
Potter, 1995 ^548^ | All patients previously treated

Ten studies remained for analysis after these exclusions. They included a total of 251 epicondylitis patients and 97 control subjects. Two (20%) were multi-center studies; the rest were conducted at a single institution. Six articles (60%) came from institutions outside the United States.

#### Internal Validity and Generalizability of Results

Because of the small size of the evidence base on diagnosis of epicondylitis, we will discuss the quality of literature issues related to both internal validity and generalizability of study results in the same section of this report.

Information related to these aspects of study quality was incompletely reported (see Table 207 and Table 208). The relevant data are summarized in Table 209 and Table 210. Some study aspects affect both internal validity and generalizability (e.g. age), so they were included in both sets of tables. Basic demographic information about patients (e.g. age and sex) was usually reported, but in some studies, this was not reported for the control subjects. Comorbidities were reported in only 3 of the 10 articles. Indicators of reliability in diagnostic studies (such as blinding of test operators) were rarely reported. Six studies (60%) had a potential selection bias for patients with relatively easy to diagnose conditions.

Table 207. Study Characteristics Relating to Internal Validity

Article | Funded by for-profit institution? | Inclusion criteria reported? | Exclusion criteria reported | Method of diagnosis reported | Patient selection | Comorbidity reported | Sex reported | Possible sex bias | Ages reported | Possible age bias | Duration of condition reported | Test operator blinded | Test reader blinded | Multiple readers | Method for multiple readers | Independent reference standard | Were patients given both test and reference
Benjamin, 1999 ^549^ | NR | Yes | Yes | Yes | Prospective | No | Yes | NC | Yes | NC | No | No | No | NR | NR | No | No
Bredella, 1999 ^74^ | NR | Yes | NR | Yes | Prospective | No | Yes | NC | Yes | NC | No | No | No | 3 | NR | No | No
Steinborn, 1999 ^71^ | NR | Yes | Yes | Yes | Retrospective | No | Yes | No | Yes | P | Yes | No | No | 2 | NR | No | No
Bauer, 1998 ^550^ | NR | Yes | NR | Yes | NR | No | Yes | No | Yes | No | No | No | No | NR | NR | No | No
Friedman, 1998 ^73^ | No | Yes | Yes | Yes | NR | Yes | Yes | No | Yes | No | Yes | Yes | No | NR | NR | No | No
Martin, 1998 ^540^ | NR | Yes | NR | Yes | Prospective | No | NR | GNR | Yes | P | Yes | No | Yes | 2 | Indep | No | No
Smith, 1994 ^541^ | NR | Yes | Yes | Yes | NR | No | Yes | NC | Yes | NC | Yes | No | Yes | 3 | Indep | No | No
Wright, 1992 ^72^ | NR | Yes | Yes | Yes | Prospective | Yes | Yes | NC | Yes | NC | No | Yes | No | NR | NR | No | No
Hyland, 1990 ^551^ | NR | Yes | Yes | Yes | Prospective | No | Yes | NC | NR | NC | Yes | No | Yes | 2 | Indep | No | No
Binder, 1984 ^542^ | NR | Yes | Yes | Yes | NR | Yes | Yes | GNR | Yes | ANR | Yes | No | No | NR | NR | No | No

[underlined: Key:]

Possible sex bias: No—proportion women in epicondylitis group within 20% of proportion of women in control group; P—Patients were more likely to be female; C—Controls were more likely to be female; GNR—Genders not reported for both groups; NC—Study did not contain a separate control group

Possible age bias: No—mean age of epicondylitis group within 5 years of mean age of control group; P—Patients were older than controls; C—Controls were older than patients; ANR—Ages not reported for both groups; NC—Study did not contain a separate control group

Method for multiple test readers: Indep—Independent

NR-Not reported

Table 208. Study Characteristics Relating to Generalizability of Results

Article | Years in which trial was conducted | Number of centers | Country(s) where trial was conducted | Inclusion criteria reported | Exclusion criteria reported | Are patient comorbidity reported? | Sex reported | Age reported | Duration of condition reported | Did all patients have previous conservative treatment? | Did any patients have previous surgical treatment? | Source of patients adequately described and generalizable to broader clinical practice? | Potential selection bias for easy cases? | Potential selection bias for difficult cases?
Benjamin, 1999 ^549^ | NR | Single | USA | Yes | Yes | No | Yes | Yes | No | No | No | No | Yes | No
Bredella, 1999 ^74^ | NR | Multiple (<5) | USA | Yes | NR | No | Yes | Yes | No | No | No | No | No | No
Steinborn, 1999 ^71^ | NR | Single | Germany | Yes | Yes | No | Yes | Yes | Yes | No | No | No | Yes | No
Bauer, 1998 ^550^ | NR | Single | USA | Yes | NR | No | Yes | Yes | No | No | No | No | Yes | No
Friedman, 1998 ^73^ | NR | Single | New Zealand | Yes | Yes | Yes | Yes | Yes | Yes | No | No | No | Yes | No
Martin, 1998 ^540^ | NR | Single | USA | Yes | NR | No | NR | Yes | Yes | No | No | No | Yes | No
Smith, 1994 ^541^ | NR | Single | United Kingdom | Yes | Yes | No | Yes | Yes | Yes | No | No | No | No | No
Wright, 1992 ^72^ | NR | Single | Australia | Yes | Yes | Yes | Yes | Yes | No | No | No | No | Yes | No
Hyland, 1990 ^551^ | NR | Multiple (>5) | Australia | Yes | Yes | No | Yes | NR | Yes | No | No | No | No | No
Binder, 1984 ^542^ | NR | Single | United Kingdom | Yes | Yes | Yes | Yes | Yes | Yes | No | No | No | No | No

[underlined: Key:]

NR—not reported

Table 209. Quality of Reporting and Internal Validity of Results

Study characteristic | N studies reporting | Details
Whether trial was funded by a for-profit institution | 1 (10%) | No for-profit funding: 1 (10%)
Patient inclusion criteria | 10 (100%) | See Table 218
Patient exclusion criteria | 7 (70%) | See Table 218
Method of diagnosis | 10 (100%) | Clinical: 9 (90%)
| | Non-clinical: 1 (10%)
Was selection of patients prospective or retrospective? | 6 (60%) | Prospective: 5 (50%)
| | Retrospective: 1 (10%)
Were patient comorbidities reported? | 3 (30%) | Various
Was the sex distribution of patients reported? | 9 (90%) | a-Percentage female: 55.5%
Was the percentage of females in the patient group within 20 percentage points of the control group? | 3 (30%) | Yes: 3 (30%)
Were patient ages reported? | 9 (90%) | a-Mean age: 42.3 years
Was the mean patient age within 5 years of the mean control age? | 4 (40%) | Yes: 2 (20%)
| | No, patients were = 5 years older: 2 (20%)
Was the duration of patients' condition reported? | 6 (60%) | a-Mean duration: 14.6 months
Was the test operator blinded? | 2 (20%) | Yes: 2 (20%)
Was the test reader blinded? | 3 (30%) | Yes: 3 (30%)
Were there multiple test readers? | 5 (50%) | 2 readers: 3 (30%)
| | 3 readers: 2 (20%)
What was the method for multiple test readers? | 3 (30%) | Independent: 3 (30%)
Was the test compared to an independent reference standard? | 0 (0%) | NA
Were all patients given the study test and the reference standard? | 0 (0%) | NA

[underlined: Key:]

NA-not applicable

a Calculated on a per-patient basis (i.e., weighted by number of patients in each study reporting this characteristic)

Table 210. Quality of Reporting and Generalizability of Results

Study characteristic | N studies reporting | Details
Years in which study was conducted | 0 (0%) | NA
Number of centers in which trial was conducted | 10 (100%) | Single: 8 (80%)
| | Multiple (<5): 1 (10%)
| | Multiple (>5): 1 (10%)
Country(s) were trial was performed | 10 (100%) | USA: 4 (40%)
| | Other: 6 (60%)
Patient inclusion criteria | 10 (100%) | See Table 218
Patient exclusion criteria | 7 (70%) | See Table 218
Were patient comorbidities reported? | 3 (30%) | Various
Was the sex distribution of patients reported? | 9 (90%) | a-Percentage female: 55.5%
Were patient ages reported? | 9 (90%) | a-Mean age: 42.3 years
Was the duration of patients' condition reported? | 6 (60%) | a-Mean duration: 14.6 months
Did all patients have previous conservative treatment? | 10 (100%) | No: 10 (100%)
Did any patients have previous surgical treatment? | 10 (100%) | No: 10 (100%)
Adequate reporting of study's source of patients | 0 (0%) | NA
Was there a potential selection bias for easy cases? | 6 (60%) | Yes: 6 (60%)
Was there a potential selection bias for hard cases? | 0 (0%) | NA

[underlined: Key:]

NA-not applicable

a- Calculated on a per-patient basis (i.e., weighted by number of patients in each study reporting this characteristic)

None of these studies focused exclusively on medial epicondylitis (golfer's elbow). One study ^540^ combined patients with lateral and medial epicondylitis (22 lateral and 2 medial). All other studies focused exclusively on lateral epicondylitis (tennis elbow).

Four articles (40%) reported only summary data on groups of patients(i.e., mean test results for cubital tunnel syndrome group and for control group), so sensitivity and specificity could not be determined from them. Two articles reported counts of positive and negative results, but did not report them both on patients and controls. There were only four articles (40%) from which both sensitivity and specificity of at least one test for epicondylitis could be calculated. Studies that report only one of these characteristics (sensitivity or specificity) are not reliable evidence on the effectiveness of a test, because they do not give assurance that the threshold was set to favor the reported characteristic at the expense of the unreported one.

Because so few articles reported sensitivity and specificity for any test for epicondylitis, and the poor quality of reporting study design and patient characteristics in these articles make it inadvisable to draw conclusions on the basis of a single study, we did not perform quantitative analyses of diagnostics for epicondylitis.

#### Results

A tabulation of patient selection and types of controls appears in Table 211. Nerve conduction tests are not used for diagnosis of epicondylitis because epicondylitis is not a nerve impairment syndrome. Therefore, patient selection was done on the basis of signs and symptoms (3 of the 10 articles), or by unspecified diagnostic criteria (7 of the 10 articles). Table 212 summarizes the reported types of tests and patient selection in those articles. Detailed information on study design, tests reported, patient groups, and patient inclusion/exclusion criteria for each article is found in Table 215, Table 216, Table 217 and Table 218.

Table 211. Patient and Control Group Selection in Epicondylitis Diagnosis

Type of controls | Patient selection (number of articles)
| Symptoms/ presented | Unspecified diagnosis | Total
0 | 4 | | 4
0 | 1 | | 1
1 | 2 | | 3
2 | 0 | | 2
3 | 7 | | 10

Table 212. Epicondylitis Tests and Patient Groups

Legend:
Numeric entries in each cell— Total number of articles, articles from which sensitivity and specificity can be calculated
Tests Reported | Patient selection
| Symptoms/presented | Unspecified diagnosis
Nerve Conduction | 0, 0 | 0, 0
Composite Nerve Conduction | 0, 0 | 0, 0
Imaging | 1, 0 | 2, 2
Sensory | 1, 0 | 0, 0
Signs/Symptoms | 2, 0 | 3, 1
Other | 0, 0 | 3, 2

See Table 3 for the definition of these groups

Table 215. Epicondylitis - Study Design

Article | N centers | Epicon. groups | Epicon. patients | Negative groups | Negative subjects | Was the design prospective or retrospective? | What was the level of reporting? | Could sensitivity and specificity be determined?
Benjamin, 1999 ^549^ | Single | 1 | 10 | 0 | 0 | Prospective | Summary | No: only summary statistics reported
Bredella, 1999 ^74^ | Multiple (<5) | 1 | 35 | 0 | 0 | Prospective | Counts | No control group
Steinborn, 1999 ^71^ | Single | 1 | 23 | 1 | 7 | Retrospective | Counts | Reported by authors
Bauer, 1998 ^550^ | Single | 1 | 10 | 1 | 7 | NR | Summary | No: only summary statistics reported
Friedman, 1998 ^73^ | Single | 1 | 17 | 1 | 7 | NR | Summary | No: only summary statistics reported
Martin, 1998 ^540^ | Single | 1 | 24 | 1 | 16 | Prospective | Counts | Calculated by ECRI
Smith, 1994 ^541^ | Single | 1 | 40 | 0 | 0 | NR | Counts | Calculated by ECRI
Wright, 1992 ^72^ | Single | 1 | 17 | 0 | 0 | Prospective | Summary | No: only summary statistics reported
Hyland, 1990 ^551^ | Multiple (>5) | 1 | 25 | 0 | 0 | Prospective | Counts | No control group
Binder, 1984 ^542^ | Single | 1 | 50 | 1 | 60 | NR | Counts | Calculated by ECRI

Table 216. Epicondylitis - Tests Reported

Article | Signs/ Symptoms | Sensory Tests | Nerve Conduction | Composite Nerve Cond. | Imaging | Other
Benjamin, 1999 ^549^ | | □ | □ | □ | □ | □
Bredella, 1999 ^74^ | □ | □ | □ | □ | | □
Steinborn, 1999 ^71^ | □ | □ | □ | □ | | □
Bauer, 1998 ^550^ | □ | □ | □ | □ | □
Friedman, 1998 ^73^ | | □ | □ | □ | □ | □
Martin, 1998 ^540^ | □ | □ | □ | □ | | □
Smith, 1994 ^541^ | □ | □ | □ | □ | □
Wright, 1992 ^72^ | | | □ | □ | □ | □
Hyland, 1990 ^551^ | | □ | □ | □ | □ | □
Binder, 1984 ^542^ | | □ | □ | □ | □

Table 217. Epicondylitis - Patient Groups

Article | Disorder type | Patient selection | Number of patients for which results are reported | Percent female | Mean age | Age of youngest | Age of oldest | Duration of condition before treatment (months) | Shortest duration | Longest duration | Are patient comorbidities reported?
Benjamin, 1999 ^549^ | Epicondylitis | Unspecified diagnosis | 10 | 30 | 42 | | | | | | No
Bredella, 1999 ^74^ | Epicondylitis | Symptoms/ presented | 35 | 51 | 45 | 22 | 63 | | 3 | 36 | No
Steinborn, 1999 ^71^ | Normal | Healthy volunteers | 7 | 71 | 25 | 22 | 29 | | | | No
Steinborn, 1999 ^71^ | Epicondylitis | Unspecified diagnosis | 23 | 65 | 47 | 29 | 58 | 17.1 | 1 | 84 | No
Bauer, 1998 ^550^ | Normal | Healthy volunteers | 7 | 0 | 38.8 | | | | | | No
Bauer, 1998 ^550^ | Epicondylitis | Unspecified diagnosis | 10 | 0 | 40.8 | | | | | | No
Friedman, 1998 ^73^ | Normal | Healthy volunteers | 7 | 100 | 34.6 | | | | | | Yes
Friedman, 1998 ^73^ | Epicondylitis | Unspecified diagnosis | 17 | 100 | 38.9 | | | 26 | | | Yes
Martin, 1998 ^540^ | Normal | Healthy volunteers | 16 | NR | 31 | 22 | 46 | | | | No
Martin, 1998 ^540^ | Epicondylitis | Unspecified diagnosis | 24 | NR | 38 | 29 | 62 | 5.5 | 1 | 24 | No
Smith, 1994 ^541^ | Epicondylitis | Unspecified diagnosis | 40 | 55 | 40 | | | 23 | | | No
Wright, 1992 ^72^ | Epicondylitis | Symptoms/ presented | 17 | 65 | 44.7 | 36 | 54 | | 2 | 120 | Yes
Hyland, 1990 ^551^ | Epicondylitis | Symptoms/ presented | 25 | 24 | | | | 21.9 | 2 | 156 | No
Binder, 1984 ^542^ | Normal | Healthy volunteers | 60 | NR | | | | | | | Yes
Binder, 1984 ^542^ | Epicondylitis | Unspecified diagnosis | 50 | 68 | 43 | | | 4.5 | 1 | 12 | Yes

Table 218. Epicondylitis - Reported Inclusion and Exclusion Criteria

Article | Reported Patient Inclusion Criteria | Reported Patient Exclusion Criteria
Benjamin, 1999 ^549^ | Clinical diagnosis of lateral epicondylitis. | Prior elbow surgery, bilateral symptoms
Bredella, 1999 ^74^ | Patients referred for MRI imaging of the elbow to rule out lateral epicondylitis. All had symptoms. None had corticosteroid injection in the 3 months prior to MRI. | None reported
Steinborn, 1999 ^71^ | Clinical diagnosis of lateral epicondylitis, based on clinical findings and history including muscle weakness, pain localized to the lateral epicondyle,and aggravation of pain by weight-bearing and resisted supination and wrist extension. | Steroid injections in the 2 months before MRI.
Bauer, 1998 ^550^ | Clinical diagnosis of tennis elbow. | None reported
Friedman, 1998 ^73^ | Patients who had been assessed or treated at a rehabilitation clinic. Inclusion criteria were clinical features such as 1) tenderness at the lateral eipcondyle; 2) pain in the elbow or lateral forearm on resisted wrist extension; 3) pain in the elbow or lateral forearm on resisted finger extension; 4) pain in the elbow or lateral forearm on resisted wrist supination. | Bilateral symptoms, history of fibromyalgia or other disability involving upper extremity.
Martin, 1998 ^540^ | Diagnosis of either lateral or medial epicondylitis based on history and physical exam. | None reported
Smith, 1994 ^541^ | Patients with unilateral epicondylitis recruited from rheumatology outpatient clinics. Localized pain and lateral epicondylar tenderness, increased pain on wrist extension. | Bilateral symptoms, cervical spine symptoms.
Wright, 1992 ^72^ | Patients reported lateral elbow pain of at least 6 weeks duration, and if they experienced pain during two or more of the following five tests: 1) Palpation of the lateral epicondyle; 2) Resisted wrist extension; 3) Passive stretching of the extensor muscle group; 4) Pain on gripping a hand dynamometer; 5) Pain on resisted extension of the middle finger. | Bilateral symptoms, neurological impairment, serious injury or fracture to the upper limbs, cervical or thoracic spine, history of any arthritic condition.
Hyland, 1990 ^551^ | Lateral elbow pain. Non-irritable symptomatic elbows in which pain provoked by activity or examination was quickly relieved with a short period of rest. Positive extension-adduction test with the forearm in supination position, and at least one of the following: pain upon resisted wrist extension, or pain upon passive stretch of the forearm extensors. | Pain of cervical origin or contribution.
Binder, 1984 ^542^ | Localized tenderness near the lateral epicondyle and pain on resisted wrist dorsiflexion. | Localized or generalized arthritis, abnormal ESR (undefined), positive Rose-Waaler, or neurological symptoms or signs in the affected limb.

Nine of the 10 articles (90%) reported only clinical signs and symptoms to diagnose epicondylitis. Table 213 lists the specific signs and symptoms that were reported as inclusion criteria for epicondylitis patients. Three studies performed clinical diagnosis but did not report the specific signs and symptoms that were assessed. Nerve conduction tests are not used for diagnosis of epicondylitis because epicondylitis is not a nerve impairment syndrome.

Table 213. Reported Clinical Inclusion Criteria in Studies of Lateral Epicondylitis

Article | Signs and symptoms used in diagnosis
| RWE | RS | GR | RFE | WT | SE | MW | EA | Other
Benjamin, 1999 ^549^ | | | | | | | | | Clinical diagnosis
Bredella, 1999 ^74^ | | | | | | | | | MRI signal intensity
Steinborn, 1999 ^71^ | ✓ | ✓ | | | ✓ | | ✓
Bauer, 1998 ^550^ | | | | | | | | | Clinical diagnosis
Friedman, 1998 ^73^ | ✓ | ✓ | | ✓
Martin, 1998 ^540^ | | | | | | | | | Clinical diagnosis
Smith, 1994 ^541^ | ✓
Wright, 1992 ^72^ | ✓ | | ✓ | ✓ | | ✓
Hyland, 1990 ^551^ | ✓ | | ✓ | | | ✓ | | ✓
Binder, 1984 ^542^ | ✓ | ✓ | ✓ | | ✓
Totals | 6 | 3 | 3 | 2 | 2 | 2 | 1 | 1 | 4

[underlined: Key:]

RWE-pain or tenderness upon resisted wrist extension

RS-pain or tenderness upon resisted supination of forearm (also called Mill's test)

GR-grip strength

RFE-pain or tenderness upon resisted extension of middle finger

WT- weights test

SE-stretching of extensors

MW-muscle weakness

EA-pain or tenderness with extension adduction test

The only study that did not use clinical signs and symptoms to diagnose epicondylitis was Bredella ^74^ . This was an MRI study in which patients were “referred for MR imaging of the elbow to rule out lateral epicondylitis.” The authors stated that epicondylitis is typically diagnosed clinically, and that the need for MRI only arises when “symptoms are resistant to medical management.”

The resisted wrist extension test (RWE) was used most frequently in operational definitions of epicondylitis (six of the 10 articles). This test is positive if the patient feels pain or tenderness upon resisted extension of the wrist. Only 4 of the 6 actually reported RWE findings (Table 214). However, it was not possible to determine both sensitivity and specificity of the RWE test for any of these four studies. Two studies ^541,^ ^542^ required positive RWE findings in all patients included in the study, thus they cannot be used to assess the effectiveness of the RWE test because of selection bias. Friedman et al. did not report RWE findings in their control group, so specificity could not be determined. Wright et al. ^72^ had no control group, so specificity could not be determined.

Table 214. Resisted Wrist Extension for the Diagnosis of Lateral Epicondylitis

Article | N | Was positive RWE a criterion for inclusion of patients in the study? | How many patients had pain or tenderness upon RWE? | Could sensitivity and specificity be derived from the published results?
Steinborn, 1999 ^71^ | 23 | No | NR | No
Friedman, 1998 ^73^ | 17 | No | 4 (24%) | No
Smith, 1994 ^541^ | 40 | Yes | 40 (100%) | No
Wright, 1992 ^72^ | 17 | No | 16 (94%) | No
Hyland, 1990 ^551^ | 25 | No | NR | No
Binder, 1983 ^542^ | 50 | Yes | 50 (100%) | No

RWE-Resisted wrist extension

NR-Not reported

Thus there were no articles in the evidence base we examined that reported sensitivity and specificity of the RWE test.

#### Conclusions

For diagnosis of epicondylitis, the evidence base is small and heterogeneous. None of the relevant studies are sufficiently large or well-designed to permit one to draw a strong evidence-based conclusion from them on any individual test for epicondylitis.

### Question #2. What are the specific indications for surgery for epicondylitis?

No published studies directly address specific indications for surgery for epicondylitis. Therefore, in this section we present the characteristics of patients who have received surgery as described in published studies. Because patients enrolled in clinical trials may differ from the general population of patients encountered in general practice, these data may not accurately reflect the characteristics of most patients who have received surgery for epicondylitis. However, they represent the most comprehensive set of available information.

#### Evidence base

For this question, we included controlled trials and case series that described patients being surgically treated for epicondylitis. We identified 19 such studies.

#### Failure of conservative treatment

Nine of the 19 available studies (47.4%) reported that the main criterion for entry into the trial was the presence of epicondylitis that had failed to respond to conservative treatment. Eight of the 19 available studies (42.1%) reported no details about patient inclusion/exclusion criteria for entry into the trial.

#### Patient demographics

The ages and gender composition of the patient groups included in the studies are listed in Table 219. All 19 of the studies provided information about the sex of their patients. The sexes were almost equally represented in the patient groups. Overall, 43.61% of the patients were female, with a range from 7.9 to 76% female. The gender compositions of patient groups from the individual studies are shown in Figure 57. Fifteen of the 19 available studies reported information about the ages of the patients. Patients who received surgery for epicondylitis were predominantly of middle age. The mean age of the patients was 44.3 years old, with a range from 16 to 70 years of age. The mean ages and range of ages of each individual study are shown in Figure 58.

Table 219. Age and sex of patients receiving surgery for epicondylitis

Study | Number of patients | Number of males | Number of females | Percent female | Age reported as mean or median? | Age | Age of youngest patient | Age of oldest patient
Grundberg 2000 ^552^ | 34 | 17 | 17 | 50.0 | Mean | 43 | 27 | 64
Almquist 1998 ^83^ | 61 | 37 | 24 | 39.3 | Mean | 43.3 | 27 | 63
Bankes 1998 ^553^ | 24 | 11 | 13 | 54.2 | Mean | 45.3 | 32 | 54
Organ 1997 ^554^ | 34 | 16 | 18 | 52.9 | Mean | 40 | 28 | 70
Wilhelm 1996 ^84^ | 166 | 70 | 96 | 57.8 | Mean | 44.5 | 21 | 62
Gabel 1995 ^555^ | 26 | 18 | 8 | 30.8 | Mean | 43 | 17 | 64
Kurvers 1995 ^556^ | 40 | 28 | 12 | 30.0 | Mean | 42 | 22 | 56
Ollivierre 1995 ^557^ | 48 | 38 | 10 | 20.8 | Mean | 42 | 16 | 66
Newey 1994 ^558^ | 28 | 13 | 15 | 53.6 | Mean | 44.8 | NR | NR
Verhaar 1993 ^559^ | 63 | 42 | 21 | 33.3 | Mean | 45 | 25 | 67
Wittenberg 1992 ^560^ | 86 | 60 | 26 | 30.2 | Mean | 47.5 | 25 | 67
Vangsness 1991 ^561^ | 38 | 35 | 3 | 7.9 | Mean | 43 | 21 | 65
Tan 1989 ^562^ | 25 | 8 | 17 | 68.0 | NR | NR | NR | NR
Goldberg 1988 ^563^ | 30 | 8 | 22 | 73.3 | NR | NR | NR | NR
Chotigavanich 1986 ^564^ | 50 | 12 | 38 | 76.0 | NR | NR | NR | NR
Calvert 1985 ^565^ | 37 | 21 | 16 | 43.2 | Mean | 43.7 | NR | NR
Baumgard 1982 ^566^ | 34 | 22 | 12 | 35.3 | Mean | 48 | 30 | 67
O'Neil 1980 ^567^ | 50 | 27 | 23 | 46.0 | NR | NR | NR | NR
Rosen 1980 ^568^ | 50 | 38 | 12 | 24.0 | Mean | 49 | 18 | 64

NR = not reported

Figure 57. Sex distribution in trials of surgical treatment for epicondylitis

The vertical line indicates the mean % of females

Figure 58. Distribution of patient ages in studies of surgical treatment for epicondylitis

The vertical line indicates the mean age

#### Signs and symptoms

Descriptions of signs and symptoms of the patients before treatment were incompletely reported. The number of studies reporting on each sign and symptom are listed in Table 220. Only six different signs and symptoms were reported on, and less than 16% of the studies reported on the presence of any given symptom or sign, as is shown in Figure 59. The mean percentages of patients with each sign and symptom reported by the studies are listed in Table 221 and shown in Figure 60.

Table 220. Reporting of signs and symptoms in studies of surgical treatment for epicondylitis

Sign or symptom | Number of studies reporting
Clumsiness | 0
Lifting test | 0
Middle finger test | 0
Pain | 2
Resisted pronation | 3
Resisted supination | 1
Resisted wrist extension | 1
Restricted range of motion | 0
Stiffness | 0
Swelling | 1
Symptoms with ADLs | 0
Tenderness | 3
Weakness | 0
Weakness of grip | 0

ADL = activities of daily living

Table 221. Signs and symptoms of patients treated with surgery for epicondylitis

Study | Number of patients | Sign or symptom | Number of patients with sign or symptom | Percentage of patients
Almquist 1998 ^83^ | 61 | Pain | 61 | 100.0
Goldberg 1988 ^563^ | 30 | Pain | 30 | 100.0
Gabel 1995 ^555^ | 26 | Resisted pronation | 26 | 100.0
Verhaar 1993 ^559^ | 63 | Resisted pronation | 34 | 54.0
Baumgard 1982 ^566^ | 34 | Resisted pronation | 34 | 100.0
Verhaar 1993 ^559^ | 63 | Resisted supination | 31 | 49.2
Verhaar 1993 ^559^ | 63 | Resisted wrist extension | 63 | 100.0
Goldberg 1988 ^563^ | 30 | Swelling | 3 | 10.0
Almquist 1998 ^83^ | 61 | Tenderness | 61 | 100.0
Gabel 1995 ^555^ | 26 | Tenderness | 26 | 100.0
Verhaar 1993 ^559^ | 63 | Tenderness | 63 | 100.0

Figure 59. Reporting of symptoms and signs in studies of surgical treatment for epicondylitis

Figure 60. Symptoms of patients with epicondylitis

Only three out of the 19 studies reported the duration of symptoms before treating the patients with surgery. These data are listed in Table 222. The mean duration before treatment was 27.7 months, with a range of 3 to 126 months.

Table 222. Duration of symptoms before surgical treatment for epicondylitis

Study | Number of patients | Mean duration, months | Shortest duration, months | Longest duration, months
Grundberg 2000 ^552^ | 34 | 18 | 3 | 66
Almquist 1998 ^83^ | 61 | 31.3 | 6 | 72
Bankes 1998 ^553^ | 24 | 32.2 | 11 | 126

Because so few studies reported on signs and symptoms, or duration of symptoms, it is difficult to arrive at a generalized characterization of patients who received surgical treatment for epicondylitis.

#### Employment characteristics

Only five of the 19 studies reported employment-related data on their patients. The occupations of patients receiving surgery for epicondylitis and the percentage of patients in each study with that occupation are listed in Table 223. The number of studies reporting each occupational category are shown in Figure 61, and the reported percentages of patients with each occupation are shown in Figure 62.

Table 223. Reported occupations of patients receiving surgery for epicondylitis

Study | Occupation | Number of Patients | Number of patients with occupation | Percent of patients with occupation
Verhaar 1993 ^559^ | Assistive living services | 63 | 4 | 6.3
Kurvers 1995 ^556^ | Beauty specialist | 40 | 1 | 2.5
Chotigavanich 1986 ^564^ | Businessman | 50 | 9 | 18.0
Verhaar 1993 ^559^ | Cleaning services | 63 | 4 | 6.3
Kurvers 1995 ^556^ | Clerical and administrative support | 40 | 4 | 10.0
Tan 1989 ^562^ | Clerical and administrative support | 25 | 3 | 12.0
Verhaar 1993 ^559^ | Clerk | 63 | 1 | 1.6
Verhaar 1993 ^559^ | Construction | 63 | 7 | 11.1
Wittenberg 1992 ^560^ | Domestic workers | 86 | 12 | 14.0
Tan 1989 ^562^ | Factory operator | 25 | 3 | 12.0
Verhaar 1993 ^559^ | Farmer/gardener | 63 | 4 | 6.3
Chotigavanich1986 ^564^ | Government officer | 50 | 10 | 20.0
Kurvers 1995 ^556^ | Homemaker | 40 | 8 | 20.0
Verhaar 1993 ^559^ | Homemaker | 63 | 10 | 15.9
Tan 1989 ^562^ | Homemaker | 25 | 7 | 28.0
Chotigavanich 1986 ^564^ | Homemaker | 50 | 27 | 54.0
Tan 1989 ^562^ | Laborer | 25 | 2 | 8.0
Chotigavanich 1986 ^564^ | Laborer | 50 | 4 | 8.0
Verhaar 1993 ^559^ | Machine operator/mechanic | 63 | 11 | 17.5
Kurvers 1995 ^556^ | Manual Worker | 40 | 15 | 37.5
Wittenberg 1992 ^560^ | Manual Worker | 86 | 31 | 36.0
Kurvers 1995 ^556^ | Music (organ) student | 40 | 1 | 2.5
Kurvers 1995 ^556^ | Nurse | 40 | 4 | 10.0
Tan 1989 ^562^ | Nurse | 25 | 3 | 12.0
Verhaar 1993 ^559^ | Piano player | 63 | 1 | 1.6
Kurvers 1995 ^556^ | Psychologist | 40 | 1 | 2.5
Kurvers 1995 ^556^ | Sales workers - manager/supervisors | 40 | 1 | 2.5
Wittenberg 1992 ^560^ | Sales workers - manager/supervisors | 86 | 12 | 14.0
Verhaar 1993 ^559^ | Sculptor | 63 | 1 | 1.6
Kurvers 1995 ^556^ | Teacher | 40 | 1 | 2.5
Verhaar 1993 ^559^ | Teacher | 63 | 1 | 1.6
Tan 1989 ^562^ | Teacher | 25 | 4 | 16.0
Tan 1989 ^562^ | Technical | 25 | 3 | 12.0
Wittenberg 1992 ^560^ | Typists | 86 | 13 | 15.1
Kurvers 1995 ^556^ | Unemployed | 40 | 2 | 5.0
Wittenberg 1992 ^560^ | Unemployed | 86 | 6 | 7.0

Figure 61. Percentage of studies reporting occupations of patients with epicondylitis

Figure 62. Percentage of patients with reported occupations receiving surgery for epicondylitis

The categorization of occupations used by the studies was not uniform, but in some cases, categories can be combined across studies. However, in many cases, descriptions of types of employment are unclear and there may be considerable overlap between groups. From the reported information it is not possible to determine the amount and type of arm/hand use required on a regular basis for any of the occupational groups.

#### Comorbidities

Comorbid conditions were not reported by any of the 19 studies. One study excluded patients who had carpal or cubital tunnel syndrome in addition to epicondylitis. Because of the lack of information, no conclusions can be drawn regarding the presence of comorbidities among patients receiving surgery for epicondylitis or the impact of comorbidities on whether a patient is a candidate for surgery.

#### Conclusions

Nineteen studies of patients who received surgery for epicondylitis were identified. A typical patient who received surgery for epicondylitis was middle-aged and equally likely to be male or female, but due to a lack of reported data, few trends or characteristics of patients who received surgery could be identified.

### Question #3. What are the relative benefits and harms of various surgical and nonsurgical interventions for persons with epicondylitis?

#### Evidence base

We considered only controlled trials that evaluated therapies as treatments for patients with epicondylitis for this section of the report. We retrieved 57 studies that met the inclusion criteria (see the section Inclusion Criteria). Six were excluded because they contained reporting or design difficulties serious enough to preclude interpretation of the results. These studies, and the reasons for their exclusion, are shown in Table 224. Thirty-eight randomized controlled trials, four randomized crossover trials, and eight controlled trials that evaluated eighteen different types of therapies as treatments for epicondylitis were included in the answer to this question. These trials are listed in Table 225. All of the trials studied only patients with lateral epicondylitis except for that of Stahl 1997, who studied patients with medial epicondylitis, and Brattberg 1983, who studied a mixed population of patients with lateral or medial epicondylitis. We have organized our answer to this question into sub-sections, one for each type of treatment.

Table 224. Excluded studies

Study | Reason for exclusion
Simunovic 1998 ^569^ | Patients were treated until they improved, and only then were they crossed over to the placebo treatment. This creates a bias in favor of improvement.
Burton 1985 ^570^ | Insufficient details to allow comparison of patient groups. Data from control group not reported.
Heyse-Moore 1984 ^571^ | Patients were allocated into different treatment groups on the basis of what symptoms they presented with, and thus the treatment groups cannot be directly compared.
Rosenthal 1982 ^572^ | It is unclear from the few details provided whether the patients actually had lateral epicondylitis.
Day 1978 ^573^ | Patients were treated until they improved. This creates a bias in favor of improvement.
Baily 1957 ^574^ | Many patients received confounding co-interventions, such as extra injections, physiotherapy, etc. that are incompletely described.

Table 225. Trials evaluating interventions for epicondylitis

Therapies evaluated | Study | Trial Design
Acupuncture | Molsberger 1994 ^575^ | Randomized controlled trial
| Haker 1990 ^576^ | Randomized controlled trial
Bracing | Wuori 1998 ^577^ | Randomized controlled crossover
| Forbes 1990 ^578^ | Crossover
Bracing compared to physiotherapy | Solveborn 1997 ^579^ | Controlled trial
Bracing plus physiotherapy | Clements 1993 ^580^ | Controlled trial
ESWT | Rompe 1996 ^581^ , ^582^ | Randomized controlled trial
GAGPs injections | Akermark 1995 ^583^ | Randomized controlled trial
Laser | Basford 2000 ^584^ | Randomized controlled trial
| Papadopoulos 1996 ^585^ | Randomized controlled trial
| Krasheninnikoff 1994 ^586^ | Randomized controlled trial
| Vasseljen 1992 ^587^ | Randomized controlled trial
| Haker 1991 ^588^ | Randomized controlled trial
| Haker 1991 ^589^ | Randomized controlled trial
| Haker 1990 ^590^ | Randomized controlled trial
Laser compared to ultrasound plus massage | Vasseljen 1992 ^591^ | Randomized controlled trial
Manipulations | Vicenzino 1996 ^592^ | Randomized controlled crossover
Manipulations compared to Ultrasound plus physiotherapy | Drechsler 1997 ^593^ | Randomized controlled trial
Manipulations | Burton 1988 ^594^ | Randomized controlled trial
Manipulations plus bracing
Manipulations plus topical NSAIDs
Manipulations plus topical NSAIDs plus bracing
Oral NSAIDs | Labelle 1997 ^595^ | Randomized controlled trial
| Adelaar 1987 ^596^ | Randomized controlled trial
| Stull 1986 ^597^ | Randomized controlled trial
PEMF | Devereaux 1985 ^598^ | Randomized controlled trial
Physiotherapy compared to ultrasound | Pienimaki 1996 ^599^ ^600^ | Randomized controlled trial
Steroid injections | Stahl 1997 ^601^ | Randomized controlled trial
| Solveborn 1995 ^602^ | Randomized controlled trial
| Price 1991 ^603^ | Randomized controlled trial
| Kivi 1982 ^604^ | A-B trial
| Clarke 1975 ^605^ | Controlled trial
Steroid injection | Halle 1986 ^606^ | Randomized controlled trial
TENS
Ultrasound
Phonophoresis
Steroid injections compared to manipulation | Verhaar 1995 ^607^ | Randomized controlled trial
Steroid injections compared to acupuncture | Brattberg 1983 ^608^ | Controlled trial
Steroid injection compared to Oral NSAIDs | Hay 1999 ^609^ | Randomized controlled trial
| Saartok 1986 ^610^ | Randomized controlled trial
Steroid injections | Haker 1993 ^611^ | Randomized controlled trial
Bracing
Immobilization
Surgery | Almquist 1998 ^83^ | Controlled trial
| Wilhelm 1996 ^84^ | Controlled trial
TENS | Johannsen 1993 ^612^ | Randomized controlled trial
Topical DMSO | Percy 1981 ^613^ | Randomized controlled trial
Topical NSAIDs | Demirtas 1998 ^614^ | Randomized controlled trial
| Schapira 1991 ^615^ | Randomized controlled trial
| Burnham 1998 ^616^ | Randomized controlled crossover
Ultrasound | Lundeberg 1988 ^617^ | Randomized controlled trial
| Binder 1985 ^618^ | Randomized controlled trial
| Haker 1991 ^619^ | Randomized controlled trial
Ultrasound | Holdsworth 1993 ^620^ | Randomized controlled trial
Phonophoresis
Ultrasound plus bracing
Phonphoresis plus bracing
Ultrasound | Stratford 1989 ^621^ | Randomized controlled trial
Phonophoresis
Ultrasound plus massage
Phonophoresis plus massage

ESWT = extracorporal shock wave therapy

GAGPs = glucosaminoglycan polysulfate

NSAID = non steroidal anti-inflammatory drug

PEMF = pulsed electromagnetic field

TENS = transcutaneous electrical nerve stimulation

DMSO = dimethylsulfoxide

### What are the relative benefits and harms of low-level laser therapy for persons with epicondylitis?

The literature addressing this question consists of seven studies that compared low level laser treatment to sham laser treatment. Therefore, in this section we address the benefits and harms of laser therapy relative to sham treatment, but the literature included in this section does not allow one to determine the effectiveness of laser therapy relative to any other type of therapy.

Low level red or infrared lasers have been used to treat pain and speed healing. The lasers are thought to possess biostimulating and regenerative properties; however, the physiological basis of such properties is uncertain. Low-level lasers have also been claimed to decrease pain by increasing serotinin metabolism and by slowing nerve conduction. ^584,^ ^586^

#### Internal validity

We identified seven studies that included a total of 320 patients that evaluated low-level laser therapy for treating epicondylitis. All seven studies were prospective double-blinded randomized controlled trials that compared laser therapy to sham laser therapy. Details of the designs of the studies relevant to the internal validity of the studies are shown in Table 226.

Table 226. Internal validity

Study | Number of patients | Number of centers | Funded by a for-profit agency? | Study design | Prospective? | Blinding | %Attrition | Intent to treat analysis | Compliance
Basford 2000 ^584^ | 52 | 1 | No | RCT | Yes | Double | 9.6 | No | NA
Papadopoulos 1996 ^585^ | 29 | 1 | No | RCT^a^ | Yes | Double | 0 | Yes | NA
Krasheninnikoff 1994 ^586^ | 48 | 1 | NR | RCT | Yes | Double | 4.2 | Yes | NA
Vasseljen 1992 ^587^ | 30 | 1 | NR | RCT | Yes | Double | 3.3 | Yes | NA
Haker 1991 ^588^ | 52 | 1 | NR | RCT | Yes | Double | 26.9 | No | NA
Haker 1991 ^589^ | 60 | 1 | NR | RCT^a^ | Yes | Double | 28.3 | No | NA
Haker 1990 ^590^ | 49 | 1 | NR | RCT | Yes | Double | 20.4 | No | NA

a may have been improperly randomized

NA = not applicable

NR = not reported

RCT = randomized controlled trial

Two of the studies had statistically significant differences in the gender compositions between their patient groups. The Papadopoulos 1994 trial contained a sham group that was 86.7% female, and a laser group that was 57.1% female (chi-squared test, calculated by ECRI, p = 0.002426). The Haker 1991 ^589^ trial contained a sham group that was 13.8% female and a laser group that was 37.9% female (chi-squared test, calculated by ECRI, p = 0.035808). These differences are surprising in a randomized controlled trial, and could suggest that the randomization process was not optimal. This may have influenced the reported results.

Neither the three studies by Haker, nor the study by Basford 2000, did not use intent-to-treat analysis. The three studies by Haker had quite high attrition rates (over 20%). Ignoring attrition when analyzing the data can create a bias in the results. Where possible, we have tried to compensate for this by attempting to gauge the maximum possible effect of not following this principle. Thus, we assumed that all patients who were not followed until the end of the study received unsuccessful treatment. This is a conservative assumption. However, if statistical significance is obtained under this assumption, one can be more confident that the magnitude of this design weakness is not large enough to overturn the results of a statistically significant trial. We were able to compensate for not following the intent-to-treat principle for the trials by Haker, but not for the trial Basford 2000. Our compensation did not change the conclusions of any of the trials.

#### Generalizability

Details about the patients enrolled in these trials are shown in Table 227. The mean patient age in these trials ranged from 44.3 to 48.5. Krasheninnikoff 1994 did not report the gender composition of the patient groups; the other studies reported that their patient groups were 25.0% to 72.4% female. These patient characteristics approximate those reported in published studies of the epidemiology of epicondylitis (see the Introduction), suggesting that the results of the studies are broadly generalizable beyond their particular patient groups.

Table 227. Generalizability: patient characteristics

Study | Number of patients | Mean age and range | % female | Duration of condition mean and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Did the study exclude patients with severe disease? | Did the study exclude patients with mild disease?
Basford 2000 ^584^ | 52 | 45.1 | 51.9 | 6.4 | NR | NR | NR | NR | NR | NR | NR | No | No
Papadopoulos 1996 ^585^ | 29 | 45 | 72.4 | 5.8 | NR | 0 | 0 | 0 | 0 | 0 | 0 | No | No
Krasheninnikoff 1994 ^586^ | 48 | 48.5 (37–64) | NR | 3 (1–12) | NR | 0 | 0 | NR | 0 | 0 | NR | No | No
Vasseljen 1992 ^587^ | 30 | 45.5 (25–63) | 50.0 | 3.5 (1–12) | NR | 0 | NR | NR | NR | NR | NR | No | No
Haker 1991 ^589^ | 60 | 45.3 (33–65) | 25.0 | 5.5 (1–60) | NR | 0 | NR | 0 | 0 | NR | NR | No | No
Haker 1991 ^588^ | 52 | 44.3 (22–66) | 34.6 | 9.5 (1–60) | NR | NR | NR | NR | NR | NR | NR | No | No
Haker 1990 ^590^ | 49 | 46.7 (24–70) | 42.8 | 7 (1–36) | NR | 0 | NR | 0 | 0 | NR | NR | No | No

NR = not reported

The presence of various co-morbidities is incompletely reported in these studies. Some studies excluded patients with co-morbidities, indicated in Table 227 by a zero under that comorbidity. This somewhat limits the generalizability of these studies, as comorbidities are not exclusion criteria for laser treatment.

None of the studies reported any information about the occupations or employment status of the patients. The extent to which the employment characteristics of these patients may be generalized to the overall population of epicondylitis patients cannot be determined.

#### Results

##### Success of Treatment

Four studies that enrolled a total of 173 patients reported on success of treatment. This outcome was evaluated by asking the patients to rate their symptoms on categorical scales. The results are shown in Table 228 and summarized in Table 229. Effect sizes (Hedges'd) were calculated for each study using a conservative correction for attrition as discussed previously. The effect sizes of the one to 1.5 month followup time and the longest followup time for each study were combined meta-analytically using a fixed-effect model. The results of these analyses are shown in Table 230. The studies were found to not be heterogeneous by the Q-test at either time point, and thus a summary effect size is statistically valid. The summary effect sizes for both meta-analyses were positive, indicating a trend towards laser therapy being more successful, but both 95% confidence intervals contained zero, indicating that there was no statistically significant difference between success of treatment when comparing laser therapy to sham treatment. The effect sizes of are shown graphically in Figure 63 and Figure 64. A U-test of the data showed that the distribution of the effect sizes of the laser treatment groups and the sham treatment groups overlapped by 89.9% at the one to 1.5 month followup time, and 83.7% at the longest followup times. This is shown graphically in Figure 65 and Figure 66.

Table 228. Results of the success of treatment with laser therapy

Study | Number of patients | Global outcome, patient-rated | Statistical significance of the difference between groups^a^
Krasheninnikoff 1994 ^586^ | 18 sham | Sham- at one month, 3 cured, 7 more effective, 8 unchanged. At 2.5 months, 6 cured, 5 more effective, 7 unchanged. | Chi-squared test
| 18 laser | Laser- at one month, 2 cured, 9 more effective, 7 unchanged. At 2.5 months, 6 cured, 4 more effective, 8 unchanged. | At one month, p = 0.772338
| | | At 2.5 months, p = 0.914947
| | | Not statistically significantly different
Vasseljen 1992 ^587^ | 13 sham | Sham- at two weeks, 0 cured, 8 more effective, 5 no change, 2 worse. At 1.5 months, 3 cured, 5 more effective, 5 no change, 2 worse. At 5.5 months, 4 (30.7%) were successfully treated. | Chi-squared test
| 15 laser | Laser- at two weeks, 3 cured, 7 more effective, 3 no change, 2 worse. At 1.5 months, 7 cured, 5 more effective, 1 no change, 2 worse. At 5.5 months, 8 (53.3%) were successfully treated. | At 2 weeks, p = 0.456057
| | | At 1.5 months, p = 0.121335
| | | At 5.5 months, p = 0.136037
| | | Not statistically significantly different
Haker 1991 ^589^ | 29 sham | Sham: at 1.5 months, 0 excellent, 5 good, 17 improved,10 some improvement, 7 unchanged. At 3 months, 4 excellent, 7 good, 8 improved, 2 some improvement, 6 unchanged. At 6 months, 3 excellent, 6 good, 10 improved, 4 some improvement, 0 unchanged. | Chi-squared test
| 29 laser | Laser- at 1.5 months, 1 excellent, 7 good, 16 improved, 9 some improvement, 5 unchanged. At 3 months, 2 excellent, 11 good, 10 improved, 1 some improvement, 4 unchanged. At 6 months, 3 excellent, 15 good, 5 improved, 1 some improvement, 0 unchanged | At 1.5 months, p = 0.097781
| | | At 3 months, p = 0.023323
| | | At 6 months, p = 0.006687
| | | Difference is statistically significant for 3 and 6 months of followup
Haker 1990 ^590^ | 26 sham | Sham: at 1.5 months, 1 excellent, 11 good, 9 improved, 4 some improvement, 5 unchanged. At 3 months, 1 excellent, 12 good, 6 improved, 1 some improvement, 6 unchanged. At one year, 8 excellent, 6 good, 6 improved, 3 some improvement, and 1 unchanged. | Chi-squared test
| 23 laser | Laser: at 1.5 months, 1 excellent, 4 good, 12 improved, 7 some improvement, 6 unchanged. At 3 months, 5 excellent, 7 good, 8 improved, 3 some improvement, 2 unchanged. At one year, 6 excellent, 8 good, 4 improved, 2 some improvement, 8 unchanged. | At 1.5 months, p = 0.065075
| | | At 3 months, p = 0.015251
| | | At one year, p = 0.107943
| | | Difference is statistically significant for 3 months of followup

a calculated by ECRI

Table 229. Success of treatment with laser therapy for epicondylitis

Study | Number of patients | Followup time | Which procedure was more effective? | Was the difference statistically significant? | Effect size d (95% CI)^a^
Krasheninnikoff 1994 ^586^ | 18 sham | 1 month | Laser | No | 0.19 (-0.46 to 0.85)
| 18 laser | 2.5 months | Sham | No | -0.11 (-0.77 to 0.54)
Vasseljen 1992 ^587^ | 15 sham | 2 weeks | Laser | No | 0.64 (-0.09 to 1.38)
| 15 laser | 1.5 months | Laser | No | 0.73 (-0.01 to 1.47)
| | 5.5 months | Laser | No | 0.61 (-0.23 to 1.46)
Haker 1991 ^589^ | 29 sham | 1.5 months | Laser | No | 0.28 (-0.24 to 0.80)
| 29 laser | 3 months | Laser | Yes | 0.24 (-0.28 to 0.76)
| | 6 months | Laser | Yes | 0.50 (-0.03 to 1.02)
Haker 1990 ^590^ | 26 sham | 1.5 months | Sham | No | -0.44 (-1.01 to 0.13)
| 23 laser | 3 months | Laser | Yes | 0.43 (-0.13 to 1.00)
| | 12 months | Sham | No | -0.01 (-0.58 to 0.55)

a calculated by ECRI

Table 230. Results of meta-analysis of effect of laser therapy vs. sham therapy on global outcome

Analysis | Study | N | Effect size | 95% CI | P value | Standardized residual | Outlier by std. Residual?
One to 1.5 months | Krasheninnikoff 1994 ^586^ | 36 | 0.19 | -0.46 to 0.85 | 0.56 | 0.20 | No
| Vasseljen 1992 ^587^ | 30 | 0.73 | -0.01 to 1.47 | 0.053 | 1.74 | No
| Haker 1991 ^589^ | 58 | 0.28 | -0.24 to 0.80 | 0.29 | 0.68 | No
| Haker 1990 ^590^ | 49 | -0.44 | -1.01 to 0.13 | 0.13 | -2.34 | Yes
Longest followup time, conservative correction for attrition | Krasheninnikoff 1994 ^586^ | 36 | -0.11 | -0.77 to 0.54 | 0.73 | -1.15 | No
| Vasseljen 1992 ^587^ | 30 | 0.61 | -0.23 to 1.46 | 0.15 | 0.98 | No
| Haker 1991 ^589^ | 58 | 0.50 | -0.03 to 1.02 | 0.062 | 1.26 | No
| Haker 1990 ^590^ | 49 | -0.01 | -0.58 to 0.55 | 0.96 | -1.00 | No
Longest followup time, opposite correction for attrition | Krasheninnikoff 1994 ^586^ | 36 | -0.11 | -0.77 to 0.54 | 0.73 | 0.15 | No
| Vasseljen 1992 ^587^ | 30 | -0.51 | -0.51 to 1.09 | 0.48 | 1.19 | No
| Haker 1991 ^589^ | 58 | -0.85 | -0.85 to 0.19 | 0.21 | -0.81 | No
| Haker 1990 ^590^ | 49 | -0.77 | -0.77 to 0.35 | 0.47 | -0.21 | No
Summary 1 to 1.5 months | 4 RCT's | 173 | 0.13 | -0.17 to 0.43 | 0.39 | Q = 6.77 | P of Q = 0.079
Summary, longest, conservative | 4 RCT's | 173 | 0.22 | -0.08 to 0.53 | 0.15 | Q = 3.59 | P of Q = 0.31
Summary longest, opposite | 4 RCT's | 173 | -0.16 | -0.46 to 0.15 | 0.31 | Q = 1.68 | P of Q = 0.64

Figure 63. Effect sizes of laser therapy compared to sham therapy as a treatment for epicondylitis, 1 to 1.5 months of followup

Figure 64. Effect sizes of laser therapy compared to sham therapy as a treatment for epicondylitis, longest times of followup

Figure 65. Overlap of effect size distributions in patients receiving laser or sham therapy, 1–1.5 months of followup

Figure 66. Overlap of effect size distributions in patients receiving laser or sham therapy, longest times of followup

Because the attrition rates in the studies by Haker are high at the longest followup times (>20%), we performed an analysis to see how attrition might have affected the overall results. We originally assumed that all of the patients lost to followup had failed treatment. Using the opposite assumption, that all of the patients lost to followup had been cured, our conclusions did not change. The summary effect size was not statistically significant under either of our assumptions (Table 230). However, using the the conservative assumption, a trend towards laser therapy being more effective was observed, while under the opposite assumption a trend towards sham therapy being more effective was observed.

Data from other times of followup were not combined meta-analytically because only one or two studies reported data for each of the other times of followup.

##### Work Status

Only one study of 30 patients reported this outcome. The study counted the number of patients working or not working 5.6 months after the study began. The data from this study are summarized in Table 231 and Table 232. A statistically nonsignificant difference in work status was reported between sham treated and laser treated patients. This study could have detected a 26% or greater difference between groups, so statistical power may not be a substantial issue with it.

Title 231. Results of work status after treatment with laser therapy

Study | N patients | Time of followup | Number of patients working | Statistical significance of the difference between groups
Vasseljen 1992 ^587^ | 13 Sham | 5.5 months | 9 sham treated patients were working and 13 laser treated patients were working | Chi-squared test^a^
| 15 Laser | | | p = 0.262

a calculated by ECRI

Title 232. Work status after treatment with laser therapy

Study | Number of patients | Which procedure had more patients working? | Was the difference statistically significant? | Effect size d (95% CI)^a^ | What is the minimal difference between groups the study had the statistical power to detect?
Vasseljen 1992 ^587^ | Sham 13 | Laser | No | 0.57 (-0.48 to 1.61) | 26%
| Laser 15

a calculated by ECRI

##### Pain

The effect of laser treatment on pain was reported by four studies of 143 patients in total. All four studies reported pain rated by the patients on visual analog scales (VAS). The data reported by the studies is shown in Table 233 and summarized in Table 234. The reported results of the studies are shown graphically in Figure 67 and the effect sizes (Hedges' d) of the longest followup times are shown graphically in Figure 68. The results for all other time points are similar to that found for the longest followup times.

Title 233. Results of the effect of laser treatment on pain

Study | N patients | Pain measurements | Statistical significance of the difference between groups
Basford 2000 ^584^ | 24 sham | No data reported | Wilcoxon's rank sum test
| 23 laser | | At 2 weeks, p = 0.551
| | | At 1 month, p = 0.371
| | | At 2 months, p = 0.488
Papadopoulos 1994 ^585^ | 15 sham | No data reported | Test not reported
| 14 laser | | NS
Krasheninnikoff 1994 ^586^ | 18 sham | At one month, | Mann-Whitney rank sum test
| 18 laser | Sham- 22 median 95% CI (12 to 63) | p >0.05
| | Laser- 27 median 95% CI (5 to 50)
Vasseljen 1992 ^587^ | 15 sham | Mean (95% CI) | t-test
| 15 laser | Sham- at time 0, 3.8 (2.75 to 4.8). At 2 weeks, 3.8 (2.75 to 4.7). At 1.5 months, 3.2 (2.4 to 4.2). At 5.5 months, 0.7 (0.4 to 1.0) | at time 0, p = 0.591
| | Laser- at time 0, 4.2 (3.2 to 5.2). At 2 weeks, 3.6 (2.2 to 4.95). At 1.5 months, 2.65 (1.5 to 3.8). At 5.5 months, 0.49 (0.2 to 0.75) | at 2 weeks, p = 0.814
| | | at 1.5 months, p = 0.504
| | | at 5.5 months, p = 0.317

Title 234. Summary of the effect of laser treatment on pain

Study | N patients | Which procedure was most effective at treating pain? | Was the difference statistically significant? | Effect size d (95% CI)^a^ | What is the minimal difference between groups that the study had the statistical power to detect?
Basford 2000 ^584^ | 24 Sham | No difference | No at all followup times | 0.20 (-0.37 to 0.77)^b^ | NC
| 23 Laser
Papadopoulos 1994 ^585^ | 15 Sham | No difference | No at all followup times | NC | NC
| 14 Laser
Krasheninnikoff 1994 ^586^ | 18 Sham | Sham | No at all followup times | -0.66 (-1.33 to 0.01) | NC
| 18 Laser
Vasseljen 1992 ^587^ | 15 Sham | Laser | No at all followup times | 1.41 (0.61 to 2.21) | 86%
| 15 Laser

a calculated by ECRI

b the direction of this effect size was chosen at random and is not to be interpreted as supporting one treatment group over the other

NC = could not be calculated from reported data

Figure 67. Effectiveness of laser therapy at treating pain

Figure 68. Effect sizes: laser treament on pain

Because an effect size could be calculated for only three of the studies, we did not perform a meta-analysis. None of the studies reported a statistically significant difference in pain outcomes between the two groups. However, all of the studies are small. Due to limitations in the reported data, we were only able to perform a power analysis for one of the studies. Our calculations show that the study by Vasseljen 1992 could have detected only an 86% or larger difference between the treatment groups. The other studies are of similar sizes. Thus, it is unlikely that they would have found a statistically significant difference even if the difference between groups were rather large. Therefore, these studies cannot be taken as proof that laser therapy provides no pain relief.

##### Function and Activites of Daily Living

None of the studies reported a patient-oriented measure of these outcomes.

##### Quality of Life

None of the studies reported on this outcome.

##### Morbidity and Complications

None of the studies reported any side effects or complications of laser therapy.

#### Conclusions

Seven studies that included a total of 320 patients were identified that evaluated low-level laser therapy for treating epicondylitis. All seven studies were double-blinded randomized controlled trials that compared laser therapy to sham laser therapy.

A meta-analysis of the results of the four studies that reported “success of treatment” did not find a statistically significant difference in outcome between laser and sham treated patients. The four studies that reported the effect of laser treatment on pain also did not find a statistically significant difference in outcome between laser and sham treated patients. However, we were unable to perform a meta-analysis of the outcome pain, and because all of these studies were small their individual results cannot be taken as definitive proof that laser therapy has no effect on the pain of epicondylitis. Only one study examined work status of patients after laser treatment. It failed to find a statistically significant effect of laser treatment on work status and did have sufficient statistical power to detect medium or large differences between groups. However, it is difficult to draw firm evidence-based conclusions from the results of a single study.

The results of all seven small randomized double-blinded controlled trials are consistent with the results of our meta-analysis, and suggest that if there is an effect of laser therapy on epicondylitis, it is not large.

### What are the relative benefits and harms of oral and topical anti-inflammatory drug therapy for persons with epicondylitis?

Non-steroidal anti-inflammatory drugs (NSAIDs) are a class of drugs that act to reduce inflammation. Most are also potent analgesics. NSAIDs used to treat epicondylitis can be taken orally or applied topically to the elbow joint. Common NSAIDs used to treat epicondylitis include diclofenac, salicylate, diflunisal, and naproxen.

Dimethylsufoxide (DMSO), although not an NSAID, has been included in this section. DMSO can be applied topically. It rapidly penetrates the skin and spreads throughout the body. It has been reported to have anti-inflammatory and analgesic properties.

The relevant literature consists of seven trials. One trial evaluated the use of DMSO as compared to placebo. Three trials compared the relative effectiveness of different types of NSAIDs. Three trials compared the effectiveness of different types of NSAIDs to placebo.

#### Internal validity

Seven randomized controlled trials that enrolled a total of 405 patients were included in this section of the report. The therapies used by the different trials are summarized in Table 235. Details of the designs of these trials are shown in Table 236. One double-blinded trial of 51 patients evaluated the use of topical DMSO as compared to placebo. One double-blinded trial of 206 patients compared oral diclofenac to placebo. Two double-blinded trials of 47 patients, one of which was a crossover trial, compared topical diclofenac to placebo. Two unblinded trials of 62 patients compared the effectiveness of oral diflunisal to oral naproxen. We do not consider lack of blinding in these two particular trials to be a serious design flaw. It is unlikely that knowledge of which type of NSAID was administered, by either the patients or the evaluating physician, would affect the results of the trial.

Title 235. Summary of the treatments evaluated

Study | Group 1 | Group 2
Burnham 1998 ^616^ | Topical diclofenac | Placebo
Schapira 1991 ^615^ | Topical diclofenac | Placebo
Demirtas 1998 ^614^ | Topical diclofenac | Topical salicylate
Labelle 1997 ^595^ | Oral diclofenac | Placebo
Adelaar 1987 ^596^ | Oral diflunisal | Oral naproxen
Stull 1986 ^597^ | Oral dilfunisal | Oral naproxen
Percy 1981 ^613^ | Topical DMSO | Placebo

Title 236. Internal validity

Study | Number of patients | Number of centers | Funded by a for-profit agency? | Study design | Prospective? | Blinding | %Attrition | Intent to treat analysis | Compliance
Demirtas 1998 ^614^ | 40 | 1 | NR | RCT | Yes | No | 0 | Yes | NR
Burnham 1998 ^616^ | 14 | 1 | NR | RCT | Yes | Double | 0 | Yes | NR
| | | | Xover
Labelle 1997 ^595^ | 206 | Multiple | Yes | RCT | Yes | Double | 0.49 | Yes | 49.5
Schapira 1991 ^615^ | 32 | 1 | Yes | CT | Yes | Double | 0 | Yes | NR
Adelaar 1987 ^596^ | 22 | 1 | NR | RCT | Yes | No | 18.2 | No | NR
Stull 1986 ^597^ | 40 | 1 | Yes | RCT | Yes | No | 5.0 | No | NR
Percy 1981 ^613^ | 51 | 1 | Yes | RCT | Yes | Double | 21.6 | No | NR

RCT = randomized controlled trial

Xover = crossover

CT = controlled trial

NR = not reported

Three of the trials did not analyze their data according to the intent-to-treat principle. Two of these studies (Adelaar 1987 and Percy 1981) had attrition rates over 15%. Ignoring attrition when analyzing the data can create a bias in the results. Where possible, we have tried to compensate for this by attempting to gauge the maximum possible effect of not following this principle. Thus, we assumed that all patients who were not followed until the end of the study received unsuccessful treatment. This is a conservative assumption. However, if statistical significance is obtained under this assumption, one can be more confident that the magnitude of this design weakness is not large enough to overturn the results of a statistically significant trial. We were able to compensate for not following the intent-to-treat principle for the trial by Adelaar 1987 for one outcome, but not for any other outcomes, and we were unable to compensate for not following the intent-to-treat principle for Percy 1981 or for Stull 1986. For the one outcome of Adelaar 1987 that we were able to compensate for, the conclusions of the trial did not change.

#### Generalizability

Characteristics of the patients are shown in Table 237. Studies of the epidemiology of epicondylitis (see the Introduction) have found that typical patients are in their mid-forties and are equally likely to be of either sex. All of the trials included patients that are similar to these characteristics except the trials by Stull 1986 and Schapira 1991 which did not report the mean age of their patient groups and the trial by Adelaar 1987 which had a mean age of 34.5 years (This is younger than the general population of patients with epicondylitis; see the epidemiology subsection of the introduction to this evidence report, as well as the answer to question two regarding epicondylitis).

Title 237. Generalizability: patient characteristics

Study | Number of patients | Mean age and range | % female | Duration of condition mean and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Did the study exclude patients with severe disease? | Did the study exclude patients with mild disease?
Burnham 1998 ^616^ | 14 | 42.5 | 42.8 | 8.3 (2–24) | NR | NR | NR | NR | NR | NR | NR | No | No
Demirtas 1998 ^614^ | 40 | 45.0 (25–61) | 65 | 5.0 (2–13) | NR | NR | NR | NR | NR | NR | NR | No | No
Labelle 1997 ^595^ | 206 | 43.7 | 59 | NR | | 0 | NR | 0 | 0 | NR | NR | No | No
Schapira 1991 ^615^ | 32 | (34–78) | 65.6 | NR | NR | NR | NR | NR | NR | NR | 0 | No | No
Adelaar 1987 ^596^ | 22 | 34.5 (20–49) | 54.5 | NR | NR | NR | 0 | NR | NR | 0 | 0 | No | No
Stull 1986 ^597^ | 40 | NR | 42.5 | NR | NR | NR | NR | NR | NR | NR | NR | No | No
Percy 1981 ^613^ | 51 | 47.9 (28–64) | 29.4 | NR | NR | NR | NR | NR | NR | NR | 0 | No | No

NR = not reported

The presence of various comorbidities associated with epicondylitis is incompletely reported in these studies. Some studies excluded patients with some comorbidities, indicated by a zero in Table 237 under that comorbidity. This somewhat limits the generalizability of these studies, as comborbidites may not be exclusion criteria for treatment with anti-inflammatories.

Only one of the trials reported information on the occupations of the patients (Table 238). Therefore, the extent to which the employment characteristics of these patients may be generalized to the overall epicondylitis population cannot be determined from the information available.

Title 238. Generalizability: patient occupations

Study | Number of patients | % Patients employed | % Patients on Workers' compensation | % Patients retired | % Patients homemakers | Reported occupations
Burnham 1998 ^616^ | 14 | NR | NR | NR | NR | NR
Demirtas 1998 ^614^ | 40 | NR | NR | NR | NR | NR
Labelle 1997 ^595^ | 206 | NR | NR | NR | NR | NR
Schapira 1991 ^615^ | 32 | NR | NR | NR | NR | NR
Adelaar 1987 ^596^ | 22 | NR | NR | NR | 9.1 | 13.6% blue-collar worker
| | | | | | 13.6% custodial worker
| | | | | | 9.1% student
| | | | | | 9.1% nurse
| | | | | | 9.1% clerical worker
| | | | | | 9.1% health care worker
| | | | | | 4.5% broker
| | | | | | 4.5% computer programmer
Stull 1986 ^597^ | 40 | NR | NR | NR | NR | NR
Percy 1981 ^613^ | 51 | NR | NR | NR | NR | NR

NR = not reported

#### Results

##### Success of Treatment-NSAIDs

Three studies reported on the success of treatment as rated by patients. The results of these trials are summarized in Table 239. Because there were two or fewer studies comparing the same NSAID treatments, no meta-analysis could be performed. The conclusions of the trials are summarized in Table 240. Two trials of a total of 51 patients reported on the relative success of treating with naproxen as compared to diflunisal. Both trials measured success by asking the patients to rate their symptoms after the course of drugs. Neither trial found a statistically significant difference between the treatment groups. However one study reported a slight advantage to taking naproxen, while the other study reported a slight advantage to taking diflunisal (Figure 69 and Figure 70). One trial of a total of 128 patients reported on the recurrence of symptoms three months after taking a course of diclofenac or placebo. There was no statistically significant difference in the rates of recurrence of symptoms between-treatment groups. The statistical power of these studies suggest that they could have detected, depending on the trial, a 17% or 22% difference between groups. Therefore, if there is a difference between any of the treatments, it is unlikely to be large.

Title 239. Results of the success of treatment with NSAIDs

Study | Number of patients | Success of treatment | Statistical significance of difference between groups
Labelle 1997 ^595^ | 64 Placebo | At 3 months: | Test NR
| 64 NSAIDs | Placebo: 27 patients still had symptoms | P = 0.52
| | NSAIDs: 23 patients still had symptoms
Adelaar 1987 ^596^ | 9 naproxen | At 0.5 months, patient-rated global outcome: | Exact chi-squared t test
| 9 diflunisal | Naproxen- 0 excellent, 7 improved, 2 no change, 0 worse | NS
| | Diflunisal- 0 excellent, 7improved, 1 no change, 1 worse
Stull 1986 ^597^ | 16 naproxen | At 0.5 months, patient-rated global outcome: | Pearson chi-squared
| 17 diflunisal | Naproxen- 1 excellent, 11 improved, 3 no change, 1 worse | P = 0.368
| | Diflunisal- 3 excellent, 13 improved, 1 no change, 0 worse

Title 240. Success of treating epicondylitis with NSAIDs

Study | Number of patients | Time of follow-up | Which treatment was more successful? | Was the difference statistically significant? | What is the minimal difference between groups the study had the power to detect? | Effect size d (95% CI)^a^
Labelle 1997 ^595^ | 64 oral diclofenac | 3 months | diclofenac | No | 17% | 1.44 (1.05 to 1.83)
| 64 placebo
Adelaar 1987 ^596^ | 9 oral diflunisal | 0.5 months | naproxen | No | 22% | 0.70 (-0.20 to 1.6)
| 9 oral naproxen
Stull 1986 ^597^ | 17 oral diflunisal | 0.5 months | diflunisal | No | 22% | -0.40 (-1.09 to 0.29)
| 16 oral naproxen

a calculated by ECRI

Figure 69. Success of treating epicondylitis with NSAIDs: naproxen vs. diflunisal

Figure 70. Effect sizes of diflunisal vs. naproxen

The trial by Demirtas 1998 compared topical salicylate treatments to topical diclofenac treatments. This trial did not report any patient-oriented outcomes, and for this reason we have not tabled any of its results. Demirtas 1998 reported that topical diclofenac was more effective at treating the symptoms of epicondylitis than was topical salicylate.

##### Success of treatment- DMSO

The trial by Percy 1981, which compared topical DMSO treatments to sham topical treatments, did not report any patient-oriented outcomes. For this reason, we have not tabled results or calculated effect sizes. However, this trial did report global outcome as rated by the treating physician. There was a trend towards the sham topical group being rated as having better outcomes than the topical DMSO group, but the difference was not statistically significant. There was insufficient information for us to calculate the statistical power of this study to detect differences between groups.

##### Work Status

One trial of 128 patients reported that there was no statistically significant difference in the number of work days missed due to epicondylitis between a group treated with diclofenac and a group treated with placebo. These data are shown in Table 241.

Title 241. Effect of NSAID treatment on work status

Study | N patients | Which treatment resulted in fewer sick days? | Was the difference significant? | Did the study have sufficient power? | Effect size d (95% CI)
Labelle 1997 ^595^ | 64 oral diclofenac | No difference | No | Could not calculate from reported information | Could not calculate from reported information
| 64 placebo | | t-test

##### Pain

Four trials reported on pain. These studies are shown in Table 242. One of the trials, including 28 patients, compared topical diclofenac to a placebo. Two studies of a total of 62 patients compared oral naproxen to oral diflunisal. One study of 128 patients compared oral diclofenac to placebo. Because there were two or fewer trials of each combination of NSAIDs, no meta-analysis could be performed. The results reported by the studies are summarized in Table 243. Diclofenac, either topically applied or taken orally, was found to relieve pain more effectively than placebo. There was a tendency for diflunisal to relieve pain more effectively than naproxen, but only the results of the Stull study were statistically significant.

Title 242. Results of the effect of NSAIDs on pain

Study | Number of patients | Pain | Statistical significance of difference between groups
Burnham 1998 ^616^ | 14 topical diclofenac | Patient-rated by VAS, mean (SD) | ANOVA
| 14 placebo | At time 0, NSAIDs = 3.5 (1.7) | NS at time 0
| | Placebo = 3.5 (1.7) | P = 0.007 at 1 week
| | At 1 week, NSAIDs = 2.1 (2.1)
| | Placebo = 3.6 (2.0)
Labelle 1997 ^595^ | 64 oral diclofenac | Patient-rated pain by VAS, mean (SD) | Student t test
| 64 placebo | At 1 month | p <0.005
| | NSAIDs = 29.9 (26.3)
| | Placebo = 16 (27.4)
Adelaar 1987 ^596^ | 9 diflunisal | Patient-rated pain, mean | Exact chi-squared t-test
| 9 naproxen | At time 0, diflunisal = 1.9 | NS
| | Naproxen = 2.1
| | At 2 weeks, diflunisal = 0.9
| | Naproxen = 1.1
Stull 1986 ^597^ | 16 diflunisal | Patient-rated pain relief | Pearson chi-squared
| 17 naproxen | At 2 weeks | P = 0.019
| | Diflunisal: 4 no pain, 9 mild pain, 3 moderate pain, 0 severe pain
| | Naproxen: 5 no pain, 8 mild pain, 3 moderate pain, 1 severe pain

Title 243. Effect of treatment with NSAIDs on pain related to epicondylitis

Study | Number of patients | Time of followup | Which treatment resulted in less pain? | Was the difference significant? | Minimal difference between groups the study had the power to detect | Effect size d (95% CI)^a^
Burnham 1998 ^616^ | 14 topical diclofenac | 1 week | Topical diclofenac | Yes | NA | 0.71 (-0.05 to -1.47)
| 14 placebo
Labelle 1997 ^595^ | 64 oral diclofenac | 1 month | Oral diclofenac | Yes | NA | 0.51 (0.16 to 0.87)
| 64 placebo
Adelaar 1987 ^596^ | 9 oral diflunisal | 2 weeks | Oral diflunisal | No | Cannot calculate from the reported data | Cannot calculate from the reported data
| 9 oral naproxen
Stull 1986 ^597^ | 17 oral diflunisal | 2 weeks | Oral diflunisal | Yes | NA | 0.02 (-0.66 to 0.71)
| 17 oral naproxen

a calculated by ECRI

##### Function

Three studies of 180 patients in total reported data relevant on patient function. The results of the studies are shown in Table 244. The results reported by the studies are summarized in Table 245. One study reported a trend, that did not reach statistical significance, towards fewer functional limitations when patients were treated with oral diclofenac as compared to placebo. The low statistical power of this study may have contributed to its failure to detect a statistically significant difference. Only large (>68.7%) differences could be detected. Two studies compared oral diflunisal to oral naproxen. One study reported no difference in functional limitations, while the other reported a statistically significant advantage in function after treatment with diflunisal.

Title 244. Results of function

Study | Number of patients | Functional assessment | Statistical significance of difference between groups
Labelle 1997 ^595^ | 64 Placebo | At one month, mean (SD) | Student t-test
| 64 Oral diclofenac | ADL: placebo -2.4 (2.8) | ADL, p = 0.52
| | Diclofenac- -3.3 (2.8) | VAS, p = 0.1
| | Arm function by VAS: placebo 21.8 (27.6)
| | Diclofenac 18.5 (29.1)
Adelaar 1987 ^596^ | 9 Oral diflunisal | Patient rated function mean | Exact chi-squared t-test
| 9 Oral naproxen | At time zero, dilfunisal 1.7 | NS
| | Naproxen 1.7
| | At 2 weeks, dilfunisal 0.4
| | Naproxen 0.4
Stull 1986 ^597^ | 17 Oral naproxen | Number of patients with self-reported functional limitations at 2 weeks | Chi-squared test^a^
| 17 Oral diflunisal | Naproxen = 11 | P = 0.039
| | Diflunisal = 5

a calculated by ECRI

ADL = activities of daily living

Title 245. Effect of NSAIDs on hand/arm function

Study | Number of patients | Which treatment resulted in fewer functional limitations? | Was the difference significant? | Minimal difference between groups the study had the power to detect | Effect size d (95% CI)^a^
Labelle 1997 ^595^ | 64 oral diclofenac | Oral diclofenac | No | 68.7% | ADL: 0.32 (-0.03 to 0.67)
| 64 placebo | | | | VAS: 0.12 (-0.23 to 0.46)
Adelaar 1987 ^596^ | 9 oral diflunisal | No difference | No difference | Cannot calculate from the reported data | Cannot calculate from the reported data
| 9 oral naproxen
Stull 1986 ^597^ | 17 oral diflunisal | Oral diflunisal | Yes | NA | 0.80 (0.00 to 1.59)
| 17 oral naproxen

a calculated by ECRI

##### Quality of life

None of the studies reported this outcome.

##### Morbidity and complications

Percy 1981 reported that topical DMSO irritated the skin at the site of application in 94% of the patients. ^613^ The irritation consisted of burning, itching, pain, congestion, edema, urticaria, vesicles, and dermatitis. Topical NSAIDs were reported to have few side effects except for occasional mild rashes. ^615,^ ^616^ Oral NSAIDs were reported to occasionally cause gastrointestinal problems such as nausea and vomiting. ^596,^ ^595^

#### Conclusions

Seven randomized controlled trials of a total of 405 patients evaluated the use of oral NSAIDs, topical NSAIDs, and topical DMSO as treatments for epicondylitis. Because there were two or fewer trials studying each combination of drugs, no meta-analysis could be performed. General trends reported by the trials can be described. However, because these trends are based on the results of at most two trials, they may be subject to over-interpretation. Confirmatory studies would increase our confidence in their results. In addition, the small size of most of these studies may have contributed to their failure to reach statistical significance.

One double-blinded randomized controlled trial of 51 patients reported that physicians believed that patients treated with placebo tended to have better outcomes than did patients treated with topical DMSO. However, this trend was not statistically significant.

Two randomized controlled trials of a total of 62 patients compared oral naproxen to oral diflunisal. One study reported no statistically significant difference in outcomes when comparing patients treated with the two different drugs, and did not find a consistent trend in favor of one drug. The other study reported that diflunisal treatment consistently resulted in better outcomes. For some outcomes (pain, function) the difference reached statistical significance.

One randomized controlled trial of 128 patients compared oral diclofenac to placebo. The group treated with diclofenac had statistically significantly less pain than the placebo group, but the NSAID treatment had no statistically significant effect on hand/arm function, number of days of missed work, or global outcome. Oral NSAIDs were reported to occasionally cause gastrointestinal side effects.

One double-blinded randomized controlled trial and one double blinded randomized crossover trial, of a total of 47 patients, compared topical diclofenac to placebo. One of the studies reported no differences between the two groups for any of the outcomes, while the other study reported the group treated with the NSAID may have had some statistically significant benefit from the treatment. One randomized controlled trial of 40 patients compared topical diclofenac to topical salicylate, and reported that diclofenac was more effective for treating epicondylitis. Topical NSAIDs were reported to occasionally cause mild skin rashes.

### What are the relative benefits and harms of injections of steroids, anesthetics, and other substances for persons with epicondylitis?

Injections of glucocorticoid steroids have been used to give long-lasting (days to weeks) relief from pain and inflammation at localized sites. Steroids used for this purpose include hydrocortisone, prednisone, prednisolone, methylprednisolone, triamcinolone, and betamethasone. Local anesthetics temporarily block sensory nerve conduction at the site of injection. Anesthetics used for this purpose include lidocaine, bupivacaine, lignocaine, and procaine. Injections of glucosamines are said to promote the healing of damaged joints, in particular, the damage associated with osteoarthritis.

The relevant literature consists of one trial that compared injections of glucosamines to placebo, one trial that compared the relative effectiveness of injections of different types of steroids, one trial that compared injections of anesthetics alone to injections of steroids plus anesthetics, one trial that compared injections of steroids alone to injections of steroids plus anesthetics, and two trials that compared the relative effectiveness of injections of different combinations of steroids and anesthetics.

#### Internal validity

The treatments evaluated by each of the studies are summarized in Table 246. Details of the study designs are shown in Table 247. One randomized double-blinded controlled study of 65 patients evaluated the effect of injections of glucosaminoglycan polysulfate as compared to placebo injections. One randomized double-blinded controlled trial of 58 patients compared a combination of methylprednisolone plus lidocaine to lidocaine alone. Two double-blinded randomized controlled trials of a total of 254 patients compared different combinations of steroids plus local anesthetics. One double-blinded controlled trial of 46 patients compared injections of hydocortisone to injections of methylprednisolone. If patients are not randomly assigned to groups, there may be important differences between these groups that could contribute to any observed differences in outcomes.

Title 246. Summary of the treatments

Study | Injections group 1 | Injections group 2
Akermark 1995 ^583^ | glucosamines | Placebo injection
Clarke 1975 ^605^ | hydrocortisone | methylprednisolone
Stahl 1997 ^601^ | methylprednisolone plus lidocaine | lidocaine
Solveborn 1995 ^602^ | triamcinolone plus lidocaine | triamcinolone plus bupivacaine
Price 1991 ^603^ | lignocaine plus triamcinolone or lignocaine plus hydrocortisone | lignocaine
Kivi 1982 ^604^ | methylprednisolone | lidocaine plus betamethasone

Title 247. Internal validity

Study | Number of patients | Number of centers | Funded by a for-profit agency? | Study design | Prospective? | Blinding | %Attrition | Intent to treat analysis | Compliance
Akermark 1995 ^583^ | 65 | Multiple | NR | RCT | Yes | Double | 7.7 | No | NA
Stahl 1997 ^601^ | 58 | 1 | No | RCT | Yes | Double | 0 | Yes | NA
Solveborn 1995 ^602^ | 109 | 1 | NR | RCT | Yes | Double | 42.2 | No | NA
Price 1991 ^603^ | 145 | 1 | Yes | RCT | Yes | Double | 0 | Yes | 51.7
Kivi 1982 ^604^ | 88 | 1 | NR | A-B | Yes | No | 13.6 | No | NA
Clarke 1975 ^605^ | 46 | 1 | Yes | CT | Yes | Double | 0 | Yes | NA

RCT = randomized controlled trial

CT = controlled trial

NA = not applicable

NR = not reported

One trial compared injections of a steroid to injections of a steroid plus a local anesthetic. This trial (Kivi 1982) was an unblinded A-B trial, in which the patients were given steroid injections for 6 months, and then were given a steroid plus an anesthetic for an additional 6 months. In addition, another group of patients was treated with injections of steroid plus anesthetic only, but the results from this group were pooled with that of the cross-over treatment group. Lack of blinding of the patient and the evaluating physician to the treatment type can alter measurements of treatment effect as discussed previously.

Three of the seven trials did not analyze their data according to the intent-to-treat principle. Ignoring attrition when analyzing the data can create a bias in the results. Where possible, we have tried to compensate for this by attempting to gauge the maximum possible effect of not following this principle. Thus, we assumed that all patients who were not followed until the end of the study received unsuccessful treatment. This is a conservative assumption. However, if statistical significance is obtained under this assumption, one can be more confident that the magnitude of this design weakness is not large enough to overturn the results of a statistically significant trial. Due to incomplete data reporting, we were unable to compensate for attrition in any of these trials.

#### Generalizability

Characteristics of the patients included in these studies are shown in Table 248. Studies of the epidemiology of epicondylitis (see the Introduction) have found that typical patients are in their mid-forties and are equally likely to be of either sex. All of the trials included patients similar to the typical epicondylitis patient except for the study by Stahl 1997, which included a group of patients who were predominantly male (76% male). The trial by Clarke 1975 did not report sufficient data on sex or age to be able to determine whether the results of the study are generalizable or not.

Title 248. Generalizability: patient characteristics

Study | Number of patients | Mean age and range | % female | Duration of condition mean and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Did the study exclude patients with severe disease? | Did the study exclude patients with mild disease?
Stahl 1997 ^601^ | 58 | 42 | 24.1 | 4.5 | NR | 0 | 0 | 0 | 0 | NR | NR | No | No
Akermark 1995 ^583^ | 65 | 44 (27–60) | 44.6 | 11 (3–36) | NR | NR | NR | NR | NR | 0 | NR | No | No
Solveborn 1995 ^602^ | 109 | 43.8 | NR | 8.2 | NR | NR | NR | NR | NR | NR | NR | No | No
Price 1991 ^603^ | 145 | 46 (19–65) | 48.9 | 6 (2–38) | NR | NR | NR | NR | NR | NR | NR | No | No
Kivi 1982 ^604^ | 88 | 43 (22–64) | 43.2 | NR | NR | NR | NR | NR | NR | NR | NR | No | No
Clarke 1975 ^605^ | 46 | NR | NR | NR | NR | 0 | NR | NR | NR | NR | NR | No | No

NR = not reported

The presence of various comorbidities associated with epicondylitis is incompletely reported in these studies. Some studies excluded patients with some comorbidities, indicated in Table 248 by a zero under that comorbidity. This somewhat limits the generalizability of these studies, as comorbidities may not be exclusion criteria for receiving injections of anethestics, steroids, or glucosamines.

Occupations and employment status of the patients are shown in Table 249. Only two of the studies reported any data on the occupations of their patient groups. Therefore, the extent to which the employment characteristics of these patients may be generalized to the overall epicondylitis population cannot be determined from the information available.

Title 249. Generalizability: patient occupations

Study | Number of patients | % Patients employed | % Patients on Workers' compensation | % Patients retired | % Patients homemakers | Reported occupations
Stahl 1997 ^601^ | 58 | NR | NR | NR | NR | 46.6% white collar workers
| | | | | | 29.3% manual laborers
Akermark 1995 ^583^ | 65 | NR | NR | NR | NR | NR
Solveborn 1995 ^602^ | 109 | NR | NR | NR | NR | NR
Price 1991 ^603^ | 145 | NR | NR | NR | NR | NR
Kivi 1982 ^604^ | 88 | NR | NR | NR | 18.1 | 18.1% heavy manual labor
| | | | | | 29.5% office work
Clarke 1975 ^605^ | 46 | NR | NR | NR | NR | NR

NR = not reported

#### Results

##### Glucosamines

One double-blinded randomized controlled trial of a total of 65 patients evaluated the effect of injections of glucosamines as compared to placebo injections on epicondylitis. The patients received weekly injections for five weeks. The study evaluated two different patient-oriented outcomes: success of the treatment, and pain when carrying out activities of daily living (ADL), as rated by the patient on a visual analog scale (VAS). The reported data are shown in Table 250 and summarized in Table 251. For both outcomes, glucosamine injections had a statistically significant effect 1 to 3 months after treatment, but by six months the differences between the two groups had become statistically insignificant.

Title 250. Results of treating epicondylitis with injections of glucosamines

Study | Outcome measurement | Treatment group | N patients | Time in months | Number of failures (%) | | Statistical test | P value
Akermark 1995 ^583^ | Number of treatment failures | GAGPS | 32 | 1 | 11 (34.4%) | | Mantel-Haenszel | 0.12
| | placebo | 28 | 1 | 17 (60.7%)
| | GAGPS | 32 | 1.5 | 4 (12.5%) | | | 0.011
| | placebo | 28 | 1.5 | 12 (42.9%)
| | GAGPS | 32 | 3 | 6 (18.8%) | | | 0.051
| | placebo | 28 | 3 | 12 (10.7%)
| | GAGPS | 32 | 6 | 9 (28.1%) | | | 0.22
| | placebo | 28 | 6 | 13 (46.4%)
| Pain-patient rated | Treatment group | N | Months | Mean | SD | Statistical test | P value
| | GAGPS | 32 | 0 | 62.8 | 15.4 | ANOVA | NS
| | placebo | 28 | 0 | 58.6 | 17.9
| | GAGPS | 32 | 1 | 44.1 | 19.9 | | 0.051
| | placebo | 28 | 1 | 48.4 | 20.8
| | GAGPS | 32 | 1.5 | 30.3 | 20.7 | | 0.0053
| | placebo | 28 | 1.5 | 40.5 | 25.6
| | GAGPS | 32 | 3 | 30.7 | 24.7 | | 0.021
| | placebo | 28 | 3 | 40.8 | 27.7
| | GAGPS | 32 | 6 | 33 | 25.3 | | 0.18
| | placebo | 28 | 6 | 37.3 | 30.1

a calculated by ECRI

Title 251. Results of treating epicondylitis with injections of glucosamines

Study | Number of patients | Outcome | Followup time | Which treatment was more effective? | Was the difference statistically significant? | Effect size d (95% CI)^a^
Akermark 1995 ^583^ | 32 GAGPS | Number of treatment failures | 1 month | GAGPs | No | 0.59 (0.01 to 1.17)
| 28 placebo | | 1.5 months | GAGPs | Yes | 0.90 (0.19 to 1.61)
| | | 3 months | GAGPs | No | 0.64 (0.00 to 1.28)
| | | 6 months | GAGPs | No | 0.43 (-0.16 to 1.02)
| 32 GAGPS | Patient rated pain | 1 month | GAGPs | No | 0.21 (-0.08 to 0.95)
| 28 placebo | | 1.5 months | GAGPs | Yes | 0.44 (-0.08 to 0.95)
| | | 3 months | GAGPs | Yes | 0.38 (-0.13 to 0.89)
| | | 6 months | GAGPs | No | 0.15 (-0.35 to 0.66)

GAGPS = glucosaminoglycan polysulfate

a calculated by ECRI

The study reported that 40.6% of the patients treated with glucosamines experienced pain at the site of the injection and 6.3% developed hematomas at the site of injection, compared to 17.9% of the placebo group who experienced pain, and 0% who developed hematomas at the site.

##### Different types of steroids

One double-blinded controlled trial of 46 patients compared injections of hydrocortisone to injections of methylprednisolone for treating epicondylitis. The data reported from this trial are shown in Table 252 and summarized in Table 253. The trial reported on whether the treatments were successful in treating the pain of epicondylitis, and on whether the pain recurred after six months. No statistically significant difference in either of these outcomes was found between treatment with the two different steroids. Injections of these steroids were reported to cause pain and bruising in a low percentage of patients. There was no statistically significant difference in the rates of such side effects between the two steroids. The study had the statisticaly power to detect fairly small (19–23%) differences between groups. This suggests that if there is a difference between groups, it is not large.

Title 252. Hydrocortisone compared to methylprednisone for treating epicondylitis

Study | Outcome measured | Number of patients | Number of patients considered to have a successful treatment | Statistical signficance of the difference between groups
Clarke 1975 ^605^ | A success was two pain-free visits; a failure was three injections without improvement over the course of 2 months | 48 methylprednisone | 21 methylprednisone | Test NR
| | 55 hydrocortisone | 20 hdrocortisone | NS
| Recurrence of symptoms by mailed questionnaire 6 months later | 24 methylprednisone | 16 methylprednisone | Test NR
| | 23 hydrocortisone | 10 hydrocortisone | NS

Title 253. Hydrocortisone compared to methylprednisone for treating epicondylitis

Study | Outcome measured | Number of patients | Which steroid was more effective? | Was the difference statistically significant? | Minimal difference between groups the study had the power to detect | Effect size d (95% CI)^a^
Clarke 1975 ^605^ | Success of treatment | 48 methylprednisone | methylprednisone | No | 19% | 0.17 (-0.27 to 0.61)
| | 55 hydrocortisone
| Recurrence of symptoms by mailed questionnaire | 24 methylprednisone | methylprednisone | No | 23% | 0.52 (-0.13 to 1.2)
| | 23 hydrocortisone

a calculated by ECRI

##### Glucocorticoids plus anesthetics compared to anesthetics

One randomized double-blinded controlled trial of 58 patients compared a combination of methylprednisolone plus lidocaine to lidocaine alone. In addition to the injections, all patients in this trial received oral NSAIDs, physical therapy, and were advised to rest the affected arm. The patients each received a single injection. The trial evaluated the pain the patients were experiencing as rated by the patient. The data are shown in Table 254 and summarized in Table 255. The patients treated with the steroid plus the anesthetic had statistically significantly less pain at 1.5 months, but not at longer followup times, than did patients treated only with an anesthetic.

Title 254. Results of treating epicondylitis with anesthetics compared to anesthetics plus glucocorticoids

Study | Outcome measured | Treatment group | N patients | Time in months | Outcome mean (SE) | Statistical significance of difference between groups
Stahl 1997 ^601^ | Patient-rated pain | Methylprednisolone plus lidocaine | 43 | 0 | 3.7 (0.26) | T test p >0.5
| | lidocaine | 30 | 0 | 3.5 (0.24)
| | Methylprednisolone plus lidocaine | 43 | 1.5 | 1.5 (0.3) | T test p <0.03
| | lidocaine | 30 | 1.5 | 2.2 (0.29)
| | Methylprednisolone plus lidocaine | 43 | 12 | 0.5 (0.18) | T test p >0.5
| | lidocaine | 30 | 12 | 0.6 (0.17)

Table 255. Effectiveness of treating epicondylitis with anesthetics compared to anesthetics plus glucocorticoids

Study | Number of patients | Time of followup | Which treatment was most effective? | Was the difference statisticallysignificant? | Effect size d (95% CI)^a^
Stahl 1997 ^601^ | 43 Methylprednisolone plus lidocaine | 0 months | No difference | No | -0.13 (-0.60 to 0.33)
| 30 lidocaine | 1.5 months | Methylprednisolone plus lidocaine | Yes | 0.39 (-0.08 to 0.86)
| | 12 months | Methylprednisolone plus lidocaine | No | 0.09 (-0.37 to 0.56)

a calculated by ECRI

##### Glucocorticoids plus anesthetics compared to glucocorticoids

One A-B trial compared injections of lidocaine plus betamethasone to injections of methylprednisolone. The data reported by the trial are shown in Table 256 and summarized in Table 257. The trial reported the success of the treatment as rated by the patient (global outcome). Steroids plus anesthetics were found to be more effective than steroids alone, but the difference did not reach statistical significance. The study was large enough to detect fairly small differences in outcomes between the groups. The trial also reported the number of work-days the patients missed due to their epicondylitis. There was insufficient data reported about work status to determine if the difference was statistically significant.

Title 256. Results of trials comparing steroids to steroids plus anesthetics as a treatment for epicondylitis

Study | Outcome measured | Number of patients | Reported data | Statistical signficance of the difference between groups
Kivi 1982 ^604^ | Success of treatment, at 12 months | 47 Betamethasone and lidocaine | Steroid plus lidocaine: 36 excellent, 7 good, 3 same, 1 worse | Chi-squared test p = 0.057
| | 21 methylprednisolone | Steroid: 16 excellent, 3 good, 2 same, 0 worse
| Days off work, at 12 months | 47 Betamethasone plus lidocaine | Steroid plus lidocaine: Mean 16.4 days off | Cannot calculated from the reported data
| | 21 Methylprednisone | Steroid: Mean 12.2 days off

NC = could not calculate from the reported data

Title 257. Effectiveness of steroids compared to steroids plus anesthetics as a treatment for epicondylitis

Study | Outcome measured | Number of patients | Which treatment was most effective? | Was the difference statistically significant? | What was the minimal difference between groups the study had the power to detect? | Effect size d (95% CI)^a^
Kivi 1982 ^604^ | Success of treatment | 47 Betamethasone plus lidocaine | Betamethasone plus lidocaine | No | 8% | 0.13 (-0.39 to 0.64)
| | 21 Methylprednisone
| Days off work | 47 Betamethasone plus lidocaine | Methylprednisone | Not reported; cannot determine from reported data | Cannot calculated from the reported data | Cannot calculate from the reported data
| | 21 Methylprednisone

a calculated by ECRI

##### Different combinations of glucocorticoids plus anesthetics

Two double-blinded randomized controlled trials of a total of 254 patients compared different combinations of steroids plus local anesthetics as a treatment for epicondylitis. One of the trials compared triamcinolone plus lidocaine to triamcinolone plus bupivacaine (Solveborn 1995). The other trial compared lignocaine alone to lignocaine plus hydrocortisone, lignocaine plus 10 mg of triamcinolone, and lignocaine plus 20 mg of triamcinolone (Price 1991). The trial by Solveborne 1995 did not report any data or statistics, but reported only that patients receiving bupivacaine had a better outcome two weeks after the injection than did patients receiving the lidocaine. The data reported by Price 1991 are shown in Table 258 and summarized in Table 259. Price 1991 reported that at one month, the group treated only with lignocaine had significantly less improvement than did the other groups, but that this difference was not statistically significant by 6 months. Price 1991 reported that some of the patients who received injections of triamcinolone experienced skin atrophy at the site of injection.

Table 258. Results of the study by Price 1991: patient-reported pain on VAS

Study | Treatment group | N patients | Months | Outcome mean (95% CI) | Effect size d (95% CI)^a^
Price 1991 ^603^ | Ligno | 29 | 1 | 46 (37–55)
| Ligno +hydro | 29 | 1 | 28 (18–38) | 3.66 (2.82 to 4.50)
| Ligno + triam | 29 | 1 | 17 (10–25) | 6.78 (5.44 to 8.12)
| Ligno + 10 triam | 23 | 1 | 27 (18–37) | 3.99 (3.05 to 4.93)
| Ligno + 20 triam | 28 | 1 | 28 (19–37) | 3.86 (2.98 to 4.74)
| Ligno | 27 | 2 | 35 (26–43)
| Ligno +hydro | 27 | 2 | 30 (19–41) | 0.99 (0.42 to 1.55)
| Ligno + triam | 27 | 2 | 20 (10–30) | 3.13 (2.34 to 3.93)
| Ligno + 10 triam | 22 | 2 | 29 (17–40) | 1.16 (0.55 to 1.77)
| Ligno + 20 triam | 24 | 2 | 22 (14–31) | 2.98 (2.18 to 3.77)
| Ligno | 25 | 6 | 12 (8–17)
| Ligno +hydro | 26 | 6 | 24 (14–35) | -2.83 (-3.60 to -2.05)
| Ligno + triam | 27 | 6 | 18 (7–28) | -1.40 (-2.01 to -0.80)
| Ligno + 10 triam | 22 | 6 | 35 (21–48) | -4.52 (-5.60 to -3.44)
| Ligno + 20 triam | 27 | 6 | 33 (22–45) | -4.55 (-5.58 to -3.52)

a calculated by ECRI, using lignocaine as the control group in each case. A positive effect size indicates the treatment group had less pain than the control group

Table 259. Summary of the study by Price 1991

Study | Number of patients | Time of followup | Which treatment was more successful? | Was the difference statistically significant? | Relevant effect size d (95% CI)
Price 1991 ^603^ | 29 Ligno | 1 month | Lignocaine plus triamcinolone | Yes | 6.78 (5.44 to 8.12)
| 29 Ligno +hydro
| 30 Ligno + triam
| 27 Ligno + 10 triam
| 29 Ligno + 20 triam
| | 2 months | Lignocaine plus triamcinolone | No | 3.13 (2.34 to 3.93)
| | 6 months | Lignocaine | No | NA

Ligno = lignocaine

Hydro = hydrocortisone

Triam = triamcinolone

#### Conclusions

One randomized double-blinded study reported that injections of glucosamines are effective in treating the symptoms of epicondylitis in the short term (less than 6 months) as measured by global outcome and patient-reported pain. However, injections of glucosamines were found to have a high rate of side effects- 40% of patients experienced pain at the site of injection, and 6% developed hematomas at the site of injection.

One randomized double-blinded study reported that injections of methylprednisolone plus lidocaine were statistically significantly more effective at treating pain than were injections of lidocaine.

One randomized double-blinded study reported that injections of lignocaine plus triamcinolone were statistically significantly more effective at treating pain than were injections of lignocaine or injections of lignocaine plus hydrocortisone.

One randomized double-blinded study reported that injections of triamcinolone plus bupivacaine were more successful at treating epicondylitis than were injections of triamcinolone plus lidocaine.

One study reported a trend towards more successful treatment of epicondylitis after injections of methylprednisolone than after injections of hydrocortisone. However, this study was of less than optimal design, which makes it problematic to come to a definitive evidence-based conclusion on the basis of its results.

One study reported no difference in rates of successful treatment or number of work-days missed after treatment with injections of methylprednisolone as compared to injections of betamethasone plus lidocaine. This study had sufficient statistical power to have detected relatively small differences between-treatment groups. However, design flaws in this study make it problematic to come to a definitive evidence-based conclusion on the basis of its results.

### What are the relative benefits and harms of ultrasound and phonophoresis therapy for persons with epicondylitis?

Ultrasound has been used as a therapy for the treatment of musculoskeletal pain. Ultrasound has been said to increase blood flow, membrane permeability, and to alter connective tissues and nerve conduction speed. ^622,^ ^623^ Phonophoresis refers to using ultrasound to drive a drug suspended in a coupling medium into the tissues. ^623^

The relevant literature on this topic consists of three trials comparing ultrasound to sham or no treatment, and two trials comparing ultrasound to phonophoresis of hydrocortisone.

#### Internal validity

Two studies of 82 patients in total compared ultrasound alone to phonophoresis of hydrocortisone. Three studies of a total of 220 patients compared ultrasound treatment to sham or no treatment. Details of the study design are shown in Table 260. All of the studies were randomized controlled trials. All except for the study by Holdsworth 1993 were double-blinded; the study by Holdsworth 1993 blinded only the patients to the treatment administered. Lack of blinding of the evaluating physician is a design weakness. If the evaluating physician is aware of the treatment given, it is possible that he/she may unconsciously bias the patient's reponses by giving leading instructions. ^474^

Table 260. Internal validity

Study | Number of patients | Number of centers | Funded by a for-profit agency? | Study design | Prospective? | Blinding | %Attrition | Intent to treat analysis | Compliance
Holdsworth 1993 ^620^ | 42 | 1 | NR | RCT | Yes | Patients | 14.3 | No | NA
Haker 1991 ^619^ | 45 | 1 | NR | RCT | Yes | Double | 28.9 | No | NA
Stratford 1989 ^621^ | 40 | 1 | No | RCT | Yes | Double | 0 | Yes | NA
Lundeberg 1988 ^617^ | 99 | 1 | NR | RCT | Yes | Double | 0 | Yes | NR
Binder 1985 ^618^ | 76 | 1 | NR | RCT | Yes | Double | 0 | Yes | NA

RCT = randomized controlled trial

NA = not applicable

NR = not reported

Two of the studies did not analyze their data according to the intent-to-treat principle. Ignoring attrition when analyzing the data can create a bias in the results. However, we were unable to compensate for the attrition from these two studies due to incomplete data reporting.

#### Generalizability

Details of the patient groups are shown in Table 261. Studies of the epidemiology of epicondylitis (see the Introduction) have found that the typical patient with epicondylitis is in the mid-forties and equally likely to be male or female. All of the patient groups enrolled in these trials are similar in mean age and gender composition to the typical patients.

Table 261. Generalizability: patient characteristics

Study | Number of patients | Mean age and range | % female | Duration of condition mean and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Did the study exclude patients with severe disease? | Did the study exclude patients with mild disease?
Holdsworth 1993 ^620^ | 42 | 45.3 (22–62) | 35.7 | NR | NR | 0 | 0 | 0 | 0 | NR | NR | No | No
Haker 1991 ^619^ | 45 | 49.3 (34–67) | 44.4 | 8.5 (1–60) | NR | NR | NR | NR | NR | NR | NR | No | No
Stratford 1989 ^621^ | 40 | 43.3 | 50.0 | 4.3 | NR | NR | NR | 0 | NR | NR | NR | No | No
Lundeberg 1988 ^617^ | 99 | 38 (21–68) | 43.4 | NR | NR | 0 | NR | 0 | 0 | NR | NR | No | No
Binder 1985 ^618^ | 76 | 43.3 (29–65) | 63.2 | 4.6 (1–12) | NR | 0 | NR | 0 | 0 | NR | NR | No | No

NR = not reported

The presence of various comorbidities associated with epicondylitis is incompletely reported in these studies. Some studies excluded patients with some comorbidities, indicated in Table 261 by a zero under that comorbidity. This limits the generalizability of these studies, as combordities are not usually an exclusion criterion for treatment with ultrasound or phonophoresis.

None of the studies reported any information on patient employment characteristics. Therefore, the extent to which the employment characteristics of these patients may be generalized to the overall epicondylitis population cannot be determined from the information available.

#### Results

##### Success of Treatment

Two studies of a total of 59 patients measured the success of ultrasound treatment. One of these studies compared ultrasound to phonophoresis, while the other compared ultrasound to sham ultrasound. These data are shown in Table 262 and summarized in Table 263. One study measured treatment by asking the patients to rate their condition as excellent, improved, or the same/worse, while the other study asked the patients to rate their condition on a 10 cm visual analog scale (VAS). The studies reported no statistically significant difference between ultrasound treatment and sham treatment, and no statistically significant difference between ultrasound and phonophoresis treatment. Although the Holdsworth 1993 study was so small (n=16 patients) it could only have detected a 82.5% or larger difference, the Haker 1991 study could have detected a 20% or greater difference. Hence, this latter study suggests that that, if there is an effect of ultrasound on patient-rated treatment success, it is not large.

Table 262. Results of treating epicondylitis with ultrasound

Study | Number of patients | Reported outcome | Statistical significance of difference between groups
Holdsworth 1993 ^620^ | 7 Phonophoresis | At 1.5 months, mean (SE) patient-rated global outcome on VAS | ANOVA
| 9 Ultrasound | Phonophoresis: 49.6 (12.4) | p >0.05
| | Ultrasound: 63 (12.2)
Haker 1991 ^619^ | 21 Ultrasound | At 3 months, patient-rated global outcome | Mann-Whitney U-test
| 22 Sham | Ultrasound: 8 excellent, 8 improved, 5 same or worse | NS
| | Sham: 10 excellent, 7 improved, 5 same or worse

Table 263. Success of treating epicondylitis with ultrasound

Study | Number of patients | Time of followup | Which treatment was more successful? | Was the difference statistically significant? | Minimal difference between groups the study had the power to detect | Effect size d (95% CI)
Holdsworth 1993 ^620^ | 7 phonophoresis | 1.5 months | Ultrasound | No | 82.5% | 0.33
| 9 ultrasound | | | | | (-0.55 to 1.20)
Haker 1991 ^619^ | 22 sham | 3 months | Sham | No | 20% | -0.19
| 21 ultrasound | | | | | (-0.79 to 0.41)

##### Work Status

None of the studies reported data applicable to this outcome.

##### Pain

Three studies of a total of 161 patients reported pain after treating epicondylitis with ultrasound. One of these studies compared ultrasound alone to phonophoresis, while the other two studies compared ultrasound to sham or no treatment. The data from these studies are shown in Table 264 and summarized in Table 265. The study comparing ultrasound to phonophoresis reported no statistically significant difference in pain between the two treatment groups. It was, however, too small to detect differences between the treatment groups of less than 50%.

Table 264. Effect of ultrasound treatment on pain related to epicondylitis

Study | Number of patients | Reported outcome: patient-reported pain on VAS | Statistical signficance of difference between groups
Stratford 1989 ^621^ | 10 phonophoresis | At 2.5 months, mean (SD) | ANCOVA
| 9 ultrasound | Phonophoresis: 21.8 (30.4) | P = 0.87
| | Ultrasound: :28.3 (17)
Lundeberg 1988 ^617^ | 33 ultrasound | At 3 months, mean (SD) | Wilcoxon's rank sum test
| 33 No treatment | Ultrasound 2.8 (0.3) | NS
| 33 sham | No treatment 2.1 (0.5)
| | Sham 2.4 (0.3)
Binder 1985 ^618^ | 38 Ultrasound | 0.5 months, mean | Wilcoxon's rank sum test
| 38 No treatment | Utlrasound 0.75 No treatment 2.2 | At 1 month p <0.01
| | 1 months, mean | At 2 month p <0.005
| | Ultrasound 3.4 No treatment 1.5
| | 2 months, mean
| | Ultrasound 4 No treatment 1.7

Table 265. Pain experienced by patients treated with ultrasound

Study | Number of patients | Time of followup | Which treatment resulted in less pain? | Was the difference statistically significant? | Minimal difference between groups the study had the power to detect | Effect size d (95% CI)^a^
Stratford 1989 ^621^ | 10 phonophoresis | 2.5 months | Phonophoresis | No | 54.3% | 0.26 (-0.34 to 0.86)
| 9 ultrasound
Lundeberg 1988 ^617^ | 33 ultrasound | 3 months | Ultrasound | No | Could not calculate from the reported data | Vs. no: 1.68 (1.12 to 2.24)
| 33 No treatment | | | | | Vs. sham: 1.32 (0.79 to 1.85)
| 33 sham
Binder 1985 ^618^ | 38 Ultrasound | 1 and 2 months | Ultrasound | Yes at both times of followup | NA | 1 month: 0.60 (0.14 to 1.06)
| 38 No treatment | | | | | 2 months: 0.66 (0.20 to 1.12)

a calculated by ECRI

One of the studies comparing ultrasound to sham or no treatment reported no statistically significant difference in pain between-treatment groups, while the other study reported a significant decrease in pain experienced by the group treated with ultrasound as compared to the untreated group. However, the effect sizes we calculated for both of these studies suggested a statistically significant effect of ultrasound as compared to no or sham treatment.

##### Function and Activities

One study reported data on patient-reported function and activities of daily living. This study compared phonophoresis to ultrasound, and measured pain upon performing activities of daily living, function as rated by VAS, and the ability to perform recreational activities. No statistically significant difference for any of the outcomes was reported; however, the study could have detected only a 73.6% or larger difference between the groups, so it could have missed clinically important effects. The reported results are shown in Table 266 and summarized in Table 267.

Table 266. Effect of ultrasound on hand/arm function

Study | Number of patients | Patient-reported hand/arm function- VAS | Statistical signficance of the difference between groups
Stratford 1989 ^621^ | 10 phonophoresis | At 2.5 months, mean (SD) | ANCOVA
| 9 ultrasound | Phonophoresis 78.8 (23.7) | p >0.05
| | Ultrasound 66 (25)

Table 267. Function after treatment with ultrasound

Study | Number of patients | Followup time | Which treatment resulted in more effective function? | Was the difference statistically significant? | Minimal difference between groups the study had the power to detect | Effect size d (95% CI)^a^
Stratford 1989 ^621^ | 10 phonophoresis | 2.5 months | phonophoresis | No | 73.6% | 0.50 (-0.39 to 1.39)
| 9 ultrasound

a : calculated by ECRI

##### Quality of Life

None of the included studies reported on this outcome.

##### Morbidity and Complications

None of the included studies reported data applicable to this outcome.

#### Conclusions

Two randomized controlled trials of 82 patients in total compared ultrasound treatment to phonophoresis of hydrocortisone as a therapy for epicondylitis. Neither study reported statistically significant differences between-treatment groups for any of the outcomes. When interpreting these results, it is important to keep in mind that both studies may have been too small to be able to detect clinically relevant differences between-treatment groups.

Three randomized controlled trials of 220 patients in total compared ultrasound treatment to sham ultrasound treatment or no treatment as a therapy for epicondylitis. All three of the studies reported a trend towards better outcomes in the groups treated with ultrasound. However, this difference reached statistical significance in only one of the studies. Although low statistical power may explain the negative results of the two “nonsignificant” studies, further research is required to demonstrate this.

### What are the relative benefits and harms of bracing, physiotherapy, and manipulation as therapy for persons with epicondylitis?

Splints, braces, and other supportive devices to be worn around the elbow are advocated by some as a therapy for epicondylitis. The devices are said to reduce the stresses to the forearm extensor muscle origin by providing a counterforce brace and thus allow the area to rest and heal while not interfering with normal activity. ^78,^ ^624,^ ^625^ Most braces used to treat epicondylitis consist of a band that straps tightly around the forearm just below the elbow. Physiotherapy for the treatment of epicondylitis refers to programs that generally aim gradually to stretch and strengthen the tendons and muscles of the forearm, in hopes that this will allow the affected area to resist stresses more effectively. ^626^ Manipulation refers to forced movements of the affected limb. Practitioners claim that manipulation returns out-of-place body parts to their original sites and releases adhesions. ^75^

The relevant literature that addresses this question consists of one trial that compared manipulation to no treatment, and four trials that evaluated the relative effectiveness of different types of braces and physiotherapy.

#### Internal validity

Details of the designs of the trials are shown in Table 268. We identified one randomized double-blinded crossover study of 15 patients that evaluated a manipulative technique (contralateral glide) as compared to a placebo manipulation and no manipulation.

Table 268. Internal validity

Study | Number of patients | Number of centers | Funded by a for-profit agency? | Study design | Prospective? | Blinding | %Attrition | Intent to treat analysis | Compliance
Wuori 1998 ^577^ | 50 | 1 | No | RCT | Yes | No | 0 | Yes | NA
| | | | Xover
Solveborn 1997 ^579^ | 185 | 1 | NR | CT | Yes | No | 29.2 | No | 88.1
Vicenzino 1996 ^592^ | 15 | 1 | NR | RCT | Yes | Double | 0 | Yes | NA
| | | | Xover
Clements 1993 ^580^ | 19 | 1 | NR | CT | Yes | No | 15.8 | No | 52.6
Forbes 1990 ^578^ | 19 | 1 | Yes | Xover | Yes | No | 0 | Yes | NA

NR = not reported

RCT = randomized controlled trial

CT = controlled trial

Xover = crossover

NA = not applicable

We included four studies that enrolled a total of 273 patients that evaluated braces as therapy for epicondylitis. Two crossover trials and one controlled trial compared braces to either a placebo brace or no treatment. A controlled trial of 185 patients compared a brace to physiotherapy. None of these four studies were blinded. Lack of blinding of the patient to the type of treatment, particularly when using subjective outcome measures, can alter measurements of treatment effect because patients might unconsciously rate their condition differently in order to please the clinician. ^474^ Lack of blinding of the evaluating physician may result in the physcian unconsciously biasing the patient's responses by giving leading instructions. ^474^

Compliance was low in the two longer term trials. In the trial by Clements 1993, only 52.6% of the patients followed the prescribed regimen. In the trial by Solveborn 1997, compliance was initially high (88.1%), but at the longest followup time (3 months) compliance had dropped to 55%.

Statistical analysis was not intent-to-treat in the trials by Solveborn 1997 or Clements 1993. Both of these trials had attrition rates greater than 15%. Ignoring attrition when analyzing the data can create a bias in the results. Where possible, we have tried to compensate for this by attempting to gauge the maximum possible effect of not following this principle. Thus, we assumed that all patients who were not followed until the end of the study received unsuccessful treatment. This is a conservative assumption. However, if statistical significance is obtained under this assumption, one can be more confident that the magnitude of this design weakness is not large enough to overturn the results of a statistically significant trial. We were not able to compensate for attrition in the trial Clements 1993 due to incomplete data reporting, but we were able to compensate for attrition in the trial by Solveborn 1997. Compensating for attrition did not change the conclusions of this trial.

#### Generalizability

Details of the patient characteristics are shown in Table 269. Studies of the epidemiology of epicondylitis (see the Introduction) have found that the typical patient is in the mid-forties and is equally likely to be male or female. Forbes 1990 did not report the ages of the patients. The mean ages of the patient groups in the other studies are all in the mid-forties. Solveborn 1997 did not report the sexes of the patients. The trial by Clements 1993 was predominantly male (73.7%), and the trial by Forbes 1990 was predominantly female (84.2%). It is possible these patient groups may be composed of atypical patients.

Table 269. Generalizability: patient characteristics

Study | Number of patients | Mean age and range | % female | Duration of condition mean and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Did the study exclude patients with severe disease? | Did the study exclude patients with mild disease?
Wuori 1998 ^577^ | 50 | 44.5 | 46 | 7.5 | NR | NR | NR | 0 | NR | NR | NR | No | No
Solveborn 1997 ^579^ | 185 | 43.5 (19–71) | NR | 12.3 (0–72) | NR | NR | NR | NR | NR | NR | NR | No | No
Vicenzino 1996 ^592^ | 15 | 44 (22–62) | 53.3 | 8 (2–36) | NR | NR | NR | NR | NR | NR | NR | No | No
Clements 1993 ^580^ | 19 | 42.4 (33–54) | 26.3 | NR | NR | 0 | 0 | NR | NR | NR | NR | No | No
Forbes 1990 ^578^ | 19 | NR | 84.2 | NR | NR | NR | NR | NR | NR | NR | NR | No | No

NR = not reported

The presence of various comorbidities associated with epicondylitis is incompletely reported in these studies. Some studies excluded patients with some comorbidities, indicated in Table 269 by a zero under that comborbidity. This somewhat limits the generalizability of these studies, as comorbidities are not exclusion criteria for the treatments evaluated in this section.

The occupations and employment status of the patients are shown in Table 270. Only one study reported any information about the employment status of its patients. Therefore, the extent to which the employment characteristics of these patients may be generalized to the overall epicondylitis patient population cannot be determined from the information available.

Table 270. Generalizability: patient occupations

Study | Number of patients | % Patients employed | % Patients on Workers' compensation | % Patients retired | % Patients homemakers | Reported occupations
Wuori 1998 ^577^ | 50 | NR | NR | NR | NR | NR
Solveborn 1997 ^579^ | 185 | NR | NR | NR | NR | NR
Vicenzino 1996 ^592^ | 15 | NR | NR | NR | NR | NR
Clements 1993 ^580^ | 19 | NR | NR | NR | 10.5 | 21.0% food services
| | | | | | 15.7% mechanic/repairman
| | | | | | 5.2% nurse
| | | | | | 5.2% librarian
| | | | | | 5.2% engineer
| | | | | | 5.2% office worker
Forbes 1990 ^578^ | 19 | NR | NR | NR | NR | NR

NR = not reported

#### Results

##### Manipulation

One randomized controlled crossover trial of 15 patients compared a contralateral glide manipulation technique to no manipulation and to a placebo manipulation (Table 271). Patient-reported pain (VAS) and function (activities of daily living; ADL) were measured before treatment, and 24 hours after each treatment. Outcomes after each treatment were not directly compared. Instead, pre-post outcome measurements were compared. There were no statistically significant changes in these patient-oriented outcomes for any of the treatments. Statistical significance was defined as p <0.05, but the test used was not described. The reported data were insufficient for effect size of power calculations.

Table 271. Effect of treatment with manipulation on epicondylitis

Study | Number of patients | Which treatment was more effective? | Was the difference statistically significant? | Was the effect size statistically significant? | Did the study have sufficient power to detect the observed difference?
Vicenzino 1996 ^592^ | 15 manipulation | No difference | No | Could not calculate from the reported data | Could not calculate from reported data
| 15 placebo

##### Braces and physiotherapy

##### Success of Treatment

One trial that compared wearing a brace for several months to receiving regular physiotherapy reported on this outcome. The data are shown in Table 272 and summarized in Table 273. For both followup times, physiotherapy was statistically significantly more successful than was bracing.

Table 272. Results of treating epicondylitis with bracing or physiotherapy

Study | Number of patients | N patients treated successfully (%) | Statistical significance of difference between groups
Solveborn 1997 ^579^ | 91 Bracing | At 1 month, Bracing 56 (61.5%) | Chi-squared test
| 85 Physiotherapy | Physiotherapy 80 (95%) | At 1 month, p <0.0001
| | At 3 months, Bracing 23 (25.3%) | At 3 months, p <0.01
| | Physiotherapy 38 (44.7%)

Table 273. Success of treating epicondylitis with bracing or physiotherapy

Study | Number of patients | Time of followup | Which treatment was more successful? | Was the difference statistically significant? | Effect size d (95% CI)^a^
Solveborn 1997 ^579^ | 91 Bracing | 1 and 3 months | Physiotherapy | Yes | At 1 month:
| 84 Physiotherapy | | | | -1.39 (-1.99 to -0.79)
| | | | | At 3 months:
| | | | | -0.44 (-0.79 to -0.08)

a calculated by ECRI

##### Work Status

The trial by Solveborn 1997 reported the number of days patients were unable to work due to their condition. These data are shown in Table 274 and summarized in Table 275. At three months and nine months of followup, the group treated with physiotherapy had statistically significantly fewer days of not working than did the group treated with bracing.

Table 274. Results of treating epicondylitis with bracing or physiotherapy on work status

Study | Number of patients | Mean number of days off work | Statistical significance of difference between groups
Solveborn 1997 ^579^ | 91 Bracing | At 1 month: bracing 14 | Chi-squared test
| 94 Physiotherapy | Physiotherapy 14 | At 1 month NS
| | At 3 months: | At 3 months p <0.01
| | Bracing 20 | At 9 months p <0.01
| | Physiotherapy 13
| | At 9 months:
| | Bracing 24
| | Physiotherapy 14

Table 275. Effect of treating epicondylitis with bracing or physiotherapy on work status

Study | Number of patients | Which treatment resulted in fewer days off work? | Was the difference statistically significant? | Effect size
Solveborn 1997 ^579^ | 91 Bracing | Physiotherapy | No at 1 month | Could not calculate from the reported data
| 94 Physiotherapy | | Yes at 3 and 9 months

##### Pain

The crossover trial by Wuori 1998 asked the patients to rate their pain before, during, and after tests of grip strength while wearing various types of braces. There were no statistically significant differences in pain reported from tests wearing the different types of braces (data shown in Table 276 and summarized in Table 277). However, the trial by Wuori 1998 had insufficient power to detect differences between the groups of less than 64%.

Table 276. Results of treatment with bracing on pain related to epicondylitis

Study | Number of patients | Pain reported by patients | Statistical significance of difference between groups
Wuori 1998 ^577^ | 50 Count'Rforce brace | Mean (SD) | ANOVA
| 50 Airprene brace | Before other tests | Before other tests NS
| 50 Placebo brace | CountRforce 1.3 (1.7) Airprene1.4 (1.9) Placebo 1.4 (1.8) | During other tests NS
| | During other tests | After other tests NS
| | CountRforce 3.4 (2.1) Airprene 3.3 (2.3) Placebo 3.4 (2.4)
| | After other tests
| | CountRforce1.5 (1.7) Airprene 1.7 (2.1) Placebo 1.4 (1.8)
Solveborn 1997 ^579^ | 91 Bracing | 1 month | Paired t-test
| 94 Physiotherapy | Bracing 39 (22) | 1 month p <0.0001
| | Physiotherapy 27 (21) | 3 months p <0.0001
| | 3 months | 9 months p <0.045
| | Bracing 32 (21)
| | Physiotherapy 20 (22)
| | 9 months
| | Bracing 19 (19)
| | Physiotherapy 13 (20)

Table 277. Effect of treatment with bracing on pain related to epicondylitis

Study | Number of patients | Which treatment resulted in less pain? | Was the difference statistically significant? | Minimal difference between groups the study had the power to detect | Effect size d (95% CI)^a^
Wuori 1998 ^577^ | 50 Count'Rforce brace | Airprene brace | No | 64% | Before other tests:
| 50 Airprene brace | | | | CountRforce -0.06 (-0.45 to 0.34)
| 50 Placebo brace | | | | Airprene 0.00 (-0.39 to 0.39)
| | | | | During other tests:
| | | | | CountRforce 0.00 (-0.39 to 0.39)
| | | | | Airprene -0.04 (-0.43 to 0.35)
| | | | | After other tests:
| | | | | CountRforce 0.06 (-0.34 to 0.35)
| | | | | Airprene 0.15 (-0.24 to 0.54)
Clements 1993 ^580^ | 10 bracing plus physiotherapy | Bracing plus physiotherapy | Yes | NA | Could not calculate from the reported data
| 9 physiotherapy | | t-test
Solveborn 1997 ^579^ | 91 Bracing | Physiotherapy | Yes | NA | 1 month:056 (0.26 to 0.85)
| 94 Physiotherapy | | | | 3 months: 0.56
| | | | | (0.26 to 0.85)
| | | | | 9 months: 0.31
| | | | | (0.02 to 0.60)

a calculated by ECRI

The trial by Clements 1993 reported that patients who had been treated with a brace plus physiotherapy for a month had statistically significantly less self-reported pain than did patients treated only with physiotherapy (t-test; p <0.05). The trial by Solveborn 1997 reported that all times of followup the patients treated with physiotherapy reported less pain than did the patients treated by bracing (data shown in Table 276 and summarized in Table 277).

Table 278. The Effect of Bracing plus Physiotherapy on Function

Study | Number of patients | Which treatment resulted in greater function? | Was the difference statistically significant? | Was the effect size statistically significant? | Did the study have sufficient power to detect the observed difference?
Clements 1993 ^580^ | 10 bracing plus physiotherapy | Bracing plus physiotherapy | No | Could not calculate from the reported data | Cannot calculate from the reported data
| 9 physiotherapy

##### Function

Clements 1993 reported no statistically significant difference between patients treated with a brace plus physiotherapy and patients treated only with physiotherapy. ^580^ Although statistical power could not be calculated from the data provided, this study was small (n = 19), suggesting that only large differences could be detected.

##### Quality of life

None of the studies reported on this outcome.

##### Morbidity and Complications

No morbidity or complications were reported by the studies.

#### Conclusions

Three crossover trials and two controlled trials evaluated the effectiveness of physiotherapy, elbow bracing, and manipulation as treatments for epicondylitis. Because only one study evaluated manipulation, only two evaluated short-term effects of braces, only one evaluated bracing vs. physiotherapy, and only one evaluated bracing plus physiotherapy, it is difficult to draw firm evidence-based conclusions from the available data.

Simply wearing an elbow brace is reported by two studies to have no effect on pain. One study reported that wearing a brace regularly over the course of several months is not as effective in treating epicondylitis as is physiotherapy, but a different study reported that wearing a brace regularly in addition to physiotherapy may be more effective than physiotherapy alone. One manipulative technique, the contralateral glide procedure, may have some benefit for the treatment of epicondylitis. These general trends are drawn from at most two studies per outcome. Confirmatory studies would strengthen confidence in these results.

### What are the relative benefits and harms of acupuncture therapy for persons with epicondylitis?

Stimulation of acupuncture points is thought to induce the release of endorphins and thus induce an analgesic effect. ^627^ The relevant literature that addressed this question consists of two trials that compared acupuncture to sham acupuncture.

#### Internal validity

We identified two randomized controlled trials of a total of 134 patients that evaluated the effect of acupuncture on epicondylitis. Details of the designs of the trials are shown in Table 279. The trial by Molsberger 1994 was double-blinded. The trial by Haker 1990 was blinded as to rater only, and thus is susceptible to bias from a placebo effect.

Table 279. Internal validity

Study | Number of patients | Number of centers | Funded by a for-profit agency? | Study design | Prospective? | Blinding | %Attrition | Intent to treat analysis | Compliance
Molsberger 1994 ^575^ | 48 | 1 | NR | RCT | Yes | Double | 0 | Yes | NA
Haker 1990 ^576^ | 86 | 1 | NR | RCT | Yes | Rater | 4.7^a^ | Yes | NA

a : Attrition at longest follow up time (12 months)

One trial (Haker 1990) treated the control group with superficially inserted needles, while the other trial (Molsberger 1994) treated the control group with blunt probes at a different site. The appropriate control group to use in trials of acupuncture is unclear. Attempts at performing sham acupuncture, including inserting needles at other sites, inserting needles only superficially, and only stimulating the skin with a blunt probe, have been reported to have similar physiological effects as true acupuncture. ^627^ Therefore any comparison of acupuncture to placebo may yield a greater apparent effect than any comparison of acupuncture and sham acupuncture. However, comparing acupuncture to no treatment does not control for any placebo effect.

#### Generalizability

Details of the patient characteristics are shown in Table 280. Studies of the epidemiology of epicondylitis (see the Introduction) have found that the typical patient is in the mid-forties and that approximately equal proportions of men and women are affected. The patients in both studies are similar to this profile.

Table 280. Generalizability: patient characteristics

Study | Number of patients | Mean age and range | % female | Duration of condition mean and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Did the study exclude patients with severe disease? | Did the study exclude patients with mild disease?
Molsberger 1994 ^575^ | 48 | 47.9 | 54.2 | 15.4 | NR | 0 | | NR | NR | NR | NR | No | No
Haker 1990 ^576^ | 86 | 46.9 (25–70) | 34.9 | 9 (1–120) | NR | 0 | NR | 0 | 0 | NR | NR | No | No

The presence of various comorbidities associated with epicondylitis is incompletely reported in these studies. Both studies excluded patients with certain comorbidities, indicated in Table 280 by a zero under that comorbidity. This somewhat limits the generalizability of these studies, as comborbidities are not generally exclusion criteria for treatment with acupuncture.

Neither study reported employment characteristics of their patient groups. Therefore, the extent to which the employment characteristics of these patients may be generalized to the overall epicondylitis patient population cannot be determined from the information available.

#### Results

##### Success of Treatment

Both studies reported on the global outcome success of treatment. The data reported by the studies are shown in Table 281 and summarized in Table 282. Both studies reported that acupuncture was statistically significantly more successful than control treatment at early followup times (two to four weeks). Only one of the trials followed the patients for longer than two weeks, and it reported that at longer followup times the difference between the groups was not statistically significant. The results of the shorter followup times of the studies are shown graphically in Figure 71. We calculated an effect size (Hedges' d) for each study. At all followup times, the effect sizes indicated that patients treated with acupuncture had statistically significantly better outcomes. Figure 72 displays the effect sizes for the shorter followup times.

Table 281. Results of global assessment of acupuncture

Study | Number of patients | Global assessment patient-reported | Statistical significance of difference between groups
Haker 1990 ^576^ | 44 acupuncture | Acupuncture- | Mann-Whitney U test
| 38 control | 1 month: 7 excellent, 15 good, 17 well improved, 4 improved, 1 same or worse | P<0.01 at 1 month,
| | 3 months: 14 excellent, 19 good, 3 well improved, 4 improved, 3 same or worse | NS at 3 and 12 months
| | 12 months: 26 excellent, 8 good, 3 well improved, 1 improved, 2 same or worse
| | Control-
| | 1 month: 2 excellent, 6 good, 17 well-improved, 3 improved, 10 same or worse
| | 3 months: 7 excellent, 14 good, 9 well improved, 3 improved, 2 same or worse
| | 12 months: 13 excellent, 16 good, 2 well improved, 2 improved, 2 same or worse
Molsberger 1994 ^575^ | 24 acupuncture | At 2 weeks | Chi-squared p <0.01
| 24 control | Acupuncture- 19 treated successfully
| | Control- 6 treated successfully

Table 282. Success of treating epicondylitis with acupuncture

Study | Number of patients | Time of followup | Which treatment was more successful? | Was the difference statistically significant? | Effect size d (95% CI)^a^
Haker 1990 ^576^ | 44 Acupuncture | 1 month | Acupuncture | Yes | 0.84 (0.39 to 1.29)
| 38 Control | 3 months | Acupuncture | No | 0.44 (0.00 to 0.88)
| | 12 months | Acupuncture | No | 0.75 (0.30 to 1.20)
Molsberger 1994 ^575^ | 24 Acupuncture | 2 weeks | Acupuncture | Yes | 1.32 (0.58 to 2.06)
| 24 Control

a calculated by ECRI

Figure 71. Success of acupuncture: statistical tests

The results of Haker were statistically significant at 1 month only.

Figure 72. Success of acupuncture: effect sizes

The results of Haker are presented for the 1 month time point only.

##### Work Status

Neither of the included studies reported on this outcome.

##### Pain

The study by Molsberger 1994 reported on the degree of relief the patients had from their pain and on how long the relief lasted after the treatment. The group treated with acupuncture had significantly greater pain relief and the pain relief lasted significantly longer than it did in the control group. The data reported for this outcome are shown in Table 283 and summarized in Table 284.

Table 283. Results of the effect of acupuncture treatment on pain related to epicondylitis

Study | Pain measured by | Number of patients | Reported outcome | Statistical significance of difference between groups
Molsberger et al. 1994 ^575^ | Patient-rated relief of pain | 24 Acupuncture | Acupuncture- mean 55.8 SD 2.95 | t-test
| | 24 Control | Control- mean 15 SD 2.77 | p <0.01 for both outcomes
| Patient-rated duration of the relief of pain | 24 Acupuncture | Acupuncture- mean 20.2 SD 21.54
| | 24 Control | Control- mean 1.4 SD 3.5

SD = standard deviation

Table 284. Effect of acupuncture treatment on pain related to epicondylitis

Study | Number of patients | Time of followup | Which treatment resulted in less pain? | Was the difference statistically significant? | Effect size d (95% CI)^a^
Molsberger 1994 ^575^ | 24 Acupuncture | 2 weeks | Acupuncture | Yes | Relief of pain: 14.02 (11.16 to 16.89)
| 24 Control | | | | Duration of pain relief: 1.20 (0.58 to 1.81)

a calculated by ECRI

##### Function and Activities

Neither of the studies reported either of these outcomes.

##### Quality of life

Neither of the studies reported this outcome.

##### Morbidity and Complications

No complications or morbidity were reported by either study.

#### Conclusions

Two randomized controlled trials of a total of 134 patients evaluated the effect of acupuncture on epicondylitis. Both studies reported patients treated with acupuncture had better global outcomes and greater pain relief than did patients treated with sham acupuncture at relatively short (2–4 weeks) followup times. The effect seemed to diminish at longer followup times. However, this latter observation was based on only one study so additional data are needed to confirm it.

### What are the relative benefits and harms of surgical treatment for persons with epicondylitis?

Surgical techniques used to treat epicondylitis can be divided into four broad categories: denervation, nerve decompression, excision of tissues, and lengthening of the extensor tendon (ERCB). ^83^ Further information about these categories is provided in the Introduction. The relevant literature addressing this question consists of two studies evaluating the relative merits of different surgical procedures. Neither study compared surgical treatment to no or sham treatment, and neither study compared surgical treatment to nonsurgical treatments, so the absolute effectiveness of surgical treatment cannot be determined.

#### Internal validity

We identified two controlled trials of surgical techniques for the treatment of epicondylitis. These trials enrolled a total of 227 patients. Details of the study designs are shown in Table 285. The study by Almquist 1998 is a retrospective case-controlled trial. Patients treated with limited surgical resection of the lateral extensor aponeurosis (limited fasciectomy) were compared to patients treated with either limited resections or wide resections plus rotation of the vascular pedicle of the anconeus muscle into the defect created by the excision of tissue. Patients were chosen consecutively from the records of one clinic. A major difficulty with this study is that the group of patients treated with limited fasciectomy plus anconeous transfer had all been previously treated with fasciectomy only, with poor results, while the other two groups had not had previous surgical treatments. Hence, the patients in these two groups were different prior to the study.

Table 285. Internal validity

Study | Number of patients | Number of centers | Funded by a for-profit agency? | Study design | Prospective? | Blinding | %Attrition | Intent to treat analysis | Compliance
Almquist 1998 ^83^ | 61 | 1 | No | CT | No | No | 0 | Yes | NA
Wilhelm 1996 ^84^ | 166 | 1 | NR | CT | No | No | 11.4 | No | NA

CT = controlled trial

NR = not reported

NA = not applicable

The study by Wilhem 1996 was a historically controlled study that compared three different surgical techniques. The groups in this study were not treated at the same time, i.e., all of the denervation surgeries were performed from 1970 to 1990, all of the denervation plus decompression surgeries were performed from 1980 to 1990, and all of the denervation plus disinsertion surgeries were performed after 1991. Because the different groups were not treated during the same time periods, other factors aside from the surgical techniques, such as improvements in general post-operative care, could have affected the results.

The study by Wilhelm 1996 did not use intent-to-treat analysis. Ignoring attrition when analyzing the data can create a bias in the results. Where possible, we have tried to compensate for this by attempting to gauge the maximum possible effect of not following this principle. Thus, we assumed that all patients who were not followed until the end of the study received unsuccessful treatment. This is a conservative assumption. However, if statistical significance is obtained under this assumption, one can be more confident that the magnitude of this design weakness is not large enough to overturn the results of a statistically significant trial. We were able to compensate for not following the intent-to-treat principle for the trial by Wilhelm 1996, and found that the conclusions of the study did not change after compensation.

Neither study blinded the patients or the evaluating physician to the type of treatment, which can bias the results.

#### Generalizability

Characteristics of the patient groups are shown in Table 286. Our analysis of patients treated with surgery for epicondylitis (see the answer to Question 2) found that the typical patient was of either sex and in their mid-forties. The patients in both studies fit this profile.

Table 286. Generalizability: patient characteristics

Study | Number of patients | Mean age and range | % female | Duration of condition mean and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Did the study exclude patients with severe disease? | Did the study exclude patients with mild disease?
Almquist 1998 ^83^ | 61 | 43.9 (27–63) | 39.3 | 27.3 (6–72) | NR | NR | NR | NR | NR | NR | NR | No | No
Wilhelm 1996 ^84^ | 166 | 44.5 (21–62) | 57.8 | NR | NR | NR | NR | NR | NR | NR | NR | No | No

NR = not reported

Neither study reported on the presence of comorbidities or employment characteristics. Therefore, the extent to which these patient groups can be generalized to the overall epicondylitis population cannot be determined from the information available.

#### Results

##### Success of Treatment

The study by Wilhem 1996 reported that patients treated with denervation alone rated their outcomes more positively than did patients treated with denervation plus decompression or with denervation plus disinsertion. These data are reported in Table 287 and summarized in Table 288. The difference in outcomes was statistically significant between the denervation and denervation plus decompression groups, but was not statistically significant between the denervation and the denervation plus disinsertion groups. The denervation plus decompression group rated their outcomes statistically significantly more positively than did the denervation plus disinsertion group.

Table 287. Results of the success of surgery at treating epicondylitis

Study | Number of patients | Success of treatment | Statistical significance of difference between groups
Wilhem 1996 ^84^ | 39 denervation | Denervation: 29 excellent, 4 good, 2 fair, 1 poor | Chi-squared test
| 46 denervation and disinsertion | Disinsertion: 30 excellent, 7 good, 3 fair, 2 poor | Denervation vs. disinsertion p = 0.159
| 81 denervation and decompression | Decompression: 36 excellent, 13 good, 16 fair, 10 poor | Denervation vs. decompression P = 0.0071
| | | Disinsertion vs. decompression p=0.033

Table 288. Success of surgery at treating picondylitis

Study | Number of patients | Which treatment was most successful? | Was the difference significant? | Effect size d (95% CI)^a^
Wilhem 1996 ^84^ | 39 denervation | Denervation | Yes, between denervation and decompression | Disinsertion: 1.13 (0.71 to 1.55)
| 46 denervation and disinsertion | | Yes, between decompression and disinsertion | Denvervation: 0.75 (0.36 to 1.14)
| 81 denervation and decompression | | No, between denervation and disinsertion

a calculated by ECRI using decompression plus denervation as the control group

##### Work Status

Almquist 1998 reported on the number of patients able to resume normal work after treatment. These data are reported in Table 289 and summarized in Table 290. Wide fasciectomy plus anconeus transfer was reported to have a better outcome than did fasciectomy alone or limited fasciectomy plus anconeus transfer. The difference, however, was not statistically significant, despite the fact that the study had sufficient power to detect a difference between groups as small as 3%. Hence, this negative finding is probably not the consequence of a small sample size.

Table 289. Results of surgical treatment on work status

Study | N patients | Percentage of patients able to return to normal work | Statistical significance of the difference between groups
Almquist 1998 ^83^ | 16 fasciectomy | Fasciectomy - 81% | Chi-squared test
| 31 wide fasciectomy plus anconeus transfer | Wide fasciectomy plus anconeus transfer- 96% | P>0.05
| 14 limited fasciectomy plus anconeus transfer | Limited fasciectomy - 86%

Table 290. Effect of surgical treatment on work status

Study | N patients | Which treatment resulted in more patients returning to work? | Was the difference significant? | Minimal difference between groups the study had the power to detect | Effect size d (95% CI)^a^
Almquist 1998 ^83^ | 16 fasciectomy | Wide fasciectomy plus anconeus transfer | No | 3% | Wide fasciectomy:
| 31 wide fasciectomy plus anconeus transfer | | | | 1.05 (-0.25 to 2.35)
| 14 limited fasciectomy plus anconeus transfer | | | | limited fasciectomy:
| | | | | 0.17 (-0.90 to 1.25)

a calculated by ECRI with fasciectomy alone as the control group

##### Pain

Almquist 1998 reported that patients treated with wide fasciectomy plus anconeus transfer had more pain relief than did patients treated with fasciectomy. This difference was reported to be statistically significant. Patients treated with wide fasciectomy plus anconeus transfer were reported to have more pain relief than patients treated with limited fasciectomy plus anconeus transfer, but the difference in outcomes between these two groups was not statistically significant. These data are reported in Table 291 and summarized in Table 292.

Table 291. Results of surgical treatment on pain

Study | N patients | Percentage of patients with pain relief | Statistical significance of the difference between groups
Almquist 1998 ^83^ | 16 fasciectomy | Fasciectomy- 62% | Chi-squared test
| 31 wide fasciectomy plus anconeus transfer | Wide fasciectomy plus anconeus transfer- 87% | P<0.05 between wide plus transfer and fasciectomy only
| 14 limited fasciectomy plus anconeus transfer | Limited fasciectomy- 86%

Table 292. Effect of surgical treatment on pain

Study | N patients | Which treatment resulted in more pain relief? | Was the difference significant? | Effect size d (95% CI)^a^
Almquist 1998 ^83^ | 16 fasciectomy | Wide fasciectomy plus anconeus transfer | Yes, between wide plus transfer and fasciectomy; No, between wide plus transfer and limited | Wide fasciectomy: 0.76 (-0.05 to 1.56)
| 31 wide fasciectomy plus anconeus transfer | | | Limited fasciectomy: 0.69 (-0.31 to 1.68)
| 14 limited fasciectomy plus anconeus transfer

a calculated by ECRI with fasciectomy alone as the control group

##### Function and Activities

Neither of the included studies reported patient-oriented measurements of these outcomes.

##### Quality of Life

Neither of the included studies reported on this outcome.

##### Morbidity and Complications

Morbidity and complications related to the surgery were not reported by either study. Wilhem 1996 did describe the length of time required to recover from surgery. Denervation required only 2.7 weeks of recovery, as compared to 5.7 weeks to recover from denervation plus disinsertion and 11.7 weeks to recover form denervation plus decompression. These differences were reported to be statistically significant. These data are summarized in Table 293.

Table 293. Length of time after surgery before returning to work

Study | Number of patients | Which treatment had the shortest recovery time? | Was the difference significant?
Wilhem 1996 ^84^ | 39 denervation | Denervation | Yes
| 46 denervation and disinsertion
| 81 denervation and decompression

#### Conclusions

One retrospective case-controlled study of 61 patients compared fasciectomy, wide fasciectomy plus anconeus transfer, and re-operation of failed fasciectomy to include an anconeus transfer. This study reported that patients treated with wide fasciectomy plus anconeus transfer had better outcomes than did patients treated with either fasciectomy or re-operation of failed fasciectomy to include an anconeus transfer. However, the design of this study was not optimal, and precludes one from making a firm evidence-based conclusion.

One non-parallel historically controlled trial of 166 patients reported that simple denervation lead to statistically significantly better global outcome and greater pain relief than did denervation plus decompression. Simple denervation was also reported to lead to better global outcome, and greater pain relief, than did denervation plus disinsertion, but the difference was not statistically significant. However, design difficulties with this study preclude one from using its results to make a firm evidence-based conclusion.

### What are the relative benefits and harms of transcutaneous electrical nerve stimulation therapy for persons with epicondylitis?

Transcutaneous electrical nerve stimulation therapy (TENS) refers to applying an electrical current across the skin. TENS has been reported to relieve pain and stimulate wound healing. The scope of our answer to this question is determined by the scope of the published literature. The relevant literature consists of one study that compared TENS to sham TENS treatment.

#### Internal validity

One double-blinded randomized crosover trial was identified that employed transcutaneous electrical nerve stimulation therapy (TENS) for treating epicondylitis. Details of this study are shown in Table 294. The study treated one patient group with a Rebox device, which delivers a low-current voltage to the patient. The control group received sham treatment with a disabled Rebox device. After ten treatments, the groups spent a week receiving no treatment, then they received the opposite treatment.

Table 294. Internal validity

Study | Number of patients | Number of centers | Funded by a for-profit agency? | Study design | Prospective? | Blinding | %Attrition | Intent to treat analysis | Compliance
Johannsen 1993 ^612^ | 35 | 1 | NR | RCT | Yes | Double | 8.6 | No | NA

Analysis and reported data are for only those who completed the entire trial (not intent-to-treat). Ignoring attrition when analyzing the data can create a bias in the results. However, attrition in this trial was not substantial (8.6%).

#### Generalizability

The characteristics of the patients are shown in Table 295. The mean age of the patients was 43, which is similar to that reported in studies of the epidemiology of epicondylitis (see the Introduction). However, the patients were predominantly male (82.9% male). Studies of the epidemiology of epicondylitis (see the Introduction) have indicated that patients with epicondylitis are equally likely to be of either sex. Thus, this may be an atypical group of patients. No information as to the occupations or employment status of the patients was reported. The study excluded patients with various comorbidities. This limits the generalizability of the study, as comorbidities are not generally exclusion criteria for treatment with TENS.

Table 295. Generalizability: patient characteristics

Study | Number of patients | Mean age and range | % female | Duration of condition mean and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Did the study exclude patients with severe disease? | Did the study exclude patients with mild disease?
Johannsen 1993 ^612^ | 35 | 43 (36–58) | 17.1 | 6 (3–12) | NR | 0 | 0 | 0 | 0 | NR | NR | No | No

#### Results

Three outcomes were reported by this study; none were patient-oriented.Because no patient-oriented outcomes were reported, we have not shown any tables of data or performed any analysis.We will, however, briefly discuss the outcomes and results reported by this study.Grip strength was measured using a dynamometer with both the elbow extended and flexed.Mean improvements were reported.The amount of pain the patient experienced while lifting a 2 kg weight with the elbow extended and the forearm pronated was also measured and reported as mean improvements.For all three outcomes, differences between the treatment groups were statistically insignificant until the complete course of ten treatments had been administered, at which time a statistically significantly better outcome was found for the patients receiving TENS.

#### Conclusions

One randomized controlled crossover trial of 35 patients reported that patients treated with TENS had statistically significantly better outcomes than did patients receiving sham treatment.However, none of the reported outcomes were patient-oriented, and reaching definitive evidence-based conclusions from the results of a single trial is problematic.Further research into this treatment is necessary.

### What are the relative benefits and harms of pulsed electromagnetic field therapy for persons with epicondylitis?

Pulsed electromagnetic fields (PEMF) have been said to speed healing, alleviate pain, and reduce inflammation.The scope of our answer to this question is determined by the scope of the published literature.The relevant literature consists of one trial that compared PEMF therapy to sham PEMF therapy.

#### Internal validity

One double-blinded randomized controlled trial of 30 patients that evaluated pulsed electromagnetic fields (PEMF) as a therapy for epicondylitis was identified.The study design is summarized in Table 296.The gender compositions of the two groups appears to be different, but chi-squared tests calculated by ECRI indicate the difference is of borderline statistical significance (p = 0.06).

Table 296. Internal validity

Study | Number of patients | Number of centers | Funded by a for-profit agency? | Study design | Prospective? | Blinding | %Attrition | Intent to treat analysis | Compliance
Devereaux 1985 ^598^ | 30 | 1 | NR | RCT | Yes | Double | 0 | Yes | NA

#### Generalizability

Only patients diagnosed with epicondylitis who had a positive thermographic pattern with a hot area near the lateral epicondyle were included in the trial.Data on what percentage of epicondylitis patients in general who have such a thermographic pattern are not available.Thus, it is unclear whether these patients are typical epicondylitis patients.Other characteristics of these patients are shown in Table 297.The mean age (43.3 years) and percent female (43.3%) are similar to those found in studies of the epidemiology of epicondylitis (see the Introduction).No information as to the occupations or employment status of the patients was reported.The study did exclude patients with some comorbidities, which further limits the generalizability of the trial as comorbidities are not exclusion criteria for treatment with PEMF.

Table 298. Success of treating epicondylitis with PEMF

Study | Number of patients | Which treatment was more effective? | Was the difference statistically significant? | Was the effect size statistically significant? | Did the study have sufficient power to detect the observed difference?
Devereaux 1985 ^598^ | 15 PEMF | PEMF | No Wilcoxon rank sum test | Cannot calculate from the reported data | Cannot calculate from the reported data
| 15 Sham

PEMF = pulsed electrical magnetic field

Table 297. Generalizability:patient characteristics

Study | Number of patients | Mean age and range | % female | Duration of condition mean and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Did the study exclude patients with severe disease? | Did the study exclude patients with mild disease?
Devereaux 1985 ^598^ | 30 | 43.8 | 43.3 | 10.0 | NR | 0 | NR | 0 | 0 | 0 | NR | No | No

#### Results

The patients were evaluated every two weeks for the ability to lift weight, pain upon wrist dorisflexion, effect on work, pain during common activities of daily living (ADL), tenderness over the elbow, and grip strength.Data were only reported for grip strength, not for any of the patient-oriented outcomes.Grip strength was statistically significantly more effective at 6 weeks evaluation in the group given PEMF as compared to the group given sham treatment.However, examination of the data indicates that this difference is primarily the result of a mean decrease in grip strength at 6 weeks in the sham-treated group.For all of the other outcomes, at all time points, there were no reported statistically significant differences between the treatment groups.However, this study was small (n = 30), so it is possible that it lacked sufficient power to detect a statistically significant difference between the treatment groups.Because data reporting was incomplete, power calculations cannot be performed for this study.

#### Conclusions

A single double-blinded randomized controlled trial of 30 patients reported that there were no statistically significant differences in the signs and symptoms of epicondylitis between patients treated with PEMF and patients receiving sham treatment.When interpreting the results of this trial, it must be kept in mind that the small size of the trial may have prevented the results from reaching statistical significance.

### What are the relative benefits and harms of extracorporal shock-wave therapy for persons with epicondylitis?

Extracorporal shock wave therapy (ESWT) refers to passing a shock wave through a localized area of the body.It has been reported to relieve pain. ^581^ The relevant literature consists of one published study that compared ESWT to a sham ESWT procedure.

#### Internal validity

Two manuscripts by the same group have been published evaluating ESWT as a treatment for epicondylitis.Both manuscripts refer to the same study; the earlier manuscript includes fewer patients. ^582^ Therefore, only the later manuscript is discussed in this report. ^581^ Details of the study design are shown in Table 299.The study was a randomized controlled trial.Neither the patients nor the evaluating physicians were blinded to the type of treatment received.Lack of blinding of the patient to the type of treatment, in particular when using subjective outcome measures, can alter measurements of treatment effect because patients might unconsciously rate their condition differently in order to please the clinician. ^474^ If the evaluating physician is aware of the treatment given, it is possible that he/she may unconsciously bias the patient's responses by giving leading instructions. ^474^

Table 299. Internal validity

Study | Number of patients | Number of centers | Funded by a for-profit agency? | Study design | Prospective? | Blinding | %Attrition | Intent to treat analysis | Compliance
Rompe 1996 ^581^ | 115 | 1 | NR | RCT | Yes | No | 13.0 | No | NA

NR = not reported

NA = not applicable

RCT = randomized controlled trial

The trial did not analyze the data by the intent-to-treat principle.Ignoring attrition when analyzing the data can create a bias in the results.For this particular trial, we were unable to compensate for the failure to follow the intent-to-treat principle.The attrition rate from this trial was substantial (13.0%) and thus may have biased the results.

#### Generalizability

Characteristics of the patient groups enrolled in the trial are shown in Table 300.All of the patients had been diagnosed with lateral epicondylitis.The mean age of the patients was 42.9, and the patient group was 50.4% female.These patient characteristics match those reported in published studies of the epidemiology of epicondylitis (see the Introduction), suggesting that the results of the study are generalizable beyond this particular patient group.The study did not report any information as to the occupations or employment status of the patients.The study excluded patients with arthritic changes of the elbow, which may limit its generalizability to the overall epicondylitis patient population.

Table 300. Generalizability information:patient characteristics

Study | Number of patients | Mean age and range | % female | Duration of condition mean and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Did the study exclude patients with severe disease? | Did the study exclude patients with mild disease?
Rompe 1996 ^581^ | 115 | 42.9 (26–61) | 50.4 | 22.9 (10–120) | NR | 0 | NR | NR | NR | NR | NR | No | No

#### Results

The reported patient-oriented results are shown in Table 301 and summarized in Table 302.The patients were asked to rate their improvement in pain and function.There is a statistically significant better outcome for patients treated with ESWT as compared to sham therapy at all followup times.We calculated an effect size for each time point and outcome and this is shown in Table 301.

Table 301. Results of treating epicondylitis with ESWT

Study | Outcome | Treatment group | N | Time of followup months | Reported outcome | | | | Statistical test | Hedges'd (95% CI)^a^
Rompe 1996 ^581^ | Patient-rated improvement in pain and function | | | | Excellent | Good | Acceptable | Poor | Chi-squared test^a^ P<0.000001 at all time points
| | ESWT | 50 | 1 | 11 | 16 | 18 | 5 | | 2.76 (2.22 to 3.31)
| | Sham | 50 | 1 | 0 | 10 | 16 | 24
| | ESWT | 50 | 1.5 | 10 | 16 | 18 | 6 | | 3.05 (2.48 to 3.62)
| | Sham | 50 | 1.5 | 0 | 6 | 10 | 34
| | ESWT | 50 | 6 | 6 | 11 | 13 | 21 | | 1.20 (0.78 to 1.62)
| | Sham | 50 | 6 | 0 | 3 | 12 | 35
| Pain at night, patient-rated | ESWT | 50 | 0 | 34.6 (15.8) | | | | Fisher's exact test p >0.05 at time 0, p <0.001 at all other times | -0.21 (-0.61 to 0.18)
| | Sham | 50 | 0 | 31.2 (16)
| | ESWT | 50 | 1 | 13.2 (9.9) | | | | | 1.49 (1.04 to 1.93)
| | Sham | 50 | 1 | 34.6 (17.6)
| | ESWT | 50 | 1.5 | 7.7 (8.8) | | | | | 1.91 (1.44 to 2.38)
| | Sham | 50 | 1.5 | 35.1 (18.1)
| | ESWT | 50 | 6 | 7.3 (8.7) | | | | | 1.48 (1.04 to 1.93)
| | Sham | 50 | 6 | 27.3 (16.8)

a calculated by ECRI

Table 302. Effect of ESWT on epicondylitis

Study | Number of patients | Which treatment resulted in the greatest improvement? | Was the difference statistically significant? | Was the effect size statistically significant?
Rompe 1996 ^581^ | 50 ESWT | ESWT, at 1, 1.5, and 6 months | Yes | Yes
| 50 Sham

ESWT = extracorporal shock wave therapy

#### Conclusions

One randomized controlled trial of 100 patients reported that patients treated with ESWT had statistically significantly greater improvements in pain and arm function than did patients given sham treatment.However, it is difficult to reach firm evidence-based conclusions from the results of this trial because the lack of blinding and lack of intent-to-treat analysis of this trial may have affected its results.

### What are the relative benefits and harms of various combinations of therapy for persons with epicondylitis?

#### Internal validity

Five studies that compared combinations of therapies are discussed in this section.The therapies used are summarized in Table 303.Some of the data from the trials by Holdsworth 1993 and Straford 1989 were also included in the section on ultrasound therapy.Details of the study designs are summarized in Table 304.

Table 303. Summary of trials of mixed therapies for epicondylitis

Study | Treatments compared
Drechsler 1997 ^593^ | Manipulations plus home exercise
| Ultrasound plus physiotherapy plus home exercise
Holdsworth 1993 ^620^ | Ultrasound
| Ultrasound plus brace
| phonophoresis
| Phonophoresis plus brace
Vasseljen 1992 ^591^ | Laser
| Ultrasound plus deep friction massage
Stratford 1989 ^621^ | Ultrasound
| Ultrasound plus deep friction massage
| Phonophoresis
| Phonophoresis plus deep friction massage
Burton 1988 ^594^ | Manipulation
| Manipulation plus brace
| Manipulation plus cream
| Manipulation plus cream plus brace

Table 304. Internal validity

Study | Number of patients | Number of centers | Funded by a for-profit agency? | Study design | Prospective? | Blinding | %Attrition | Intent to treat analysis | Compliance
Drechsler 1997 ^593^ | 18 | 1 | NR | RCT | Yes | No | 0 | Yes | NR
Holdsworth 1993 ^620^ | 42 | 1 | NR | RCT | Yes | Patients | 14.3 | No | NA
Vasseljen 1992 ^591^ | 30 | 1 | NR | RCT | Yes | No | 0 | Yes | NA
Stratford 1989 ^621^ | 40 | 1 | No | RCT | Yes | Double | 0 | Yes | NA
Burton 1988 ^594^ | 33 | 1 | Yes | RCT | Yes | No | 0 | Yes | NR

RCT = randomized controlled trial

NR = not reported

NA = not applicable

All of the trials are randomized controlled trials.Three of the five trials were not blinded.The trial by Stratford 1989 was double-blinded as to whether patients received ultrasound or phonophoresis, but the patients were aware of their status as regards massage therapy or not.Likewise, the trial by Holdsworth 1993 blinded the patients as to whether they received ultrasound or phonophoresis, but the patients were aware of their status as regards being assigned an elbow brace or not.None of the studies reported on compliance with the prescribed treatments.

The study Holdsworth 1993 did not use intent-to-treat analysis.This study had a high attrition rate (14.3%).Ignoring attrition when analyzing the data can create a bias in the results.We were not able to compensate for not following the intent-to-treat principle for this trial because of the nature of the data reported.

#### Generalizability

Details of the patient characteristics are shown in Table 305.Epidemiology studies of epicondylitis (see the Introduction) have found that the typical patient is in the mid-forties and of either sex.All of the patient groups of these studies fit this profile.

Table 305. Generalizability:patient characteristics

Study | Number of patients | Mean age and range | % female | Duration of condition mean and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Did the study exclude patients with severe disease? | Did the study exclude patients with mild disease?
Drechsler 1997 ^593^ | 18 | 45.9 (30–57) | 55.6 | NR | 0 | 0 | NR | 0 | 0 | NR | 0 | No | No
Holdsworth 1993 ^620^ | 42 | 45.3 (22–62) | 35.7 | NR | NR | 0 | 0 | 0 | 0 | NR | NR | No | No
Vasseljen 1992 ^591^ | 30 | 45.5 (25–70) | 56.7 | 2.1 (1–12) | NR | 0 | NR | NR | NR | NR | NR | No | No
Stratford 1989 ^621^ | 40 | 43.3 | 50.0 | 4.3 | NR | NR | NR | 0 | NR | NR | NR | No | No
Burton 1988 ^594^ | 33 | 45.1 | 48.5 | 1.2 | NR | NR | NR | NR | NR | NR | NR | No | No

NR = not reported

The presence of various comorbidities associated with epicondylitis is incompletely reported in these studies.Some studies excluded patients with various comorbidities, indicated in Table 305 with a zero under that comorbidity.This limits the generalizability of the studies, as comorbidities are not usually exclusion criteria for the treatments discussed in this section.

None of studies reported any information as to patient occupations or employment status.Therefore, the extent to which the employment characteristics of these patients may be generalized to the overall population of epicondylitis patients cannot be determined from the available data.

#### Results

##### Manipulations plus exercise compared to ultrasound plus physiotherapy

The study by Drechsler 1997 compared a combination of manipulations designed to increase mobility of the elbow plus a regimen of home exercises to a combination of ultrasound, physiotherapy, and home exercises.This study measured grip strength, self-reported difficulties in performing activities, and measurements of upper limb tension.The data recorded for the patient-oriented outcome difficulties in performing activities are shown in Table 306 and summarized in Table 307.The authors performed an analysis of variance (ANOVA) on their data and found that patients treated with manipulations plus home exercises had fewer difficulties in performing activities of daily living than patients treated with ultrasound, physiotherapy, and home exercises.The difference in outcomes was statistically non-significant at 1.5 months of followup, but was statistically significant by 3 months of followup.

Table 306. Treating epicondylitis with ultrasound plus physiotherapy compared to manipulations

Study | Number of patients | Patient-reported difficulties in performing ADL | Statistical significance of difference between groups
Drechsler 1997 ^593^ | 10 US, physiotherapy | Mean (SD) | ANOVA
| 8 Manipulations | At 1.5 months | At 1.5 months, NS
| | US + physio:1.9 (0.233) | At 3 months, p <0.05
| | Manipulations:1.875 (0.295)
| | At 3 months
| | US + physio:2.1 (0.0314)
| | Manipulations:1.5 (0.189)

US = ultrasound

Physio = physiotherapy

Table 307. Treating epicondylitis with ultrasound plus physiotherapy compared to manipulations

Study | Number of patients | Which treatment was most successful? | Was the difference statistically significant? | Effect size d (95% CI)^a^
Drechsler 1997 ^593^ | 10 US, physiotherapy | Manipulation | At 1.5 months, No | At 1.5 months, 0.11 (-0.77 to 0.99)
| 8 Manipulations | | At 3 months, Yes | At 3 months, 4.24 (2.66 to 5.82)

a calculated by ECRI

US = ultrasound

##### Ultrasound with or without bracing

Holdsworth 1993 compared groups treated with ultrasound combined with elbow bracing therapy to groups treated with ultrasound only.The data reported by Holdsworth 1993 are shown in Table 308 and summarized in Table 309.Holdsworth 1993 reported that the addition of bracing to either ultrasound or phonophoresis had no statistically significant effect on patient-rated success of the treatment.However, this trial could have detected only an 83% or larger difference between groups.Therefore, its small size may have caused it to miss clinically important effects.

Table 308. Results of treating epicondylitis with ultrasound plus bracing

Study | Number of patients | Patient-rated success of treatment on VAS | Statistical significance of difference between groups
Holdsworth 1993 ^620^ | 7 Phonophoresis | 1.5 months mean (SE) | ANOVA
| 10 Phonophoresis plus bracing | Phonophoresis:49.6 (12.4) | NS
| 9 ultrasound | Phonophoresis + bracing:55.9 (16.1)
| 8 Ultrasound plus bracing | Ultrasound:63 (12.2)
| | Ultrasound + bracing:62.6 (11.3)

Table 309. Treating epicondylitis with ultrasound plus bracing

Study | Number of patients | Which treatment was more successful? | Was the difference statistically significant? | Minimal difference between groups the study had the power to detect | Effect size d (95% CI)^a^
Holdsworth 1993 ^620^ | 7 Phonophoresis | Phonophoresis | No | 83.5% | Phonophoresis:
| 10 Phonophoresis plus bracing | | | | 0.33 (-0.55 to 1.21)
| 9 Ultrasound | | | | 0.15 (-0.73 to 1.03)
| 8 Ultrasound plus bracing | | | | 0.01 (-0.87 to 0.89)

a calculated by ECRI using ultrasound as the comparison group

##### Ultrasound plus massage compared to laser

Vasseljen 1992 compared laser therapy to a mixture of ultrasound and deep friction massage.Each patient received eight treatments.Pain (physician-rated) was measured after all the treatments had been administered, and four weeks later.The group treated with ultrasound plus massage had significantly less pain (p <0.01; ANOVA) after treatment than did the group treated with laser therapy.

##### Ultrasound plus massage compared to ultrasound

Stratford 1989 compared ultrasound plus deep friction massage to ultrasound alone.Each patient received nine treatments over the course of five weeks.The results are shown in Table 310 and summarized in Table 311.The study did not find a statistically significant difference between any of the treatment combinations.However, the study could have only detected a 42% or larger difference between the groups.Therefore, it was too small to detect a small to moderate clinically important effect.

Table 310. Results of treating epicondylitis with ultrasound plus massage as compared to ultrasound

Study | Type of Treatment | Number of patients with successful treatment | Statistical significance of difference between groups
Stratford 1989 ^621^ | 10 Phonophoresis | 3 phonophoresis | Chi-squared test^a^
| 10 Phonophoresis plus massage | 2 phonophoresis plus massage | Phonophoresis with or without massage P = 0.61
| 9 Ultrasound | 1 ultrasound | Ultrasound with or withour massage P = 0.19
| 11 Ultrasound plus massage | 4 ultrasound plus massage

a calculated by ECRI

Table 311. Success of treating epicondylitis with ultrasound plus massage as compared to ultrasound

Study | Number of patients | Which treatment was most successful? | Was the difference statistically significant? | Minimal difference between groups the study had the power to detect | Effect size d (95% CI)^a^
Stratford 1989 ^621^ | 10 Phonophoresis | Ultrasound plus massage | No | 42% | Phonophoresis: 0.71 (-0.65 to 2.07)
| 10 Phonophoresis plus massage | | | | Phonophoresis plus massage: 0.43 (-1.0 to 1.85)
| 9 Ultrasound | | | | Ultrasound plus massage: 0.95 (-0.39 to 2.28)
| 11 Ultrasound plus massage

a calculated by ECRI with ultrasound as the comparison group

##### Manipulation plus bracing

Burton 1988 compared manipulations to improve mobility of the elbow to manipulations plus bracing, manipulations plus a topical anti-inflammatory cream, and a combination of all three therapies.Burton 1988 measured patient-rated hand-arm function.The data are shown in Table 312 and summarized in Table 313.No statistically significant differences between groups were found.However, this study lacks the statistical power to detect less than a 67% difference between the therapies, and thus could not have detected small to moderate clinically important effects.

Table 312. Results of treatment of epicondylitis with combinations of manipulation, bracing, and topical anti-inflammatories

Study | Number of patients | Mean (SD) of patient-rated function VAS | | | Effect size d (95% CI)^a^
Burton 1988 ^594^ | 8 Bracing plus manipulation | Initial measure | Bracing plus manipulation | 3.2 (0.4) | 0.0 (-0.88 to 0.88)
| 8 Bracing plus cream plus manipulation | | Bracing plus cream plus manipulation | 3.6 (1.0) | 0.35 (-0.54 to 1.23)
| 9 Cream plus manipulation | | Cream plus manipulation | 3 (0.7) | -0.19 (-1.07 to 0.68)
| 8 Manipulation | | Manipulation | 3.2 (1.2)
| | 1 week | Bracing plus manipulation | 2.8 (0.8) | 0.00 (-0.88 to 0.88)
| | | Bracing plus cream plus manipulation | 2.8 (1.4) | 0.00 (-0.88 to 0.88)
| | | Cream plus manipulation | 2.5 (0.7) | -0.29 (-1.17 to 0.59)
| | | Manipulation | 2.8 (1.2)
| | 2 weeks | Bracing plus manipulation | 2.5 (1.1) | 0.00 (-0.88 to 0.88)
| | | Bracing plus cream plus manipulation | 2.5 (1.7) | 0.00 (-0.88 to 0.88)
| | | Cream plus manipulation | 1.7 (0.6) | -0.63 (-1.53 to 0.26)
| | | Manipulation | 2.5 (1.6)
| | 4 weeks | Bracing plus manipulation | 1.6 (1.0) | 0.08 (-0.79 to 0.96)
| | | Bracing plus cream plus manipulation | 1.5 (1.6) | 0.00 (-0.88 to 0.88)
| | | Cream plus manipulation | 1 (0.8) | -0.44 (-1.33 to 0.44)
| | | Manipulation | 1.5 (1.3)

a calculated by ECRI with manipulation as the comparision group

Table 313. Treatment of epicondylitis with combinations of manipulation, bracing, and topical anti-inflammatories

Study | N patients | Which treatment resulted in greater function? | Was the difference statistically significant? | Minimal difference the study had the power to detect | Where any of the effect sizes statistically significant?
Burton 1988 ^594^ | 8 Bracing plus manipulation | Bracing plus cream plus manipulation | No for all followup times | 67% | No
| 8 Bracing plus cream plus manipulation | | ANOVA test p >0.05
| 9 Cream plus manipulation
| 8 Manipulation

##### Morbidities and complications

None of the included studies reported any complications or morbidities.

#### Conclusions

Five randomized controlled trials evaluated various combinations of therapies for the treatment of epicondylitis.Because no two trials evaluated the same combinations, no meta-analysis could be performed.One trial of 18 patients found that patients treated with manipulation plus a home exercise program had fewer difficulties in performing activities of daily living than did patients treated with a combination of ultrasound, physiotherapy, and home exercise.The other four trials did not find statistically significant differences between-treatment groups. However, these studies were small, which may have prevented them from detecting clinically important differences between the treatment groups.One of these studies reported a trend towards phonophoresis being rated as more successful than ultrasound, phonophoresis plus bracing, or ultrasound plus bracing.One of these studies reported a trend towards ultrasound plus deep friction massage being rated as more successful than ultrasound, phonophoresis, or phonophoresis plus deep friction massage.One of these studies reported no statistically significant functional differences after treatment with various combinations of bracing, manipulation, and topical anti-inflammatory cream.One of these studies reported a trend towards less pain experienced by patients treated with ultrasound plus deep friction massage than those treated with laser therapy.

No firm evidence-based conclusions as to the effectiveness of these combinations of therapies can be reached from the results presented by these trials.Four of the studies included too few patients to be able to have detected small but clinically meaningful effects of the therapies.Although the fifth study did find a statistically significant difference between groups for one outcome, it was a small study (n = 18) that did not blind either the patients or the evaluating physicians to treatments.Further studies are required to corroborate this study's results.

### What are the relative benefits and harms of different therapies for persons with epicondylitis?

#### Internal validity

Seven studies were identified that directly compared the efficacy of different therapies for treating epicondylitis.Details of the therapies compared by these studies are summarized in Table 314.One of the trials (Brattberg 1983) was not randomized; the rest of the trials are randomized controlled trials.Three of the trials did not use blinding, and two blinded only the evaluating physician, not the patients.

Table 315. Internal validity

Study | Number of patients | Number of centers | Funded by a for-profit agency? | Study design | Prospective? | Blinding | %Attrition | Intent to treat analysis | Compliance
Hay 1999 ^609^ | 182 | Multiple | NR | RCT | Yes | Rater | 0.55 | Yes | NR
Pienimaki 1996 ^599^ | 42 | 1 | NR | RCT | Yes | Rater | 7.1 | No | NA
Verhaar 1995 ^607^ | 106 | 1 | No | RCT | Yes | No | 2.8 | No | NA
Haker 1993 ^611^ | 76 | 1 | NR | RCT | Yes | Double | 6.6 | No | NA
Halle 1986 ^606^ | 48 | 1 | NR | RCT | Yes | No | 0 | Yes | NR
Saartok 1986 ^610^ | 21 | 1 | NR | RCT | Yes | Double | 14.2 | No | NR
Brattberg 1983 ^608^ | 63 | 1 | NR | CT | Yes | No | 4.8 | No | NA

RCT = randomized controlled trial

CT = controlled trial

NR = not reported

NA = not applicable

Table 314. Summary of the trials comparing different therapies for epicondylitis

Study | Treatments compared
| Group 1 | Group 2
Hay 1999 ^609^ | Injection of methylprednisolone and lidocaine | Naproxen, 500 mg 2X/day
| | Placebo pills
Pienimaki 1996 ^599^ | Physical therapy | Ultrasound
Verhaar 1995 ^607^ | Injection of triamcinolone and lidocaine | Deep friction massage and manipulations, 12 times over 4 weeks
Haker1993 ^611^ | Injection of bupivacaine and triamcinolone | Epicondylitis clasp, worn daily for 3 months
| | Elbow immobilized in splint, worn daily for 3 months
Halle 1986 ^606^ | Injection of hydrocortisone and lidocaine | Ultrasound
| TENS | Phonophoresis of hydrocortisone
Saartok 1986 ^610^ | Injection of betamethasone | Naproxen, 250 mg/day for 2 weeks
Brattberg 1983 ^608^ | Injection of steroids, unspecified type, unspecified number of injections | Acupuncture at five points in the region of the elbow. One to two treatments per week for four weeks

TENS = transcutaneous electrical nerve stimulation therapy

NSAID = non steroidal anti-inflammatory drug

Only two of the studies (Hay 1999 and Halle 1986) used intent-to-treat analysis.Attrition rates were fairly low (less than 10%) in four out of the five studies that did not use intent-to-treat analysis.However, in the study by Saartok 1986 attrition rates were greater than 10%.Ignoring attrition when analyzing the data can create a bias in the results.Where possible, we have tried to compensate for this by attempting to gauge the maximum possible effect of not following this principle.Thus, we assumed that all patients who were not followed until the end of the study received unsuccessful treatment.This is a conservative assumption.However, if statistical significance is obtained under this assumption, one can be more confident that the magnitude of this design weakness is not large enough to overturn the results of a statistically significant trial.We were able to compensate for not following the intent-to-treat principle in all of the trials included in this section.This compensation suggests that failure to follow the intent-to-treat principle did not alter the conclusions of any of these trials.

The trial by Hay 1999 is a multi-center trial that may be potentially confounded by co-interventions.By 12 months of followup, approximately 35–38% of the patients in all groups had received some unspecified treatment in addition to their assigned treatment.Because approximately equal numbers of patients in each group received additional treatments, it is possible that these interventions did not affect the results of the trial.However, the types of interventions are not specified.Thus, it is theoretically possible that patients in one group received different co-interventions than did patients in other groups, and thus the co-interventions could affect the results of the trial.

#### Generalizability

Details of the patient characteristics are shown in Table 316.The patients in all of the trials appear to be fairly typical of epicondylitis patients in general (see the epidemiology subsection in the Introduction).However, the Saartok trial appears to be predominantly male (19.0% female), and the Haker trial is also predominantly male (25.0% female); studies of the epidemiology of epicondylitis suggest that the general population is approximately 50% female.Thus, these two trials may be drawn from special subpopulations and their results may not be generalizable.

Table 316. Generalizability: patient characteristics

Study | Number of patients | Mean age and range | % female | Duration of condition mean and range | % Patients with diabetes | % Patients with arthritis | % Patients with previous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Did the study exclude patients with severe disease? | Did the study exclude patients with mild disease?
Hay 1999 ^609^ | 182 | NR | 42.8 | NR | NR | 0 | NR | NR | NR | 0 | NR | No | No
Pienimaki 1996 ^599^ | 42 | 42 (31–53) | 59.5 | NR | NR | 0 | 0 | 0 | 0 | NR | NR | No | No
Verhaar 1995 ^607^ | 106 | 43 | 47 | 8 | NR | 0 | NR | 0 | 0 | NR | NR | No | No
Haker 1993 ^611^ | 76 | 47.8 | 25 | 5 (1–36) | NR | 0 | NR | 0 | 0 | NR | NR | No | No
Halle 1986 ^606^ | 48 | (20–59) | 54.1 | NR | NR | NR | NR | 0 | 0 | NR | NR | No | No
Saartok 1986 ^610^ | 21 | 45 | 19.0 | NR | NR | NR | NR | NR | NR | NR | NR | No | No
Brattberg 1983 ^608^ | 63 | (30–60) | 36.5 | NR | NR | NR | NR | NR | NR | NR | NR | No | No

NR = not reported

Some of the studies excluded patients with various comorbidities, indicated by a zero under that comorbidity.This limits the generalizability of the studies, as comorbidities are not usually exclusion criteria for the treatments discussed in this section.

Patient employment characteristics are incompletely reported in these studies (Table 317).Therefore, the extent to which the employment characteristics of these patients may be generalized to the overall epicondylitis patient population cannot be determined from the information available.

Table 317. Generalizability: occupations

Study | Number of patients | % Patients employed | % Patients on Workers' compensation | % Patients retired | % Patients homemakers | Reported occupations
Hay 1999 ^609^ | 182 | 62.6 | NR | NR | NR | NR
Pienimaki 1996 ^599^ | 42 | 30.9 | NR | NR | NR | NR
Verhaar 1995 ^607^ | 106 | NR | NR | NR | NR | NR
Haker 1993 ^611^ | 76 | NR | NR | NR | NR | NR
Halle 1986 ^606^ | 48 | NR | NR | 6.3 | 29.1 | 33.3% blue collar workers
| | | | | | 31.3% white collar workers
Saartok 1986 ^610^ | 21 | NR | NR | NR | NR | NR
Brattberg 1983 ^608^ | 63 | NR | NR | NR | NR | NR

NR = not reported

#### Results

##### NSAIDs compared to corticosteroid injections

Two randomized controlled trials of a total of 203 patients compared oral NSAIDs (naproxen) to corticosteroid injections (methylprednisolone and betamethasone).Both studies measured pain and function.In addition, they rated the overall success of the treatments.One of the studies reported no statistically significant difference in outcomes between the study groups, while the other study reported that the patients treated with corticosteroid injections had statistically statistically significantly better outcomes than did patients treated with oral NSAIDs or with placebo.The patient-oriented outcomes reported by these two studies are shown in Table 318 and summarized in Table 319.The study that reported no significant difference in outcomes (Saartok 1986) only had a total of 21 patients, and thus may have been too small for the difference in outcomes between its patient groups to reach statistical significance.We calculated that this study could have detected a 36% or greater difference between its groups.The fact that the Hay trial found a larger difference than this suggests that the results of these two trials are truly different, and not simply the result of a lack of statistical power on the part of the Saartok trial.As discussed previously, it is possible that the Hay trial was confounded by co-interventions.

Table 318. Results of treating epicondylitis with NSAIDs as compared to steroid injections

Study | Number of patients | Global assessment- patient rated categories | Statistical significance of difference between groups
Hay 1999 ^609^ | 52 corticosteroid injection | Corticosteroid injections: 22 complete recovery, 26 improvement, 3 no change, 1 worse, 0 much worse | Mann-Whitney U test
| 53 NSAIDS | NSAIDs: 3 complete recovery, 27 improvement, 16 no change, 7 worse, 0 much worse | p <0.05 injections compared to NSAID and injections compared to placebo
| 56 placebo | Placebo: 2 complete recovery, 26 improvement, 23 no change, 4 worse, 1 much worse
Saartok 1986 ^610^ | 11Corticosteroid injection | Corticosteroid injections: 1 much improved, 5 improved, 2 no change, 4 worse, 0 much worse | Mann-Whitney U test
| 10 NSAIDs | NSAIDs: 0 much improved, 6 improved, 3 no change, 1 worse, 0 much worse | NS

Table 319. Success of treating epicondylitis with NSAIDs as compared to steroid injections

Study | Number of patients | Time of followup | Which treatment was more successful? | Was the difference statistically significant? | Minimal difference the study had the power to detect | Effect size d (95% CI)^a^
Hay 1999 ^609^ | 52 steroid injection | One month | Injection of corticosteroids | Yes | NA | Steroids vs. placebo: 0.57 (0.18 to 0.95)
| 53 oral NSAIDs | | | | | NSAIDs vs. placebo: -0.08 (-0.46 to 0.30)
| 56 placebo | | | | | Steroids vs. NSAIDs: 1.31 (0.88 to 1.73)
Saartok 1986 ^610^ | 11 steroid injection | 2 weeks | No difference | No | 36% | 0.54 (-0.33 to 1.42)
| 10 oral NSAIDs

a calculated by ECRI

NSAID = non steroidal anti-inflammatory drug

##### Acupuncture compared to corticosteroid injections

One controlled trial of 63 patients compared acupuncture treatment to injections of corticosteroids.This trial reported only patient-rated pain.Patients were followed for different times after the treatment, with a mean followup time of 5.8 months, and a range of 2 to 9 months.Statistical tests performed by the authors indicated that acupunture treatment was statistically significantly more successful at relieving pain than was corticosteroid treatment.The data are summarized in Table 320.The calculated effect size agrees with the statistical tests performed by the authors.However, when interpreting the results of this trial it must be kept in mind that all of the patients had been found to be unresponsive to treatment with corticosteroid injections before being enrolled in the trial.

Table 320. Success of treating epicondylitis with acupuncture as compared to steroid injections

Study | Number of patients | Pain-patient rated categories | Statistical significance of difference between groups | Effect size d (95% CI)^a^
Brattberg 1983 ^608^ | 34 acupuncture | Acupuncture:8 no pain, 9 slight pain, 4 better, 3 improved, 10 unchanged, 0 worse | Chi-squared test | -0.59 (-1.09 to -0.08)
| 26 corticosteroid injection | Injections:2 no pain, 6 slight pain, 0 better, 8 improved, 6 unchanged, 4 worse | P<0.05
| | | Statistically significant

a calculated by ECRI

##### Physiotherapy compared to corticosteroid injections

One randomized controlled trial of 106 patients compared a combination of exercises and deep friction massage designed to improve mobility of the elbow to injections of corticosteroids.The reported results for the other patient-oriented outcomes are shown in Table 321 and summarized in Table 322.Manipulation and massage were found to be statistically significantly less effective than are injections of corticosteroids at treating pain and are rated as less effective by patients.Statistically significantly more patients treated with corticosteroid injections returned to work, but the effect size calculated for this outcome did not reach statistical significance.

Table 321. Results of treating epicondylitis with physiotherapy as compared to steroid injections

Study | Number of patients | Outcome measured | Outcome measurement At 1.5 months | Statistical significance of difference between groups
Verhaar 1995 ^607^ | 52 corticosteroid injection | Global assessment - patient rated categories | corticosteroid injection:18 excellent, 18 good, 10 moderate, 6 poor | Chi-squared test
| 51 Manipulations and massage | | Manipulations and massage:1 excellent, 12 good, 15 moderate, 23 poor | P<0.001
| | Pain - patient rated categories | Injection:22 absent, 20 slight, 9 moderate,1 severe | Chi-squared test
| | | Manipulations and massage:3 absent, 19 slight, 22 moderate, 7 poor | p <0.001
| | Return to work | Injection:9 resumed work, 15 still working, 9 unable to work, 19 did not work and still do not | Chi-squared test
| | | Manipulations and massage:4 resumed work, 14 still working, 13 unable to work, 20 did not work and still do not | p <0.05

Table 322. Success of treating epicondylitis with manipulations compared to injections of steroids

Study | Number of patients | Time of followup | Which treatment was more successful? | Was the difference statistically significant? | Effect size d (95% CI)^a^
Verhaar 1995 ^607^ | 52 steroid injection | 1.5 months | Injections of corticosteroids | Yes (Chi-squared test) | Global assessment: 1.15 (0.74 to 1.56)
| 51 manipulation | | | | Pain:1.02 (0.61 to 1.43)
| | | | | Return to work:0.10 (-0.29 to 0.48)

a calculated by ECRI

##### Bracing or immobilization compared to corticosteroid injections

One randomized controlled trial of 76 patients compared forearm elbow bracing, immobilization of the elbow, and corticosteroid injections.The authors report that after two weeks, the group treated with the corticosteroid injections had a statistically significantly better result for the outcome patient-rated pain than did the other two treatment groups.At longer followup times, however, the authors report there was no statistically significant difference between the treatment groups.The data from the longer followup times were not reported.The calculated effect size agrees with the statistical tests performed by the authors.The data are summarized in Table 323.

Table 323. Results of bracing, injections, and splinting compared

Study | Number of patients | Patient-rated improvement in pain | Statistical signficance of the difference between groups | Effect size d (95% CI)^a^
Haker 1993 ^611^ | 17 bracing | At 0.5 months, | Chi-squared test | Bracing: 1.04 (0.36 to 1.71)
| 19 corticosteroid injection | bracing | Injections vs. bracing | Splinting: 1.19 (0.51 to 1.86)
| 19 immobilization / splinting | 1 excellent, 1 good, 4 improved, 3 somewhat improved, 8 no change | p = 0.000055
| | injections | Injections vs. splinting
| | 3 excellent, 10 good, 2 improved, 3 somewhat improved, 1 no change | p = 0.000427
| | splinting | Splinting vs. bracing
| | 0 excellent, 1 good, 6 improved, 6 somewhat improved, 6 no change | p = 0.000001
| | | Injections are most effective

a calculated by ECRI using corticosteroid injections as the comparison group

##### TENS, ultrasound, phonophoresis, and injections of corticosteroids compared

One randomized controlled trial of 48 patients compared four different treatments for epicondylitis:TENS, ultrasound, phonophoresis of hydrocortisone, and injections of corticosteroids.This study measured patient-reported pain in several ways, and combined the results into a summary percentage.The authors report that there was no statistically significant difference in outcomes between any of the treatment groups.The calculated effect sizes agree with the results of the authors' statistical tests.However, the study was small and this may be the reason why the difference in outcomes between the groups did not reach statistical significance.The data reported by this study are shown in Table 324 and summarized in Table 325.

Table 324. Results of comparing injections, TENS, phonophoresis, and ultrasound

Study | Number of patients | Global outcome | Statistical significance of difference between groups
Halle1986 ^606^ | 12 Corticosteroid injection | Corticosteroid injection:63% improved, 25% unchanged, 12% worse | Kruskal-Wallas ANOVA test
| 12 phonphoresis | phonophoresis:65% improved, 12% unchanged, 23% worse | NS
| 12 TENS | TENS:56% improved, 23% unchanged, 21% worse
| 12 ultrasound | ultrasound:69% improved, 12% unchanged, 19% worse

Table 325. The study by Halle 1986 lacks statistical power

Study | Number of patients | Followup time | Which treatment was most effective? | Was the difference statistically significant? | Minimal difference between groups the study had the power to detect | Effect size d (95% CI)^a^
Halle 1986 ^606^ | 12 injections | 0.13 month | Corticosteroid injections | No | 31% | Phonophoresis: -0.67 (-1.49 to 0.15)
| 12 phonophoresis | | | | | TENS:-0.02 (-0.82 to 0.78)
| 12 ultrasound | | | | | Ultrasound:-0.53 (-1.35 to 0.28)
| 12 TENS

a calculated by ECRI using injections as the control group

##### Physiotherapy compared to ultrasound

One randomized controlled trial of 42 patients compared ultrasound treatment to a regimen of stretching, strengthening, and conditioning exercises.This study reported only one patient-oriented outcome, return to work.The reported results for this outcome are shown in Table 326 and summarized in Table 327.The study may be too small (n = 39) for its results on patients returning to work to have reached statistical significance.

Table 326. Results of physiotherapy compared to ultrasound

Study | Number of patients | Number of patients not working | Statistical significance of difference between groups
Pienimaki 1996 ^599^ | 19 ultrasound | 6 ultrasound | Chi-squared test
| 20 Physiotherapy | 2 physiotherapy | p = 0.355

Table 327. Physiotherapy compared to ultrasound

Study | Number of patients | Followup time | Which treatment resulted in more patients returning to work? | Was the difference statistically significant? | Minimal difference between groups the study had the power to detect | Effect size d (95% CI)^a^
Pienimaki 1996 ^599^ | 19 ultrasound | 2 months | Physiotherapy | No | 31% | 0.77 (-0.20 to 1.74)
| 20 physiotherapy

a calculated by ECRI

#### Conclusions

One randomized controlled trial of 106 patients reported that patients treated with injections of corticosteroids had better outcomes than did patients treated with manipulations and deep friction massage.One randomized controlled trial of 76 patients reported that patients treated with injections of corticosteroids had better outcomes than did patients treated with braces or immobilization.

Two randomized controlled trials of a total of 203 patients compared oral NSAIDs to injections of corticosteroids.One study did not find a statistically significant difference between the groups.The other study reported that patients treated with injections of corticosteroids had better outcomes than did the patients treated with oral NSAIDs.This study may have been confounded by co-interventions administered to the patients in addition to their allocated treatment.

One randomized controlled trial of 63 patients reported that patients treated with acupuncture had better outcomes than patients treated with corticosteroid injections.However, this study included only patients previously found to be unresponsive to injections of corticosteroids.

Two randomized controlled trials, one comparing TENS, ultrasound, phonophoresis, and injections of steroids, the other comparing physical therapy to ultrasound, reported no statistically significant differences between-treatment groups.However, both trials may have been too small to be able to have detected clinically meaningful differences between-treatment groups.

Thirty-eight randomized controlled trials, four randomized crossover trials, and eight controlled trials of a total of 3147 patients evaluated eighteen different types of treatments for epicondylitis and reported 73 different outcomes.The studies tend to be small, and there are too few studies addressing each treatment to allow any definitive evidence-based conclusions to be made.Two tentative conclusions can be reached:Laser therapy does not appear to be an effective treatment for epicondylitis, and patients with epicondylitis who were treated with acupuncture had better global outcomes and greater pain relief than patients given sham acupuncture.

### Question #4. Is there a correlation between specific clinical findings and specific treatment outcomes among patients with epicondylitis?

In addressing this question, we consider whether published literature suggests that there are clinical findings that predict positive or negative outcomes after treatment for epicondylitis.The studies we considered all attempted to identify predictors by using regression techniques or by comparing outcomes in different groups of patients with different pre-treatment clinical findings.

#### Excluded studies

As discussed in the Methods section, we retrieved articles identified by our literature searches according to certain a priori criteria.However, not all of the retrieved studies met our more specific inclusion criteria for this question.These latter studies, and the reason we did not consider them for this question are shown in Table 328.

Table 328. Excluded studies

Author | Reason for exclusion
Seegenschmiedt et al. 1998 ^628^ | Incomplete description of multivariate analysis (did not describe all variables and unclear description of some variables)
Gabel and Morrey 1995 ^555^ | Stratified study that did not examine any correlations that were also examined by at least two other studies
Verhaar et al. 1993 ^559^ | Stratified study that did not examine any correlations that were also examined by at least two other studies

#### Evidence base

After these exclusions, there remained three studies with a total of 160 patients.

#### Study quality

The criteria used to evaluate study quality were identical to those described in Question 4 for carpal tunnel syndrome.Table 329 shows relevant quality characteristics of studies that met the inclusion criteria for this question.All studies performed some type of multiple regression analysis.Two were prospective and one was retrospective.

Table 329. Study quality

Author/year | Prospective? | Methods used to identify predictor variables
Kurvers et al. 1995 ^556^ | No | Multiple regression
Stratford et al. 1989 ^621^ | Yes | Multiple regression
Gerberich et al. 1985 ^629^ | Yes | Multiple logistic regression

#### Results

Table 330 shows the relationship of specific clinical findings to treatment outcomes in those studies that used regression to identify predictor variables.There are three such studies with a total of 160 patients.Also presented in this table are non-clinical variables (e.g. age, gender) to show all of the variables used in each multiple regression (the variables relevant to the present question are bolded in Table 330).

Table 330. Relationship between specific clinical findings and treatment outcomes among patients with Epicondylitis (multiple regression analysis)

Author/year | N | Treatment | Outcomes | Variables used in multiple regression
| | | | Age | Gender | Hobbies | Comorbidity (ulnar neuritis) | Duration of symptoms | Functional limitations | Site of pain | Severity of pain | Grip strength | Timing of onset (acute or gradual) | Compliance with rest | Use of hydrocortisone cream | Number of treatments
Kurvers et al. 1995 ^556^ | 38 (ME) | Surgery | Global outcome (level of symptoms) | NS | NS | NS | Sig | - | - | - | - | - | NS | - | - | -
Stratford et al. 1989 ^621^ | 40 (LE) | Ultrasound | Global outcome (success/failure) | NS | NS | - | - | NS | - | Sig | - | NS | - | NS | - | -
Gerberich et al. 1985 ^629^ | 82 (LE) | Ultrasound | Global outcome (improvement) | NS | NS | - | - | NS | NS | - | Sig | - | - | - | NS | Sig (males)
| | | | | | | | | | | | | | | | NS (females)

LE - Lateral epicondylitis

ME - Medial epicondylitis

a Variables in boldface indicate clinical findings

Only one study reported on each combination of outcome and clinical finding.All three studies reported correlations between variables and global assessment of the success of the treatment.None of the studies reported correlation coefficients or p-values.

Stratford et al. included only two clinical findings in their multiple regression analysis:grip strength and site of pain. ^621^ They found that grip strength did not correlate with treatment outcome, but site of pain did.Patients with pain over the origin of the extensor carpi radialis longus (ECRL) had better outcomes than did patients with pain elsewhere.Patients with pain over the origin of the extensor carpi radialis brevis (ECRB) had poorer outcomes than did patients with pain elsewhere.

Gerberich et al. incorporated only two clinical findings into their analysis:severity of pain before treatment, and degree of functional limitations before treatment. ^629^ They reported no statistically significant correlation between the degree of functional limitations and success of the treatment, but found a correlation between severity of pain and success of the treatment.Patients with severe pain had poorer outcomes than patients with milder pain.

Kurvers et al. included only one clinical finding in their analysis:timing of the onset of symptoms (acute or gradual). ^556^ They found no statistically significant correlation between the timing of the onset of symptoms and the success of the treatment.

#### Conclusions

None of the three studies that addressed this question evaluated the relationship between the same combination of clinical findings, outcomes, and treatment type.One study reported that the site of pain could be used to predict response to treatment, one reported that the severity of pain could be used to predict response to treatment, and one reported that the timing of onset of symptoms (acute vs. gradual) did not correlate with the response to treatment.Because only one study addressed each outcome, it is difficult to reach firm evidence-based conclusions from the available data.

### Question #5. Is there a correlation between duration of symptoms and specific treatment outcomes among patients with epicondylitis?

In addressing this question, we consider whether published literature suggests that duration of symptoms predicts positive or negative outcomes after treatment for carpal tunnel syndrome.The studies we considered all attempted to identify predictors by using regression techniques or by comparing outcomes in different groups of patients with different duration of symptoms.

#### Excluded studies

No studies were excluded due to failure to meet the question-specific criteria.

#### Evidence base

Seven studies with a total of 319 patients addressed this question.

#### Study quality

The criteria used to evaluate study quality were identical to those described in Question 4 for carpal tunnel syndrome.Seven studies were identified that reported treatment outcomes stratified or analyzed by duration of symptoms.These studies are listed in Table 331.Four studies (two prospective and two retrospective) performed multiple regression to identify predictor variables.The remaining three studies (one prospective and two retrospective) used stratification or alternative statistical comparisons.

Table 332. Relationship between duration of symptoms and treatment outcomes among patients with Epicondylitis (multiple regression analysis)

Author/year | N | Treatment | Outcomes | Mean duration of symptoms (range) | Statistical significance (duration associated with better outcome) | Other variables examined
Seegenschmiedt and Keilholz 1998 ^628^ | 104 (LE and ME) | Radiotherapy | Global outcome (Response to treatment) | 15 months (6–86 months) | Sig (shorter duration - <12 months) | Immobilization in plaster (sig), other variables not reported
Kurvers et al. 1995 ^556^ | 38 (ME) | Surgery | Global outcome (level of symptoms) | 12 months (6–30 months) | NS | Age, gender, timing of symptom onset, comorbid conditions, hobbies
Stratford et al. 1989 ^621^ | 40 (LE) | Ultrasound | Global outcome (success/failure) | NR | NS | Age, gender, compliance, grip strength, site of pain
Gerberich et al. 1985 ^629^ | 82 (LE) | Ultrasound | Global outcome (improvement) | 9.8 months | NS | Age, gender, severity of pain, degree of functional limitations, use of hydrocortisone cream, number of treatments

LE - Lateral epicondylitis

ME - Medial epicondylitis

NS - Not signficant

Table 331. Study quality

Author/year | Prospective? | Methods used to identify predictor variables
Bankes and Jessop1998 ^553^ | No | Not described
Seegenschmiedt 1998 ^628^ | No | Multiple regression
Kurvers 1995 ^556^ | No | Multiple regression
Newey and Pattterson1994 ^558^ | No | Stratification
Verhaar 1993 ^559^ | Yes | chi-square test for linear trends
Stratford 1989 ^621^ | Yes | Multiple regression
Gerberich 1985 ^629^ | Yes | Multiple logistic regression

#### Results

The treatments and outcomes used in studies that performed a multiple regression are shown inTable 332.Two studies using ultrasound therapy found no statistically significant correlation between duration of symptoms before treatment and response to treatment with ultrasound.One surgical trial also found no statistically significant correlation between duration of symptoms and treatment outcome.The remaining trial was the largest trial and the only trial using radiotherapy, and this trial found a significant correlation between shorter duration of symptoms and a better treatment outcome.

Three studies used stratification or statistical techniques that did not control for the effects of other predictor variables (Table 333) All three studies evaluated surgical treatments.Two studies (one prospective, one retrospective) reported no statistically significant correlation between duration of symptoms and success of surgical treatment, while one retrospective study reported a significant correlation between shorter duration of symptoms and a better treatment outcome.

Table 333. The relationship between duration of symptoms and treatment outcomes among patients with Epicondylitis (stratification or univariate statistical comparisons)

Author/ year | N | Treatment | Outcomes | Mean duration of symptoms (range) | Statistical significance (duration associated with better outcome)
Bankes and Jessop 1998 ^553^ | 20 | Surgery | Global outcome (patient improvement) | 32.2 (11–126) | NS
Newey and Pattterson 1994 ^558^ | 27 | Surgery | Global outcome (pain relief) | 32.5 (8–108) | Sig (shorter duration)
Verhaar 1993 ^559^ | 57 | Surgery | Global outcome (patient satisfaction) | NR | NS

LE - Lateral epicondylitis

ME - Medial epicondylitis

NS - Not signficant

#### Conclusions

Seven studies examined whether duration of symptoms correlated with treatment outcomes.These studies employed three different treatments, so this correlation might be altered if these treatments have differential success rates.Only one of the four studies that employed multiple regression found a statistically significant relationship between symptom duration and outcomes, and this study was retrospective.One of three studies that stratified patients according to their duration of symptoms found a statistically significant correlation with treatment outcomes.This study was also retrospective.Consequently, although there is some evidence to suggest a relationship, it is contradictory and not strong.Two prospective studies that employed multiple regression did not find such a relationship.Both were of patients who had received ultrasound.These latter data seem to suggest that there is not a strong correlation between symptom duration and treatment outcome.However, currently available evidence about use of ultrasound in patients with epicondylitis or de Quervain's disease does not allow firm evidence-base conclusions, and the effectiveness of ultrasound for carpal tunnel is suspect.Thus, lack of treatment effectiveness could obscure potential relationships between symptom duration and treatment-related outcomes.Therefore, one cannot draw firm evidence-based conclusions from currently available data.

### Question #6. Is there a relationship between patient characteristics and specific treatment outcomes among patients with epicondylitis?

In addressing this question, we consider whether published literature suggests that there are demographic variables that predict positive or negative outcomes after treatment for carpal tunnel syndrome.The studies we considered all attempted to identify predictors by using regression techniques or by comparing outcomes in different groups of patients with different pre-treatment demographic characteristics.

#### Excluded studies

As discussed in the Methods section, we retrieved articles identified by our literature searches according to certain a priori criteria.However, not all of the retrieved studies met our more specific inclusion criteria for this question.These latter studies, and the reason we did not consider them for this question are shown in Table 334.

Table 334. Excluded studies

Author | Reason for exclusion
Seegenschmiedt et al. 1998 ^628^ | Study did not report whether demographic variables were included in the multiple regression analysis
O'Neil 1980 ^567^ | Stratified study that conducted a demographic variable/outcome comparison not performed by any other study

#### Evidence base

After these exclusions, there remained six studies with 277 patients.

#### Study quality

The criteria used to evaluate study quality were identical to those described for Question 4 for carpal tunnel syndrome.Table 335 shows the studies that met the inclusion criteria for this question.Three studies (two prospective and one retrospective) performed multiple regression to identify predictor variables.The remaining three studies (one prospective and two retrospective) performed stratification or alternative statistical comparisons.

Table 335. Study quality

Author/year | Prospective? | Methods used to identify predictor variables
Gabel and Morrey1995 ^555^ | No | Statistical analysis (method not described)
Kurvers 1995 ^556^ | No | Multiple regression
Newey and Pattterson1994 ^558^ | No | Stratification
Verhaar 1993 ^559^ | Yes | chi-square test for linear trends
Stratford 1989 ^621^ | Yes | Multiple regression
Gerberich 1985 ^629^ | Yes | Multiple logistic regression

#### Results

Three studies that addressed this question performed multiple regression to identify predictor variables (Table 336).Two of the studies treated patients with ultrasound and one used surgical treatment.None of the three studies found a statistically significant correlation between age and outcome, or gender and outcome.One study reported that there was no statistically significant correlation between patients with hobbies involving knitting or needlework and outcomes.The only study that examined co-morbidities reported that patients with coexistent ulnar neuritis had a poorer outcome after surgery than did patients without ulnar neuritis.

Table 336. Relationship between patient characteristics and treatment outcomes among patients with Epicondylitis (multiple regression analysis)

Author/ year | N | Treatment | Outcomes | Variables used in multiple regression
| | | | Age^a^ | Gender | Hobbies | Comorbidity (ulnar neuritis) | Duration of symptoms | Functional limitations | Site of pain | Severity of pain | Grip strength | Timing of onset (acute or gradual) | Compliance with rest | Use of hydrocortisone cream | Number of treatments
Kurvers et al. 1995 ^556^ | 38 (ME) | Surgery | Global outcome (response to treatment) | NS | NS | NS | Sig | - | - | - | - | - | NS | - | - | -
Stratford et al. 1989 ^621^ | 40 (LE) | Ultrasound | Global outcome (success/failure) | NS | NS | - | - | NS | - | Sig | - | NS | - | NS | - | -
Gerberich et al. 1985 ^629^ | 82 (LE) | Ultrasound | Global outcome (improvement) | NS | NS | - | - | NS | NS | - | Sig | - | - | - | NS | Sig (males)
| | | | | | | | | | | | | | | | NS (females)

LE - Lateral epicondylitis

ME - Medial epicondylitis

NS - Not significant

a Variable in boldface indicate patient characteristics

Three other studies performed stratification or statistical comparisons that did not control for the effects of other predictor variables (Table 337).All studies evaluated surgical treatments.Age was the only relevant variable reported by all of these studies, and none found a statistically significant correlation between age and treatment outcome.

Table 337. The relationship between duration of symptoms and treatment outcomes among patients with Epicondylitis (stratification or univariate statistical comparisons)

Author/year | N | Treatment | Outcome | Age
Gabel and Morrey 1995 ^555^ | 26 (LE) | Surgery | Global outcome (Excellent to poor) | NS
Newey and Patterson 1994 ^558^ | 28 (LE) | Surgery | Global outcome (Pain relief) | NS
Verhaar 1993 ^559^ | 63 (LE) | Surgery | Global outcome (Level of satisfaction) | NS

LE - Lateral epicondylitis

NS - Not significant

#### Conclusions

Six studies reported data that addressed this question.Three of them used multiple regression to identify predictor variables.All three studies found no statistically significant correlation between gender or age and response to treatment.One study found no such correlation between certain hobbies and response to treatment.The only study that examined co-morbidities reported that patients with co-existant ulnar neuropathy had significantly poorer outcomes than patients without ulnar neuropathy.However, it is difficult to reach evidence-based conclusions from the results of a single study.

### Question #7: What are the surgical and nonsurgical costs or charges for treatment of epicondylitis?

According to Medicare Provider Analysis and Review (MEDPAR), average total charges per patient for the DRG (diagnosis-related group) of major shoulder/elbow procedures with comorbidities or complications are $9,008.94 (calculated by dividing total charges by number of discharges).For the DRG shoulder, elbow or forearm procedures, except major joint procedures, without comorbidities or complications, average total charges per patient are $7729.16.The Median Costs for Hospital Outpatient Services Dataset contains median costs for services that are reimbursed under Medicare for the hospital outpatient prospective payment system.The reported median cost for strapping of the elbow or wrist is $62.61 (cost of open release was not reported by this database).

### Question #8. For persons who have had surgery to treat epicondylitis, what are the appropriate methods for preventing the recurrence of symptoms, and how does this vary depending on subject characteristics or other underlying health problems?

This question distinguishes between symptom recurrence and continued symptoms after failed treatment.Rates of recurrence, possible reasons for recurrence, and recommended strategies to avoid recurrence have not been addressed by the available literature.In the absence of controlled trials, no analysis may be performed and no conclusions may be drawn

### Question #9: What instruments, if any, can accurately assess functional limitations in an individual with epicondylitis?

We address this question in the same manner that we addressed Question 9, Carpal Tunnel Syndrome.The reader is referred to that section of this evidence report for detail.Briefly, we define an instrument that can accurately assess functional limitations in an individual with epicondylitis as one that has test-retest reliability, internal reliability, content validity, concurrent validity, predictive validity, and responds to treatment.

#### Evidence base

Three studies with a total of 122 patients met the inclusion criteria (see the section Inclusion Criteria).These studies are listed in Table 338.The functional assessment instruments evaluated by them are listed in Table 339.

Table 338. Trials of functional assessment instruments that met the inclusion criteria

Study | Instruments evaluated^a^ | N subjects | Outcome measurements
Overend 1999 ^315^ | PRFEQ | 50 | Validity
| | | Test-retest reliability
Stratford 1993 ^630^ | F-VAS | 40 | Validity
| | | Response to treatment
Stratford 1987 ^631^ | F-VAS | 32 | Validity
| | | Response to treatment
| | | Test-retest reliability

a The full names of the instruments and descriptions of the instruments are given inTable 339.

Table 339. Instruments evaluated to measure functional limitations associated with epicondylitis

Instrument | Abbreviation | First described by | Scoring system | Subjects covered | Extent of use^a^
Patient-rated forearm evaluation questionnaire | PREFQ | Overend 1999 ^632^ | Functional categories | Common activities of daily living | Not widely used
Functional visual analog scale | F-VAS | Stratford 1987 ^631^ | VAS | Not described | Not widely used

a a search of Medline for the assessment instrument found that there were fewer than 3 studies reporting the use of each of the instruments

#### Study quality

##### Internal validity

Studies evaluating instruments need not include a separate control group, because each patient acts as his/her own control.All of the studies included in this section are single-arm prospective cohort studies.Factors relating to the quality of the studies are shown in Table 340.None of the studies administered and scored the instruments with evaluators who were blinded to the identity, history, and other test scores of the patients.Studies that did not use blinded evaluators may be subject to bias.

Table 340. Details of study design

Study | Number of patients | Number of centers | Funded by a for-profit agency? | Study design | Prospective | Blinding | % Attrition | Intent to treat analysis | % Compliance
Overend 1999 ^632^ | 50 | 1 | No | Cohort | Yes | No | 6 | No | NA
Stratford 1993 ^630^ | 40 | 1 | NR | Cohort | Yes | No | 0 | Yes | NA
Stratford 1987 ^631^ | 32 | 1 | No | Cohort | Yes | No | 0 | Yes | NA

NA = not applicable

##### Generalizability

An important factor in evaluating assessment instruments is the patient group.In order to accurately evaluate the instrument, it is important that the test group be similar to the patients that the instrument will be used to evaluate in clinical practice.Details of the patient groups are shown in Table 341.The mean ages and gender composition of the patient groups are similar to that reported in epidemiology studies of epicondylitis (see the Introduction).None of the studies reported on the presence of co-morbid conditions that may have contributed to functional limitations.None of the studies reported any information as to the occupations or employment status of the patients.

Table 341. Study generalizability: patient characteristics

Study | Number of patinets | Mean age and range | % female | Duration of condition mean and range months | % Patients with diabetes | % Patients with arthritis | % Patients with prevous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neruopathy | % Patients pregnant | % Patients on kidney dialysis | Did the study exclude patients with severe disease? | Did the study exclude patients with mild disease?
Overend 1999 ^632^ | 50 | 45 | 48.9 | NR | NR | NR | NR | NR | NR | NR | NR | No | No
Stratford 1993 ^630^ | 40 | 43 | 50 | 4.2 | NR | NR | NR | 0 | NR | NR | NR | No | No
Stratford 1987 ^631^ | 32 | 44.9 (32–61) | NR | 3.7 (0–12) | NR | NR | NR | NR | NR | NR | NR | No | No

NR = not reported

#### Results

##### Test-retest reliability

Both instruments (F-VAS and PRFEQ) are reported to give consistent results when administered to the same subjects on different days (Table 342).

Table 342. Results of test-retest reliability tests

Study | Number of patients | Tests evaluated | Time between test administrations | Type of statistical comparison being made | Was the instrument reliable?
Overend 1999 ^632^ | 50 | PRFEQ | NR | Correlation coefficient r = 0.89 | Yes
Stratford 1987 ^631^ | 32 | F-VAS | 4 days | Correlation coefficient r = 0.85 | Yes

NR = not reported

##### Internal reliability

None of the included studies reported data relevant to this aspect of instrument evaluation.

##### Content validity

None of the included studies reported data that addressed this aspect of validity.

##### Response to treatment

Stratford reported that scores on the F-VAS increase as patients are successfully treated for epicondylitis (Table 343).

Table 343. Results of response to treatment tests

Study | Number of patients | Test evaluated | Treatment | Time of testing months | Effect size Hedges' d (95% CI)^a^ | Was the instrument responsive to treatment?
Stratford 1993 ^630^ | 40 | F-VAS | Not reported | 1 | 0.97 (0.22 to 1.72) | Yes
Stratford 1987 ^631^ | 32 | F-VAS | Ultrasound | 1.5 | 1.60 (1.04 to 2.16) | Yes

a calculated by ECRI

##### Concurrent validity

All three trials compared the scores on the assessment instruments to pain-free hand grip strength, as is shown in Table 344.A moderate correlationm (r = 0.36) between hand grip strength and the results of the PRFEQ was reported.Stratford 1993 and Stratford 1987 reported the scores on the F-VAS correlated well with hand grip strength.

Table 344. Results of validity tests

Study | Number of patients | Test evaluated | Type of statistical comparison being made | Validated against | Was the instrument valid by this measurement?
Overend 1999 ^632^ | 50 | PRFEQ | Intraclass correlation coefficient r = -0.36 | Hand grip strength | Yes, but r is low
Stratford 1993 ^630^ | 40 | F-VAS | Interclass correlation coefficient r = 0.53 | Hand grip strength | Yes
Stratford 1987 ^631^ | 32 | F-VAS | Interclass correlation coefficient r = 0.66 | Hand grip strength | Yes

The instruments were not validated against any other measurements of hand/arm function.

##### Predictive validity

None of the included studies reported data relevant to this aspect of instrument evaluation.

#### Conclusion

Three studies evaluated two different instruments as ways to measure functional limitations of patients with epicondylitis.The results of the studies are summarized in Table 345.Neither assessment instrument was shown to be a useful instrument for evaluating functional limitations in persons with epicondylitis.However, it is difficult to reach firm evidence-based conclusions about the instruments evaluated in this report due to the limited evidence base.

Table 345. Utility of assessment instruments for evaluating functional limitations associated with epicondylitis

Instrument | Is the instrument Valid? | Responsive to treatment? | Reliable? | Strength of Evidence
Patient-rated forearm evaluation questionnaire | No | NR | Yes | One study of 50 patients
Functional visual analog scale | Yes | Yes | Yes | Two studies of 72 patients by the same group

NR = not reported

### Question #10: What are the functional limitations for an individual with epicondylitis before treatment?

This question addresses the functional limitations of individuals before receiving conservative or surgical treatment for epicondylitis.Our objective is to catalogue these limitations, and not to address the effectiveness of these treatments.We address the effectiveness of conservative and surgical treatments in Question 3. The available literature governs our approach to the present question.Hence, we consider functional status rather than functional limitations, because no published studies specifically addressed the latter.In addition, the only available data operationally defines functional status in terms of scores on certain written tests.Therefore, we also address functional status in these terms.The validity and reliability of these written tests is discussed in Question 9.Study inclusion criteria are described under Methods.

#### Excluded studies

As discussed in the Methods section, we retrieved articles identified by our literature searches according to certain a priori criteria.However, not all of the retrieved studies met our more specific inclusion criteria for this question.These latter studies, and the reason we did not consider them for this question are shown in Table 346.

Table 346. Excluded studies

Author | Reason for exclusion
Pienimaki and Vanharanta 1998 ^544^ | Study reported that patients received prior treatment

#### Evidence base

Two studies (with a total of 82 patients) remained that addressed this question after the above exclusion.

#### Internal validity

Aspects of study quality that are most relevant to the present question are shown in Table 347.Because we are cataloging functional status rather than using it to determine treatment effectiveness, randomization and the use of control groups are not of paramount importance here.Therefore, Table 347 does not depict these aspects of study design.However, the following variables are important:attrition rates, whether the trial was prospective, and whether the raters of functional status (in this case the patients) were blinded to the treatment the patient received.Attrition was low (6%) or non-existent in the two included studies.Both were unblinded prospective case series.Because it is difficult to blind patients to the treatment received, we are considering unblinded studies to be of acceptable quality for this question.

Table 347. Study quality

Author | Number of patients | Number of centers | Funded by a for-profit agency? | Prospective | Blinding | % Attrition | Intent to treat analysis | % Compliance
Overend 1999 ^632^ | 50 | 1 | No | Yes | No | 6 | No | NA
Stratford 1987 ^631^ | 32 | 1 | No | Yes | No | 0 | Yes | NA

NA - Not applicable

#### Generalizability

Selected patient characteristics are presented in Table 348.Both studies reported mean age of patients and percent female, one study reported duration of symptoms, and no studies reported comorbidities or severity of disease.Mean age and percent female patients were consistent with the numbers reported by epidemiologic studies (see Introduction section, epicondylitis, subheading epidemiology).

Table 348. Patient characteristics

Author | Number of patients | Mean age (range) | % female | Duration of condition (range) | % Patients with diabetes | % Patients with arthritis | % Patients with prevous relevant injuries | % Patients with other relevant nerve impingement conditons | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Did the study exclude patients with severe disease? | Did the study exclude patients with mild disease?
Overend 1999 ^632^ | 50 | 45 | 48.9 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Stratford1987 ^631^ | 32 | 44.9 (32–61) | 50 | Mean:111 days (3–364) | NR | NR | NR | NR | NR | NR | NR | NR | NR

NR - Not reported

No study reported information concerning patient employment or occupation (Table 349).Therefore, one cannot determine the generalizability of these studies in terms of occupational variables.

Table 349. Patient occupation

Author | Year | ID# | Number of patients | % Patients employed | % Patients on Workers Compensation | % Patients retired | % Patients homemakers | Reported Occupations
Overend | 1999 | ^632^ | 50 | NR | NR | NR | NR | NR
Stratford | 1987 | ^631^ | 32 | NR | NR | NR | NR | NR

NR - Not reported

#### Results

Table 350 shows the results of the two studies that addressed this question. Overend (1999) excluded patients with prior surgery or elbow injection (within the last 30 days), but there is still uncertainty about whether some patients received prior treatment. ^632^ Stratford (1987) did not report whether patients had received prior treatment.Both studies used different functional status scales, so their results are not directly comparable.They found similar mean or median values in their pre-treatment study groups (between 30–40% of the maximum score).

Table 350. Studies with pre-treatment functional limitation data for patients with lateral epicondylitis

Study | N | Study Design | Stratified subgroups | n | Scale | Overall meanpre-treatment functional status score (SD) | % of maximum score
Overend (1999) ^632^ | 50 | Stratified case series | Male | 24 | PRFEQ (0–10 scale) | 2.8 (1.9) | 28
| | | Female | 23 | | 4.1 (2.1) | 41
| | | | | | p = 0.033^a^
| | | Subacute LE | 35 | | 3.6 (2.0) | 36
| | | Chronic LE | 12 | | 3.1 (2.2) | 31
| | | | | | p = 0.475^a^
| | | Work-related LE | 21 | | 4.2 (2.3) | 42
| | | Non-work-related LE | 26 | | 2.8 (1.7) | 28
| | | | | | p = 0.022^a^
| | | Total group | 47 | | 3.4 (2.1) | 34
Stratford (1987) ^631^ | 32 | Prospective case series | NA | NA | PFF (0–8) | Median:3 | 37.5

a Calculated by ECRI

PFF - Pain-Free Function Index

PRFEQ - Patient Rated Forearm Evaluation Scale

#### Conclusions

This question is addressed by only two studies comprised of a total of 82 patients.Although these studies suggest that the functional difficulties experienced by patients with epicondylitis are increased by 30% to 40%, the low number of studies and patients makes it difficult to arrive at an evidence-based answer to this question.

### Question #11: What are the functional limitations of an individual with epicondylitis after treatment?

This question considers the functional limitations of an individual after they have received conservative or surgical treatment for epicondylitis.In addressing it, our objective is to catalogue these limitations, and not to address the effectiveness of these treatments.We address the effectiveness of conservative and surgical treatments in Question 3.

#### Excluded studies

As discussed in the Methods section, we retrieved articles identified by our literature searches according to certain a priori criteria.However, one of the retrieved studies did not meet our more specific inclusion criteria for this question.This study, and the reason we did not consider it for this question is shown in Table 351.

Table 351. Excluded studies

Author | Reason for exclusion
Stratford et al., 1987 ^631^ | Study reports median value for successes and failures but does not report the number or percentage of successes and failures.

#### Evidence base

After this exclusion, there were no studies that met the general or question-specific inclusion criteria.

#### Conclusion

There were no studies that met the inclusion criteria for this question.Therefore, it cannot be answered in an evidence-based fashion.

## DeQuervain's Disease

### Question #1: What are the appropriate methods and approaches for the early identification and diagnosis of de Quervain's disease?

#### Inclusion Criteria

We included articles for this question if they reported data that could be used for evaluation of the test in diagnosing de Quervain's disease, and they included ten or more patients.

#### Evidence Base

We found no diagnostic studies that met the inclusion criteria.

#### Results

Three review articles stated that diagnosis of de Quervain's disease is made by the Finkelstein's test. ^53,^ ^85,^ ^87^ In this test, the patient makes a fist around the thumb, and the examiner deviates the wrist in an ulnar direction (away from the base of the thumb). If the patient experiences intense pain on the radial side of the wrist, the test is positive. All included treatment studies of de Quervain's disease (see question 3, below) listed Finkelstein's test among the inclusion criteria. ^88,^ ^633–635^ This suggests that Finkelstein's test is routinely used in diagnosis of this condition.

#### Conclusion

There is no published evidence by which one can assess the effectiveness of any test for DeQuervain's disease. Therefore it is not possible to reach evidence-based conclusions about these tests.

### Question #2: What Are The Specific Indications For Surgery For de Quervain's Disease?

Published evidence does not directly address the specific indications for surgery for de Quervain's disease. Therefore, we describe the reported characteristics of patients who have received surgery for de Quervain's disease in published studies. The extent to which these patients represent typical surgical candidates is unclear. Patients included in published studies of a procedure are frequently a subset of patients who are candidates for that procedure. They may represent an unusual group of interest, or an optimized group most likely to benefit from the procedure. Therefore, the data presented here, while informative, may not accurately reflect the overall patient population. They do, however, represent the best data available, and is the most comprehensive compilation of de Quervain's disease patient characteristics compiled to date.

#### Excluded studies

As discussed in the Methods section, we retrieved articles identified by our literature searches according to certaina priori criteria. However, one of the retrieved studies did not meet our more specific inclusion criteria for this question. This study, and the reason we did not consider it for this question are shown in Table 352.

Table 352. Excluded studies

Author and year | Reason for exclusion
Kay 2000 ^86^ | Demographic information not reported separately for surgical and non-surgical patients

#### Evidence base

Three studies with a total of 160 patients contained information relevant to this question for patients with de Quervain's disease. Table 353shows selected patient characteristics and reported surgical indications. Information not reported by these studies included race, extent of disease, pregnancy, menopause, oral contraceptive use, alcohol use, smoking status, whether patients were overweight, workers' compensation status, and whether the patient retained a lawyer.

Table 353. Specific indications for surgery for de Quervain's disease

Author/year | N | Mean age (range) | % female | Study design | Signs and symptoms | Occupations (n) | Specific indications for surgery
Ta et al. (1999) ^88^ | 43 | 48 (24–73) | 79.1 | Retrospective stratified case series | Pain over radial aspect of wrist aggravated by excessive use of thumb, a positive Finkelstein test | Packer (10), domestic (9), secretary (7), machine operator (6), computer engineer (3), teacher (2), hospital orderly (2), salesperson (2), carpenter (1), and business executive (1) | Specific indications not reported
Witt et al. (1991) ^633^ | 95 | 44 (16–75) | 77 | Prospective stratified case series | Pain radiating from radial styloid process to thumb and forearm, increased pain on passive movement of thumb and wrist, swelling and tenderness over first dorsal compartment, and positive result on Finkelstein testing | Housekeeping (26), Secretarial and clerical work (17), light manual labor (16), managerial or professional work (16), strenuous manual labor (4), music (2), education (2) | Failure of non-operative treatment
Yuasa et al. (1998) ^634^ | 22 | 47 (21–67) | 95.5 | Retrospective case series | Radial wrist pain, tenderness over first extensor compartment, and positive Finkelstein's test results | NR | Failure of non-operative treatment

NR - Not reported

#### Conclusions

Two of the three studies that addressed this question reported that surgery was performed only on patients who did not benefit from conservative (non-operative) treatment. ^633,^ ^634^ However, with so few studies and so many unreported patient characteristics, one cannot assume that the present data are representative of the larger patient population with de Quervain's disease.

### Question #3: What are the relative benefits and harms of various surgical and nonsurgical interventions for persons with de Quervain's disease?

For this question, we included any controlled trials (even retrospective) as long as at least two groups (treated or otherwise) were comparable. Study inclusion criteria for this question are listed under Methods (section).

#### Excluded studies

As discussed in the Methods section, we retrieved articles identified by our literature searches according to certain a priori criteria. However, not all of the retrieved studies met our more specific inclusion criteria for this question. These latter studies, and the reason we did not consider them for this question are shown in Table 354.

Table 354. Excluded studies

Author | Reason for exclusion
Kay 2000 ^86^ | Uncontrolled study
Ta et al. 1999 ^88^ | Uncontrolled study
Yuasa et al. 1998 ^634^ | Uncontrolled study
Witt et al. 1991 ^633^ | Uncontrolled study

#### Evidence base

After these exclusions, one trial describing 87 patients remained.

#### Internal validity

The criteria used to evaluate study quality were identical to those described for Question 3 under carpal tunnel syndrome. Table 355shows the internal validity of the only study that met the inclusion criteria. Because this study was non-randomized, retrospective and unblinded, it is particularly susceptible to bias. The extent of such bias, if any, and its impact on interpretation of the results, can not be determined.

Table 355. Study quality

Author | Number of patients | Number of centers | Funded by a for-profit agency? | Study design | Prospective | Blinding | % Attrition | Intent to treat analysis | % Compliance
Weiss 1994 ^635^ | 87 | 1 | No | Non-randomized controlled trial | No | No | 0 | Yes | NR

NR - Not reported

#### Generalizability

Selected patient characteristics are presented in Table 356. Because there were so few studies (even counting excluded studies) evaluating treatment of de Quervain's disease, the generalizability of the study by Weiss et al. to the larger patient population cannot be determined. However, the study appears to be consistent with the epidemiological information reported in review articles of de Quervain's disease (see Introduction, de Quervain's disease, subheading epidemiology).

Table 356. Patient characteristics

Author | Number of patients | Mean age (range) | % female | Duration of condition mean and range (months) | % Patients with diabetes | % Patients with arthritis | % Patients with prevous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Did the study exclude patients with severe disease? | Did the study exclude patients with mild disease?
Weiss 1994 ^635^ | 87 | 38 (17–72) | 85.1 | 7 (0.25–36) | 5.7 | 1.1 | 10.3 | 5.7 | 0 | 1.1 | 0 | NR | NR

Weiss et al. presented little specific information related to occupation (Table 357), but as already noted, there are too few studies to determine the generalizability of this study to the larger patient population.

Table 357. Patient occupation

Author | Number of patients | % Patients employed | % Patients on Workers Compensation | % Patients retired | % Patients homemakers | Reported Occupations
Weiss 1994 ^635^ | 87 | NR | 39.1 | NR | NR | Heavy manual labor, lightlabor, keyboard or typing activities

#### Results

Weiss et al. found a statistically significant increase in the number of treatment successes after corticosteroid plus lidocaine (CS) injection compared to immobilization splints or splints plus injection (Table 358and Table 359). Treatment successes were defined as patients with no or minimal symptoms who did not subsequently require surgery.

Table 358. Results of global assessment

Study | Number of wrists^a^ | Global assessment patient-reported categories | Statistical significance of difference between groups
Weiss 1994 ^635^ | 42 CS injection | 29 successes, 13 failures | Fisher's exact test
| 37 immobilization splint | 11 successes, 26 failures | P <0.001
| 14 CS injection plus immobilization splint | 8 successes, 6 failures

a Results were reported based on number of wrists, rather than patients, that received treatment.

CS - Corticosteroid plus lidocaine

Table 359. Success of nonsurgical treatments for de Quervain's disease

Study | Number of wrists^a^ | Length of followup (months) | Which treatment was more successful? | Was the difference statistically significant? | Effect size Hedges'd (95% CI)
Weiss 1994 ^635^ | 42 CS injection | Mean (range)^b^ | CS injection | Yes | Injection vs splint:
| 37 immobilization splint | 13 (6–14) | | | 0.91 (0.38 to1.44)
| 14 CS injection plus immobilization splint | | | | Injection plus splint vs splint:
| | | | | 0.62 (-0.08 to 1.32)

a Results were reported based on number of wrists, rather than patients, that received treatment

b Length of followup only reported for patients who did not undergo eventual surgery (treatment successes)

CS - Corticosteroid plus lidocaine

#### Conclusions

Although one study found that corticosteroid plus lidocaine injection produced more treatment successes than immobilization splints among de Quervain's patients, there were design problems with this study. Because of these problems and the fact that only one study addressed this question, it is difficult to reach firm evidence-based conclusions concerning the effectiveness of any treatment for de Quervain's disease. However, lack of evidence of an effect does not constitute evidence of lack of effect.

### Question #4: Is there a relationship between specific clinical findings and specific treatment outcomes among patients with de Quervain's disease?

In addressing this question, we consider whether published literature suggests that there are clinical findings that predict positive or negative outcomes after treatment for de Quervain's disease. The studies we considered all attempted to identify predictors by using regression techniques or by comparing outcomes in different groups of patients with different pre-treatment clinical findings.

#### Excluded studies

We did not exclude any study that addressed this question.

#### Evidence base

Evidence that addresses this question is derived from one study of 43 patients.

#### Study quality

The criteria used to evaluate study quality were identical to those described for Question 4 under carpal tunnel syndrome. One retrospective study (Ta et al., 1999) addressed this question for patients with de Quervain's disease (Table 360). ^88^ Of 43 patients who received surgery, 31 had a septated first dorsal compartment. The authors attempted to identify predictor variables by performing a multiple logistic regression with descending stepwise variable selection.

Table 360. Study quality

Author | Prospective? | Methods used to identify predictor variables
Ta et al. (1999) ^88^ | No | Multiple logistic regression

#### Results

The results of the only study that addressed this question are shown in Table 361. Odds ratios for non-septated and septated patients were not significantly different for a global outcome (patient satisfaction) or complications.

Table 361. Relationship between clinical findings and treatment outcomes

Author | Treatment | Variables examined | Comparison groups | Outcomes | Results
Ta et al. (1999) ^88^ | Surgery (n = 43) | Age, gender, steroid treatment, septation, duration of symptoms, occupational status | Septation | Global outcome (patient satisfaction -yes/no) | Odds Ratio (95% CI)
| | | No (12) | Complications (yes/no) | 1.0 (referent)
| | | Yes (31) | | 0.53 (0.07–3.68)
| | | | | p = 0.61
| | | | | 1.0 (referent)
| | | | | 1.25 (0.79–9.66)
| | | | | p = 1.00

#### Conclusions

This question was addressed by only one relatively small retrospective study. This precludes a firm evidence-based answer to this question.

### Question #5: Is there a relationship between duration of symptoms and specific treatment outcomes among patients with de Quervain's disease?

In addressing this question, we consider whether published literature suggests that duration of symptoms predicts positive or negative outcomes after treatment for de Quervain's disease. The studies we considered all attempted to identify predictors by using regression techniques or by comparing outcomes in different groups of patients with different duration of symptoms.

#### Excluded studies

As discussed in the Methods section, we retrieved articles identified by our literature searches according to certain a priori criteria. However, one study did not meet our more specific inclusion criteria for this question. This study, and the reason we did not consider it for this question are shown in Table 362.

Table 362. Excluded Studies

Author | Reason for exclusion
Witt et al. (1991) ^633^ | Stratified study with no duration of symptoms stratifications/outcome comparisons reported by other studies

#### Evidence base

After the above exclusion, there remained one study with 43 patients.

#### Study quality

The criteria used to evaluate study quality were identical to those described for Question 4 under carpal tunnel syndrome. Only one study addressed this question for patients with de Quervain's disease (Table 363). Ta et al. (1999) conducted a retrospective study that attempted to identify predictor variables with a multiple logistic regression in descending stepwise order.

Table 363. Study quality

Author/year | Prospective? | Methods used to identify predictor variables
Ta et al. (1999) ^88^ | No | Multiple logistic regression

#### Results

Table 364shows the results of the study by Ta et al. Patients with a longer duration of symptoms were more likely to experience satisfaction after surgery. ^88^

Table 364. Relationship between duration of symptoms and treatment outcomes among patients with de Quervain's disease

Author/year | Treatment(s) | Variables examined | Comparison groups | Outcomes | Results
Ta et al. (1999) ^88^ | Surgery (n = 43) | Age, gender, steroid treatment, septation, duration of symptoms, occupational status | Duration of symptoms | Global outcome (patient satisfaction -yes/no) | Odds Ratio (95% CI)
| | | 1–3 months (n = 2) | | 1.0 (referent)
| | | 4–6 months (n = 8) | | 1.21 (0.75–2.36)
| | | 7–9 months (n = 14) | | 1.16 (0.91–2.03)
| | | 10–12 months (n = 2) | | 1.42 (1.12–2.78)
| | | 13–15 months (n = 16) | | 1.74 (1.08–2.24)
| | | >15 months (n = 1) | | 1.62 (1.04–3.12)
| | | | | p = 0.034
| | | | Complications (yes/no) | 1.0 (referent)
| | | | | 0.82 (0.54–1.71)
| | | | | 1.15 (0.72–1.86)
| | | | | 1.79 (0.46–2.53)
| | | | | 1.21 (0.63–1.85)
| | | | | 1.72 (0.89–2.65)
| | | | | p = 0.24

#### Conclusions

This question was addressed by only one relatively small retrospective study. This precludes a firm evidence-based answer to this question.

### Question #6: Is there a relationship between factors such as patients' age, gender, socioeconomic status and/or racial or ethnic grouping and specific treatment outcomes among patients with de Quervains's disease?

In addressing this question, we consider whether published literature suggests that there are demographic variables that predict positive or negative outcomes after treatment for carpal tunnel syndrome. The studies we considered all attempted to identify predictors by using regression techniques or by comparing outcomes in different groups of patients with different pre-treatment demographic characteristics.

#### Excluded studies

As discussed in the Methods section, we retrieved articles identified by our literature searches according to certain a priori criteria. However, one of the retrieved studies did not meet our more specific inclusion criteria for this question. This study, and the reason we did not consider it for this question are shown in Table 365.

Table 365. Excluded studies

Author | Reason for exclusion
Witt et al. (1991) ^633^ | Stratified study with no demographic variable stratifications/outcome comparisons reported by other studies

#### Evidence base

After the above exclusion, there remained one study with 43 patients.

#### Study quality

The criteria used to evaluate study quality were identical to those described for Question 4. One study addressed this question for patients with de Quervain's disease (Table 366). Ta et al. (1999) conducted a retrospective study that attempted to identify predictor variables with a multiple logistic regression in descending stepwise order.

Table 366. Study quality

Author/year | Prospective? | Methods used to minimize differences between stratified groups | Is the stratification confounded?
Ta et al. (1999) ^88^ | No | Multiple logistic regression | No

#### Results

Table 367shows the results of the study by Ta et al. They found that there was no statistically significant relationship between occupational status, age, or gender and patient satisfaction or complications. ^88^

Table 367. Relationship between patient demographics and treatment outcomes

Author | Treatment(s) | Variables examined | Comparison groups | Outcomes | Results
Ta et al. (1999) ^88^ | Surgery (n = 43) | Age, gender, steroid treatment, septation, duration of symptoms, occupational status | Occupational status | Global outcome (patient satisfaction -yes/no) | Odds Ratio (95% CI)
| | | Unemployed (n = 12) | | 1.0 (referent)
| | | Employed (n = 31) | | 3.60 (0.36–5.26)
| | | | | p = 0.36
| | | | Complications (yes/no) | 1.0 (referent)
| | | | | 0.32 (0.12–3.78)
| | | | | p = 0.62
| | | Age (years) | Global outcome (patient satisfaction-yes/no) | Odds Ratio (95% CI)
| | | 21–30 (n = 3) | | 0.92 (0.57–1.36)
| | | 31–40 (n = 9) | | 0.80 (0.43–1.21)
| | | 41–50 (n = 14) | | 1.06 (0.82–1.16)
| | | 51–60 (n = 9) | | 1.02 (0.64–1.47)
| | | >60 (n = 8) | | (referent)
| | | | | p = 0.16
| | | | Complications (yes/no) | 1.06 (0.76–1.53)
| | | | | 0.72 (0.52–1.27)
| | | | | 0.94 (0.85–1.33)
| | | | | 0.88 (0.72–1.10)
| | | | | p = 0.41
| | | Gender | Global outcome (patient satisfaction-yes/no) | Odds Ratio (95% CI) (referent)
| | | Female (n = 34) | | 0.40 (0.11–1.42)
| | | Male (n = 9) | | p = 0.54
| | | | Complications (yes/no) | (referent)
| | | | | 4.15 (0.54–35.10)
| | | | | p = 0.16

#### Conclusions

This question was addressed by only one relatively small retrospective study. This precludes a firm evidence-based answer to this question.

### Question #7: What are the surgical and nonsurgical costs or charges for treatment of de Quervain's disease?

According to the Medicare Provider Analysis and Review (MEDPAR) database, which covers hospital inpatient services, average total charges per patient for the DRG (diagnosis-related group) of hand or wrist procedures (excepting major joint procedures) without complications or comorbidities are $7,408.14 (calculated by dividing total charges by number of discharges). The Median Costs for Hospital Outpatient Services Dataset contains median costs for services that are reimbursed under Medicare for the hospital outpatient prospective payment system. The reported median cost for application of a short arm static splint is $72.69.

### Question #8: For persons who have had surgery for de Quervain's disease, what are the most effective methods for preventing the recurrence of symptoms, and how does this vary depending on subject characteristics or other underlying health problems?

There were no published studies that addressed this question.

### Question #9: What instruments, if any, can accurately assess functional limitations in an individual with de Quervain's disease?

There were no published studies that addressed this question.

### Question #10: What are the functional limitations for an individual with de Quervain's disease before treatment?

There were no published studies that addressed this question.

### Question #11: What are the functional limitations of an individual with de Quervain's disease after treatment?

There were no published studies that addressed this question.

## Non-Treatment-Specific Questions

### Question#12. What are the cumulative effects on functional abilities among individuals with more than one worker-related musculoskeletal disorder of the upper extremity in the same limb?

In this question, we address studies of patients with more than one worker-related, upper extremity musculoskeletal disorder in the same limb, including patients reported to suffer from “double crush” syndrome. We acknowledge that the existence of “double crush” syndrome is controversial. ^14,^ ^636–638^ However, we include it because these patients are experiencing symptoms, and it is important to determine whether these symptoms can be relieved.

#### Excluded studies

As discussed in the Methods section, we retrieved articles identified by our literature searches according to certain a priori criteria. Of the 23 publications that were retrieved as possibly addressing this question, none met our criteria for inclusion (Table 368). Twenty-one studies were excluded for not containing functional ability data. The remaining two reported information indirectly related to functional abilities, but neither measured functional abilities using validated functional status scales or attempted to determine a patient's ability to perform individual functional activities. ^639,^ ^640^ One of these studies evaluated outcomes such as grip strength, pinch strength, and range of motion, ^639^ while the other study reported the number of patients with grip weakness or pinch weakness. ^640^ None of these outcomes is a direct measure of the ability of patients to perform daily or work-related activities.

Table 368. Excluded studies reporting patients with more than one work-related musculoskeletal disorder of the upper extremity in the same limb

Study | Reason for exclusion
Bursell 1999 ^641^ | No functional activity outcomes
Chung 1999 ^642^ | No functional activity outcomes
Richardson 1999 ^638^ | No functional activity outcomes
Baba 1998 ^643^ | No functional activity outcomes
Morgan 1998 ^644^ | No functional activity outcomes
Chaudhry 1997 ^637^ | No functional activity outcomes
Guzel 1997 ^645^ | No functional activity outcomes
Moore 1996 ^646^ | No functional activity outcomes
Golovchinsky 1995 ^258^ | No functional activity outcomes
Lanzetta 1995 ^647^ | No functional activity outcomes
Nemchausky 1995 ^648^ | No functional activity outcomes
Sie 1992 ^649^ | No functional activity outcomes
Gonzalez 1991 ^650^ | No functional activity outcomes
Grundberg and Reagan 1991 ^639^ | No functional activity measures using validated functional status scales or assessing ability to perform specific functional activities.
Narakas 1990 ^640^ | No relevant functional activity measures
Wood 1990 ^651^ | No functional activity outcomes
Kerrigan 1988 ^652^ | No functional activity outcomes
Osterman 1988 ^653^ | No functional activity outcomes
Eason 1985 ^654^ | No functional activity outcomes
Hurst 1985 ^655^ | No functional activity outcomes
Bryar 1984 ^656^ | No functional activity outcomes
Massey 1981 ^657^ | No functional activity outcomes
Nissenbaum 1980 ^658^ | No functional activity outcomes

#### Evidence base

After the above exclusions, no studies remained that met the general or question-specific inclusion criteria.

#### Conclusions

There were no studies that met the inclusion criteria for this question. Therefore, it cannot be answered in an evidence-based fashion.

### Question#13. What level of function can patients achieve in what period of time when required to change hand dominance as they are a result of injury to their dominant hand?

In this question, we address studies of patients that were forced to change hand dominance. Workers may be required to perform tasks with the non-dominant hand because of severe injury or amputation prevents the use of the dominant hand. Workers may also wish to switch tasks to the non-dominant had to give relief to the dominant hand.

#### Excluded studies

We did not exclude any study from consideration for this question.

#### Evidence base

We found two studies with a total of 89 patients that addressed the use of the non-dominant hand in work activities and the effect of training programs or learning on this transfer. The two studies differed in the type of patients they examined. Mitchell-Krever and Lacroix, 1998 ^659^ looked at extensive skill training in patients who could not use their dominant arm, while Salazar and Knapp, 1996 ^660^ used volunteer subjects to evaluate differences between dominant and non-dominant hands and the effect of learning.

#### Internal Validity

Both studies examined for this section were prospective observational studies in which issues of randomization, blinding, and compliance are not relevant (Table 369). These issues are applicable for questions comparing the outcomes of different treatments or treatment and placebo. The present question does not relate to treatment, and neither of the included studies had more than one patient group. There was no attrition for the outcomes evaluated up to two to six months of followup. However, Mitchel-Krever et al. reported an 80% loss to followup at their 1.5 to two year evaluation of outcomes.

Table 369. Internal Validity

Author | Number of patients | Number of centers | Funded by a for-profit agency? | Prospective | % Attrition | Intent to treat analysis
Mitchell-Krever and Lacroix 1998 ^659^ | 53 | 1 | NR | Yes | At 2–6 months:0 | Yes
| | | | | At 1.5–2 years: 80
Salazar and Knapp 1996 ^660^ | 36 | 1 | NR | Yes | 0 | Yes

NR - Not reported

#### Generalizability

Patient ages were similar in the two studies, they fall within the typical range reported in epidemiologic studies (see Introduction section for the individual disorders), and roughly half of the patients in each study were female (Table 370). Other patient characteristics were incompletely reported.

Table 370. Generalizability

Author | Number of patients | Mean age (range) | % female | Duration of condition mean and range (months) | % Patients with diabetes | % Patients with arthritis | % Patients with prevous relevant injuries | % Patients with other relevant nerve impingement conditions | % Patients with peripheral neuropathy | % Patients pregnant | % Patients on kidney dialysis | Did the study exclude patients with severe disease? | Did the study exclude patients with mild disease?
Mitchell-Krever and Lacroix 1998 ^659^ | 53 | Range: 20–59 | 41.5 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Salazar and Knapp 1996 ^660^ | 36 | Range: 20–55 | 66.7 | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA

NR - Not reported

#### Results

Both studies used measures of individual functional activities to determine level of function in non-dominant hands. The results are shown in Table 371. In the study by Mitchell-Krever and Lacroix, higher scores indicate better function. Three of the tests in this study (finger dexterity, Purdue pegboard test, and the O'Connor tweezer dexterity test) were particularly informative because the reported scores represent percentile ranking compared to the same sex dominant hand. Because Salazar and Knapp measured the time it took to perform specific tasks, lower scores indicate better functional ability in their study. Both studies showed statistically significant improvement over time in the functional ability of non-dominant hands.

Table 371. Results of outcomes measured in publications that reported information on changing hand dominance

Author | Length of followup | Outcome | | Pretest Mean | Pretest SD | Post-test Mean | Post-test SD
Mitchell-Krever and Lacroix, 1998 ^659^ | Mean: 5 months (range 2–6 months) | Peg transfer ^a^ | | 53.68 | 10.97 | 87.43 | 11.10
| | Peg turn ^a^ | | 49.53 | 12.21 | 89.06 | 10.63
| | Rivets and washers ^a^ | | 41.85 | 11.76 | 77.30 | 13.66
| | Finger dexterity ^a^ | | 26.11 | 24.43 | 61.97 | 29.74
| | Purdue pegboard test ^a^ | | 13.77 | 17.53 | 42.93 | 26.10
| | O'Connor Tweezers Dexterity test ^a^ | | 10.40 | 17.61 | 38.55 | 29.71
| | Writing - manuscript ^a^ | | 7.27 | 2.68 | 15.42 | 4.95
| | Writing - cursive ^a^ | | 7.44 | 3.26 | 14.82 | 6.05
| | Typing speed ^a^ | | 8.21 | 4.79 | 17.83 | 8.05
| | Typing accuracy | | 94.92 | 4.78 | 95.00 | 4.75
| | Keypadding speed ^a^ | | 10.73 | 5.26 | 30.71 | 13.85
| | Keypadding accuracy | | 95.21 | 9.41 | 96.17 | 3.45
| | Grip strength ^a^ | | 32.57 | 14.36 | 36.97 | 13.68
Salazar and Knapp, 1996^660b^ | One week after first test | Bolts task
| | | Men | 36.9 | 10.2 | 33.0 | 8.3
| | | Women | 46.5 | 13.4 | 42.9 | 12.7
| | O'Connor Tweezers
| | Dexterity test ^c^
| | | Men | 33.7 | 11.4 | 24.4 | 6.0
| | | Women | 34.2 | 13.5 | 31.2 | 15.0
| | Drilling task ^c^
| | | Men | 36.4 | 10.9 | 20.0 | 6.8
| | | Women | 63.1 | 27.9 | 34.4 | 22.1
| | Nail-driving task
| | | Men | 15.9 | 5.8 | 15.2 | 4.0
| | | Women | 58.3 | 35.8 | 48.4 | 28.0

a Significant improvement between pre- and post-test scores, t-test with P<0.001 as reported in Mitchell-Krever and Lacroix, 1998 ^659^

b Only data for non-preferred hand is presented

c Significant improvement between pre- and post-test scores, F-test with P<0.05 as reported in Salazar and Knapp, 1996 ^660^

Mitchell-Krever and Lacroix found that almost every task improved after their training program as assessed during a two to six month followup period. Gross motor skills, fine motor skills, combined fine and gross motor skills, writing skills, and grip strength all showed statistically significant improvement. Typing and keypadding speed also increased, but accuracy for both skills was unchanged perhaps because accuracy was already high (>95%). Age was not related to post-test performance except for manuscript writing (no data reported) and sex had no effect on any of the pre- and post-tests except for the strength measurement where men were stronger than women (no data reported). A questionnaire was sent to participants one-and-a-half to two years following program completion to assess the long-term effects of the program. However, only 20% of the participants returned the questionnaire, and this attrition rate may be too high to allow a meaningful conclusion about the long-term outcomes of this training program. The results assessed at two to six months do not suffer from this difficulty.

Salazar and Knapp reported their results separately for men and women. Both men and women showed an increase in the dexterity test using tweezers and in the drilling task. However the bolt task and nail-driving test showed no improvement after one week. The lack of improvement in the bolt task may have been due to a ceiling effect, as the participants were already performing as fast as possible on the first day. The lack of improvement in nail-driving may have been related to the physical nature of the task and more time may be needed to learn how to use the non-dominant hand in this task.

#### Conclusions

The evidence presented in these two studies suggests that learning and training in the use of the non-dominant hand is possible and statistically significant improvement can be accomplished in 2 to 6 months of training. For some activities, statistically significant improvement can be accomplished within one week. However, these studies lack long-term followup data to determine how well the interventions work towards providing the patient with employment opportunities and if the improvement of the non-dominant hand is sufficient to allow resumption of normal activities.