# Appendix A. Search Strategies

## PubMed/Medline syntax

#1 cumulative trauma disorders[mh] OR (repetitive AND (motion OR strain)) OR “cumulative trauma” OR “work-related musculoskeletal disorders” OR “occupation-related syndromes” OR “occupational disorders” OR “overuse syndrome”

#2 #1 AND (arm[mh] OR bones of upper extremity[mh] OR “upper extremity” OR arm injuries[mh] OR arm* OR shoulder* OR elbow* OR wrist* OR hand* OR finger* OR digit*).

#3 (“De Quervain” OR “de Quervain” OR “DeQuervain”) OR ((tenosynovitis OR tenovaginitis) AND stenos*) OR “trigger wrist”

#4 “trigger finger” OR “trigger digit” OR ((tenosynovitis OR tenovaginitis) AND (finger* OR digit OR digits OR thumb*) AND stenos*)

#5 Cubital tunnel syndrome OR (ulnar AND entrap* AND elbow*)

#6 Carpal tunnel syndrome OR (median AND entrap* AND wrist)

#7 Epicondylitis OR “tennis elbow” OR "golfer's elbow

#8 #2 or #3 or #4 or #5 or #6 or #7

To restrict retrieval of articles identified by the above-described searches to clinical trials we employed the following:

(clinical trials[mh] OR clinical trial[pt] OR controls[ab] OR randomized controlled trials[mh] OR random allocation[mh] OR randomized controlled trial[pt] OR random* OR double-blind method[mh] OR single-blind method[mh] OR “single-dummy” OR “double-dummy” OR sham OR controls[ab] OR controlled clinical trials[mh] OR controlled clinical trial [pt] OR multicenter study[pt] OR meta-analysis OR meta-analysis[pt] OR placebo* OR outcomes research[mh] OR prospective studies[mh] OR “evidence-based medicine” OR “systematic review”)

To retrieve articles related to diagnostic concepts we employed the following syntax:

(diagnosis OR diagnose OR diagnostic OR di[sh] OR “gold standard” OR “ROC” OR “receiver operating characteristic” OR sensitivity OR specificity OR sensitivity and specificity[mh] OR likelihood OR “false positive” OR “false negative” OR “true positive” OR “true negative” OR “predictive value”)

To retrieve articles on therapeutic concepts we employed the following syntax:

(th[sh] OR su[sh] OR dt[sh] OR effectiveness OR efficacy OR “intention to treat” OR treat OR treatment OR therapy OR therapeutic OR “outcome assessment” OR “relative risk”)

### HCUPnet

We searched the HCUPnet database for the following ICD-9 procedure codes:

#### ICD-9 Procedure Codes

80.14 | 82.09 | 82.36 | 82.52 | 82.92 | 80.92 | 83.72 | 83.77
80.24 | 82.11 | 82.39 | 82.53 | 82.93 | 81.85 | 83.73 | 83.79
80.34 | 82.12 | 82.41 | 82.54 | 82.94 | 88.22 | 83.75 | 83.85
80.44 | 82.19 | 82.42 | 82.57 | 82.95 | 83.01 | 83.76 | 84.99
80.74 | 82.21 | 82.43 | 82.59 | 80.12 | 83.31 | 83.83 | 88.84
80.94 | 82.22 | 82.44 | 82.71 | 80.22 | 83.61 | 83.88 | 93.04
82.01 | 82.31 | 82.45 | 82.85 | 80.32 | 83.62 | 83.97 | 93.12
82.02 | 82.33 | 82.46 | 82.86 | 80.42 | 83.64 | 83.65 | 93.17
82.03 | 82.35 | 82.51 | 82.91 | 80.72 | 83.71 | 83.74 | 93.27

#### Datasets CPT Codes

The HCUPnet database was searched for the following CPT:

9991 | ANESTHESIA ACUPUNCTURE
9992 | OTHER ACUPUNCTURE
053 | SYMPATH NERVE INJECTION*
0539 | SYMPATH NERVE INJECT NEC
8294 | INJECT BURSA OF HAND
8295 | INJECT TENDON OF HAND
923 | INJECT STEROID
9929 | INJECT/INFUSE NEC
9354 | APPLICATION OF SPLINT
9927 | IONTOPHORESIS
932 | OTH PT MUSCULOSKEL MANIP*
936 | OSTEOPATHIC MANIPULATION*
9367 | OSTEOPATH MANIPULAT NEC
8392 | INSERT SKEL MUSC STIMULA
8393 | REMOV SKEL MUSC STIMULAT
9327 | MUSC OR TEND STRETCHING
9308 | ELECTROMYOGRAPHY
9314 | JOINT MOVEMENT TRAINING
9383 | OCCUPATIONAL THERAPY
9361 | OMT FOR GEN'L MOBILIZAT
8211 | TENOTOMY OF HAND
8313 | OTHER TENOTOMY
8092 | EXCISION OF ELBOW NEC
8093 | EXCISION OF WRIST NEC
8235 | HAND FASCIECTOMY NEC
8344 | OTHER FASCIECTOMY
82 | HAND MUSCL/TEND/FASC OPS*
8201 | EXPLOR TEND SHEATH-HAND
821 | DIV HAND MUSC/TEND/FASC*
8221 | EXC LES TEND SHEATH HAND
8232 | EXCIS HAND TEND FOR GRFT
8241 | SUTURE TENDN SHEATH HAND
8242 | DELAY SUT FLEX TEND HAND
8243 | DELAY SUT HAND TEND NEC
8244 | SUTUR FLEX TEND HAND NEC
8245 | SUTURE HAND TENDON NEC
830 | INCIS MUS/TEND/FASC/BURS*
8301 | TENDON SHEATH EXPLORAT
831 | MUSCL/TEND/FASC DIVISION*
8331 | EXCIS LES TENDON SHEATH
836 | SUTURE MUSCL/TENDON/FASC*
8361 | TENDON SHEATH SUTURE
8362 | DELAYED TENDON SUTURE
8364 | OTHER SUTURE OF TENDON
837 | MUSCLE/TENDON RECONSTRUC*
8371 | TENDON ADVANCEMENT
8372 | TENDON RECESSION
8373 | TENDON REATTACHMENT
8375 | TENDON TRNSFR/TRANSPLANT
8376 | OTHER TENDON TRANSPOSIT
8383 | TENDON PULLEY RECONSTRUC
8385 | MUSC/TEND LNG CHANGE NEC
807 | SYNOVECTOMY*
8070 | SYNOVECTOMY-SITE NOS
8073 | WRIST SYNOVECTOMY
8074 | HAND SYNOVECTOMY
8079 | SYNOVECTOMY-SITE NEC
82 | HAND MUSCL/TEND/FASC OPS*
8201 | EXPLOR TEND SHEATH-HAND
821 | DIV HAND MUSC/TEND/FASC*
8221 | EXC LES TEND SHEATH HAND
8241 | SUTURE TENDN SHEATH HAND
8242 | DELAY SUT FLEX TEND HAND
8243 | DELAY SUT HAND TEND NEC
8244 | SUTUR FLEX TEND HAND NEC
8245 | SUTURE HAND TENDON NEC
825 | HAND MUSC/TEND TRANSPLAN*
8251 | HAND TENDON ADVANCEMENT
8252 | HAND TENDON RECESSION
8253 | HAND TENDON REATTACHMENT
0443 | CARPAL TUNNEL RELEASE
8174 | ARTHROPLASTY CARPAL WIT
8175 | ARTHROPLASTY CARPAL W/O
8257 | TRANSPOSIT HAND TEND NEC
8259 | TRANSPOSIT HAND MUSC NEC
8376 | OTHER TENDON TRANSPOSIT
8379 | OTHER MUSCLE TRANSPOSIT
0532 | NEUROLYT INJEC-SYMP NRV
047 | OTHER PERIPH NEUROPLASTY*
0479 | OTHER NEUROPLASTY
8022 | ELBOW ARTHROSCOPY
8822 | SKEL XRAY-ELBOW/FOREARM
8023 | WRIST ARTHROSCOPY
8823 | SKEL XRAY-WRIST & HAND

#### Diagnostic Related Groups (DRGs)

The HCUPnet database was searched for the following:

006 | SURG | CARPAL TUNNEL RELEASE
007 | SURG | PERIPH & CRANIAL NERVE & OTHER NERV SYST PROC W CC
008 | SURG | PERIPH & CRANIAL NERVE & OTHER NERV SYST PROC W/O CC
216 | SURG | BIOPSIES OF MUSCULOSKELETAL SYSTEM & CONNECTIVE TISSUE
223 | SURG | MAJOR SHOULDER/ELBOW PROC, OR OTHER UPPER EXTREMITY PROC W CC
224 | SURG | SHOULDER, ELBOW OR FOREARM PROC, EXC MAJOR JOINT PROC, W/O CC
226 | SURG | SOFT TISSUE PROCEDURES W CC
227 | SURG | SOFT TISSUE PROCEDURES W/O CC
228 | SURG | MAJOR THUMB OR JOINT PROC, OR OTH HAND OR WRIST PROC W CC
229 | SURG | HAND OR WRIST PROC, EXCEPT MAJOR JOINT PROC, W/O CC
232 | SURG | ARTHROSCOPY
233 | SURG | OTHER MUSCULOSKELET SYS & CONN TISS O.R. PROC W CC
234 | SURG | OTHER MUSCULOSKELET SYS & CONN TISS O.R. PROC W/O CC
240 | MED | CONNECTIVE TISSUE DISORDERS W CC
241 | MED | CONNECTIVE TISSUE DISORDERS W/O CC
246 | MED | NON-SPECIFIC ARTHROPATHIES
247 | MED | SIGNS & SYMPTOMS OF MUSCULOSKELETAL SYSTEM & CONN TISSUE
248 | MED | TENDONITIS, MYOSITIS & BURSITIS
249 | MED | AFTERCARE, MUSCULOSKELETAL SYSTEM & CONNECTIVE TISSUE
250 | MED | FX, SPRN, STRN & DISL OF FOREARM, HAND, FOOT AGE >17 W CC
251 | MED | FX, SPRN, STRN & DISL OF FOREARM, HAND, FOOT AGE >17 W/O CC
252 | MED | FX, SPRN, STRN & DISL OF FOREARM, HAND, FOOT AGE 0–17
256 | MED | OTHER MUSCULOSKELETAL SYSTEM & CONNECTIVE TISSUE DIAGNOSES
462 | MED | REHABILITATION

#### Ambulatory Payment Classifications (APCs)

The HCUPnet database was searched for the following APCs:

0041 | Arthroscopy
0042 | Arthroscopically-Aided Procedures
0047 | Arthroplasty without Prosthesis
0049 | Level I Musculoskeletal Procedures Except Hand and Foot
0050 | Level II Musculoskeletal Procedures Except Hand and Foot
0051 | Level III Musculoskeletal Procedures Except Hand and Foot
0053 | Level I Hand Musculoskeletal Procedures
0054 | Level II Hand Musculoskeletal Procedures

#### HCPCS Codes

The HCUPnet database was searched for the following HCPCS codes:

25000 | Incision of tendon sheath
25020 | Decompression of forearm
25023 | Decompression of forearm
24000 | Exploratory elbow surgery
24006 | Release elbow joint
24100 | Biopsy elbow joint lining
24101 | Explore/treat elbow joint
24102 | Remove elbow joint lining
24301 | Muscle/tendon transfer
24305 | Arm tendon lengthening
24310 | Revision of arm tendon
24320 | Repair of arm tendon
24330 | Revision of arm muscles
24331 | Revision of arm muscles
24341 | Repair arm tendon/muscle
24350 | Repair of tennis elbow
24351 | Repair of tennis elbow
24352 | Repair of tennis elbow
24354 | Repair of tennis elbow
24356 | Revision of tennis elbow
25260 | Repair forearm tendon/muscle
25263 | Repair forearm tendon/muscle
25265 | Repair forearm tendon/muscle
25270 | Repair forearm tendon/muscle
25272 | Repair forearm tendon/muscle
25274 | Repair forearm tendon/muscle
25280 | Revise wrist/forearm tendon
25290 | Incise wrist/forearm tendon
25295 | Release wrist/forearm tendon
25310 | Transplant forearm tendon
25320 | Repair/revise wrist joint
25332 | Revise wrist joint
26035 | Decompress fingers/hand
26037 | Decompress fingers/hand
26040 | Release palm contracture
26055 | Incise finger tendon sheath
26060 | Incision of finger tendon
26121 | Release palm contracture
26123 | Release palm contracture
26125 | Release palm contracture
26130 | Remove wrist joint lining
26135 | Revise finger joint, each
26140 | Revise finger joint, each
26145 | Tendon excision, palm/finger
26170 | Removal of palm tendon, each
26180 | Removal of finger tendon
26350 | Repair finger/hand tendon
26356 | Repair finger/hand tendon
26418 | Repair finger tendon
26525 | Release finger contracture
26591 | Repair muscles of hand
26593 | Release muscles of hand
26596 | Excision constricting tissue
26989 | Hand/finger surgery
29830 | Elbow arthroscopy
29835 | Elbow arthroscopy/surgery
29836 | Elbow arthroscopy/surgery
29837 | Elbow arthroscopy/surgery
29838 | Elbow arthroscopy/surgery
29840 | Wrist arthroscopy
29843 | Wrist arthroscopy/surgery
29844 | Wrist arthroscopy/surgery
29845 | Wrist arthroscopy/surgery
29846 | Wrist arthroscopy/surgery
29848 | Wrist arthroscopy/surgery
64702 | Revise finger/toe nerve
64704 | Revise hand/foot nerve
64718 | Revise ulnar nerve at elbow
64719 | Revise ulnar nerve at wrist
64721 | Carpal tunnel surgery
95831 | Limb muscle testing, manual
95832 | Hand muscle testing, manual
95851 | Range of motion measurements
95852 | Range of motion measurements
95857 | Tensilon test
95858 | Tensilon test & myogram
95860 | Muscle test, one limb
95861 | Muscle test, two limbs
95872 | Muscle test, one fiber
95875 | Limb exercise test
95900 | Motor nerve conduction test
95903 | Motor nerve conduction test
95904 | Sense/mixed n conduction test
95925 | Somatosensory testing
95937 | Neuromuscular junction test