# Tables

Table 1a. Summary of epidemiological studies reporting on the prevalence and/or incidence of cancer related pain (N=29)

Table 1. Prevalence of Major Depressive Disorder (MDD) 12 Cross-sectional Studies on Prevalence of MDD using DSM Criteria

Table 2. Prevalence of significant depressive symptoms in adults Cross-sectional studies using the HADS

Table 3. Prevalence of Depressive Symptoms in Children with Cancer

Table 3. Prevalence of Depressive Symptoms in Children with Cancer

Author Year UI | N | Population/Setting | Cancer Type | Mean Age (range) & % Male | Prevalence
Multhern 1994 | 99 | Consecutive hospitalized children with cancer in remission | Various, 41.4% leukemia | 12.9 median (8-16) 60.6% M | Specifics not noted, <10%
Suris 1996 | 3139 - 162 chronic illness, 39 cancer | Random sample of Spanish high school students, 14-19 years old, data analyzed as chronic illness (including cancer) vs. control, no significant difference found between cancer and other chronic illnesses | ND | (14-19) ND | Significantly higher report of depressive symptoms, 30.0% of females reported "emotional problems" with 23.5% reporting suicidal ideation, 16.1% males reported "emotional" problems with 16.1% reporting suicidal ideation
Von Essen 2000 | Group 1: 16 Group 2: 35 | 2 groups of hospitalized children with cancer diagnosed no later than 1 month pre-study ages 8-18 years old | Various | Group 1: 13.3±3.3 Group 2: 12.6±3.3 Group 1: 69% M Group 2: 51% M | 14% of all subjects, 6.3% on treatment, 17.1% off treatment

Table 4. Incidence of Depressive Symptoms in Adult Cancer Patients HADS

Table 4. Incidence of Depressive Symptoms in Adult Cancer Patients HADS

Author Year UI | N | Population/Setting & Characteristics | Treatment | Time Course | Instruments | Baseline | Time 1 | Time 2
Chadurvedi 1996 | 100, 57, 21 | Consecutive newly diagnosed patients starting radiation, various cancers (55% cervix), 67% < 40 years 21% Male | Radiation | 3-4 months post-treatment | HADS (>8) | 4% | Finishing course of radiation, 44% | 3-4 months post treatment, 48%
Norden 1999 | 159, 113 | Consecutive newly diagnosed GI cancers, mean age 67 years (range 23-89) 51% Male | Biopsy | 3-6 months after diagnosis | HADS (>8 for depression or anxiety scales), MAC, IES | 21.2% | 3 or 6 months later, 12.4% | 3-4 months post treatment, 48%
Hjermstad 1999 | 130, 130, 94 | Consecutive leukemia patients for stem cell transplantation, median age 35 (range 17-55) 56% Male | BMT | 1 year | HADS (>8) | 4.6% | 2 weeks, 40% | 1 year, 10.6%
Hammerlid 1999 | 357, 345, 215 | Head and neck cancer patients pre-treatment, mean age 63 (range 18-88) 72% Male | Various, combined and radiation in majority | 1 year | HADS (>11) | 6%probable cases, 11% border-line | 3 month 13% probable cases, 11% borderline | 1 year, 8% probable cases, 9% borderline
Hopwood 2000 | 987, 718 | Lung cancer patients in clinical trails, 55% poor prognosis Gender ND | 3 clinical trials, 3 chemotherapy and 1 radiation | Time of 1st follow-up not noted | HADS (>11), RSCL | 17%probable cases, 16% border-line | 1st follow up, 29% probable cases or borderline | 1 year, 8% probable cases, 9% borderline

Table 5. Prevalence of Fatigue in Cancer Patients

Table 6. Assessment scales for pain, depression and fatigue

Table 6. Assessment scales for pain, depression and fatigue

Scales | 1980-82 | 1983-85 | 1986-88 | 1989-91 | 1992-94 | 1995-97 | 1998-2000 | 2001* | Total
VAS | 1 | 4 | 9 | 19 | 24 | 14 | 23 | 4 | 98
EORTC | | | | | 2 | 6 | 8 | | 16
HADS | | | | 1 | 4 | 1 | 8 | | 14
POMS | | 1 | 2 | | 3 | | 8 | | 14
FLIC | | | | | | 2 | 3 | | 5
SF-36 | | | | | | 2 | 3 | | 5
Rotterdam | | | | 1 | | 2 | | | 3
CHEOPS | | | | | | | 1 | 1 | 2
WHO | | | | | | 2 | | | 2
CGI | | | | | | | 1 | | 1
SLC | | | | | | | 1 | | 1
Piper | | | | | | | | | 0
FACT | | | | | | | | | 0
Total | 1 | 5 | 11 | 21 | 35 | 27 | 56 | 5

*Search was conducted in mid-2001

Table 7. Assessment Scales by Cancer Type

Table 7. Assessment Scales by Cancer Type

Cancer | VAS | HADS | EORTC | POMS | FLIC | SF-36 | FACT-An | WHO | Piper | Total
Various | 54 | 4 | 2 | 4 | | | 1 | 1 | | 66
Breast | 5 | 5 | 4 | 3 | | 1 | | | 1 | 19
Gynecological | 5 | | | | | | | | | 5
Prostate | 1 | 1 | 3 | | 1 | | | | | 5
Colorectal | 2 | | | | 2 | | | | | 4
Bone | 3 | | | | | | | | | 3
Pancreatic | 2 | 1 | | | | | | | | 3
Head and Neck | | 2 | | 1 | | | | | | 2
Hematologic | 2 | | | | | | 1 | | | 2
Laryngeal | | | | | | 2 | | | | 2
Lung | | | | 2 | | | | | | 2
Myeloma | | | | | | | | 1 | | 1
RCC | | | 1 | | | | | | | 1
Total | 74 | 13 | 10 | 10 | 3 | 3 | 2 | 2 | 1

Table 8. Most Frequently Used Assessment Tools for Pain and Pain-related Quality of Life (including function), Cited in Management of Cancer Pain: Evidence Report

Table 8. Most Frequently Used Assessment Tools for Pain and Pain-related Quality of Life (including function), Cited in Management of Cancer Pain: Evidence Report

| NSAIDS | NSAID vs Opioid | Opioid vs Opioid | Opioid Adjuvants | Misc. Inter-ventions | Bisphos-phonates | Chemo or radiotherapy | Educ, Behav, Psychology | Hypnosis | Neurolytic Celiac Plexus Block | Interim RCTs | Total Uses of Each Tool
Total # Patients 22,793 | 1102 | 1665 | 2184 | 416 | 327 | 3448 | 5403 | 1625 | 252 | 250 | 6121
Total # Studies 218 | 18 | 25 | 42 | 12 | 10 | 33 | 27 | 7 | 5 | 5 | 34
Outcome Scales 125
VAS (0-100) | 5 | 4 | 19 | 12 | 4 | 5 | 1 | | 4 | 4 | 4 | 58
VAS 10cm | 2 | 1 | 18 | | 1 | 6 | 2 | 1 | 5 | 8 | 8 | 44
Pain Intensity 5pt | 3 | 11 | 3 | | | | 5 | | 1 | | 3 | 26
Pain Intensity 4pt | 5 | 4 | 4 | | 2 | 3 | 2 | 1 | | | 3 | 24
Analgesic Consumption | | | | 3 | 3 | 7 | 1 | | | 3 | 4 | 21
McGill Pain Quest | 1 | | 5 | | 1 | | 1 | 4 | 1 | | 2 | 15
SPID | 5 | 9 | | | | | | | | | | 14
Pain Relief 4pt scale | 3 | 9 | 1 | | | | | | | | | 13
Integrated Score Method: 5 categories (0-100) | 4 | 4 | 1 | | | | | | | | | 9
TOTPAR | 2 | 6 | 1 | | | | | | | | | 9
Pain Relief 5pt scale | 3 | 2 | 1 | | 1 | | | | 1 | | | 8
Pain Intensity Difference (from baseline) | 4 | 2 | | | | | | | | | 1 | 7
EORTG QLQ-C30 | | | | | | | 1 | | | 1 | 4 | 6
Performance Status (0-4) | 4 | | | | | 1 | | | | 1 | | 6
Daily Numeric Pain Scale (0-10) | | | | | 1 | | | | | | 5 | 6
Karnofsky Scale | | | 1 | 1 | | 1 | | | 1 | 1 | | 5
Peak Pain Relief | | 2 | | | | | 1 | 2 | | | | 5
PPID | 1 | 4 | | | | | | | | | | 5
Global Efficacy of Interventions 3pt scale | | 2 | 2 | | | 1 | | | | | | 5
Side Effect Scale 4pt | | 1 | 3 | | | | | | | 1 | | 5
Global Evaluation (1-5) | | 4 | 1 | | | | | | | | | 5

Table 9. Frequency of use, fatigue assessment scales

Table 10. Frequency of use, fatigue assessment instruments by cancer type

Table 10. Frequency of use, fatigue assessment instruments by cancer type

Cancer | EORTC | VAS | MFI | POMS | FACT | Piper | GLQ-8 | Rhoten | Symptom Distress | Yoshitake | Pearson-Byars | SF-36 | Total
Breast | 5 | 5 | 4 | 4 | 1 | 4 | 1 | | 2 | 1 | 2 | 1 | 30
Lung | 3 | 5 | 2 | 2 | 1 | | 1 | 1 | 1 | 1 | | | 17
Prostate | 2 | 3 | 4 | 1 | | 1 | | 1 | | | | | 12
Gynecological | 2 | | 3 | 2 | 1 | | 1 | | | | | | 9
Lymphoma | 1 | | 3 | 1 | 1 | | 1 | 1 | 1 | | | | 9
Colorectal | 1 | 2 | | 1 | 1 | | | 1 | | | | | 6
GI | 1 | 3 | 1 | 1 | | | | | | | | | 6
Hodgkin's | 2 | 1 | 1 | | | | | | | | | | 4
Melanoma | 1 | | | 1 | | 1 | | | 1 | | | | 4
Myeloma | 1 | 2 | | | | | | | | 1 | | | 4
Head and Neck | | | 1 | 1 | | | | | | | | | 2
Leukemia | | | | | 1 | | | 1 | | | | | 2
Brain | | | | 1 | | | | | | | | | 1
Liver | | | | 1 | | | | | | | | | 1
Oral | 1 | | | | | | | | | | | | 1
Skin | 1 | | | | | | | | | | | | 1
Stomach | | | | 1 | | | | | | | | | 1
Testicular | | | | | | | 1 | | | | | | 1
Bladder | | | | | | | | | | | | | 0
Total | 21 | 21 | 19 | 17 | 6 | 6 | 5 | 5 | 5 | 3 | 2 | 1

Table 11. Grading of randomized controlled trials comparing an NSAID with another NSAID or to placebo

Table 11. Grading of randomized controlled trials comparing an NSAID with another NSAID or to placebo

Author/year Unique Identifier | Study Size* | Baseline pain (VAS 0-10 cm) | Effect Size | Internal Validity | Applicability
Pannuti 1999 | 138 | 2 "moderate" (median, VRS scale) 5.3 cm (mean, VAS scale, range 1-10) | ± | A | A

Table 12. Summary table of randomized controlled trials evaluating adjuvant analgesics in the management of cancer pain.

Table 12. Summary table of randomized controlled trials evaluating adjuvant analgesics in the management of cancer pain

Number of studies | Patients enrolled/evaluated | Internal Validity | Applicability
6 | 224/212(92.4% evaluable) | A = 4 B = 2 C = 0 | A = 1 B = 5 C = 0

Table 13. Grading of randomized controlled trials evaluating adjuvant analgesics in the management of cancer pain.

Table 13. Grading of randomized controlled trials evaluating adjuvant analgesics in the management of cancer pain

Author/year Unique Identifier | Study Size* | Baseline pain (VAS 0-10 cm) | Effect Size | Internal Validity | Applicability
Adjuvants - Breakthrough pain (N=1)
Portenoy et al., 1999 99165545 | 65(65) | Mean (±SD) 4.6 ± 2.5 (0-10 numeric scale) | ± | A | A
Adjuvants - Spinal local anesthetics and other agents (N=5)
Dahm et al., 2000 20462757 | 21(9) | Not stated | ± (more doses of ropivacaine than bupivacaine used for the same degree of pain relief) | A | B
Lauretti, 1999 99287592 | 48(48) | Mean (±Variance*) 8.5 ± 1.5 control group 9 ± 1 ketamine group 8.3 ± 1.2 neostigmine group 9.4 ± 0.8 midazolam group *the expression of variance is not mentioned | + (ketamine and neostigmine better than control and midazolam) | A | B
Van Dongen, 1999 99452099 | 20(20) | Mean (±SD) 7 ± 1.3 morphine group 9 ± 1 morphine/bupivacaine group 7.7 ± 1.5 | + (the slopes of regression curves between m and M plus B differ significantly from day 10 to day 45) | B | B
Mercadante, 2000 99032200 | 10(10) | Mean (±SD) 6.6 ± 0.6 ketamine 0.25 mg/kg 5.9 ± 0.5 ketamine 0.5 mg/kg 6.5 ± 0.54 saline | ++ | A | B
Lauretti, 1999 99287592 | 60(60) | Before oral morphine treatment Control: 7.6±1.9 Dipyrone: 7.6± 1.7 Ketamine: 7.4±1.5 Nitroglycerin: 7.9±1.6 VAS>=4 at initiation of study drug administration | + (oral ketamine and transdermal nitroglycerin produced a significantly lower morphine consumption than dipyrone or additional morphine | B | B

Table 14. Summary of the evidence from randomized controlled trials comparing the efficacy of one opioid with another (or a different formulation of the same) opioid, administered through the same or different route and/or the same or different dosing schedules.

Table 14. Summary of the evidence from randomized controlled trials comparing the efficacy of one opioid with another (or a different formulation of the same) opioid, administered through the same or different route and/or the same or different dosing schedules

Number of studies | Patients enrolled/evaluated | Internal Validity | Applicability
6 | 263/205 (77.9% evaluable) | A = 4 B = 2 C = 0 I = 0 | A = 2 B = 4 C = 0 I = 0

Table 15. Summary of comparisons performed in randomized controlled trials reporting on efficacy and/or adverse effects, comparing an opioid with another opioid.

Table 15. Summary of comparisons performed in randomized controlled trials reporting on efficacy and/or adverse effects, comparing an opioid with another opioid

Author/year Unique Identifier | Opioid | Control | Route(s)/Modes of administration
Moolenaar, 2000 20407008 | Morphine (MSR-controlled release suppository) | Morphine (MSC-oral tablets) | Oral, rectal
Heiskanen, 2000 21075895 | Oxycodone (CR) | Morphine (CR) | Oral
Hunt, 1999 99414499 | Fentanyl | Morphine | Subcutaneous
Bruera, 1999 99349918 | Morphine (CR-suppository) | Morphine (CR-suppository) | Rectal (different administration schedule; 12-hourly and once daily)
Mercadante, 1998 99032200 | Methadone | Morphine | Oral
Parris, 1998 99019888 | Oxycodone (CR) | Oxycodone (IR) | Oral

Table 16. Grading of individual randomized controlled trials reporting on the effects of opioid with another (or the same) opioid, administered through the same or different routes/modes/schedules of administration.

Table 16. Grading of individual randomized controlled trials reporting on the effects of opioid with another (or the same) opioid, administered through the same or different routes/modes/schedules of administration

Author/year Unique Identifier | Study Size* | Baseline pain (VAS 0-10 cm) | Effect Size | Internal Validity | Applicability
Moolenaar, 2000 20407008 | 25(25) | NR | ± | A | B
Heiskanen, 2000 21075895 | 45(45) | Pain intensity at baseline none or slight and escape analgesic doses <=2 per day. Baseline pain intensity was reached after a titration period | ± | A | B
Hunt, 1999 99414499 | 30(23) | NR | ± | A | B
Bruera, 1999 99349918 | 12(6) | NR | ± | B | B
Mercadante, 1998 99032200 | 40(40) | NR | ++ | B | A
Parris, 1998 99019888 | 111(66) | Mean (±SE) 1.5 ± 0.1 CR Oxycodone 1.3 ± 01IR Oxycodone (0-3, 0=none, 1=slight, 2=moderated, 3=severe) | ± | A | A

Table 17. Summary of the evidence from randomized controlled trials reporting on the relative efficacy of bisphosphonates (various doses) or bisphophonates versus placebo.

Table 17. Summary of the evidence from randomized controlled trials reporting on the relative efficacy of bisphosphonates (various doses) or bisphophonates versus placebo

Number of studies | Patients enrolled/evaluated | Internal Validity | Applicability
5 | 1437/1371 (95.4% evaluable) | A = 2 B = 3 C = 0 I = 0 | A = 3 B = 2 C = 0 I = 0

Table 18. Grading of individual randomized controlled trials reporting on the relative efficacy of bisphosphonates (various doses) or bisphophonates versus placebo.

Table 18. Grading of individual randomized controlled trials reporting on the relative efficacy of bisphosphonates (various doses) or bisphophonates versus placebo

Author/year Unique Identifier | Study Size* | Baseline pain (VAS 0-10 cm) | Effect Size | Internal Validity | Applicability
Tian 1999 99134535 | 160(105) | NR | ++ | B | B
Arican 1999 99456328 | 53(50) | NR | ++ | B | B
Lipton 2000 20164356 | 750(750) | NR | +++ | A | A
Hultborn 1999 20095088 | 404(404) | NR | +++ | B | A
Koeberle 1999 99124160 | 70(62) | Severe pain:67mm Moderate pain:36mm | +++ | A | A

Table 19. Summary of the evidence from randomized controlled trials reporting on the efficacy of chemotherapeutic drugs in the management of cancer pain.

Table 19. Summary of the evidence from randomized controlled trials reporting on the efficacy of chemotherapeutic drugs in the management of cancer pain

Number of studies | Patients enrolled/evaluated | Internal Validity | Applicability
7 | 1379/1334 (96.73% evaluable) | A = 2 B = 4 C = 0 I = 0 | A = 6 B = 0 C = 0 I = 0

Table 20. Grading of individual randomized controlled trials reporting on the efficacy of chemotherapeutic drugs in the management of cancer pain.

Table 20. Grading of individual randomized controlled trials reporting on the efficacy of chemotherapeutic drugs in the management of cancer pain

Author/year Unique Identifier | Study Size* | Baseline pain (VAS 0-10 cm) | Effect Size | Internal Validity | Applicability
Kantoff, 1999 20030045 | 242(234) | NR | + | B | A
Osoba, 1999 20029930 | 161(161) | NR | +++ | B | A
Kramer, 2000 20389254 | 331(294) | Not VAS | ++ | B | A
Small, 2000 20200496 | 458(458) | Suramin+HC=4.0 Placebo+HC= 3.9 | +++ | A | A
Fossa, 2000 20229671 | 113(113) | Not VAS | + | B | A
Riccardi, 2000 20184074 | 74(74) | NR | + | A | A

Table 21. Summary of the evidence from randomized controlled trials reporting on the efficacy of external-beam radiation in the management of cancer pain.

Table 21. Summary of the evidence from randomized controlled trials reporting on the efficacy of external-beam radiation in the management of cancer pain

Number of studies | Patients enrolled/evaluated | Internal Validity | Applicability
4 | 2859/2770(96.8% evaluable) | A = 0 B = 4 C = 0 I = 0 | A = 1 B = 8 C = 8 I = 0

Table 22. Grading of individual randomized controlled trials reporting on the efficacy of external-beam radiation in the management of cancer pain.

Table 22. Grading of individual randomized controlled trials reporting on the efficacy of external-beam radiation in the management of cancer pain

Author/year Unique Identifier | Study Size | Baseline pain (VAS 0-10 cm) | Effect Size | Internal Validity | Applicability
"The bone pain trial working party," 1999 20043645 | 761(761) | None: 32 (4%) Mild: 211 (29%) Moderate: 325 (44%) Severe: 168 (23%) Pain score on a 4-point graded scale (none, mild, moderate, severe) | ± | B | A
Roos, 2000 20171357 | 90(90) | Mild: 16% Moderate: 42% Severe: 38% Unknown: 3% Pain score on a 4-point graded scale (none, mild, moderate, severe) | + | B | B
Steenland, 1999 20043644 | 1171(1157) | Mean = 6.30 | ± | B | A
Whelan, 1999 20283039 | 837(762) | Not stated | + | B | A

Table 23. Grading of individual randomized controlled trials reporting on the efficacy of various physical treatments (reflexology and acupuncture) in the management of cancer pain.

Table 23. Grading of individual randomized controlled trials reporting on the efficacy of various physical treatments (reflexology and acupuncture) in the management of cancer pain

Author/year Unique Identifier | Study Size* | Baseline pain (VAS 0-10 cm) | Effect Size | Internal Validity | Applicability
Stephenson, 2000 | 23 | 20 (mean) | ± | B | B
Wen, 1998 | 48 | NR | ± | I | B

Table 24. Summary of the evidence from randomized controlled trials reporting on the efficacy of cognitive behavioral interventions in the management of cancer pain.

Table 24. Summary of the evidence from randomized controlled trials reporting on the efficacy of cognitive behavioral interventions in the management of cancer pain

Number of studies | Patients enrolled/evaluated | Internal Validity | Applicability
4 | 390/350 (89.74% evaluable) | A = 1 B = 3 C = 0 I = 0 | A = 0 B = 3 C = 0 I = 1

Table 25. Grading of individual randomized controlled trials reporting on the efficacy of cognitive behavioral interventions in the management of cancer pain.

Table 25. Grading of individual randomized controlled trials reporting on the efficacy of cognitive behavioral interventions in the management of cancer pain

Author/year Unique Identifier | Study Size* | Baseline pain (VAS 0-10 cm) | Effect Size | Internal Validity | Applicability
Clotfelder, 1999 99120134 | 60(53) | 14.2 experimental 17.5 control | ++ | B | B
De Wit, 1999 20029919 | 159 | 2.4 average pain | -* | B | I
Du Pen, 1999 99385437 | 96 (81) | 3.5 baseline, 6.1 worst (experimental group) 3.5 baseline, 6.0 worst (control group) | + | A | B
Ward, 2000 20505578 | 43 (25) | 3.33 experimental group 4.56 control | ± | B | B

*Not enough information in the article to assign a score for effect size

Table 26. Comparisons of active treatment versus placebo/no treatment for treatment of mucositis (absent vs present).

Table 26. Comparisons of active treatment versus placebo/no treatment for treatment of mucositis (absent vs present)

Treatment/studies | Relative Risk [95% CI]
Chlorhexidine Dodd 1996 Ferreti 1988 Ferreti 1990 Wahlin 1989 Subtotal | 0.91 [0.57, 1.45] 0.26 [0.06, 1.09] 0.10 [0.01, 0.73] 1.14 [0.57, 2.29] 0.70 [0.49, 1.01]
Ice chips Cascinu 1994 Mahood 1991 Subtotal | 0.64 [0.37, 1.08] 0.54 [0.38, 0.76] 0.57 [0.43, 0.77]
Prostaglandin Duenas 1996 Labar 1993 Subtotal | 3.11 [0.94, 10.27] 0.94 [0.84, 1.05] 1.09 [0.92, 1.29]
Glutamine Jebb 1994 Subtotal | 0.82 [0.46, 1.45] 0.82 [0.46, 1.45]
Chamomile Fidler 1996 Subtotal | 0.79 [0.58, 1.07] 0.79 [0.58, 1.07]
Allopurinol mouthrinse Loprinzi 1990 Subtotal | 1.49 [1.10, 2.03] 1.49 [1.10, 2.03]

Table 27. Comparisons of active treatment versus placebo/no treatment for treatment of mucositis (grade 0-2 versus 3+).

Table 27. Comparisons of active treatment versus placebo/no treatment for treatment of mucositis (grade 0-2 versus 3+)

Treatment/studies | Relative Risk [95% CI]
Ice chips Cascinu 1994 Mahood 1991 Subtotal | 0.36 [0.12, 1.07] 0.43 [0.19, 0.97] 0.40 [0.21, 0.77]
Prostaglandin Labar 1993 Subtotal | 1.06 [0.66, 1.70] 1.06 [0.66, 1.70]
Glutamine Jebb 1994 Subtotal | 1.25 [0.40, 3.87] 1.25 [0.40, 3.87]
Sucralfate Shenep 1988 Subtotal | 0.33 [0.10, 1.08] 0.33 [0.10, 1.08]
CM-CSF (molgramostrim) Cartee 1995 Subtotal | 1.88 [0.52, 6.76] 1.88 [0.52, 6.76]
Chamomile Fidler 1996 Subtotal | 1.49 [0.51, 4.31] 1.49 [0.51, 4.31]
Allopurinol mouthrinse Loprinzi 1990 Subtotal | 1.13 [0.54, 2.34] 1.13 [0.54, 2.34]

Table 28. Grading of individual randomized controlled trials reporting on the effects of prophylactic antiviral treatments against zoster pain and PHN.

Table 28. Grading of individual randomized controlled trials reporting on the effects of prophylactic antiviral treatments against zoster pain and PHN

Author/year Unique Identifier | Study Size* | Baseline pain (VAS 0-10 cm) | Effect Size | Internal Validity | Applicability
Betts/1975 75181958 | 60 | NA | - | B | B
Ch'ien/1976 76216149 | 87 | NA | None | C | C
Merigan/1978 78156258 | 90 | NA | + | B | B
Stevens/1980 80108369 | 97 | NA | ± | B | B
Merigan/1981 81230966 | 32 | NA | ± | B | B
Whitley/1982 82272286 | 121 | NA | + | B | B
Balfour/1983 84032170 | 20 | NA | + | C | I
Shepp/1986 86092132 | 22 | NA | + | B | B
Leyland-Jones/1986 86279775 | 34 | NA | + | B | B

Table 29. Summary of randomized controlled trials comparing various treatments of herpes with respect to zoster pain and Postherpetic Neuralgia (PHN) in cancer patients.

Table 29. Summary of randomized controlled trials comparing various treatments of herpes with respect to zoster pain and Postherpetic Neuralgia (PHN) in cancer patients

Author Year UI | Treatments compared | Conclusion based on any pain outcomes
Betts/1975 75181958 | Cytarabine versus placebo | Cytarabine was worse compared to placebo
Ch'ien/1976 76216149 | Adenine arabinoside (ara-A) versus placebo | No conclusion can be drawn by this study.
Merigan/1978 78156258 | Interferon (three doses) versus placebo (Three studies) | Interferon beneficial compared to placebo.
Stevens/1980 80108369 | Pooled gamma-globulin [NSG] versus zoster immune globulin [ZIG] | There was no difference between the two active treatments
Merigan/1981 81230966 | Interferon versus placebo (albumin) | Interferon treatment marginally beneficial compared to placebo
Whitley/1982 82272286 | Vidarabine versus placebo | Vidarabine beneficial compared to placebo
Shepp/1986 86092132 | Acyclovir versus vidarabine | Acyclovir superior to vidarabine
Leyland-Jones/1986 86279775 | 2'-Fluoro-5-iodoarabinosylcytosine (FIAC) versus adenine arabinoside ara-A) | FIAC superior to ara-A

Table 30. Psychopharmacologic Studies of Treatment of Depression in Cancer Double-blind randomized control trialsa

Table 30. Psychopharmacologic Studies of Treatment of Depression in Cancer Double-blind randomized control trialsa

Author Year UI | N | Medication | Results | Methodological Quality | Applicability
Johnston 1972 | 50 | Thioridazine | Better than placebo for depressed mood at 1 week, but not week 3 and 6. Helpful for insomnia and crying spells at all time points (p<.05) | B | A
Purohit 1978 | 39 | Imipramine | 80% imipramine patients Improved, 42% of controls | B | B
Bruera 1985 | 40 | Methylprednisolone | Day 13 MP patients had improved depression (p<.05), day 33 no significant difference with placebo | A | B
Costa 1895 | 73 | Mianserin | Exp. group greater improvement in HDRS (p<.01) and ZSDRS (p<.05) at 4 weeks; significantly more responders on CGI in exp. Group (p<.025) | A | A
Bruera 1986 | 26 | Mazindol | No significant difference with placebo | A | B
Holland 1991 | 147 | Alprazolam vs. progressive muscle relaxation | Both groups improve, alprazolam group significantly more improvement with ABS (p=.04) and HDRS (p=.08) | B | A
Van Heerigen 1996 | 55 | Mianserin | HDRS scores lower than placebo at 2 weeks (p=.056), 4 weeks (p=.004), and 6 weeks (p=.004), number of responders significantly greater than placebo (p<.05) at 4 and 6 weeks | A | B
Eija 1996 | 15 | Amitriptyline | No significant differences | C | C
Razavi 1996 | 115 | Fluoxetine | Both groups improved, no significant difference with placebo | A | I
Razavi 1996 | 91 randomized | Fluoxetine | No significant difference in change in depression scores or percentage of responders (HADS <8) | B | B
Holland 1998 | 37 | Fluoxetine vs. Desipramine | Both groups improved significantly by both scales, no significant differences between drugs | A | A
Razavi 1999 | 27 | Trazodone vs. Clorazepate | By CGI, 91% T group responders, 57% C group, but no significant differences; by HADS scores decreased in both but no significant differences | B | B
Musselman 2001 | 20 per group | Paroxetine | Patoxetine significantly reduced the incidence of depression (p=.04), 11% in paroxetine vs. 45% in control; paroxetine had significant effect on severity of depressive symptoms (p<.001) | A | C

a The Holland, 1991 study is not double-blinded.

Table 31. RCTs of Treatment of Fatigue in Cancer Patients

Table 31. RCTs of Treatment of Fatigue in Cancer Patients

Author Year UI | N | Treatment | Effect | Methodological Quality | Applicability
Spiegel 1981 81206415 | 86 | weekly support group for one year | Declines in vigor and increasing fatigue were seen in control group but not in the treatment group (p<.01). Those who participated in weekly group session for one year had significantly lower scores on POMS fatigue subscale. | C | B
Forester 1985 85094657 | 100 | Psychotherapy | SADS administered at baseline, near midpoint of RT, at end of RT and 4 weeks and 8 weeks post-RT. Only at 4 weeks post RT was there a significantly greater change from baseline fatigue scores in the therapy group compared with control group. | C | I
Decker 1992 92291348 | 82 | Relaxation therapy | Treatment group had a nonsignificant change in fatigue score over the course of treatment, whereas in controls, fatigue increased significantly. | C | I
Mock 1997 97387565 | 46 | Exercise | Exercise group scored significantly higher than usual care group on physical functioning (p=0.003) and symptom intensity, especially fatigue. | B | B
Ahles 1999 99446233 | 34 | Massage vs. quiet time | Borderline significant results for fatigue (p=0.06). Most robust effects at Day -7 assessment (first week of treatment). | C | B
Dimeo 1999 99256640 | 59 | Aerobic exercise (biking) vs. control | No significant differences were present at baseline; control group had significantly more fatigue at discharge compared with baseline (p<0.02), exercise group did not. | B | B
Gaston-Johansson 2000 20395088 | 110 | Comprehensive Coping Strategy Program vs. no treatment | Fatigue significantly less in treatment group compared with control at day 7. Significance disappears in multivariate analysis when controlled for demographic variables and fatigue at day -2. | B | B
Oyama 2000 20440886 | 30 | Bedside Wellness System using virtual reality technology vs. chemo as usual | There was a statistically significant difference between level of fatigue in treatment and control groups after 2 treatments, but not after 1. | C | A
Mock 2001 11879296 PMID | 48 | walking program vs. usual care | Fatigue scores did not differ significantly between exercise and usual care groups at end of treatment. | C | B
Littlewood 2001 21281037 | 251 | Epoetin alfa vs. placebo | There was a strong statistically significant correlation between hemoglobin levels and QOL. The mean increase in hemoglobin level from baseline to last value was significantly greater in the epoetin alfa group than the placebo group (2.2 g/dL v. 0.5 g/dL, P<0.001). Significant differences observed for epoetin for all 5 cancer and anemia-specific primary QOL measures (P<.0048) | A | A