# References and Bibliography

Available from URL: http://www.jcaho.org. 2000.
Oncology. 1999;13:113-47. [pmid: 10370925].
Oncology. 1999;13:113-47. [pmid: 10370925].
Bone Pain Trial Working Party.Radiother Oncol 1999 52(2):111 21 10577696
Bethesda, MD: National Cancer Institute. 1999.
Gastroenterology. 1984;86:116-4.
Abergel RP, Lyons RF, Castel JC et al Biostimulation of wound healing by lasers: experimental approaches in animal models and in fibroblast cultures J Dermatol Surg Oncol 1987 Feb 13(2):127 33
Abergel RP, Meeker CA, Lam TS et al Control of connective tissue metabolism by lasers: recent developments and future prospects J Am Acad Dermatol 1984 Dec 11(6):1142 50
Adamietz IA, Rahn R, Bottcher HD et al [Prevention of radiochemotherapy-induced mucositis. Value of the prophylactic mouth rinsing with PVP-iodine solution] Strahlenther Onkol 1998 Mar 174(3):149 55
Addy M, Wright R Comparison of the in vivo and in vitro antibacterial properties of providone iodine and chlorhexidine gluconate mouthrinses J Clin Periodontol 1978 Aug 5(3):198 205
Ahles TA, Tope DM, Pinkson B et al Massage therapy for patients undergoing autologous bone marrow transplantation J Pain Symptom Manage 1999 Sep 18(3):157 63
Ahles TA, Ruckdeschel JC, Blanchard EB Cancer-related pain--I. Prevalence in an outpatient setting as a function of stage of disease and type of cancer J Psychosom Res 1984 28(2):115 9 6610747
Ahsberg E, Furst CJ Dimensions of fatigue during radiotherapy--an application of the Swedish Occupational Fatigue Inventory (SOFI) on cancer patients Acta Oncol 2001 40(1):37 43 11321658
Akechi T, Kugaya A, Okamura H et al Fatigue and its associated factors in ambulatory cancer patients: a preliminary study J Pain Symptom Manage 1999 Jan 17(1):42 8
Alexander PJ, Dinesh N, Vidyasagar MS Psychiatric morbidity among cancer patients and its relationship with awareness of illness and expectations about treatment outcome Acta Oncol 1993 32(6):623 6 8260179
Allison RR, Vongtama V, Vaughan J et al Symptomatic acute mucositis can be minimized or prophylaxed by the combination of sucralfate and fluconazole Cancer Invest 1995 13(1):16 22 7834470
Alper BS, Lewis PR Does treatment of acute herpes zoster prevent or shorten postherpetic neuralgia? J Fam Pract 2000 Mar 49(3):255 64
Altmann S, Hoffmanns H [Cytoprotection with amifostine in radiotherapy or radio-chemotherapy of head and neck tumors] Strahlenther Onkol 1999 Nov 175Suppl 4:30 3
Diagnostic and Statistical Manual of Mental Disorders. 4thed. Washington, D.C.: American Psychiatric Association. 1994.
Anderson PM, Schroeder G, Skubitz KM Oral glutamine reduces the duration and severity of stomatitis after cytotoxic cancer chemotherapy Cancer 1998 Oct 1 83(7):1433 9
Andrykowski MA, Curran SL, Lightner R Off-treatment fatigue in breast cancer survivors: a controlled comparison J Behav Med 1998 Feb 21(1):1 18
Arican A, Icli F, Akbulut H et al The effect of two different doses of oral clodronate on pain in patients with bone metastases Med Oncol 1999 16(3):204 10 10523801
Arolt V, Fein A, Driessen M et al Depression and social functioning in general hospital in-patients J Psychosom Res 1998 Aug 45(2):117 26
Atkinson A, Barsevick A, Cella D et al NCCN Practice Guidelines for Cancer-Related Fatigue Oncology (Huntingt) 2000 Nov 14(11A):151 61
Balfour HHJ, McMonigal KA, Bean B Acyclovir therapy of varicella-zoster virus infections in immunocompromised patients. [Review] [18 refs] J Antimicrob Chemother 1983 12Suppl B:169 79
Barker G, Loftus L, Cuddy P et al The effects of sucralfate suspension and diphenhydramine syrup plus kaolin-pectin on radiotherapy-induced mucositis Oral Surg Oral Med Oral Pathol 1991 Mar 71(3):288 93
Beach P, Siebeneck B, Buderer NF et al Relationship between fatigue and nutritional status in patients receiving radiation therapy to treat lung cancer Oncol Nurs Forum 2001 Jul 28(6):1027 31
Beck SL, Falkson G Prevalence and management of cancer pain in South Africa Pain 2001 94(1):75 84 11576747
Bensadoun RJ, Franquin JC, Ciais G et al Low-energy He/Ne laser in the prevention of radiation-induced mucositis. A multicenter phase III randomized study in patients with head and neck cancer Support Care Cancer 1999 Jul 7(4):244 52
Berard RM, Boermeester F, Viljoen G Depressive disorders in an out-patient oncology setting: prevalence, assessment, and management Psychooncology 1998 Mar 7(2):112 20
Berger AM, Higginbotham P Correlates of fatigue during and following adjuvant breast cancer chemotherapy: a pilot study Oncol Nurs Forum 2000 Oct 27(9):1443 8
Berger AM Patterns of fatigue and activity and rest during adjuvant breast cancer chemotherapy Oncol Nurs Forum 1998 Jan 25(1):51 62
Berger AM, Kilroy TJ. Oral complications. In: Hellman S and Rosenberg S, editors. Cancer: Principles and practice of oncology. Philadelphia: Lippincott-Raven. 1997:p. 2714-25.
Bernabei R, Gambassi G, Lapane K et al Management of pain in elderly patients with cancer. SAGE Study Group. Systematic Assessment of Geriatric Drug Use via Epidemiology [see comments] JAMA 1998 279(23):1877 82 9634258
Bernhoft CH, Skaug N Oral findings in irradiated edentulous patients Int J Oral Surg 1985 Oct 14(5):416 27
Betts RF, Zaky DA, Douglas RG et al Ineffectiveness of subcutaneous cytosine arabinoside in localized herpes zoster Ann Intern Med 1975 82(6):778 83 166586
Bindemann S, Soukop M, Kaye SB Randomised controlled study of relaxation training Eur J Cancer 1991 27(2):170 4 1827283
Bjordal K, Kaasa S Psychometric validation of the EORTC Core Quality of Life Questionnaire, 30-item version and a diagnosis-specific module for head and neck cancer patients Acta Oncol 1992 31(3):311 21 1622651
Bodey GP, Samonis G, Rolston K Prophylaxis of candidiasis in cancer patients Semin Oncol 1990 Jun 17(3 Suppl 6):24 8
Bonica JJ. The Management of Pain. 2nded. Philadelphia: Lea & Febiger. 1990.
Bonica JJ. Treatment of cancer pain: current status and future need. In: Fields HL, Dubner R, and Cervero R, editors. Advances in pain research and therapy. New York: Raven Press, Ltd. 1985.
Bottomley A Depression in cancer patients: a literature review. [Review] [105 refs] Eur J Cancer Care (Engl) 1998 Sep 7(3):181 91
Bower JE, Ganz PA, Desmond KA et al Fatigue in breast cancer survivors: occurrence, correlates, and impact on quality of life J Clin Oncol 2000 Feb 18(4):743 53
Breitbart W, Rosenfeld B, Kaim M et al A randomized, double-blind, placebo-controlled trial of psychostimulants for the treatment of fatigue in ambulatory patients with human immunodeficiency virus disease Arch Intern Med 2001 Feb 12 161(3):411 20
Breitbart W, Rosenfeld B, Pessin H et al Depression, hopelessness, and desire for hastened death in terminally ill patients with cancer JAMA 2000 Dec 13 284(22):2907 11
Brescia FJ, Portenoy RK, Ryan M et al Pain, opioid use, and survival in hospitalized patients with advanced cancer J Clin Oncol 1992 10(1):149 55 1345797
Bridge LR, Benson P, Pietroni PC et al Relaxation and imagery in the treatment of breast cancer BMJ 1988 Nov 5 297(6657):1169 72
Brincker H Prevention of mycosis in granulocytopenic patients with prophylactic ketoconazole treatment Mykosen 1983 May 26(5):242 7
Brincker H Prophylactic treatment with miconazole in patients highly predisposed to fungal infection. A placebo-controlled double-blind study Acta Med Scand 1978 204(1-2):123 8 356523
Broeckel JA, Jacobsen PB, Horton J et al Characteristics and correlates of fatigue after adjuvant chemotherapy for breast cancer J Clin Oncol 1998 May 16(5):1689 96
Browman GP, Cripps C, Hodson DI et al Placebo-controlled randomized trial of infusional fluorouracil during standard radiotherapy in locally advanced head and neck cancer J Clin Oncol 1994 Dec 12(12):2648 53
Bruera E, Belzile M, Neumann CM et al Twice-daily versus once-daily morphine sulphate controlled-release suppositories for the treatment of cancer pain. A randomized controlled trial Support Care Cancer 1999 7(4):280 3 10423055
Bruera E, Brenneis C, Michaud M et al Association between asthenia and nutritional status, lean body mass, anemia, psychological status, and tumor mass in patients with advanced breast cancer J Pain Symptom Manage 1989 Jun 4(2):59 63
Bruera E, Brenneis C, Michaud M et al Use of the subcutaneous route for the administration of narcotics in patients with cancer pain Cancer 1988 Jul 62(2):407 11
Bruera E, Carraro S, Roca E et al Double-blind evaluation of the effects of mazindol on pain, depression, anxiety, appetite, and activity in terminal cancer patients Cancer Treat Rep 1986 Feb 70(2):295 8
Bruera E, Roca E, Cedaro L et al Action of oral methylprednisolone in terminal cancer patients: a prospective randomized double-blind study Cancer Treat Rep 1985 Jul 69(7-8):751 4
Buchanan AG, Riben PD, Rayner EN et al Nystatin prophylaxis of fungal colonization and infection in granulocytopenic patients: correlation of colonization and clinical outcome Clin Invest Med 1985 8(2):139 47 3879598
Bukberg J, Penman D, Holland JC Depression in hospitalized cancer patients Psychosom Med 1984 May 46(3):199 212
Buntzel J, Glatzel M, Schuth J et al [Cytoprotection with amifostine in the framework of radiochemotherapy in previously irradiated head and neck carcinoma] Strahlenther Onkol 1999 Nov 175Suppl 4:37 40
Buntzel J, Kuttner K, Frohlich D et al Selective cytoprotection with amifostine in concurrent radiochemotherapy for head and neck cancer Ann Oncol 1998 May 9(5):505 9
Butow P, Coates A, Dunn S et al On the receiving end. IV: Validation of quality of life indicators Ann Oncol 1991 Sep 2(8):597 603
Capizzi RL The preclinical basis for broad-spectrum selective cytoprotection of normal tissues from cytotoxic therapies by amifostine Semin Oncol 1999 Apr 26(2 Suppl 7):3 21
Caraceni, A., Portenoy, R. K. and and a Working Group of the IASP Task Force on Cancer Pain. An International Survey of Cancer Pain Characteristics and Syndromes. Pain. 1999. Ref Type: In Press.
Carl W, Havens J The cancer patient with severe mucositis Curr Rev Pain 2000 4(3):197 202 10998733
Carnel SB, Blakeslee DB, Oswald SG et al Treatment of radiation- and chemotherapy-induced stomatitis Otolaryngol Head Neck Surg 1990 Apr 102(4):326 30
Carr DB, Jacox AK, Chapman CR et al. Acute pain management: operative or medical procedures and trauma. Clinical Practice Guideline No. 1 AHCPR pub. No 92-0032. Rockville, MD: Agency for Health Care Policy and Research, U.S. Department of Health and Human Services. 1992.
Cartee L, Petros WP, Rosner GL et al Evaluation of GM-CSF mouthwash for prevention of chemotherapy-induced mucositis: a randomized, double-blind, dose-ranging study Cytokine 1995 Jul 7(5):471 7
Carter DL, Hebert ME, Smink K et al Double blind randomized trial of sucralfate vs placebo during radical radiotherapy for head and neck cancers Head Neck 1999 Dec 21(8):760 6
Cascinu S, Fedeli A, Fedeli SL et al Oral cooling (cryotherapy), an effective treatment for the prevention of 5-fluorouracil-induced stomatitis Eur J Cancer B Oral Oncol 1994 Jul 30B(4):234 6
Caselli D, Arico M, Michelone G et al Antifungal chemoprophylaxis in cancer children: a prospective randomized controlled study Microbiologica 1990 Oct 13(4):347 51
Cassem NH. Depressed patients. In: Cassem NH, Stern TA, and Rosenbaum JF, editors. Massachusetts General Hospital Handbook of General Hospital Psychiatry. St. Louis: Mosby. 1997.
Cella D, Davis K, Breitbart W et al Cancer-related fatigue: prevalence of proposed diagnostic criteria in a United States sample of cancer survivors J Clin Oncol 2001 Jul 15 19(14):3385 91
Cella D The Functional Assessment of Cancer Therapy-Anemia (FACT-An) Scale: a new tool for the assessment of outcomes in cancer anemia and fatigue Semin Hematol 1997 Jul 34(3 Suppl 2):13 9
Cengiz M, Ozyar E, Ozturk D et al Sucralfate in the prevention of radiation-induced oral mucositis J Clin Gastroenterol 1999 Jan 28(1):40 3
Cervero P, Laird JMA Visceral pain Lancet 1999 353(9170):2145 8 10382712
Ch'ien LT, Whitley RJ, Alford CA et al Adenine arabinoside for therapy of herpes zoster in immunosuppressed patients: preliminary results of a collaborative study J Infect Dis 1976 133Suppl:A184 A191 180198
Chalder T, Berelowitz G, Pawlikowska T et al Development of a fatigue scale J Psychosom Res 1993 37(2):147 53 8463991
Chan CW, Molassiotis A The impact of fatigue on Chinese cancer patients in Hong Kong. [see comments.] Support Care Cancer 2001 Jan 9(1):18 24
Chandrasekar PH, Gatny CM The effect of fluconazole prophylaxis on fungal colonization in neutropenic cancer patients. Bone Marrow Transplantation Team J Antimicrob Chemother 1994 Feb 33(2):309 18
Chang VT, Hwang SS, Feuerman M et al Symptom and quality of life survey of medical oncology patients at a veterans affairs medical center: a role for symptom assessment Cancer 2000 88(5):1175 83 10699909
Chapman CR, Garvin J Suffering: the contributions of persistent pain The Lancet 1999 353(9171):2233 7
Chaturvedi SK, Chandra PS, Channabasavanna SM et al Levels of anxiety and depression in patients receiving radiotherapy in India Psychooncology 1996 5(4):343 6
Chaturvedi SK, Shenoy A, Prasad KM et al Concerns, coping and quality of life in head and neck cancer patients Support Care Cancer 1996 May 4(3):186 90
Chen ML, Chang HK, Yeh CH Anxiety and depression in Taiwanese cancer patients with and without pain J Adv Nurs 2000 Oct 32(4):944 51
Chochinov HM, Tataryn D, Clinch JJ et al Will to live in the terminally ill Lancet 1999 Sep 4 354(9181):816 9
Chochinov HM, Wilson KG, Enns M et al "Are you depressed?" Screening for depression in the terminally ill Am J Psychiatry 1997 May 154(5):674 6
Clarkson JE, Worthington HV, Eden OB Prevention of oral mucositis or oral candidiasis for patients with cancer receiving chemotherapy (excluding head and neck cancer) Cochrane Database Syst Rev 2000(2):
Cleeland CS, Gonin R, Hatfield AK et al Pain and its treatment in outpatients with metastatic cancer N Engl J Med 1994 Mar 3 330(9):592 6
Cleeland CS Barriers to the management of cancer pain Oncology (Huntingt) 1987 Apr 1(2 Suppl):19 26 2484445
Cliff AM, MacDonagh RP Psychosocial morbidity in prostate cancer: II. A comparison of patients and partners BJU Int 2000 Nov 86(7):834 9
Clotfelter CE The effect of an educational intervention on decreasing pain intensity in elderly people with cancer Oncol Nurs Forum 1999 Jan 26(1):27 33
Collins JJ, Byrnes ME, Dunkel IJ et al The measurement of symptoms in children with cancer J Pain Symptom Manage 2000 May 19(5):363 77
Colon EA, Callies AL, Popkin MK et al Depressed mood and other variables related to bone marrow transplantation survival in acute leukemia Psychosomatics 1991 32(4):420 5 1961856
Conley BA, Ord RA Current status of retinoids in chemoprevention of oral squamous cell carcinoma: an overview J Craniomaxillofac Surg 1996 Dec 24(6):339 45
Cook DJ, Sackett DL, Spitzer WO Methodologic guidelines for systematic reviews of randomized control trials in health care from the Potsdam Consultation on Meta-Analysis J Clin Epidemiol 1995 Jan 48(1):167 71
Costa D, Mogos I, Toma T. Efficacy and safety of mianserin in the treatment of depression of women with cancer. Acta Psychiatr Scand Suppl. 1985;320:85-92. [pmid: 3901675].
Coyle N, Adelhardt J, Foley KM et al Character of terminal illness in the advanced cancer patient: pain and other symptoms during the last four weeks of life [see comments] J Pain Symptom Manage 1990 5(2):83 93 2348092
Crosby V, Wilcock A, Corcoran R The safety and efficacy of a single dose (500 mg or 1 g) of intravenous magnesium sulfate in neuropathic pain poorly responsive to strong opioid analgesics in patients with cancer J Pain Symptom Manage 2000 19(1):35 9 10687324
Curt GA, Breitbart W, Cella D et al Impact of cancer-related fatigue on the lives of patients: new findings from the Fatigue Coalition Oncologist 2000 5(5):353 60 11040270
Cuttner J, Troy KM, Funaro L et al Clotrimazole treatment for prevention of oral candidiasis in patients with acute leukemia undergoing chemotherapy. Results of a double-blind study Am J Med 1986 Nov 81(5):771 4
Dahm P, Lundborg C, Janson M et al Comparison of 0.5% intrathecal bupivacaine with 0.5% intrathecal ropivacaine in the treatment of refractory cancer and noncancer pain conditions: results from a prospective, crossover, double-blind, randomized study Reg Anesth Pain Med 2000 Sep 25(5):480 7
Daut RL, Cleeland CS, Flanery RC Development of the Wisconsin Brief Pain Questionnaire to assess pain in cancer and other diseases Pain 1983 Oct 17(2):197 210
Daut RL, Cleeland CS The prevalence and severity of pain in cancer Cancer 1982 50(9):1913 8 7116316
Davar G, Hans G, Fareed MU et al Behavioral signs of acute pain produced by application of endothelin-1 to rat sciatic nerve Neuroreport 1998 Jul 13 9(10):2279 83
De Pauw BE Practical modalities for prevention of fungal infections in cancer patients Eur J Clin Microbiol Infect Dis 1997 Jan 16(1):32 41
de Wit R, van Dam F, Abu-Saad HH et al Empirical comparison of commonly used measures to evaluate pain treatment in cancer patients with chronic pain J Clin Oncol 1999 Apr 17(4):128 0
de Wit R, van Dam F, Hanneman M et al Evaluation of the use of a pain diary in chronic cancer pain patients at home Pain 1999 Jan 79(1):89 99
Dean GE, Spears L, Ferrell BR et al Fatigue in patients with cancer receiving interferon alpha Cancer Pract 1995 May 3(3):164 72
Decker TW, Cline-Elsen J, Gallagher M Relaxation therapy as an adjunct in radiation oncology J Clin Psychol 1992 May 48(3):388 93
Demetri GD, Kris M, Wade J et al Quality-of-life benefit in chemotherapy patients treated with epoetin alfa is independent of disease response or tumor type: results from a prospective community oncology study. Procrit Study Group J Clin Oncol 1998 Oct 16(10):3412 25
Denning DW, Donnelly JP, Hellreigel KP et al Antifungal prophylaxis during neutropenia or allogeneic bone marrow transplantation: what is the state of the art? Ad HOC Working Group Chemotherapy 1992 38Suppl 1:43 9 1611930
Derogatis LR, Morrow GR, Fetting J et al The prevalence of psychiatric disorders among cancer patients JAMA 1983 Feb 11 249(6):751 7
DerSimonian R, Laird N Meta-analysis in clinical trials Control Clin Trials 1986 Sep 7(3):177 88
Devine EC, Westlake SK The effects of psychoeducational care provided to adults with cancer: meta-analysis of 116 studies Oncol Nurs Forum 1995 Oct 22(9):1369 81
Diel IJ, Solomayer EF, Costa SD et al Reduction in new metastases in breast cancer with adjuvant clodronate treatment [see comments] N Engl J Med 1998 339(6):357 63 9691101
Dimeo F, Rumberger BG, Keul J Aerobic exercise as therapy for cancer fatigue Med Sci Sports Exerc 1998 Apr 30(4):475 8
Dimeo F, Bertz H, Finke J et al An aerobic exercise program for patients with haematological malignancies after bone marrow transplantation Bone Marrow Transplant 1996 Dec 18(6):1157 60
Dimeo FC, Stieglitz RD, Novelli-Fischer U et al Effects of physical activity on the fatigue and psychologic status of cancer patients during chemotherapy Cancer 1999 May 15 85(10):2273 7
Dodd MJ, Dibble S, Miaskowski C et al A comparison of the affective state and quality of life of chemotherapy patients who do and do not develop chemotherapy-induced oral mucositis J Pain Symptom Manage 2001 Jun 21(6):498 505
Dodd MJ, Miaskowski C, Shiba GH et al Risk factors for chemotherapy-induced oral mucositis: dental appliances, oral hygiene, previous oral lesions, and history of smoking Cancer Invest 1999 17(4):278 84 10225008
Dodd MJ, Larson PJ, Dibble SL et al Randomized clinical trial of chlorhexidine versus placebo for prevention of oral mucositis in patients receiving chemotherapy Oncol Nurs Forum 1996 Jul 23(6):921 7
Donnelly S, Walsh D, Rybicki L The symptoms of advanced cancer: identification of clinical and research priorities by assessment of prevalence and severity J Palliat Care 1995 11(1):27 32
Dorr W, Jacubek A, Kummermehr J et al Effects of stimulated repopulation on oral mucositis during conventional radiotherapy Radiother Oncol 1995 Nov 37(2):100 7
Du Pen SL, Du Pen AR, Polissar N et al Implementing guidelines for cancer pain management: results of a randomized controlled clinical trial J Clin Oncol 1999 Jan 17(1):361 70
Duenas-Gonzalez A, Sobrevilla-Calvo P, Frias-Mendivil M et al Misoprostol prophylaxis for high-dose chemotherapy-induced mucositis: a randomized double-blind study Bone Marrow Transplant 1996 May 17(5):809 12
Egger M, Smith GD, Phillips AN Meta-analysis: principles and procedures BMJ 1997 Dec 6 315(7121):1533 7
Eija K, Tiina T, Pertti NJ Amitriptyline effectively relieves neuropathic pain following treatment of breast cancer Pain 1996 Feb 64(2):293 302
Eisenberg E, Berkey CS, Carr DB et al Efficacy and safety of nonsteroidal antiinflammatory drugs for cancer pain: a meta-analysis J Clin Oncol 1994 Dec 12(12):2756 65
Emanuel EJ, Fairclough DL, Daniels ER et al Euthanasia and physician-assisted suicide: attitudes and experiences of oncology patients, oncologists, and the public. [see comments.] Lancet 1996 Jun 29 347(9018):1805 10
Endicott J Measurement of depression in patients with cancer Cancer 1984 May 15 53(10 Suppl):2243 9 6704912
Epstein JB, Wong FL The efficacy of sucralfate suspension in the prevention of oral mucositis due to radiation therapy Int J Radiat Oncol Biol Phys 1994 Feb 1 28(3):693 8
Epstein JB, Vickars L, Spinelli J et al Efficacy of chlorhexidine and nystatin rinses in prevention of oral complications in leukemia and bone marrow transplantation Oral Surg Oral Med Oral Pathol 1992 Jun 73(6):682 9
Epstein JB, Stevenson-Moore P, Jackson S et al Prevention of oral mucositis in radiation therapy: a controlled study with benzydamine hydrochloride rinse Int J Radiat Oncol Biol Phys 1989 Jun 16(6):1571 5
Epstein JB, Stevenson-Moore P Benzydamine hydrochloride in prevention and management of pain in oral mucositis associated with radiation therapy Oral Surg Oral Med Oral Pathol 1986 Aug 62(2):145 8
Epstein JB. Benzydamine HCL in prevention of oropharyngeal mucositis in radiation therapy: Literature review and clinical study. Res Clin Forum. 1986;10:91-7.
Espie CA, Freedlander E, Campsie LM et al Psychological distress at follow-up after major surgery for intra-oral cancer J Psychosom Res 1989 33(4):441 8 2795516
Evans DL, McCartney CF, Nemeroff CB et al Depression in women treated for gynecological cancer: clinical and neuroendocrine assessment Am J Psychiatry 1986 Apr 143(4):447 52
Fawzy FI, Cousins N, Fawzy NW et al A structured psychiatric intervention for cancer patients. I. Changes over time in methods of coping and affective disturbance Arch Gen Psychiatry 1990 Aug 47(8):720 5
Feber T Management of mucositis in oral irradiation Clin Oncol (R Coll Radiol) 1996 8(2):106 11 8859608
Felson DT Bias in meta-analytic research J Clin Epidemiol 1992 Aug 45(8):885 92 1624971
Ferrell BR, Ferrell BA. Pain in the Elderly. A report of the Task Force on Pain in the Elderly of the International Association for the Study of Pain. Seattle: IASP Press. 1996.
Ferretti GA, Raybould TP, Brown AT et al Chlorhexidine prophylaxis for chemotherapy- and radiotherapy-induced stomatitis: a randomized double-blind trial Oral Surg Oral Med Oral Pathol 1990 Mar 69(3):331 8
Ferretti GA, Ash RC, Brown AT et al Control of oral mucositis and candidiasis in marrow transplantation: a prospective, double-blind trial of chlorhexidine digluconate oral rinse Bone Marrow Transplant 1988 Sep 3(5):483 93
Ferretti GA, Ash RC, Brown AT et al Chlorhexidine for prophylaxis against oral infections and associated complications in patients receiving bone marrow transplants J Am Dent Assoc 1987 Apr 114(4):461 7
Fidler P, Loprinzi CL, O'Fallon JR et al Prospective evaluation of a chamomile mouthwash for prevention of 5-FU-induced oral mucositis Cancer 1996 Feb 1 77(3):522 5
Field MJ, Cassel CKe. Approaching death. Improving care at end of life. Institude of Medicine. Washington, D.C.: National Academy Press. 1997.
Foley KM The treatment of cancer pain N Engl J Med 1985 313(2):84 95 2582259
Foote RL, Loprinzi CL, Frank AR et al Randomized trial of a chlorhexidine mouthwash for alleviation of radiation-induced mucositis J Clin Oncol 1994 Dec 12(12):2630 3
Forester B, Kornfeld DS, Fleiss JL Psychotherapy during radiotherapy: effects on emotional and physical distress Am J Psychiatry 1985 Jan 142(1):22 7
Fossa SD, Curran D, Aaronson NK et al Quality of life of patients with newly diagnosed poor prognosis M1 prostate cancer undergoing orchiectomy without or with mitomycin C. Results from the EORTC Phase-III trial 30893 Eur Urol 2000 37(5):541 51 10765092
Franzen L, Henriksson R, Littbrand B et al Effects of sucralfate on mucositis during and following radiotherapy of malignancies in the head and neck region. A double-blind placebo-controlled study Acta Oncol 1995 34(2):219 23 7718260
Fuccella LM, Conti F, Corvi G et al Double-blind study of the analgesic effect of indoprofen (K 4277) Clin Pharmacol Ther 1975 17(3):277 83 47280
Furst CJ, Ahsberg E Dimensions of fatigue during radiotherapy. An application of the Multidimensional Fatigue Inventory Support Care Cancer 2001 Jul 9(5):355 60
Gabrilove JL, Cleeland CS, Livingston RB et al Clinical evaluation of once-weekly dosing of epoetin alfa in chemotherapy patients: improvements in hemoglobin and quality of life are similar to three-times-weekly dosing J Clin Oncol 2001 Jun 1 19(11):2875 82
Gaston-Johansson F, Fall-Dickson JM, Nanda J et al The effectiveness of the comprehensive coping strategy program on clinical outcomes in breast cancer autologous bone marrow transplantation Cancer Nurs 2000 Aug 23(4):277 85
Gaston-Johansson F, Fall-Dickson JM, Bakos AB et al Fatigue, pain, and depression in pre-autotransplant breast cancer patients Cancer Pract 1999 Sep 7(5):240 7
Geels P, Eisenhauer E, Bezjak A et al Palliative effect of chemotherapy: objective tumor response is associated with symptom improvement in patients with metastatic breast cancer J Clin Oncol 2000 18(12):2395 405 10856099
Ger LP, Ho ST, Wang JJ et al The prevalence and severity of cancer pain: a study of newly-diagnosed cancer patients in Taiwan J Pain Symptom Manage 1998 15(5):285 93 9654833
Gerteis MG, Edgman-Levitan S, Daley J et al. Through the patient's eyes. Understanding and promoting patient-centered care. The Jossey-Bass Health Series. San Francisco: Jossey-Bass Publishers. 1999.
Gessner U, Koeberle D, Thuerlimann B et al Economic analysis of terminal care for patients with malignant osteolytic bone disease and pain treated with pamidronate Support Care Cancer 2000 8(2):115 22 10739358
Gilbert MR, Grossman SA Incidence and nature of neurologic problems in patients with solid tumors Am J Med 1986 81(6):951 4 3799654
Girod SC, Pfahl M Retinoid actions and implications for prevention and therapy of oral cancer Int J Oral Maxillofac Surg 1996 Feb 25(1):69 73
Given CW, Given B, Azzouz F et al Predictors of pain and fatigue in the year following diagnosis among elderly cancer patients J Pain Symptom Manage 2001 Jun 21(6):456 66
Glaspy J, Bukowski R, Steinberg D et al Impact of therapy with epoetin alfa on clinical outcomes in patients with nonmyeloid malignancies during cancer chemotherapy in community oncology practice. Procrit Study Group J Clin Oncol 1997 Mar 15(3):1218 34
Glaus A, Crow R, Hammond S A qualitative study to explore the concept of fatigue/tiredness in cancer patients and in healthy individuals. [see comments.] Support Care Cancer 1996 Mar 4(2):82 96
Glaus A Assessment of fatigue in cancer and non-cancer patients and in healthy individuals. [see comments.] Support Care Cancer 1993 Nov 1(6):305 15
Golden RN, McCartney CF, Haggerty JJ, Jr. et al The detection of depression by patient self-report in women with gynecologic cancer International Journal of Psychiatry in Medicine 1991 21(1):17 27 2066254
Goudas L, Carr DB, Bloch R et al. Management of Cancer Pain. Evidence Report/Technology Assessment No. 35 (Prepared by the New England Medical Center Evidence-based Practice Center under Contract No 290-97-0019). AHRQ Publication No. 02-E002. Rockville, MD: Agency for Healthcare Research and Quality; 2001.
Grandi S, Eava GA, Cunsoln A et al. Major depression associated with masectomy. Med Sci Res. 1987;15:283-4.
Grassi L, Indelli M, Marzola M et al Depressive symptoms and quality of life in home-care-assisted cancer patients J Pain Symptom Manage 1996 Nov 12(5):300 7
Greenberg DB, Gray JL, Mannix CM et al Treatment-related fatigue and serum interleukin-1 levels in patients during external beam irradiation for prostate cancer J Pain Symptom Manage 1993 May 8(4):196 200
Greenberg DB, Sawicka J, Eisenthal S et al Fatigue syndrome due to localized radiation J Pain Symptom Manage 1992 Jan 7(1):38 45
Greenwald HP, Bonica JJ, Bergner M The prevalence of pain in four cancers Cancer 1987 60(10):2563 9 2444328
Gregoire G, Derderian F, Le Lorier J Selecting the language of the publications included in a meta-analysis: is there a Tower of Babel bias? J Clin Epidemiol 1995 Jan 48(1):159 63
Groenvold M, Fayers PM, Sprangers MA et al Anxiety and depression in breast cancer patients at low risk of recurrence compared with the general population: a valid comparison? J Clin Epidemiol 1999 Jun 52(6):523 30
Grond S, Radbruch L, Meuser T et al Assessment and treatment of neuropathic cancer pain following WHO guidelines Pain 1999 79(1):15 20 9928771
Grond S, Zech D, Diefenbach C et al Assessment of cancer pain: a prospective evaluation in 2266 cancer patients referred to a pain service Pain 1996 64(1):107 14 8867252
Groopman JE, Molina JM, Scadden DT Hematopoietic growth factors. Biology and clinical applications N Engl J Med 1989 Nov 23 321(21):1449 59
Hall A, A'Hern R, Fallowfield L Are we using appropriate self-report questionnaires for detecting anxiety and depression in women with early breast cancer? Eur J Cancer 1999 Jan 35(1):79 85
Hammerlid E, Ahlner-Elmqvist M, Bjordal K et al A prospective multicentre study in Sweden and Norway of mental distress and psychiatric morbidity in head and neck cancer patients Br J Cancer 1999 May 80(5-6):766 74
Hann DM, Garovoy N, Finkelstein B et al Fatigue and quality of life in breast cancer patients undergoing autologous stem cell transplantation: a longitudinal comparative study J Pain Symptom Manage 1999 May 17(5):311 9
Hann DM, Jacobsen PB, Azzarello LM et al Measurement of fatigue in cancer patients: development and validation of the Fatigue Symptom Inventory Qual Life Res 1998 May 7(4):301 10
Hanson WR, Marks JE, Reddy SP et al. Protection from radiation-induced oral mucositis by a mouth rinse containing the prostaglandin E1 analog, Misoprostol: A placebo-controlled double blind trial. In: Honn K, editors. Eicosanoids and other bioactive lipids in cancer, inflammation and radiation injury 2. New York: Plenum Press. 1997.
Hanson WR, Marks JE, Reddy SP et al Protection from Radiation-Induced Oral Mucositis by Misoprostol, a Prostaglandin E(1) Analog: A Placebo-Controlled, Double-Blind Clinical Trial Am J Ther 1995 Nov 2(11):850 7
Hardman A, Maguire P, Crowther D The recognition of psychiatric morbidity on a medical oncology ward J Psychosom Res 1989 33(2):235 9 2724199
Heiskanen TE, Ruismaki PM, Seppala TA et al Morphine or oxycodone in cancer pain? Acta Oncol 2000 39(8):941 7 11207001
Helgason S, Petursson G, Gudmundsson S et al Prevalence of postherpetic neuralgia after a first episode of herpes zoster: prospective study with long term follow up BMJ 2000 Sep 30 321(7264):794 6 27491
Henderson JM, Ord RA Suicide in head and neck cancer patients J Oral Maxillofac Surg 1997 Nov 55(11):1217 21
Henry DH, Brooks BJ, Jr., Case DC, Jr. et al Recombinant Human Erythropoietin Therapy for Anemic Cancer Patients Receiving Cisplatin Chemotherapy Cancer J Sci Am 1995 Nov 1(4):25 2
Herrmann C, Brand-Driehorst S, Kaminsky B et al Diagnostic groups and depressed mood as predictors of 22-month mortality in medical inpatients Psychosom Med 1998 Sep 60(5):570 7
Hickok JT, Morrow GR, McDonald S et al Frequency and correlates of fatigue in lung cancer patients receiving radiation therapy: implications for management J Pain Symptom Manage 1996 Jun 11(6):370 7
Higginson IJ, Hearn J A multicenter evaluation of cancer pain control by palliative care teams. [Review] [41 refs] J Pain Symptom Manage 1997 14(1):29 35 9223840
Hiraga K, Mizuguchi T, Takeda F The incidence of cancer pain and improvement of pain management in Japan Postgraduate Medical Journal 1991 67Suppl 2:S14 S25 1758814
Hjermstad MJ, Loge JH, Evensen SA et al The course of anxiety and depression during the first year after allogeneic or autologous stem cell transplantation Bone Marrow Transplant 1999 Dec 24(11):1219 28
Hjermstad MJ, Fossa SD, Bjordal K et al Test/retest study of the European Organization for Research and Treatment of Cancer Core Quality-of-Life Questionnaire J Clin Oncol 1995 May 13(5):1249 54
Holland JC, Romano SJ, Heiligenstein JH et al A controlled trial of fluoxetine and desipramine in depressed women with advanced cancer Psycho-Oncology 1998 Jul 7(4):291 300
Holland JC, Morrow GR, Schmale A et al A randomized clinical trial of alprazolam versus progressive muscle relaxation in cancer patients with anxiety and depressive symptoms J Clin Oncol 1991 Jun 9(6):1004 11
Holley S, Borger D Energy for living with cancer: preliminary findings of a cancer rehabilitation group intervention study Oncol Nurs Forum 2001 Oct 28(9):1393 6
Holley SK Evaluating patient distress from cancer-related fatigue: an instrument development study Oncol Nurs Forum 2000 Oct 27(9):1425 31
Hopwood P, Stephens RJ Depression in patients with lung cancer: prevalence and risk factors derived from quality-of-life data J Clin Oncol 2000 Feb 18(4):893 903
Hopwood P, Howell A, Maguire P Screening for psychiatric morbidity in patients with advanced breast cancer: validation of two self-report questionnaires Br J Cancer 1991 Aug 64(2):353 6
Hopwood P, Howell A, Maguire P Psychiatric morbidity in patients with advanced cancer of the breast: prevalence measured by two self-rating questionnaires Br J Cancer 1991 Aug 64(2):349 52
Horiot JC, Le Fur R, N'Guyen T et al Hyperfractionation versus conventional fractionation in oropharyngeal carcinoma: final analysis of a randomized trial of the EORTC cooperative group of radiotherapy Radiother Oncol 1992 Dec 25(4):231 41
Howell SJ, Radford JA, Smets EM et al Fatigue, sexual function and mood following treatment for haematological malignancy: the impact of mild Leydig cell dysfunction Br J Cancer 2000 Feb 82(4):789 93
Huang EY, Leung SW, Wang CJ et al Oral glutamine to alleviate radiation-induced oral mucositis: a pilot randomized trial Int J Radiat Oncol Biol Phys 2000 Feb 1 46(3):535 9
Hultborn R, Gundersen S, Ryden S et al Efficacy of pamidronate in breast cancer with bone metastases: a randomized, double-blind placebo-controlled multicenter study Anticancer Res 1999 Jul 19(4C):3383 92
Hunt R, Fazekas B, Thorne D et al A comparison of subcutaneous morphine and fentanyl in hospice cancer patients J Pain Symptom Manage 1999 Aug 18(2):111 9
Hurny C, Bernhard J, Joss R et al "Fatigue and malaise" as a quality-of-life indicator in small-cell lung cancer patients. The Swiss Group for Clinical Cancer Research (SAKK). [see comments.] Support Care Cancer 1993 Nov 1(6):316 20
Ibbotson T, Maguire P, Selby P et al Screening for anxiety and depression in cancer patients: the effects of disease and treatment Eur J Cancer 1994 30A(1):37 40 8142161
Irvine D, Vincent L, Graydon JE et al The prevalence and correlates of fatigue in patients receiving treatment with chemotherapy and radiotherapy. A comparison with the fatigue experienced by healthy individuals Cancer Nurs 1994 Oct 17(5):367 78
Irvine DM, Vincent L, Graydon JE et al Fatigue in women with breast cancer receiving radiation therapy Cancer Nurs 1998 Apr 21(2):127 35
Jackson JL, Gibbons R, Meyer G et al The effect of treating herpes zoster with oral acyclovir in preventing postherpetic neuralgia. A meta-analysis Arch Intern Med 1997 Apr 28 157(8):909 12
Jacobsen PB, Hann DM, Azzarello LM et al Fatigue in women receiving adjuvant chemotherapy for breast cancer: characteristics, course, and correlates J Pain Symptom Manage 1999 Oct 18(4):233 42
Jacox A, Carr DB, Payne R et al. Management of Cancer Pain. Clinical Practice Guideline. AHCPR Publication No. 94-0592ed. Rockville: Agency for Health Care Policy and Research. U.S. Department of Health and Human Services. 1994.
Jadad-Bechara AR. Meta-analysis of randomised clinical trials in pain relief [Doctoral thesis]. Oxford: University of Oxford. 1994.
Jadad AR, Moore RA, Carroll D et al Assessing the quality of reports of randomized clinical trials: is blinding necessary? Control Clin Trials 1996 Feb 17(1):1 12
Jansen SJ, Stiggelbout AM, Nooij MA et al Response shift in quality of life measurement in early-stage breast cancer patients undergoing radiotherapy Qual Life Res 2000 9(6):603 15 11236851
Jebb SA, Osborne RJ, Maughan TS et al 5-fluorouracil and folinic acid-induced mucositis: no effect of oral glutamine supplementation Br J Cancer 1994 Oct 70(4):732 5
Johnston B Relief of mixed anxiety-depression in terminal cancer patients. Effect of thioridazine New York State Journal of Medicine 1972 Sep 15 72(18):2315 7
Joly F, Henry-Amar M, Arveux P et al Late psychosocial sequelae in Hodgkin's disease survivors: a French population-based case-control study J Clin Oncol 1996 Sep 14(9):2444 53
Jones R, Pearson J, McGregor S et al Randomised trial of personalised computer based information for cancer patients BMJ 1999 Nov 6 319(7219):1241 7 28275
Joranson DE, Gilson AM, Dahl JL et al Pain management, controlled substances, and state medical board policy: a decade of change J Pain Symptom Manage 2002 Feb 23(2):138 47
Joranson DE, Gilson AM Regulatory barriers to pain management Semin Oncol Nurs 1998 May 14(2):158 63
Kaanders JH, Pop LA, Uitterhoeve RJ et al. Prevention of irradiation mucositis in the oral cavity and oropharynx by PTA lozenges. In: editors. 35th Annual ASTRO Meeting. New Orleans: Pergamon Press. 1993.
Kaasa S, Loge JH, Knobel H et al Fatigue. Measures and relation to pain Acta Anaesthesiol Scand 1999 Oct 43(9):939 47
Kaasa S, Bjordal K, Aaronson N et al The EORTC core quality of life questionnaire (QLQ-C30): validity and reliability when analysed with patients treated with palliative radiotherapy Eur J Cancer 1995 Dec 31A(13-14):2260 3
Kalso E, Tasmuth T, Neuvonen PJ Amitriptyline effectively relieves neuropathic pain following treatment of breast cancer Pain 1996 Feb 64(2):293 302
Kannan V, Bapsy PP, Anantha N et al Efficacy and safety of granulocyte macrophage-colony stimulating factor (GM-CSF) on the frequency and severity of radiation mucositis in patients with head and neck carcinoma Int J Radiat Oncol Biol Phys 1997 Mar 15 37(5):1005 10
Kantoff PW, Halabi S, Conaway M et al Hydrocortisone with or without mitoxantrone in men with hormone-refractory prostate cancer: results of the cancer and leukemia group B 9182 study J Clin Oncol 1999 Aug 17(8):2506 13
Karthaus M, Rosenthal C, Huebner G et al Effect of topical oral G-CSF on oral mucositis: a randomised placebo-controlled trial Bone Marrow Transplant 1998 22(8):781 5 9827976
Kathol RG, Mutgi A, Williams J et al Diagnosis of major depression in cancer patients according to four sets of criteria Am J Psychiatry 1990 Aug 147(8):1021 4
Kelsen DP, Portenoy RK, Thaler HT et al Pain and depression in patients with newly diagnosed pancreas cancer J Clin Oncol 1995 13(3):748 55 7884435
Kessler RC, McGonagle KA, Zhao S et al Lifetime and 12-month prevalence of DSM-III-R psychiatric disorders in the United States. Results from the National Comorbidity Survey Arch Gen Psychiatry 1994 Jan 51(1):8 19
Kharchenko OV, Cernjuk VN, Butovich IA [Inhibitory effect of linoleyl-hydroxamic acid on the oxidation of linoleic acid by 12-lipoxygenase from porcine leukocytes] Ukr Biokhim Zh 1999 Jan 71(1):33 7
Kim JH, Chu F, Lakshmi V et al A clinical study of benzydamine for the treatment of radiotherapy-induced mucositis of the oropharynx Int J Tissue React 1985 7(3):215 8 3899970
King KB, Nail LM, Kreamer K et al Patients' descriptions of the experience of receiving radiation therapy Oncol Nurs Forum 1985 Jul 12(4):55 61
Klimberg VS, Souba WW, Dolson DJ et al Prophylactic glutamine protects the intestinal mucosa from radiation injury Cancer 1990 Jul 1 66(1):62 8
Knobel H, Havard LJ, Brit LM et al Late medical complications and fatigue in Hodgkin's disease survivors J Clin Oncol 2001 Jul 1 19(13):3226 33
Knobel H, Loge JH, Nordoy T et al High level of fatigue in lymphoma patients treated with high dose therapy J Pain Symptom Manage 2000 Jun 19(6):446 56
Knobf MT Physical and psychologic distress associated with adjuvant chemotherapy in women with breast cancer J Clin Oncol 1986 May 4(5):678 84
Kobashi-Schoot JA, Hanewald GJ, van Dam FS et al Assessment of malaise in cancer patients treated with radiotherapy Cancer Nurs 1985 Dec 8(6):306 13
Koeberle D, Bacchus L, Thuerlimann B et al Pamidronate treatment in patients with malignant osteolytic bone disease and pain: a prospective randomized double-blind trial [see comments] Support Care Cancer 1999 7(1):21 7 9926970
Kramer JA, Curran D, Piccart M et al Randomised trial of paclitaxel versus doxorubicin as first-line chemotherapy for advanced breast cancer: quality of life evaluation using the EORTC QLQ-C30 and the Rotterdam symptom checklist Eur J Cancer 2000 36(12):1488 97 10930796
Kyriaki M, Eleni T, Efi P et al The EORTC core quality of life questionnaire (QLQ-C30, version 3.0) in terminally ill cancer patients under palliative care: validity and reliability in a Hellenic sample Int J Cancer 2001 Oct 1 94(1):135 9
Labar B, Mrsic M, Pavletic Z et al Prostaglandin E2 for prophylaxis of oral mucositis following BMT Bone Marrow Transplant 1993 May 11(5):379 82
Lancaster T, Silagy C, Gray S Primary care management of acute herpes zoster: systematic review of evidence from randomized controlled trials Br J Gen Pract 1995 Jan 45(390):39 45
Landis SH, Bolden S, Wingo PA Cancer Statistics CA: A Cancer Journal for Clinicians 1999 49(1):8 11 10200775
Lang SS, Patt RB. You Don't Have to Suffer. A Complete Guide to Relieving Cancer Pain for Patients and Their Families. New York: Oxford University Press. 1994.
Langendijk JA, Aaronson NK, de Jong JM et al Prospective study on quality of life before and after radical radiotherapy in non-small-cell lung cancer J Clin Oncol 2001 Apr 15 19(8):2123 33
Larue F, Colleau SM, Brasseur L et al Multicentre study of cancer pain and its treatment in France [see comments] BMJ 1995 310(6986):1034 7 7728056
Lau J, Ioannidis JP, Schmid CH Quantitative synthesis in systematic reviews Ann Intern Med 1997 Nov 1 127(9):820 6
Lauretti GR, Lima IC, Reis MP et al Oral ketamine and transdermal nitroglycerin as analgesic adjuvants to oral morphine therapy for cancer pain management Anesthesiology 1999 Jun 90(6):1528 33
Lauretti GR, Gomes JM, Reis MP et al Low doses of epidural ketamine or neostigmine, but not midazolam, improve morphine analgesia in epidural terminal cancer pain therapy J Clin Anesth 1999 Dec 11(8):663 8
Lees N, Lloyd-Williams M Assessing depression in palliative care patients using the visual analogue scale: a pilot study Eur J Cancer Care (Engl) 1999 Dec 8(4):220 3
Lever SA, Dupuis LL, Chan HS Comparative evaluation of benzydamine oral rinse in children with antineoplastic-induced stomatitis Drug Intell Clin Pharm 1987 Apr 21(4):359 61
Leyland-Jones B, Donnelly H, Groshen S et al 2'-Fluoro-5-iodoarabinosylcytosine, a new potent antiviral agent: efficacy in immunosuppressed individuals with herpes zoster J Infect Dis 1986 154(3):430 6 3525694
Lievens Y, Haustermans K, Van den WD et al Does sucralfate reduce the acute side-effects in head and neck cancer treated with radiotherapy? A double-blind randomized trial Radiother Oncol 1998 May 47(2):149 53
Liossi C, Hatira P Clinical hypnosis versus cognitive behavioral training for pain management with pediatric cancer patients undergoing bone marrow aspirations Int J Clin Exp Hypn 1999 47(2):104 16 10208073
Lipton A, Theriault RL, Hortobagyi GN et al Pamidronate prevents skeletal complications and is effective palliative treatment in women with breast carcinoma and osteolytic bone metastases: long term follow-up of two randomized, placebo-controlled trials Cancer 2000 88(5):1082 90 10699899
Littlewood TJ, Bajetta E, Nortier JW et al Effects of epoetin alfa on hematologic parameters and quality of life in cancer patients receiving nonplatinum chemotherapy: results of a randomized, double-blind, placebo-controlled trial J Clin Oncol 2001 Jun 1 19(11):2865 74
Loeser JD, Melzack R Pain: an overview Lancet 1999 353(9164):1607 9 10334273
Loge JH, Abrahamsen AF, Ekeberg O et al Fatigue and psychiatric morbidity among Hodgkin's disease survivors J Pain Symptom Manage 2000 Feb 19(2):91 9
Loge JH, Abrahamsen AF, Ekeberg O et al Hodgkin's disease survivors more fatigued than the general population J Clin Oncol 1999 Jan 17(1):253 61
Lojeski E, Stevens RA Postherpetic neuralgia in the cancer patient. [Review] [93 refs] Current Review of Pain 2000 4(3):219 26 10998737
Lojeski E, Stevens RA. Postherpetic Neuralgia in the Cancer Patient. Current Review of Pain. 2000;4:219-26. [pmid: 10998737].
Longman AJ, Braden CJ, Mishel MH Side effects burden in women with breast cancer Cancer Pract 1996 Sep 4(5):274 80
Loprinzi CL, Cianflone SG, Dose AM et al A controlled evaluation of an allopurinol mouthwash as prophylaxis against 5-fluorouracil-induced stomatitis Cancer 1990 Apr 15 65(8):1879 82
Lortholary O, Dupont B Antifungal prophylaxis during neutropenia and immunodeficiency Clin Microbiol Rev 1997 Jul 10(3):477 504 172931
Lovely MP, Miaskowski C, Dodd M Relationship between fatigue and quality of life in patients with glioblastoma multiformae Oncol Nurs Forum 1999 Jun 26(5):921 5
Ludwig H, Sundal E, Pecherstorfer M et al Recombinant human erythropoietin for the correction of cancer associated anemia with and without concomitant cytotoxic chemotherapy. [see comments.] Cancer 1995 Dec 1 76(11):2319 29
Lyons RF, Abergel RP, White RA et al Biostimulation of wound healing in vivo by a helium-neon laser Ann Plast Surg 1987 Jan 18(1):47 50
Maciejewski B, Zajusz A, Pilecki B et al Acute mucositis in the stimulated oral mucosa of patients during radiotherapy for head and neck cancer Radiother Oncol 1991 Sep 22(1):7 11
Mahood DJ, Dose AM, Loprinzi CL et al Inhibition of fluorouracil-induced stomatitis by oral cryotherapy J Clin Oncol 1991 Mar 9(3):449 52
Makkonen TA, Minn H, Jekunen A et al Granulocyte macrophage-colony stimulating factor (GM-CSF) and sucralfate in prevention of radiation-induced mucositis: a prospective randomized study Int J Radiat Oncol Biol Phys 2000 Feb 1 46(3):525 34
Makkonen TA, Bostrom P, Vilja P et al Sucralfate mouth washing in the prevention of radiation-induced mucositis: a placebo-controlled double-blind randomized study Int J Radiat Oncol Biol Phys 1994 Aug 30 30(1):177 82
Maraste R, Brandt L, Olsson H et al Anxiety and depression in breast cancer patients at start of adjuvant radiotherapy. Relations to age and type of surgery Acta Oncol 1992 31(6):641 3 1466892
Mardiak J, Bohunicky L, Chovanec J et al Adjuvant clodronate therapy in patients with locally advanced breast cancer--long term results of a double blind randomized trialSlovak Clodronate Collaborative Group.Neoplasma 2000 47(3):177 80 11043842
Martin MV Irradiation mucositis: a reappraisal Eur J Cancer B Oral Oncol 1993 Jan 29B(1):1 2 8180570
Mascarin, M., Franchin, G., Minatel, M., and Miller, T. A The effect of filgrastin (G-CSF) on mucositis in head and neck patients treated with hyperfractionated radiotherapy (RT). Annual Meeting of the American Society of Clinical Oncology 15739.1996 Ref Type: Abstract
Mast ME Correlates of fatigue in survivors of breast cancer Cancer Nurs 1998 Apr 21(2):136 42 9556940
Masucci G New clinical applications of granulocyte-macrophage colony-stimulating factor Med Oncol 1996 Sep 13(3):149 54 9106173
Masucci G, Fernberg JO, Hoglund-Ersin L et al. Beneficial treatment of radiotherapy induced mucositis with rh-GM-CSF in patients with tumors of the oral cavity/oropharynx. Sixth International Congress of Anti-Cancer Treatment Paris, France, 1996. 1996;83.
Matejka M, Nell A, Kment G et al Local benefit of prostaglandin E2 in radiochemotherapy-induced oral mucositis Br J Oral Maxillofac Surg 1990 Apr 28(2):89 91
Matthews RH, Ercal N Prevention of mucositis in irradiated head and neck cancer patients J Exp Ther Oncol 1996 Mar 1(2):135 8
Max B. Collecting Better Data About Drug Treatment?. In: Cohen MJM and Campbell JN, editors. Pain Treatment Centers at the Crossroads: A Practical and Conceptual Reappraisal. Seattle: IASP Press. 1996.
McHugh P, Lewis S, Ford S et al The efficacy of audiotapes in promoting psychological well-being in cancer patients: a randomised, controlled trial Br J Cancer 1995 Feb 71(2):388 92
McIlroy P Radiation mucositis: a new approach to prevention and treatment Eur J Cancer Care (Engl) 1996 Sep 5(3):153 8 9117049
McLachlan SA, Devins GM, Goodwin PJ Factor analysis of the psychosocial items of the EORTC QLQ-C30 in metastatic breast cancer patients participating in a psychosocial intervention study Qual Life Res 1999 Jun 8(4):311 7
McQuay H, Moore A. An evidence-based resource for pain relief. Oxford: Oxford University Press. 1998.
McQuay H, Carroll D, Jadad AR et al Anticonvulsant drugs for management of pain: a systematic review. [see comments.]. [Review] [53 refs] BMJ 1995 Oct 21 311(7012):1047 52
McQuay HJ, Tramer M, Nye BA et al A systematic review of antidepressants in neuropathic pain Pain 1996 Dec 68(2-3):217 27
McQuellon RP, Wells M, Hoffman S et al Reducing distress in cancer patients with an orientation program Psychooncology 1998 May 7(3):207 17
Meek PM, Nail LM, Barsevick A et al Psychometric testing of fatigue instruments for use with cancer patients Nurs Res 2000 Jul 49(4):181 90
Mendoza TR, Wang XS, Cleeland CS et al The rapid assessment of fatigue severity in cancer patients: use of the Brief Fatigue Inventory Cancer 1999 Mar 1 85(5):1186 96
Mercadante S, Ripamonti C, Casuccio A et al Comparison of octreotide and hyoscine butylbromide in controlling gastrointestinal symptoms due to malignant inoperable bowel obstruction Support Care Cancer 2000 8(3):188 91 10789958
Mercadante S, Arcuri E, Tirelli W et al Analgesic effect of intravenous ketamine in cancer patients on morphine therapy: a randomized, controlled, double-blind, crossover, double-dose study J Pain Symptom Manage 2000 Oct 20(4):246 52
Mercadante S, Casuccio A, Agnello A et al Morphine versus methadone in the pain treatment of advanced-cancer patients followed up at home J Clin Oncol 1998 Nov 16(11):3656 61
Mercadante S, Armata M, Salvaggio L Pain characteristics of advanced lung cancer patients referred to a palliative care service Pain 1994 59(1):141 5 7531837
Meredith R, Salter M, Kim R et al Sucralfate for radiation mucositis: results of a double-blind randomized trial Int J Radiat Oncol Biol Phys 1997 Jan 15 37(2):275 9
Merigan TC, Gallagher JG, Pollard RB et al Short-course human leukocyte interferon in treatment of herpes zoster in patients with cancer Antimicrob Agents Chemother 1981 19(1):193 5 181382 6166245
Merigan TC, Rand KH, Pollard RB et al Human leukocyte interferon for the treatment of herpes zoster in patients with cancer N Engl J Med 1978 298(18):981 7 347294
Merlano M, Corvo R, Margarino G et al Combined chemotherapy and radiation therapy in advanced inoperable squamous cell carcinoma of the head and neck. The final report of a randomized trial Cancer 1991 Feb 15 67(4):915 21
Merren MD Gabapentin for treatment of pain and tremor: a large case series South Med J 1998 91(8):739 44 9715219
Meuser T, Pietruck C, Radbruch L et al Symptoms during cancer pain treatment following WHO-guidelines: a longitudinal follow-up study of symptom prevalence, severity and etiology Pain 2001 93(3):247 57 11514084
Meyer TJ, Mark MM Effects of psychosocial interventions with adult cancer patients: a meta-analysis of randomized experiments. [see comments.] Health Psychology 1995 Mar 14(2):101 8
Miaskowski C Biology of mucosal pain J Natl Cancer Inst Monogr 2001(29):37 40
Miaskowski C, Lee KA Pain, fatigue, and sleep disturbances in oncology outpatients receiving radiation therapy for bone metastasis: a pilot study J Pain Symptom Manage 1999 May 17(5):320 32
Miller TA, Jacobson ED Gastrointestinal cytoprotection by prostaglandins Gut 1979 Jan 20(1):75 87
Mills EE The modifying effect of beta-carotene on radiation and chemotherapy induced oral mucositis Br J Cancer 1988 Apr 57(4):416 7
Miser AW, McCalla J, Dothage JA et al Pain as a presenting symptom in children and young adults with newly diagnosed malignancy Pain 1987 29(1):85 90 3588003
Miser AW, Dothage JA, Wesley RA et al The prevalence of pain in a pediatric and young adult cancer population Pain 1987 29(1):73 83 3588002
Mock V, Pickett M, Ropka ME et al Fatigue and Quality of Life Outcomes of Exercise During Cancer Treatment Cancer Pract 2001 May 9(3):119 27
Mock V, Dow KH, Meares CJ et al Effects of exercise on fatigue, physical functioning, and emotional distress during radiation therapy for breast cancer Oncol Nurs Forum 1997 Jul 24(6):991 1000
Moher D, Pham B, Jones A et al Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses? Lancet 1998 Aug 22 352(9128):609 13
Molassiotis A A correlational evaluation of tiredness and lack of energy in survivors of haematological malignancies Eur J Cancer Care (Engl) 1999 Mar 8(1):19 25
Monga U, Kerrigan AJ, Thornby J et al Prospective study of fatigue in localized prostate cancer patients undergoing radiotherapy Radiat Oncol Investig 1999 7(3):178 85
Moolenaar F, Meijler WJ, Frijlink HW et al Clinical efficacy, safety and pharmacokinetics of a newly developed controlled release morphine sulphate suppository in patients with cancer pain Eur J Clin Pharmacol 2000 Jun 56(3):219 23
Moore A, McQuay H, Gavaghan D Deriving dichotomous outcome measures from continuous data in randomised controlled trials of analgesics Pain 1996 Aug 66(2-3):229 37
Morris DB. Illness and Culture in the Postmodern Age. Berkeley: University of California Press. 1998.
Morton RP, Davies AD, Baker J et al Quality of life in treated head and neck cancer patients: a preliminary report Clin Otolaryngol 1984 Jun 9(3):181 5
Mose S, Adamietz IA, Saran F et al Can prophylactic application of immunoglobulin decrease radiotherapy-induced oral mucositis? Am J Clin Oncol 1997 Aug 20(4):407 11
Mulhern RK, Fairclough DL, Douglas SM et al Physical distress and depressive symptomatology among children with cancer Child Health Care 1994 23(3):167 79
Musselman DL, Lawson DH, Gumnick JF et al Paroxetine for the prevention of depression induced by high-dose interferon alfa. [see comments.] N Engl J Med 2001 Mar 29 344(13):961 6
Nagashima R Mechanisms of action of sucralfate J Clin Gastroenterol 1981 3(Suppl 2):117 27 6798100
SEER Cancer Statistics. Available from URL: www.seer.ims.nci.nih.gov (http://seer.cancer.gov/publicdata/). National Institutes of Health. 1999.
A double-blind phase III prospective randomized study of Bacitracin, Clotrimazole, Gentamicin (BCOG) lozenges versus placebo lozenges for radiation-associated mucositis in head and neck cancer. In: editors. NCIC CTG Trial: HN: 2 (Multicentre). 1997.
Newell S, Sanson-Fisher RW, Girgis A et al The physical and psycho-social experiences of patients attending an outpatient medical oncology department: a cross-sectional study Eur J Cancer Care (Engl) 1999 Jun 8(2):73 82
Newell S, Sanson-Fisher RW, Girgis A et al How well do medical oncologists' perceptions reflect their patients' reported physical and psychosocial problems? Data from a survey of five oncologists Cancer 1998 Oct 15 83(8):1640 51
Nicolatou O, Sotiropoulou-Lontou A, Skarlatos J et al A pilot study of the effect of granulocyte-macrophage colony-stimulating factor on oral mucositis in head and neck cancer patients during X-radiation therapy: a preliminary report Int J Radiat Oncol Biol Phys 1998 Oct 1 42(3):551 6
Nordin K, Glimelius B Predicting delayed anxiety and depression in patients with gastrointestinal cancer Br J Cancer 1999 Feb 79(3-4):525 9
Northway MG, Libshitz HI, Osborne BM et al Radiation esophagitis in the opossum: radioprotection with indomethacin Gastroenterology 1980 May 78(5 Pt 1):883 92
Novik Y, Ryan LM, Haller DG et al Phase II protocol for the evaluation of new treatments in patients with advanced gastric carcinoma: results of ECOG 5282 Med Oncol 1999 16(4):261 6 10618689
Oguchi M, Shikama N, Sasaki S et al Mucosa-adhesive water-soluble polymer film for treatment of acute radiation-induced oral mucositis Int J Radiat Oncol Biol Phys 1998 Mar 15 40(5):1033 7
Okuno SH, Foote RL, Loprinzi CL et al A randomized trial of a nonabsorbable antibiotic lozenge given to alleviate radiation-induced mucositis Cancer 1997 Jun 1 79(11):2193 9
Okutomi T, Kato Y, Ichihara H et al [Clinical effects of adjuvant therapy using Z-100 (Ancer 20 injection) for oral cancer--prevention of stomatitis and hematopoietic impairment] Gan To Kagaku Ryoho 2000 Jan 27(1):65 71
Okuyama T, Tanaka K, Akechi T et al Fatigue in ambulatory patients with advanced lung cancer: prevalence, correlated factors, and screening J Pain Symptom Manage 2001 Jul 22(1):554 64
Okuyama T, Akechi T, Kugaya A et al Factors correlated with fatigue in disease-free breast cancer patients: application of the Cancer Fatigue Scale Support Care Cancer 2000 May 8(3):215 22
Okuyama T, Akechi T, Kugaya A et al Development and validation of the cancer fatigue scale: a brief, three-dimensional, self-rating scale for assessment of fatigue in cancer patients J Pain Symptom Manage 2000 Jan 19(1):5 14
Oshitani T, Okada K, Kushima T et al [Clinical evaluation of sodium alginate on oral mucositis associated with radiotherapy] Nippon Gan Chiryo Gakkai Shi 1990 Jun 20 25(6):1129 37
Osoba D, Tannock IF, Ernst DS et al Health-related quality of life in men with metastatic prostate cancer treated with prednisone alone or mitoxantrone and prednisone [see comments] J Clin Oncol 1999 17(6):1654 63 10561201
Ottenweller JE, Natelson BH, Gause WC et al Mouse running activity is lowered by Brucella abortus treatment: a potential model to study chronic fatigue Physiol Behav 1998 Mar 63(5):795 801
Owens NJ, Nightingale CH, Schweizer RT et al Prophylaxis of oral candidiasis with clotrimazole troches Arch Intern Med 1984 Feb 144(2):290 3
Oxman AD, Guyatt GH Guidelines for reading literature reviews CMAJ 1988 Apr 15 138(8):697 703
Oyama H, Kaneda M, Katsumata N et al Using the bedside wellness system during chemotherapy decreases fatigue and emesis in cancer patients J Med Syst 2000 Jun 24(3):173 82
Palmblad J, Lonnqvist B, Carlsson B et al Oral ketoconazole prophylaxis for Candida infections during induction therapy for acute leukaemia in adults: more bacteraemias J Intern Med 1992 Apr 231(4):363 70
Pannuti F, Robustelli C, Ventaffrida V et al A double-blind evaluation of the analgesic efficacy and toxicity of oral ketorolac and diclofenac in cancer pain. The TD/10 recordati Protocol Study Group Tumori 1999 85(2):96 100 10363074
Parris WC, Johnson BW, Jr., Croghan MK et al The use of controlled-release oxycodone for the treatment of chronic cancer pain: a randomized, double-blind study J Pain Symptom Manage 1998 Oct 16(4):205 11
Parsons J. The effect of radiation on normal tissues of the head and neck. In: Million R and Cassisi N, editors. Management of head and neck cancer: A multidisciplinary approach. Philadelphia: JB Lippincott. 1994:p. 245-89.
Parulekar W, Mackenzie R, Bjarnason G et al Scoring oral mucositis Oral Oncol 1998 Jan 34(1):63 71
Pascoe S, Edelman S, Kidman A Prevalence of psychological distress and use of support services by cancer patients at Sydney hospitals Aust NZ J Psychiatry 2000 Oct 34(5):785 91
Passik SD, Kirsh KL, Donaghy KB et al An attempt to employ the Zung Self-Rating Depression Scale as a "lab test" to trigger follow-up in ambulatory oncology clinics: criterion validity and detection J Pain Symptom Manage 2001 Apr 21(4):273 81
Passik SD, Dugan W, McDonald MV et al Oncologists' recognition of depression in their patients with cancer J Clin Oncol 1998 Apr 16(4):1594 600
Pearl ML, Fischer M, McCauley DL et al Transcutaneous electrical nerve stimulation as an adjunct for controlling chemotherapy-induced nausea and vomiting in gynecologic oncology patients Cancer Nurs 1999 22(4):307 11 10452208
Peters K, Mucke R, Hamann D et al Supportive use of amifostine in patients with head and neck tumors undergoing radio-chemotherapy. Is it possible to limit the duration of the application of amifostine? Strahlenther Onkol 1999 Nov 175Suppl 4:23 6
Peters LJ, Ang KK, Thames HD. Altered fractionation schedules. In: Perez C and Brady L, editors. Principles and practice of radiation oncology. Philadelphia: JB Lippincott. 1992:p. 97-113.
Petzke F, Radbruch L, Zech D et al Temporal presentation of chronic cancer pain: transitory pains on admission to a multidisciplinary pain clinic J Pain Symptom Manage 1999 17(6):391 401 10388244
Pfeiffer P, Hansen O, Madsen EL et al A prospective pilot study on the effect of sucralfate mouth-swishing in reducing stomatitis during radiotherapy of the oral cavity Acta Oncol 1990 29(4):471 3
Pfeiffer P, Madsen EL, Hansen O et al Effect of prophylactic sucralfate suspension on stomatitis induced by cancer chemotherapy. A randomized, double-blind cross-over study Acta Oncol 1990 29(2):171 3 1692228
Pillsbury HC, III, Webster WP, Rosenman J Prostaglandin inhibitor and radiotherapy in advanced head and neck cancers Arch Otolaryngol Head Neck Surg 1986 May 112(5):552 3
Pinder KL, Ramirez AJ, Black ME et al Psychiatric disorder in patients with advanced breast cancer: prevalence and associated factors Eur J Cancer 1993 29A(4):524 7 8435204
Pinto LH, Canary PC, Araujo CM et al Prospective randomized trial comparing hyperfractionated versus conventional radiotherapy in stages III and IV oropharyngeal carcinoma Int J Radiat Oncol Biol Phys 1991 Aug 21(3):557 62
Piper BF, Dodd MJ, Ream E. Improving the clinical measurement of cancer treatment-related fatigue. In: editors. Better Health Through Nursing Research: International State of the Science. Washington, D.C.: American Nurses Association. 1999.
Pirl WF, Siegel GI, Goode MJ et al. Depression in men receiving androgen deprivation therapy for prostate cancer: a pilot study. Psychooncology. 2002;11:1-6. [pmid: 11835588].
Porock D, Kristjanson LJ, Tinnelly K et al An exercise intervention for advanced cancer patients experiencing fatigue: a pilot study J Palliat Care 2000 16(3):30 6
Porteder H, Rausch E, Kment G et al Local prostaglandin E2 in patients with oral malignancies undergoing chemo- and radiotherapy J Craniomaxillofac Surg 1988 Nov 16(8):371 4
Portenoy RK, Lesage P. Management of cancer pain. The Lancet. 1999;353:1695-700.
Portenoy RK, Payne R, Coluzzi P et al Oral transmucosal fentanyl citrate (OTFC) for the treatment of breakthrough pain in cancer patients: a controlled dose titration study Pain 1999 Feb 79(2-3):303 12
Portenoy RK, Kornblith AB, Wong G et al Pain in ovarian cancer patients. Prevalence, characteristics, and associated symptoms Cancer 1994 74(3):907 15 8039118
Portenoy RK, Miransky J, Thaler HT et al Pain in ambulatory patients with lung or colon cancer. Prevalence, characteristics, and effect Cancer 1992 70(6):1616 24 1516015
Portenoy RK, Hagen NA Breakthrough pain: definition, prevalence and characteristics [see comments] Pain 1990 41(3):273 81 1697056
Prada A, Chiesa F Effects of benzydamine on the oral mucositis during antineoplastic radiotherapy and/or intra-arterial chemotherapy International Journal of Tissue Reactions 1987 9(2):115 9 3610509
Prada A, Lozza L, Moglia D et al Effects of benzydamine on radio-polychemotherapeutic mucositis of the oral cavity Int J Tissue React 1985 7(3):237 9 3899973
Purohit DR, Navlakha PL, Modi RS et al The role antidepressants in hospitalised cancer patients. (A pilot study) Journal of the Association of Physicians of India 1978 Apr 26(4):245 8
Rahn R, Adamietz IA, Boettcher HD et al Povidone-iodine to prevent mucositis in patients during antineoplastic radiochemotherapy Dermatology 1997 195Suppl 2:57 61
Raletic-Savic J, Zivanovic A, Savic D [Use of prostin E2 in the treatment of stomatitis caused by radiotherapy] Arh Hig Rada Toksikol 1991 Sep 42(3):295 301
Razavi D, Kormoss N, Collard A et al Comparative study of the efficacy and safety of trazodone versus clorazepate in the treatment of adjustment disorders in cancer patients: a pilot study J Int Med Res 1999 27(6):264 72 10726235
Razavi D, Allilaire JF, Smith M et al The effect of fluoxetine on anxiety and depression symptoms in cancer patients Acta Psychiatrica Scandinavica 1996 Sep 94(3):205 10
Razavi D, Delvaux N, Farvacques C et al. Screening for adjustment disorders and major depressive disorders in cancer in-patients. Br J Psychiatry. 1990 Jan;156:79-83.
Redeker NS, Lev EL, Ruggiero J Insomnia, fatigue, anxiety, depression, and quality of life of cancer patients undergoing chemotherapy Sch Inq Nurs Pract 2000 14(4):275 90 11372188
Riccardi A, Tinelli C, Brugnatelli S et al Doubling of the epirubicin dosage within the 5-fluorouracil, epirubicin and cyclophosphamide regimen: a prospective, randomized, multicentric study on antitumor effect and quality of life in advanced breast cancer Int J Oncol 2000 16(4):769 76 10717247
Rice DH, Gill G The effect of irradiation upon the bacterial flora in patients with head and neck cancer Laryngoscope 1979 Nov 89(11):1839 41
Richardson A, Ream E, Wilson-Barnett J Fatigue in patients receiving chemotherapy: patterns of change. [erratum appears in Cancer Nurs 1998 Jun;21(3):195.] Cancer Nurs 1998 Feb 21(1):17 30
Richardson A, Ream EK Self-care behaviours initiated by chemotherapy patients in response to fatigue Int J Nurs Stud 1997 Feb 34(1):35 43
Richardson A Fatigue in cancer patients: a review of the literature. [Review] [93 refs] Eur J Cancer Care (Engl) 1995 Mar 4(1):20 32
Richardson JL, Shelton DR, Krailo M et al The effect of compliance with treatment on survival among patients with hematologic malignancies J Clin Oncol 1990 Feb 8(2):356 64
Robert A Cytoprotection by prostaglandins Gastroenterology 1979 Oct 77(4 Pt 1):761 7 38173
Rolla G, Loe H, Schiott CR Retention of chlorhexidine in the human oral cavity Arch Oral Biol 1971 Sep 16(9):1109 16
Roos DE, O'Brien PC, Smith JG et al A role for radiotherapy in neuropathic bone pain: preliminary response rates from a prospective trial (Trans-tasman radiation oncology group, TROG 96.05) [published erratum appears in Int J Radiat Oncol Biol Phys 2000 May 1;47(2):545] Int J Radiat Oncol Biol Phys 2000 46(4):975 81 10705020
Rosso M, Blasi G, Gherlone E et al Effect of granulocyte-macrophage colony-stimulating factor on prevention of mucositis in head and neck cancer patients treated with chemo-radiotherapy J Chemother 1997 Oct 9(5):382 5
Roth AJ, Kornblith AB, Batel-Copel L et al Rapid screening for psychologic distress in men with prostate carcinoma: a pilot study Cancer 1998 May 15 82(10):1904 8
Rovirosa A, Ferre J, Biete A Granulocyte macrophage-colony-stimulating factor mouthwashes heal oral ulcers during head and neck radiotherapy Int J Radiat Oncol Biol Phys 1998 Jul 1 41(4):747 54
Rowbotham M, Harden N, Stacey B et al Gabapentin for the treatment of postherpetic neuralgia: a randomized controlled trial JAMA 1998 Dec 2 280(21):1837 42
Rusthoven JJ, Ahlgren P, Elhakim T et al Varicella-zoster infection in adult cancer patients. A population study Arch Intern Med 1988 Jul 148(7):1561 6
Samaranayake LP, Robertson AG, MacFarlane TW et al The effect of chlorhexidine and benzydamine mouthwashes on mucositis induced by therapeutic irradiation Clin Radiol 1988 May 39(3):291 4
Samonis G, Rolston K, Karl C et al Prophylaxis of oropharyngeal candidiasis with fluconazole Rev Infect Dis 1990 Mar 12Suppl 3:S369 S373
Santini V, Giles FJ The potential of amifostine: from cytoprotectant to therapeutic agent Haematologica 1999 Nov 84(11):1035 42
Sarhill N, Walsh D, Nelson KA et al Methylphenidate for fatigue in advanced cancer: a prospective open-label pilot study Am J Hosp Palliat Care 2001 May 18(3):187 92
Sarna L, Brecht ML Dimensions of symptom distress in women with advanced lung cancer: a factor analysis Heart Lung 1997 Jan 26(1):23 30
Schechter NL, Berde CB, Yaster M. Pain in Infants, Children, and Adolescents. Baltimore: Williams & Wilkins. 1993.
Scherlacher A, Beaufort-Spontin F [Radiotherapy of head-neck neoplasms: prevention of inflammation of the mucosa by sucralfate treatment] HNO 1990 Jan 38(1):24 8
Schimpff S, Serpick A, Stoler B et al Varicella-Zoster infection in patients with cancer Ann Intern Med 1972 Feb 76(2):241 54
Schneider RA Reliability and validity of the Multidimensional Fatigue Inventory (MFI-20) and the Rhoten Fatigue Scale among rural cancer outpatients Cancer Nurs 1998 Oct 21(5):370 3
Schneider SB, Nishimura RD, Zimmerman RP et al Filgrastim (r-metHuG-CSF) and its potential use in the reduction of radiation-induced oropharyngeal mucositis: an interim look at a randomized, double-blind, placebo-controlled trial Cytokines Cell Mol Ther 1999 Sep 5(3):175 80
Schonekas KG, Wagner W, Prott FJ Amifostine--a radioprotector in locally advanced head and neck tumors Strahlenther Onkol 1999 Nov 175Suppl 4:27 9
Schubert MM, Newton RE The use of benzydamine HCl for the management of cancer therapy-induced mucositis: preliminary report of a multicentre study Int J Tissue React 1987 9(2):99 103 3610519
Schulz KF, Chalmers I, Hayes RJ et al Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials JAMA 1995 Feb 1 273(5):408 12
Schwartz A, Meek P Additional construct validity of the Schwartz Cancer Fatigue Scale J Nurs Meas 1999 7(1):35 45 10394773
Schwartz AL, Mori M, Gao R et al Exercise reduces daily fatigue in women with breast cancer receiving chemotherapy Med Sci Sports Exerc 2001 May 33(5):718 23
Schwartz AL, Nail LM, Chen S et al Fatigue patterns observed in patients receiving chemotherapy and radiotherapy. [see comments.] Cancer Invest 2000 18(1):11 9 10701362
Schwartz AL Daily fatigue patterns and effect of exercise in women with breast cancer Cancer Pract 2000 Jan 8(1):16 24 10732535
Schwei MJ, Honore P, Rogers SD et al Neurochemical and cellular reorganization of the spinal cord in a murine model of bone cancer pain J Neurosci 1999 Dec 15 19(24):10886 97
Schwenk W, Bohm B, Muller JM Postoperative pain and fatigue after laparoscopic or conventional colorectal resections. A prospective randomized trial Surg Endosc 1998 Sep 12(9):1131 6
Segre G, Hammarstrom S Aspects of the mechanisms of action of benzydamine Int J Tissue React 1985 7(3):187 93 4044146
Servaes P, van der WS, Prins J et al Fatigue in disease-free cancer patients compared with fatigue in patients with chronic fatigue syndrome Support Care Cancer 2001 Jan 9(1):11 7
Sheard T, Maguire P The effect of psychological interventions on anxiety and depression in cancer patients: results of two meta-analyses Br J Cancer 1999 Aug 80(11):1770 80
Shenep JL, Kalwinsky DK, Hutson PR et al Efficacy of oral sucralfate suspension in prevention and treatment of chemotherapy-induced mucositis J Pediatr 1988 Oct 113(4):758 63
Shepp DH, Dandliker PS, Meyers JD Treatment of varicella-zoster virus infection in severely immunocompromised patients. A randomized comparison of acyclovir and vidarabine N Engl J Med 1986 314(4):208 12 3001523
Skarstein J, Aass N, Fossa SD et al Anxiety and depression in cancer patients: relation between the Hospital Anxiety and Depression Scale and the European Organization for Research and Treatment of Cancer Core Quality of Life Questionnaire J Psychosom Res 2000 Jul 49(1):27 34
Small EJ, Meyer M, Marshall ME et al Suramin therapy for patients with symptomatic hormone-refractory prostate cancer: results of a randomized phase III trial comparing suramin plus hydrocortisone to placebo plus hydrocortisone J Clin Oncol 2000 Apr 18(7):1440 50
Smets EM, Visser MR, Garssen B et al Understanding the level of fatigue in cancer patients undergoing radiotherapy J Psychosom Res 1998 Sep 45(3):277 93
Smets EM, Visser MR, Willems-Groot AF et al Fatigue and radiotherapy: (B) experience in patients 9 months following treatment Br J Cancer 1998 Oct 78(7):907 12
Smets EM, Garssen B, Bonke B et al The Multidimensional Fatigue Inventory (MFI) psychometric qualities of an instrument to assess fatigue J Psychosom Res 1995 Apr 39(3):315 25
Sneeuw KCA, Aaronson NK, van Wouwe MCC et al. Prevalence and screening of psychiatric disorder in patients with early stage breast cancer [abstract]. [Presented at the International Congress of Psychosocial Oncology, 12-14 October 1992, Beaune, France.]. Qual Life Res. 1993;2:50-1.
Sokal JE, Firat D. Varicella-zoster infection in Hodgkin's disease. Am J Med. 1965;39:452-63. [pmid: 14338296].
Sonis S, Edwards L, Lucey C The biological basis for the attenuation of mucositis: the example of interleukin-11 Leukemia 1999 Jun 13(6):831 4
Sonis S, Clark J Prevention and management of oral mucositis induced by antineoplastic therapy Oncology (Huntingt) 1991 Dec 5(12):11 8
Sonis ST, Eilers JP, Epstein JB et al Validation of a new scoring system for the assessment of clinical trial research of oral mucositis induced by radiation or chemotherapy. Mucositis Study Group Cancer 1999 May 15 85(10):2103 13
Sonis ST Mucositis as a biological process: a new hypothesis for the development of chemotherapy-induced stomatotoxicity Oral Oncol 1998 Jan 34(1):39 43
Sorkin LS. Antibody activation and immune reactions: potential linkage to pain and neuropathy. Pain Medicine. 2000;1:296-302. [pmid: 15101875].
Spiegel D, Kato PM Psychosocial influences on cancer incidence and progression. [Review] [158 refs] Harv Rev Psychiatry 1996 May 4(1):10 26
Spiegel D, Bloom JR, Yalom I Group support for patients with metastatic cancer. A randomized outcome study Arch Gen Psychiatry 1981 May 38(5):527 33
Spijkervet FK, van Saene HK, van Saene JJ et al Mucositis prevention by selective elimination of oral flora in irradiated head and neck cancer patients J Oral Pathol Med 1990 Nov 19(10):486 9
Spijkervet FK, van Saene HK, Panders AK et al Effect of chlorhexidine rinsing on the oropharyngeal ecology in patients with head and neck cancer who have irradiation mucositis Oral Surg Oral Med Oral Pathol 1989 Feb 67(2):154 61
Quality of Life and Pharmacoeconomics in Clinical Trials. 2ed. Philadephia: Lippincott-Raven. 1996.
Steenland E, Leer JW, van Houwelingen H et al The effect of a single fraction compared to multiple fractions on painful bone metastases: a global analysis of the Dutch Bone Metastasis Study [see comments] [published erratum appears in Radiother Oncol 1999 Nov;53(2):167] Radiother Oncol 1999 52(2):101 9 10577695
Stein KD, Martin SC, Hann DM et al A multidimensional measure of fatigue for use with cancer patients Cancer Pract 1998 May 6(3):143 52
Stephenson NL, Weinrich SP, Tavakoli AS The effects of foot reflexology on anxiety and pain in patients with breast and lung cancer Oncol Nurs Forum 2000 Jan 27(1):67 72
Stevens DA, Merigan TC Zoster immune globulin prophylaxis of disseminated zoster in compromised hosts. A randomized trial Arch Intern Med 1980 140(1):52 4 6153260
Stevens PE, Dibble SL, Miaskowski C Prevalence, characteristics, and impact of postmastectomy pain syndrome: an investigation of women's experiences Pain 1995 61(1):61 8 7644250
Stone P, Richardson A, Ream E et al Cancer-related fatigue: inevitable, unimportant and untreatable? Results of a multi-centre patient survey. Cancer Fatigue Forum Ann Oncol 2000 Aug 11(8):971 5
Stone P, Hardy J, Huddart R et al Fatigue in patients with prostate cancer receiving hormone therapy Eur J Cancer 2000 Jun 36(9):1134 41
Stone P, Richards M, A'Hern R et al A study to investigate the prevalence, severity and correlates of fatigue among patients with cancer in comparison with a control group of volunteers without cancer Ann Oncol 2000 May 11(5):561 7
Stone P, Hardy J, Broadley K et al Fatigue in advanced cancer: a prospective controlled cross-sectional study Br J Cancer 1999 Mar 79(9-10):1479 86
Suris JC, Parera N, Puig C Chronic illness and emotional distress in adolescence J Adolesc Health 1996 Aug 19(2):153 6
Sutherland HJ, Lockwood GA, Cunningham AJ A simple, rapid method for assessing psychological distress in cancer patients: Evidence of validity for linear analog scales J Psychosoc Oncol 1989 7(1-2):31 43
Sutherland SE, Browman GP Prophylaxis of oral mucositis in irradiated head-and-neck cancer patients: a proposed classification scheme of interventions and meta-analysis of randomized controlled trials Int J Radiat Oncol Biol Phys 2001 Mar 15 49(4):917 30
Symonds RP, McIlroy P, Khorrami J et al The reduction of radiation mucositis by selective decontamination antibiotic pastilles: a placebo-controlled double-blind trial Br J Cancer 1996 Jul 74(2):312 7
Tanner NS, Stamford IF, Bennett A Plasma prostaglandins in mucositis due to radiotherapy and chemotherapy for head and neck cancer Br J Cancer 1981 Jun 43(6):767 71
Tarnawski A, Hollander D, Krause WJ et al Does sucralfate affect the normal gastric mucosa? Histologic, ultrastructural, and functional assessment in the rat Gastroenterology 1986 Apr 90(4):893 905
Tasmuth T, von Smitten K, Kalso E Pain and other symptoms during the first year after radical and conservative surgery for breast cancer Br J Cancer 1996 74(12):2024 31 8980408
Miller, A. B. (ed.). National Cancer Control Programmes. Policies and Managerial Guidelines. Geneva: World Health Organisation. 1993.
Theriault RL, Lipton A, Hortobagyi GN et al Pamidronate reduces skeletal morbidity in women with advanced breast cancer and lytic bone lesions: a randomized, placebo-controlled trial. Protocol 18 Aredia Breast Cancer Study Group J Clin Oncol 1999 17(3):846 54 10071275
Thomas R, Daly M, Perryman B et al Forewarned is forearmed--benefits of preparatory information on video cassette for patients receiving chemotherapy or radiotherapy--a randomised controlled trial Eur J Cancer 2000 Aug 36(12):1536 43
Tian JH, Zhang JM, Hou QT et al Multicentre trial on the efficacy and toxicity of single-dose samarium-153-ethylene diamine tetramethylene phosphonate as a palliative treatment for painful skeletal metastases in China Eur J Nucl Med 1999 26(1):2 7 9933654
Tombes MB, Gallucci B The effects of hydrogen peroxide rinses on the normal oral mucosa Nurs Res 1993 Nov 42(6):332 7
Trog D, Bank P, Wendt TG et al Daily amifostine given concomitantly to chemoradiation in head and neck cancer. A pilot study Strahlenther Onkol 1999 Sep 175(9):444 9
Twycross RG, Wilcock A. Symptom Management in Advanced Cancer. 3rd ed. Oxon: Radcliffe Medical Press Ltd. 2001.
Twycross RG The measurement of pain in terminal carcinoma J Int Med Res 1976 4(2 Suppl):58 67 67975
Tyring S, Barbarash RA, Nahlik JE et al Famciclovir for the treatment of acute herpes zoster: effects on acute disease and postherpetic neuralgia. A randomized, double-blind, placebo-controlled trial. Collaborative Famciclovir Herpes Zoster Study Group Ann Intern Med 1995 Jul 15 123(2):89 96
US Population Statistics. Available from URL: U.S.Bureau of the Census. U.S.Bureau of the Census. 1999.
Vacha P, Marx M, Engel A et al [Side effects of postoperative radiochemotherapy with amifostine versus radiochemotherapy alone in head and neck tumors. Preliminary results of a prospective randomized trial] Strahlenther Onkol 1999 Nov 175Suppl 4:18 22
Vainio A, Auvinen A Prevalence of symptoms among patients with advanced cancer: an international collaborative study. Symptom Prevalence Group J Pain Symptom Manage 1996 12(1):3 10 8718910
van Dongen RT, Crul BJ, van Egmond J Intrathecal coadministration of bupivacaine diminishes morphine dose progression during long-term intrathecal infusion in cancer patients Clin J Pain 1999 15(3):166 72 10524468
van Heeringen K, Zivkov M Pharmacological treatment of depression in cancer patients. A placebo-controlled study of mianserin British Journal of Psychiatry 1996 Oct 169(4):440 3
Vara-Thorbeck R, Ruiz-Requena E, Guerrero-Fernandez JA Effects of human growth hormone on the catabolic state after surgical trauma Horm Res 1996 45(1-2):55 60
Ventafridda V, Bonezzi C, Caraceni A et al Antidepressants for cancer pain and other painful syndromes with deafferentation component: comparison of amitriptyline and trazodone Ital J Neurol Sci 1987 8(6):579 87 3323130
Verdi CJ Cancer therapy and oral mucositis. An appraisal of drug prophylaxis Drug Saf 1993 Sep 9(3):185 95 8240724
Vogelzang NJ, Breitbart W, Cella D et al Patient, caregiver, and oncologist perceptions of cancer-related fatigue: results of a tripart assessment survey. The Fatigue Coalition Semin Hematol 1997 Jul 34(3 Suppl 2):4 12
Volmink J, Lancaster T, Gray S et al Treatments for postherpetic neuralgia--a systematic review of randomized controlled trials Fam Pract 1996 Feb 13(1):84 91
von Essen L, Enskar K, Kreuger A et al Self-esteem, depression and anxiety among Swedish children and adolescents on and off cancer treatment Acta Paediatr 2000 Feb 89(2):229 36
Vuorinen E Pain as an early symptom in cancer Clin J Pain 1993 9(4):272 8 8118092
Wagner W, Radmard A, Schonekaes KG A new administration schedule for amifostine as a radioprotector in cancer therapy Anticancer Res 1999 May 19(3B):2281 3
Wagner W, Alfrink M, Haus U et al Treatment of irradiation-induced mucositis with growth factors (rhGM-CSF) in patients with head and neck cancer Anticancer Res 1999 Jan 19(1B):799 803
Wagner W, Prott FJ, Schonekas KG Amifostine: a radioprotector in locally advanced head and neck tumors Oncol Rep 1998 Sep 5(5):1255 7
Wahlin YB Effects of chlorhexidine mouthrinse on oral health in patients with acute leukemia Oral Surg Oral Med Oral Pathol 1989 Sep 68(3):279 87
Walker CB Microbiological effects of mouthrinses containing antimicrobials J Clin Periodontol 1988 Sep 15(8):499 505 3053791
Wang XS, Janjan NA, Guo H et al Fatigue during preoperative chemoradiation for resectable rectal cancer Cancer 2001 Sep 15 92(6 Suppl):1725 32
Ward S, Donovan HS, Owen B et al An individualized intervention to overcome patient-related barriers to pain management in women with gynecologic cancers Res Nurs Health 2000 23(5):393 405 11052393
Wen D, Jiebin Y Clinical study on acupuncture treatment of stomach carcinoma pain Journal of Traditional Chinese Medicine 1998 18(1):31 8 10437260
Whelan TJ, Levine M, Julian J et al The effects of radiation therapy on quality of life of women with breast carcinoma: results of a randomized trialOntario Clinical Oncology Group.Cancer 2000 88(10):2260 6 10820347
Whelan TJ, Levine M, Julian J et al The effects of radiation therapy on quality of life of women with breast carcinoma: results of a randomized trialOntario Clinical Oncology Group.Cancer 2000 May 15 88(10):2260 6
White H Strokes and net clinical benefit Aust N Z J Med 1993 Dec 23(6):737 8 8141714
Whitley RJ, Soong SJ, Dolin R et al Early vidarabine therapy to control the complications of herpes zoster in immunosuppressed patients N Engl J Med 1982 307(16):971 5 7110300
Williams C, Whitehouse JM, Lister TA et al Oral anticandidal prophylaxis in patients undergoing chemotherapy for acut- leukemia Med Pediatr Oncol 1977 3(3):275 80 311410
Williams PD, Ducey KA, Sears AM et al Treatment type and symptom severity among oncology patients by self-report Int J Nurs Stud 2001 Jun 38(3):359 67
Winstead-Fry P Psychometric assessment of four fatigue scales with a sample of rural cancer patients J Nurs Meas 1998 6(2):111 22 10028778
Winston DJ, Chandrasekar PH, Lazarus HM et al Fluconazole prophylaxis of fungal infections in patients with acute leukemia. Results of a randomized placebo-controlled, double-blind, multicenter trial Ann Intern Med 1993 Apr 1 118(7):495 503
Wolfe J, Grier HE, Klar N et al Symptoms and Suffering at the End of Life in Children with Cancer N Engl J Med 2000 342(5):326 33 10655532
Wolff SN. Epidemiology: the distribution and determination of adult cancer. In: Parris WC, Foster H, and Melzack R, editors. Cancer Pain Management: Principles and Practice. Boston: Butterworth-Heinemann. 1997:p. 25-30.
Woo B, Dibble SL, Piper BF et al Differences in fatigue by treatment methods in women with breast cancer Oncol Nurs Forum 1998 Jun 25(5):915 20
Woolf CJ, Mannion RJ Neuropathic pain: aetiology, symptoms, mechanisms, and management Lancet 1999 353(9168):1959 64 10371588
Woolf CJ, Bennett GB, Doherty M et al. Towards a mechanism-based classification of pain?. Pain. 1998;77:227-9. [pmid: 9808347].
Worden JW, Weisman AD Preventive psychosocial intervention with newly diagnosed cancer patients Gen Hosp Psychiatry 1984 Oct 6(4):243 9
Yellen SB, Cella DF, Webster K et al Measuring fatigue and other anemia-related symptoms with the Functional Assessment of Cancer Therapy (FACT) measurement system J Pain Symptom Manage 1997 Feb 13(2):63 74
Yeo E, Alvarado T, Fainstein V et al Prophylaxis of oropharyngeal candidiasis with clotrimazole J Clin Oncol 1985 Dec 3(12):1668 71
Zeppetella G, O'Doherty CA, Collins S Prevalence and characteristics of breakthrough pain in cancer patients admitted to a hospice J Pain Symptom Manage 2000 20(2):87 92 10989246