# Appendix B. Glossary for Fatigue Assessment Scales

Brief Fatigue Inventory -: 9 items, scored 1-10 to assess severity of fatigue, amount of interference with function caused by fatigue, presence of factors that worsen fatigue.

Cancer Fatigue Scale -: 15 items and 3 subscales (physical, affective, and cognitive) generated by factor analysis. Maximum score = 60. Physical = easily tired, urge to lie down, exhaustion, etc. Affective = lack of energy, lack of interest, lack of concentration. Cognitive = forgetfulness, speaking errors, carelessness. Each item is rated on a scale from 1-5.

Cancer-Related Fatigue Distress Scale (CRFDS) -: 35 cognitive distress questions reduced to 3; 147 physical distress questions reduced to 8; 142 psychological distress questions reduced to 7; 52 social distress questions reduced to 3; 21 spiritual distress questions reduced to 2. Total = 20 items, rated on a scale of 0 (none) to 10 (severe).

Checklist Individual Strength (CIS) -: 20 item questionnaire measuring 4 aspects of fatigue: fatigue severity (8 items); concentration (5 items); motivation (4 items); physical activity (3 items). Each item is scored on a 7-point Likert scale.

EORTC QLQ-C30 -: 6 functioning scales: physical functioning (5 items); role functioning (2 items); cognitive (2 items); emotional (4 items); social (2 items); QOL (2 items). 3 symptom scales: pain (2 items); fatigue (3 items); emesis (2 items).

Fatigue Questionnaire -: to estimate severity. Asks about fatigue symptoms in last month. Two items ask about duration and extent of fatigue. Seven items cover physical fatigue. Four cover mental fatigue.

Fatigue Severity Scale -: 9 item scale with statements scored from 1 (strongly disagree) to 7 (strongly agree).

Fatigue Symptom Inventory -: 13 item self-report measure for intensity and duration of fatigue and impact on QOL.

Functional Assessment of Cancer Therapy/Anemia (FACT-An) -: Composed of FACT-F plus 7 miscellaneous nonfatigue items related to anemia. FACT-F is composed of FACT-G plus Fatigue Subscale (13 items) = 20 items total.

GLQ-8 -: 8 item LASA instrument to measure cancer related QOL.

Lee Fatigue Scale -: VAS modified to numeric rating of 1-10, with descriptions of anchors from 1 (least) to 10 (extremely tired).

McCorkle and Young -: see Symptom Distress Scale.

Memorial Symptom Assessment Scale (MSAS) -: patient rates frequency, severity, distress for 32 symptoms. Frequency and severity are rated from 1-4, and distress is rated on a 5-point scale.

Multidimensional Assessment of Fatigue (MAF) -: severity, distress, interference items scaled from 0-10, ends anchored by "not at all" to "a great deal". Frequency item is categorical scale (0-4). Global fatigue calculated by summing severity and distress, adding item mean for interference, and adding the product of the categorical score on frequency by 2.5.

Multidimensional Fatigue Inventory (MFI-20) -: 5 scales relating to general fatigue, physical and mental fatigue, reduced activity and motivation. Each scale has 4 items, and each is rated on a 5-point response.

Multidimensional Fatigue Symptom Inventory (MFSI) -: 83 items to assess global (11 items), somatic (21 items), affective (17 items), cognitive (14 items), and behavioral (7 items) symptoms of fatigue.

Nottingham Health Profile (NHP) -: 6 subscales: energy (3 items); pain (8 items); emotional reactions (9 items); sleep (5 items); social isolation (5 items); physical mobility (9 items). Items were scored in a yes/no format.

Pearson Byars Fatigue Feeling Checklist -: 13 statements describing fatigue symptoms, rated on a scale of 1 (better than), 2 (same as) or 3 (worse than) and having a total range of 13-39.

Piper Fatigue Scale -: 22 items rated from 0-10 measuring 4 dimensions of subjective fatigue for a total score between 0-220. Each item is anchored by strong/weak.

Profile of Mood States (POMS): Fatigue Subscale -: self-rating measure of six emotions; tension/anxiety, depression/dejection, anger/hostility, vigor, fatigue, and confusion. Seven items, rated on a scale of 0-28.

Rhoten Fatigue Scale (RFS) -: 1 item VAS to measure fatigue. Stem is 'not tired; full of energy' and the other is 'totally exhausted'.

Rotterdam Symptom Checklist -: 30 items assessing physical and psychological symptom distress on a 4-point scale. 8 other items describe performance of daily activities. 2 items (tiredness and lack of energy) selected.

Schwartz Cancer Fatigue Scale (SCFS) -: 28 items measured using a 5-point scale.

SF-36 -: 5 variables: "lots of energy" rated from 1-6; "worn out" rated from 1-6; "tired" rated from 1-6; "full of pep" rated from 1-6; "vitality" rated from 4-24.

Subjective Symptom Test of Fatigue (Japanese Association of Industrial Health) -: 30 items in 3 categories (drowsiness/dullness, difficulty in concentration, projection of physical disintegration). Rated on a 4-point scale.

Swedish Occupational Fatigue Inventory (SOFI) -: 25 verbal expressions rated on a scale of 0-6. 0 = not at all → 6 = high degree.

Symptom Distress Scale (SDS) (also referred to as McCorkle and Young) -: 13 items: nausea, insomnia, pain, fatigue, bowel pattern, concentration, appearance, outlook, breathing, and cough.

Symptom Transition Scale -: measured severity of illness aspect of side effects burden.

Therapy-Related Symptom Checklist (TRSC) -: 25 items rated on a 5-point scale.

Visual Analogue Scale (VAS) -: 100 mm scale