# Appendix A. Abbreviations

ACS | American Cancer Society
AHRQ | Agency for Healthcare Research and Quality
AIDS | Acquired immunodeficiency syndrome
ANOVA | Analysis of Variance
APD | Aminohydropropyloxidine disodium pamidronate
APAP | Acetaminophen
ARS | Adjective rating scale
BMT | Bone marrow transplant
CARES | Cancer Rehabilitation Evaluation System
CCSI | Cognitive Coping Strategizing Inventory
CFS | Cancer Fatigue Scale
CNS | Central nervous system
CRF | Cancer-related Fatigue
CRFDS | Cancer related Fatigue Distress Scale
CSA | Controlled Substances Act
CSF | Cerebrospinal fluid
CT scan | Computed tomographic scan
DSM | Diagnostic and Statistical Manual of Mental Disorders
ECOG | Eastern Cooperative Oncology Group
EMLA | Eutectic mixture of local anesthetic
EORTC | European Organization for Research and Treatment of Cancer
FACT | Functional Assessment of Cancer Therapy
FDA | Food and Drug Administration
FLIC | Function of Living Index Cancer
FSI | Fatigue Symptom Inventory
GHQ | General Health Questionnaire
GI | Gastrointestinal
HADS | Hospital Anxiety and Depression Scale
HIV | Human immunodeficiency virus
HRQOL | Health-related Quality of Life
IM | Intramuscular
IV | Intravenous
IRS | Immediate release hydromorphone
JCAHO | Joint Commission for the Accreditation of Healthcare Organizations
LASA | Linear Analogue Self-Assessment
LFS | Lee Fatigue Scale
MAC | Mental Adjustment to Cancer
MAF | Multidimensional Assessment of Fatigue
MAOI | Monamine oxidase inhibitors
MFI | Multidimensional Fatigue Inventory
MFSI | Multidimensional Fatigue Symptom Inventory
MHIQ | McMaster Health Index Questionnaire
MMS | Mini-Mental State
MRI | Magnetic resonance imaging
MSAS | Memorial Symptom Assessment Scale
NCCW | National Comprehensive Cancer Network
NCPB | Neurolytic celiac plexis block
NHP | Nottingham Health Profile
NRS | Numerical rating scale
NSAID | Nonsteroidal anti-inflammatory drug
OMAR | Office of Medical Applications of Research
OTTAT | Oncology Treatment Toxicity Assessment Tool
PAC | Psychological Adjustment to Cancer Scale
PACIS | Perceived Adjustment to Chronic Illness Scale
PCA | Patient-controlled analgesia
PCC | Percutaneous cervical cordotomy
PFS | Piper Fatigue Scale
PID | Pain intensity difference (from baseline)
POMS | Profile of Moods States
QOL | Quality of Life
RCT | Randomized controlled trial
RFS | Rhoten Fatigue Scale
RSCL | Rotterdam Symptom Checklist
SCFS | Schwartz Cancer Fatigue Scale
SIP | Sickness Impact Profile
SPID | Summed pain intensity difference
SRH | Slow release hydromorphone
TENS | Transcutaneous electrical nerve stimulation
TOTPAR | Total pain relief
TRSC | Therapy-related Symptom Checklist
VAS | Visual analogue scale
WHO | World Health Organization