# Appendixes

Appendix A. Abbreviations

Appendix B. Glossary for Fatigue Assessment Scales