# Acronyms and Abbreviations

Abbreviation | Term
^ | to the power of
+ANA | antinuclear antibody
IV-C7S | 7S type IV collagen
A1 | mild inflammation
A2 | moderate inflammation
A3 | marked inflammation
abnl | abnormal
AFP | alpha fetoprotein
Alb | albumin
ALT | alanine aminotransferase
AMA | against medical advice
ASMA | antismooth muscle antibody
AST | aspartate aminotransferase
beta-NAG | N-acetyl-beta-glucosaminidase
bid | twice a day
Bili | bilirubin
bx | biopsy
CA | carbohydrate antigen
CAH | chronic active hepatitis
CC | case control
CD4 | CD4 count (cell type)
CEA | carcoembryonic antigen
CHC | chronic hepatitis C
CI | confidence interval
CohP | cohort prospective
CohR | cohort retrospective
CPH | chronic persistent hepatitis
Cr | creatinine
CS | case series
CSA | cyclosporine
CT | computerized tomography
D | day(s)
DM | diabetes mellitus
Des | Desmet
Disc/withdr | discontinued treatments or withdrew from study
Dose red | dose reduction
dx | diagnosis
el | elevated
ELISA | enzyme-linked immunosorbent assay
ETR | end of treatment response
f/u | follow-up
G | grade
g | gram(s)
GGT | gamma glutamyl transpeptidase
HA | hyaluronic acid
HbsAg | hepatitis B surface antigen
HAI | histological activity index
HBV | hepatitis B virus
HCC | hepatocellular carcinoma
HCV | hepatitis C virus
Hgb | hemoglobin
hr | hour(s)
IDU | intravenous drug user
IFN | interferon
Ig | immunoglobulin
IL | interleukin
ISH | Ishak
ITT | intention to treat
IV | intravenous
Kno | Knodell
L | liter(s)
LDH | lactate dehydrogenase
LL | lower limit
Ly IFN alpha | lymphoid interferon
MRI | magnetic resonance imaging
min | minute(s)
Met | Metavir
mL | milliliter(s)
MMP | matrix metalloproteinase
Mn-SOD | manganese superoxide dismutase
mo(s) | month(s)
MRI | magnetic resonance imaging
MU | million units
n/s | not specified
NASH | nonalcoholic steatohepatitis
ng | nanograms
nl | normal
NP | n-terminal polypeptide
NR | not reported
NS | not significant
OCPs | oral contraceptives
OLT | orthotopic liver transplant
PCHE | pseudocholinesterase
PCR | polymerase chain reaction
peg-IFN | pegylated interferon
P-III-P | Procollagen type III peptides
pts | patients
plts | platelets
PT | prothrombin time
PTT | partial thromboplastin time
qd | once a day
r IFN | recombinant IFN
r/o | rule out
RBV | ribavirin
RCT | randomized controlled trial
S | staging
S0 | no fibrosis
S1, S2 | mild (portal) fibrosis
S3 | moderate (bridging) fibrosis
S4 | severe fibrosis (cirrhosis)
SBR | sustained biochemical response
sec | second(s)
Sch | Scheuer
SR | sustained response
SVR | sustained virological response
tid | three times a day
TIMP | tissue inhibitor of metalloproteinase
tiw | three times a week
tx | treatment
U/S | ultrasound
ug | micrograms
UL | upper limit
w/ | with
w/I | within
w/o | without
WBC | white blood cell
WHO | World Health Organization
wk | week(s)
XS | cross-sectional
yr(s) | year(s)