# Evidence Tables

Evidence Table 1. Overall summary of studies addressing the relation of initial liver biopsy results to outcomes of treatment for chronic hepatitis C

Author, Year | Location | N | Inclusion Criteria | Exclusion Criteria | Study Aims
Studies with multivariate analyses
Studies comparing peg-IFN + RBV with IFN alpha 2b + RBV
Manns, 2001 | United States Canada | 1530 | ALT >34 for women and >43 for men, detectable HCV in serum, nl Cr, initial liver bx w/ CHC in past year, tx naïve, WBC <13, neutrophil >1.5, Hgb 12 for women and 13 for men, plts >100,000, nl Bili, nl Alb | HIV+, immune suppression, depression, other psychiatric illness, decompensated liver disease, comorbidities: cardiovascular, neurologic or hematologic, no contraception, AFP >50 mg/L, DM | To assess the safety and of two different regimens of Peg IFN and RBV compared w/ IFN alpha 2b and RBV and identify predictors and response for peg IFN alpha 2b.
| Europe Argentina
Studies comparing IFN + RBV with IFN alone
Berg, 2000 | Germany | 185 | El ALT, any previous treatment, HCV+, detectable HCV in serum | Psychiatric illness, acute or chronic IDU, HBV+, decompensated liver disease, acute or chronic EtOH, immune suppression, plts <100,000, depression, HIV+, severe concurrent diseases, Hgb <11 g/dL, pregnancy | To examine if 12 wk combination therapy is more effective in improving initial and SVR compared w/ IFN monotherapy in untreated pts. Pts who achieved a virologic response were treated w/ IFN alpha monotherapy for an additional 40 wks and then SVR was evaluated 24 wks after end of tx
Mangia, 2001 | Italy | 192 | Detectable HCV in serum, ALT available for 6 mos, initial liver bx | DM, HBV+, decompensated liver disease: ascites, bleeding varices, and encephalopathy, pregnancy, depression, EtOH, HIV+, plts <100,000, autoimmune disorder, significant medical illness, IFN monotherapy, WBC <3500, Hgb <12 for females and <13 for males, other psychiatric illness | To compare the efficacy of a high dose regimen of IFN alpha2b (5 mu tiw) for 12 mos alone or in combination w/ RBV for the tx of naïve pts w/ CHC. Secondary aims were to evaluate the effects of baseline features on the response to therapy and to determine a reliable point in time during tx to predict non response.
McHutchison, 2000 | United States | 1712 | | | To evaluate racial differences in response to therapy in pts w/ CHC, and potential contributing factors that might account for such differences
Saracco, 2001 | Europe | 594 | HCV+, detectable HCV in serum, initial liver bx w/i prior 2 yrs, nonresponse to previous therapy, IFN monotherapy, age >18 and <65 | Concomitant significant medical illness, IDU, HBV+, decompensated liver disease, relapse after previous therapy: >=1 course of IFN, pregnancy, depression, HIV+, cardiovascular comorbidity: ischemic cardiovascular disease, neurologic comorbidity: seizures, hematologic comorbidity: hemolytic anemia or hemophilia, abnl uric acid, obesity-induced liver disease, 12 mos nonresponse to previous therapy: IFN and ribavirin combination therapy, other comorbidities: Wilson's disease, hemochromatosis, or autoimmune hepatitis, IFN + RBV, WBC <3000, neutrophil <500, Hgb <10 g/dL, plts <70,000, GI comorbidity, alpha-1antitrypsin deficiency | To assess if higher than standard doses of IFN given w/ RBV for prolonged periods of administration improved the rate of sustained response in previous IFN-alone nonresponders. The study compares the efficacy and safety of 3 mu and five mu of IFN plus 1000 mg daily RBV for either 6 or 12 mos
Studies comparing peg-IFN with IFN alpha2b
Lindsay, 2001 | United States Europe | 1299 | U/S: no mass lesion, detectable HCV in serum, initial liver bx w/i 1 yr of enrollment, AFP w/i nl limits, ALT el >= 1 time w/i 6 mos of enrollment, WBC >4, neutrophil >1.8, Hgb >12 in females and > 13 in males, plts >130 | Hemophilia, breast feeding, illicit drug use, HBV+, HCC, pregnancy, HIV+, active IDU, hemochromatosis,alpha-1-antitrypsin deficiency, Wilson's disease, EtOH, NASH, any antiviral therapy, hemoglobinopathy, other medical conditions that could interfere with participation, any prior tx, autoimmune hepatitis | To evaluate the efficacy of pegIFN alpha 2b compared w/IFN alpha 2b in tx-naïve pts w/CHC
| Australia
Studies comparing peg-IFN with IFN alpha2a
Zeuzem, 2000 | Germany | 120 | HCV+, age >18 and <70 yrs, presence of fibrosis: CHC on liver bx, initial liver bx w/i 1 yr, el ALT for >=6 mos before tx, WBC >2500, plts >70,000 | EtOH >50 g/d of ethanol, IDU w/i previous year, GI comorbidity, immune suppression: organ transplant or autoimmune disorder, psychiatric illness, HIV+, HBV+, cardiovascular comorbidity, pregnancy, neurologic comorbidity, malignancy comorbidity, anaphylactic allergy to IFN, other comorbidities: liver disease from another cause OR renal disease OR rheumatologic disease, other viral infections: systemic bacterial or fungal infection, lactation, IFN + RBV, IFN monotherapy, amantadine, hematologic comorbidity | To compare the efficacy, safety, and health related quality of life of IFN alpha alone or in combination w/ amantadine for tx of CHC.
Studies comparing different doeses of IFN
Ascione, 1998 | Europe | 80 | Positive HCV antibodies, ALT 2x nl for 1 yr, initial liver bx: chronic active liver damage or persistent CHC, age 18–60 yrs | Chronic disease that could affect life expectancy, active IDU, homosexual men, HBV+, HCC, pregnancy or absence of contraceptive use in women of childbearing age, immune suppression, GI comorbidity: Fe, copper, alpha-1-antitrypsin deficiency or previous liver decompensation, Alb <3.0 g/L, esophageal varices F2–F3, decompensated DM, any previous therapy, WBC <3000, plts <100,000, Bili >51 Mol/L, HIV+ | To see if doubling the dose of IFN improved long-term response. To evaluate efficacy of the tx regimens in cirrhotic pts
Kumada, 1996 | Japan | 54 | ALT >70 IU/L for 6 mos, initial liver bx determination of CHC, presence of cirrhosis, presence of fibrosis, detectable HCV in serum, positive HCV antibodies | Drug-induced liver disease, Wilson's disease, EtOH liver disease, PBC, autoimmune hepatitis, chronic HBV+ | To describe the relationship between the therapeutic effect of IFN in CHC pts and various factors including: dosage, age, gender, disease durration, +/- blood transfusion, pre-tx ALT levels, pre-tx liver histology (HAI score), HCV-RNA concentration, and HCV genotype.
Payen, 1998 | France | 247 | Abnl ALT for 6 mos, initial liver bx IFN monotherapy: 3 mu IFN, tiw for 6 mos, HCV+, detectable HCV in serum | Adverse reaction to previous therapy: grade 3 or 4 by WHO classification, HBV+, presence of cirrhosis, age <18 yrs, HIV+, Fe deposition in liver, women of childbearing age not using contraceptives, severe associated disease, pregnancy | To compare the efficacy of IFN alpha2b regimens in pts w/ CHC who relapsed after an initial 6 mos IFN tx
Studies comparing IFN + amantidine with IFN alone
Zeuzem, 2000a | Canada Europe | 531 | HCV+, detectable HCV in serum: RNA >2000 copies per mL, el ALT on >=2 occasions in previous 6 mos, initial liver bx w/ hepatitis, liver bx findings consistent with CHC, adults | Malignancy, decompensated liver disease, HBV+, immune suppression, depression, other psychiatric illness, HIV+, hepatitis A infection, other comorbidities: seizure, neurologic OR cardiovascular, AFP >25 ng/mL, chronic pulmonary disease, autoimmune disorder, unwillingness to practice contraception, severe retinopathy, IFN monotherapy, neutrophil <1500, plts <90,000, Cr 1.5x UL of nl | To compare the efficacy and safety of peg-IFN alpha-2a administered once per wk w/ the efficacy and safety of IFN alpha-2a tiw for 48 wks.
| Australia
Studies of IFN + colchicine
Angelico, 2000 | Italy | 65 | Age: 18–65, ALT >1.5x nl, Ishak score > 1 or < 5 on initial liver bx, detectable HCV in serum, | HBV+ | To determine whether the combination of colcichine and IFN alpha is more effective than IFN alpha alone in treating non-cirrhotic pts w/ CHC
Studies with univariate analyses
Studies of IFN alone
Saracco, 1997 | Italy | 164 | HCV+, initial liver bx, ALT abnl x 6 mos before entry | Current or past drug addiction,HBsAg+, presence of cirrhosis, HIV+, liver disease of any other etiology | To assess the effects of prolonged tx w/ different doses of IFN alpha 2b on relapse rate of pts w/ CHC. To determine factors predictive of sustained response
Shiffman, 2000 | United States | 95 | WBC >2500, nl PT, nl Bili, HCV+, detectable HCV in serum, plts >90,000 | HIV+, active IDU, HBV+, hepatitis delta infection, EtOH “on a regular basis,” immune suppression, other viral infections, any other cause of hepatitis, chronic renal failure, pregnancy | To see if pts w/ nl ALT levels and CHC responded to IFN as well as those w/ el ALT levels and if predictors of sustained response could be applied to them as well.
Villa, 2001 | Italy | 30 | Consecutively seen in clinic, ALT 2x nl for 6 mos, HBV+, HCV+ | IFN tx, peg-IFN + RBV tx | To determine the outcome of medium to high doses of IFN therapy in pts w/ HBV-HCV.
Studies of IFN + RBV
Di Bisceglie, 2001 | United States | 124 | Initial liver bx w/i 12 mos of rx, IFN monotherapy >=36 mu, detectable HCV in serum, positive HCV antibodies | | To see if nonresponders to IFN alone would respond to a combination of IFN/RBV for either 24 or 48 wks
Shiffman, 2000a | United States | 140 | ALT, IFN monotherapy, pregnancy, nonresponse to previous therapy: IFN monotherapy | IFN monotherapy: max dose 6 mu IFN alpha-2a, OR max dose 9 mg IFN alphacon, OR max dose 3 mu IFN alpha-2b, any other type of liver disease, IDU, EtOH | To determine whether combination IFN/RBV was effective in tx of IFN monotherapy nonresponders.
| | | | | To determine subgroups who did not respond.
Studies of IFN + amantidine
Mangia, 2001a | Italy | 200 | Detectable HCV in serum, initial liver bx, el ALT for 6 mos | EtOH, current IDU, depresson, other psychiatric illness, HBV+, decompensated liver disease, plts < 100,000, HIV+, DM, significant medical illness, WBC < 3,500, immune suppression | To assess the efficacy and safety of IFN+amantadine compared to IFN monotherapy in naïve pts w/ CHC
Studies with stratified analyses
Studies of different types of IFN
Villa, 1996 | Italy | 60 | Age >18 and <65 yrs, ALT >2x UL of | | Wilson's disease, autoimmune
A prospective double blinded,
| | | nl for >= 6 mos | disorder, alpha-1-antitrypsin deficiency, HIV+, immune suppression: immunosuppressive therapy w/i past 6 mos, decompensated liver disease, presence of cirrhosis: Child's grade B or C, HBV+, EtOHism, plts <100,000, WBC, IFN monotherapy | randomized study comparing IFN beta w/ recombinant IFN and leukocyte-derived IFN alpha. The outcomes measured were histological, biochemical, and virological responses.
Studies comparing peg-IFN with IFN
Heathcote, 2000 | United States Canada | 271 | ALT, initial liver bx | AFP >100 ng/mL, plts <75,000, WBC <500, IFN monotherapy, presence of any other liver disease, comorbidities: malignancy, GI, neurologic, or cardiovascular, HIV+, depression, psychiatric illness, decompensated liver disease | To compare the efficacy and safety of two doses of peg-IFN alpha-2a, given once wkly, w/ the safety and efficacy of a standard regimen of unmodified IFN alpha-2a in pts w/ HCV and cirrhosis or fibrosis.

Evidence Table 2. Characteristics of patients in studies addressing the relation of liver biopsy results to outcomes of treatment for chronic hepatitis C

Author, Year | Study Design | Study Groups | N | Mean age % Male Race | % w/ Cirrhosis | Scoring System | Mean Activity (A) Fibrosis (S) | % w/ Score Activity (A) Fibrosis (S) | Mean ALT (U/L) Mean yrs w/ HCV HCV genotype (%)
Studies with multivariate analyses
Studies comparing peg-IFN + RBV with IFN alpha 2b + RBV
Manns, 2001 | RCT
| | IFN: peg-IFN2b, 1.5 mg/kg, qw, 48 wks | 511 | 43 | | | | S3 29
| | | | 63 | | Kno | 7.9
| | RBV: 800 mg qd, 48 wks | | | | | | | 1 | 68.10
| | | | | | | | | 2,3 | 28.96
| | | | | | | | | 4,5,6 | 3.13
| | IFN (initial): peg-IFN2b, 1.5 mg/kg, qw, 4 wks | 514 | 44 | | | | S3 30
| | | | 66 | | Kno | 7.9
| | IFN (maintenance): peg-IFN2b, 0.5 mg/kg, qw, 44 wks | | | | | | | 1 | 67.90
| | | | | | | | | 2,3 | 29.96
| | RBV: 1000–1200 mg qd, 48 wks | | | | | | | 4,5,6 | 2.33
| | IFN: alpha-2b, 3 mu tiw, 48 wks | 505 | 43 | | | | S3 28
| | RBV: 100–1200 mg qd, 48wks | | 67 | | Kno | 7.8
| | | | | | | | | 1 | 67.92
| | | | | | | | | 2,3 | 28.91
| | | | | | | | | 4,5,6 | 3.17
Studies comparing IFN + RBV with IFN alone
Berg, 2000 | RCT
| | IFN: alpha-2a, 6 mu tiw, 12 wks | 93 | 42 | | HAI | | S 1.5 | 70
| | RBV: 7 mg/kg, bid, 12 wks | | 57 | | | | | 15.2
| | | | | | | | | 1a | 24.73
| | | | | | | | | 1a/b | 1.08
| | | | | | | | | 1b | 47.31
| | | | | | | | | 2a | 2.15
| | | | | | | | | 2a/c | 1.08
| | | | | | | | | 2b | 3.23
| | | | | | | | | 3a | 18.28
| | | | | | | | | 4 | 2.15
| | IFN: alpha-2a, 6 mu tiw, 12 wks | 92 | 42 | | HAI | | S 1.5 | 82
| | | | | | | | | 14.7
| | | | | | | | | 1a | 20.65
| | | | | | | | | 1a/b | 1.09
| | | | | | | | | 1b | 54.35
| | | | | | | | | 2a | 2.17
| | | | | | | | | 2a/c | 1.09
| | | | | | | | | 2b | 1.09
| | | | | | | | | 3a | 17.39
| | | | | | | | | 4 | 2.17
Mangia, 2001 | RCT
| | IFN: alpha-2b, 5 mu tiw, 12 mos | 96 | 49 | | Sch | | A>1 19.8
| | | | 72 | | Sch | | A0,1 80.2 | 8
| | | | | | Sch | | S1,2 93.8 | 1b | 53.13
| | | | | | Sch | | S3 6.2 | 2a | 33.33
| | | | | | | | | 3 | 9.38
| | | | | | | | | other | 4.17
| | IFN: alpha-2b, 5 mu tiw, 12 mos | 96 | 46 | | Sch | | A>1 26.0
| | RBV: 1000–1200 mg qd, 12 mos | | 61 | | Sch | | A0,1 74.0 | 7
| | | | | | Sch | | S1,2 89.6 | 1b | 41.67
| | | | | | Sch | | S3 10.4 | 2a | 35.42
| | | | | | | | | 3 | 17.71
| | | | | | | | | other | 5.21
McHutchison, 2000 | RCT
| | IFN (210 pts): alpha-2b, 3 mu tiw, 24 wks | 1600 | 43 | | HAI | 7.1
| | | | 65 | | Kno | S 1.5 | | 17
| | IFN (461 pts): alpha-2b, 3 mu tiw, 24 wks | | | | Kno | | S3 1.1 | 1 | 65.06
| | | | | | Kno | | S4 0.2 | Non-1 | 34.94
| | IFN (464 pts): alpha-2b, 3 mu tiw, 48 wks
| | IFN (465 pts): alpha-2b, 3 mu tiw, 48 wks
| | RBV (461 pts): 1000/1200 mg qd, 24 wks
| | RBV (464 pts): 1000/1200 mg qd, 48 wks
| | IFN (12 pts): alpha-2b, 3 mu tiw, 24 wks | 53 | 46 | | HAI | 7.8
| | | | 68 | | Kno | S 1.7 | | 18
| | IFN (13 pts): alpha-2b, 3 mu tiw, 48 wks | | | | Kno | | S3 47.2 | 1 | 96.23
| | | | | | Kno | | S4 11.3 | non-1 | 3.77
| | IFN (13 pts): alpha-2b, 3 mu tiw, 48 wks
| | IFN (15 pts): alpha-2b, 3 mu tiw, 24 wks
| | RBV (13 pts): 1000/1200 mg qd, 48 wks
| | RBV (15 pts): 1000/1200 mg qd, 24 wks
| | IFN (1 pts): alpha-2b, 3 mu tiw, 24 wks | 27 | 45 | | Kno | S 1.5
| | | | 81 | | Kno | | S4 40.7 | 21
| | IFN (13 pts): alpha-2b, 3 mu tiw, 24 wks | | | | | | | 1 | 59.26
| | | | | | | | | non-1 | 40.74
| | IFN (6 pts): alpha-2b, 3 mu tiw, 48 wks
| | IFN (7 pts): alpha-2b, 3 mu tiw, 48 wks
| | RBV (13 pts): 1000/1200 mg qd, 24 wks
| | RBV (7 pts): 1000/1200 mg qd, 48 wks
| | IFN (12 pts): alpha-2b, 3 mu tiw, 48 wks | 32 | 45 | | HAI | 7.9
| | | | 75 | | HAI | | 40.6 | 21
| | IFN (5 pts): alpha-2b, 3 mu tiw, 48 wks | | | | Kno | | | 1 | 78.13
| | | | | | Kno | S3 | 6.2 | non-1 | 21.88
| | IFN (7 pts): alpha-2b, 3 mu tiw, 24 wks | | | | Kno | S4 | 88
| | IFN (8 pts): alpha-2b, 3 mu tiw, 24 wks
| | RBV (12 pts): 1000/1200 mg qd, 48 wks
| | RBV (8 pts): 1000/1200 mg qd, 24 wks
Saracco, 2001 | RCT
| | IFN: alpha-2b, 3 mu tiw, 12 mos | 139 | 46 | 12 | ISH | A 2.6
| | RBV: 1000 mg qd, 12 mos | | 66 | | ISH | S 6.2
| | | | | | | | | 1 | 66.91
| | | | | | | | | 2 | 16.55
| | | | | | | | | 3 | 9.35
| | | | | | | | | 4 | 7.19
| | IFN: alpha-2b, 5 mu tiw, 12 mos | 162 | 44 | 9 | ISH | A 2.5
| | RBV: 1000 mg qd, 12 mos | | 75 | | ISH | S 6.4
| | | | | | | | | 1 | 60.49
| | | | | | | | | 2 | 19.14
| | | | | | | | | 3 | 13.58
| | | | | | | | | 4 | 6.79
| | IFN: alpha-2b, 3 mu tiw, 6 mos | 142 | 46 | 15 | ISH | A 2.8
| | RBV: 1000 mg qd, 6 mos | | 77 | | ISH | S 6.2
| | | | | | | | | 1 | 67.61
| | | | | | | | | 2 | 14.79
| | | | | | | | | 3 | 14.08
| | | | | | | | | 4 | 3.52
| | IFN: alpha-2b, 5 mu tiw, 6 mos | 151 | 45 | 7 | ISH | A 2.6
| | RBV: 1000 mg qd, 6 mos | | 78 | | ISH | S 6.0
| | | | | | | | | 1 | 68.87
| | | | | | | | | 2 | 13.25
| | | | | | | | | 3 | 11.26
| | | | | | | | | 4 | 6.62
Studies comparing peg-IFN with IFN alpha-2b
Lindsay, 2001 | RCT
| | IFN: peg-IFN2b, 0.5 ng/kg, qw, 48 wks | 315 | 43.1 | 3 | HAI | A 6.8
| | | | 59 | | HAI | S1.4 | | 18.5
| | | | C: 90.1 | | | | | 1 | 67.30
| | | | | | | | | 2 | 11.11
| | | | | | | | | 3 | 16.83
| | | | | | | | | other | 4.76
| | IFN: peg-IFN2b, 1.0 ng/kg, qw, 48 wks | 297 | 43.7 | 3 | HAI | A 6.9
| | | | 63 | | HAI | S 1.4 | | 20.4
| | | | C: 90.9 | | | | | 1 | 67.00
| | | | | | | | | 2 | 10.10
| | | | | | | | | 3 | 17.85
| | | | | | | | | Other | 5.05
| | IFN: peg-IFN2b, 1.5 ng/kg, qw, 48 wks | 304 | 42.9 | 4 | HAI | A 6.7
| | | | 63 | | HAI | S 1.3 | | 19.2
| | | | C: 94.0 | | | | | 1 | 73.36
| | | | | | | | | 2 | 10.53
| | | | | | | | | 3 | 13.49
| | | | | | | | | other | 2.63
| | IFN: alpha-2b, 3 mu tiw, 48 wks | 303 | 42.6 | 4 | HAI | A 7.1
| | | | 68 | | HAI | S 1.4 | | 18.6
| | | | C: 89.1 | | | | | 1 | 71.62
| | | | | | | | | 2 | 9.24
| | | | | | | | | 3 | 17.49
| | | | | | | | | other | 1.65
Studies comparing peg-IFN with IFN alpha-2a
Zeuzem, 2000 | RCT
| | Amantadine: 100 mg, Twice a day, 48 wks | 60 | 42.1
| | | | 62
| | IFN (initial): alpha-2a, 6 mu tiw, 24 wks | | | | | | | 1 | 70.00
| | | | | | | | | 2 | 5.00
| | IFN (maintenance): alpha-2a, 3 mu, tiw, 24 wks | | | | | | | 3 | 21.67
| | | | | | | | | 4 | 1.67
| | IFN (initial): alpha-2a, 6 mu tiw, 24 60 wks | 60 | 41.6
| | | | 60
| | IFN (maintenance): alpha-2a, 3 mu, tiw, 24 wks | | | | | | | 1 | 66.67
| | | | | | | | | 2 | 5.00
| | | | | | | | | 3 | 25.00
| | | | | | | | | 4 | 1.67
Studies comparing different doeses of IFN
Ascione, 1998 | RCT
| | IFN (initial): alpha-2b, 3 mu tiw, 12 mos | 40 | | | | | S3, A2 37.5
| | | | 53 | | | | | 5.74
| | | | | | | | | 1b | 62.50
| | | | | | | | | 2a | 37.50
| | IFN (initial): alpha-2b, 6 mu tiw, 12 mos | 40
| | | | 70 | | | | | 5.44
| | | | | | | | | 1b | 67.50
| | | | | | | | | 2a | 32.50
Kumada, 1996 | RCT | IFN (initial): natural IFN, 5 mu, bid, 20 wks | 27 | 56.1 | | HAI | 10.2
| | | | 56 | | HAI | | CPH I 22.2 | 6.7
| | IFN (initial): natural IFN, 5 mu, qd, 2 wks | | | | HAI | | CPH II a 63.0 | 1b | 44.44
| | | | | | | | | 1b+2a | 3.70
| | IFN (initial): natural IFN, 5 mu, qw, 12 wks | | | | HAI | | CPH II b 14.8 | 2a | 44.44
| | | | | | | | | 2a+2b | 3.70
| | IFN (initial): natural IFN, 5 mu tiw, 4 wks | | | | | | | 2b | 3.70
| | IFN (maintenance): natural IFN, 5 mu, bid, 20 wks
| | IFN (maintenance): natural IFN, 5 mu, qd, 2 wks
| | IFN (maintenance): natural IFN, 5 mu, qw, 12 wks
| | IFN (maintenance): natural IFN, 5 mu tiw, 4 wks
| | IFN (initial): natural IFN, 10 mu, bid, 20 wks | 27 | 53.4 | | | | CPH II b 18.5
| | | | 67 | | | | | 6.9
| | IFN (initial): natural IFN, 10 mu, qd, 2 wks | | | | HAI | 9.1 | | 1b | 77.78
| | | | | | HAI | | CPH I 25.9 | 1b+2a | 0.00
| | IFN (initial): natural IFN, 10 mu, qw, 12 wks | | | | HAI | | CPH II a 55.6 | 2a | 11.11
| | | | | | | | | 2a+2b | 0.00
| | IFN (initial): natural IFN, 10 mu, tiw, 4 wks | | | | | | | 2b | 11.11
| | IFN (maintenance): natural IFN, 10 mu, bid, 20 wks
| | IFN (maintenance): natural IFN, 10 mu, qd, 2 wks
| | IFN (maintenance): natural IFN, 10 mu, qw, 12 wks
| | IFN (maintenance): natural IFN, 10 mu tiw, 4 wks
Payen, 1998 | RCT
| | IFN: alpha-2b, 3 mu tiw, 6 mos | 75 | 45.6 | | HAI | 7.2
| | | | 92 | | | | | 8.83
| | | | C: 98.6 | | | | | 1 | 5.33
| | | | | | | | | 1a | 10.67
| | | | | | | | | 1b | 28.00
| | | | | | | | | 2 | 13.33
| | | | | | | | | 3 | 16.00
| | | | | | | | | other | 8.00
| | IFN: alpha-2b, 3 mu tiw, 12 mos | 91 | 44.1 | | HAI | 7.6
| | | | 71 | | | | | 9.47
| | | | C: 100 | | | | | 1 | 3.30
| | | | | | | | | 1a | 3.30
| | | | | | | | | 1b | 29.67
| | | | | | | | | 2 | 15.38
| | | | | | | | | 3 | 23.08
| | | | | | | | | other | 5.49
| | IFN: alpha-2b, 10 mu tiw, 6 mos | 81 | 42.1 | | HAI | 8
| | | | 70 | | | | | 9.08
| | | | C: 100 | | | | | 1 | 2.47
| | | | | | | | | 1a | 3.70
| | | | | | | | | 1b | 33.33
| | | | | | | | | 2 | 9.88
| | | | | | | | | 3 | 28.40
| | | | | | | | | other | 6.17
Studies comparing IFN + amantidine with IFN alone
Zeuzem, 2000a | RCT
| | IFN (initial): peg-IFN2a, 180 ?g, qw, 48 wks | 267 | 40.5 | | HAI | 8.6 | A1 65.0
| | | | 67 | | | | A2 30.0
| | | | C: 86.1, | | | | A3 3.3 | 1a | 29.96
| | | | B: 2.24, A: 8.98,
| | | | O: 2.62 | | | | S1 88.4 | 1b | 32.96
| | | | | | | | S3 7.1 | 2 | 9.36
| | | | | | | | | 3 | 25.47
| | | | | | | | | 4 | 1.87
| | | | | | | | | not specified | 0.37
| | IFN (initial): alpha-2a, 6 mu tiw, 12 wks | 264 | 41 | | HAI | 3.4 | A1 60.0
| | | | 67 | | | | A2 40.0
| | IFN (maintenance): alpha-2a, 3 mu, tiw, 36 wks | | C: 84.8, | | | | A3 0.0 | 1a | 31.44
| | | | B: 1.89, A: 9.84,
| | | | O: 3.40 | | | | S1 84.8 | 1b | 29.55
| | | | | | | | S3 4.9 | 2 | 12.88
| | | | | | | | | 3 | 23.86
| | | | | | | | | 4 | 1.14
| | | | | | | | | not specified | 1.14
Studies of IFN + colchicine
Angelico, 2000 | RCT
| | IFN (initial): alpha-2a, 6 mu tiw, 6 mos | | 34 | 46
| | | | 59 | | | | | 6.9
| | IFN (maintenance): alpha-2a, 3 mu, tiw, 6 mos | | | | | | | 1b | 61.76
| | | | | | | | | non 1b | 32.35
| | | | | | | | | not specified | 5.88
| | Colcichine (initial): 1 mg, 6x/wk, 3 yrs | 31 | 49
| | | | 58 | | | | | 7.5
| | IFN (initial): alpha-2a, 6 mu tiw, 6 mos | | | | | | | 1b | 64.52
| | | | | | | | | non 1b | 25.81
| | IFN (maintenance): alpha-2a, 3 mu, tiw, 6 mos | | | | | | | not specified | 9.68
Studies with univariate analyses
Studies of IFN alone
Saracco, 1997 | RCT
| | IFN (initial): alpha-2b, 3 mu tiw, 3 mos | 54 | 45.4
| | | | 61
| | IFN (maintenance): alpha-2b, 3 mu, tiw, 21 mos | | | | | | | 1b | 55.56
| | IFN (initial): alpha-2b, 3 mu tiw, 3 mos | 34 | 48.5
| | | | 65
| | IFN (maintenance): alpha-2b, 6 mu, tiw, 21 mos | | | | | | | 1b | 44.12
| | IFN (initial): alpha-2b, 3 mu tiw, 3 mos | 65
| | IFN (maintenance): alpha-2b, 6 mu, tiw, 3 mos | | | | | | | 1b | 161.54
| | IFN (initial): alpha-2b, 3 mu tiw, 3 mos | 11
| | IFN (maintenance): alpha-2b, 6 mu, tiw, 18 mos
Shiffman, 2000 | RCT
| | IFN (initial): alpha-2a, 6 mu, qd, 3 mos | | 47 | 43 | | | | 21 | 68.1
| | | | 47
| | IFN (initial)1: alpha-2a, 6 mu tiw, 3 mos | | C: 59.5 | | | | | 1 | 74.47
| | IFN (maintenance): alpha-2a, 3 mu, tiw, 12 mos
| | IFN (initial): alpha-2a, 6 mu tiw, 6 mos | | 48 | 43.4 | | | | 10 | 62.2
| | | | 52
| | IFN (maintenance): alpha-2a, 3 mu, tiw, 12 mos | | C: 45.8 | | | | | 1 | 75.00
Villa, 2001 | RTnc
| | IFN: 6 mu tiw, 6 mos | 14 | 34 | | HAI | A 1.9
| | | | 71 | | HAI | S 11.6
| | | | | | | | | 1a | 7.14
| | | | | | | | | 1b | 78.57
| | | | | | | | | 2a | 14.29
| | IFN: 9 mu tiw, 6 mos | 16 | 33 | | HAI | A 1.7
| | | | 75 | | HAI | S 11.9
| | | | | | | | | 1a | 31.25
| | | | | | | | | 1b | 43.75
| | | | | | | | | 2a | 25.00
Studies of IFN + RBV
Di Bisceglie, 2001 | RCT
| | IFN: alpha-2b, 3 mu tiw, 24 wks | 63 | 43 | | Sch | | A0 20.6 | 90
| | RBV: 1000–1200 mg qd, 24 wks | | 70 | | Sch | | A1 30.2
| | | | C: 96.8 | | Sch | | A2 25.4 | 1 | 74.60
| | | | | | Sch | | A3 23.8 | 2 | 19.05
| | | | | | | | | 3 | 6.35
| | IFN: alpha-2b, 3 mu tiw, 48 wks | 61 | 46 | | Sch | | A0 18.0 | 100
| | RBV: 1000–1200 mg qd, 48 wks | | 57 | | Sch | | A1 21.3
| | | | C: 98.3 | | Sch | | A2 41.0 | 1 | 86.89
| | | | | | Sch | | A3 19.7 | 2 | 9.84
| | | | | | | | | 3 | 3.28
Shiffman, 2000a | RCT
| | IFN (initial): alpha-2b, 5mu tiw, 3 mos | 48 | 44.5 | 21 | Kno | 7.3
| | | | 60
| | IFN (maintenance): alpha-2b, 5 mu, tiw, 3 mos | | C: 50, B: 50 | | | | | 1 | 89.58
| | IFN (initial): alpha-2b, 3 mu, tiw, 3 mos | 42 | 43.6 | 19 | Kno | 7
| | | | 69
| | IFN (maintenance): alpha-2b, 5 mu, tiw, 3 mos | | C: 69.0, B: 30.9 | | | | | 1 | 88.10
| | RBV: 1000–1200 mg, divided dose, twice daily, 9 mos
| | IFN: alpha-2b, 5 mu, tiw, 6 mos | 50 | 42.9 | 14 | Kno | 6.4
| | RBV: 1000–1200 mg, divided dose, twice daily, 9 mos | | 66
| | | | C:64, B:36 | | | | | 1 | 90.00
Studies of IFN + amantidine
Mangia, 2001a | RCT
| | IFN (initial): alpha-2a, 6 mu tiw, 12 mos | 101 | 48 | | HAI | | S0-3 48.5
| | | | 70 | | HAI | | S1-3 51.5 | 7.1
| | | | | | | | | 1 | 59.41
| | | | | | | | | 2a | 25.74
| | | | | | | | | 3 | 10.89
| | | | | | | | | 4 | 3.96
| | Amantadine (initial): 100 mg, bid, 12 mos | 99 | 46 | | HAI | | S0-3 36.4
| | | | 62 | | HAI | | S1-3 63.6 | 7.1
| | IFN (initial): alpha-2a, 6 mu tiw, 12 mos | | | | | | | 1 | 52.53
| | | | | | | | | 2a | 34.34
| | | | | | | | | 3 | 7.07
| | | | | | | | | 4 | 6.06
Studies with stratified analyses
Studies of different types of IFN
Villa, 1996 | RCT
| | IFN (maintenance): alpha-2a, 3 mu, tiw, 6 mos | 21 | 45 | 33 | | | S3, A2 66.7 | 185
| | | | 71
| | IFN (maintenance): natural IFN, 3 mu tiw, 6 mos | 20 | 46 | 35 | | | S3, A2 65.0 | 171
| | | | 70
| | IFN (maintenance): beta IFN, 3 mu, tiw, 6 mos | 19 | 41 | 16 | | | S3, A2 84.2 | 153
| | | | 79
Studies comparing peg-IFN with IFN
Heathcote, 2000 | RCT
| | IFN: alpha-2a, 3 mu tiw, 48 wks | 88 | 46.9 | 76 | HAI | 12.8 | | 104.1
| | | | 70
| | | | C: 87.5, | | | | | 1a | 31.82
| | | | B: 5.68, A: 3.40, | | | | | 1b | 21.59
| | | | O: 3.40 | | | | | 2 | 13.64
| | | | | | | | | 3 | 30.68
| | | | | | | | | 4 | 0.00
| | | | | | | | | not specified | 2.27
| | IFN: peg-IFN2a, 90 mg, qw, 48 wks | 96 | 47.2 | 79 | HAI | 12.7 | | 104.1
| | | | 74
| | | | C: 90.6, | | | | | 1a | 28.13
| | | | B: 1.04, A: 2.08, | | | | | 1b | 32.29
| | | | O: 6.25 | | | | | 2 | 7.29
| | | | | | | | | 3 | 27.08
| | | | | | | | | 4 | 2.08
| | | | | | | | | not specified | 3.13
| | IFN: peg-IFN2a, 180 mg, qw, 48 wks | 87 | 47.1 | 79 | HAI | 13.4 | | 123.3
| | | | 72
| | | | C: 86.2, | | | | | 1a | 37.93
| | | | B: 5.74, A: 2.29 | | | | | 1b | 17.24
| | | | O: 5.74 | | | | | 2 | 16.09
| | | | | | | | | 3 | 22.99
| | | | | | | | | 4 | 1.15
| | | | | | | | | not specified | 4.60

Evidence Table 3. Methodologic quality of studies addressing the relation of initial liver biopsy results to outcomes of treatment for chronic hepatitis C

Author, Year | Representativeness^a^ | Bias^b^ | Description^c^ | Outcomes^d^ | Statistics^e^ | Conflict^f^ | Total
Studies with multivariate analyses
Studies comparing peg-IFN + RBV with IFN alpha 2b + RBV
Manns, 2001 | 100 | 50 | 0 | 80 | 83 | 50 | 63
Studies comparing IFN + RBV with IFN alone
Berg, 2000 | 90 | 0 | 0 | 85 | 83 | 0 | 86
Mangia, 2001 | 80 | 50 | 0 | 60 | 100 | 0 | 58
McHutchison, 2000 | 25 | -- | -- | 40 | 83 | 50 | 49
Saracco, 2001 | 88 | 100 | 0 | 70 | 100 | 0 | 64
Studies comparing peg-IFN with IFN alpha2b
Lindsay, 2001 | 90 | 100 | 0 | 85 | 100 | 50 | 75
Studies comparing peg-IFN with IFN alpha2a
Zeuzem, 2000 | 100 | 100 | 0 | 60 | 100 | 50 | 87
Studies comparing different doeses of IFN
Ascione, 1998 | 100 | 0 | 0 | 80 | 100 | 50 | 56
Kumada, 1996 | 90 | 100 | 0 | 75 | 83 | 0 | 70
Payen, 1998 | 75 | 100 | 0 | 85 | 83 | 50 | 81
Studies comparing IFN + amantidine with IFN alone
Zeuzem, 2000a | 100 | 50 | 0 | 70 | 100 | 100 | 90
Studies of IFN + colchicine
Angelico, 2000 | 75 | 100 | 0 | 85 | 100 | 100 | 87
Studies with univariate analyses
Studies of IFN alone
Saracco, 1997 | 70 | 100 | 0 | 75 | 83 | 0 | 66
Shiffman, 2000 | 88 | 50 | 0 | 80 | 100 | 100 | 89
Villa, 2001 | 90 | 50 | 0 | 35 | 67 | 100 | 48
Studies of IFN + RBV
Di Bisceglie, 2001 | 75 | 50 | 0 | 85 | 67 | 50 | 76
Shiffman, 2000a | 100 | 100 | 0 | 60 | 83 | 50 | 69
Studies of IFN + amantidine
Mangia, 2001a | 88 | 50 | 0 | 85 | 100 | 50 | 91
Studies with stratified analyses
Studies of different types of IFN
Villa, 1996 | 60 | 0 | 0 | 60 | 33 | 50 | 31
Studies comparing peg-IFN with IFN
Heathcote, 2000 | 100 | 100 | 0 | 70 | 83 | 50 | 88

a Representativeness: The total maximum for this section was 10 points. This included setting and population described and start and end date specified (2 points); detailed description of inclusion and exclusion criteria or statement that all potential trainees enrolled (2 points); information about excluded or not-participating patients (2 points); appropriateness of the spectrum of disease included in the study sample (2 points); and description of key patient characteristics at enrollment (2 points).

b Bias and Confounding: The total maximum score was 2 points. This included whether there was an independent, blind comparison of initial liver biopsy to outcomes.

c Description of Biopsy: The total maximum score was 2 points. This included description of the technique and size of liver biopsy.

d Outcomes and Followup: The total maximum score was 10 points. This included description of complications, side effects and adverse reactions (2 points); sufficient description of criteria for determining outcomes (2 points); reporting on the numbers and reasons for withdrawals from the study or losses to followup (2 points); proportion of patients who withdrew from the study or were lost to followup (2 points); and sufficiency of the planned length of followup (2 points).

e Statistical Quality and Interpretation: The total maximum score was 6 points. This included whether magnitude of difference between groups and an index variability was stated (2 points); whether analyses and statistical tests were clearly identified (2 points); and appropriate handling of crossovers and/or dropouts in the analysis (2 points).

f Conflict of Interest: The total maximum score was 2 points. This included whether the study reported the source of funding and the role played by the funding entity.

g Total Score is the mean of the percentage scores from the categories, Representativeness, Bias and Confounding, Description of Biopsy, Outcomes and Followup, and Statistical Quality and Interpretation.

Evidence Table 4. Results of studies addressing the relation of initial liver biopsy results to outcomes of treatment for chronic hepatitis C

| | | | | Multivariate
Author, Yr | Rx Group | | Outcome | Histological Variable(s) | Adj. Parameter Estimate Relating to SVR | Adj. p-value | Other Significant Independent Variables
Studies comparing peg-IFN + RBV with IFN alpha 2b + RBV
Manns, 2001 | A | IFN (maintenance): pegIFN2b, 1.5 mg/kg, once wkly, 48 wks | SVR | Absence of cirrhosis | NR** | NR | Weight, age, HCV viral load, HCV genotype other than 1b
| | | | Absence of bridging fibrosis or cirrhosis | NR | <.01
| | RBV (maintenance): 800 mg qd, 48 wks
| B | IFN (initial): pegIFN2b, 1.5 mg/kg, once wkly, 4 wks
| | IFN (maintenance): pegIFN2b, 0.5 mg/kg, once wkly, 44 wks
| | RBV (maintenance): 1000–1200 mg qd, 48 wks
| C | IFN (maintenance): alpha-2b, 3 mu tiw, 48 wks
Studies comparing IFN + RBV with IFN alone
Berg, 2000 | A | IFN: alpha-2a, 6 mu tiw, 12 wks | SVR | Histologic activity, grade and stage | NR | NR | HCV genotype GGT levels
| | RBV: 7 mg/kg, bid, 12 wks
| B | IFN: alpha-2a, 6 mu tiw, 12 wks
Mangia, 2001 | A | IFN (maintenance): alpha-2b, 5 mu tiw, 12 mos | SVR | Histologic grade | NR^b^ | NS | Genotype, IFN-ribavirin tx
| B | IFN (maintenance): alpha-2b, 5 mu tiw, 12 mos | | Histologic stage | NR^c^ | NS
| | RBV (maintenance): 1000–1200 mg qd, 12 mos | | Histologic stage | NR^d^ | NS
McHutchison, 2000 | A | IFN (210 pts): alpha-2b, 3 mu tiw, 24 wks | SVR | Degree of fibrosis | NR** | NR | IFN-ribavirin tx, gender, genotype, baseline viral load, compliance
| | IFN (461 pts): alpha-2b, 3 mu tiw, 24 wks
| | IFN (464 pts): alpha-2b, 3 mu tiw, 48 wks
| | IFN (465 pts): alpha-2b, 3 mu tiw, 48 wks
| | RBV (461 pts): 1000/1200 mg qd, 24 wks
| | RBV (464 pts): 1000/1200 mg qd, 48 wks
| B | IFN (12 pts): alpha-2b, 3 mu tiw, 24 wks
| | IFN (13 pts): alpha-2b, 3 mu tiw, 48 wks
| | IFN (13 pts): alpha-2b, 3 mu tiw, 48 wks
| | IFN (15 pts): alpha-2b, 3 mu tiw, 24 wks
| | RBV (13 pts): 1000/1200 mg qd, 48 wks
| | RBV (15 pts): 1000/1200 mg qd, 24 wks
| C | IFN (1 pts): alpha-2b, 3 mu tiw, 24 wks
| | IFN (13 pts): alpha-2b, 3 mu tiw, 24 wks
| | IFN (6 pts): alpha-2b, 3 mu tiw, 48 wks
| | IFN (7 pts): alpha-2b, 3 mu tiw, 48 wks
| | RBV (13 pts): 1000/1200 mg qd, 24 wks
| | RBV (7 pts): 1000/1200 mg qd, 48 wks
| D | IFN (12 pts): alpha-2b, 3 mu tiw, 48 wks
| | IFN (5 pts): alpha-2b, 3 mu tiw, 48 wks
| | IFN (7 pts): alpha-2b, 3 mu tiw, 24 wks
| | IFN (8 pts): alpha-2b, 3 mu tiw, 24 wks
| | RBV (12 pts): 1000/1200 mg qd, 48 wks
| | RBV (8 pts): 1000/1200 mg qd, 24 wks
Saracco, 2001 | A | IFN (maintenance): alpha-2b, 3 mu tiw, 12 mos | SVR | Grade ≥5.2 | OR: 1.0 (0.73 – 1.45) | 0.8 | Age ≤44, genotype 2 or 3, tx with 5 mu IFN-ribavirin for 12 mos
| | | | Stage ≥2.3 | OR: 0.93 (0.34 – 2.56) | 0.8
| | RBV (maintenance): 1000 mg qd, 12 mos | | Cirrhosis | OR: 0.5 (0.14 – 1.77) | 0.2
| B | IFN (maintenance): alpha-2b, 5 mu tiw, 12 mos
| | RBV (maintenance): 1000 mg qd, 12 mos
| C | IFN (maintenance): alpha-2b, 3 mu tiw, 6 mos
| | RBV (maintenance): 1000 mg qd, 6 mos
| D | IFN (maintenance): alpha-2b, 5 mu tiw, 6 mos
Studies comparing peg-IFN with IFN alpha-2b
Lindsay, 2001 | A | IFN (initial): pegIFN2b, 0.5 ng/kg, once wkly, 48 wks | SVR | HAI score | OR 2.2, 95% CI (1.1 – 4.8) | NS | HCV genotype other than 1, HCV RNA ≤2x10^6^ copies/mL
| B | IFN (initial): pegIFN2b, 1.0 ng/kg, once wkly, 48 wks
| C | IFN (initial): pegIFN2b, 1.5 ng/kg, once wkly, 48 wks
| D | IFN (initial): alpha-2b, 3 mu tiw, 48 wks
Studies comparing peg-IFN with IFN alpha-2a
Zeuzem, 2000 | A | Amantadine: 100 mg, Twice a day, 48 wks | SVR | Fibrosis at baseline | NR | NS | HCV genotype
| | IFN (initial): alpha-2a, 6 mu tiw, 24 wks
| | IFN (maintenance): alpha-2a, 3 mu tiw, 24 wks
| B | IFN (initial): alpha-2a, 6 mu tiw, 24 wks
Studies comparing different doses of IFN
Ascione, 1998 | A | IFN: alpha-2b, 3 mu tiw, 12 mos | SBR | Liver histology (chronic hepatitis v. cirrhosis) | NR | NR
| B | IFN: alpha-2b, 6 mu tiw, 12 mos
Kumada, 1996 | A | IFN (initial): natural IFN, 5 mu, bid, 20 wks | SVR | HAI score | 0.0018^a^ | 0.98 | HCV RNA concentration, genotype non 1b
| | IFN (initial): natural IFN, 5 mu, once wkly, 12 wks
| | IFN (initial): natural IFN, 5 mu, qd, 2 wks
| | IFN (initial): natural IFN, 5 mu tiw, 4 wks
| | IFN (maintenance): natural IFN, 5 mu, bid, 20 wks
| | IFN (maintenance): natural IFN, 5 mu, once wkly, 12 wks
| | IFN (maintenance): natural IFN, 5 mu, qd, 2 wks
| | IFN (maintenance): natural IFN, 5 mu tiw, 4 wks
| B | IFN (initial): natural IFN, 10 mu, bid, 20 wks
| | IFN (initial): natural IFN, 10 mu, once wkly, 12 wks
| | IFN (initial): natural IFN, 10 mu, qd, 2 wks
| | IFN (initial): natural IFN, 10 mu tiw, 4 wks
Payen, 1998 | A | IFN (maintenance): alpha-2b, 3 mu tiw, 6 mos | SVR | Pre-treatment Knodell index | mean 0.76 95% CI (0.61–0.95) | 0.015 | High level ALT, low viral load, viral genotype = 3, tx for 12 mos
| B | IFN (maintenance): alpha-2b, 3 mu tiw, 12 mos
| C | IFN (maintenance): alpha-2b, 10 mu tiw, 6 mos
Zeuzem, 2000a | A | IFN (initial): pegIFN2a, 180 ug, once wkly, 48 wks | SVR | Absence of cirrhosis or bridging fibrosis | NR | 0.03 | Tx with peg-IFN alpha 2a, age, smaller body surface, decreased HCV RNA, increased ALT quotient, HCV genotype other than 1
| B | IFN (initial): alpha-2a, 6 mu tiw, 12 wks
| | IFN (maintenance): alpha-2a, 3 mu tiw, 36 wks
Studies of IFN + colchicine
Angelico, 2000 | A | IFN (initial): alpha-2a, 6 mu tiw, 6 mos | Bio-chemical response^e^ | Low stage pre-treatment, | NR | 0.036 | Colchicine tx
| | | | Low grade pre-treatment | NR | 0.49
| | IFN (maintenance): alpha-2a, 3 mu tiw, 6 mos
| B | Colcichine (initial): 1 mg, 6x/wk, 3 yrs
| | IFN (initial): alpha-2a, 6 mu tiw, 6 mos
| | IFN (maintenance): alpha-2a, 3 mu tiw, 6 mos

a Estimate of Cox Proportional Hazard

b Based on analysis of total study population

c Based on analysis of Group A

d Based on analysis of Group B

e Similar results were found for SVR, data not presented

* P < 0.05

** Text reported that the statistic was significant but did not report the p-value

Evidence Table 5. Overall summary of studies evaluating biochemical tests and serologic measures of fibrosis that may predict findings of liver biopsy

Author, Year | Location | N | Inclusion Criteria | Exclusion Criteria | Study Aims
Extracellular matrix
Casaril, 2000 | Italy | 183 | HCV+ | Other viral infections: autoimmune hepatitis, HIV+, HCC, decompensated liver disease, IDU, Fe overload w/i 2y, chronic inflammatory disease, EtOH | To investigate the relationship between serum iron load and fibrosis as measured by liver bx and serum tests.
Di Costanzo, 1996 | Italy | 68 | Abnl ALT for > 3 yr, initial liver bx w/compatible histology, HCV+ | Large esophageal varices, other causes of liver disease, any disease that increases collagen metabolism, pulmonary fibrosis, rheumatic disease, decompensated liver disease | To evaluate whether assays for connective tissue polypeptides may be clinically useful in predicting primary response to IFN therapy
Fortunato, 2001 | Italy | 103 | Laboratory-confirmed hepatitis C, initial liver bx | Liver disease of any other etiology, HBV+, alcoholism, IFN, any previous therapy | To determine if a multivariate function based on 6 biochemical serum markers can distinguish chronic hepatitis from cirrhosis
Fukuda, 1998 | Japan | 36 | Congenital coagulation disorder, referred to the Hemophilia Group | | To determine whether serum fibrosis markers predict liver results in hemophiliacs bx results in hemophiliacs
Fukuzaki, 2000 | Japan | 78 | | IFN therapy, other chronic liver disease | To observe changes in HA, serum type IV collagen 7S region, and P-III-P in pts with complete, biochemical, or no response to IFN tx
Gabrielli, 1997 | Italy | 139 | ALT 2x UL of nl for 6 mos, initial liver bx showing CHC, positive HCV antibodies | Comorbidity: autoimmune or renal disease, malignancy comorbidity, IDU, other illicit drug use, EtOH >80 g/d | To correlate serum levels of laminin and type III procollagen w/histology
Giannini, 2001 | Italy | 109 | ALT >1.5x UL of nl for 6 mo, HCV+ | IFN monotherapy, autoimmune disease, any extrahepatic disease, HIV+, HBV+, EtOH | To assess the usefulness of serum P-III-P as a marker of hepatic fibrogenesis in pts w/CHC
Guechot, 1994 | Not specified | 176 | HCV+, serum alkaline phosphatase 2x nl, anti-mitochondrial antibodies titer > 1/100 | EtOH >50g/day, HBV+, pulmonary fibrosis, rheumatic disorders, | To determine the diagnostic value of aminoterminal propeptide of type III procollagen level and hyluronan levels in serum as markers of fibrosis
Guechot, 1996 | France | 326 | Initial liver bx: findings consistent with CHC infection, detectable HCV in serum, HCV+ | Rheumatic disease, pulmonary fibrosis, other chronic liver disease, HBV+ | To determine the diagnostic accuracy of HA and type III procollagen amino terminal peptide
Ikeda, 2000 | Japan | 205 | Initial liver bx, detectable HCV in serum, HCV+ | HCC, HBV+ | To use common laboratory data to discriminate between chronic hepatitis and cirrhosis.
Ishibashi, 1996 | Japan | 121 | ALT 1.5 UL of nl, detectable HCV in serum, HCV+ | IFN, any previous therapy, serum autoimmune markers, presence of cirrhosis, HBV+, EtOH | To evaluate the effect of IFN tx on serum markers of fibrosis
Jeffers, 1995 | United States | 86 | HCV+, initial liver biopsy, ALT el x 6 mos | Heavy EtOH, HBV+, negative autoantibodies, hepatotoxic drugs other liver disease | To correlate the level of P-III-P w/HCV-RNA concentration, ALT and histologic severity of disease
Kasahara, 1997 | Japan | 98 | ALT el for >= 6 mo, initial liver bx showing CHC, detectable HCV in serum, positive antibodies | EtOH, autoimmune hepatitis, HIV+, | To determine if MMPs MMP-1, and MMP-2, and tissue inhibitors of MMPs, TIMP-1, and TIMP-2, are associated w/bx findings.
Lichtinghagen, 1999 | Germany | | | | To examine the expression, concentration and activity of MMP-1, -2, -7 and -9 in liver and serum of pts w/CHC, HCV cirrhosis and healthy controls. To evaluate those parameters as markers of hepatic fibroproliferation.
Lichtinghagen, 2000 | Germany | 80 | Initial liver bx | Malignancy: assessed with chest x-rays, abdominal U/S, AFFP, CEA, and CA 19-9 | To assess if levels (or ratios) of MMP-2 and -9, in relation to their tissue inhibitors, are associated w/stage of HCV induced liver disease. (Levels were assessed for both circulating and expressed proteins in polymorphonuclear and mononuclear leukocytes.)
Lichtinghagen, 2001 | Germany | 46 | | | To evaluate the correlation between hepatic mRNA expression of MMP-2, -7, -9, TIMP-1, -2, and -3 w/disease activity of CHC.
Lo Iacono, 1998 | Spain, Italy | 52 | Abnl ALT, detectable HCV in serum, HCV+, age 18–60 yrs | Other viral infections: non-organ-specific auto-antibodies, HIV+, decompensated liver disease: “clinically advanced cirrhosis,” screened HBV antibodies, IDU, EtOH >80 g/d | To investigate the basal levels of circulating adhesion molecules and follow changes w/IFN therapy.
McHutchison, 2000a | United States Canada | 486 | HCV+, initial liver bx > 1cm length, or 3 portal triads | EtOH, chronic liver disease of any other etiology | To determine whether serum HA was a reliable predictor of cirrhosis and fibrosis
Murawaki, 1999 | Japan | 176 | Initial liver bx | Antiviral therapy, EtOH | To elucidate the clinical usefulness of the serum MMP-2 concentration in chronic viral liver disease.
Murawaki, 2001 | Japan | 165 | Initial liver bx, HCV+, plts, ALT, collagen, other serological markers, detectable HCV in serum | Presence of fibrosis, presence of cirrhosis, decompensated liver disease, peg-IFN monotherapy, peg-IFN + RBV, EtOH, IFN monotherapy, anti-retroviral therapy for HIV, IFN, IFN + RBV | Compare ROC serum IV-C and plt count for predicting fibrosis stage.
Murawaki, 2001a | Japan | 169 | Abnl ALT, detectable HCV in serum | Antiviral therapy, extrahepatic illnesses, presence of cirrhosis, EtOH | To assess the usefulness of serum fibrotic markers for diagnosing fibrotic staging and necroinflammatory grading in CHC.
Ninomiya, 1998 | Japan | 49 | Informed consent, ALT el for >= 6 mo, initial liver bx, detectable HCV in serum, HCV+ | Drug-induced liver disease, autoimmune hepatitis, HBV+, EtOH | 1. To evaluate HA as a marker of fibrosis.; 2. To investigate the effect of IFN tx on fibrosis.
Ohashi, 1998 | Japan | 62 | Initial liver bx, CHC w/o any other liver disease | | To clarify the effect of IFN tx on the serum markers of hepatic fibrosis and hepatic histological features.
Plevris, 2000 | United Kingdom | 221 | Initial liver bx | IFN tx | To evaluate serum HA as a marker of liver cirrhosis in pts w/chronic liver disease
Serejo, 2001 | Portugal | 117 | Detectable HCV in serum | Drug-induced liver disease, immune suppression-induced liver disease, HBV+, alcoholic liver disease | To assess clinical significance of serum P-III-P in assessing its ability to act as a marker for fibrogenins in pts treated w/alpha IFN.
Ueno, 2001 | Japan | 52 | ALT, initial liver bx, detectable HCV in serum, HCV+ | Routine medication use, high levels of antinuclear, antibody or antimitochondrial antibody, HBV+, excessive EtOH | To compare hepatic histological changes w/serum fibrosis markers before and after IFN tx alpha. To investigate the usefulness of serum fibrosis markers in the long-term followup of pts w/CHC.
Verbaan, 1997 | Sweden | 109 | Initial liver bx, HCV+ | IFN tx | To evaluate how well serum levels of P-III-P, IV-C and IgG correlate w/histological features
Walsh, 1999 | United Kingdom | 38 | | Wilson's disease, alph-1-antitrypsin hemochromatosis, HBV+, excessive EtOH | To evaluate the association of P-III-P (measured by two commercially available tests) and liver fibrosis
Walsh, 1999a | United Kingdom | 52 | Detectable HCV in serum, initial liver bx | EtOH, HBV+, decompensated liver disease, immune suppression, Wilson's disease, alpha-1-antitrypsin deficiency, hemochromatosis, significant extrahepatic disease | To determine the sensitivity/specificity of MMP-2, TIMP-1, TIMP-2 in detecting advanced liver disease (ISHAK >/= F3 and HAI > 6)
Walsh, 2000 | Europe | 42 | CHC via blood, transfusion, HIV- | HBsAg+, absence of liver autoantibodies, nl caeruloplasmin, alpha-1-antitrypsin deficiency, hemochromatosis, EtOH | To correlate laminin and IV-C w/liver bx findings
Wong, 1998 | United Kingdom | 130 | Detectable HCV in serum, initial liver bx | EtOH, HBV+, HCC, immune suppression, HIV+, liver disease of any other etiology, primary fibrosis, rheumatic disorders | To show that serum HA is a good marker for fibrosis in CHC pts.
Yamada, 1996 | Japan | 35 | ALT el for >6 mo, initial liver bx showing CHC, detectable HCV in serum, HCV+ | Any antiviral therapy, IFN + RBV, peg-IFN monotherapy, peg-INF + RBV, inflammatory connective tissue diseases, autoantibodies, presence of cirrhosis, HBV+ habitual EtOH | To examine the effect of IFN on serum HA levels. To determine the correlation between serial serum levels of HA and liver bx findings.
Yamada, 1998 | Japan | 36 | Detectable HCV in serum, HCV+ | Any previous therapy, connective tissue disorder, other viral infections: autoantibodies, HBV+, habitual EtOH | To see if serum P-III-P, IV-C and HA correlated w/stage of liver fibrosis in pts w/HCV, and to evaluate the effects of IFN therapy on these numbers
Cytokines/cytokine receptors
Izzo, 1996 | Italy | 297 | AFP, U/S, detectable HCV in serum for >5 yrs, HCV+ | Malignancy, HIV+, immune suppression, HCC, decompensated liver disease, HBV+ | To determine whether sIL-2R are el in pts w/CHC and whether these levels correlate w/histological severity of hepatic injury
Nutt, 2000 | United States | 70 | ALT, initial liver bx, detectable HCV in serum, positive HCV antibodies | GI comorbidity: other chronic liver diseases, HIV+, HBV+ | To compare liver histology of HCV+ w/nl ALT to HCV+ w/el ALT
Zylberberg, 1999 | France, Belgium | 154 | Detectable HCV in serum, HCV+ | Antiviral or immunomodulatory therapy for >= 6 mo, hemodialysis, HIV+ | To investigate the relationship between sTNF-alpha receptors and disease activity w/fibrosis.
Enzymes
Anderson, 2000 | Canada | 133 | HCV+, ALT el for >= 6 mo | Liver pathology not available, other chronic liver disease | To evaluate the clinical utility of ALT and AST in CHC pts.
Assy, 2000 | Canada | 79 | HCV+ | Other previous or concurrent liver disease, drug-induced hepatitis, hemochromatosis, HIV+, HBV+ | To assess the predictive values of age, gender, route of transmission, steatosis, EtOH, and ALT and AST on liver bx findings
Barbaro, 1996 | Italy | 156 | HCV+, detectable HCV in serum | Hypertension, chronic, EtOH, HBV+, pregnancy, metabolic liver disease, autoimmune hepatitis, age <18 yrs, diabetes, CD4 <400, hepatotoxic drugs w/i 6 mo, any previous antiviral therapy, WBC <2500, neutrophil <1000, Hgb <10, Bili >3 x nl, PT >5 over control, Cr >2 x nl, other viral hepatitis | To evaluate the association between glutathione and HIV status, HCV replication, and liver bx findings.
Choi, 1999 | United States | 38 | Serological markers: ALT and HCV-RNA, HCV+ | | To determine whether ALT levels and histopathological changes in liver bx specimens correlate w/HCV disease progression or response to IFN tx.
Enzymes
Goldstein, 1999 | United States | 81 | Bx w/>3 portal tracts, AFP, initial liver bx, detectable HCV in serum, positive HCV antibodies | Yolk sac carcinoma, HIV+, HCC, HBV+, EtOH >60 g/d for >5 yrs | To show a relationship between AFP, ALT, inflammation and fibrosis, and hepatocyte MIB-1 scores.
Gordon, 2000 | United States | 1744 | HCV+, detectable HCV in serum, ALT abnl x 6 mos prior to study | | To see if pretreatment ALT levels correlate w/histologic features and whether these values influence response to tx
Haber, 1995 | United States | 90 | HCV+, liver bx slides on file | Difficulty making firm HCV diagnosis | To determine the relationship between serum aminotransferase levels and histological grade in HCV
Healey, 1995 | United Kingdom | 42 | HCV+, Detectable HCV in serum, initial liver bx, >= 3 serial transminases of serum alanine aminotransferase | | To determine the correlation between liver histology and serum transaminases in hepatitis C infection
Imbert-Bismut, 2001 | France | 339 | Initial liver bx, detectable HCV in serum, HCV+ | Inadequate liver bx, other liver disease, HIV+, HBV+ | To assess the predictive value of basic serum biochemical markers for diagnosis of liver fibrosis in pts w/CHC
Imperiale, 2000 | United States | 177 | ALT measured w/i 4 mo of liver bx, initial liver bx between 1993 and 1998, detectable HCV in serum, HCV+ | GI comorbidity: primary biliary cirrhosis or primary sclerosing cholangitis, Wilson's disease and alpha-1-antitrypsin, autoimmune suppression as cause of liver disease, HBV+ | To evaluate the AST/ALT ratio in ability to diagnose cirrhosis in pts w/CHC infection.
Jamal, 1999 | United States | 275 | ALT in 4 consecutive determinations either all nl or all el, detectable HCV in serum, HCV+, HCV genotype | IFN monotherapy, hemochromatosis, autoimmune disease, immune suppression, HCC, HBV+ <18 yrs | To describe the clinical and histological features of pts w/CHC and nl ALT levels.
Kobayashi, 2000 | Japan | 61 | Initial liver bx, IFN monotherapy for 6 mos, positive HCV antibodies | | To assess the correlation between serial changes in ALT levels and histological outcome 5 yrs after tx of pts w/CHC w/IFN for 6 mos.
Luo, 1998 | Taiwan | 93 | ALT >=1.5 x nl for >6 mo, HCV+ | Renal dialysis, HIV+, HBV+, metabolic liver disease, hepatotoxic drugs, homosexuality, IDU, EtOH >60 g/d | To study the relationship between ALT levels, histology, serum HCV-RNA and HCV genotypes in pts w/CHC.
McCormick, 1996 | United States | 44 | Adequate size of liver bx, other serological markers: ALT w/i 4 wk of liver bx, initial liver bx, nl serum Fe, negative AMA, nl ceruloplasmin, detectable HCV in serum | HBV+ | To evaluate whether ALT level or HCV-RNA levels can predict histological measures in pts w/CHC.
Michielsen, 1997 | Belgium | 51 | ALT el for >6 mo, initial liver bx, detectable HCV in serum, CAH | Pts w/persistently nl AST/ALT levels | To determine if a correlation exists between el AST and/or ALT, and histological disease in pts w/CHC
Ono, 1999 | Japan | 435 | HCV+ | HCC: diffuse, HCC or portal vein invasion | To evaluate the stage of liver fibrosis using routine clinical blood biochemistry tests
Park, 2000 | Australia | 153 | El ALT for >= 6 mo w/i 4 mo of bx, initial liver bx: CHC or cirrhosis, presence of fibrosis, HCV+ | Antiviral treatment at time of bx, liver disease w/any other etiology, EtOH >20 g/d currently or w/i 5 yrs | To see if AST/ALT ratio greater than one predicted cirrhosis accurately in pts w/HCV
Poynard, 1997 | France | 500 | Initial liver bx consistent w/CHC, HCV+ | HBV+, any IFN tx, other liver disease | To assess the predictive value of (1)social and clinical factors (age, gender, infection duration, delay between biologic determination and bx, homosexuality, transmission via blood transfuction, transmission by IDU, body weight, ethnicity) and (2) biologicial factors (AST/ALT, GGT, serum bili, serum albumin, PT, WBC, plts, serum Hgb, serum creatinine) for the presence of histologic activity or fibrosis.
Sheth, 1998 | United States | 139 | Biochemical determinations w/i 4 mo of liver bx, ALT el for 6 mo, HCV+ | | To evaluate whether the ratio of AST to ALT predicts cirrhosis and fibrosis stage in pts w/CHC infection
Shima, 2000 | Japan | 36 | CHC on initial liver bx | Detectable HCV in serum after prior tx and 3 yrs following tx, metabolic disease, autoimmune hepatitis, HBV+, alcohol abuse | To evaluate the relationship between serum total bile acid and liver inflammation and fibrosis in IFN treated pts
Stanley, 1996 | United Kingdom | 100 | HCV+ | | To examine liver histology in pts w/nl an abnl ALT and chronic HCV infection
Tsushima, 1999 | Japan | 53 | Detectable HCV in serum, HCV+ | | To evaluate the association of plasma TGF-B1 w/liver fibrosis.
Yeo, 2001 | United States | 60 | ALT between nl and 2X nl, positive HCV antibodies | | To examine the relationship between HCV-RNA levels and severity of disease in pts w/chronic HCV
Viral markers
Adinolfi, 1998 | Italy | 36 | ALT el for >= 6 mo, detectable HCV in serum, positive HCV antibodies | IFN or immunosuppressive therapy malignancy comorbidity, immune suppression, presence of cirrhosis, HBV+, excessive alcohol intake | To evaluate the relationship between HCV-RNA levels in serum, liver, and periportal blood mononuclear cells and the degree of liver injury in CHC pts
Iijima, 2000 | Japan | 135 | >= 5 yrs f/u of liver bx, HCV core protein, initial liver bx, detectable HCV in serum, HCV+ | IFN tx, any antiviral therapy, malignancy, HIV+, immune suppression, cirrhosis, HBV+, EtOH >80 g/d, age >60 yrs | To determine if HCV viremia correlates w/degree of fibrosis
Kao, 1996 | Taiwan | 94 | ALT >62 for >1 yr, initial liver bx, detectable HCV in serum, HCV+ | Lamivudine for HBV, anti-retroviral therapy for HIV, IFN, any previous therapy, drug-induced hepatitis, immune suppression, HBV+, IDU, EtOH | To clarify the relationship between serum HCV titer and histological severity
Papatheodoridis, 1997 | Greece | 112 | Detectable HCV in serum | HBV+, HIV+, autoantibodies, alcoholic liver disease, therapy in previous 6 mos | To investigate the significance of IgM anti core antibody associations with HCV genotype and liver disease necroinflammatory action
Puoti, 1999 | Italy | 59 | Signed consent, ALT nl 3 times at 2-mo intervals for >= 6 mo, detectable HCV in serum, HCV+ | Abnl ferritin, plts <100,000, any previous therapy, HBV+, EtOH >60 g/d for men and >40 g/d for women | To see if HCV carriers w/nl ALT levels show a correlation between serum HCV-RNA titers and liver histology which could be used as a non-invasive means to separate healthy carriers from those w/liver damage.
Miscellaneous
Bayati, 1998 | United States | 200 | Initial liver bx | EtOH >60 g/d for >5 yrs | To determine the relation between AFP and liver histology in pts w/CHC.
Chu, 2001 | Taiwan | 115 | ALT 1.5x nl for >6 mos, U/S w/o evidence of HCC, detectable HCV in serum, positive HCV antibodies | Renal dialysis, exposure to hepatotoxic medications, metabolic liver disease, HCC, decompensated liver disease, HBV+, IDU, EtOH >60 g/d | To assess the prevalence of el AFP in pts w/CHC and to evaluate the clinical, virologic and histopathological significance.

Evidence Table 6. Characteristics of patients in studies evaluating biochemical tests and serologic measures of fibrosis that may predict findings of liver biopsy

Author, Year | Study Design | Study Groups | N | Mean age % Male Race | % w/ Cirrhosis | Scoring System | Mean Acitvity Fibrosis (S) | % w/ Score Acitvity (A) Fibrosis (S) | Mean ALT (U/L) Mean yrs w/ HCV HCV genotype
Extracellular matrix
Casaril, 2000 | CC
| | A: CHC Pts | 102 | 42.5 | | Sch
| | | | 54
| | B: Healthy subjects w/ nl liver function tests and negative viral studies | 81 | 44.2 | | Sch
| | | | 58
Di Costanzo, 1996 | CohP
| | A: Responders to IFN alpha | 22 | 47.1 | 18 | HAI | A 9.5
| | | | 77 | | HAI | S 2.2
| | B: Nonresponders to IFN alpha | 46 | 50.3 | 41 | HAI | A 9.1
| | | | 72 | | HAI | S 2.7
Fortunato, 2001 | XS
| | A: Pts w/ chronic HCV infection | 54
| | B: Pts w/ cirrhosis from HCV infection | 49
Fukuda, 1998 | CohR
| | O: Hemophilia Pts who had liver bx before IFN tx | 36 | 31
| | | | 94
Fukuzaki, 2000
| | A: Complete response: ALT 2x nl range (<40 U/l) during tx and maintained for 24 wks and HCV RNA- at 42 wks post tx | 23 | 46 | | HAI | | | 78
| | | | 39
| | | | | | | | | 1b/2a | 39.13
| | | | | | | | | 2b | 56.52
| | B: Biochemical response: ALT 2x nl range (<40 U/l) during tx and maintained for 24 wks and HCV RNA+ at 42 wks post tx | 9 | 53 | | | | | 75
| | | | 78
| | | | | | | | | 1b/2a | 55.56
| | | | | | | | | 2b | 44.44
| | C: No response | 46 | 53 | | | | | 105
| | | | 37 | | | | | 1b/2a | 1b/2a
| | | | | | | | | 2b | 6.52
Gabrielli, 1997
| | A: Pts w/ chronic HCV infection | 99 | 50 | | Sch
| | | | 64
| | B: Healthy controls | 40
Giannini, 2001 | CS
| | O: Pts w/ chronic HCV infection | 109 | 44 | | HAI/Tri | S 0.9
| | | | 74 | | HAI/Tri | A 6.5
Guechot, 1994 | CC
| | A: Pts in cohort of ursodiol for PBC trial | 78
| | | | 9
| | B: Pts in trial of alpha-IFN for viral hepatitis C treatment | 58
| | | | 71
| | C: Healthy controls | 40
| | | | 25
Guechot, 1996 | XS
| | O: HCV+ pts | 326 | 43.6 | 16 | HAI | | A0 13.5
| | | | 55 | | HAI | | A1 52.8
| | | | | | HAI | | A3 17.5
| | | | | | HAI | | A4 16.2
Ikeda, 2000 | CS
| | O: 205 consecutive Pts w/ CHC | 205 | 56
| | | | 55
Ishibashi, 1996 | CohP
| | A: Complete responders to IFN tx | 49
| | B: Relapsers after IFN tx | 36
| | C: Nonresponders to IFN tx | 36
Jeffers, 1995 | XS
| | A: Pts w/ mild CAH | 34 | | | HAI | | | 114
| | B: Pts w/ moderate-severe CAH | 25 | | | | | | 169
| | C: Pts w/ cirrhosis | 27 | | | | | | 160
Kasahara, 1997 | CohP
| | A: IFN tx, sustained response | 26 | 52.2 | | HAI | 8.8
| | | | 54
| | | | | | | | | 1b | 53.85
| | | | | | | | | 2a | 34.62
| | | | | | | | | 2b | 3.85
| | | | | | | | | not specified | 0.00
| | B: IFN tx, transient response | 21 | 51.7 | | HAI | 8.2
| | | | 62
| | | | | | | | | 1b | 90.48
| | | | | | | | | 2a | 0.00
| | | | | | | | | 2b | 4.76
| | | | | | | | | not specified | 9.52
| | C: IFN tx, no response | 51 | 55.3 | | HAI | 9.2
| | | | 43
| | | | | | | | | 1b | 92.16
| | | | | | | | | 2a | 5.88
| | | | | | | | | 2b | 1.96
| | | | | | | | | not specified | 0.00
Lichtinghagen, 1999 | CS
| | A: Pts w/ CHC presenting to OP clinic | | | | MHAI
| | B: Nl serum and plasma from healthy blood donors
| | C: Livers explanted, but unable to transplant
| | D: Cirrhotic liver from transplant pts
Lichtinghagen, 2000 | CohR
| | A: Healthy controls | 20 | | | MHAI
| | B: HCV+ Pts w/ chronic hepatitis | 40
| | C: HCV+ Pts w/ cirrhosis | 20
Lichtinghagen, 2001 | CS
| | A: Pts w/ CHC | 29 | | | MHAI
| | B: Pts w/ CHC and cirrhosis | 7
| | C: Nl controls | 10
Lo Iacono, 1998
| | O: CHC virus Pts w/ recurring IFN tx | 52 | 40.8 | | HAI | A 4.4
| | | | 63 | | Sch | S 1.6
| | | | | | | | | 1b | 73.08
| | | | | | | | | non-1b | 26.92
McHutchison, 2000a | CohR
| | O: Pts w/ CHC enrolled in a tx study for CHC | 486 | | | | | A0 22.2 | 132
| | | | 73 | | | | A1 49.2
| | | | | | | | A3 12.5
| | | | | | | | A4 16.0
Murawaki, 1999 | CC
| | A: Pts w/ minimal chronic hepatitis. | 24 | 49 | | HAI
| | | | 83
| | B: Pts w/ mild chronic hepatitis. | 21 | 51
| | | | 62
| | C: Pts w/ moderate chronic hepatitis. | 17 | 49
| | | | 53
| | D: Pts w/ liver cirrhosis | 35 | 58
| | | | 74
| | E: Pts w/ hepatocellular carinoma. | 55 | 65
| | | | 69
| | F: Control Pts w/ no liver disease. | 24 | 46
| | | | 58
Murawaki, 2001 | CS
| | O: Pts HCV+ w/liver bx (fibrosis < F4) | 165 | 53 | | Met/Des | | S0 9.0
| | | | 67 | | Met/Des | | S1 78.0
| | | | | | Met/Des | | S2 40.0
| | | | | | Met/Des | | S3 38.0
Murawaki, 2001a | CohP
| | O: Pts w/ chronic HCV w/o cirrhosis | 169 | 53 | | Des
| | | | 66
Ninomiya, 1998 | CohP
| | A: IFN tx, complete response | 16 | 44.9 | | HAI | A 3.0
| | | | 56 | | HAI | S 10.8
| | B: IFN tx, partial response | 25 | 42.3 | | HAI | A 3.2
| | | | 64 | | HAI | S 9.5
| | C: IFN tx, no response | 8 | 52.6 | | HAI | A 3.5
| | | | 75 | | HAI | S 10.9
Ohashi, 1998 | CohP
| | A: Pts who completely responded to IFN. | 27 | 48.8 | | HAI
| | | | 56
| | | | | | | | | 1a | 0.00
| | | | | | | | | 1b | 25.93
| | | | | | | | | 2a | 25.93
| | | | | | | | | 2b | 11.11
| | | | | | | | | mixed | 7.41
| | | | | | | | | not specified | 11.11
| | B: Pts who did not respond to IFN. | 35 | 54.2
| | | | 66
| | | | | | | | | 1a | 0.00
| | | | | | | | | 1b | 57.14
| | | | | | | | | 2a | 8.57
| | | | | | | | | 2b | 5.71
| | | | | | | | | mixed | 0.00
| | | | | | | | | not specified | 2.86
Plevris, 2000 | CohP
| | A: Pts w/ liver disease caused by HCV infection | 69 | | | HAI
| | B: Pts w/ liver disease caused by alcohol
| | C: Pts w/ autoimmune liver disease
| | D: Pts w/ primary bilary cirrhosis
| | E: Pts w/ cryptogenic liver disease
Serejo, 2001 | CohP
| | A: Pts who were sustained responders. | 44 | 35.9 | | HAI | A 7.5 | A0-A1 50.0 | 1 | 38.64
| | | 64 | | | | | A2 50.0 | mixed | 13.64
| | | | | | | | A3 0.0 | other | 20.45
| | B: Pts who were relapsers. | 35 | 39.9 | | HAI | A 6.9 | A0-A1 65.7 | 1 | 40.00
| | | | 51 | | | | A2 34.3 | mixed | 25.71
| | | | | | | | A3 0.0 | other | 17.14
| | C: Pts who were nonresponders. | 38 | 45.5 | | HAI | A 11.1 | A0-A1 34.2 | 1 | 42.11
| | | 68 | | | | | A2 28.9 | mixed | 7.89
| | | | | | | | A3 36.8 | other | 23.68
Ueno, 2001 | CohP
| | A: Complete responders w/ bx done <2 yrs after tx. | 12 | 47 | | Met | A 1.6
| | | | 50 | | Met | S 1.4
| | B: Nonresponders w/ bx done <2 yrs after tx | 24 | 48 | | Met | A 2.0 | | 77
| | | | 71 | | Met | S 1.1
| | C: Complete responders w/ bx done >2 yrs after tx | 10 | 51 | | Met | A 2.5 | | 71
| | | | 60 | | Met | S 1.1
| | D: Nonresponders w/ bx done > 2 yrs after tx | 6 | 51 | | Met | A 1.5 | | 94
| | | | 67 | | Met | S 1.3
Verbaan, 1997 | CohR
| | O: Pts w/ CHC infection | 109 | 46 | | HAI
| | | | 66
Walsh, 1999
| | A: Pts w/ CHC infection | 33 | | | MHAI
| | B: Healthy controls | 5
Walsh, 1999a | CohP
| | A: CHC w/liver bx | 43 | | | MHAI
| | | | 67
| | B: Healthy controls | 19
Walsh, 2000 | XS
| | A: Pts w/ chronic HCV infection | 37
| | | | 65
| | B: Healthy controls | 5
| | | | 80
Wong, 1998 | CS
| | O: CHC virus Pts | 130 | 37
| | | | 72
Yamada, 1996 | CohP
| | A: Pts who were complete responders to IFN tx. | 9 | | | Oth
| | B: Pts who were partial responders to IFN tx. | 14
| | C: Pts who were nonresponders to IFN tx. | 12
Yamada, 1998 | CohP
| | O: Japanese Pts w/ CHC and hemophilia | 36 | 31 | | Des
| | | | 94
Cytokines/cytokine receptors
Izzo, 1996 | CC
| | A: Pts w/ chronic HCV infection | 123 | 53.9
| | | | 67
| | B: Healthy HBV and HCV- controls | 174
Nutt, 2000 | CS
| | A: HCV+ consecutive Pts w/ liver bx and nl ALT on >/= 2 occasions | 35 | 44 | | HAI | A 4
| | | | 80
| | B: HCV+ consecutive Pts w/ liver bx and el ALT | 35 | 46 | | HAI | A 7
| | | | 91
Zylberberg, 1999 | CC
| | A: Pts w/ CHC | 60 | 48
| | | | 68
| | | | | | | | | 1 | 60.00
| | | | | | | | | 2 | 6.67
| | | | | | | | | 3 | 20.00
| | | | | | | | | Other | 13.33
| | B: Pts w/ chronic HBV | 34 | 41
| | | | 76
| | C: Healthy control Pts
Enzymes
Anderson, 2000 | CohR
| | O: | 133 | 45.6
| | | | 70
Assy, 2000 | CohR
| | O: Pts w/ chronic HCV infection | 79 | 43.5 | | Des | S 1.5
| | | 59 | | | HAI | A 3.5
Barbaro, 1996 | CC
| | A: Pts+ for HIV and HCV infection | 55 | 17 | | HAI | | S0 3.6
| | | | 82 | | HAI | | S1 3.6
| | | | | | HAI | | S2 47.3
| | | | | | HAI | | S3 38.2
| | | | | | HAI | | S4 7.3
| | B: HCV+ pts | 50 | 30 | | HAI | | S0 4.0
| | | | 94 | | HAI | | S1 6.0
| | | | | | HAI | | S2 42.0
| | | | | | HAI | | S3 42.0
| | | | | | HAI | | S4 6.0
| | C: Healthy controls | 51 | 30
| | | | 69
Choi, 1999 | CS
| | O: Pts w/ CHC infection | 38 | 44 | | Oth
| | | | 39
Goldstein, 1999 | XS
| | O: CHC Pts given AFP, ALT testing, and liver bx | 81
Gordon, 2000 | CohP
| | A: ALT <1.3 × nl in pts w/ HCV | 105 | 40.9 | | MHAI
| | B: ALT >1.3 × nl in pts w/ HCV | 1639 | 42.9
Haber, 1995 | CS
| | O: Pts w/ serologically confirmed HCV | 90 | 40.9 | | HAI
| | | | 69 | | | | | 14.5
Healey, 1995 | CohR
| | A: HCV+ normal AST | 19 | 38.9 | | HAI
| | | | 42
| | B: HCV+ abnormal AST | 23 | 35.7
| | | | 61
Imbert-Bismut, 2001 | XS
| | A: CHC Pts tested in first yr period | 205 | 47 | | Met | | A0 25.4 | 108
| | | | 53 | | | | A1 41.5
| | | | | | | | A2 30.7
| | | | | | | | A3 2.4
| | | | | | | | S0 17.6
| | | | | | | | S1 44.4
| | | | | | | | S2 19.5
| | | | | | | | S3 8.8
| | | | | | | | S4 9.8
| | B: CHC Pts tested in second yr, as confirmatory group | 134 | 48 | | | | A0 12.7 | 122
| | | | 84 | | | | A1 59.7
| | | | | | | | A2 24.6
| | | | | | | | A3 3.0
| | | | | | | | S0 14.9
| | | | | | | | S1 40.3
| | | | | | | | S2 20.9
| | | | | | | | S3 7.5
| | | | | | | | S4 16.4
Imperiale, 2000 | CohR
| | O: A cohort of Pts w/ HCV. | 177 | 42.3 | | Oth
| | | | 36
Jamal, 1999 | CC
| | A: HCV Pts w/ nl ALT levels. | 75 | 44 | | MHAI | S 1.4
| | | | 60 | | | | | 21
| | | | C: 46.6, O: 53.3
| | B: HCV Pts w/ abnl ALT levels. | 200 | 44
| | | | 58 | | | | | 20
| | | | C: 42, O: 58
Kobayashi, 2000 | CohR
| | O: consecutive Pts treated w/ alpha-IFN for 6 mos w/ f/u of 5 yrs | 61 | 47 | | MHAI | | | 96
| | | | 77
| | | | | | | | | 1b | 86.89
| | | | | | | | | other | 13.11
Luo, 1998
| | O: 93 Pts w/ CHC. | 93 | 53 | | Oth | A 1.3
| | | | 72 | | | A 2.3
| | | | | | | A 2.6 | | 1b | 38.71
| | | | | | | | S1-S2 39.8 | 2a | 13.98
| | | | | | | | S3 47.3 | 2b | 11.83
| | | | | | | | S4 12.9 | mixed | 3.23
| | | | | | HAI | S 1.5 | | not specified | 3.23
McCormick, 1996 | CohR
| | O: Pts w/ CHC who were either treated or untreated and were biopsied. | 44 | | | HAI
| | | | 77
Michielsen, 1997 | CS
| | O: CHC Pts | 51 | 47 | | HAI/Oth
| | | | 53
Ono, 1999 | XS
| | O: Pts w/ chronic HCV infection | 435 | 58 | | Des
| | | | 73
Park, 2000 | CohR
| | O: Pts w/ CHC | 153 | 46.5 | | Sch | | | 20
| | | | 64
Poynard, 1997 | XS
| | O: Pts w/ chronic HCV infection | 500 | 49.1 | | Met
| | | | 58
| | | | C: 97.2, O: 0.8
Sheth, 1998 | CohR
| | A: Ratio of AST to ALT >/= 1 in Pts w/ CHC | | | | Oth
| | B: Ratio of AST to ALT </= 1 in Pts w/ CHC
Shima, 2000 | CohP
| | O: Pts w/ chronic HCV infections w/ sustained response to IFN tx | 36 | 56 | | HAI | <10 77.8
| | | | 67 | | HAI | >11 22.2
Stanley, 1996 | CS
| | A: Pts w/ chronic HCV infection and nl ALT | 15 | 38.9 | | Oth
| | | | | | | | | 1a | 20.00
| | | | | | | | | 3a | 13.33
| | B: Pts w/ chronic HCV infection and el ALT | 85 | 38.2
| | | | | | | | | 1a | 29.41
| | | | | | | | | 3a | 29.41
Tsushima, 1999 | CohR
| | A: Pts receiving IFN tx. | 43 | 51.8 | | Oth
| | | | 74
| | B: Pts not receiving IFN tx. | 10 | 57.6
| | | | 80
Yeo, 2001 | CS
| | O: Pts w/ chronic HCV infection | 60 | | | HAI
| | | | 47
| | | | C: 80, B: 20 | | | | | 1a | 43.33
| | | | | | | | | 1b | 31.67
| | | | | | | | | 2a/b | 8.33
| | | | | | | | | unknown | 18.33
Viral markers
Adinolfi, 1998 | XS
| | O: HCV+ Pts undergoing liver bx and HCV-RNA levels | 36 | 53 | 25 | HAI | | A1 25.0
| | | | 64 | | HAI | | A2 33.3
| | | | | | HAI | | A3 16.7 | 1b | 52.78
| | | | | | | | | 2a/c | 33.33
| | | | | | | | | 3a | 5.56
| | | | | | | | | 4 | 2.78
| | | | | | | | | mixed | 5.56
Iijima, 2000 | CS
| | O: CHC Pts not receiving antiviral therapy | 135 | 49.5 | | HAI/Des
| | | | 70
Kao, 1996 | XS
| | A: Pts w/ chronic persistent hepatitis | 34 | 43 | | Oth | | | 131
| | | | 59 | | | | | 1b | 64.71
| | B: Pts w/ CAH and/or liver cirrhosis | 30 | 51 | | | | | 162
| | | | 67 | | | | | 1b | 66.67
| | C: Pts w/ HCC | 30 | 65 | | | | | 74
| | | | 73 | | | | | 1b | 80.00
Papatheodoridis, 1997
| | O: Pts w/ chronic HCV | 112 | 43.7 | | HAI
| | | | 69
| | | | | | | | | 1a | 7.14
| | | | | | | | | 1b | 24.11
| | | | | | | | | 2a | 5.36
| | | | | | | | | 3a | 18.75
| | | | | | | | | 4a | 2.68
Puoti, 1999 | CohP
| | O: Anti-HCV+ Pts w/ persistently nl ALT | 59 | 47.5 | | HAI | A 0.8
| | | | 34 | | HAI | S 4.0
Miscellaneous
Bayati, 1998 | CS
| | A: Pts w/ a nl AFP level of <10. | 125 | 52.5 | 46 | Des
| | | | 56 | | | | | 22.5
| | B: Pts w/ a high AFP level of >/= 10. | 75 | 57.7 | 68
| | | | 48 | | | | | 26.4
Chu, 2001 | XS
| | A: Chronic HCV Pts w/ el AFP | 33 | 57 | | HAI/Sch
| | | | 36
| | | | | | | | | 1b | 72.73
| | | | | | | | | non-1b | 21.21
| | B: Chronic HCV Pts w/ nl AFP | 82 | 49
| | | | 29
| | | | | | | | | 1b | 45.12
| | | | | | | | | non-1b | 43.90

Evidence Table 7. Methodologic quality of studies evaluating biochemical tests and serologic measures of fibrosis that may predict findings of liver biopsy

Author, Year | Representativeness^a^ | Bias^b^ | Description^c^ | Outcomes^d^ | Statisties^e^ | Conflict^f^ | Total^g^
Extracellular matrix
Casaril, 2000 | 70 | 50 | 0 | 0 | 100 | 0 | 44
Di Costanzo, 1996 | 60 | 100 | 50 | 75 | 100 | 50 | 77
Fortunato, 2001 | 50 | 100 | 100 | 50 | 100 | 50 | 80
Fukuda, 1998 | 50 | 50 | 0 | 100 | 25 | 0 | 45
Fukuzaki, 2000 | 50 | 0 | 0 | 0 | 67 | 0 | 29
Gabrielli, 1997 | 60 | 100 | 100 | 50 | 100 | 50 | 82
Giannini, 2001 | 70 | 100 | 100 | 50 | 100 | 0 | 84
Guechot, 1994 | 40 | 0 | 50 | 33 | 100 | 0 | 45
Guechot, 1996 | 60 | 50 | 50 | 50 | 67 | 0 | 55
Ikeda, 2000 | 90 | 0 | 50 | 100 | 50 | 0 | 58
Ishibashi, 1996 | 50 | 0 | 50 | 50 | 100 | 0 | 50
Jeffers, 1995 | 70 | 100 | 0 | 100 | 75 | 0 | 69
Kasahara, 1997 | 70 | 100 | 50 | 25 | 67 | 0 | 62
Lichtinghagen, 1999 | 20 | 0 | 0 | 0 | 33 | 0 | 11
Lichtinghagen, 2000 | 30 | 100 | 0 | 33 | 100 | 50 | 53
Lichtinghagen, 2001 | 30 | 100 | 0 | 50 | 100 | 50 | 56
Lo Iacono, 1998 | 80 | 100 | 50 | 56 | 67 | 50 | 71
McHutchison, 2000a | 100 | 50 | 50 | 50 | 100 | 0 | 70
Murawaki, 1999 | 50 | 50 | 0 | 50 | 100 | 50 | 50
Murawaki, 2001 | 50 | 100 | 50 | 50 | 100 | 50 | 70
Murawaki, 2001a | 50 | 100 | 50 | 0 | 100 | 50 | 60
Ninomiya, 1998 | 60 | 50 | 0 | 25 | 67 | 50 | 40
Ohashi, 1998 | 80 | 50 | 0 | 50 | 100 | 0 | 56
Plevris, 2000 | 30 | 100 | 100 | 50 | 100 | 0 | 76
Serejo, 2001 | 50 | 100 | 0 | 50 | 100 | 0 | 60
Ueno, 2001 | 80 | 100 | 100 | 25 | 67 | 50 | 74
Verbaan, 1997 | 90 | 100 | 100 | 83 | 67 | 50 | 88
Walsh, 1999 | 50 | 50 | 0 | 67 | 100 | 50 | 53
Walsh, 1999a | 50 | 100 | 0 | 50 | 100 | 0 | 60
Walsh, 2000 | 50 | 50 | 0 | 50 | 100 | 0 | 50
Wong, 1998 | 80 | 50 | 0 | 100 | 100 | 0 | 66
Yamada, 1996 | 60 | 100 | 0 | 50 | 100 | 0 | 62
Yamada, 1998 | 60 | 50 | 50 | 50 | 100 | 0 | 62
Cytokines/cytokine receptors
Izzo, 1996 | 80 | 0 | 50 | 25 | 67 | 50 | 44
Nutt, 2000 | 60 | 100 | 0 | 100 | 75 | 0 | 67
Zylberberg, 1999 | 60 | 100 | 0 | 25 | 67 | 0 | 50
Enzymes
Anderson, 2000 | 70 | 0 | 0 | 0 | 100 | 50 | 34
Assy, 2000 | 70 | 100 | 0 | 50 | 100 | 50 | 64
Barbaro, 1996 | 60 | 100 | 100 | 25 | 100 | 0 | 77
Choi, 1999 | 40 | 50 | 0 | 50 | 75 | 0 | 43
Goldstein, 1999 | 60 | 100 | 50 | 50 | 100 | 0 | 72
Gordon, 2000 | 83 | 50 | 0 | 50 | 100 | 0 | 57
Haber, 1995 | 100 | 100 | 0 | 100 | 100 | 50 | 80
Healey, 1995 | 60 | 100 | 50 | 25 | 17 | 0 | 50
Imbert-Bismut, 2001 | 90 | 100 | 50 | 50 | 100 | 50 | 78
Imperiale, 2000 | 75 | 50 | 0 | 50 | 100 | 0 | 55
Jamal, 1999 | 75 | 100 | 0 | 50 | 100 | 0 | 65
Kobayashi, 2000 | 75 | 100 | 50 | 50 | 100 | 0 | 75
Luo, 1998 | 60 | 100 | 100 | 50 | 100 | 0 | 82
McCormick, 1996 | 50 | 50 | 0 | 50 | 75 | 0 | 45
Michielsen, 1997 | 70 | 100 | 0 | 50 | 100 | 0 | 64
Ono, 1999 | 90 | 100 | 50 | 50 | 100 | 0 | 78
Park, 2000 | 50 | 50 | 0 | 50 | 100 | 0 | 50
Poynard, 1997 | 50 | 100 | 0 | 50 | 100 | 50 | 60
Sheth, 1998 | 80 | 50 | 0 | 50 | 100 | 0 | 56
Shima, 2000 | 60 | 100 | 0 | 50 | 100 | 0 | 62
Stanley, 1996 | 88 | 100 | 50 | 50 | 100 | 0 | 78
Tsushima, 1999 | 63 | 100 | 100 | 33 | 100 | 0 | 79
Yeo, 2001 | 70 | 100 | 0 | 67 | 100 | 100 | 67
Viral markers
Adinolfi, 1998 | 60 | 0 | 0 | 50 | 50 | 50 | 32
Iijima, 2000 | 80 | 100 | 0 | 25 | 100 | 50 | 61
Kao, 1996 | 80 | 50 | 0 | 50 | 100 | 50 | 56
Papatheodoridis, 1997 | 88 | 100 | 0 | 50 | 100 | 0 | 68
Puoti, 1999 | 70 | 100 | 50 | 50 | 100 | 0 | 74
Miscellaneous
Bayati, 1998 | 63 | 50 | 0 | 50 | 75 | 0 | 48
Chu,2001 | 90 | 100 | 100 | 50 | 100 | 50 | 88

a Representativeness: The total maximum for this section was 10 points. This included setting and population described and start and end date specified (2 points); detailed description of inclusion and exclusion criteria or statement that all potential trainees enrolled (2 points); information about excluded or not-participating patients (2 points); appropriateness of the spectrum of disease included in the study sample (2 points); and description of key patient characteristics at enrollment (2 points).

b Bias and Confounding: The total maximum score was 2 points. This included whether there was an independent, blind comparison with a reference standard.

c Description of Biopsy: The total maximum score was 2 points. This included description of the technique and size of liver biopsy.

d Outcomes and Followup: The total maximum score was 8 points. This included description of complications, side effects and adverse reactions (2 points); sufficient description of criteria for determining outcomes (2 points); reporting on the numbers and reasons for withdrawals from the study or losses to followup (2 points); and proportion of patients who withdrew from the study or were lost to followup (2 points).

e Statistical Quality and Interpretation: The total maximum score was 6 points. This included whether magnitude of difference between groups and an index variability was stated (2 points); whether analyses and statistical tests were clearly identified (2 points); and appropriate handling of crossovers and/or dropouts in the analysis (2 points).

f Conflict of Interest: The total maximum score was 2 points. This included whether the study reported the source of funding and the role played by the funding entity.

g Total Score is the mean of the percentage scores from the categories, Representativeness, Bias and Confounding, Description of Biopsy, Outcomes and Followup, and Statistical Quality and Interpretation.

Evidence Table 8: Results of studies evaluating biochemical tests and serologic measures of fibrosis that may predict findings of liver biopsy )

| | | | | | | Statistical Tests of Relation to Biopsy Findings
Author, Year | Study Groups | N | Staging System: mean | Grading System: mean | Serologic Measure | Threshold Value | Correlation Coefficient^a^ | ROC | Sensitivity | Specificity
Extracellular matrix
Casaril, 2000 | A: CHC Pts | 102 | | | laminin | | Sp: 0.44*
| B: Healthy subjects w/ nl liver function tests and negative viral studies | 81 | | | P-III-P | | Sp: 0.30*
Di Costanzo, 1996 | A: Responders to IFN alpha | 22 | HAI: 2.24 | | Laminin
| B: Non-responders to IFN alpha | 46 | HAI: 2.75 | | P-III-P
Fortunato, 2001 | A: Pts w/ chronic HCV infection | 54 | | | Albumin
| | | | | ALP
| B: Pts w/ cirrhosis from HCV infection | 49 | | | ALT
| | | | | Apo A1
| | | | | Apo B
| | | | | AST
| | | | | AST/ALT ratio
| | | | | Cholesterol
| | | | | Direct Bili
| | | | | Fibronectin
| | | | | GPX
| | | | | LDII
| | | | | LDL
| | | | | MnSOD
| | | | | PCHE
| | | | | P-III-P
| | | | | Plts
| | | | | PT
| | | | | Total Bili
Fukuda, 1998 | O: Hemophilia Pts who had liver bx before IFN tx | 36 | | | HA | | n/s: 0.78*
| | | | | type IV collagen | | n/s: 0.38*
Fukuzaki, 2000 | A: Complete response: ALT twice normal range (<40 IU/l) durring tx and maintained for 24 wks and HCV RNA- at 42 wks post tx | 23 | | | HA
| | | | | IV 7s
| | | | | PIIIP
| B: Biochemical response: ALT twice normal range (<40 IU/l) durring tx and maintained for 24 wks and HCV RNA+ at 42 wks post tx | 9
| C: No response | 46
Gabrielli, 1997 | A: Pts w/ chronic HCV infection | 99 | | | Laminin | 1.8 | | | 51.7 | 80
| | | | | P-III-P | 1.0 | | | 34.4 | 20.6
| B: Healthy controls | 40
Giannini, 2001 | O: Pts w/ chronic HCV infection | 109 | Oth: 0.9 | Oth: 6.5 | P-III-P | | Sp: 0.03*
Guechot, 1994 | A: Pts in cohort of ursodiol for PBC trial | 78 | | | HA GroupA | | | | 0.51 | 0.74
| | | | | HA GroupB | | | | 0.55 | 0.92
| B: Pts in trial of alpha-interferon for viral hepatitis C treatment | 58 | | | PIII NP | | | | 0.62 | 0.77
| | | | | GroupA
| | | | | PIII NP | | | | 0.4 | 0.66
| C: healthy controls | 40 | | | GroupB
Guechot, 1996 | O: HCV+ pts | 326 | | | HA | | Pr: 0.58*
| | | | | HA | 110 | | 0.92 | 79.2 | 89.4
| | | | | HA | 85 | | 0.86 | 64.5 | 91.2
| | | | | P-III-P | | Pr: 0.34*
| | | | | P-III-P | 0.8 | | 0.69 | 70 | 63.4
| | | | | P-III-P | 1.0 | | 0.73 | 60 | 74
Ikeda, 2000 | O: 205 consecutive Pts w/ CHC | 205 | | | gamma | 10 × 10^4^ / mm^3^ | n/s: 0.57^ b^
| | | | | globulin
| | | | | gender | 10 × 10^4^ / mm^3^ | n/s: -0.21^ b^
| | | | | HA | 10 × 10^4^ / mm^3^ | n/s: 0.42^ b^
| | | | | Plts | 10 × 10^4^ / mm^3^ | n/s: -0.43^ b^ | | 81.1 | 89.8
Ishibashi, 1996 | A: Complete responders to IFN tx | 49 | HAI: 1.4 | HAI: 6.3 | HA | | Sp: 0.51*
| | | | | IV-75 | | Sp: 0.42*
| B: Relapsers after IFN tx | 36 | HAI: 1.3 | HAI: 6.4 | P-III-P | | Sp: 0.33*
| C: Non-responders to IFN tx | 36 | HAI: 2.1 | HAI: 7.7
Jeffers, 1995 | A: Pts w/ mild CAH | 34 | | | P-III-P | Abnormal | | | 70
| B: Pts w/ moderate-severe CAH | 25 | | | P-III-P | Abnormal | | | 58 | 82
| C: Pts w/ cirrhosis | 27
Kasahara, 1997 | A: IFN tx, sustained response | 26 | HAI: 2 | HAI: 6.8 | MMP-2 | | Sp: 0.26*
| B: IFN tx, transient response | 21 | HAI: 1.7 | HAI: 6.5 | TIMP-1 | | Sp: 0.30*
| C: IFN tx, no response | 51 | HAI: 2.3 | HAI: 7.4
Lichtinghagen, 1999 | A: Pts w/ CHC presenting to OP clinic | | | | MMP-1
| | | | | MMP-2
| B: Nl serum and plasma from healthy blood donors | | | | MMP-7
| C: Livers explanted, but unable to transplant
| D: Cirrhotic liver from transplant pts
Lichtinghagen, 2000 | A: Healthy controls | 20 | | | MMP-2 | | Sp: ns
| B: HCV+ Pts w/ chronic hepatitis | 40 | | | MMP-9 | | Sp: ns
| C: HCV+ Pts w/ cirrhosis | 20 | | | Ratio of MMP-2:TIMP-1 | | Sp: -0.38
| | | | | TIMP-1 | | Sp: ns
| | | | | TIMP-2 | | Sp: ns
Lichtinghagen, 2001 | A: Pts w/ CHC | 29 | | | MMP-7 | | Sp: 0.53* | 0.75
| B: Pts w/ CHC and cirrhosis | 7 | | | MMP-9 | | Sp: 0.39* | 0.67
| C: nl controls | 10 | | | TIMP-1 | | Sp: 0.46* | 0.76
| | | | | TIMP-2 | | Sp: 0.34* | 0.66
| | | | | TIMP-3 | | ns | 0.55
| | | | | TIMP-4 | | Sp: 0.52* | 0.72
Lo Iacono, 1998 | O: CHC virus Pts w/ recurring IFN tx | 52 | Sch: 1.6 | HAI: 4.4 | P-III-P | >10.57 | | 0.73 | 88.9 | 51.7
| | | | | sICAM-1 | >520 | | 0.75 | 63.6 | 55.9
| | | | | sVCAM-1 | >1280 | | 0.96 | 100 | 85.3
McHutchison, 2000a | O: Pts w/ CHC enrolled in a tx study for CHC | 486 | HAI: 1.5 | HAI: 2.4 | HA | | n/s: 0.54*
| | | | | HA | 100 | | | 76 | 82
| | | | | HA | 110 | | | 73 | 83
| | | | | HA | 60 | | | 88 | 59
| | | | | HA | 80 | | | 83 | 72
Murawaki, 1999 | A: Pts w/ minimal chronic hepatitis. | 24 | | | 7S collagen | 8.5 | | | | 85
| | | | | HA | 100 | | | | 93
| B: Pts w/ mild chronic hepatitis. | 21 | | | IV collagen | 150 | | | | 81
| C: Pts w/ moderate chronic hepatitis. | 17 | | | MMP-2 | 700ng/mL | | | | 89
| D: Pts w/ liver cirrhosis | 35
| E: Pts w/ hepatocellular carinoma. | 55
| F: control Pts w/ no liver disease. | 24
Murawaki, 2001 | O: Pts HCV + w/liver bx (fibrosis < F4) | 165 | | | Plts | 14×10^4^/mm^3^ | | | 68 | 73
| | | | | Plts | 16×10^4^/mm^3^ | | | 68 | 71
| | | | | Type IV Collagen | 110 ng/ml | | | 71 | 73
| | | | | Type IV Collagen | 130 ng/ml | | | 66 | 75
Murawaki, 2001a | O: Pts w/ chroinc HCV w/o cirrhosis. | 169 | | | ALT | 80 | | | 61 | 66
| | | | | HA | 50 | | | 75 | 80
| | | | | HA | 70 | | | 50 | 79
| | | | | IV-C7S | 6 | | | 70 | 73
| | | | | IV-C7S | 6.5 | | | 63 | 73
| | | | | MMP-2 | 550 | | | 75 | 70
| | | | | MMP-2 | 575 | | | 68 | 69
| | | | | P-III-NP | 0.8 | | | 74 | 52
| | | | | P-III-NP | 0.9 | | | 64 | 59
| | | | | TIMP-1 | 160 | | | 79 | 56
| | | | | TIMP-1 | 170 | | | 82 | 34
Ninomiya, 1998 | A: IFN tx, complete response | 16 | MHAI: 3 | MHAI: | HA after treatment | | Sp: 0.56*
| B: IFN tx, partial response | 25 | MHAI: 3.2 | MHAI: 9.5
| C: IFN tx, no response | 8 | MHAI: 3.5 | MHAI: | HA before treatment | | Sp: 0.61*
| | | | | P-III-P after treatment | | Sp: 0.51*
| | | | | P-III-P before treatment | | Sp: 0.53*
| | | | | Type IV collagen after treatment | | Sp: 0.32*
| | | | | Type IV collagen before treatment | | Sp: 0.24
Ohashi, 1998 | A: Pts who completely responded to IFN. | 27 | | | HA
| | | | | IV-C | | 0.49
| B: Pts who did not respond to IFN. | 35 | | | P-III-P | | 0.53
Plevris, 2000 | A: Pts w/ liver disease caused by HCV infection | 69 | | | HA | 100 | | | 72 | 95
| | | | | HA | 200 | | | 67 | 98
| B: Pts w/ liver disease caused by alcohol | | | | HA | 300 | | | 47 | 100
| C: Pts w/ autoimmune liver disease
| D: Pts w/ primary bilary cirrhosis
| E: Pts w/ cryptogenic liver disease
Serejo, 2001 | A: Pts who were sustained responders. | 44 | | | P-III-P
| B: Pts who were relapsers. | 35
| C: Pts who were non-responders. | 38
Ueno, 2001 | A: Complete responders w/ bx done < 2 years after tx. | 12 | | | HA | | Sp: 0.29*
| B: Non-responders w/ bx done < 2 years after tx | 24 | | | P-III-P | | Sp: 0.33*
| C: Complete responders w/ bx done more than 2 years after tx | 10 | | | type IV collagen | | Sp: 0.35*
| D: Non-responders w/ bx done more than 2 years after tx | 6
Verbaan, 1997 | O: Pts w/ CHC infection | 109 | | | IgG | | Sp: 0.43*
| | | | | P-III-P | 1.11 | Sp: 0.32* | | 78 | 56
| | | | | type-IV collagen | 250 | Sp: 0.43* | | 87 | 75
Walsh, 1999 | A: Pts w/ CHC infection | 33 | | | ALT | 155 | | 0.51 | 71 | 44
| B: Healthy controls | 5 | | | CIS P-III-P | 0.8 U/mL | | 0.76* | 50 | 85.7
| | | | | Orion P-III-P | 4.2 ng/L | | 0.67 | 85 | 37.5
Walsh, 1999a | A: CHC w/ liver bx | 43 | | | ALT | | | 0.59 | 67 | 52
| B: Healthy controls | 19 | | | MMP-2 | 860 | | 0.67 | 69 | 59
| | | | | TIMP-1 | 500 | | 0.73* | 94 | 57
| | | | | TIMP-2 | 102 | | 0.73* | 85 | 47
Walsh, 2000 | A: Pts w/ chronic HCV infection | 37 | | | ALT | | | 0.54*
| | | | | Laminin | 1.26 | | 0.82* | 80 | 85.3
| B: Healthy controls | 5 | | | type IV collagen | 148 | | 0.85* | 80 | 73.3
Wong, 1998 | O: CHC virus Pts | 130 | | | ALT | | | | 76 | 48
| | | | | AST | | | | 48 | 39
| | | | | HA | | | | 86 | 88
Yamada, 1996 | A: Pts who were complete responders to IFN tx. | 9 | Oth: 2.11 | | HA | | Sp: 0.79*
| | | | | P-III-P | | Sp: 0.45*
| B: Pts who were partial responders to IFN tx. | 14 | Oth: 1.78 | | type-IV collagen | | Sp: 0.42*
| C: Pts who were non-responders to IFN tx. | 12 | Oth: 7.08
Yamada, 1998 | O: Japanese Pts w/ CHC and hemophilia | 36 | Desm: 1.9 | | HA | | Sp: 0.78*
| | | | | type IV collagen | | Sp: 0.38*
Cytokines/cytokine receptors
Izzo, 1996 | A: Pts w/ chronic HCV infection | 123 | | | IL-2R
| B: Healthy HBV and HCV- controls | 174
Nutt, 2000 | A: HCV + consecutive Pts w/ liver bx and nl ALT on >= 2 occasions | 35 | HAI: 4 | | ALT
| B: HCV + consecutive Pts w/ liver bx and elevated ALT | 35 | HAI: 7
Zylberberg, 1999 | A: Pts w/ CHC | 60 | | | sTNF-R55
| B: Pts w/ chronic HBV | 34 | | | sTNF-R75
| C: Healthy control Pts | | | | TNF-alpha
Enzymes
Anderson, 2000 | O | 133 | | | AST/ALT ratio > 1 | | | | 31 | 95
Assy, 2000 | O: Pts w/ chronic HCV infection | 79 | Desm: 1.5 | HAI: 3.5 | ALT | | M: 0.51*
| | | | | AST | | M: 0.64*
Barbaro, 1996 | A: Pts+ for HIV and HCV infection | 55 | | | CD4 plus | | Pr: 0.02
| | | | | T-cell count
| B: HCV+ pts | 50 | | | Plasma glutathione | | Pr: 0.74*
| C: Healthy controls | 51
Choi, 1999 | O: Pts w/ CHC infection | 38 | | | ALT
| | | | | HCV RNA
Goldstein, 1999 | O: CHC Pts given AFP, ALT testing, and liver bx | 81 | | | AFP
| | | | | ALT
Gordon, 2000 | A: ALT < 1.3 × nl in pts w/ HCV | 105 | MHAI: | MHAI:
| B: ALT > 1.3 × nl in pts w/ HCV | 1639 | MHAI: | MHAI:
Haber, 1995 | O: Pts w/ serologically confirmed HCV | 90 | HAI: 3.4 | | ALT/AST
Healey, 1995 | A: HCV+ normal AST | 19 | | | AST
| B: HCV+ abnormal AST | 23
Imbert-Bismut, 2001 | A: CHS Pts tested in first year period | 205 | | | 10 markers in logistic regression, group A | | | 0.86
| B: CHS Pts tested in second year, as confirmatory group | 134
| | | | | 10 markers in logistic regression, group B | | | 0.89
| | | | | 6 markers in logistic regression, group A | | | 0.82
| | | | | 6 markers in logistic regression, group B | | | 0.85
Imperiale, 2000 | O: A cohort of Pts w/ HCV. | 177 | | | AST/ALT | >1 | | | 56 | 90
Jamal, 1999 | A: HCV Pts w/ nl ALT levels. | 75 | MHAI: 1.4 | | ALT
| B: HCV Pts w/ abnl ALT levels. | 200 | MHAI:
Kobayashi, 2000 | O: consecutive Pts treated w/ alpha-IFN for 6 mos w/ f/u of 5 years | 61 | | | ALT
Luo, 1998 | O: 93 Pts w/ CHC. | 93 | Oth: 0.5 | Oth: 7.7 | ALT
| | | | | HCV RNA
McCormick, 1996 | O: Pts w/ CHC who were either treated or untreated and were biopsied. | 44 | | | ALT | | Sp: 0.49*
| | | | | HCV titer | | Sp: 0.35
Michielsen, 1997 | O: CHC Pts | 51 | | | ALT | | Sp: 0.08
| | | | | AST | | Sp: 0.29*
Ono, 1999 | O: Pts w/ chronic HCV infection | 435 | | | ALB | < 4 vs. > 4
| | | | | Alkaline | 1IV
| | | | | phosphatase
| | | | | ALT
| | | | | AST
| | | | | GTP
| | | | | LDH | 1IV
| | | | | Plts | 104
| | | | | PT | 1%
| | | | | total Bili
| | | | | WBC
Park, 2000 | O: Pts w/ CHC | 153 | | | AST/ALT | 1 | | | 46.7 | 95.9
Poynard, 1997 | O: Pts w/ chronic HCV infection | 500 | | | Age
| | | | | AST
| | | | | Bili
| | | | | Body weight
| | | | | Creatinine
| | | | | GGT
| | | | | IDU
| | | | | Index: age, Plts | | | 0.79
| | | | | Plts
| | | | | PT
Sheth, 1998 | A: Ratio of AST to ALT >= 1 in Pts w/ CHC | | | | AST/ALT | > 1 | | | | 100
| B: Ratio of AST to ALT >= 1 in Pts w/ CHC
Shima, 2000 | O: Pts w/ chronic HCV Infections w/sustained response to IFN tx | 36 | HAI: 2 | HAI: 8 | Cholinesterase
| | | | | Plts
| | | | | Total bile acid
| | | | | Zinc sulphate turbidity test
Stanley, 1996 | A: Pts w/ chronic HCV infection and nl ALT | 15 | | | ALT | > normal | Sp: ns
| B: Pts w/ chronic HCV infection and elevated ALT | 85
Tsushima 1999 | A: Pts receiving IFN tx. | 43 | Oth: 1 | | ALT/AST
| B: Pts not receiving IFN tx. | 10 | Oth: 2
Yeo,2001 | O: Pts w/chronic HCV infection | 60 | | | ALT | > 100
| | | | | HCV-RNA
| | | | | Viral genotype
Viral markers
Adinolfi, 1998 | O: HCV+Pts undergoing liver bx and HCV-RNA levels | 36 | | | HCV RNA
Iijima, 2000 | O: CHC Pts w/chronic persistent hepatitis | 135 | | | HCV core protein
Kao,1996 | A: Pts w/chronic persistent hepatitis | 34 | | | HCV titer
| B: Pts w/CAH and /or liver cirrhosis | 30
| C: Pts w/ HCC | 30
Papatheodoridis, 1997 | O: Pts w/chronic HCV | 112 | | | IgM anti HCV core
Puoti, 1999 | O: Anti-HCV+Pts w/persistently nl ALT | 59 | HAI: 0.8 | HAI:4 | HCV RNA | | Sp: 0.43*
Miscellaneous
Bayati, 1998 | A: Pts w/ a nl AFP level of <10. | 125 | | | AFP | 17.8 | | | | 98.6
| B: Pts w/ a high AFP level of >=10. | 75
Chu, 2001 | A: Chronic HCV Pts w/ elevated AFP | 33 | | | AFP
| B: Chronic HCV Pts w/ nl AFP | 82

a Correlation coefficient: Pr = Pearson's r, Sp = Spearman's p, M = Multivariate, n/s = not specified

b p-value not reported for correlation coefficient

ns = no correlation coefficient given, but it was mentioned that the value was nonsignificant (p>0.05)

* Correlation coefficient is statistically significant (p<0.05)

Evidence Table 9. Overall summary of randomized controlled trials of current treatment options for chronic hepatitis C

Author, Year | Location | N | Inclusion Criteria | Exclusion Criteria | Study Aims
Studies of current treatment options in naïve patients
Pegylated interferon/ribavirin combination therapy
Glue, 2000 | France | 72 | ALT: 1 abnl result w/i past 6 mos, detectable HCV in serum, “adult” age, initial liver bx, nl Bili, nl Alb, nl Cr, nl fasting blood sugar, nl TSH, nl AFP, nl hematologic parameters, nl PT, antibody titers <1:160 | IFN + RBV, HBV+, decompensated liver disease, depression, other psychiatric illness, RBV monotherapy, liver disease of other etiology, IFN monotherapy, any clinical trial or investigational drug w/i 30 ds prior, HIV+ | To assess the safety, pharmacokinetics, and efficacy of peg-IFN alpha-2b plus RBV in pts w/ CHC
Manns, 2001 | United States Canada Europe Argentina | 1530 | ALT >34 for women and >43 for men, detectable HCV in serum, nl Cr, initial liver bx w/CHC in past year, tx naïve, WBC >13, neutrophil >1.5, Hgb 12 for women and 13 for men, plts >100,000, nl Bili, nl Alb | HIV+, immune suppression, depression, other psychiatric illness, decompensated liver disease, comorbidities: cardiovascular, neurologic or hematologic, no contraception, AFP >50 mg/L, DM | To assess the safety and efficacy of two different regimens of Peg IFN and RBV compared w/ IFN alpha 2b and RBV and identify predictors and response for peg IFN alpha 2b.
Pegylated interferon monotherapy
Heathcote, 2000 | United States Canada | 271 | ALT, initial liver bx | AFP >100 ng/y, plts <75,000, WBC <500, IFN monotherapy, presence of any other liver disease, comorbidities: malignancy, GI, neurologic, or cardiovascular, HIV+, depression, psychiatric illness, decompensated liver disease | To compare the efficacy and safety of two doses of peg-IFN alpha-2a, given once wkly, w/ the safety and efficacy of a standard regimen of unmodified IFN alpha-2a in pts w/ HCV and cirrhosis or fibrosis.
Lindsay, 2001 | United States Europe Australia | 1299 | U/S: no mass lesion, detectable HCV in serum, initial liver bx w/i 1 y of enrollment, AFP w/i nl limits, ALT el >= 1 time w/i 6 mo of enrollment, WBC >4, neutrophil>1.8, Hgb >12 in females and >13 in males, plts > 130,000/mm^3 | Hemophilia, breast feeding, illicit drug use, HBV+, HCC, pregnancy, HIV+, active IDU, hemochromatosis, alpha-1-antitrypsin deficiency, Wilson's disease, EtOH, NASH, any antiviral therapy, hemoglobinopathy, other medical conditions that could interfere with participation, any prior tx, autoimmune hepatitis | To evaluate the efficacy of pegIFN alpha 2b compared w/ IFN alpha 2b in tx-naïve pts w/ CHC
Reddy, 2001 | United States | 158 | HCV+, detectable HCV in serum, initial liver bx w/i prior 12 mo | Neurologic comorbidity: seizure disorder, IDU, other illicit drug use, presence of bridging fibrosis, presence of cirrhosis, non-response to previous therapy, pregnancy, depression, other psychiatric illness, EtOH in the past 12 mo, any antiviral therapy, cardiovascular comorbidity, other comorbidities: retinopathy, unstable thyroid dysfunction, renal or liver disease from any other cause, WBC <1500, plts 70,000, Cr 1.5x U/L of nl range, any treatment for HCV | To evaluate safety and efficacy of four doses of once-wkly peg-(40 kD) IFN alpha-2a administered for 48 wks, compared w/ 3 mu of IFN alpha-2a tiw. The study intends to establish the most appropriate dose of Peg (40 kD) IFN alpha-2a for larger trials.
Zeuzem, 2000a | Canada Europe Australia | 531 | HCV+, detectable HCV in serum: RNA >2000 copies per mL, el ALT on >=2 occasions in previous 6 mo, initial liver bx w/ hepatitis, liver bx findings consistent with CHC, adults | Malignancy, decompensated liver disease, HBV+, immune suppression, depression, other psychiatric illness, HIV+, hepatitis A infection, other comorbidities: seizure, neurologic OR cardiovascular, AFP >25 ng/mL, chronic pulmonary disease, autoimmune disorder, unwillingness to practice contraception, severe retinopathy, IFN monotherapy, neutrophil <1500, plts <90,000, Cr 1.5x UL of nl | To compare the efficacy and safety of peg-IFN alpha-2a administered once per wk w/ the efficacy and safety of IFN alpha-2a tiw for 48 wks.
Interferon/ribavirin combination therapy
Berg, 2000 | Germany | 185 | El ALT, any previous treatment, HCV+, detectable HCV in serum | Psychiatric illness, acute or chronic IDU, HBV+, decompensated liver disease, acute or chronic EtOH, immune suppression, plts <100 nl, depression, HIV+, severe concurrent diseases, Hgb <11 g/dL, pregnancy | To examine if 12 wk combination therapy is more effective in improving initial and SVR compared w/ IFN monotherapy in untreated pts. pts who achieved a virologic response were treated w/ IFN alpha monotherapy for an additional 40 wks and then SVR was evaluated 24 wks after end of tx
el-Zayadi, 1999 | Egypt | 52 | Hgb >12, ALT el for 6 mo, U/S w/absence of focal hepatic lesion, initial liver bx, HCV+, HCV genotype 4 | Contraindication to IFN, decompensated liver disease, HCV genotype 1, 2, or 3 | To asses the efficacy of IFN alpha 2b alone and w/ RBV as initial therapy in male Egyptian pts w/ CHC, genotype 4.
Ferenci, 2001 | Austria | | Hgb >12 for males and >13 for females, WBC >3000, ALT 1.5x nl for >=6 mos, initial liver bx w/i 1 yr prior, detectable HCV in serum, plts >100,000, age 19-65 yrs | HIV+, EtOH, IDU, sexually active women refusing contraception, HBV+, decompensated liver disease, pregnancy or breast feeding, depression, other psychiatric illness, cardiovascular comorbidity: CHD, DM, autoimmune disorders, any unstable medical condition | To test two different schedules of high-dose induction therapy w/ IFN in combination w/ RBV, compared w/ a standard IFN/RBV combination therapy
Mangia, 2001 | Italy | 192 | Detectable HCV in serum, ALT available for 6 mo, initial liver bx | DM, HBV+, decompensated liver disease: ascites, bleeding varices, and encephalopathy, pregnancy, depression, EtOH, HIV+, plts <100,000, autoimmune disorder, significant medical illness, IFN monotherapy, WBC <3500, Hgb <12 for females and <13 for males, other psychiatric illness | To compare the efficacy of a high dose regimen of IFN alpha2B (5 mu tiw) for 12 mos alone or in combination w/ RBV for the tx of naïve pts w/ CHC. Secondary aims were to evaluate the effects of baseline features on the response to therapy and to determine a reliable point in time during tx to predict non response.
Studies of interferon/amantadine combination therapy, with or without ribavirin
Caronia, 2001 | United Kingdom | 179 | Age: 18-70, HCV+, detectable HCV in serum, no previous tx, CHC on initial liver bx, ALT 1.3x UL of nl w/i last 6 mos | EtOH >28 units/wk, active IDU, HBV+, liver disease of any other etiology, High ceruplasmin, serum autoantibody titer >1:40 | To assess the efficacy of combination therapy w/ IFN alpha and amantadine compared to IFN monotherapy in previously untreated pts w/ CHC
Helbling, 2002 | Switzerland | 246 | Tx naïve, HCV proven by bx w/i prior 2 yrs, detectable HCV in serum, Cr <1.5x UL of nl, age 18-65 yrs | Decompensated liver disease, HIV+, depression, other psychiatric illness, pregnancy, refusal to use contraception, presence of fibrosis: 28 Child-Pugh points, HBV+, illicit drug use w/i 1 yr of study, EtOH >20 g/d for females and >40 g/d for males, immune suppression, psychosocial instability, lactation, comorbidity: cardiovascular, neurologic, hematologic, pulmonary, renal, metabolic, rheumatologic, or malignancy, U/S: focal lesion w/i 1 mo of tx, WBC <2000, plts >50,000, TSH el, AFP above nl, IFN | To clarify in a large, double-blind randomized placebo-controlled trial the efficacy, safety and cost-effectiveness of amantadine and IFN alpha for tx of naïve pts w/ CHC
Mangia, 2001a | Italy | 200 | Detectable HCV in serum, initial liver bx, el ALT for 6 mos | EtOH, current IDU, depresson, other psychiatric illness, HBV+, decompensated liver disease, plts < 100,000, HIV+, DM, significant medical illness, WBC <3,500, immune suppression | To assess the efficacy and safety of IFN+amantadine compared to IFN monotherapy in naïve pts w/ CHC
Tabone, 2001 | Italy | 180 | Detectable HCV in serum, HCV+, CHC w/o cirrhosis on initial liver bx, ALT 1.5x UL of nl in 3 lab draws | Chronic EtOH, active IDU, other illicit drug use, depression, other psyciatric illness, HBV+, HIV+, pregnancy, neurologic comorbidity, hematologic comorbidity, cardiovascular comorbidity, autoimmune disease, metabolic disease, renal disease, WBC < 2,500, plts <100,00 | To assess the efficacy and tolerability of IFN + amantadine in the tx of CHC
Zeuzem, 2000 | Germany | 120 | HCV+, age >18 and <70 y, presence of fibrosis:CHC on liver bx, initial liver bx w/i 1 y, el ALT for >=6 mo before tx, WBC >2500, plts >70,000 | EtOH > 50 g/d of ethanol, IDU w/i previous year, GI comorbidity, immune suppression: organ transplant or autoimmune disorder, psychiatric illness, HIV+, HBV+, cardiovascular comorbidity, pregnancy, neurologic comorbidity, malignancy comorbidity, anaphylactic allergy to IFN, other comorbidities: liver disease from another cause OR renal disease OR rheumatologic disease, other viral infections: systemic bacterial or fungal infection, lactation, IFN + RBV, IFN monotherapy, amantadine, hematologic comorbidity | To compare the efiicacy, safety, and health realted quality of life of IFN alpha alone or in combination w/ amantadine for tx of CHC.

Evidence Table 10. Characteristics of patients in randomized controlled trials of current treatment options for chronic hepatitis C

Author, Year | Study Design | Study Groups | N | Mean age % Male Race | % w/ Cirrhosis | Scoring System | Mean Activity (A) Fibrosis (S) | % w/ Score Activity (A) Fibrosis (S) | Mean ALT (U/L) Mean yrs w/HCV HCV genotype (%)
Studies of current treatment options in naive patients
Pegylated interferon/ribavirin combination therapy
Glue, 2000 | RCT
| | IFN: peg-IFN2b, .35 ug/kg, qw, 24 wks | 12
| | RBV: 600–800 mg qd, 24 wks
| | IFN: peg-IFN2b, .7 ug/kg, qw, 24 wks | 18
| | RBV: 600–1200 mg qd, 24 wks
| | IFN: peg-IFN2b, 1.4 ug/kg, qw, 24 wks | 18
| | RBV: 600–1200 mg qd, 24 wks
| | IFN: peg-IFN2b, .35 ug/kg, qw, 24 wks | 6
| | IFN: peg-IFN2b, .7 ug/kg, qw, 24 wks | 9
| | IFN: peg-IFN2b, 1.4 ug/kg, qw, 24 wks | 9
Manns, 2001 | RCT
| | IFN: peg-IFN2b, 1.5 mg/kg, qw, 48 wks | 511 | 43 | | | | S3 29
| | | | 62.8 | | Kno | 7.9
| | RBV: 800 mg qd, 48 wks | | | | | | | 1 | 68.10
| | | | | | | | | 2, 3 | 28.96
| | | | | | | | | 4,5,6 | 3.13
| | IFN (initial): peg-IFN2b, 1.5 mg/kg, qw, 4 wks | 514 | 44 | | | | S3 30
| | | | 66.1 | | Kno | 7.9
| | IFN (maintenance): peg-IFN2b, 0.5 mg/kg, qw, 44 wks | | | | | | | 1 | 67.90
| | | | | | | | | 2, 3 | 29.96
| | RBV: 1000–1200 mg qd, 48 wks | | | | | | | 4,5,6 | 2.33
| | IFN: alpha-2b, 3 mu tiw, 48 wks | 505 | 43 | | | | S3 28
| | RBV: 1000–1200 mg qd, 48 wks | | 66.5 | | Kno | 7.8
| | | | | | | | | 1 | 67.92
| | | | | | | | | 2, 3 | 28.91
| | | | | | | | | 4,5,6 | 3.17
Pegylated interferon monotherapy
Heathcote, 2000 | RCT
| | IFN: alpha-2a, 3 mu tiw, 48 wks | 88 | 46.9 | 76 | HAI | 12.8 | | 104.1
| | | | 70.5
| | | | C: 87.5, | | | | | 1a | 31.82
| | | | B: 5.68, | | | | | 1b | 21.59
| | | | A: 3.40, | | | | | 2 | 13.64
| | | | O: 3.40 | | | | | 3 | 30.68
| | | | | | | | | 4 | 0.00
| | | | | | | | | not specified | 2.27
| | IFN: peg-IFN2a, 90 mg, qw, 48 wks | 96 | 47.2 | 79 | HAI | 12.7 | | 104.1
| | | | 74.0
| | | | C: 90.6, | | | | | 1a | 28.13
| | | | B: 1.04, | | | | | 1b | 32.29
| | | | A: 2.08, | | | | | 2 | 7.29
| | | | O: 6.25 | | | | | 3 | 27.08
| | | | | | | | | 4 | 2.08
| | | | | | | | | not specified | 3.13
| | IFN: peg-IFN2a, 180 mg, qw, 48 wks | 87 | 47.1 | 79 | HAI | 13.4 | | 123.3
| | | | 72.4
| | | | C: 86.2, | | | | | 1a | 37.93
| | | | B: 5.74, | | | | | 1b | 17.24
| | | | A: 2.29, | | | | | 2 | 16.09
| | | | O: 5.74 | | | | | 3 | 22.99
| | | | | | | | | 4 | 1.15
| | | | | | | | | not specified | 4.60
Lindsay, 2001 | RCT
| | IFN: peg-IFN2b, 0.5 ng/kg, qw, 48 wks | 315 | 43.1 | 3 | HAI | A 6.8
| | | | 58.7 | | HAI | S 1.4 | | 18.5
| | | | C: 90.1 | | | | | 1 | 67.30
| | | | | | | | | 2 | 11.11
| | | | | | | | | 3 | 16.83
| | | | | | | | | other | 4.76
| | IFN: peg-IFN2b, 1.0 ng/kg, qw, 48 wks | 297 | 43.7 | 3 | HAI | A 6.9
| | | | 63.3 | | HAI | S 1.4 | | 20.4
| | | | C: 90.9 | | | | | 1 | 67.00
| | | | | | | | | 2 | 10.10
| | | | | | | | | 3 | 17.85
| | | | | | | | | other | 5.05
| | IFN: peg-IFN2b, 1.5 ng/kg, qw, 48 wks | 304 | 42.9 | 4 | HAI | A 6.7
| | | | 62.5 | | HAI | S 1.3 | | 19.2
| | | | C: 94.0 | | | | | 1 | 73.36
| | | | | | | | | 2 | 10.53
| | | | | | | | | 3 | 13.49
| | | | | | | | | other | 2.63
| | IFN: alpha-2b, 3 mu tiw, 48 wks | 303 | 42.6 | 4 | HAI | A 7.1
| | | | 68.3 | | HAI | S 1.4 | | 18.6
| | | | C: 89.1 | | | | | 1 | 71.62
| | | | | | | | | 2 | 9.24
| | | | | | | | | 3 | 17.49
| | | | | | | | | other | 1.65
Reddy, 2001 | RCT
| | IFN: alpha-2a, 3 mu tiw, 48 wks | 33 | 41.8 | | HAI | 10.8
| | | | 78.8
| | | | C: 78.7, | | | | | 1 | 81.82
| | | | B; 12.1, | | | | | non-1 | 15.15
| | | | A: 3.03, | | | | | unknown | 3.03
| | | | O: 6.06
| | IFN: peg-IFN2a, 45 μgx3a;g, qw, 48 wks | 20 | 41.9 | | HAI | 11.7
| | | | 65.0
| | | | C: 90, | | | | | 1 | 75.00
| | | | B: 10, A: 0, | | | | | non-1 | 25.00
| | | | O: 0 | | | | | unknown | 0.00
| | IFN: peg-IFN2a, 90 μg, qw, 48 wks | 20 | 43.1 | | HAI | 10.6
| | | | 70.0
| | | | C: 95, B: 0, | | | | | 1 | 70.00
| | | | A: 5, O: 0 | | | | | non-1 | 30.00
| | | | | | | | | unknown | 0.00
| | IFN: peg-IFN2a, 180 μg, qw, 48 wks | 45 | 42 | | HAI | 10.7
| | | | 82.2
| | | | C: 88.8, | | | | | 1 | 77.78
| | | | B: 8.88, A: 0, | | | | | non-1 | 22.22
| | | | O: 2.22 | | | | | unknown | 0.00
| | IFN: peg-IFN2a, 270 μg, qw, 48 wks | 41 | 41.6 | | HAI | 10
| | | | 85.4
| | | | C: 87.8, | | | | | 1 | 63.41
| | | | B: 9.75, A: 0, | | | | | non-1 | 29.27
| | | | O: 2.43 | | | | | unknown | 7.32
Zeuzem, 2000a | RCT
| | IFN (initial): peg-IFN2a, 180 μg, qw, 48 wks | 267 | 40.5 | | HAI | 8.6 | A1 65.0
| | | | 66.7 | | | | A2 30.0
| | | | C: 86.1, | | | | A3 3.3 | 1a | 29.96
| | | | B: 2.24, | | | | | 1b | 32.96
| | | | A: 8.98, | | | | S1 88.4 | 1b | 32.96
| | | | O: 2.62 | | | | S3 7.1 | 2 | 9.36
| | | | | | | | | 3 | 25.47
| | | | | | | | | 4 | 1.87
| | | | | | | | | not specified | 0.37
| | IFN (initial): alpha-2a, 6 mu tiw, 12 wks | 264 | 41 | | HAI | 3.4 | A1 60.0
| | | | 66.7 | | | | A2 40.0
| | IFN (maintenance): alpha-2a, 3 mu, tiw, 36 wks | | C: 84.8, | | | | A3 0.0 | 1a | 31.44
| | | | B; 1.89, | | | | S1 84.8 | 1b | 29.55
| | | | A: 9.84, | | | | S1 84.8 | 1b | 29.55
| | | | O: 3.40 | | | | S3 4.9 | 2 | 12.88
| | | | | | | | | 3 | 23.86
| | | | | | | | | 4 | 1.14
| | | | | | | | | not specified | 1.14
Interferon/ribavirin combination therapy
Berg, 2000 | RCT
| | IFN: alpha-2a, 6 mu tiw, 12 wks | 93 | 42 | | HAI | S 1.5 | | 70
| | RBV: 7 mg/kg, bid, 12 wks | | 57.0 | | | | | 15.2
| | | | | | | | | 1a | 24.73
| | | | | | | | | 1a/b | 1.08
| | | | | | | | | 1b | 47.31
| | | | | | | | | 2a | 2.15
| | | | | | | | | 2a/c | 1.08
| | | | | | | | | 2b | 3.23
| | | | | | | | | 3a | 18.28
| | | | | | | | | 4 | 2.15
| | IFN: alpha-2a, 6 mu tiw, 12 wks | 92 | 42 | | HAI | S 1.5 | | 82
| | | | 55.4 | | | | | 14.7
| | | | | | | | | 1a | 20.65
| | | | | | | | | 1a/b | 1.09
| | | | | | | | | 1b | 54.35
| | | | | | | | | 2a | 2.17
| | | | | | | | | 2a/c | 1.09
| | | | | | | | | 2b | 1.09
| | | | | | | | | 3a | 17.39
| | | | | | | | | 4 | 2.17
el-Zayadi, 1999
| | IFN: alpha-2b, 3 mu tiw, 24 wks | 26 | 42 | | HAI | S 5.0 | | 116
| | RBV: 1000 mg qd, 24 wks | | 100.0 | | HAI | T 9.4
| | IFN: alpha-2b, 3 mu tiw, 24 wks | 26 | 39 | | HAI | S 5.0 | | 123
| | | | 100.0 | | HAI | T 9.7
Ferenci, 2001 | RCT
| | IFN (initial 1): alpha-2b, 10 mu, qd, 2 wks | 130 | 39.4 | | | | | 68
| | | | 73.8
| | IFN (initial 2): alpha-2b, 10 mu, qed, 12 wks | | | | | | | 1a | 22.31
| | | | | | | | | 1b | 50.77
| | IFN (maintenance): alpha-2b, 5 mu, qed, 24 wks | | | | | | | 2 | 1.54
| | | | | | | | | 3a | 23.85
| | RBV: 1000–1200 mg qd, 38 wks | | | | | | | 4 | 1.54
| | IFN (initial): alpha-2b, 5 mu, qd, 14 wks | 124 | 42.8 | | | | | 66
| | | | 70.2
| | IFN (maintenance): alpha-2b, 5 mu, qed, 24 wks | | | | | | | 1a | 14.52
| | | | | | | | | 1b | 53.23
| | RBV: 1000–1200 mg qd, 38 wks | | | | | | | 2 | 3.23
| | | | | | | | | 3a | 23.39
| | | | | | | | | 4 | 5.65
| | IFN: alpha-2b, 5 mu, qed, 38 wks | 119 | 39.9 | | | | | 79
| | RBV: 1000–1200 mg qd, 38 wks | | 66.4
| | | | | | | | | 1a | 18.49
| | | | | | | | | 1b | 43.70
| | | | | | | | | 2 | 4.20
| | | | | | | | | 3a | 26.89
| | | | | | | | | 4 | 6.72
Mangia, 2001 | RCT
| | IFN: alpha-2b, 5 mu tiw, 12 mos | 96 | 49 | | Sch | | A>1 19.8
| | | | 71.9 | | Sch | | A0,1 80.2 | 8
| | | | | | Sch | | S1,2 93.8 | 1b | 53.13
| | | | | | Sch | | S3 6.2 | 2a | 33.33
| | | | | | | | | 3 | 9.38
| | | | | | | | | other | 4.17
| | IFN: alpha-2b, 5 mu tiw, 12 mos | 96 | 46 | | Sch | | A>1 26.0
| | RBV: 1000-1200 mg qd, 12 mos | | 61.5 | | Sch | | A0,1 74.0 | 7
| | | | | | Sch | | S1,2 89.6 | 1b | 41.67
| | | | | | Sch | | S3 10.4 | 2a | 35.42
| | | | | | | | | 3 | 17.71
| | | | | | | | | other | 5.21
Studies of interferon/amantadine combination therapy, with or without ribavirin
Caronia, 2001 | RCT
| | IFN (Pilot study): alpha-2a, 4.5 mu, tiw, 48 wks | 18 | 42 | 0 | | | | 1 | 55.56
| | Amantadine (Pilot study): 200 mg, qd, 48 wks | 18 | 40 | | 0 | | | 1 | 50.00
| | IFN (Pilot study): alpha-2a, 4.5 mu, tiw, 48 wks
| | IFN (Multicenter): alpha-2a, 4.5 mu, tiw, 48 wks | 71 | 42 | 10 | | | | 1 | 28.17
| | Amantadine (Multicenter): 200 mg, qd, 48 wks | 72 | 43 | 8 | | | | 1 | 26.39
| | IFN (Multicenter): alpha-2a, 4.5 mu, tiw, 48 wks
| | IFN (Combined): alpha-2a, 4.5 mu tiw, 48 wks | 89 | 42 | | | | | 1 | 33.71
| | Amantadine (Combined): 200 mg, qd, 48 wks | 90 | 41 | 7 | | | | 1 | 31.11
| | IFN (Combined): alpha-2a, 4.5 mu tiw, 48 wks
Helbling, 2002 | RCT
| | Amantadine: 100 mg, bid, 52 wks | 125 | 39 | | | | A1 47.2 | 101
| | IFN (initial): alpha-2a, 6 mu tiw, 20 wks | | 65.6 | | | | A2 34.4
| | | | | | | | A3 14.4 | 1 | 52.80
| | IFN (maintenance): alpha-2a, 3 mu, tiw, 32 wks | | | | | | S1-S2 26.4 | 2 | 9.60
| | | | | | | | S3 64.8 | 3 | 27.20
| | | | | | | | S4 4.8 | 4 | 4.00
| | | | | | | | | 6 | 0.80
| | Amantadine (initial): Placebo | 121 | 38 | | | | A1 52.1 | 111
| | IFN (initial): alpha-2a, 6 mu tiw, 20 wks | | 72.7 | | | | A2 40.5
| | | | | | | | A3 9.9 | 1 | 42.98
| | IFN (maintenance): alpha-2a, 3 mu, tiw, 32 wks | | | | | | S1-S2 24.0 | 2 | 9.09
| | | | | | | | S3 75.2 | 3 | 41.32
| | | | | | | | S4 3.3 | 4 | 4.96
Mangia, 2001a | RCT
| | IFN (initial): alpha-2a, 6 mu tiw, 12 mos | 101 | 48 | | HAI | | S0–3 48.5
| | | | 70.3 | | HAI | | S1–3 51.5 | 7.1
| | | | | | | | | 1 | 59.41
| | | | | | | | | 2a | 25.74
| | | | | | | | | 3 | 10.89
| | | | | | | | | 4 | 3.96
| | Amantadine (initial): 100 mg, bid, 12 mos | 99 | 46 | | HAI | | S0–3 36.4
| | | | 61.6 | | HAI | | S1–3 63.6 | 7.1
| | IFN (initial): alpha-2a, 6 mu tiw, 12 mos | | | | | | | 1 | 52.53
| | | | | | | | | 2a | 34.34
| | | | | | | | | 3 | 7.07
| | | | | | | | | 4 | 6.06
Tabone, 2001 | RCT
| | IFN (initial): alpha-2a, 6 mu, qed, 6 mos | 90 | 44 | | | | | 114
| | | | 66.7
| | IFN (maintenance): alpha-2a, 3 mu, qed, 6 mos | | | | | | | 1/4 | 58.89
| | | | | | | | | 2/3 | 41.11
| | Amantadine: 100 mg, bid, 12 mos | 90 | 42 | | | | | 103
| | IFN (initial): alpha-2a, 6 mu, qed, 6 mos | | 62.2 | | | | | 1/4 | 52.22
| | IFN (maintenance): alpha-2a, 3 mu, qed, 6 mos | | | | | | | 2/3 | 47.78
Zeuzem, 2000 | RCT
| | Amantadine: 100 mg, Twice a day, 48 wks | 60 | 42.1
| | | | 61.7
| | IFN (initial): alpha-2a, 6 mu tiw, 24 wks | | | | | | | 1 | 70.00
| | IFN (maintenance): alpha-2a, 3 mu, tiw, 24 wks | | | | | | | 2 | 5.00
| | | | | | | | | 3 | 21.67
| | | | | | | | | 4 | 1.67
| | IFN (initial): alpha-2a, 6 mu tiw, 24 wks | 60 | 41.6
| | | | 60.0
| | IFN (maintenance): alpha-2a, 3 mu, tiw, 24 wks | | | | | | | 1 | 66.67
| | | | | | | | | 2 | 5.00
| | | | | | | | | 3 | 25.00
| | | | | | | | | 4 | 1.67

Evidence Table 11. Methodologic quality of randomized controlled trials of current treatment options for chronic hepatitis C

Author, Year | Representativeness^a^ | Bias^b^ | Description^c^ | Outcomes^d^ | Statistics^e^ | Conflict^f^ | Total^g^
Pegylated interferon/ribavirin combination therapy
Glue, 2000 | 63 | 33 | 100 | 85 | 0 | 0 | 56
Manns, 2001 | 100 | 83 | 75 | 80 | 88 | 50 | 85
Pegylated interferon monotherapy
Heathcote, 2000 | 100 | 67 | 50 | 70 | 83 | 50 | 74
Lindsay, 2001 | 88 | 83 | 100 | 85 | 100 | 50 | 91
Reddy, 2001 | 63 | 75 | 50 | 70 | 83 | 50 | 68
Zeuzem, 2000a | 100 | 50 | 75 | 70 | 100 | 100 | 79
Interferon/ribavirin combination therapy
Berg, 2000 | 88 | 67 | 75 | 85 | 83 | 0 | 80
el-Zayadi, 1999 | 38 | 50 | 50 | 85 | 33 | 0 | 51
Ferenci, 2001 | 88 | 33 | 50 | 70 | 75 | 0 | 63
Mangia, 2001 | 75 | 83 | 50 | 60 | 100 | 0 | 74
Studies of interferon/amantadine combination therapy, with or without ribavirin
Caronia, 2001 | 88 | 67 | 50 | 85 | 17 | 50 | 61
Helbling, 2002 | 100 | 100 | 75 | 75 | 100 | 50 | 90
Mangia, 2001a | 88 | 67 | 75 | 85 | 100 | 50 | 83
Tabone, 2001 | 88 | 67 | 75 | 85 | 83 | 100 | 80
Zeuzem, 2000 | 100 | 100 | 100 | 60 | 100 | 50 | 92

a Representativeness: The total maximum for this section was 8 points. This included setting and population described and start and end date specified (2 points); detailed description of inclusion and exclusion criteria or statement that all potential trainees enrolled (2 points); information about excluded or not-participating patients (2 points); and description of key patient characteristics at enrollment (2 points).

b Bias and Confounding: The total maximum score was 6 points. This included whether assignment of patients to study groups was randomized (2 points); whether groups had any differences in key patient characteristics (2 points); and whether clinicians, patients, and outcome assessors were blinded (2 points).

c Description of Therapy/Management: The total maximum score was 4 points. This included sufficiently detailed description of the treatment regimen (2 points); and description of other treatments or tests given to subjects (2 points).

d Outcomes and Followup: The total maximum score was 10 points. This included description of complications, side effects and adverse reactions (2 points); sufficient description of criteria for determining outcomes (2 points); reporting on the numbers and reasons for withdrawals from the study or losses to followup (2 points); proportion of patients who withdrew from the study or were lost to followup (2 points); and sufficiency of the planned length of followup (2 points).

e Statistical Quality and Interpretation: The total maximum score was 8 points. This included whether magnitude of difference between groups and an index variability was stated (2 points); whether analyses and statistical tests were clearly identified (2 points); whether adjustment of potential confounders were multi-variate or stratified analyses and coding of confounders (2 points); and appropriate handling of crossovers and/or dropouts in the analysis (2 points).

f Conflict of Interest: The total maximum score was 2 points. This included whether the study reported the source of funding and the role played by the funding entity.

g Total Score is the mean of the percentage scores from the categories, Representativeness, Bias and Confounding, Description of Therapy/Management, Outcomes and Followup, and Statistical Quality and Interpretation.

Evidence Table 12. Results of randomized controlled trials of current treatment options for chronic hepatitis C

| | | Biochemical Response | | Vital Response | | Histological Response | Adverse Events
| | | ETR | SR | ETR | ER | | Disc/Withdr | Dose Red
Author, Year Follow-up | Study Groups | | % | % | % | % | % | % | %
Studies of current treatment options in naïve patients
Pegylated interferon/ribavirin combination therapy
Glue, 2000 | A | IFN: peg-IFN2b, 0.35 ug/kg, qiw, 24 wks | | | 58^a^ | 17^a^
6 mos. | | RBV: 600–800 mg qd, 24 wks
| B | IFN: peg-IFN2b, 0.7 ug/kg, qiw, 24 wks | | | 69^a^ | 53^a^
| | RBV: 600–1200 mg qd, 24 wks
| C | IFN: peg-IFN2b, 1.4 ug/kg, qiw, 24 wks | | | 81^a^ | 60^a^
| | RBV: 600–1200 mg qd, 24 wks
| D | IFN: peg-IFN2b, 0.35 ug/kg, qiw, 24 wks | | | 50^a^ | 0^a^
| E | IFN: peg-IFN2b, 0.7 ug/kg, qiw, 24 wks | | | 63^a^ | 44^a^
| F | IFN: peg-IFN2b, 1.4 ug/kg, qiw, 24 wks | | | 50^a^ | 42^a^
Manns, 2001 | A | IFN: peg-IFN2b, 1.5 mg/kg, qiw, 48 wks | 65 | 54 | 65* | 54* | 14 | 2.7 | 8.3
6 mos. | | RBV: 800 mg qd, 48 wks
| B | IFN (initial): peg-IFN2b, 1.5 mg/kg, qiw, 4 wks | 63 | 48 | 56 | 47 | 13 | 2.5 | 7.0
| | IFN (maintenance): peg-IFN2b, 0.5 mg/kg, qiw, 44 wks
| | RBV: 1000–1200 mg qd, 48 wks
| C | IFN: alpha-2b, 3 mu tiw, 48 wks | 69 | 47 | 54* | 47* | 13 | 2.6 | 6.7
| | RBV: 1000–1200 mg qd, 48 wks
Pegylated interferon monotherapy
Heathcote, 2000 | A | IFN: alpha-2a, 3 mu tiw, 48 wks | 22*^†^ | 15* | 14*^†^ | 8.0* | 31*^a^ | 8 | 14
6 mos. | B | IFN: peg-IFN2a, 90 μg, qiw, 48 wks | 35* | 20 | 42* | 15 | 44^a^ | 7 | 9
| C | IFN: peg-IFN2a, 180 μg, qiw, 48 wks | 39^†^ | 34* | 44*^†^ | 30* | 54*^a^ | 13 | 10
Lindsay, 2001 | A | IFN: peg-IFN2b, 0.5 ng/kg, qiw, 48 wks | 25 ^c^ | 17 ^§ c^ | 33 ^§^ | 18 ^§^ | 20 | 2.9 | 2.9
6 mos. | B | IFN: peg-IFN2b, 1.0 ng/kg, qiw, 48 wks | 31 ^c^ | 24 ^§ c^ | 41 ^§^ | 25 ^§^ | 19 | 3.7 | 4.7
| C | IFN: peg-IFN2b, 1.5 ng/kg, qiw, 48 wks | 26 ^c^ | 18 ^§ c^ | 39 ^§^ | 23 ^§^ | 15 | 2.3 | 4.9
| D | IFN: alpha-2b, 3 mu tiw, 48 wks | 20^c^ | 12^R c^ | 24^R^ | 12^R^ | 13 | 2.0 | 2.0
Reddy, 2001 | A | IFN: alpha-2a, 3 mu tiw, 48 wks | 15 | 9.0*^†^ | 12*^†^ | 3.0*^†^ | 57^a^ | 9
6 mos. | B | IFN: peg-IFN2a, 45 ug, qiw, 48 wks | 20 | 10 | 30 | 10 | 47^a^ | 10
| C | IFN: peg-IFN2a, 90 ug, qiw, 48 wks | 20 | 25 | 45 | 30 | 59^a^ | 0
| D | IFN: peg-IFN2a, 180 ug, qiw, 48 wks | 38 | 38* | 60 | 36* | 63^a^ | 22
| E | IFN: peg-IFN2a, 270 ug, qiw, 48 wks | 27 | 27^†^ | 56^†^ | 29^†^ | 66^a^ | 20
Zeuzem, 2000a | A | IFN (initial): peg-IFN2a, 180 mcg, qiw, 48 wks | 46 | 45* | 69* | 39* | 63^a^ | 7 | 20
6 mos. | B | IFN (initial): alpha-2a, 6 mu tiw, 12 wks | 39 | 25 | 28* | 19* | 55^a^ | 10 | 18
| | IFN (maintenance): alpha-2a, 3 mu tiw, 36 wks
Interferon/ribavirin combination therapy
Berg, 2000 | A | IFN: alpha-2a, 6 mu tiw, 12 wks | | | 37* | 26 | | 2 | 24*
6 mos. | | RBV: 7 mg/kg, bid, 12 wks
| B | IFN: alpha-2a, 6 mu tiw, 12 wks | | | 29* | 17 | | 3 | 7*
el-Zayadi, 1999 | A | IFN: alpha-2b, 3 mu tiw, 24 wks | 62* | 38* | 35* | 19 | 56^a^ | 3.8 | 35
6 mos. | | RBV: 1000 mg qd, 24 wks
| B | IFN: alpha-2b, 3 mu tiw, 24 wks | 69* | 15* | 11* | 8 | 46^a^ | 3.8 | 0
Ferenci, 2001 | A | IFN (initial 1): alpha-2b, 10 mu, qd, 2 wks | 54 | 50.8 | 55.3 | 48.5 | | | 7
6 mos. | | IFN (initial 2): alpha-2b, 10 mu, every other day, 12 wks
| | IFN (maintenance): alpha-2b, 5 mu, every other day, 24 wks
| | RBV: 1000–1200 mg qd, 38 wks
| B | IFN (initial): alpha-2b, 5 mu, qd, 14 wks | 54 | 41.1 | 48.4 | 40.3 | | | 10
| | IFN (maintenance): alpha-2b, 5 mu, every other day, 24 wks
| | RBV: 1000–1200 mg qd, 38 wks
| C | IFN: alpha-2b, 5 mu, every other day, 38 wks | 56 | 41.1 | 50.4 | 40.3 | | | 9
| | RBV: 1000–1200 mg qd, 38 wks
Mangia, 2001 | A | IFN: alpha-2b, 5 mu tiw, 12 mos | 40* | 23* | 34* | 21* | | 8.3
6 mos. | B | IFN: alpha-2b, 5 mu tiw, 12 mos | 69* | 57* | 59* | 54* | | 10.4
| | RBV: 1000–1200 mg qd, 12 mos
Studies of interferon combination therapy with amantadine, with or without ribavirin
Studies of naïve patients
Caronia, 2001 | A | IFN (Pilot study): alpha-2a, 4.5 mu tiw, 48 wks | | | 33^c^ | 29^c^
| B | Amantadine (Pilot study): 200 mg qd, 48 wks | | | 54^c^ | 50^c^
| | IFN (Pilot study): alpha-2a, 4.5 mu tiw, 48 wks
| C | IFN (Multicenter): alpha-2a, 4.5 mu tiw, 48 wks | | | 17^c^ | 15^c^
| D | Amantadine (Multicenter): 200 mg qd, 48 wks | | | 25^c^ | 18^c^
| | IFN (Multicenter): alpha-2a, 4.5 mu tiw, 48 wks
| E | IFN (Combined): alpha-2a, 4.5 mu tiw, 48 wks | | | 19^c^ | 17^c^
| F | Amantadine (Combined): 200 mg qd, 48 wks | | | 31^c^ | 23^c^
| | IFN (Combined): alpha-2a, 4.5 mu tiw, 48 wks
Helbling, 2002 | A | Amantadine: 100 mg, bid, 52 weeks | 28.9 | 25.6 | 30.6 | 20.7 | | 11.2 | 24
6 mos. | | IFN (initial): alpha-2a, 6 mu tiw, 20 weeks
| | IFN (maintenance): alpha-2a, 3 mu tiw, 32 weeks
| B | IFN (initial): alpha-2a, 6 mu tiw, 20 weeks | 29.6 | 20.8 | 28.8 | 13.6 | | 8.8 | 18.4
| | IFN (maintenance): alpha-2a, 3 mu tiw, 32 weeks
Mangia, 2001a | A | IFN (initial): alpha-2a, 6 mu tiw, 12 mos | 34.6 | 18.8* | 28.7* | 16.8* | | 8.0
| B | IFN (initial): alpha-2a, 6 mu tiw, 12 mos | 46.5 | 36.4* | 45.5* | 29.3* | | 7.1
| | Amantadine (initial): 100 mg, bid, 12 mos
Tabone, 2001 | A | IFN (initial): alpha-2a, 6 mu, qed, 6 mos | | | 37^c^ | 17^c^
| | IFN (maintenance): alpha-2a, 3 mu, qed, 6 mos
| B | Amantadine: 100 mg, bid, 12 mos | | | 47^c^ | 24^c^
| | IFN (initial): alpha-2a, 6 mu, qed, 6 mos
| | IFN (maintenance): alpha-2a, 3 mu, qed, 6 mos
Zeuzem, 2000 | A | Amantadine: 100 mg, bid, 48 wks | 37 | 20 | 33 | 17 | | 7 | 2
6 mos. | | IFN (initial): alpha-2a, 6 mu tiw, 24 wks
| | IFN (maintenance): alpha-2a, 3 mu tiw, 24 wks
| B | IFN (initial): alpha-2a, 6 mu tiw, 24 wks | 35 | 25 | 33 | 37 | | 3 | 8
| | IFN (maintenance): alpha-2a, 3 mu tiw, 24 wks

a Percentage based on a denominator different from the group N

c Complete response, defined as combined virological and biochemical response

* p < 0.05 for the pairwise comparison between two groups marked with this symbol

† p < 0.05 for the pairwise comparison between two groups marked with this symbol

R p < 0.05 for the comparison groups marked with this symbol and the group marked

R Reference group for comparison

Evidence Table 13. Overall summary of randomized controlled trials of current treatment options for selected subgroups of patients with chronic hepatitis C

Author, Year | Location | N | Inclusion Criteria | Exclusion Criteria | Study Aims
Studies of current treatment options in nonresponders/relapsers to prior therapy
Studies of nonresponders
Barbaro, 1999 | Italy | 200 | IFN monotherapy >3 and/or <6 mo, IFN alpha-2b prior to study (not <3 mo and not >6 mo) and were nonresponders (no biochemical and viral response at end of tx), age <18 y, nonresponse to previous therapy: defined as ALT/HCV response from previous tx, detectable HCV in serum, HCV+, EtOHism | Hepatitis delta infection, decompensated liver disease, HBV+, DM, immune suppression, HIV+, other viral infections: EBV, CMV, and mycobacterial, cardiomyopthies, neurologic comorbidity, malignancy comorbidity, pregnancy, Wilson's disease, PT >5 sec longer than nl, Cr 2x nl, Bili >3x nl, Hgb <10 g/dL, neutrophil <1000, hypertension, use of hepatotoxic drugs in past 6 mo, malnutrition, hemochromatosis, alpha-1-antitrypsin, autoimmune hepatitis, neoplastic disease, metabolic disorder, other comorbidity: malnutrition, WBC <2500 | Randomized controlled trial assessing clinical efficacy of IV recombinant IFN-beta compared w/ IFN-alpha-2b + RBV in pts w/ CHC unresponsive to IFN-alpha-2b at standard doses.
Bresci, 2000 | Italy | 100 | ALT 2x UL of nl, 3 times in last 6 mo, IFN monotherapy: IFN alpha-2b (3 mu tiw, for 4 mo) not w/i 6 mo of the study, detectable HCV in serum | Any antiviral agents w/i 6 mo of study, concomitant liver disease, thyroid dysfunction, pre-existing anemia, metabolic disorders (hemochromatosis, Wilson's disease, alph-1-antitrypsin deficiency), drug-induced liver disease, HIV+, immune suppression, presence of cirrhosis, hepatitis delta infection, HBV+, EtOH >40 g/d | To test the effectiveness of high dose IFN plus RBV vs. high dose IFN alone in previous IFN nonresponders.
Di Bisceglie, 2001 | United States | 124 | Initial liver bx w/i 12 mos of rx, IFN monotherapy >=36 mu, detectable HCV in serum, positive HCV antibodies | | To see if nonresponders to IFN alone would respond to a combination of IFN/RBV for either 24 or 48 wks
Ferenci, 2001a | Austria | 157 | HCV+, detectable HCV in serum, ALT 2x UL of nl, IFN monotherapy 5 mu tiw for 3 mo | Autoimmune thyroiditis, HBV+, depression, HIV+, EtOH >50 g/d, HBV surface antibodies, plts <100,000, uncontrolled DM, other liver diseases, WBC <3000, Hgb <12, cardiovascular or coronary artery disease | To study the efficacy of high-dose IFN alpha w/ or w/o RBV in IFN nonresponders.
Puoti, 2001 | Italy | 63 | Detectable HCV in serum, age 18–60 yrs, ALT 1.5x nl, AFP, U/S, initial liver bx, IFN monotherapy, nonresponse to previous therapy | Depression, other psychiatric illness, pregnancy, adverse reaction to previous therapy, HIV+, HBV+, metabolic disorder, IDU, alcohol abuse, decompensated liver disease, cardiovascular comorbidity, other comorbidities: autoimmune, ascites, encephalopathy, uncontrolled diabetes, uncontrolled diabetes, unable to use OCPS, and neurologic, malignancy comorbidities: hemolytic anemia and thyroid disease, plts <100,000, WBC <3000, Hgb <12 for females and <13 for males | To assess efficacy of varying doses of IFN and RBV in previous nonresponders. Doses of IFN included 3 mu tiw, 5 mu tiw and 5 mu qd.
Saracco, 2001 | Europe | 594 | HCV+, detectable HCV in serum initial liver bx w/i prior 2 yrs, nonresponse to previous therapy, IFN monotherapy, age >18 and <65 | Concomitant significant medical illness, IDU, HBV+, decompensated liver disease, relapse after previous therapy: >=1 course of IFN, pregnancy, depression, HIV+, cardiovascular comorbidity: ischemic cardiovascular disease, neurologic comorbidity: seizures, hematologic comorbidity: hemolytic anemia or hemophilia, abnl uric acid, obesity-induced liver disease, nonresponse to previous therapy: IFN and ribavirin combination therapy, other comorbidities: Wilson's disease, hemochromatosis, or autoimmune hepatitis, IFN + RBV, WBC <3000, neutrophil <500, Hgb <10 g/dl, plts <70,000, GI comorbidity, alpha-1antitrypsin deficiency | To assess if higher than standard doses of IFN given w/ RBV for prolonged periods of administration improved the rate of sustained response in previous IFN-alone nonresponders. The study compares the efficacy and safety of 3 mu and five mu of IFN plus 1000 mg daily RBV for either 6 or 12 mos
Shiffman, 2000a | United States | 140 | ALT, IFN monotherapy, pregnancy, nonresponse to previous therapy: IFN monotherapy | IFN monotherapy: max dose 6 mu IFN alpha-2a, OR max dose 9 mg IFN alphacon, OR max dose 3 mu IFN alpha-2b, any other type of liver disease, IDU, EtOH | To determine whether combination IFN/RBV was effective in tx of IFN monotherapy nonresponders.
| | | | | To determine subgroups who did not respond.
Tripi, 2000 | Italy | 72 | Nonresponse to previous therapy: nonresponse to >= 2 courses of IFN (6 mu tiw, for 4 mo), detectable HCV in serum, ALT 2x UL of nl range, initial liver bx: CHC, IFN monotherapy 6 mo prior to study | HBV+, IDU, other illicit drug use, EtOH >50 g/d, Epstein-Barr virus, cytomegalovirus, immune suppression | To investigate the efficacy of IFN alone or IFN in combination w/ RBV in the retx of HCV+ nonresponders to IFN monotherapy
Studies of relapsers
Chapman, 2001 | New Zealand | 32 | ALT 1.5x nl, initial liver bx prior to initial tx, IFN monotherapy: 3 mu tiw for 6 mo ; relapsed w/i 6 mo of tx, contraception, detectable HCV in serum | Lactating, cardiovascular comorbidity, pregnancy | To compare the effect of high dose, long-term IFN therapy w/ shorter duration and lower dose IFN and RBV in IFN relapsers.
Di Marco, 2000 | Italy | 50 | HCV+, initial liver bx, relapse after previous therapy, interferon monotherapy, age 18–65 yrs | Hemoglobinopathy, detectable HCV in serum, decompensated liver disease, HCC, immune suppression HIV+, HBV+, autoimmune disease, any antiviral therapy, uncontrolled diabetes, Hgb <12 for females and <13 for males, WBC <3000, plts <100,000, IFN, hematologic comorbidity: anemia, neutropenia, thrombocytopenia | To compare SVR in 6 vs. 12 mos of IFN alpha 2b 6 mu tiw and RBV 1–1.2 g/day in IFN relapsers. To examine the tolerability of higher doses of IFN + RBV. To identify predictors of response. To assess HCV viral dynamics.
Enriquez, 2000 | Spain | 120 | HCV+, detectable HCV in serum, 6-mo duration of HCV+, el ALT for 6 mo, initial liver bx, relapse after previous therapy, nonresponse to previous therapy, 18–55 yrs | Cardiovascular comorbidity, IDU w/i the last year, presence of cirrhosis, decompensated liver disease, immune suppression, depression, HIV+, PT <50%, neurologic or GI comorbidity, renal insufficiency, poorly controlled DM, WBC <3000, neutrophil <1500, Hgb <12 for females and <13 for males, plts <100,000, other psychiatric illness | To see whether retx w/ IFN plus RBV for 24 or 48 wks would be beneficial in pts who relapsed or did not respond to previous IFN monotherapy
Studies of nonresponders and relapsers
Bonkovsky, 2001 | United States | | Age >17, HCV+, detectable HCV in serum, prior tx w/ IFN w/ nonresponse or relapse, ALT 1.2x UL of nl, WBC >2,500, neutrophils >1,500, Hgb >12, plts >75,000 | Decompensated liver disease, pregnancy, breastfeeding, or women of childbearing age refusing to use contraception, Immune suppression, depression or other psychiatric illness, cardiovascular comorbidity, alpha-1-antitrypsin deficiency, EtOH/non-EtOH steatohepatosis, hemochromatosis, Wilson's disease, severe renal disease, pulmonary disease, creatinine >2.0, transplant recipient, steroids/immunosuppression | To determine whether 600 mg RBV/day would prove as efficacious as 1000–1200 mg/day when combined w/ IFN (3 mu, tiw) for therapy of pts who relapsed or failed to respond to standard IFN
Cavalletto, 2000 | Italy | 100 | Nonresponse to previous therapy, HCV+, detectable HCV in serum, presence of fibrosis: CHC, presence of cirrhosis: CHC, age 18–60 yrs, relapse after previous therapy, peg-IFN alpha monotherapy >= 6 mo, initial liver bx w/i 12 mo of enrollment, initiation of therapy 12–24 mo after last tx w/alpha-IFN | Adverse reaction to previous therapy, allergy to IFN: intolerant to 1st course, pregnancy or “rejects contraception,” HIV+, hematologic comorbidity: hemolytic disorder, HBV+, “recent” history of IDU, “recent” history of EtOH, decompensated liver disease: bx <1 yrs | To assess the effect of adding RBV to alpha-IFN for the retx of alpha-IFN relapsers and of previous alpha-IFN nonresponders.
Min, 2001 | United States | 154 | IFN monotherapy for >3 mos, abnl ALT, initial liver bx showing CHC and/or cirrhosis, detectable HCV in serum | Women unwilling or unable to use contraceptives, IFN w/i 3 mos, IFN + RBV w/i 3 mos, immunomodulating or antiviral drugs w/i 3 mos, seizure disorder, other liver disease, cardiovascular comorbidity, severe psychiatric disorder, immune suppression, decompensated liver disease | To evaluate the efficacy of high dose IFN in combination w/ RBV in treating pts w/ CHC resistant to IFN monotherapy
Studies of interferon/amantadine combination therapy, with or without ribavirin
Studies of nonresponders
Brillanti, 2000 | Italy | | Nonresponse to previous therapy: defined as no HCV-RNA clearance and no ALT normalization; IFN alpha 3–6 mu, HCV+, absence of circulating anti-IFN antibodies, IFN monotherapy, 3–6 mu Ly or r IFN alpha for >=4 mo, initial liver bx: before first tx,el ALT for 6 mo, detectable HCV in serum | Comorbidities: GI, “other causes of chronic liver disease,” pulmonary, renal, neurologic, seizure, diabetes, and cardiovascular, HBV+, immune suppression, depression, other psychiatric illness, HIV+, decompensated liver disease, plts <100,000 autoimmune hepatitis, alcoholic liver disease, WBC <3000, Hgb <12 in women and <13 in men
Gaeta, 2001 | Italy | 40 | Initial liver bx w/i prior 12 mo, ALT 1.5x UL of nl, nonresponsive to previous IFN alpha therapy, detectable HCV in serum, HCV+, HCV genotype 1b, age <60 yrs | Antihistamine, contraindication to IFN, renal disease, psychiatric illness, HIV+, decompensated liver disease, HBV+ | To evaluate the efficacy and tolerability of high dose IFN plus amantadine for CHC pts who were nonresponders to a previous course of IFN
Teuber, 2001 | Germany | 55 | Age: 18–70, HCV+, detectable HCV in serum, ALT, initial liver bx, nonresponse to previous IFN, WBC >2,500, Plts >70,000 | EtOH >50g, IDU or other illicit drug use w/i past year, HBV+, HIV+, decompensated liver disease, pregnancy and lactation, immune suppression, depression, other psychiatric illness, cardiovascular comorbidity, neurologic comorbidity, bleeding disorders, malignancy, autoimmune disorders, metabolic disease, renal disease, rheumatologic | To evaluate the efficacy, tolerability, and health-related quality of live of IFN alpha 2a plus amantadine in omparison w/ IFN alpha 2a plus placebo in previous nonresponders
Younossi, 2001 | United States | 118 | Nonresponse to previous IFN monotherapy, initial liver bx, IFN monotherapy tiw for >=12 wk, HCV+ | Other liver diseases, decompensated liver disease, immune suppression, severe depression, other severe psychiatric illness, HIV+, seizure disorders, DM, renal insufficiency, uncontrolled thyroid disease, plts <100,000, WBC <3000, Hgb <13 for males and <12 for females, active cardiovascular disease | To compare a 24 wk regimen of IFN alpha-2b plus RBV to IFN alpha-2b plus amantadine in nonresponders to previous IFN monotherapy
Studies of treatment outcomes in other subgroups
Subgroup: Renal
Campistol, 1999 | Spain | 36 | Detectable HCV in serum, HCV+ | HIV+, HBV+ | Multicenter randomized trial assessing the efficacy and tolerance of IFN alpha-2b in tx of HCV induced chronic hepatitis in pts undergoing hemodialysis, w/ evaluation following renal transplant.
Subgroup: Race/ethnicity
McHutchison, 2000 | United States | 1712 | | | To evaluate racial differences in response to therapy in pts w/ CHC, and potential contributing factors that might account for such differences
Reddy, 1999 | United States | 470 | | | To retrospectively analyze data from the consensus IFN trial looking at outcomes in the specific tx arms (IFN-alpha-2b 3 mu tiw and alphacon IFN 9 mg) based on race.
| Canada
Subgroup: Hemophiliacs
Rumi, 1997 | Italy | 95 | HCV+, detectable HCV in serum, ALT >= 2x nl on 3 occasions over 6 mo, HIV+ | Peg-IFN monotherapy, HBV+, decompensated liver disease, HCC, EtOH >80 g/d, Peg-IFN + RBV, IFN, IFN + RBV, IFN monotherapy, steroid, WBC <3000, plts <100,000, non-organ-specific autoantibodies, thyroid dysfunction | To evaluate the efficacy of long term (6 mo) IFN tx in hemophiliac pts
Subgroup: HBV/HCV coinfection
Villa, 2001 | Italy | 30 | Consecutively seen in clinic, ALT 2x nl for 6 mos, HBV+, HCV+ | IFN tx, peg-IFN + RBV tx | To determine the outcome of medium to high doses of IFN therapy in pts w/ HBV-HCV.
Studies of interferon in nonresponders/relapsers
Bresci, 1996 | Italy | 150 | ALT 2x UL of nl 3 times w/i 6 mo, 3 mu of rIFN, tiw, for 6 mo, nonresponse to previous therapy: detectable HCV in serum | Alpha-1-antitrypsin deficiency, Wilson's disease, hemochromatosis, drug-induced liver disease, immune suppression: autoimmune factors (+ANA, ASMA), presence of cirrhosis, hepatitis delta infection, HBV+, EtOH >40 g/d | To investigate the efficacy of different types of IFN and dosages in previous nonresponders to IFN tx (3 mu, tiw, for 6 mos)
Chemello, 1997 | Italy | 88 | ALT 2.5x UL of nl, IFN monotherapy, detectable HCV in serum, relapse after previous therapy: 3 mu IFN alpha tiw for 6 mo or 3–6 mu IFN alpha tiw for 12 mo, nonresponse to previous therapy: 3 mu IFN alpha tiw for 6 mo or 3–6 mu IFN alpha tiw for 12 mo, age >18 and <55 yrs | Autoimmune disease, EtOH, HBV+, decompensated liver disease, HIV+, plts <100,000, metabolic disorders, ascites, varices, encephalopathy, WBC <3000, adverse reaction to previous therapy | Efficacy of retx w/ IFN in previous nonresponders and relapsers. The endpoints addressed were 1) predictors of virological and biochemical response and 2) influence of initial tx schedule on retx.
Gaeta, 1997 | Italy | 69 | ALT 2x UL on 3 consecutive monthly samples, initial liver bx to test for HCV, LyIFN alpha for >= 4 mo, r IFN alpha for >=4 mo, nonresponse to previous therapy for >=4 mos w/ either r or LyIFN alpha, detectable HCV in serum | Abnl thyroid function, HIV+: tested for antibodies, decompensated liver disease, HBV+: screened for surface antigen HBsAg, immune suppression | To evaluate the efficacy and safety of leukocyte IFN-alpha in the retx of pts w/ chronic HCV who have failed to respond to therapy w/ either recombinant IFN-alpha or LyIFN-alpha.
Heathcote, 1998 | United States | 337 | Plts 75 x 10^9, neutrophil >1.5 x 10^6, Hgb >10, ALT >48 x 2 consecutive values, consensus IFN 9 μγ tiw for 24/52 mo, consensus IFN 3 μγ tiw for 24/52 mo, IFN monotherapy 3 mu tiw for 24/52 mo | Seizure disorder and currently taking medication, thyroid disease in which nl thyroid function was not attainable, neurologic comorbidity, HIV+, depression, decompensated liver disease, IDU, EtOH | To determine the safety and efficacy of retx of CHC w/ consensus IFN for 24 wks vs. 48 wks at higher doses (15 μg) in nonresponders and relapsed pts.
| Canada
Kagawa, 1998 | Japan | 62 | ALT el persistently for >= 6 mo, initial liver bx: active CHC, detectable HCV in serum | HCC, hepatitis delta infection, HBV+ | To evaluate the effect of higher doses of IFN in initial nonresponders. To evaluate early virologic response as a predictor of sustained response.
Payen, 1998 | France | 247 | Abnl ALT for 6 mo, initial liver bx IFN monotherapy: 3 mu IFN, tiw for 6 mo, HCV+, detectable HCV in serum | Adverse reaction to previous therapy: grade 3 or 4 by WHO classification, HBV+, presence of cirrhosis, age <18 yrs, HIV+, Fe deposition in liver, women of childbearing age not using contraceptives, severe associated disease, pregnancy | To compare the efficacy of IFN alpha2b regimens in pts w/ CHC who relapsed after an initial 6 mo IFN tx
Poynard, 1999 | France | 58 | ALT 1.5x nl in last 6 mo, IFN monotherapy: >= 3 mu tiw, for 24–48 wk, detectable HCV in serum, relapse after previous therapy, liver bx with CHC w/o cirrhosis, age 18–70 yrs | Neurologic comorbidity, EtOH 50 g/d, IDU, other illicit drug use, HBV+, hepatitis delta infection, immune suppression, depression, other psychiatric illness, cardiovascular comorbidity, plts <70,000, hematologic comorbidity, renal disease, pulmonary disease, thyroid disease, severe medical disorder, MRI HCC, AFP >100, neutrophil <2, HIV+ | To compare the effect of high-dose, short duration (14 wks) IFN regimen in relapsers w/ standard 6 mo IFN regimen of 3 mu tiw.
Shiffman, 1999 | United States | 53 | Nl alpha-antitrypsin, HCV+, detectable HCV in serum, nonresponse to previous therapy: IFN alfa-2b, histologic response to prior IFN tx, nl ceruloplasmin, nl antinuclear antibody, nl anti-smooth-muscle antibody, initial liver bx, ALT el 6 mo, WBC, IFN monotherapy, nl hepatic Fe levels, plts >90,000 | HIV+, active IDU, abnl Alb, abnl Bili, HBV+, immune suppression, chronic EtOH, abnl prothrombin, abnl AFT, pregnancy | To assess if continued maintenance of IFN prevents HCV progression in virologic nonresponders who achieved a histological response after an initial 6 mo IFN tx.

Evidence Table 14. Characteristics of patients in randomized controlled trials of current treatment options for selected subgroups of patients with chronic hepatitis C

Author, Year | Study Design | Study Groups | N | Mean age % Male Race | % w/ Cirrhosis | Scoring System | Mean Activity (A) Fibrosis (S) | % w/ Score Activity (A) Fibrosis (S) | Mean ALT (U/L) Mean yrs w/ HCV HCV genotype (%)
Studies of current treatment options in nonresponders/relapsers to prior therapy
Studies of nonresponders
Barbaro, 1999 | RCT
| | IFN: beta IFN, 6 mu, 6 days/week, 12 wks | 100 | 33 | | HAI | S 2.3 | | 178
| | | | 67.0 | | HAI | T 11.7
| | | | | | | | | 1b | 45.00
| | | | | | | | | 2a/c | 43.00
| | | | | | | | | 3a | 12.00
| | IFN: alpha-2b, 6 mu tiw, 12 wks | 100 | 32 | | HAI | S 2.2 | | 175
| | RBV: 1000–1200 mg qd, 12 wks | | 65.0 | | HAI | T 11.5
| | | | | | | | | 1b | 43.00
| | | | | | | | | 2a/c | 44.00
| | | | | | | | | 3a | 13.00
Bresci, 2000 | RCT
| | IFN: 6 mu tiw, 6 mos | 50 | 52 | | HAI | S 2.0 | | 149
| | RBV: 1000–1200 mg qd, 6 mos | | 56.0 | | Kno | A 10.3 | | 7
| | | | | | | | | 1 | 78.00
| | IFN: 6 mu, bid, 6 mos | 50 | 48 | | HAI | S 2.2 | | 150
| | | | 52.0 | | Kno | A 9.7 | | 8
| | | | | | | | | 1 | 74.00
Di Bisceglie, 2001 | RCT
| | IFN: alpha-2b, 3 mu tiw, 24 wks | 63 | 43 | | Sch | | A0 20.6 | 90
| | RBV: 1000–1200 mg qd, 24 wks | | 69.8 | | Sch | | A1 30.2
| | | | C: 96.8 | | Sch | | A2 25.4 | 1 | 74.60
| | | | | | Sch | | A3 23.8 | 2 | 19.05
| | | | | | | | | 3 | 6.35
| | IFN: alpha-2b, 3 mu tiw, 48 wks | 61 | 46 | | Sch | | A0 18.0 | 100
| | RBV: 1000–1200 mg qd, 48 wks | | 57.4 | | Sch | | A0 21.3
| | | | C: 98.3 | | Sch | | A2 41.0 | 1 | 86.89
| | | | | | | | A3 19.7 | 2 | 9.84
| | | | | | | | | 3 | 3.28
Ferenci, 2001a | RCT
| | IFN (initial): alpha-2b, 5 mu tiw, mos | 76 | | | | | S3, A2 55.3 | 65.4
| | | | 71.1 | | | | S4, A3 21.1
| | IFN (maintenance): alpha-2b, 10 mu, tiw, 3 mos | | | | | | | 1a | 15.79
| | | | | | | | | 1a/b | 2.63
| | | | | | | | | 1b | 68.42
| | | | | | | | | 3 | 6.58
| | | | | | | | | 4 | 6.58
| | IFN (initial): alpha-2b, 5 mu tiw, 3 mos | 81 | | | | | S3, A2 63.0 | 69.8
| | | | 70.4 | | | | S4, A3 17.3
| | IFN (maintenance): alpha-2b, 10 mu, tiw, 2 mos | | | | | | | 1a | 22.22
| | | | | | | | | 1a/b | 2.47
| | RBV: 1000–2000 mg qd, 6 mos | | | | | | | 1b | 62.96
| | | | | | | | | 3 | 6.17
| | | | | | | | | 4 | 6.17
Puoti, 2001
| | IFN: alpha-2b, 3 mu tiw, 24 wks | 21
| | RBV: 1000–1200 mg qd, 24 wks | | 85.7 | | | | | 12
| | | | | | | | | 1 | 71.43
| | | | | | | | | 2 | 19.05
| | | | | | | | | 3 | 4.76
| | | | | | | | | 4 | 4.76
| | IFN: alpha-2b, 5 mu tiw, 24 wks | 21
| | RBV: 1000–1200 mg qd, 24 wks | | 81.0 | | | | | 10
| | | | | | | | | 1 | 71.43
| | | | | | | | | 2 | 23.81
| | | | | | | | | 3 | 4.76
| | | | | | | | | 4 | 4.76
| | IFN: alpha-2b, 5 mu, qd, 24 wks | 21
| | RBV: 1000–1200 mg qd, 24 wks | | 81.0 | | | | | 15
| | | | | | | | | 1 | 61.90
| | | | | | | | | 2 | 9.52
| | | | | | | | | 3 | 14.29
| | | | | | | | | 4 | 14.29
Saracco, 2001 | RCT
| | IFN: alpha-2b, 3 mu tiw, 12 mos | 139 | 46 | 12 | ISH | A 2.6
| | RBV: 1000 mg qd, 12 mos | | 66.2 | | ISH | S 6.2
| | | | | | | | | 1 | 66.91
| | | | | | | | | 2 | 16.55
| | | | | | | | | 3 | 9.35
| | | | | | | | | 4 | 7.19
| | IFN: alpha-2b, 5 mu tiw, 12 mos | 162 | 44 | 9 | ISH | A 2.5
| | RBV: 1000 mg qd, 12 mos | | 74.7 | | ISH | S 6.4
| | | | | | | | | 1 | 60.49
| | | | | | | | | 2 | 19.14
| | | | | | | | | 3 | 13.58
| | | | | | | | | 4 | 6.79
| | IFN: alpha-2b, 3 mu tiw, 6 mos | 142 | 46 | 15 | ISH | A 2.8
| | RBV: 1000 mg qd, 6 mos | | 76.8 | | ISH | S 6.2
| | | | | | | | | 1 | 67.61
| | | | | | | | | 2 | 14.79
| | | | | | | | | 3 | 14.08
| | | | | | | | | 4 | 3.52
| | IFN: alpha-2b, 5 mu tiw, 6 mos | 151 | 45 | 7 | ISH | A 2.6
| | RBV: 1000 mg qd, 6 mos | | 78.1 | | ISH | S 6.0
| | | | | | | | | 1 | 68.87
| | | | | | | | | 2 | 13.25
| | | | | | | | | 3 | 11.26
| | | | | | | | | 4 | 6.62
Shiffman, 2000a | RCT
| | IFN (initial): alpha-2b, 5 mu tiw, 3 mos | 48 | 44.5 | 21 | Kno | 7.3 | | 1 | 89.58
| | | | 60.4
| | IFN (maintenance): alpha-2b, 5 mu, tiw, 3 mos | | C: 50,
| | | | B: 50
| | IFN (initial): alpha-2b, 3 mu tiw, 3 mos | 42 | 43.6 | 19 | Kno | 7 | | 1 | 88.10
| | | | 69.0
| | IFN (maintenance) : alpha-2b, 5mu, tiw, 3 mos | | C: 69.0,
| | | | B: 30.9
| | RBV: 1000–1200 mg, Divided dose, twice daily, 9 mos
| | IFN: alpha-2b, 5 mu tiw, 6 mos 50 | 50 | 42.9 | 14 | Kno | 6.4 | | 1 | 90.00
| | RBV: 1000– mg, Divided dose, twice daily, 9 mos | | 66.0
| | | | C: 64,
| | | | B: 36
Tripi, 2000 | RCT
| | IFN: Leukocyte IFN alpha, 6 mu tiw, 6 mos | 24 | 46.2 | | HAI | A 1.3 | | 184.5
| | | | 50.0 | | HAI | S 3.4
| | | | | | | | | 1a | 12.50
| | | | | | | | | 1b | 66.67
| | | | | | | | | 2a | 12.50
| | | | | | | | | 2a and b | 4.17
| | | | | | | | | 2b | 4.17
| | IFN: Leukocyte IFN alpha, 6 mu tiw, 6 mos | 48 | 49.4 | | HAI | A 2.1 | | 168.8
| | | | 75.0 | | HAI | S 4.8
| | RBV: 1200 mg qd, 6 mos | | | | | | | 1a | 4.17
| | | | | | | | | 1b | 70.83
| | | | | | | | | 2a | 10.42
| | | | | | | | | 2a and b | 2.08
| | | | | | | | | 2b | 12.50
Studies of relapsers
Chapman, 2001 | RCT
| | IFN (initial): alpha-2a, 6 mu tiw, 6 mos | | 16 | 37
| | | | 56.3
| | IFN (maintenance): alpha-2a, 3 mu, tiw, 6 mos | | | | | | | 1 | 75.00
| | | | | | | | | 2 | 25.00
| | IFN: alpha-2a, 3 mu tiw, 6 mos | 16 | 38
| | RBV: 1000 mg qd, 3 mos | | 62.5
| | | | | | | | | 1 | 37.50
| | | | | | | | | 2 | 62.50
Di Marco, 2000 | RCT
| | IFN: alpha-2b, 6 mu tiw, 6 mos | 25 | 46.1 | 12 | Met | | A1, A2 64.0
| | RBV: 1000–1200 mg, bid, 6 mos | | 68.0 | | Met | | A3 36.0
| | | | | | Met | | S1–S3 88.0 | 1b | 76.00
| | | | | | Met | | S4 12.0 | other | 24.00
| | IFN: alpha-2b, 6 mu tiw, 12 mos | 25 | 45.6 | 16 | Met | | A1–A2 72.0
| | RBV: 1000–1200 mg, bid, 12 mos | | 84.0 | | Met | | A3 28.0
| | | | | | Met | | S1–S3 84.0 | 1b | 40.00
| | | | | | Met | | S4 16.0 | other | 28.00
Enriquez, 2000 | RCT
| | IFN: alpha-2b, 3 mu tiw, 24 wks | 58 | 40.22
| | RBV: 1000–1200 mg qd, 24 wks | | 79.3
| | | | | | | | | 1 | 82.76
| | | | | | | | | non-1 | 15.52
| | IFN: alpha-2b, 3 mu tiw, 48 wks | 62 | 39.87
| | RBV: 1000–1200 mg qd, 48 wks | | 77.4
| | | | | | | | | 1 | 80.65
| | | | | | | | | non-1 | 17.74
Studies of nonresponders and relapsers
Bonkovsky, 2001 | RCT
| | IFN: alpha-2b, 3 mu tiw, 24 wks | 35 | 44
| | RBV: 600 mg, 400 mg A.M./200 mg | | 68.6
| | P.M., 24 wks | | C: 91.4, | | | | | 1 | 68.57
| | | | B: 0, A: 0, | | | | | non-1 | 28.57
| | | | O: 8.57 | | | | | not specified | 2.86
| | IFN: alpha-2b, 3 mu tiw, 24 wks | 34 | 44
| | RBV: 1000–1200 mg qd, 24 wks | | 61.8
| | | | C: 97.0, | | | | | 1 | 70.59
| | | | B: 2.94, A: 0, | | | | | non-1 | 26.47
| | | | O: 0 | | | | | not specified | 2.94
Cavalletto, 2000 | RCT
| | IFN (initial): natural IFN, 6 mu tiw, 2 mos | 50 | 38 | | ISH | A 3.0
| | | | 60.0 | | ISH | S 8.9
| | IFN (maintenance): natural IFN, 3 mu tiw, 6 mos | | | | ISH | | 3–4 22.0 | 1 | 56.00
| | | | | | ISH | | 6 12.0 | 2 | 20.00
| | | | | | | | | 3 | 24.00
| | IFN (initial): natural IFN, 6 mu tiw, 2 mos | 50 | 40 | | ISH | A 3.1
| | | | 94.0 | | ISH | S 9.6
| | IFN (maintenance): natural IFN, 3 mu tiw, 6 mos | | | | ISH | | 3–4 28.0 | 1 | 68.00
| | | | | | ISH | | 6 12.0 | 2 | 20.00
| | RBV: 1000–1200 mg qd, 6 mos | | | | | | | 3 | 12.00
Min, 2001 | RCT
| | IFN: alpha-2b, 3 mu tiw, 12 mos | 81 | 47
| | RBV: 1000–1200 mg, bid, 12 mos | | 69.1
| | | | C: 77.1, | | | | | 1 | 87.65
| | | | B: 6.17, | | | | | non-1 | 12.35
| | | | O: 16.0
| | IFN: alpha-2b, 5 mu tiw, 12 mos | 73 | 47.2
| | RBV: 1000–1200 mg, bid, 12 mos | | 74.0
| | | | C: 80.8, | | | | | 1 | 83.56
| | | | B: 8.21, | | | | | non-1 | 17.81
| | | | O: 10.9
Studies of interferon/amantadine combination therapy, with or without ribavirin
Studies of nonresponders
Brillanti, 2000 | RCT
| | Amantidine: | 20 | 47
| | IFN: alpha-2b, 5 mu tiw, 12 mos | | 65.0
| | RBV: 800 – 1000 mg qd, 12 mos | | | | | | | 1 | 55.00
| | | | | | | | | 2 | 30.00
| | | | | | | | | 3 | 10.00
| | | | | | | | | 4 | 5.00
| | Amantidine: 200 mg qd, 12 mos | 40 | 49
| | IFN: alpha-2b, 5 mu tiw, 12 mos | | 67.5
| | RBV: 800 – 1000 mg qd, 12 mos | | | | | | | 1 | 57.50
| | | | | | | | | 2 | 27.50
| | | | | | | | | 3 | 7.50
| | | | | | | | | 4 | 7.50
Gaeta, 2001 | RCT
| | Amanitidine (initial): 100 mg, bid, 4 wks | 21 | 44.7 | 5 | Kno | S 5.0
| | | | 66.7 | | Sch | A 1.5
| | Amanitidine (maintenance): 100 mg, bid, 5 mos | | | | | | | 1b | 100.00
| | IFN (initial): alpha-2a, 4.5 mu, qd, 4 wks
| | IFN (maintenance): alpha-2a, 6 mu, tiw, 5 mos
| | IFN (initial): alpha-2a, 4.5 mu, qd, 4 wks | 19 | 48.4 | 11 | Kno | S 5.5
| | | | 63.2 | | Sch | A 1.5
| | IFN (maintenance): alpha-2a, 6 mu, tiw, 5 mos | | | | | | | 1b | 100.00
Teuber, 2001 | RCT
| | Amantidine: 100 mg, bid, 48 wks | 26 | 47.7 | | | | | 73
| | IFN (initial): alpha-2a, 6 mu tiw, 24 wks | | 73.1 | | | | | 10.9
| | | | | | | | | 1 | 84.62
| | IFN (maintenance): alpha-2a, 6 mu, tiw, 24 wks | | | | | | | non-1 | 15.38
| | Amantidine: Placebo | 29 | 45.7 | | | | | 64
| | IFN (initial): alpha-2a, 6 mu tiw, 24 wks | | 41.4 | | | | | 14.9
| | | | | | | | | 1 | 93.10
| | IFN (maintenance): alpha-2a, 6 mu, tiw, 24 wks | | | | | | | non-1 | 6.90
Younossi, 2001 | RCT
| | IFN: alpha-2b, 3 mu tiw, 24 wks | 59 | 46.1 | 17 | HAI | 8.1
| | RBV: 800 mg qd, 24 wks | | 62.7
| | | | C: 79.6, | | | | | 1a/b | 83.05
| | | | B: 18.6, | | | | | other | 13.56
| | | | O: 1.69
| | Amantidine: 200 mg qd, 24 wks | 59 | 45.6 | 17 | HAI | 7.1
| | IFN: alpha-2b, 3 mu tiw, 24 wks | | 61.0
| | | | C: 72.8, | | | | | 1a/b | 71.19
| | | | B: 10.1, | | | | | other | 25.42
| | | | O: 10.1
Studies of treatment outcomes in other subgroups
Subgroup: Renal
Campistol, 1999 | RCT
| | IFN: alpha-2b, 3 mu tiw, 6 mos | 19 | 42
| | | | 47.4
| | IFN: None | 17 | 48
| | | | 58.8
Subgroup: Race/ethnicity
McHutchison, 2000 | RCT
| | IFN (210 pts): alpha-2b, 3 mu tiw, 214 wks | 600 | 43 | | HAI | 7.1
| | | | 65.1 | | Kno | S 1.5 | | 17
| | IFN (461 pts): alpha-2b, 3 mu tiw, 24 wks | | | | Kno | | S3 1.1 | 1 | 65.06
| | | | | | Kno | | S4 0.2 | non- 1 | 34.94
| | IFN (464 pts): alpha-2b, 3 mu tiw, 48 wks
| | IFN (465 pts): alpha-2b, 3 mu tiw, 48 wks
| | RBV (461 pts): 1000/1200 mg qd, 24 wks
| | RBV (464 pts): 1000/1200 mg qd, 48 wks
| | IFN (12 pts): alpha-2b, 3 mu tiw, 24 wks | 53 | 46 | | HAI | 7.8
| | | | 67.9 | | Kno | S 1.7 | | 18
| | IFN (13 pts): alpha-2b, 3 mu tiw, 48 wks | | | | Kno | | S3 47.2 | 1 | 96.23
| | | | | | Kno | | S4 11.3 | non-1 | 3.77
| | IFN (13 pts): alpha-2b, 3 mu tiw, 48 wks
| | IFN (15 pts): alpha-2b, 3 mu tiw, 24 wks
| | RBV (13 pts): 1000/1200 mg qd, 48 wks
| | RBV (15 pts): 1000/1200 mg qd, 24 wks
| | IFN (1 pts): alpha-2b, 3 mu tiw, 24 wks | 27 | 45 | | Kno | S 1.5
| | | | 81.5 | | Kno | | S4 40.7 | 21
| | IFN (13 pts): alpha-2b, 3 mu tiw, 24 wks | | | | | | | 1 | 59.26
| | | | | | | | | non-1 | 40.74
| | IFN (6 pts): alpha-2b, 3 mu tiw, 48 wks
| | IFN (7 pts): alpha-2b, 3 mu tiw, 48 wks
| | RBV (13 pts): 1000/1200 mg qd, 24 wks
| | RBV (7 pts): 1000/1200 mg qd, 48 wks
| | IFN (12 pts): alpha-2b, 3 mu tiw, 48 wks | 32 | 45 | | HAI | 7.9
| | | | 75.0 | | HAI | | 40.6 | 21
| | IFN (5 pts): alpha-2b, 3 mu tiw, 48 wks | | | | Kno | | | 1 | 78.13
| | | | | | Kno | S3 | 6.2 | non- 1 | 21.88
| | IFN (7 pts): alpha-2b, 3 mu tiw, 24 wks | | | | Kno | S4 | 88
| | IFN (8 pts): alpha-2b, 3 mu tiw, 24 wks
| | RBV (12 pts): 1000/1200 mg qd, 48 wks
| | RBV (8 pts): 1000/1200 mg qd, 24 wks
Reddy, 1999 | RCT
| | IFN (Caucasians): alpha-2a, 3 mu or alphacon1, 9 mu tiw, 24 wks | 380 | 42 | | | | S4 3.16 | 132
| | | | 73.9 | | HAI | 7
| | | | | | | | | 1 | 2.11
| | | | | | | | | 1a | 37.89
| | | | | | | | | 1b | 26.05
| | | | | | | | | 2a | 3.95
| | | | | | | | | 2b | 12.11
| | | | | | | | | 3 | 3.95
| | | | | | | | | Other/mixed | 2.89
| | IFN (African Americans): alpha-2a, 3 mu or alphacon1, 9 mu tiw, 24 wks | 40 | 43 | | | | S4 12.5 | 116
| | | | 62.5 | | HAI | 6
| | | | | | | | | 1 | 2.50
| | | | | | | | | 1a | 52.50
| | | | | | | | | 1b | 32.50
| | | | | | | | | 2a | 10.00
| | | | | | | | | 2b | 2.50
| | | | | | | | | 3 | 0.00
| | | | | | | | | Other/mixed | 0.00
| | IFN (Hispanics): alpha-2a, 3 mu or alphacon1, 9 mu tiw, 24 wks | 40 | 45 | | | | S4 50.0 | 118
| | | | 70.0 | | HAI | 8
| | | | | | | | | 1 | 2.50
| | | | | | | | | 1a | 40.00
| | | | | | | | | 1b | 25.00
| | | | | | | | | 2a | 2.50
| | | | | | | | | 2b | 12.50
| | | | | | | | | 3 | 10.00
| | | | | | | | | other/mixed | 7.50
| | IFN (Asians): alpha-2a, 3 mu or alphacon1, 9 mu tiw, 24 wks | 10 | 50 | | | | S4 80.0 | 117
| | | | 70.0 | | HAI | 8
| | | | | | | | | 1 | 0.00
| | | | | | | | | 1a | 20.00
| | | | | | | | | 1b | 20.00
| | | | | | | | | 2a | 20.00
| | | | | | | | | 2b | 30.00
| | | | | | | | | 3 | 0.00
| | | | | | | | | other/mixed | 10.00
Subgroup: Hemophiliacs
Rumi, 1997 | RCT
| | IFN: alpha-2b, 3 mu tiw, 6 mos | 45 | 33
| | | | | | | | | 1a | 57.78
| | | | | | | | | 1b | 22.22
| | | | | | | | | 2 | 6.67
| | | | | | | | | 3 | 24.44
| | IFN: None | 50 | 34
| | | | | | | | | 1a | 38.00
| | | | | | | | | 1b | 18.00
| | | | | | | | | 2 | 18.00
| | | | | | | | | 3 | 28.00
Subgroup: HBV/HCV coinfection
Villa, 2001 | RTnc
| | IFN: 6 mu tiw, 6 mos | 14 | 34 | | HAI | A 1.9
| | | | 71.4 | | HAI | S 11.6
| | | | | | | | | 1a | 7.14
| | | | | | | | | 1b | 78.57
| | | | | | | | | 2a | 14.29
| | IFN: 9 mu tiw, 6 mos | 16 | 33 | | HAI | A 1.7
| | | | 75.0 | | HAI | S 11.9
| | | | | | | | | 1a | 31.25
| | | | | | | | | 1b | 43.75
| | | | | | | | | 2a | 25.00
Studies of interferon in nonresponders/relapsers
Bresci, 1996 | RCT
| | IFN: alpha-2b, 3 mu tiw, 6 mos | 30 | 46 | | | | S3, A2 70.7 | 120
| | | | 56.7 | | | | | 8
| | IFN: alpha-2b, 6 mu tiw, 6 mos | 30 | 50 | | | | S3, A2 76.7 | 140
| | | | 66.7 | | | | | 9
| | IFN: alphacon1, 3 mu tiw, 6 mos | 30 | 49 | | | | S3, A2 80.0 | 138
| | | | 53.3 | | | | | 7
| | IFN: natural IFN, 3 mu tiw, 6 mos | 30 | 47 | | | | S3, A2 73.3 | 136
| | | | 60.0 | | | | | 9
| | IFN: None | 30 | 48 | | | | S3, A2 76.7 | 146
| | | | 56.7 | | | | | 8
Chemello, 1997 | RCT
| | IFN: 3–6 mu tiw, 6–12 mos | 26 | 26
| | | | 88.5
| | | | | | | | | 1 | 88.46
| | | | | | | | | 2 | 88.46
| | | | | | | | | 3 | 0.00
| | IFN: 3–6 mu tiw, 6–12 mos | 66 | 46
| | | | 72.7
| | | | | | | | | 1 | 57.58
| | | | | | | | | 2 | 34.85
| | | | | | | | | 3 | 7.58
Gaeta, 1997 | RCT
| | IFN (initial): Leukocyte IFN, 3 – 6 mu tiw, 6 mos | 44 | 51.02 | | HAI | | 11.4
| | | | 61.4
| | IFN (maintenance): Leukocyte IFN, 3 – 6 mu tiw, 6 mos | | | | | | | 1a | 13.64
| | | | | | | | | 1b | 34.09
| | | | | | | | | 2a | 11.36
| | | | | | | | | 3 or 4 | 4.55
| | IFN (initial): Recombinant or lymphoblastoid IFN alpha, 3 – 6 mu, tiw, 12 mos | 25 | 47.2 | | HAI | | 24
| | | | 64.0
| | | | | | | | | 1a | 8.00
| | | | | | | | | 1b | 64.00
| | | | | | | | | 2a | 4.00
| | | | | | | | | 3 or 4 | 4.00
Heathcote, 1998 | RCT
| | IFN (Relapsers): alphacon1, 15 μg, tiw, 24 wks | 167 | 44.7
| | | | 74.3
| | | | | | | | | 1 | 70.06
| | IFN (Nonresponders): alphacon1, 15 μg, tiw, 24 wks | 167 | 44.7
| | | | 74.3
| | | | | | | | | 1 | 70.06
| | IFN (Relapsers): alphacon1, 15 μg, tiw, 48 wks | 170 | 44.3
| | | | 75.9
| | | | | | | | | 1 | 74.12
| | IFN (Nonresponders): alphacon1, 15 μg, tiw, 48 wks | 170 | 44.3
| | | | 75.9
| | | | | | | | | 1 | 74.12
Kagawa, 1998 | RCT
| | Early responders IFN (initial): alphacon1, 6 mu, qd, 4 wks | 30
| | Early responders IFN (maintenance): alphacon1, 6 mu tiw, 22 wks
| | IFN (initial): alphacon1, 6 mu, qd, 4 wks | 16
| | IFN (maintenance): alphacon1, 6 mu, tiw, 22 wks
| | IFN (initial): alphacon1, 6 mu, qd, 4 wks | 16
| | IFN (maintenance): alphacon1, 6 mu, tiw, 18 wks
Payen, 1998 | RCT
| | IFN: alpha-2b, 3 mu tiw, 6 mos | 75 | 45.6 | | HAI | 7.2
| | | | 92.0 | | | | | 8.83
| | | | C:98.6 | | | | | 1 | 5.33
| | | | | | | | | 1a | 10.67
| | | | | | | | | 1b | 28.00
| | | | | | | | | 2 | 13.33
| | | | | | | | | 3 | 16.00
| | | | | | | | | other | 8.00
| | IFN: alpha-2b, 3 mu tiw, 12 mos | 91 | 44.1 | | HAI | 7.6
| | | | 71.4 | | | | | 9.47
| | | | C:100 | | | | | 1 | 3.30
| | | | | | | | | 1a | 3.30
| | | | | | | | | 1b | 29.67
| | | | | | | | | 2 | 15.38
| | | | | | | | | 3 | 23.08
| | | | | | | | | Other | 5.49
| | IFN:alpha-2b, 10 mu tiw, 6 mos | 81 | 42.1 | | HAI | 8
| | | | 70.4 | | | | | 9.08
| | | | C:100 | | | | | 1 | 2.47
| | | | | | | | | 1a | 3.70
| | | | | | | | | 1b | 33.33
| | | | | | | | | 2 | 9.88
| | | | | | | | | 3 | 28.40
| | | | | | | | | other | 6.17
Poynard, 1999
| | IFN: alpha-2b, 3 mu tiw, 24 wks | 29 | 38 | | | | | 2.6
| | | | 62.1 | | | | | 2.92
| | | | | | | | | 1 | 48.28
| | | | | | | | | 2/3 | 37.93
| | | | | | | | | 4 | 13.79
| | IFN (initial): alpha-2b, 10 mu, 6 days a week, 2 wks | 29 | 39
| | | | 62.1 | | | | | 3.17
| | IFN (maintenance): alpha-2b, 10 mu, tiw, 12 wks | | | | | | | 1 | 51.72
| | | | | | | | | 2/3 | 37.93
| | | | | | | | | 4 | 6.90
Shiffman, 1999 | RCT
| | IFN: None | 27 | 48.8 | 22 | Kno | A 14.8
| | | | 51.9 | | Kno | S 3.4
| | | | C: 85.1, O: 14.8
| | IFN: alpha-2b, 5 mu tiw, 24 mos | 26 | 47.8 | 27 | Kno | A. 7.7
| | | | 57.7 | | Kno | S 1.8
| | | | C: 88.4, O: 11.5

Evidence Table 15. Methodologic quality of randomized controlled trials of current treatment options for selected subgroups of patients with chronic hepatitis C

Author, Year | Representativeness^a^ | Bias^b^ | Description^c^ | Outcomes^d^ | Statistics^e^ | Conflict^f^ | Total^g^
Studies of current treatment options in nonresponders/relapsers to prior therapy
Studies of nonresponders
Barbaro, 1999 | 100 | 83 | 50 | 80 | 100 | 0 | 83
Bresci, 2000 | 50 | 67 | 50 | 75 | 50 | 0 | 58
Di Bisceglie, 2001 | 75 | 67 | 50 | 85 | 67 | 50 | 69
Ferenci, 2001a | 63 | 17 | 50 | 70 | 38 | 0 | 47
Puoti, 2001 | 75 | 50 | 50 | 85 | 100 | 50 | 72
Saracco, 2001 | 88 | 83 | 100 | 70 | 88 | 0 | 86
Shiffman, 2000a | 100 | 100 | 100 | 60 | 83 | 50 | 89
Tripi, 2000 | 63 | 58 | 50 | 85 | 38 | 50 | 59
Studies of relapsers
Chapman, 2001 | 38 | 50 | 50 | 65 | 17 | 50 | 44
Di Marco, 2000 | 88 | 67 | 50 | 80 | 100 | 0 | 77
Enriquez, 2000 | 75 | 33 | 50 | 80 | 100 | 0 | 68
Studies of nonresponders and relapsers
Bonkovsky, 2001 | 88 | 83 | 100 | 80 | 50 | 100 | 80
Cavalletto, 2000 | 100 | 67 | 50 | 90 | 100 | 50 | 81
Min, 2001 | 100 | 50 | 75 | 80 | 83 | 50 | 78
Studies of interferon/amantadine combination therapy, with or without ribavirin
Studies of nonresponders
Brillanti, 2000 | 100 | 67 | 100 | 75 | 100 | 50 | 88
Gaeta, 2001 | 50 | 67 | 100 | 70 | 0 | 0 | 57
Teuber, 2001 | 75 | 92 | 75 | 85 | 83 | 0 | 82
Younossi, 2001 | 63 | 100 | 100 | 80 | 100 | 100 | 89
Studies of treatment outcomes in other subgroups
Subgroup: Renal
Campistol, 1999 | 33 | 67 | 75 | 65 | 100 | 0 | 68
Subgroup: Race/ethnicity
McHutchison, 2000 | 25 | 33 | 50 | 40 | 88 | 50 | 47
Reddy, 1999 | 38 | 75 | 75 | 80 | 63 | 50 | 66
Subgroup: Hemophiliacs
Rumi, 1997 | 75 | 58 | 100 | 90 | 75 | 0 | 80
Subgroup: HBV/HCV coinfection
Villa, 2001 | 88 | 83 | 75 | 35 | 67 | 100 | 70
Studies of interferon in nonresponders/relapsers
Bresci, 1996 | 88 | 50 | 50 | 70 | 67 | 0 | 65
Chemello, 1997 | 88 | 58 | 75 | 30 | 63 | 50 | 63
Gaeta, 1997 | 50 | 50 | 100 | 80 | 50 | 50 | 66
Heathcote, 1998 | 50 | 67 | 100 | 80 | 67 | 0 | 73
Kagawa, 1998 | 50 | 17 | 100 | 75 | 67 | 50 | 62
Payen, 1998 | 75 | 83 | 50 | 85 | 83 | 50 | 75
Poynard, 1999 | 63 | 83 | 75 | 65 | 83 | 50 | 74
Shiffman, 1999 | 63 | 67 | 50 | 75 | 83 | 50 | 68

a Representativeness: The total maximum for this section was 8 points. This included setting and population described and start and end date specified (2 points); detailed description of inclusion and exclusion criteria or statement that all potential trainees enrolled (2 points); information about excluded or not-participating patients (2 points); and description of key patient characteristics at enrollment (2 points).

b Bias and Confounding: The total maximum score was 6 points. This included whether assignment of patients to study groups was randomized (2 points); whether groups had any differences in key patient characteristics (2 points); and whether clinicians, patients, and outcome assessors were blinded (2 points).

c Description of Therapy/Management: The total maximum score was 4 points. This included sufficiently detailed description of the treatment regimen (2 points); and description of other treatments or tests given to subjects (2 points).

d Outcomes and Followup: The total maximum score was 10 points. This included description of complications, side effects and adverse reactions (2 points); sufficient description of criteria for determining outcomes (2 points); reporting on the numbers and reasons for withdrawals from the study or losses to followup (2 points); proportion of patients who withdrew from the study or were lost to followup (2 points); and sufficiency of the planned length of followup (2 points).

e Statistical Quality and Interpretation: The total maximum score was 8 points. This included whether magnitude of difference between groups and an index variability was stated (2 points); whether analyses and statistical tests were clearly identified (2 points); whether adjustment of potential confounders were multi-variate or stratified analyses and coding of confounders (2 points); and appropriate handling of crossovers and/or dropouts in the analysis (2 points).

f Conflict of Interest: The total maximum score was 2 points. This included whether the study reported the source of funding and the role played by the funding entity.

g Total Score is the mean of the percentage scores from the categories, Representativeness, Bias and Confounding, Description of Therapy/Management, Outcomes and Followup, and Statistical Quality and Interpretation.

Evidence Table 16. Results of randomized controlled trials of current treatment options for selected subgroups of patients with chronic hepatitis C

| | | Biochemical Response | | Viral Response | | Histological | Adverse Events
| | | ETR | SR | ETR | SR | Response | Disc/Withdr | Dose Red
Author, Year Follow-up | Study Groups | | % | % | % | % | % | % | %
Studies of current treatment options in nonresponders/relapsers to prior therapy
Studies of nonresponders
Barbaro, 1999 | A | IFN: beta IFN, 6 mu, 6 days/wk, 12 wks | | | 17 | | 65*^a^ | 2 | 24
10 mos. | B | IFN: alpha-2b, 6 mu tiw, 12 wks | | | 12 | | 35*^a^ | 3 | 7
| | RBV: 1000-1200 mg qd, 12 wks
Bresci, 2000 | A | IFN: 6 mu tiw, 6 mos | 20 | 14 | 38*^c^ | 8^c^ | | 24
12 mos. | | RBV: 1000-1200 mg qd, 6 mos
| B | IFN: 6 mu, bid, 6 mos | 16 | 15 | 12* ^c^ | 6^c^
Di Bisceglie, 2001 | A | IFN: alpha-2b, 3 mu tiw, 2 mos | 69 | 38 | 49 | 41 | | 17 | 17
6 mos. | | RBV: 1000-1200 mg qd, 2 mos
| B | IFN: alpha-2b, 3 mu tiw, 4 mos | 64 | 47 | 36 | 36 | | 26 | 23
| | RBV: 1000-1200 mg qd, 4 mos
Ferenci, 2001a | A | IFN (initial): alpha-2b, 5 mu tiw, 3 mos | 26* | 1.3 | 11* | 1.3 | | 22
6 mos. | | IFN (maintenance): alpha-2b, 10 mu tiw, 3 mos
| B | IFN (initial): alpha-2b, 5 mu tiw, 3 mos | 43* | 8.6 | 31* | 8.6 | | 21
| | IFN (maintenance): alpha-2b, 10 mu tiw, 3 mos
| | RBV: 1000-2000 ml, qd, 6 mos
Puoti, 2001 | A | IFN: alpha-2b, 3 mu tiw, 24 wks | 52 | 5 | 52 | 5*^†^ | | | 38
6 mos. | | RBV: 1000-1200 mg qd, 24 wks
| B | IFN: alpha-2b, 5 mu tiw, 24 wks | 52 | 10 | 52 | 10* | | | 38
| | RBV: 1000-1200 mg qd, 24 wks
| C | IFN: alpha-2b, 5 mu, qd, 24 wks | 70 | 38 | 70 | 38 | | | 43
| | RBV: 1000-1200 mg qd, 24 wks
Saracco, 2001 | A | IFN: alpha-2b, 3 mu tiw, 12 mos | 47 | 16 ^§^ | 25 ^§^ | 15 | | 12
6 mos. | | RBV: 1000 mg qd, 12 mos
| B | IFN: alpha-2b, 5 mu tiw, 12 mos | 55* | 30 ^R^ | 42 ^R^ | 23* | | 14
| | RBV: 1000 mg qd, 12 mos
| C | IFN: alpha-2b, 3 mu tiw, 6 mos | 37* | 14 ^§^ | 22 ^§^ | 11* | | 12
| | RBV: 1000 mg qd, 6 mos
| D | IFN: alpha-2b, 5 mu tiw, 6 mos | 49* | 17 | 26 ^§^ | 16 | | 13
| | RBV: 1000 mg qd, 6 mos
Shiffman, 2000a | A | IFN (initial): alpha-2b, 5 mu tiw, 3 mos | 6.3 | 0 | 0 | 0 | | 21
6 mos. | | IFN (maintenance): alpha-2b, 5 mu tiw, 3 mos
| B | IFN (initial): alpha-2b, 3 mu tiw, 3 mos | 74 | 38 | 26 | 14 | | 16.7
| | IFN (maintenance): alpha-2b, 5 mu tiw, 3 mos
| | RBV: 1000-1200 mg, divided dose, bid, 9 mos
| C | IFN: alpha-2b, 5 mu tiw, 6 mos | 72 | 30 | 30 | 12 | | 20
| | RBV: 1000-1200 mg, divided dose, bid, 9 mos
Tripi, 2000 | A | IFN: alpha, 6 mu tiw, 6 mos | 25 | 0 | 4.2* | 0
6 mos. | B | IFN: alpha, 6 mu tiw, 6 mos | 38 | 8.3 | 25* | 6.3 | | 6
| | RBV: 1200 mg qd, 6 mos
Studies of relapsers
Chapman, 2001 | A | IFN (initial): alpha-2a, 6 mu tiw, 6 mos | | 44 | 63 | 50 | | | 25
6 mos. | | IFN (maintenance): alpha-2a, 3 mu tiw, 6 mos | | | | | | | 19
| B | IFN: alpha-2a, 3 mu tiw, 6 mos | | 50 | 69 | 50
| | RBV: 1000 mg qd, 3 mos
Di Marco, 2000 | A | IFN: alpha-2b, 6 mu tiw, 6 mos | | | | 36* | | 12
6 mos. | | RBV: 1000-1200 mg, bid, 6 mos
| B | IFN: alpha-2b, 6 mu tiw, 12 mos | | | | 72* | | 16
| | RBV: 1000-1200 mg, bid, 12 mos
Enriquez, 2000 | A | IFN: alpha-2b, 3 mu tiw, 24 wks | | | 45 | 16* | | | 5
6 mos. | | RBV: 1000-1200 mg qd, 24 wks
| B | IFN: alpha-2b, 3 mu tiw, 48 wks | | | 47 | 37* | | | 3
| | RBV: 1000-1200 mg qd, 48 wks
Studies of both nonresponders and relapsers
Bonkovsky, 2001 | A | IFN: alpha-2b, 3mu tiw, 24 wks | 57 | 31 | 46 | 34 | | 11
| | RBV: 600 mg qd, 24 wks
| B | IFN: alpha-2b, 3 mu tiw, 24 wks | 53 | 26.5 | 53 | 35 | | 9
| | RBV: 1000-1200 mg qd, 24 wks
Cavalletto, 2000 | A | IFN (initial): natural IFN, 6 mu tiw, 2 mos | | | | 10
6 mos. | | IFN (maintenance): natural IFN, 3 mu tiw, 6 mos
| B | IFN (initial): natural IFN, 6 mu tiw, 2 mos | | | | 24
| | IFN (maintenance): natural IFN, 3 mu tiw, 6 mos
| | RBV: 1000-1200 mg qd, 6 mos
Min, 2001 | A | IFN: alpha-2b, 2 mu tiw, 12 mos | | | 28 | 14 | | 12.3
6 mos. | | RBV: 1000-1200 mg, bid, 12 mos
| B | IFN: alpha-2b, 5 mu tiw, 12 mos | | | 29 | 22 | | 21.9
| | RBV: 1000-1200 mg, bid, 12 mos
Studies of interferon combination therapy with amantadine, with or without ribavirin
Studies of nonresponders
Brillanti, 2000 | A | IFN: alpha-2b, 5 mu tiw, 12 mos | 20* | 10* | 10* | 5* | | 0
6 mos. | | RBV: 800 - 1000 mg qd, 12 mos
| B | Amantidine: 200 mg qd, 12 mos | 78* | 58* | 68* | 48* | | 0
| | IFN: alpha-2b, 5 mu tiw, 12 mos
| | RBV: 800 - 1000 mg qd, 12 mos
Gaeta, 2001 | A | Amanitidine (initial): 100 mg, bid, 4 wks | 29 | | 0 | | | 4.8
6 mos. | | Amanitidine (maintenance): 100 mg, bid, 5 mos
| | IFN (initial): alpha-2a, 4.5 mu, qd, 4 wks
| | IFN (maintenance): alpha-2a, 6 mu tiw, 5 mos
| B | IFN (initial): alpha-2a, 4.5 mu, qd, 4 wks | 16 | | 0 | | | 16
| | IFN (maintenance): alpha-2a, 6 mu tiw, 5 mos
Teuber, 2001 | A | Amantadine: 100 mg, bid, 48 wks | 19 | 4 | 4 | 0
| | IFN (initial): alpha-2a, 6 mu tiw, 24 wks
| | IFN (maintenance): alpha-2a, 6 mu tiw, 24 wks
| B | Amantadine: Placebo | 28 | 14 | 14 | 7
| | IFN (initial): alpha-2a, 6 mu tiw, 24 wks
| | IFN (maintenance): alpha-2a, 6 mu tiw, 24 wks
Younossi, 2001 | A | IFN: alpha-2b, 3 mu tiw, 24 wks | 56.7 | 12.1 | 34.8 | 3.9 | | 20
6 mos. | | RBV: 800 mg qd, 24 wks
| B | Amantidine: 200 mg qd, 24 wks | 47.1 | 7.8 | 19.6 | 0 | | 17
| | IFN: alpha-2b, 3 mu tiw, 24 wks
Subgroup: Renal
Campistol, 1999 | A | IFN: alpha-2b, 3 mu tiw, 6 mos | | | 58 | 26 | | 53
24 mos. | B | IFN: None | | | 6
Subgroup: Race/ethnicity
McHutchison, 2000 | A | IFN (210 pts): alpha-2b, 3 mu tiw, 24 wks | | | | 27*
6 mos. | | IFN (461 pts): alpha-2b, 3 mu tiw, 24 wks
| | IFN (464 pts): alpha-2b, 3 mu tiw, 48 wks
| | IFN (465 pts): alpha-2b, 3 mu tiw, 48 wks
| | RBV (461 pts): 1000-1200 mg qd, 24 wks
| | RBV (464 pts): 1000-1200 mg qd, 48 wks
| B | IFN (12 pts): alpha-2b, 3 mu tiw, 24 wks | | | | 11*
| | IFN (15 pts): alpha-2b, 3 mu tiw, 24 wks
| | IFN (13 pts): alpha-2b, 3 mu tiw, 48 wks
| | IFN (13 pts): alpha-2b, 3 mu tiw, 48 wks
| | RBV (13 pts): 1000-1200 mg qd, 24 wks
| | RBV (7 pts): 1000-1200 mg qd, 48 wks
| C | IFN (1 pt): alpha-2b, 3 mu tiw, 24 wks | | | | 44
| | IFN (13 pts): alpha-2b, 3 mu tiw, 24 wks
| | IFN (6 pts): alpha-2b, 3 mu tiw, 48 wks
| | IFN (7 pts): alpha-2b, 3 mu tiw, 48 wks
| | RBV (13 pts): 1000-1200 mg qd, 24 wks
| | RBV (7 pts): 1000-1200 mg qd, 48 wks
| D | IFN (7 pts): alpha-2b, 3 mu tiw, 24 wks | | | | 16
| | IFN (8 pts): alpha-2b, 3 mu tiw, 24 wks
| | IFN (12 pts): alpha-2b, 3 mu tiw, 48 wks
| | IFN (5 pts): alpha-2b, 3 mu tiw, 48 wks
| | RBV (8 pts): 1000-1200 mg qd, 24 wks
| | RBV (12 pts): 1000-1200 mg qd, 48 wks
Reddy, 1999 | A | IFN (Caucasians): alpha, tiw, 24 wks | 44* | 22* | 33* | 12 | | 4 | 16
6 mos. | B | IFN (African Americans): alpha, tiw, 24 wks | 12.5* | 8* | 5* | 2.5 | | 12 | 18
| C | IFN (Hispanics): alpha, tiw, 24 wks | 25 | 10 | 28 | 10 | | 8 | 18
| D | IFN (Asians): alpha, tiw, 24 wks | 40 | 30 | 40 | 30 | | 10 | 20
Subgroup: Hemophiliacs
Rumi, 1997 | A | IFN: alpha-2b, 3 mu tiw, 6 mos | | 26^c^ | | 13^c^
12 mos. | B | IFN: None | | 0^c^ | | 0^c^
Subgroup: HBV/HCV coinfection
Villa, 2001 | A | IFN: 6 mu tiw, 6 mos | 64 | | 86
| B | IFN: 9 mu tiw, 6 mos | 81 | | 75
Studies of interferon in nonresponders/relapsers
Bresci, 1996 | A | IFN: alpha-2b, 3 mu tiw, 6 mos | 16.7 | 7.7 | 7.7^c^ | 3.3^c^
6 mos. | B | IFN: alpha-2b, 6 mu tiw, 6 mos | 30 | 10 | 16.7^c^ | 7.7^c^
| C | IFN: alphacon1, 3 mu tiw, 6 mos | 20 | 7.7 | 10^c^ | 3.3^c^
| D | IFN: natural IFN, 3 mu tiw, 6 mos | 23 | 7.7 | 10^c^ | 3.3^c^
| E | IFN: None | 10 | 10 | 0^c^ | 0^c^
Chemello, 1997 | A | IFN: 3-6 mu tiw, 6-12 mos | 8 | 0 | 0 | 0
| B | IFN: 3-6 mu tiw, 6-12 mos | 42 | 20 | 23 | 20
Gaeta, 1997 | A | IFN (initial): alpha, 3 - 6 mu tiw, 6 mos | 30* | 23* | 14 | 6.8
12 mos. | | IFN (maintenance): alpha, 3 - 6 mu tiw, 6 mos
| B | IFN: alpha, 3 - 6 mu tiw, 12 mos | 0* | 0* | 0 | 0
Heathcote, 1998 | A | IFN (Relapsers): alphacon1, 15 ug, tiw, 24 wks | 88 | 39 | 72 | 28
6 mos. | B | IFN (Nonresponders): alphacon1, 15 ug, tiw, 24 wks | 26 | 12 | 19 | 5
| C | IFN (Relapsers): alphacon1, 15 ug, tiw, 48 wks | 76 | 52 | 76 | 58
| D | IFN (Nonresponders): alphacon1, 15 ug, tiw, 48 wks | 25 | 17 | 17 | 13
Kagawa, 1998 | A | Early responders IFN (initial): alphacon1, 6 mu, qd, 4 wks | | 67 | 80 | 63 ^R^
6 mos. | | Early responders IFN (maintenance): alphacon1, 6 mu tiw, 22 wks
| B | IFN (initial): alphacon1, 6 mu, qd, 4 wks | | 13 | 25 | 6 ^§^ | | 12.5
| | IFN (maintenance): alphacon1, 6 mu tiw, 22 wks
| C | IFN (initial): alphacon1, 6 mu, qd, 4 wks | | 6 | 44 | 0 ^§^ | | 6.25
| | IFN (maintenance): alphacon1, 6 mu tiw, 18 wks
Payen, 1998 | A | IFN: alpha-2b, 3 mu tiw, 6 mos | 71 | 12 ^§^ | 44 ^§^ | 11 ^§^ | 46^a^ | | 14
6 mos. | B | IFN: alpha-2b, 3 mu tiw, 12 mos | 69 | 36 ^R^ | 43 ^§^ | 24 ^R^ | 57^a^ | | 38.5
| C | IFN: alpha-2b, 10 mu tiw, 6 mos | 84 | 19 ^§^ | 60 ^R^ | 14 ^§^ | 38^a^ | | 30.8
Poynard, 1999 | A | IFN: alpha-2b, 3 mu tiw, 24 wks | 86 | 17 | 38 | 14 | 28* | 21
11 mos. | B | IFN (initial): alpha-2b, 10 mu, 6 days a wk, 2 wks | 79 | 6.9 | 28 | 0 | 6.9* | 14
| | IFN (maintenance): alpha-2b, 10 mu tiw, 12 wks
Shiffman, 1999 | A | IFN: Placebo | 41 | | 3.7 | | 37*
36 mos. | B | IFN: alpha-2b, 5 mu tiw, 24 mos | 62 | | 23 | | 62*

a Percentage based on a denominator different from the group N

c Complete response, defined as combined virological and biochemical response

* p < 0.05 for the pairwise comparison between two groups marked with this symbol

† p < 0.05 for the pairwise comparison between two groups marked with this symbol

R p < 0.05 for the comparison groups marked with this symbol and the group marked

R Reference group for comparison

Evidence Table 17. Overall summary of long-term outcomes of chronic hepatitis C

Author, Year | Location | N | Cohort Source | Inclusion Criteria | Exclusion Criteria | Study Aims
Randomized controlled trials
Bernardinello, 1999 | Italy | 61 | Tertiary care | IFN monotherapy, presence of nodules on bx, presence of fibrosis: >= 2 regenerative nodules on bx, age 18-65 yrs | Plts <50,000, WBC <2000, Child's C, portal hypertension, renal dysfunction, thyroid disease, immune suppression, decompensated liver disease, EtOH >80 g/d | To find the short- and long term effects of IFN tx in pts w/ CHC w/ a long-term follow-up of 5 yrs.
Chemello, 1999 | Italy | 157 | Unclear | ALT 2x UL nl for 6 mo prior to randomization, initial liver bx showing chronic liver disease, detectable HCV in serum, age 18-60 yrs | Thyroid disease, active EtOH, IDU, pregnancy, immune suppression, other causes of liver disease, plts <100,000, portal hypertension, ascites, varices, IFN monotherapy, WBC <3000, hematologic comorbidity: cytopenia | A 5 yr followup of a RCT comparing daily and tiw human leukocyte IFN alpha induction in CHC, followed by 3 mu IFN alpha tiw for 3 mos
Nishiguchi, 2001 | Japan | 90 | Tertiary care | Abnl ALT for >1 yr, presence of cirrhosis, detectable HCV in serum | Plts<50,000, liver disease of any other etiology, HIV+, immune suppression: excluded for autoimmune hepatitis, HCC, HBV+, EtOH | To assess Child-Pugh progression, mortality, and HCC at long-term followup of 8 yrs after IFN tx alpha in HCV infected cirrhotic pts.
Long-term outcomes of treatment
Aizawa, 2000 | Japan | 153 | Tertiary care | ALT 2xUL nl, initial liver bx, HCV+ | HBV+ | Long-term observation of pts w/ CHC to elucidate the incidence of HCC and the factors that predict HCC.
Benvegnu, 1997 | Italy | 429 | Tertiary care | Presence of cirrhosis, detectable HCV in serum, HCV+ | Autoimmune or metabolic liver disease, HCC, HBV+, excessive EtOH | To investigate the relationship between HCV genotype and the natural course of HCV, its complications, and development of HCC in cirrhotic pts
Bruno, 1997 | Milan, Italy | 163 | Tertiary care | Presence of cirrhosis, HCV+, presence of fibrosis | IFN, HCC, Child's C, hemochromatosis, autoimmune hepatitis, sclerosing cholangitis, age >70 yrs, ALT >400 | To prospectively follow a cohort of HCV pts w/ cirrhosis and evaluate if the HCV genotype impacts the development of HCC. In addition, the aim was to elicit other independent risk factors for HCC
Fattovich, 1997 | Italy. France, United Kingdom | 329 | Tertiary care | ALT 1.5x UL of nl for 6 mo, compensated cirrhosis, presence of cirrhosis, HCV+ | Ascites, varices, encephalopathy, jaundice, any other potential cause of chronic liver disease, HCC, HBV+ | To evaluate the role of IFN alpha in preventing the development of HCC or decompensation in a cohort of Caucasian pts w/ compensated cirrhosis.
Horiike, 1998 | Japan | 88 | Unclear | | | To elucidate the effect of IFN therapy on the subsequent development of HCC in pts w/ CHC.
Ikeda, 2001 | Japan | 694 | Tertiary care | Presence of cirrhosis, detectable HCV in serum, HCV+ | Aggressive CHC, subacute hepatitis, HIV+ | To elucidate whether IFN suppresses the rate of carcinogenesis in pts w/ HCV cirrhosis; To show the role of IFN in cancer presentation in liver cirrhosis type C. 1) To what extent could IFN decrease the carcinogenesis rate from HCV-related cirrhosis. 2) To explore the effective tx by using IFN therapy in prevention
Inoue, 2000 | Japan | 923 | Tertiary care | Positive HCV antibodies | Presence of cirrhosis, HBV+ | To evaluate whether IFN reduces the incidence of HCC
Shibata, 1998 | Japan | 242 | Tertiary care | AFP <2x nl, HCV+ | Inadequate liver samples for histological assessment, presence of cirrhosis, presence of fibrosis, HCC, hepatitis A or HBV | To determine if irregular regeneration of hepatocytes is a risk factor for HCC in pts w/ chronic hepatitis or cirrhosis of the liver caused by the HCV
Shindo, 2001 | Japan | 250 | Community based | ALT 1.5x UL of nl for 6 mo, CHC on initial liver bx, detectable HCV in serum, HCV+ | Refusal to take IFN, other forms of liver disease, presence of cirrhosis, HBV+, EtOH | To study the impact of long- term biochemical response to IFN in pts who did not have serum viral response, and to determine their clinical characteristics and long-term outcomes of cirrhosis and HCC
Tanaka, 2000 | Japan | 726 | Tertiary care | HCV+: 1st or 2nd generation ELISA, reside in Osaka Prefecture at time of dx of HCV | HBV+ at initial dx of HCV | To study the effects of IFN on long-term outcome of pts w/ CHC namely on incidence of HCC
Toyoda, 2001 | Japan | 291 | Community based | All Pts treated w/varied doses but only nonresponders were included, relapse after previous therapy, detectable HCV in serum, HCV+ | Presence of cirrhosis, presence of fibrosis, HBV+ | To evaluate the effects of dose and duration of IFN tx on rates of HCC in pts w/ non-sustained response to tx. The pts are non-cirrhotics.
Yabuuchi, 2000 | Japan | 419 | Tertiary care | Initial liver bx | Serious illness, immune suppression, pregnancy, HBV+ | To determine the characteristics of pts w/ CHC showing long-term normal- ization in ALT levels but not viral eradication. Also, the study investigated the incidence of HCC in these pts
Yatsuhashi, 2000 | Japan | 186 | Tertiary care | ALT el for 6 mos, initial liver bx showing CHC, detectable HCV in serum, positive HCV | Afp>400, U/S if evidence of HCC, HCC, presence of cirrhosis, presence of fibrosis, HBV+, daily EtOH >80 g/d for 5 yrs | To measure the natural history outcome in incidence of HCC of HCV in 186 individuals.
Long-term studies of natural history
Barrett, 2001 | Ireland | 155 | Community based | Detectable HCV in serum, HCV+ | Mode of transmission: anti-D immunoglobulin in 1997, HCV genotype 1b, female | To study the natural history of HCV in a cohort of women w/ either chronic infection or spontaneous self-limited infection. Histology, symptomatology, psychosocial impact, and extrahepatic manifestations of HCV, and HLA class II associations evaluated.
Benhamou, 2001 | France | | Tertiary care | HCV+, detectable HCV in serum, presence of fibrosis/cirrhosis, HIV+, antiretroviral therapy for HIV | HBV+, immune suppression, doubtful compliance with antiretroviral therapy | To analyze the impact of different retroviral agents, including protease inhibitor therapy on HCV related liver fibrosis in HIV/HCV coinfected pts
Chiaramonte, 1999 | Italy | 259 | Tertiary care | Presence of cirrhosis, HBV+, HCV+ | Wilson's disease, hemochromatosis, alcoholic liver disease, <12-mo f/u, immune suppression, HCC, decompensated liver disease | To prospectively assess the incidence of HCC in pts w/ HBV, HCV, or both w/ Child's Grade A viral cirrhosis
Cottone, 1994 | Italy | 147 | Unclear | Age > 40 yrs, Child's A cirrhosis | | To determine the risk of HCC in Child's A cirrhosis, whether 6 mos screening interval is adequate, and determine the role of AFP in screening
Forns, 2001 | Spain | 116 | Unclear | ALT el for 6 mos, histopathologic dx of HCV | Negative anti-HCV during f/u, Wilson’s disease, autoimmune hepatitis, anti-smooth muscle antibody 1:100, antinuclear antibody 1:100, decompensated liver disease, HBV+, EtOH >40 g/d | To analyze the long-term outcome of a large cohort of Spanish pts w/ CHC followed for more than 20 yrs to identify risk factors associated w/ progression of the disease
Furusyo, 2000 | Japan | | Community based | ALT, plt count, AST, GGT, Serum HA, serum type IV collagen | Current IFN, anti-retroviral therapy for HIV, lamivudine for HBV | To evaluate the liver damage of hemodialysis pts w/ HCV viremia through ALT and markers of hepatic fibrogenesis
Gentilini, 1997 | Italy | 405 | Unclear | Abdominal U/S, presence of cirrhosis, initial liver bx, prothrombin, upper Cl endoscopy, ALT, plts, Bili, Alb, GGT | EtOH, pulmonary or metabolic disorder, HBV+, decompensated liver disease: portal hypertension, renal insufficiency | To examine the natural history of HBV and HCV in cirrhotics w/o portal hypertension
Harris, 2002 | United kingdom | 1400 | Community based | | Dates of counseling not clear, transfused after blood tested for HCV, not flagged in NHS central register, any other exposure to blood products, IDU | To determine the clinical course of HCV infection in the first decade of infection in a group of pts who acquired their infections on a known date
Hayashi, 2000 | Japan | 274 | Community based | ALT nl, AFP yearly 1994-1998, U/S yearly 1994-1998,HCV+,HCV genotype | HBV+ | To clarify the mechanism of liver damage induced by HCV and whether it is related to HCC
Ikeda, 1993 | Japan | 795 | Unclear | Presence of fibrosis/cirrhosis | HCC, idiopathic portal hypertension, Budd-Chiari syndrome, subacute hepatitis, chronic aggressive hepatitis w/ severe bridging necrosis, types of cirrhosis other than viral or alcoholic | To examine the incidence of HCC and explore risk factors for HCC in pts w/ cirrhosis, focusing on the difference between HCV and HBV
Kliem, 1996 | Germany | 162 | Tertiary care | Seen on 4-12 occasions/y, immune suppression: kidney transplant, HCV+ | HCC, HBV+ | To determine the impact of CHC on morbidity and mortality after kidney transplantation.
Kobayashi, 1996 | Japan | 136 | Tertiary care | Histological assessment: examination >= 5 yrs after initial examination, abnl ALT 3 times in 6 mos prior to tx, age 18-60 yrs | Therapy: antiviral or immunosuppressive agents during f/u, complications that would affect prognosis, HIV+ HBV+, EtOH >80 g/d | To assess if the long-term histological outcome differs between HCV genotypes 1 and 2
Kobayashi, 2000 | Japan | 61 | Unclear | Initial liver bx, IFN monotherapy for 6 mos, positive HCV antibodies | | To assess the correlation between serial changes in ALT levels and histological outcome 5 yrs after tx of pts w/ CHC w/ IFN for 6 mos.
Lesens, 1999 | Canada | | Tertiary care | Detectable HCV in serum | | To determine if HCV behaves like an opportunistic infection in which progressive liver failure is primary manifestation in HCV/HIV coinfected pts
Matsumura, 2000 | Japan | 527 | Tertiary care | Detectable HCV in serum positive HCV antibodies | Nl ALT, immune suppression HBV+ | To study the progression of HCV in 527 pts as compared by genotypes
Meijer, 1999 | Netherlands | 45 | Tertiary care | Detectable HCV in serum | Other liver disease, HIV+, HBV+ | To elucidate the natural history of HCV in HIV negative pts w/coagulation disorders.
Murakami, 1999 | Japan | 357 | Tertiary care | Transfusion, ALT abnl >6 mos, no history of antiviral therapy HCV+, detectable HCV in serum | Autoimmune hepatitis, multiple transfusion, HBV+, tattoo, GI comorbidity: primary biliary cirrhosis, IDU, metabolic liver disease, drug-induced hepatitis, IFN monotherapy, no history of induced hepatitis, EtOH >= 80 g/d for >= 3 yrs | To identify factors related to the development of cirrhosis and HCC in pts w/ HCV and w/ a history of transfusion.
Persico, 2000 | Italy | 37 | Tertiary care | ALT persistently nl >=3 times during the year, initial liver bx no signs or symptoms of chronic liver disease, HCV+ | Decompensated liver disease, presence of fibrosis, HBV+,IDU | Prospectively evaluate progression of disease in a group of HCV+ pts w/ persistently nl ALT levels.
Punyagupta, 1999 | Thailand | 63 | Tertiary care | | | To assess long-term outcomes (5–15 yrs) of HCV pts in Thailand
Rodger, 1999 | Australia | 105 | Tertiary care | | No obtainable medical record, <16 yrs | To evaluate rates of HCC, cirrhosis and death in a cohort of HCV+ pts after 25 yrs.
Rostaing, 1996 | France | 31 | Tertiary care | Azathioprine, CSA, renal transplant, duration of HCV+ <10 yrs, HCV+ | | To determine whether immune suppression for renal transplant affects liver histology in pts w/ CHC
Takano, 1995 | Japan | 351 | Tertiary care | Histological dx of CPH or CAH, initial liver bx, AFP w/i nl range, reside w/i 1 hr commute for > 5 yrs and had already been followed >= 5 years | Presence of fibrosis/cirrhosis, decompensated liver disease, HCC at time of initial bx, concurrent HCV & HBV | To compare the incidence of HCC in pts w/ CHC vs. chronic HBV
Thomas, 2000 | United States | 1667 | Community based | HCV+, IDU, age >17 yrs | HIV+ | To assess the natural history and frequency of end stage liver disease and viral clearance in a cohort of persons infected w/ HCV secondary to intravenous drugs.
Yano, 1996 | Japan | 70 | Unclear | Initial liver bx, HCV+ | Any previous therapy, immune suppression, presence of cirrhosis, HBV+, habitual heavy EtOH | To study the pathological evolution of chronic HCV hepatitis over time

Evidence Table 18. Characteristics of patients in studies evaluating long-term outcomes of chronic hepatitis C

Author, Year | Study Design | Study Groups | N | Mean age % Male Race | % w/Cirrhosis | Scoring System | Mean Activity (A) Fibrosis (S) | % w/Score Activity (A) Fibrosis (S) | Mean ALT (U/L) Mean yrs w/HCV HCV genotype (%)
Randomized controlled trials
Bernardinello, 1999 | RCT
| | IFN (initial): beta IFN, 6 mu tiw, 6 mos | 38 | 56
| | | | 50
| | IFN (maintenance): beta IFN, 3 mu, tiw, 6 mos | | | | | | | 1 | 76.32
| | | | | | | | | 2 | 23.68
| | | | | | | | | 3 | 0.00
| | IFN (initial): None | 23 | 58
| | IFN (maintenance): | | 61
| | | | | | | | | 1 | 69.57
| | | | | | | | | 2 | 26.09
| | | | | | | | | 3 | 4.35
Chemello, 1999 | RCT
| | IFN (maintenance): 3 mu tiw, 6 mos | 108 | 48 | | | | S1–S2 25.9 | 242
| | | | 58 | | | | S3 49.1 | 9.92
| | | | | | | | S4 17.6 | 1 | 48.15
| | | | | | | | | 2 | 24.07
| | | | | | | | | 3 | 13.89
| | | | | | | | | undetermined | 6.48
| | IFN (initial): 3 mu, qd, 3 mos | 49 | 19 | | | | S1–S2 20.4 | 204
| | IFN (maintenance): 3 mu tiw, 3 mos | | 73 | | | | S3 67.3 | 9.83
| | | | | | | | S4 12.2 | 1 | 59.18
| | | | | | | | | 2 | 20.41
| | | | | | | | | 3 | 10.20
| | | | | | | | | undetermined | 10.20
Nishiguchi, 2001 | RCT
| | IFN (maintenance): Usual care | 45 | 57.3 | | HAI | T11.8 | | 100
| | | | 51
| | | | | | | | | 1 | 0.00
| | | | | | | | | 2 | 73.33
| | | | | | | | | 3 | 17.78
| | | | | | | | | 4 | 8.89
| | IFN (maintenance): 6 mu tiw, 24 wks | 45 | 54.7 | | HAI | T11.7 | | 117
| | | | 62
| | | | | | | | | 1 | 2.22
| | | | | | | | | 2 | 77.78
| | | | | | | | | 3 | 13.33
| | | | | | | | | 4 | 6.67
Long-term outcomes of treatment
Aizawa, 2000 | CohR
| | | 153 | 48.3 | | Des | | A1 42.5
| | | | 75 | | Des | | A1–A2 86.3
| | | | | | Des | | A2–A3 57.5
| | | | | | Des | | A3 13.7
| | | | | | Des | | S1 22.9
| | | | | | Des | | S2 29.4
| | | | | | Des | | S3 24.8
| | | | | | Des | | S4 22.9
Benvegnu, 1997 | Coh?
| | | 62 | 57.3 | | | | S4, A3 14.5
| | | | 29
| | | 194 | 57 | | | | S4, A3 45.2
| | | | 15
| | | 133 | 60.2 | | | | S4, A3 31.0
| | | | 11
| | | 34 | 1 | | | | S4, A3 7.9
| | | | 3
| | | 6 | 55 | | | | S4, A3 1.4
| | | | 50
Bruno, 1997 | CohP
| | IFN (initial): IFN-alpha; Only 82/163 patients elected to go through treatment, 6 mu tiw, 6 mos | 163 | 57.8
| | | | 50
| | IFN (maintenance): | | | | | | | 1a | 0.61
| | IFN-alpha; Only patients who responded to the initial 6 mo regimen went through the maintenance phase, 3 mu tiw, 6 mos | | | | | | | 1b | 61.96
| | | | | | | | | 2a/c | 29.45
| | | | | | | | | 3a | 1.23
| | | | | | | | | mixed | 1.84
| | | | | | | | | Not specified | 4.91
Fattovich, 1997 | CohR
| | IFN (maintenance): | 193 | 57
| | | 136 | 53
Horiike, 1998 | CohR
| | | 33 | 48.3 | | HAI | | S1 81.8
| | | | 64 | | HAI | | S2 9.1
| | | | | | HAI | | S3 9.1 | 1 | 33.33
| | | | | | | | | 1/2 | 9.09
| | | | | | | | | 2 | 57.58
| | | 55 | 48.7 | | HAI | | S1 54.5
| | | | 73 | | HAI | | S2 16.4
| | | | | | HAI | | S3 29.1 | 1 | 72.73
| | | | | | | | | 1/2 | 3.64
| | | | | | | | | 2 | 23.64
| | | 61 | 45.7 | | HAI | | S1 47.5
| | | | 70 | | HAI | | S2 29.5
| | | | | | HAI | | S3 23.0 | 1 | 45.90
| | | | | | | | | 1/2 | 0.00
| | | | | | | | | 2 | 16.39
Ikeda, 2001 | CohR
| | IFN (maintenance): None | 581 | 58 | | | | | 53
| | | | 62
| | | | | | | | | 1 | 57.31
| | | | | | | | | 2 | 14.29
| | | | | | | | | other | 3.61
| | IFN (maintenance): Usual care, 3–6 mu, <12 mos | 88 | 51 | | | | | 71
| | | | 75
| | | | | | | | | 1 | 46.59
| | | | | | | | | 2 | 48.86
| | | | | | | | | other | 0.00
| | IFN (maintenance): Usual care, 3–6 mu, >/= 12 mos | 25 | 25 | | | | | 62
| | | | 72
| | | | | | | | | 1 | 76.00
| | | | | | | | | 2 | 20.00
| | | | | | | | | other | 4.00
Inoue, 2000 | CohR
| | IFN (maintenance): Not specified | 224
| | | | 70
| | IFN (maintenance): No treatment | 699
| | | | 56
Shibata, 1998 | CohP
| | | 179 | 52.6
| | | | 61
| | | 63 | 54.1
| | | | 60
| | | | A: 100
Shindo, 2001 | CohR
| | | 67 | 48 | | HAI | A 1.5 | | 137
| | | | 46 | | HAI | S 8.4
| | | | | | | | | 1b | 56.72
| | | | | | | | | non-1b | 43.28
| | | 26 | 55 | | HAI | S 8.3 | | 106
| | | | 77
| | | | | | | | | 1b | 73.08
| | | | | | | | | non-1b | 26.92
| | | 70 | 46 | | HAI | A 1.5 | | 127
| | | | 76 | | HAI | S 7.5
| | | | | | | | | 1b | 91.43
| | | | | | | | | non-1b | 8.57
| | | 87 | 54 | | HAI | A 1.5 | | 166
| | | | 54 | | HAI | S 10.0
| | | | | | | | | 1b | 91.95
| | | | | | | | | non-1b | 8.05
| | | 89 | 51 | | HAI | A 1.6 | | 97
| | | | | | HAI | A 2.3
| | | | | | HAI | S 7.5 | | 1b
| | | | | | | | | non-1b
Tanaka, 2000 | CohR
| | IFN tx groups | 134 | 52.2
| | | | 70
| | | | | | | | | 1 | 58.96
| | | | | | | | | 2 | 8.21
| | | | | | | | | not available | 40.30
| | Control | 594 | 51.7
| | | | 69
| | | | | | | | | 1 | 70.03
| | | | | | | | | 2 | 23.74
| | | | | | | | | not available | 6.23
Toyoda, 2001 | CohR
| | IFN (initial): natural IFN, >500 mu, | 183 | 49.9 | | HAI/Des | | S0–S1 61.2
| | | | 63 | | HAI/Des | | S2 27.9
| | | | | | HAI/Des | | S3 10.9 | 1b | 68.31
| | | | | | | | | 2a | 23.50
| | | | | | | | | 2b | 7.10
| | | | | | | | | mixed | 1.09
| | IFN (initial): natural IFN, <500 mu, | 108 | 51.6 | | HAI/Des | | S0–S1 56.5
| | | | 61 | | HAI/Des | | S2 29.6
| | | | | | HAI/Des | | S3 13.9 | 1b | 74.07
| | | | | | | | | 2a | 20.37
| | | | | | | | | 2b | 5.56
| | | | | | | | | mixed | 0.00
Yabuuchi, 2000 | CohR
| | | 126 | 50.8 | | HAI | | S1 38.1
| | | | 71 | | HAI | | S2 33.3
| | | | | | HAI | | S3/S4 28.6
| | | 49 | 52.6 | | HAI | | S1 51.0
| | | | 59 | | HAI | | S2 30.6
| | | | | | HAI | | S3/S4 18.4
| | | 244 | 53.8 | | HAI | | S1 24.6
| | | | 66 | | HAI | | S2 32.0
| | | | | | HAI | | S3/S4 43.4
Yatsuhashi, 2000 | CohP
| | | 186 | 46 | | HAI | | A1 28.0
| | | | 75 | | HAI | | A2 47.8
| | | | | | HAI | | A3 24.2
| | | | | | HAI | | S0 29.0
| | | | | | HAI | | S1 38.2
| | | | | | HAI | | S2 19.9
| | | | | | HAI | | S3 18.3
Long-term studies of natural history
Barrett, 2001 | CohP
| | | 87 | 45.7 | | HAI | A 4.1
| | | | 0 | | HAI | S 1.1 | | 23
| | | | O: 100 | | | | | 1b | 100.00
| | | 68 | 45.8 | | HAI | A 2.1
| | | | 0 | | HAI | S 0.2 | | 23
| | | | O: 100 | | | | | 1b | 100.00
Benhamou, 2001 | CohR
| | | 63 | 37.7
| | | | 60 | | | | | 16.62
| | | | | | | | | 1 | 23.81
| | | 77 | 36.3
| | | | 100 | | | | | 14.05
| | | | | | | | | 1 | 33.77
Chiaramonte, 1999 | CohP
| | | 66 | 44.8
| | | | 76
| | | 166 | 55.5
| | | | 52
| | | 27 | 48.8
| | | | 81
Cottone, 1994 | CohP
| | | 147 | 58
| | | | 55
Forns, 2001 | CohR
| | | 116 | 42.9 | | | | | | 161
| | | | 59
Furusyo, 2000 | CohP
| | | 80
| | | | | | | | | 7.7
| | | | | | | | | 1b | 81.25
| | | | | | | | | 2a | 13.75
| | | | | | | | | 2b | 2.50
| | | | | | | | | undetermined | 2.50
| | | 153
| | | | | | | | | 3.4
| | | 228
| | | | | | | | | 1b | 88.60
| | | | | | | | | 2a | 9.65
| | | | | | | | | 2b | 1.75
Gentilini, 1997 | CohP
| | | 405 | 54 | 100
| | | | 58
Harris, 2002 | CohR
| | | 925 | 43.6 | 4
| | | | 48
| | | | C: 84.6,
| | | | O: 14.5
| | | 475 | 41.5
| | | | 47
| | | | C: 68.4,
| | | | O: 31.5
Hayashi, 2000 | CohP
| | | 102
| | | | 37
| | | | | | | | | 1a | 91.18
| | | | | | | | | 2a | 8.82
| | | | | | | | | 2b | 0.00
| | | 92
| | | | 58
| | | | | | | | | 1a | 89.13
| | | | | | | | | 2a | 9.78
| | | | | | | | | 2b | 1.09
| | | 80
| | | | 71
| | | | | | | | | 1a | 87.50
| | | | | | | | | 2a | 11.25
| | | | | | | | | 2b | 1.25
Ikeda, 1993 | CohP
| | IFN (initial): | 795 | 53
| | | | 71
| | | | A: 100
Kliem, 1996 | CohR
| | | 162 | 44.5
| | | | 59
Kobayashi, 1996 | CohR
| | | 100 | 45.8 | | HAI | A 2.2 | | 89
| | | | 68 | | HAI | S 8.0
| | | | | | | | | 1b | 96.00
| | | | | | | | | other 1 | 4.00
| | | 36 | 42.7 | | HAI | A 2.1 | | 114
| | | | 78 | | HAI | S 8.1
| | | | | | | | | 2a | 55.56
| | | | | | | | | 2b | 16.67
| | | | | | | | | other 2 | 27.78
Kobayashi, 2000 | CohR
| | IFN (initial): 6–10 mu, qd, 4–8 wks | 61 | | | | | | 96
| | IFN (maintenance): 6–10 mu tiw, 16–22 wks | | 77
| | | | | | | | | 1b | 86.89
| | | | | | | | | other | 13.11
Lesens, 1999 | CS
| | | 81
| | | 53
Matsumura, 2000 | CohR
| | | 245 | 45.9
| | | | 64
| | | 143 | 51.6
| | | | 58
| | | 45 | 55.1
| | | | 49
| | | 39 | 55.6
| | | | 59
| | | 55 | 62.1
| | | | 67
Meijer, 1999 | CohR
| | | 26 | 38
| | | | | | | | | 19
| | | | | | | | | 1a | 42.31
| | | | | | | | | 1b | 30.77
| | | | | | | | | 2a | 3.85
| | | | | | | | | 2b | 11.54
| | | | | | | | | 3a | 7.69
| | | | | | | | | unclassified | 3.85
| | | 12 | 35
| | | | | | | | | 19
| | | | | | | | | 1a | 33.33
| | | | | | | | | 1b | 33.33
| | | | | | | | | 2a | 16.67
| | | | | | | | | 2b | 8.33
| | | | | | | | | 3a | 8.33
| | | | | | | | | unclassified | 0.00
| | | 7 | 46
| | | | | | | | | 19
| | | | | | | | | 1a | 42.86
| | | | | | | | | 1b | 14.29
| | | | | | | | | 2a | 0.00
| | | | | | | | | 2b | 28.57
| | | | | | | | | 3a | 14.29
| | | | | | | | | unclassified | 0.00
Murakami, 1999 | CohP
| | | 161 | 55.9
| | | | 43
| | | | | | | | | 1b | 68.94
| | | | | | | | | 2a | 24.22
| | | | | | | | | 2b | 6.83
| | | 196 | 56.9
| | | | 44
| | | | | | | | | 1b | 69.39
| | | | | | | | | 2a | 25.00
| | | | | | | | | 2b | 5.61
Persico, 2000 | CohP
| | | 37 | 40.8 | | ISH | S 8.0
| | | | 54
| | | | | | | | | 1a | 5.41
| | | | | | | | | 1b | 37.84
| | | | | | | | | 2a | 51.35
Punyagupta, 1999 | CohR
| | | 63 | | | | | S1 47.6
| | | | 54 | | | | S2 31.7
| | | | A: 100 | | | | S3 11.1
| | | | | | | | S4 9.5
Rodger, 1999 | CC
| | | 35 | 44
| | | | 71
| | | 70 | 52
| | | | 57
Rostaing, 1996 | CohR
| | | 31 | 48
| | | | 68 | | | | | 13.3
Takano, 1995 | CohR
| | | 124 | 49.6
| | | | 67
| | | 127 | 33.2
| | | | 80
Thomas, 2000 | CohP
| | | 40
| | | | | | | | | 1a | 65.00
| | | | | | | | | 1b | 32.50
| | | 1627
| | | | | | | | | 1a | 61.95
| | | | | | | | | 1b | 26.00
| | | | | | | | | other | 11.99
Yano, 1996 | CohR
| | | 70 | 44.6
| | | | 86
| | | | A: 100

Evidence Table 19. Methodologic quality of studies evaluating long-term outcomes of chronic hepatitis C

Author, Year | Representativeness^a^ | Bias ^b^ | Description ^c^ | Outcomes^d^ | Statistics^e^ | Conflict ^f^ | Total ^g^
Randomized controlled trials
Bernardinello, 1999 | 75 | 67 | 100 | 35 | 67 | 50 | 69
Chemello, 1999 | 75 | 83 | 75 | 95 | 83 | 50 | 82
Nishiguchi, 2001 | 100 | 83 | 100 | 80 | 88 | 50 | 90
Long-term outcomes of treatment
Aizawa, 2000 | 63 | 0 | 50 | 50 | 88 | 0 | 50
Benvegnu, 1997 | 75 | 75 | 75 | 40 | 50 | 50 | 63
Bruno, 1997 | 100 | 38 | 100 | 88 | 63 | 50 | 78
Fattovich, 1997 | 63 | 50 | 0 | 95 | 50 | 50 | 52
Horiike, 1998 | 38 | 50 | 0 | 60 | 50 | 0 | 40
Ikeda, 2001 | 38 | 38 | 75 | 85 | 88 | 0 | 65
Inoue, 2000 | 75 | 25 | 0 | 88 | 63 | 50 | 50
Shibata, 1998 | 88 | 25 | 50 | 88 | 100 | 50 | 70
Shindo, 2001 | 83 | -- | 100 | 80 | 63 | 0 | 81
Tanaka, 2000 | 88 | 25 | 100 | 75 | 100 | 100 | 78
Toyoda, 2001 | 75 | 100 | 75 | 80 | 100 | 50 | 86
Yabuuchi, 2000 | 38 | 33 | 0 | 40 | 67 | 0 | 36
Yatsuhashi, 2000 | 50 | 50 | 50 | 50 | 67 | 0 | 53
Long-term studies of natural history
Barrett, 2001 | 100 | 75 | 0 | 44 | 63 | 0 | 56
Benhamou, 2001 | 100 | 50 | 0 | 67 | 83 | 0 | 60
Chiaramonte, 1999 | 63 | -- | 0 | 70 | 75 | 50 | 52
Cottone, 1994 | 50 | 0 | 0 | 30 | 100 | 0 | 36
Forns, 2001 | 88 | -- | -- | 94 | 100 | 50 | 94
Furusyo, 2000 | 63 | 0 | 100 | 50 | 50 | 0 | 53
Gentilini, 1997 | 75 | 0 | 0 | 80 | 50 | 50 | 41
Harris, 2002 | 100 | 50 | 0 | 100 | 100 | 100 | 70
Hayashi, 2000 | 100 | 75 | -- | 44 | 67 | 0 | 71
Ikeda, 1993 | 88 | 0 | 25 | 55 | 100 | 0 | 54
Kliem, 1996 | 63 | 0 | 100 | 81 | 83 | 0 | 65
Kobayashi, 1996 | 88 | 100 | -- | 100 | 83 | 100 | 93
Kobayashi, 2000 | 67 | 75 | 0 | 67 | 100 | 0 | 62
Lesens, 1999 | 38 | 17 | 0 | 94 | 63 | 50 | 42
Matsumura, 2000 | 75 | -- | -- | 50 | 100 | 0 | 75
Meijer, 1999 | 88 | 50 | -- | 63 | 75 | 0 | 69
Murakami, 1999 | 88 | -- | 50 | 100 | 100 | 0 | 84
Persico, 2000 | 88 | -- | -- | 70 | 83 | 0 | 80
Punyagupta, 1999 | 25 | -- | 0 | 67 | 0 | 0 | 23
Rodger, 1999 | 25 | 25 | 50 | 38 | 25 | 0 | 33
Rostaing, 1996 | 38 | 0 | 0 | 67 | 13 | 0 | 23
Takano, 1995 | 100 | 0 | 0 | 70 | 38 | 0 | 42
Thomas, 2000 | 75 | -- | 0 | 85 | 67 | 50 | 57
Yano, 1996 | 88 | -- | -- | 100 | 100 | 0 | 96

a Representativeness: The total maximum for this section was 8 points. This included setting and population described and start and end date specified (2 points); detailed description of inclusion and exclusion criteria or statement that all potential trainees enrolled (2 points); information about excluded or not-participating patients (2 points); and description of key patient characteristics at enrollment (2 points).

b Bias and Confounding: The total maximum score was 6 points. This included whether assignment of patients to study groups was randomized (2 points); whether groups had any differences in key patient characteristics (2 points); and whether clinicians, patients, and outcome assessors were blinded (2 points).

c Description of Therapy/Management: The total maximum score was 4 points. This included sufficiently detailed description of the treatment regimen (2 points); and description of other treatments or tests given to subjects (2 points).

d Outcomes and Followup: The total maximum score was 10 points. This included description of complications, side effects and adverse reactions (2 points); sufficient description of criteria for determining outcomes (2 points); reporting on the numbers and reasons for withdrawals from the study or losses to followup (2 points); proportion of patients who withdrew from the study or were lost to followup (2 points); and sufficiency of the planned length of followup (2 points).

e Statistical Quality and Interpretation: The total maximum score was 8 points. This included whether magnitude of difference between groups and an index variability was stated (2 points); whether analyses and statistical tests were clearly identified (2 points); whether adjustment of potential confounders were multi-variate or stratified analyses and coding of confounders (2 points); and appropriate handling of crossovers and/or dropouts in the analysis (2 points).

f Conflict of Interest: The total maximum score was 2 points. This included whether the study reported the source of funding and the role played by the funding entity.

g Total Score is the mean of the percentage scores from the categories, Representativeness, Bias and Confounding, Description of Therapy/Management, Outcomes and Followup, and Statistical Quality and Interpretation.

Evidence Table 20. Results of studies evaluating long-term outcomes of patients with chronic hepatitis C

Author, Year | Group Description | Avg Length of f/u (Yr) | HCC 5 yr Incidence % | Overall Incidence % | Cirrhosis 5 yr Incidence % | Overall Incidence % | HCV Overall Mortality % | All Cause Related Mortality % | Annual Fibrosis Progression % | Overall Rate of Decompensation % | Comments
Randomized controlled trials
Bernardinello, 1999 | A: 6 mu B IFN/tiw for 6 mos - 3 mu for 6 mos | 5.0 | | 5.3 | | | | 9 | | 24* | Probable death includes OTL
| B: No tx | 5.0 | | 4.3 | | | | 4.4 | | 35*
Chemello, 1999 | A: 3 mu IFN alpha tiw × 6 mos | 6 | | | | | | | | | SVR: @ 6 mos., 9%
| | | | | | | | | | | @ 72 mos., 9%
| B: 3 mu IFN alpha qd × 3 mos, then tiw for 3 mos | 6 | | | | | | | | | SVR: @ 6 mos., 12%
| | | | | | | | | | | @ 72 mos., 12%
Nishiguchi, 2001 | A: Pts w/ HCV given symptomatic tx | 8.2 | 38 | 73* | | 56* | | 58*
| B: Pts w/ HCV given 6 mu IFN alpha, tiw for 24 wks | 9.2 | 4 | 27* | | 29* | | 11*
Long-term outcomes of treatment
Aizawa, 2000 | A: IFN therapy | 8.25 | 0 | 26 | - | | - | | | | HCC predictors: increased age, heavy drinking, histologic staging
| B: No IFN therapy | 8.25 | 12 | 45 | - | | - | | -
Benvegnu, 1997 | A: IFN therapy | 5.6 | | 5.5
| B: No IFN therapy | 5.6 | | 30.2
Bruno, 1997 | A: IFN therapy | 5.7 | | 0 | | | | | | | Risk factors included genotype 1b age >60, males
| B: No IFN therapy | 5.7 | | 28
Fattovich, 1997 | A: Pts w/ HCV, treated w/ IFN alpha | 4.8 | 4 | 4 | | | | | 8*
| B: Untreated controls | 5.3 | 11 | 12 | | | | | 29*
Horiike, 1998 | A: Complete responders to IFN | 7.6 | 0 | 0* | | | | | | | Groups A v C and B v C are significant
| B: Nonresponders to IFN | 7.6 | 1.5 | 2*
| C: No IFN received | 7.6 | 5 | 15*
Ikeda, 2001 | A: No IFN | 7.6 | 28.4 | 52.5 | | | 21 | 45.8 | | | 10 year rate for HCC
| B: Short-term IFN <12 mos | 7.6 | 24.7 | 64.9 | | | 11 | 19.3
| C: Long-term IFN >/= 12 mos | 7.6 | 16.0 | 21.2 | | | 8 | 12
Inoue, 2000 | A: Pts treated w/ IFN | 4.6 | 2.2* | 2.2 | | | 0 | 2 | | | Cox 69% decrease in HCC in patients receiving IFN
| B: Pts not treated w/ IFN | 5.9 | 9.5* | 14.4 | | | 15 | 12
Shibata, 1998 | A: Chronic hepatitis | 3.5 | | 7 | | | | | | | Untreated cirrhotics 52% HCC treated noncirrhotics 6.29%
| B: Cirrhosis | 3.5 | | 52
Shindo M, 2001 | A: Complete responders to tx (serum viral response and serum biochemical response) | 8–11 | 3 | 0 | 8 | 8
| B: Biochemical responders (nl ALT but no loss of virus) | | 3.9 | 0 | 8 | 8
| C: Short-term responders (relapse of ALT) | | | | 8 | 8
| D: Nonresponders | | | | 52 | 65.5
| E: Control group | | | | 35 | 39
Tanaka, 2000 | A: Pts in IFN tx group w/ sustained response. | 5.0 | 1.2 | 2 | | | 1 | | | | Risk of HCC in SR or TR vs controls=.16
| B: Pts in IFN tx group w/ transient response. | 4.7 | 3.7 | 3 | | | 6
| C: Pts who were nonresponders to IFN. | 4.6 | 10 | 10 | | | 6
| D: Control group - no IFN | 5.6 | 14 | 13.1 | | | 7
| E: Groups A, B, C | | | 5.5 | | | 7
Toyoda, 2001 | A: Pts who received >500 mu of IFN. | 5 | | 0 | | | | | | | Results reported for both groups combined, no difference in HCC by duration, but significant by total dose.
| B: Pts who received <500 mu of IFN. | 5 | | 15
Yabuuchi, 2000 | A: Complete responders | 4.9 | 2.3 | | | | | | | | Group A vs C and group B vs C are significant.
| B: HCV virus+ biochemical responders | 5.2 | 2.0
| C: Nonresponders | 4.9 | 14.3
Yatsuhashi, 2000 | O: Natural history of HCV in 186 individuals | | 3.9 | 45 | | 37
Long-term studies of natural history
Barrett, 2001 | A: Polymerase chain reaction+ women w/ CHC | 22.0 | | 0.0 | | 0.0
| B: Polymerase chain reaction negative women w/ CHC | | | 0.0 | | 0.0
Benhamou, 2001 | A: HIV/HCV coinfected pts treated w/ protease inhibitor | | | | 2 | 9 | | | 1.36*
| B: HIV/HCV coinfected pts not treated w/ protease inhibitor | | | | 5 | 27 | | | 2.1*
Chiaramonte, 1999 | A: Pts+ for HBsAg | 5.5 | 9 | 10 | | | | | | | Risk factors: age >50, dual infection, male
| B: HCV+ Pts | | 20 | 21
| C: Pts+ for both HBsAg and HCV | | 40 | 23
Cottone, 1994 | O: Overall | | 19
Forns, 2001 | O: Pts w/ noncirrhotic non-A, non-B hepatitis diagnosed at a tertiary hospital between 1971 and 1977 | 39 | 6 | 22 | 11
Furusyo, 2000 | A: Hemodialysis pts w/ HCV+ RNA in serum | 10 | 4
| B: Hemodialysis pts w/ HCV- RNA in serum
| C: Village residents with HCV viremia
Gentilini, 1997 | O: Pts w/ viral induced cirrhosis | | 8.6 | 9 | | 19
Harris, 2002 | A: Transfusion recipients infected w/ HCV | 11 | | | | 1 | 13 | | | | Age, gender, alcohol increase mortality. HCV-RNA level, age >40, duration associated with liver disease.
| B: Transfusion recipients negative for HCV | | | | | 2 | 9
Hayashi, 2000 | A: nl ALT levels | 5 | | 0*
| B: Itermittenlty abnl ALT | | | 4*
| C: Aways abnl ALT | | | 31
Ikeda, 1993 | O: Pts w/ cirrhosis | 5.8 | | 28 | | 29
Kliem, 1996 | O: Anit-HCV+ Pts | 7.4 | | | | | | 9 | | | HBV increases risk of progressive deterioration.
Kobayashi, 1996 | A: Pts infected w/ HCV genotype 1 | 9.4 | | 29 | | | | | | | More severe progression in patients w/ genotype 1 than genotype 2
| B: Pts infected w/ HCV genotype 2 | | | 6
Kobayashi, 2000 | O: Consecutive pts w/ CHC | 5
Lesens, 1999 | A: HIV and HCV+ hemophiliacs | 5 | | | | | 9 | 60 | | | Rate of progressive liver disease: 27% Group A, 6% Group B
| B: HCV+ and HIV- hemophiliacs | | | | | | 0 | 21
Matsumura, 2000 | A: Pts w/ mild fibrosis | 5 | | | | | | | 12 | | Overall rate for f1, f2, f3
| B: Pts w/ moderate fibrosis
| C: Pts w/ severe fibrosis
| D: Pts w/ cirrhosis
| E: Pts w/ HCC
Meijer, 1999 | A: Nl liver/spleen by U/S | 19
| B: Nl liver, enlarged spleen w/ patent portal splenic veins
| C: Abnl liver w/ patent portal/splenic veins
Murakami, 1999 | A: Pts analyzed for progression to cirrhosis. | 5.0 | | 12 | 21 | | | | | | As age at original transfusion inc., cumulative % HCC dec.
| B: Pts analyzed for progression to HCC.
Persico, 2000 | O: Asymptomatic HCV w/ persistently nl ALT levels | 7.0 | | | | 14 | | | | | Cirrhosis in patients who did not have persistent nl ALT
Punyagupta, 1999 | O: HCV positive patients | 5–15 | | 16 | 3 | | | | | | 60% deceased at 10 years and 85% at 15 years.
Rodger, 1999 | A: 35 anti-HCV+ individuals (followed up from a cohort of 238) | | | 0 | 2
| B: 70 anti-HCV- controls (followed up from a cohort of 1182) | | | 0 | 1
Rostaing, 1996 | O: Renal transplant Pts given liver bx
Takano, 1995 | A: CHC pts | | | | 10.5 | | | | | | Patients with CHC more histologically advanced
| B: Chronic HBV pts | | | 3.9
Thomas, 2000 | A: IDUs who are HCV w/ ESLD | 8.8 | | | 7 | 2 | 25 | | 2 | 98 | Reported for all groups combined
| B: IDUs who are HCV w/o ESLD
Yano, 1996 | O: HCV+ Pts w/ chronic liver disease | 8.8 | | | 50

* denotes statistical significance for a comparison between groups (p<0.05)

Evidence Table 21. Overall summary of study addressing efficacy of screening tests for hepatocellular carcinoma to improve outcomes in patients with chronic hepatitis C

Author, Year | Location | N | Inclusion Criteria | Exclusion Criteria | Study Aims
Solmi, 1996 | Italy | 2530 | AFP, U/S, initial liver bx, chronic liver disease regardless of etiology(cirrhotics and noncirrhotics) | HCC | To evaluate the possibilities of diagnosis of HCC at an early stage through the use of serial U/S and AFP on a population at risk for HCC

Evidence Table 22. Characteristics of patients in study addressing efficacy of screening tests for hepatocellular carcinoma to improve outcomes in patients with chronic hepatitis C

Author, Year | Study Design | Study Groups | N | Mean age % Male Race | % w/ Cirrhosis | Scoring System | Mean Activity (A) Fibrosis (S) | % w/ Score Activity (A) Fibrosis (S | Mean ALT (U/L) Mean yrs w/ HCV HCV genotype (%)
Solmi, 1996 | CohP
| | A: Chronic liver disease Pts w/o cancer followed in study center | 360 | 52 | 71 | | | S3, A2 29.4
| | | | 76
| | B: Pts w/ liver cirrhosis or chronic hepatitis followed in US clinics | 2170 | 56 | 70 | | | S3, A2 29.9
| | | | 65

Evidence Table 23. Methodologic quality of study containing efficacy of screening tests for hepatocellular carcinoma to improve outcomes in patients with chronic hepatitis C

Author, Year | Representativeness^a^ | Bias^b^ | Description^c^ | Outcomes^d^ | Statistics^e^ | Conflict^f^ | Total^g^
Solmi, 1996 | 100 | 50 | 100 | 65 | 33 | 0 | 70

a Representativeness: The total maximum for this section was 8 points. This included setting and population described and start and end date specified (2 points); detailed description of inclusion and exclusion criteria or statement that all potential trainees enrolled (2 points); information about excluded or not-participating patients (2 points); and description of key patient characteristics at enrollment (2 points).

b Bias and Confounding: The total maximum score was 6 points. This included whether assignment of patients to study groups was randomized (2 points); whether groups had any differences in key patient characteristics (2 points); and whether clinicians, patients, and outcome assessors were blinded (2 points).

c Description of Therapy/Management: The total maximum score was 4 points. This included sufficiently detailed description of the screening tests (2 points); and description of other treatments or tests given to subjects (2 points).

d Outcomes and Followup: The total maximum score was 10 points. This included description of complications, side effects and adverse reactions (2 points); sufficient description of criteria for determining outcomes (2 points); reporting on the numbers and reasons for withdrawals from the study or losses to followup (2 points); proportion of patients who withdrew from the study or were lost to followup (2 points); and sufficiency of the planned length of followup (2 points).

e Statistical Quality and Interpretation: The total maximum score was 8 points. This included whether magnitude of difference between groups and an index variability was stated (2 points); whether analyses and statistical tests were clearly identified (2 points); whether adjustment of potential confounders were multi-variate or stratified analyses and coding of confounders (2 points); and appropriate handling of crossovers and/or dropouts in the analysis (2 points).

f Conflict of Interest: The total maximum score was 2 points. This included whether the study reported the source of funding and the role played by the funding entity.

g Total Score is the mean of the percentage scores from the categories, Representativeness, Bias and Confounding, Description of Therapy/Management, Outcomes and Followup, and Statistical Quality and Interpretation.

Evidence Table 24. Results of study evaluating efficacy of screening tests for hepatocellular carcinoma to improve outcomes in patients with chronic hepatitis C

Article ID | Author, Year | Screening Groups | | N | Mean Followup (months) | # Cases HCC | Unifocal at Diagnosis | Resectable at Diagnosis (≤3.0 cm)
2818 | Solmi, 1996 | A | Chronic liver disease pts w/o cancer followed in study center | 360 | 56 | 24 | 18 | 18
| | B | Pts w/ liver cirrhosis or chronic hepatitis followed in US clinics | 2170 | 56 | 129 | 20 | 20

Evidence Table 25. Overall summary of studies addressing performance characteristics of screening tests for detecting hepatocellular carcinoma in patients with chronic hepatitis C

Author, Year | Location | N | Inclusion Criteria | Exclusion Criteria | Study Aims
Studies of AFP (with or without other tests)
Studies of HCV patients
Prospective cohort studies
Bruno, 1997 | Italy | 163 | Presence of cirrhosis, HCV+, presence of fibrosis | IFN, HCC, Child’s C, hemochromatosis, autoimmune hepatitis, sclerosing cholangitis, age >70 yrs, ALT >400 | To prospectively follow a cohort of HCV pts w/ cirrhosis and evaluate if the HCV genotype impacts the development of HCC. In addition, the aim was to elicit other independent risk factors for HCC.
Tradati, 1998 | Italy | 385 | Large pool clotting factor concentrates >= 10 yrs before start of study, ALT 1.5x UL of nl 3-6 mos apart | | To assess the natural history of HCC in Italian hemophiliacs w/ el ALT
| | | | | To assess whether HCC screening (U/S and AFP) leads to early detection and improved chance of curative tx
Diagnostic Test Design
Raedle, 1995 | Germany | 147 | Detectable HCV in serum, ALT el | HIV+, other causes of cirrhosis or HCC | To determine the sensitivity and specificity of anti- p53 in screening for HCC in pts w/ CHC
Studies of patients with HCV or HBV
Prospective cohort studies
Cottone, 1994 | Italy | 147 | Age > 40 yrs, Child's A cirrhosis | | To determine the risk of HCC in Child's A cirrhosis, whether 6 mos screening interval is adequate, and determine the role of AFP in screening
Ishii, 2000 | Japan | 734 | HCC at time of entry or w/i 1 yr, presence of fibrosis: histological dx in Pts w/ CHC, agreed to >= 1-y f/u and had >= 6-mo f/u before entry, PIVKA-II, AFP, U/S if HCC was not detected | | To determine if AFP and protein induced by vitamin K absence (PIVKA-II) measurements can improve detection of HCC in pts w/ chronic hepatitis.
Izzo, 1998 | Italy | 1125 | Positive sera for HBV surface antigen in 3 separate measures at 3-mo intervals or positive sera for anti-HCV in 3 separate measures at 3-mo intervals, chronic HBV or CHC or both for >5 yrs | Positive previous dx of any type of malignancy, decompensated liver disease: Child's B or C cirrhosis, encephalopathy, bleeding GI varices, ascites | To determine the incidence of HCC (resectable HCC and survival rate) in pts w/ chronic HBV and HCV
Izzo, 1999 | Italy | 1520 | HBsAg in 3 samples at 3-mo intervals or serum positive for anti-HCV virus in 3 samples at 3-mo intervals, chronic HBV or CHC infection or both for >= 5 yrs | Gastroesophageal varices, ascites, hepatic encephalopathy, bleeding, Child's B or C disease, positive history of any type of malignancy | To compare soluble IL-2 receptor to AFP as methods of screening for HCC in pts w/ chronic HBV or HCV. Also, to assess the usefulness of soluble IL-2 receptor as a marker of successful HCC tx and recurrence of disease.
Larcos, 1998 | Australia | 232 | | | To determine the incidence of HCC in pts w/ cirrhosis or chronic hepatitis and to assess cost and potential benefit of sonographic screening
Tong, 2001 | United States | 602 | 1 yr-f/u in clinic prior to study, presence of cirrhosis, HBV+ or HCV+ | HCC | To determine whether AFP or U/S was more accurate in detecting HCC, and to elucidate problems encountered using these two modalities. Clinical outcomes of pts in whom HCC was detected are also evaluated.
Trevisani, 1995 | Italy | 475 | | | To determine the prevalence of etiologic factors and clinical manifestations of HCC in pts w/ and w/o cirrhosis
Diagnostic Test Design
Nomura, 1996 | Japan | 128 | | Obstructive jaundice | To assess the diagnostic values of new enzyme immunoassays for des-gamma-carboxy prothrombin (DCP) compared to AFP in small sized HCC
Case control studies
Sassa, 1999 | Japan | 195 | Des-gamma-carboxy prothrombin, AFP | | To investigate the effectiveness of high sensitivity des-gamma-carboxy prothrombin and Lens culinaris agglutinin A-reactive AFP screening tests in diagnosing small HCC
Sato, 1993 | Japan | 361 | Presence of cirrhosis, AFP >= 30 ng/mL | | To determine the lectin reactivity of AFP in pts w/ cirrhosis who did and did not develop HCC
Tsai, 1994 | China | 404 | | | To determine the frequency of raised AFP level among Chinese pts w/ HCC related to HBV and HCV
Tsai, 1995 | Tiawan | 256 | Presence of cirrhosis, no previous therapy, serum samples collected | | To evaluate the diagnostic efficacy of AFP and 4% PEG- CICs, and C1 q-CICs in detecting HCC in cirrhotic patients
Tsai, 1997 | China | 238 | HCC group A, presence of cirrhosis: groups A and B | Previous treatment for cirrhosis or HCC, EtOH for HCC pts but not clear for control group | To evaluate the diagnostic efficacy of urinary transforming factor B-1 (TGF-B1) and AFP levels for detection of HCC in cirrhotic pts.
Van Roey, 2000 | Belgium | 140 | Initial liver bx, HCC | Non-HCC primary lesion of liver at dx or f/u | To study the characteristics of HCC pts w/ emphasis on the difference between cirrhotic HCC and noncirrhotic HCC pts
Cross-sectional studies
Cedrone, 2000 | Italy | 350 | ALT >2 x UL of nl | Pregnancy, autoimmune disorders, chronic alcohol abuse | To verify (in Western pts) w/ post-viral chronic liver disease, the utility of AFP for the detection of HCC, and the influence of HCV and HBV viral etiology on AFP levels in HCC
Studies of other serological tests (without AFP)
Studies of HCV patients
Prospective cohort studies
Kakumu, 1997 | Japan | 82 | | | To understand the roles of sTNF-alpha, IL-10, and IL-15 in the pathogenesis of type C chronic liver disease using ELISA.
Studies of patients with HCV or HBV
Cross-sectional studies
Tsuzurahara, 1997 | Japan | 170 | HBV+, detectable HCV in serum, HCV+ | | To determine whether MAGE-4 protein is detectable in sera of pts w/ HCC and other liver diseases
Case control studies
Nagai, 2001 | Japan | 129 | ALT, AFP, initial liver bx, HCC (not an inclusion criteria in the controls), presence of cirrhosis, presence of fibrosis, HCV+ | | To assess if cytokeratin 19 fragment (CK19) will be increased in serum from pts w/ hepatoma.
Studies of imaging (without AFP)
Studies of HCV patients
Prospective cohort studies
Kasahara, 1998 | Japan | 1022 | ALT >= 2x UL of nl for >=6 mos, initial liver bx, positive HCV antibodies | <200 mu IFN, duration of f/u <12 mos, encephalopathy, ascites, varices, autoimmune liver disease, alcoholic liver disease, HCC w/i 1 yr of IFN therapy, HBV+ | To evaluate the effect of IFN on HCC by assessing risk factors for carcinogenesis and incidence of HCC in pts w/ CHC treated w/ IFN.
Studies of patients with HCV or HBV
Prospective cohort studies
Colombo, 1991 | Japan | 447 | Age > 36 yrs, Presence of fibrosis/cirrhosis, Childs A or B, willing to participate in follow-up visits | HCC | To assess the magnitude of risk, the natural history of disease, and the possibilities of detecting potentially resectable tumors.

Evidence Table 26. Characteristics of patients in studies addressing performance characteristics of screening tests for detecting hepatocellular carcinoma in patients with chronic hepatitis C

Author, Year | Study Design | Study Groups | N | Mean age % Male Race | % w/ Cirrhosis | Scoring System | Mean Activity (A) Fibrosis (S) | % w/ Score Activity (A) Fibrosis (S) | Mean ALT (U/L) Mean yrs w/ HCV HCV genotype (%)
Studies of AFP (with or without other tests)
Studies of HCV patients
Prospective cohort studies
Bruno, 1997 | CohP
| | O: All HCV+ cirrhotic pts attending an outpt clinic | 163 | 57.8
| | | | 50
| | | | | | | | | 1a | 0.61
| | | | | | | | | 1b | 61.96
| | | | | | | | | 2a/c | 29.45
| | | | | | | | | 3a | 1.23
| | | | | | | | | mixed | 1.84
| | | | | | | | | not specified | 4.91
Tradati, 1998 | CohP
| | O: Hemophiliacs treated w/ blood or plasma products w/ el aminotransferases | 385 | 31 ^m^ | 10
| | | | 98 | | | | | 20
Diagnostic Test Design
Raedle, 1995 | DTD
| | O: Pts w/ CHC | 147 | 47.1
| | | | 60
Studies of patients with HCV or HBV
Prospective cohort studies
Cottone, 1994 | CohP
| | O: Child's A cirrhosis pts receiving periodic screening by AFP and U/S of the liver | 147 | 58
| | | | 55
Ishii, 2000 | CohP
| | A: HBsAg+ Pts w/ cirrhosis | 27
| | B: HCV+ Pts w/ chronic hepatitis | 295
| | C: HCV+ Pts w/ cirrhosis | 268
| | D: HBsAg+ Pts w/ cirrhosis, who were+ for HCV | 4
Izzo, 1998 | CohP
| | O: 1125 Pts w/ HBV or HCV or HBV and C infection of >5 yrs | 1125 | 56.1 | | | | S3, A2 28.9
| | | | | | | | S3, A2 71.1 | 10.2
Izzo, 1999 | CohP
| | O: 1520 Pts w/ HBV, HCV or HBV and HCV for >5 yrs | 1520 | 56 | | | | S3, A2 69.9
| | | | 61 | | | | S4, A3 30.1 | 10.6
Larcos, 1998 | CohP
| | O: Pts w/ chronic hepatitis and/or cirrhosis | 232 | 51 | | | | S3 A2 51.3
| | | | 66
| | | | A: 20.6
Tong, 2001 | CohP
| | A: Pts w/ HBV infection | 160 | 46
| | | | 71
| | | | C: 13.7,
| | | | B: 4.37,
| | | | A: 78.7,
| | | | O: 3.12
| | B: Pts w/ HCV infection | 429 | 53
| | | | 54
| | | | C: 55.9,
| | | | B: 6.29,
| | | | A: 17.7,
| | | | O: 20.0
| | C: Pts w/ both HBV and HCV infections | 13 | 49
| | | | 77
| | | | C: 46.1,
| | | | A: 46.1,
| | | | O: 7.69
Trevisani, 1995 | CohR
| | A: HCC pts w/ cirrhosis | 373 | 61.5
| | | | 79
| | B: HCC pts w/o cirrhosis | 102 | 58
| | | | 61
Diagnostic Test Design
Nomura, 1996 | DTD
| | A: HCC | 27
| | | | 74
| | B: Cirrhosis | 69
| | C: Minimal or mild chronic hepatitis with no or mild fibrosis | 17
| | D: Moderate or severe chronic hepatitis with moderate or severe fibrosis | 15
Case control studies
Sassa, 1999 | CC
| | A: Cases: HCC <2 cm maximum diameter in Pts w/ CHC and cirrhosis | 61
| | | | 62
| | | | A: 100
| | B: Controls: Pts w/ chronic hepatitis or cirrhosis | 134
| | | | A: 100
Sato, 1993 | CC
| | A: Cirrhosis caused by HCV or HBV w/ baseline AFP >/= 30 ng/mL and subsequent HCC | 33 | 54
| | | | 73
| | B: Cirrhosis caused by HCV or HBV w/ baseline AFP >/= 30 ng/mL w/o subsequent HCC | 32 | 50
| | | | 81
Tsai, 1994 | CC
| | A: HCC pts | 177 | 59
| | | | 85
| | B: Health community controls | 177
| | | | 85
Tsai, 1995 | CC
| | A: Cirrhotics w/ HCC | 101 | 57
| | | | 91
| | B: Sex-age matched controls w/ cirrhosis | 101
| | C: Healthy volunteers | 54 | 55
| | | | 85
Tsai, 1997 | CC
| | A: Non-alcoholic cirrhotic HCC | 94 | 58 ^m^
| | | | 81
| | B: Cirrhosis alone | 94
| | C: Healthly controls: anti-HCV and anti-HBV negative | 50 | 55 ^m^
| | | | 78
Van Roey, 2000 | CC
| | A: Noncirrhotics w/ HCC | 56 | 50 | | | | | 36
| | | | 61
| | B: Cirrhotics w/ HCC | 84 | 62 | | | | | 64
| | | | 82
Cross sectional studies
Cedrone, 2000 | XS
| | A: Pts w/ HCC and cirrhosis | 74 | 65.5
| | B: Pts w/ cirrhosis | 72 | 61.3
| | C: Pts w/ chronic hepatitis | 197 | 53.7
| | D: Pts w/ nl liver at bx | 7 | 54.5
Studies of other serological tests (without AFP)
Studies of HCV patients
Prospective cohort studies
Kakumu, 1997 | CohP
| | A: Asymptomatic HCV carriers w/ nl ALT for at least 1 yr | 10 | 49 | | | | | 32
| | | | 50
| | B: Pts w/ chronic hepatitis and el ALT for at least 1 yr | 28 | 54 | | | | | 111
| | | | 71
| | C: Pts+ for HCV-RNA w/ el ALT for at least 1 yr and cirrhosis | 22 | 61 | | | | | 85
| | | | 73
| | D: Pts w/ HCC | 11 | 66 | | | | | 78
| | | | 82
| | E: Healthy, HCV- controls, w/o a history of hepatitis and w/o liver disease | 11 | 45
| | | | 64
Studies of HCV or HBV patients
Cross sectional studies
Tsuzurahara, 1997 | XS
| | A: Chronic HCV | 70 | 51.2
| | | | 49
| | | | A: 100
| | B: Chronic HCV w/ cirrhosis | 55 | 61.5
| | | | 44
| | | | A: 100
| | C: Chronic HCV w/ HCC | 45 | 63.4
| | | | 82
| | | | A: 100
| | D: Others
Studies of patients with HCV or HBV
Case control studies
Nagai, 2001 | CC
| | A: Pts w/ HCC | 70 | 60
| | | | 76
| | | | A: 100
| | B: Pts w/ CAH | 14 | 53
| | | | 64
| | | | A: 100
| | C: Pts w/ liver cirrhosis | 45 | 58
| | | | 67
| | | | A: 100
Studies of imaging (without AFP)
Studies of HCV patients
Prospective cohort studies
Kasahara, 1998 | CohP
| | A: Sustained responders (6 mos following tx) | 313 | 52.4 | | HAI | 9
| | | | 67
| | | | | | | | | 1 | 35.46
| | | | | | | | | 2 | 34.82
| | | | | | | | | mixed | 2.56
| | | | | | | | | unclassified | 0.96
| | | | | | | | | untested | 26.20
| | B: Transient response | 304 | 52.6 | | HAI | 8.9
| | | | 66
| | | | | | | | | 1 | 68.42
| | | | | | | | | 2 | 10.53
| | | | | | | | | mixed | 0.99
| | | | | | | | | unclassified | 0.00
| | | | | | | | | untested | 20.07
| | C: Nonresponders | 405 | 53.5 | | HAI | 9.6
| | | | 68
| | | | | | | | | 1 | 67.90
| | | | | | | | | 2 | 9.63
| | | | | | | | | mixed | 0.00
| | | | | | | | | unclassified | 0.25
| | | | | | | | | untested | 22.22
Studies of patients with HCV or HBV
Prospective cohort studies
Colombo, 1991 | CohP
| | A: (Overall) Italian pts with cirrhosis | 447 | 55
| | | | 69
| | B: detectable with HCC at enrollment | 30 | 59
| | | | 80
| | C: detectable with HCC over follow-up | 29 | 58
| | | | 79

m Value given is a median

Evidence Table 27. Methodologic quality of studies addressing performance characteristics of screening tests for detecting hepatocellular carcinoma in patients with chronic hepatitis C

Author, Year | Representativeness^a^ | Bias ^b^ | Description ^c^ | Outcomes^d^ | Statistics^e^ | Conflict ^f^ | Total ^g^
Studies of AFP (with or without other tests)
Studies of HCV patients
Prospective cohort studies
Bruno, 1997 | 100 | 50 | 50 | 83 | 67 | 50 | 70
Tradati, 1998 | 63 | 100 | 100 | 33 | 50 | 50 | 69
Diagnostic Test Design
Raedle, 1995 | 75 | 50 | 100 | 0 | 100 | 0 | 65
Sudies of patients with HCV or HBV
Prospective cohort studies
Cottone, 1994 | 50 | 50 | 100 | 13 | 100 | 0 | 63
Ishii, 2000 | 75 | -- | 100 | 83 | 67 | 0 | 81
Izzo, 1998 | 75 | 0 | 100 | 25 | 50 | 50 | 50
Izzo, 1999 | 83 | 50 | 100 | 25 | 75 | 0 | 67
Larcos, 1998 | 25 | 50 | 100 | 100 | 25 | 0 | 60
Tong, 2001 | 63 | 0 | 100 | 50 | 67 | 0 | 56
Trevisani, 1995 | 88 | 50 | 50 | 0 | 100 | 50 | 58
Diagnostic Test Design
Nomura, 1996 | 25 | 50 | 100 | 0 | 0 | 0 | 35
Case control studies
Sassa, 1999 | 13 | 0 | 50 | 50 | 50 | 0 | 33
Sato, 1993 | 50 | 50 | 100 | 0 | 67 | 0 | 53
Tsai, 1994 | 88 | 50 | 50 | 67 | 100 | 50 | 71
Tsai, 1995 | 50 | 50 | 100 | 100 | 100 | 0 | 80
Tsai, 1997 | 63 | 50 | 50 | 50 | 100 | 0 | 63
Van Roey, 2000 | 38 | 50 | 50 | 100 | 75 | 0 | 63
Cross sectional studies
Cedrone, 2000 | 88 | 50 | 100 | 50 | 100 | 0 | 78
Studies of other serological tests (without AFP)
Studies of HCV patients
Prospective cohort studies
Kakumu, 1997 | 50 | -- | 100 | 17 | 100 | 50 | 67
Studies of patients with HCV or HBV
Cross sectional studies
Tsuzurahara, 1997 | 25 | 50 | 50 | 100 | 100 | 50 | 65
Case control studies
Nagai, 2001 | 38 | 0 | 50 | 100 | 67 | 0 | 51
Studies of imaging (without AFP)
Studies of HCV patients
Prospective cohort studies
Kasahara, 1998 | 100 | 100 | 100 | 69 | 67 | 0 | 87
Studies of patients with HCV or HBV
Prospective cohort studies
Colombo, 1991 | 88 | 0 | 100 | 83 | 75 | 0 | 69

a Representativeness: The total maximum for this section was 8 points. This included setting and population described and start and end date specified (2 points); detailed description of inclusion and exclusion criteria or statement that all potential trainees enrolled (2 points); information about excluded or not-participating patients (2 points); and description of key patient characteristics at enrollment (2 points).

b Bias and Confounding: The total maximum score was 2 points. This included whether there was an independent, blind comparison with a reference standard.

c Description of Therapy/Management: The total maximum score was 2 points. This included sufficiently detailed description of the screening tests

d Outcomes and Followup: The total maximum score was 8 points. This included description of complications, side effects and adverse reactions (2 points); sufficient description of criteria for determining outcomes (2 points); reporting on the numbers and reasons for withdrawals from the study or losses to followup (2 points); and proportion of patients who withdrew from the study or were lost to followup (2 points).

e Statistical Quality and Interpretation: The total maximum score was 6 points. This included whether magnitude of difference between groups and an index variability was stated (2 points); whether analyses and statistical tests were clearly identified (2 points); and appropriate handling of crossovers and/or dropouts in the analysis (2 points).

f Conflict of Interest: The total maximum score was 2 points. This included whether the study reported the source of funding and the role played by the funding entity.

g Total Score is the mean of the percentage scores from the categories, Representativeness, Bias and Confounding, Description of Therapy/Management, Outcomes and Followup, and Statistical Quality and Interpretation.

Evidence Table 28. Results of studies addressing performance characteristics of screening tests for detecting hepatocellular carcinoma in patients with chronic hepatitis C

Author, year | N | Study Design | Test (cutoff) | Sensitivity (%) | Specificity (%) | PPV (%) | NPV (%)
Studies of AFP (with or without other tests)
Studies of HCV patients
Cohort studies
Bruno, 1997 | 163 | CohP | AFP>20 ng/mL | 27
| | | AFP >400 ng/mL | 4.5
Tradati, 1992 | 385 | CohP | AFP >11mg/mL | 100
| | | AFP >400 mg/mL | 17
Diagnostic Test Design
Raedle, 1995 | 174 | DTD | AFP >20 ng/mL | 86 | 86
| | | AFP >100 ng/mL | 43 | 99
| | | AFP >400 ng/mL | 14
| | | +anti-p53 | 43 | 100
| | | AFP >20 ng/mL & +anti-p53 | 86 | 86
| | | AFP >100 ng/mL & +anti-p53 | 71 | 99
Studies of patients with HCV or HBV
Prospective cohort studies
Cottone, 1994 | 147 | CohP | AFP >50 ng/mL | 36
| | | AFP >400 ng/mL | 0
Ishii, 2000 | 734 | CohP | AFP >= 20 ng/mL | 61 | 78 | 6.5 | 98
| | | AFP >= 40 ng/mL | 45
| | | PIVKA-II >60 mA U/mL | 41 | 91 | 16 | 97
| | | AFP >= 40ng/mL and PIVKA II >80 mAU/mL | 66 | 85 | 15 | 98
Izzo, 1998 | 1125 | CohP | AFP >10 ng/mL | 75
| | | U/S | 87
| | | U/S or AFP >10 ng/mL | 100
Izzo, 1999 | 1520 | CohP | AFP >10 ng/mL | 80 | 95 | 81 | 94
| | | S-IL2R >850 U/mL | 99 | 96 | 86 | 100
| | | U/S | 66
| | | CT/MRI | 100
Larcos, 1998 | 232 | CohP | AFP >81 ng/mL | 17 | | 3%
| | | U/S | | | 24
Tong, 2001 | 1204 | CohP | AFP >13 ng/mL | 59 | 91 | 11 | 99
| | | AFP >19 ng/mL | 45 | 94 | 11 | 99
| | | AFP >21 ng/mL | 41 | 94 | 11 | 99
| | | AFP >24 ng/mL | 41 | 95 | 12 | 99
| | | U/S | 100 | 98 | 78 | 100
Trevisani, 1995 | 475 | CohR | AFP>20 Solitary HCC | 50
| | | AFP>20 Massive HCC | 50
| | | AFP>20 Diffuse | 70
| | | AFP>20 Multimodular | 70
| | | AFP>40 Solitary | 14
| | | AFP>40 Massive | 38
| | | AFP>40 Diffuse | 38
| | | AFP>40 Multimodular | 27
Diagnostic Test Design
Nomura, 1996 | 128 | DTD | AFP >20 | 63
| | | Conventional DCP | 17
| | | Overnight DCP | 29
| | | Avidin biotin complex DCP | 33
Case control studies
Sassa, 1999 | 195 | CC | AFP >200 mg/mL | 8 | 100
| | | AFP >200 ng/mL and AFP L3 >10% | 25 | 99 | 94 | 74
| | | AFP L3 >10% | 23 | 99 | 93 | 74
| | | H-DCP >40 mAU/mL | 45 | 99 | 93 | 80
| | | H-DCP > and AFP >200 ng/mL | 47.5 | 99 | 94 | 81
| | | H-DCP > and AFP L3 >10% | 54 | 98 | 92 | 83
Sato, 1993 | 361 | CC | AFP >=30 ng/mL | 68
| | | AFP <30 ng/mL | 86
Tsai, 1994 | 404 | CC | AFP >20 ng/mL | 74 | 100
| | | AFP >400 ng/mL | 54
Tsai, 1995 | 256 | CC | AFP >20 ng/mL | 77
| | | AFP >120 ng/mL | 67
| | | AFP >400 ng/mL | 64
| | | 3% PEG circulating immune complexes | 65
| | | AFP >120 ng/mL + 3% PEG CIC | 84 | 100
| | | AFP >400 ng/mL + 3% PEG CIC | 83 | 100
Tsai, 1997 | | | AFP >100 ng/mL | 55 | 99 | 98 | 69
| | | AFP >400 ng/mL | 48 | 100 | 100 | 66
| | | TGF B1>=50 mg/gCr | 53 | 99 | 98 | 68
| | | TGF B1 >=50 or AFP >100 ng/mL | 84 | 98 | 98 | 86
| | | TGF B1>=50 mg/gCr or AFP >400 ng/mL | 80 | 99 | 99 | 83
Van Roey, 2000 | 140 | CC | AFP>20 ng/mL | 62
| | | AFP>50 ng/mL | 55
| | | AFP>400 ng/mL | 43
| | | U/S | 51
Cross sectional studies
Cedrone, 2000 | | | AFP >13 ng/mL | 70 | 83 | 53
| | | AFP >13 ng/mL in cirrhotic pts. | 70 | 71 | 71
| | | AFP >20 ng/mL | 55 | 88 | 55
| | | AFP >20 ng/mL in cirrhotic pts. | 55 | 79 | 73
| | | AFP >50 ng/mL | 35 | 94 | 70
| | | AFP >50 ng/mL in cirrhotic pts. | 35 | 94 | 87
Studies of other serological tests (without AFP)
Studies of HCV Patients
Prospective cohort studies
Kakumu, 1997 | 80 | CohP | IL10>5 pg/ml | 63
| | | IL15 >70 pg/ml | 45
Studies of HCV or HBV patients
Cross sectional studies
Tsuzurahara, 1997 | 170 | XS | MAGE 4 >1.04 ng/mL | 47 | 77 | 43 | 80
Case control studies
Nagai, 2001 | 129 | CC | CK >2.5 ng/mL | 47 | 95 | 92 | 61
Studies of imaging (without AFP)
Studies of HCV patients
Prospective cohort studies
Kasahara, 1998 | 1022 | CohP | U/S and CT | | 96
Studies of HCV or HBV patients
Prospective cohort studies
Colombo, 1991 | 447 | CohP | U/S | 49
| | | U/S + CT | 93