# Bibliography

Abdelmalek M F, Harrison M E, Gross J B Jr, et al. Treatment of chronic hepatitis C with interferon with or without ursodeoxycholic acid: a randomized prospective trial. J Clin Gastroenterol. 1998;26(2):130-4. [pmid: 9563925].
Adinolfi L E, Andreana A, Utili R, et al. HCV RNA levels in serum, liver, and peripheral blood mononuclear cells of chronic hepatitis C patients and their relationship to liver injury. American Journal of Gastroenterology. 1998;93(11):2162-6. [pmid: 9820390].
Adinolfi L E, Utili R, Andreana A, et al. Relationship between genotypes of hepatitis C virus and histopathological manifestations in chronic hepatitis C patients. Eur J Clin Gastroenterol Hepatol. 2000;12(3):299-304.
Ahmed M M, Mutimer D J, Elias C, et al. A combined management protocol for patients with coagulation disorders infected with hepatitis c virus. Br J Haematol. 1996;95(2):383-8. [pmid: 8904898].
Aizawa Y, Shibamoto Y, Takagi I, et al. Analysis of factors affecting the appearance of hepatocellular carcinoma in patients with chronic hepatitis C. A long term follow-up study after histologic diagnosis. Cancer. 2000;89(1):53-9. [pmid: 10897000].
al-Faleh F Z, Sbeih F, al-Karawi M, et al. Treatment of chronic hepatitis C genotype 4 with alpha-interferon in Saudi Arabia: a multicenter study. Hepato-Gastroenterology. 1998;45(20):488-91. [pmid: 9638433].
Albloushi S S, Murray F E, Callagy G, et al. Changes in liver histopathology in women infected with hepatitis C through contaminated anti-D immunoglobulin injections in Ireland. Eur J Clin Gastroenterol Hepatol. 1998;10(1):69-73.
Allory Yves, Charlotte Frederic, Benhamou Yves, et al. Impact of human immunodeficiency virus infection on the histological features of Chronic hepatitis C: a case-control study. Hum Path. 2000;31(1):69-74. [pmid: 10665916].
Alric L, Duffaut M, Selves J, et al. Maintenance therapy with gradual reduction of the interferon dose over one year improves histological response in patients with chronic hepatitis C with biochemical response: results of a randomized trial. Journal of Hepatology. 2001;35(2):272-8. [pmid: 11580151].
Alter M J, Kruszon-Moran D, Nainan O V, et al. The prevalence of hepatitis C virus infection in the United States, 1988 through 1994. New England Journal of Medicine. 1999;341(8):556-2. [pmid: 10451460].
Anderson F H, Zeng L C, Rock N R, et al. An assessment of the clinical utility of serum ALT and AST in chronic hepatitis C. Hepatol Res. 2000;18(1):63-71. [pmid: 10838037].
Andreone P, Cursaro C, Gramenzi A, et al. A double-blind, placebo-controlled, pilot trial of thymosin alpha 1 for the treatment of chronic hepatitis C. Liver. 1996;16(3):207-10. [pmid: 8873009].
Andriulli A, Festa V, Leandro G, et al. Usefulness of a liver biopsy in the evaluation of patients with elevated ALT values and serological markers of hepatitis viral infection: an AIGO study. Digestive Diseases and Sciences. 2001;46(7):1409-15. [pmid: 11478491].
A new prognostic system for hepatocellular carcinoma: a retrospective study of 435 patients: the Cancer of the Liver Italian Program (CLIP) investigators. Hepatology 1998;28(3):751–5.
Angelico M, Cepparulo M, Barlattani A, et al. Unfavourable effects of colchicine in combination with interferon-alpha in the treatment of chronic hepatitis C. Alimentary Pharmacology and Therapeutics. 2000;14(11):1459-67. [pmid: 11069317].
Arase Y, Chayama K, Ikeda K, et al. Randomized controlled clinical trial of lymphoblastoid interferon-alpha for chronic hepatitis C. Hepatol Res. 2001;21(1):55-66. [pmid: 11470628].
Ariizumi S, Takasaki K, Yamamoto M, et al. Multicentric hepatocellular carcinomas tend to grow in more damaged segments of the liver. Journal of Gastroenterology. 2000;35(6):441-4. [pmid: 10864351].
Ascione A, De Luca M, Canestrini C, et al. Efficacy of high dose of recombinant alpha 2b interferon on long term response in chronic hepatitis C and cirrhosis: prospective randomized multicentre study. Italian Journal of Gastroenterology and Hepatology. 1998;30(5):517-23. [pmid: 9836109].
Assy N, Minuk G Y. Serum aspartate but not alanine aminotransferase levels help to predict the histological features of chronic hepatitis C viral infections in adults. American Journal of Gastroenterology. 2000;95(6):1545-50. [pmid: 10894594].
Badizadegan K, Jonas M M, Ott M J, et al. Histopathology of the liver in children with chronic hepatitis C viral infection. Hepatology. 1998;28(5):1416-23. [pmid: 9794930].
Banner B F, Barton A L, Cable E E, et al. A detailed analysis of the Knodell score and other histologic parameters as predictors of response to interferon therapy in chronic hepatitis C. Modern Pathology. 1995;8(3):232-8. [pmid: 7542385].
Bantel H, Lugering A, Poremba C, et al. Caspase activation correlates with the degree of inflammatory liver injury in chronic hepatitis C virus infection. Hepatology. 2001;34(4):758-67. [pmid: 11584373].
Baran R L, Oliver J H =3rd, Dodd G D, et al. Hepatocellular carcinoma: evaluation with biphasic, contrast-enhanced, helical CT. Radiology. 1996;199:505. [pmid: 8668803].
Barbacini I G, Goldoni E, De Sanctis G M, et al. Different reactivity against HCV proteins (RIBA 3) according to progression of liver damage. Panminerva Medica. 1998;40(4):269-72. [pmid: 9973819].
Barbaro G, Di Lorenzo G, Soldini M, et al. Interferon-alpha-2B and ribavirin in combination for chronic hepatitis C patients not responding to interferon-alpha alone: an Italian multicenter, randomized, controlled, clinical study. American Journal of Gastroenterology 1998;93(12):2445–51. Comment in: Am J Gastroenterol. 1999 Oct;94(10):3087–8.
Barbaro G, Di Lorenzo G, Soldini M, et al. Intravenous recombinant interferon-beta versus interferon-alpha-2b and ribavirin in combination for short-term treatment of chronic hepatitis C patients not responding to interferon-alpha. Multicenter Interferon Beta Italian Group Investigators. Scandinavian Journal of Gastroenterology. 1999;34(9):928-33. [pmid: 10522614].
Barbaro G, Di Lorenzo G, Soldini M/Parrotto S, et al. Hepatic glutathione deficiency in chronic hepatitis C: quantitative evaluation in patients who are HIV positive and HIV negative andcorrelations with plasmatic and lymphocytic concentrations and with the activity of liver disease. American Journal of Gastroenterology. 1996;91(12):2569-73. [pmid: 8946988].
Baroni G, Pastorelli A, Manzin A, et al. Hepatic stellate cell activation and liver fibrosis are associated with necroinflammatory injury and th1-like response in chronic hepatitis C. Liver. 1999;19(3):212-19. [pmid: 10395041].
Barrett S, Goh J, Coughlan B, et al. The natural course of hepatitis C virus infection after 22 years in a unique homogenous cohort: spontaneous viral clearance and chronic HCV infection. Gut. 2001;49(3):423-30. [pmid: 11511566]. [pmcid: 1728443].
Bassit La, Da Silva L, Ribeiro-Dos-Santos G, et al. Chronic hepatitis C virus infections in brazilian patients: association with genotypes, clinical parameters and response to long term alphainterferon therapy. Revista Do Instituto De Medicina Tropical De Sao Paulo. 1999;41(3):183-9. [pmid: 10529839].
Batey R G, Bensoussan A, Fan Y Y, et al. Preliminary report of a randomized, double-blind placebo-controlled trial of a Chinese herbal medicine preparation CH-100 in the treatment of chronic hepatitis C. Journal of Gastroenterology and Hepatology. 1998;13(3):244-7. [pmid: 9570235].
Bayati N, Silverman A L, Gordon S C. Serum alpha-fetoprotein levels and liver histology in patients with chronic hepatitis C. American Journal of Gastroenterology. 1998;93(12):2452-6. [pmid: 9860408].
Bell H, Hellum K, Harthug S, et al. Genotype, viral load and age as independent predictors of treatment outcome of interferon-alpha-2a treatment in patients with chronichepatitis C. Scandinavian J Arch Infect Dis. 1997;29(1):17-22.
Bellentani S, Pozzato G, Saccoccio G, et al. Clinical course and risk factors of hepatitis C virus related liver disease in the general population: report from the Dionysos study. Gut. 1999;44(6):874-80. [pmid: 10323892]. [pmcid: 1727553].
Bellobuono A, Mondazzi L, Tempini S, et al. Prospective comparison of four lymphoblastoid interferon alpha schedules for chronic hepatitis C. A multivariate analysis of factors predictive of sustained response to treatment. European Journal of Gastroenterology and Hepatology. 1997;9(12):1169-77. [pmid: 9471022].
Benhamou Y, Bochet M, Di Martino V, et al. Liver fibrosis progression in human immunodeficiency virus and hepatitis C virus coinfected patients. Hepatology. 1999;30(4):1054-58. [pmid: 10498659].
Benhamou Y, Martino V, Bochet M, et al. Factors affecting liver fibrosis in human immunodeficiency virus-and hepatitis C virus-coinfected patients: Impact of protease inhibitor therapy. Hepatology. 2001;34(2):283-7. [pmid: 11481613].
Benvegnu L, Pontisso P, Cavalletto D, et al. Lack of correlation between hepatitis C virus genotypes and clinical course of hepatitis C virus-related cirrhosis. Hepatology. 1997;25(1):211-5. [pmid: 8985292].
Berg T, Hoffmann R M, Teuber G, et al. Efficacy of a short-term ribavirin plus interferon alpha combination therapy followed by interferon alpha alone in previously untreated patients with chronic hepatitis C: a randomized multicenter trial. Liver. 2000;20(6):427-36. [pmid: 11169056].
Berlin J. Does blinding of readers affect the results of meta-analyses?. Lancet. 1997;350:185-6. [pmid: 9250191].
Bernardinello E, Cavalletto L, Chemello L, et al. Long-term clinical outcome after beta-interferon therapy in cirrhotic patients with chronic hepatitis C. TVVH Study Group. Hepato-Gastroenterology. 1999;46(30):3216-22. [pmid: 10626189].
Bierhoff E, Fischer H P, Willsch E, et al. Liver histopathology in patients with concurrent chronic hepatitis C and HIV infection. Virchows Archiv. 1997;430(4):271-7. [pmid: 9134037].
Biron Christine, Andreani Hubert, Blanc Pierre, et al. Prevalence of antiphospholipid antibodies in patients with chronicliver disease related to alcohol or hepatitis C virus: correlation with liver injury. J Lab Clin Med. 1998;131(3):243-50. [pmid: 9523848].
Bodenheimer Henry C Jr, Lindsay Karen L, Davis Gary L, et al. Tolerance and efficacy of oral ribavirin treatment of chronic hepatitisc: a multicenter trial. Hepatology. 1997;26(2):473-7. [pmid: 9252161].
Bonacini M, Groshen S, Yu M C, et al. Chronic hepatitis C in ethnic minority patients evaluated in Los Angeles County. American Journal of Gastroenterology. 2001;96(8):2438-41. [pmid: 11513187].
Bonino F, Oliveri F, Colombatto P, et al. Impact of interferon-alpha therapy on the development of hepatocellular carcinoma in patients with liver cirrhosis: results of an international survey. Journal of Viral Hepatitis. 1997;4(2):79-82. [pmid: 9429213].
Bonis P A L, Tong M J, Blatt L M, et al. A predictive model for the development of hepatocellular carcinoma, liver failure, or liver transplantation for patients presenting to clinic with chronic hepatitis C. American Journal of Gastroenterology. 1999;94(6):1605-12. [pmid: 10364032].
Bonkovsky H L, Stefancyk D, McNeal K, et al. Comparative effects of different doses of ribavirin plus interferon-alpha 2b for therapy of chronic hepatitis C: results of a controlled, randomized trial. Digestive Diseases and Sciences. 2001;46(10):2051-9. [pmid: 11680575].
Bonkovsky H L, Clifford B D, Smith L J, et al. High-Dose Interferon-Alpha-2b for Re-Treatment of nonresponders orrelapsing patients with chronic hepatitis C: a controlled randomized trial. Digestive Diseases and Sciences. 1996;41(1):149-54. [pmid: 8565748].
Bortolotti F, Resti M, Giacchino R, et al. Hepatitis C virus infection and related liver disease in children of mothers with antibodies to the virus. Journal of Pediatrics. 1997;130(6):990-3. [pmid: 9202625].
Boucher E, Guyader D, Jacquelinet S, et al. Interferon and ursodeoxycholic acid combined therapy in chronic viral C hepatitis: controlled randomized trial in 203 patients. Dig Liver Dis. 2000;32(1):29-33. [pmid: 10975752].
Boya P, Larrea E, Sola I, et al. Nuclear factor-kappa B in the liver of patients with chronic hepatitis C: decreased RelA expression is associated with enhanced fibrosis progression. Hepatology. 2001;34(5):1041-8. [pmid: 11679977].
Bresci G, Parisi G, Bertoni M, et al. High-dose interferon plus ribavirin in chronic hepatitis C not responding to recombinant alpha-interferon. Dig Liver Dis. 2000;32(8):703-7. [pmid: 11142581].
Bresci G, Parisi G, Metrangolo S, et al. Comparison among different types, dosages and duration of interferon therapy in chronic hepatitis C. Clin Drug Invest. 1998;15(4):271-7.
Brillanti S, Levantesi F, Masi L, et al. Triple antiviral therapy as a new option for patients with interferonnonresponsive chronic hepatitis C. Hepatology. 2000;32(3):630-4. [pmid: 10960460].
Brouwer J T, Nevens F, Kleter B, et al. Efficacy of interferon dose and prediction of response in chronic hepatitis C: Benelux study in 336 patients. Journal of Hepatology. 1998;28(6):951-9. [pmid: 9672169].
Bruix J. Treatment of hepatocellular carcinoma. Hepatology. 1997;25(2):259-62. [pmid: 9021931].
Brunetto M R, Oliveri F, Koehler M, et al. Effect of interferon-alpha on progression of cirrhosis tohepatocellular carcinoma: A retrospective cohort study. Lancet. 1998;351(9115):1535-9. [pmid: 10326535].
Bruno R, Debiaggi M, Sacchi P, et al. Daily interferon regimen for chronic hepatitis C: A prospective randomised study. Clinical Drug Investigation. 1999;18(1):11-6.
Bruno S, Battezzati Pier M, Bellati G, et al. Long-term beneficial effects in sustained responders to interferon-alfa therapy for chronic hepatitis C. Journal of Hepatology. 2001;34(5):748-55. [pmid: 11434622].
Bruno S, Silini E, Crosignani A, et al. Hepatitis C virus genotypes and risk of hepatocellular carcinoma in cirrhosis: A prospective study. Hepatology. 1997;25(3):754-8. [pmid: 9049231].
Buti M, Olive G, Stalgis C, et al. Quantification of serum hepatitis C virus RNA with daily or standard interferon doses plus ribavirin in nonresponder patients with chronic hepatitis C. Digestive Diseases and Sciences. 2000;45(4):685-9. [pmid: 10759235].
Caballero T, Perez-Milena A, Masseroli M, et al. Liver fibrosis assessment with semiquantitative indexes and imageanalysis quantification in sustained-responder and non-responder interferon-treated patients with chronic hepatitis C. Journal of Hepatology. 2001;34(5):740-7. [pmid: 11434621].
Cacopardo B, Berger A, Cosentino S, et al. Influence of hepatitis G virus coinfection on the clinical course of chronic hepatitis C. European Journal of Clinical Microbiology & Infectious Diseases. 1998;17(10):709-14.
Calleri G, Colombatto P, Gozzelino M, et al. Natural beta interferon in acute type-C hepatitis patients: a randomized controlled trial. Ital J Gastroenterol Hepatol. 1998;30(2):181-4. [pmid: 9675655].
Campistol J M, Esforzado N, Martinez J, et al. Efficacy and tolerance of interferon-alpha(2b) in the treatment of chronic hepatitis C virus infection in haemodialysis patients. Pre- and post-renal transplantation assessment. Nephrology, Dialysis, Transplantation. 1999;14(11):2704-9.
Caronia S, Bassendine M F, Barry R, et al. Interferon plus amantadine versus interferon alone in the treatment of naive patients with chronic hepatitis C: a UK multicentre study. Journal of Hepatology. 2001;35(4):512-6. [pmid: 11682036].
Carreno V, Martin J, Pardo M, et al. Randomized controlled trial of recombinant human granulocyte-macrophage colony-stimulating factor for the treatment of chronic hepatitis C. Cytokine. 2000;12(2):165-70. [pmid: 10671303].
Casaril M, Capra F, Gabrielli G B, et al. Long-term varisations of serum lamini and procollagen-III peptide in chronic HCV hepatitis after alpha-interferon therapy. Ital J Gastroenterol. 1996;28(1):15-9. [pmid: 8743068].
Casaril M, Stanzial A M, Tognella P, et al. Role of iron load on fibrogenesis in chronic hepatitis C. Hepato-Gastroenterology. 2000;47(31):220-5. [pmid: 10690612].
Castaldo G, Calcagno G, Sibillo R, et al. Quantitative analysis of aldolase A mRNA in liver discriminates between hepatocellular carcinoma and cirrhosis. Clin Chem. 2000;46(7):901-6. [pmid: 10894831].
Castro A, Suarez D, Inglada L, et al. Multicenter randomized, controlled study of intramuscular administration of interferon-beta for the treatment of chronic hepatitis C. J Interferon Cytokine Res. 1997;17(1):27-30. [pmid: 9041468].
Cavalletto L, Chemello L, Donada C, et al. The pattern of response to interferon alpha (alpha-IFN) predicts sustained response to a 6-month alpha-IFN and ribavirin retreatment for chronic hepatitis C. TVVH Study Group. Journal of Hepatology. 2000;33(1):128-34. [pmid: 10905596].
Cecere A, Romano C, Caiazzo R, et al. Lymphoblastoid alpha-IFN, leukocytic alpha-IFN and natural beta-IFN in the treatment of chronic hepatitis C: a clinical comparison of 150 cases. Hepatology Research. 1999;15(3):225-37.
Cedrone A, Covino M, Caturelli E, et al. Utility of alpha-fetoprotein (AFP) in the screening of patients with virus-related chronic liver disease: does different viral etiology influence AFP levels in HCC? A study in 350 western patients. Hepato-Gastroenterology. 2000;47(36):1654-8. [pmid: 11149026].
Cervello M, Virruso L, Lipani G, et al. Serum concentration of E-selectin in patients with chronic hepatitis, liver cirrhosis and hepatocellular carcinoma. Journal of Cancer Research and Clinical Oncology. 2000;126(6):345-51. [pmid: 10870645].
Cesaro S, Petris M G, Rossetti F, et al. Chronic hepatitis C virus infection after treatment for pediatric malignancy. Blood. 1997;90(3):1315-20. [pmid: 9242567].
Chan T M, Wu P C, Lau J Y N, et al. Interferon Treatment for Hepatitis C Virus Infection in Patients Onhaemodialysis. Nephrol Dial Transplant. 1997;12(7):1414-9. [pmid: 9249778].
Chapman B A, Stace N H, Edgar C L, et al. Interferon-alpha2a/ribaviran versus interferon-alpha2a alone for the retreatment of hepatitis C patients who relapse after a standard course of interferon. New Zealand Medical Journal. 2001;114(1128):103-4. [pmid: 11346153].
Chayama K, Tsubota A, Kobayashi M, et al. A pilot study of corticosteroid priming for lymphoblastoid interferonalfa in patients with chronic hepatitis C. Hepatology. 1996;23(5):953-7. [pmid: 8621174].
Chemello L, Cavalletto L, Bernardinello E, et al. Comparison of thrice weekly vs daily human leucocyte interferon-alpha therapy for chronic hepatitis C. TVVH Study Group. Journal of Viral Hepatitis. 1999;6(4):321-7. [pmid: 10607247].
Chemello L, Cavalletto L, Casarin C, et al. Persistent hepatitis C viremia predicts late relapse after sustained response to interferon-alpha in chronic hepatitis C. Annals of Internal Medicine. 1996;124(12):1058-60. [pmid: 8633819].
Chemello L, Cavalletto L, Donada C, et al. Efficacy of a second cycle of interferon therapy in patients with chronic hepatitis C. Gastroenterology. 1997;113(5):1654-9. [pmid: 9352869].
Cheng S J, Bonis P A, Lau J, et al. Interferon and ribavirin for patients with chronic hepatitis C who did not respond to previous interferon therapy: a meta-analysis of controlled and uncontrolled trials. Hepatology. 2001;33(1):231-40. [pmid: 11124841].
Chiaramonte M, Stroffolini T, Vian A, et al. Rate of incidence of hepatocellular carcinoma in patients with compensated viral cirrhosis. Cancer. 1999;85(10):2132-7. [pmid: 10326690].
Chiba T, Matsuzaki Y, Abei M, et al. The role of previous hepatitis-B virus-infection and heavy smoking in hepatitis-C virus-related hepatocellular-carcinoma. American Journal of Gastroenterology. 1996;91(6):1195-203. [pmid: 8651170].
Cho S G, Kim M Y, Kim H J, et al. Chronic hepatitis: in vivo proton MR spectroscopic evaluation of the liver and correlation with histopathologic findings. Radiology. 2001;221(3):740-6. [pmid: 11719670].
Choi Y, Putti T, Win K, et al. Correlation of viral RNA, alanine aminotransferase, and histopathology in hepatitis C virus-associated hepatitis. Molecular Diagnosis. 1999;4(3):251-4. [pmid: 10553026].
Chu C W, Hwang S J, Luo J C, et al. Clinical, virologic, and pathologic significance of elevated serum alpha-fetoprotein levels in patients with chronic hepatitis C. J Clin Gastroenterol. 2001;32(3):240-4. [pmid: 11246354].
Colombo M, Franchis R, Del Ninno E, et al. Hepatocellular carcinoma in Italian patients with cirrhosis. New England Journal of Medicine. 1991;325:675. [pmid: 1651452].
Conferences - Management of Hepatitis C 2002. 2001; accessed 2002. Web Page. Available at: http://odp.od.nih.gov/consensus/news/upcoming/hepc/hepc_info.htm
Conry-Cantilena C. Hepatitis C virus diagnostics: technology, clinical applications and impacts. Trends in Biotechnology. 1997;15(2):71-6. [pmid: 9081301].
Cotler S J, Taylor S L, Gretch D R, et al. Hyperbilirubinemia and cholestatic liver injury in hepatitis C-infected liver transplant recipients. American Journal of Gastroenterology. 2000;95(3):753-9. [pmid: 10710070].
Cottone M, Turri M, Caltagirone M, et al. Screening for hepatocellular carcinoma in patients with Child's A cirrhosis: an 8-year prospective study by ultrasound and alphafetoprotein. Journal of Hepatology. 1994;21:1029-34. [pmid: 7535323].
Craxi A, Di Marco V, Iacono O L, et al. Transfusion-associated chronic hepatitis C: alpha-N-1 interferon for 6 vs. 12 months. Journal of Hepatology. 1996;24(5):539-46. [pmid: 8773908].
Cromie S L, Jenkins P J, Bowden D S, et al. Chronic hepatitis C: effect of alcohol on hepatitic activity and viraltitre. Journal of Hepatology. 1996;25(6):821-6. [pmid: 9007708].
Crosignani A, Budillon G, Cimino L, et al. Tauroursodeoxycholic acid for the treatment of HCV-related chronic hepatitis: a multicenter placebo-controlled study. Hepato-Gastroenterology. 1998;45(23):1624-9. [pmid: 9840118].
Cummings K J, Lee S M, West E S, et al. Interferon and ribavirin vs interferon alone in the re-treatment of chronic hepatitis C previously nonresponsive to interferon: a meta-analysis of randomized trials. JAMA. 2001;285(2):193-9. [pmid: 11176813].
Curley SA, Izzo F, Gallipoli A, et al. Identification and screening of 416 patients with chronic hepatitis at high risk to develop hepatocellular cancer. Annals of Surgery 1995;222(3):375–80; discussion 380–3.
Darby S C, Ewart D W, Giangrande P L F, et al. Mortality from liver cancer and liver disease in hemophilic men and boys in UK given blood products contaminated with hepatitis C. Lancet. 1997;350:1425-31. [pmid: 9371165].
Davidoff F, DeAngelis C D, Drazen J M, et al. Sponsorship, authorship, and accountability. New England Journal of Medicine. 2001;345(11):825-6. [pmid: 11556304].
de Lucas S, Bartolome J, Rodriguez-Inigo E, et al. Distribution of hepatitis C virus infection in liver biopsies from children and adults with chronic hepatitis C. Journal of Medical Virology. 2001;64(1):1-5. [pmid: 11285561].
Degos F, Daurat V, Chevret S, et al. Reinforced regimen of interferon alfa-2a reduces the incidence of cirrhosis in patients with chronic hepatitis C: a multicentre randomised trial. Multicentre GER-CYT-04 Group. Journal of Hepatology 1998;29(2):224–32. Comment in: ACP J Club. 1999 Mar-Apr;130(2):37.
Demirhan B, Boyacioglu S, Kart H, et al. Histopathological features of hepatitis C virus infection in patients with chronic renal failure and renal transplantation. Transplantation Proceedings. 1996;28(4):2328-30. [pmid: 8769239].
Di Bisceglie A M, Bonkovsky H L, Chopra S, et al. Iron reduction as an adjuvant to interferon therapy in patients with chronic hepatitis C who have previously not responded to interferon: a multicenter, prospective, randomized, controlled trial. Hepatology. 2000;32(1):135-8. [pmid: 10869301].
Di Bisceglie A M, Thompson J, Smith-Wilkaitis N, et al. Combination of interferon and ribavirin in chronic hepatitis C: re-treatment of nonresponders to interferon. Hepatology. 2001;33(3):704-7. [pmid: 11230751].
Di Costanzo G G, Ascione A, Lanza A G, et al. Resistance to alpha interferon therapy in HCV chronic liver disease: role of hepatic fibrosis. Ital J Gastroenterol. 1996;28(3):140-6. [pmid: 8789824].
Di Marco V, Lo Iacono O, Camma C, et al. A randomized controlled trial of high-dose maintenance interferon therapy in chronic hepatitis C. Journal of Medical Virology. 1997;51(1):17-24. [pmid: 8986944].
Diago M, Suarez D, Garcia-Villarreal L, et al. Multicenter randomized study comparing initial daily induction with high dose lymphoblastoid interferon vs. standard interferon treatment for chronic hepatitis C. Journal of Medical Virology. 2001;64(4):460-5. [pmid: 11468730].
Dietrich C F, Stryjek-Kaminska D, Teuber G, et al. Perihepatic lymph nodes as a marker of antiviral response in patients with chronic hepatitis C infection. AJR. American Journal of Roentgenology. 2000;174(3):699-704. [pmid: 10701612].
DiMarco V, Almasio P, Vaccaro A, et al. Combined treatment of relapse of chronic hepatitis C with high-dose a(2)b interferon plus ribavirin for 6 or 12 months. Journal of Hepatology. 2000;33(3):456-62. [pmid: 11020002].
Donada C, Crucitti A, Donadon V, et al. Interferon alpha and ribavirin combination therapy in patients with chronic hepatitis C and mixed cryoglobulinemia. Blood. 1998;92(8):2983-4. [pmid: 9763592].
Duchatelle V, Marcellin P, Giostra E, et al. Changes in liver fibrosis at the end of alpha interferon therapy and 6 to 18 months later in patients with chronic hepatitis C: quantitative assessment by a morphometric method. Journal of Hepatology. 1998;29(1):20-8. [pmid: 9696488].
Dusheiko G, Main J, Thomas H, et al. Ribavarin treatment for patients with chronic hepatitis-C - results of a placebo-controlled study. Journal of Hepatology. 1996;25(5):591-8. [pmid: 8938532].
Dutta U, Byth K, Kench J, et al. Risk factors for development of hepatocellular carcinoma among Australians with hepatitis C: a case-control study. Aust N Z J Med. 1999;29(3):300-7. [pmid: 10868491].
Dutta U, Kench J, Byth K, et al. Hepatocellular proliferation and development of hepatocellular carcinoma: a case-control study in chronic hepatitis C. Hum Pathol. 1998;29(11):1279-84. [pmid: 9824107].
EASL International Consensus Conference on Hepatitis C. Paris, 26–28, February 1999, Consensus Statement. European Association for the Study of the Liver. Journal of Hepatology 1999;30(5):956–61.
Effect of interferon-alpha on progression of cirrhosis to hepatocellular carcinoma: a retrospective cohort study. International Interferon-alpha Hepatocellular Carcinoma Study Group. Lancet 1998;351(9115):1535–9.
el-Zayadi A, Selim O, Haddad S, et al. Combination treatment of interferon alpha-2b and ribavirin in comparison to interferon monotherapy in treatment of chronic hepatitis C genotype 4 patients. Ital J Gastroenterol and Hepatology. 1999;31(6):472-5.
Enriquez J, Gallego A, Torras X, et al. Retreatment for 24 vs 48 weeks with interferon-alpha2b plus ribavirin of chronic hepatitis C patients who relapsed or did not respond to interferon alone. Journal of Viral Hepatitis. 2000;7(6):403-8. [pmid: 11115050].
Everson G T, Jensen D M, Craig J R, et al. Efficacy of interferon treatment for patients with chronic hepatitis C: comparison of response in cirrhotics, fibrotics, or nonfibrotics. Hepatology. 1999;30(1):271-6. [pmid: 10385666].
Fabbri C, Marchetto S, Pezzoli A, et al. Efficacy of ursodeoxycholic acid in association with alpha-interferon for chronic hepatitis C in alpha-interferon non-responder patients. European Journal of Gastroenterology and Hepatology. 2000;12(5):511-5. [pmid: 10833093].
Fabris P, Marranconi F, Bozzola L, et al. Fibrogenesis serum markers in patients with chronic hepatitis C treated with alpha-IFN. Journal of Gastroenterology. 1999;34(3):345-50. [pmid: 10433010].
Fabris P, Tositti G, Negro F, et al. Interferon alfa-2b alone or in combination with ketoprofen as treatment for interferon-naive chronic hepatitis C patients. Alimentary Pharmacology and Therapeutics. 1999;13(10):1329-34. [pmid: 10540048].
Fanning L, Kenny E, Sheehan M, et al. Viral load and clinicopathological features of chronic hepatitis C (1b)in a homogeneous patient population. Hepatology. 1999;29(3):904-7. [pmid: 10051496].
Farrell G C, Bacon B R, Goldin R D. Lymphoblastoid interferon alfa-n1 improves the long-term response to a 6-month course of treatment in chronic hepatitis C compared with recombinant interferon alfa-2b: results of an international randomized controlled trial. Clinical Advisory Group for the Hepatitis C Comparative Study. Hepatology. 1998;27(4):1121-7. [pmid: 9537453].
Farrell G C, Bacon B R, Goldin R D, et al. Lymphoblastoid interferon alfa-N1 Improves the long-term response to a 6-month course of treatment in chronic hepatitis C compared with recombinant interferon alfa-2b: results of an international randomized controlled trial. Hepatology. 1998;27(4):1121-7. [pmid: 9537453].
Fasani P, Sangiovanni A, DeFazio C, et al. High prevalence of multinodular hepatocellular carcinoma in patients with cirrhosis attributable to multiple risk factors. Hepatology. 1999;29(6):1704-7. [pmid: 10347111].
Fattovich G, Giustina G, Degos F, et al. Effectiveness of interferon alfa on incidence of hepatocellular carcinoma and decompensation in cirrhosis type C. Journal of Hepatology. 1997;27(1):201-5. [pmid: 9252096].
Fattovich G, Giustina G, Degos F, et al. Morbidity and mortality in compensated cirrhosis type C: a retrospective follow-up study of 384 patients. Gastroenterology. 1997;112(2):463-72. [pmid: 9024300].
Fayyazi A, Schott P, Hartmann H, et al. Clinical, biochemical, and histological changes in hepatitis C virus infection-associated cryoglobulinemia. Z Gastroenterol. 1997;35(10):921-8. [pmid: 9370142].
Felipe M, Silva A E, Lopes E P, et al. A prospective and randomized study using ribavirin as monotherapy for the treatment of naive patients with chronic hepatitis C. Braz J Infect Dis. 2000;4(4):183-91. [pmid: 11008222].
Ferenci P, Brunner H, Nachbaur K, et al. Combination of interferon induction therapy and ribavirin in chronic hepatitis C. Hepatology. 2001;34(5):1006-11. [pmid: 11679972].
Ferenci P, Stauber R, Propst A, et al. Dose increase augments response rate to interferon-alpha in chronic hepatitis C. Digestive Diseases and Sciences. 1996;41(12 Suppl):103S-8S. [pmid: 9011466].
Ferenci P, Stauber R, Steindl-Munda P, et al. Treatment of patients with chronic hepatitis C not responding to interferon with high-dose interferon alpha with or without ribavirin: final results of a prospective randomized trial. Eur J Clin Gastroenterol Hepatol. 2001a;13(6):699-705.
Fernandez I, Castellano G, Domingo M J, et al. Influence oc viral genotype and level of viermia on the severity of liver-injury and the response to interferon therapy in Spanish patients with chronic-C infection. Scand J Gastroenterol. 1997;32(1):70-6. [pmid: 9018770].
Fernandez J L, Rendo P, delPino N, et al. A double-blind controlled trial of recombinant interferon-alpha 2b in haemodialysis patients with chronic hepatitis C virus infection and abnormal aminotransferase levels. Journal of Viral Hepatitis. 1997;4(2):113-9. [pmid: 9097267].
Fong T L, Han S H, Tsai N C, et al. A pilot randomized controlled trial of the effect of iron depletion on long-term response to alpha-interferon in patients with chronic hepatitis C. Journal of Hepatology. 1998;28(3):369-74. [pmid: 9551672].
Fontaine H, Nalpas B, Poulet B, et al. Hepatitis activity index is a key factor in determining the natural history of chronic hepatitis C. Hum Pathol. 2001;32(9):904-9. [pmid: 11567218].
Fontana R J, Israel J, LeClair P, et al. Iron reduction before and during interferon therapy of chronic hepatitis C: results of a multicenter, randomized, controlled trial. Hepatology. 2000;31(3):730-6. [pmid: 10706565].
Forns X, Ampurdanes S, Sanchez-Tapias J M, et al. Long-term follow-up of chronic hepatitis C in patients diagnosed at a tertiary-care center. Journal of Hepatology. 2001;35(2):265-71. [pmid: 11580150].
Fortunato G, Castaldo G, Oriani G, et al. Multivariate discriminant function based on six biochemical markers in blood can predict the cirrhotic evolution of chronic hepatitis. Clin Chem. 2001;47(9):1696-700. [pmid: 11514405].
Foster G R, Goldin R D, Main J, et al. Management of chronic hepatitis C: clinical audit of biopsy based management algorithm. BMJ. 1997;315(7106):453-8. [pmid: 9284661].
Freeman A J, Dore G J, Law M G, et al. Estimating progression to cirrhosis in chronic hepatitis C virus infection. Hepatology. 2001;34:809-16. [pmid: 11584380].
Fried M W, Shiffman M, Sterling R K, et al. A multicenter, randomized trial of daily high-dose interferon-alfa 2b for the treatment of chronic hepatitis c: pretreatment stratification by viral burden and genotype. American Journal of Gastroenterology. 2000;95(11):3225-9. [pmid: 11095346].
Fried M W, Shiffman M L, Reddy R K, et al. Pegylated (40 kDa) interferon alfa-2a (PEGASYS) in combination with ribavirin: efficacy and safety results from a phase III, randomized, actively-controlled multicenter study. Gastroenterology. 2001;120(2 Suppl):A289.
Friedlander L, Van Thiel D H, Faruki H, et al. New approach to HCV treatment: recognition of disease process as systemic viral infection rather than as liver disease. Digestive Diseases and Sciences. 1996;41(8):1678-81. [pmid: 8769301].
Fujisawa T, Komatsu H, Inui A, et al. Spontaneous remission of chronic hepatitis C in children. Eur J Pediatr. 1997;156(10):773-6. [pmid: 9365066].
Fujiwara K, Mochida S, Matsuo S, et al. Randomized control trial of interferon-beta injections at 12-h intervals as a therapy for chronic hepatitis C. Hepatology Research. 1998;12(3):240-51.
Fukuda Y, Nakano I, Katano Y, et al. Assessment and treatment of liver disease in Japanese haemophilia patients. Haemophilia. 1998;4(4):595-600. [pmid: 9873800].
Fukuzaki T, Kawata S, Imai Y, et al. Changes in serum hepatic fibrosis markers in biochemical responders to interferon therapy for chronic hepatitis C. Hepatology Research. 2000;17(2):156-66. [pmid: 10707009].
Furusyo N, Hayashi J, Kanamoto-Tanaka Y, et al. Liver damage in hemodialysis patients with hepatitis C virus viremia: a prospective 10-year study. Digestive Diseases and Sciences. 2000;45(11):2221-8. [pmid: 11215743].
Gabrielli G B, Capra F, Casaril M, et al. Serum laminin and type III procollagen in chronic hepatitis C: diagnostic value in the assessment of disease activity and fibrosis. Clin Chim Acta. 1997;265(1):21-31. [pmid: 9352126].
Gaeta G B, DiVirgilio D, Russo G, et al. Human leucocyte interferon-alpha in chronic hepatitis C resistant to recombinant or lymphoblastoid interferon-alpha: a randomized controlled trial. Journal of Viral Hepatitis. 1997;4(3):209-14. [pmid: 9181530].
Gaeta G B, Stornaiuolo G, Stanzione M, et al. Interferon-alpha plus amantadine in chronic hepatitis C resistant to interferon alone: a pilot randomized study. Journal of Viral Hepatitis. 2001;8(4):284-6. [pmid: 11454180].
Ganne-Carrie N, Chastang C, Uzzan B, et al. Predictive value of serum sex hormone binding globulin for the occurrence of hepatocellular carcinoma in male patients with cirrhosis. Journal of Hepatology. 1997;26(1):96-102. [pmid: 9148029].
Ganne-Carrie N, Christidis C, Chastang C, et al. Liver iron is predictive of death in alcoholic cirrhosis: a multivariate study of 229 consecutive patients with alcoholic and/or hepatitis C virus cirrhosis: a prospective follow up study. Gut. 2000;46(2):277-82. [pmid: 10644325]. [pmcid: 1727829].
Garbutt J C, West S L, Carey T S, et al. Pharmacological treatment of alcohol dependence a review of the evidence. JAMA. 1999;281(14):1318-25. [pmid: 10208148].
Garson J A, Uhnoo I, Whitby K, et al. Virological, biochemical and histological effects of human lymphoblastoid interferon in Swedish patients with chronic hepatitis C. Journal of Viral Hepatitis. 1997;4(5):325-31. [pmid: 9310931].
Gattoni A, Romano C, Cecere A, et al. Serum levels of soluble intercellular adhesion molecule 1 (sICAM-1) as a potential marker of disease activity and remission in patients with chronic hepatitis C. Panminerva Medica. 1997;39(4):256-62. [pmid: 9478063].
Gentilini P, Laffi G, Lavilla G, et al. Long course and prognostic factors of virus-induced cirrhosis of the liver. American Journal of Gastroenterology. 1997;92(1):66-72. [pmid: 8995940].
Gervais A, Martinot M, Boyer N, et al. Quantitation of hepatic hepatitis C virus RNA in patients with chronic hepatitis C. Relationship with severity of disease, viral genotype and response to treatment. Journal of Hepatology. 2001;35(3):399-405. [pmid: 11592602].
Gholson CF, Morgan K, Catinis G, et al. Chronic hepatitis C with normal aminotransferase levels: a clinical histologic study. American Journal of Gastroenterology 1997;92(10):1788–92. Comment in: Am J Gastroenterol. 1997 Oct;92(10):1775–7.
Giannini E, Arzani L, Borro P, et al. Does surveillance for hepatocellular carcinoma in HCV cirrhotic patients improve treatment outcome mainly due to better clinical status at diagnosis?. Hepatogastroenterology. 2000;47(35):1395-8. [pmid: 11100360].
Giannini E, Botta F, Fasoli A, et al. Progressive liver functional impairment is associated with an increase in AST ALT ratio. Digestive Diseases and Sciences. 1999;44(6):1249-53. [pmid: 10389705].
Giannini E, Caglieris S, Ceppa P, et al. Serum pro-collagen III peptide levels are related to lobular necrosis in untreated patients with chronic hepatitis C. Eur J Clin Gastroenterol Hepatol. 2001;13(2):137-41.
Gluck T, Seelig R, Dette S, et al. Parameters predicting responses to alpha-interferon treatment in chronic hepatitis C. Hepatogastroenterology. 1997;44(14):484-91. [pmid: 9164523].
Glue P, Fang J W, Rouzier-Panis R, et al. Pegylated interferon-alpha2b: pharmacokinetics, pharmacodynamics, safety, and preliminary efficacy data. Hepatitis C Intervention Therapy Group. Clinical Pharmacology and Therapeutics. 2000;68(5):556-67. [pmid: 11103758].
Glue P, Rouzier-Panis R, Raffanel C, et al. A dose-ranging study of pegylated interferon alfa-2b and ribavirin in chronic hepatitis C. The Hepatitis C Intervention Therapy Group. Hepatology. 2000;32(3):647-53. [pmid: 10960463].
Goldstein N S, Blue D E, Hankin R, et al. Serum alpha-fetoprotein levels in patients with chronic hepatitis C - relationships with serum alanine aminotransferase values, histologic activity index, and hepatocyte MIB-1 scores. Am J Clin Pathol. 1999;111(6):811-6. [pmid: 10361518].
Gonzalez-Peralta R P, Qian K, She J Y, et al. Clinical implications of viral quasi-species heterogeneity in chronic hepatitis C. Journal of Medical Virology. 1996;49(3):242-7. [pmid: 8818972].
Gordon S C, Fang J W, Silverman A L, et al. The significance of baseline serum alanine aminotransferase on pretreatment disease characteristics and response to antiviral therapy in chronic hepatitis C. Hepatology. 2000;32(2):400-4. [pmid: 10915749].
Graf J, Toriyama K, Itakura H. A clinico-pathological study of 163 untreated cases of chronic hepatitis C. Revista da Sociedade Brasileira de Medicina Tropical. 1996;29(1):21-5. [pmid: 8851211].
Graham CS, Baden LR, Yu E, et al. Influence of human immunodeficiency virus infection on the course of hepatitis C virus infection: a meta-analysis. 2001;33:562–9.
Grant P R, Black A, Garcia N, et al. Combination therapy with interferon-alpha plus N-acetyl cysteine for chronic hepatitis C: a placebo controlled double-blind multicentre study. Journal of Medical Virology. 2000;61(4):439-42. [pmid: 10897061].
Guechot J, Laudat A, Loria A, et al. Diagnostic Accuracy of Hyaluronan and Type Iii Procollagenamino-Terminal Peptide Serum Assays as Markers of Liver Fibrosis Inchronic Viral Hepatitis C Evaluated by Roc Curve Analysis. Clin Chem. 1996;42(4):558-63. [pmid: 8605673].
Guechot J, Poupon R E, Giral P, et al. Relationship between procollagen III aminoterminal propeptide and hyaluronan serum levels and histological fibrosis in primary biliary cirrhosis and chronic viral hepatitis C. Journal of Hepatology. 1994;20(3):388-93. [pmid: 8014451].
Guechot J, Serfaty L, Bonnand A-M, et al. Prognostic Value of Serum Hyaluronan in Patients With Compensated Hcvcirrhosis. Journal of Hepatology. 2000;32(3):447-52. [pmid: 10735615].
Guido M, Rugge M, Jara P, et al. Chronic hepatitis C in children: the pathological and clinical spectrum. Gastroenterology. 1998;115(6):1525-9. [pmid: 9834281].
Guilera M, Forns X, Torras X, et al. Pre-treatment with prednisolone does not improve the efficacy of subsequent alpha interferon therapy in chronic hepatitis C. Journal of Hepatology. 2000;33(1):135-41. [pmid: 10905597].
Gursoy M, Bilezikci B, Colak T, et al. Histologic outcome of hepatitis C virus infection in renal transplant recipients and the effect of pretransplantation interferon treatment. Transplantation Proceedings. 2000;32(3):558-60. [pmid: 10812112].
Haber M M, West A B, Haber A D, et al. Relationship of aminotransferases to liver histological status in chronic hepatitis C. American Journal of Gastroenterology. 1995;90(8):1250-7. [pmid: 7639225].
Hadziyannis A S, Papaioannou C, Spanou F, et al. Induction interferon therapy in naive patients with chronic hepatitis C: increased end-of-treatment virological responses but absence of long-term benefit. Alimentary Pharmacology and Therapeutics. 2001;15(4):551-7. [pmid: 11284785].
Hagiwara H, Hayashi N, Mita E, et al. Influence of transfusion-transmitted virus infection on the clinical features and response to interferon therapy in Japanese patients with chronic hepatitis C. Journal of Viral Hepatitis. 1999;6(6):463-9. [pmid: 10607265].
Hanley J P, Jarvis L M, Andrew J, et al. Interferon treatment for chronic hepatitis C infection in hemophiliacs--influence of virus load, genotype, and liver pathology on response. Blood. 1996;87(5):1704-9. [pmid: 8634415].
Harris H E, Ramsay M E, Andrews N, Eldridge K P. Clinical course of hepatitis C virus during the first decade of infection: cohort study. BMJ. 2002;324:1-6. [pmid: 11777781]. [pmcid: 1121932].
Hashimoto O, Ueno T, Sata M, et al. Long-term improvement of hepatic fibrosis in chronic hepatitis C treated with interferon-alpha. Hepatology Research. 1998;10(3):200-16.
Hayashi J, Furusyo N, Ariyama I, et al. A relationship between the evolution of hepatitis C virus variants, liver damage, and hepatocellular carcinoma in patients with hepatitis C viremia. J Infect Dis. 2000;181(5):1523-7. [pmid: 10823749].
Haydon G H, Jalan R, AlaKorpela M, et al. Prediction of cirrhosis in patients with chronic hepatitis C infection by artificial neural network analysis of virus and clinical factors. Journal of Viral Hepatitis. 1998;5(4):255-64. [pmid: 9751012].
Healey C J, Chapman R W, Fleming K A. Liver histology in hepatitis C infection: a comparison between patients with persistently normal or abnormal transaminases. Gut. 1995;37(2):274-8. [pmid: 7557581]. [pmcid: 1382731].
Heathcote E J, Keeffe E B, Lee S S, et al. Re-treatment of chronic hepatitis C with consensus interferon. Hepatology. 1998;27(4):1136-43. [pmid: 9537455].
Heathcote E J, Shiffman M L, Cooksley W G, et al. Peginterferon alfa-2a in patients with chronic hepatitis C and cirrhosis. New England Journal of Medicine. 2000;343(23):1673-80. [pmid: 11106716].
Hedin K, Babic A, Fryden A. Liver guide for monitoring of chronic hepatitis C. Proceedings / Amia Symposium 2000;340–3.
Heintges T, Mohr L, Hensel F, et al. Value of liver biopsy prior to interferon therapy for chronic viral hepatitis. Digestive Diseases and Sciences. 1998;43(7):1562-5. [pmid: 9690395].
Helbling B, Stamenic I, Viani F, et al. Interferon and amantadine in naive chronic hepatitis C: a double-blind, randomized, placebo-controlled trial. Hepatology. 2002;35(2):447-54. [pmid: 11826422].
Herve S, Savoye G, Riachi G, et al. Chronic hepatitis C with normal or abnormal aminotransferase levels: is it the same entity?. Eur J Clin Gastroenterol Hepatol. 2001;13(5):495-500.
Hirata M, Akbar S M F, Horiike N, et al. Noninvasive diagnosis of the degree of hepatic fibrosis using ultrasonography in patients with chronic liver disease due to hepatitis C virus. Eur J Clin Invest. 2001;31(6):528-35. [pmid: 11422403].
Hopf U, Berg T, Koenig V, et al. Treatment of chronic hepatitis C with interferon alpha: long-term follow-up and prognostic relevance of HCV genotypes. Journal of Hepatology. 1996;24(SUPPL. 2):67-73. [pmid: 8836892].
Horiike N, Fujisawa T, Michitaka K, et al. The effectiveness of interferon therapy on occurrence of hepatocellular carcinoma in chronic hepatitis C. Oncology Reports. 1998;5(5):1171-4. [pmid: 9683829].
Hoshida Y, Ikeda K, Kobayashi M, et al. Chronic liver disease in the extremely elderly of 80 years or more: clinical characteristics, prognosis and patient survival analysis. Journal of Hepatology. 1999;31(5):860-6. [pmid: 10580583].
Hwang S-J, Luo J-C, Chu C-W, et al. Hepatic steatosis in chronic hepatitis C virus infection: prevalenceand clinical correlation. Journal of Gastroenterology and Hepatology. 2001;16(2):190-5. [pmid: 11207900].
Hwang S J, Lee S D, Chan C Y, et al. A randomized, double-blind, controlled trial of consensus interferon in the treatment of Chinese patients with chronic hepatitis C. American Journal of Gastroenterology. 1999;94(9):2496-500. [pmid: 10484014].
Ideo G, Bellobuono A, Tempini S, et al. Antioxidant drugs combined with alpha-interferon in chronic hepatitis C not responsive to alpha-interferon alone: a randomized, multicentre study. European Journal of Gastroenterology and Hepatology. 1999;11(11):1203-7. [pmid: 10563527].
Iijima A, Tanaka E, Kobayashi M, et al. Relationship between histological prognosis of chronic hepatitis C and amount of hepatitis C virus core protein in serum. Journal of Gastroenterology and Hepatology. 2000;15(3):311-9. [pmid: 10764034].
Iijima Y, Kato T, Miyakawa H, et al. Effect of interferon therapy on Japanese chronic hepatitis C virus patients with anti-liver/kidney microsome autoantibody type 1. Journal of Gastroenterology and Hepatology. 2001;16(7):782-8. [pmid: 11446887].
Ikeda K, Arase Y, Saitoh S, et al. Interferon beta prevents recurrence of hepatocellular carcinoma after complete resection or ablation of the primary tumor-A prospective randomized study of hepatitis C virus-related liver cancer. Hepatology. 2000;32(2):228-32. [pmid: 10915728].
Ikeda K, Saitoh S, Kobayashi M, et al. Long-term interferon therapy for 1 year or longer reduces the hepatocellular carcinogenesis rate in patients with liver cirrhosis caused by hepatitis C virus: a pilot study. Journal of Gastroenterology and Hepatology. 2001;16(4):406-15. [pmid: 11354279].
Ikeda K, Saitoh S, Kobayashi M, et al. Distinction between chronic hepatitis and liver cirrhosis in patients with hepatitis C virus infection. Practical discriminant function using common laboratory data. Hepatology Research. 2000;18(3):252-66. [pmid: 11058829].
Ikeda K, Satoshi S, Koida I, et al. A multivariate analysis of risk factors for hepatocellular carcinogenesis: a prospective observation of 795 patients with viral and alcoholic cirrhosis. Hepatology. 1993;12:47-53. [pmid: 7686879].
Ikura Y, Morimoto H, Johmura H, et al. Relationship between hepatic iron deposits and response to interferon in chronic hepatitis C. American Journal of Gastroenterology. 1996;91(7):1367-73. [pmid: 8677997].
Imbert-Bismut F, Ratziu V, Pieroni L, et al. Biochemical markers of liver fibrosis in patients with hepatitis C virus infectiona prospective study. Lancet 2001;3571069–75.
Imperiale T F, Said A T, Cummings O W, et al. Need for validation of clinical decision aids: use of the AST/ALT ratio in predicting cirrhosis in chronic hepatitis C. American Journal of Gastroenterology. 2000;95(9):2328-32. [pmid: 11007237].
Inoue A, Tsukuma H, Oshima A, et al. Effectiveness of interferon therapy for reducing the incidence of hepatocellular carcinoma among patients with type C chronic hepatitis. Journal of Epidemiology. 2000;10(4):234-40. [pmid: 10959605].
Ishibashi K, Kashiwagi T, Ito A, et al. Changes in serum fibrogenesis markers during interferon therapy for chronic hepatitis type C. Hepatology. 1996;24(1):27-31. [pmid: 8707274].
Ishii M, Gama H, Chida N, et al. Simultaneous measurements of serum alpha-fetoprotein and protein induced by vitamin K absence for detecting hepatocellular carcinoma. South Tohoku District Study Group. American Journal of Gastroenterology. 2000;95(4):1036-40. [pmid: 10763956].
Izumi N, Enomoto N, Uchihara M, et al. Hepatic iron contents and response to interferon-alpha in patients with chronic hepatitis C. Relationship to genotypes of hepatitis C virus. Digestive Diseases and Sciences. 1996;41(5):989-94. [pmid: 8625774].
Izumi N, Kumada H, Hashimoto N, et al. Rapid decrease of plasma HCV RNA in early phase of twice daily administration of 3 MU doses interferon-beta in patients with genotype 1b hepatitis C infection: a multicenter randomized study. Digestive Diseases and Sciences. 2001;46(3):516-23. [pmid: 11318525].
Izzo F, Cremona F, Delrio P, et al. Soluble interleukin-2 receptor levels in hepatocellular cancer: a more sensitive marker than alfa fetoprotein. Annals of Surgical Oncology. 1999;6(2):178-85. [pmid: 10082044].
Izzo F, Cremona F, Ruffolo F, et al. Outcome of 67 patients with hepatocellular cancer detected during screening of 1125 patients with chronic hepatitis. Annals of Surgery. 1998;227(4):513-8. [pmid: 9563539]. [pmcid: 1191306].
Izzo F, Curley S, Maio P, et al. Correlation of soluble interleukin-2 receptor levels with severity of chronic hepatitis-C virus liver-injury and development of hepatocellular cancer. Surgery. 1996;120(1):100-5. [pmid: 8693411].
Jamal M M, Soni A, Quinn P G, et al. Clinical features of hepatitis C-infected patients with persistently normal alanine transaminase levels in the Southwestern United States. Hepatology. 1999;30(6):1307-11. [pmid: 10534355].
Jarmay K, Gallai M, Karacsony G, et al. Decorin and actin expression and distribution in patients with chronic hepatitis C following interferon-alfa-2b treatment. Journal of Hepatology. 2000;32(6):993-1002. [pmid: 10898320].
Jeffers L J, Coelho-Little M E, Cheinquer H, et al. Procollagen-III peptide and chronic viral C hepatitis. American Journal of Gastroenterology. 1995;90(9):1437-40. [pmid: 7661165].
Jenkins P J, Cromie S L, Bowden D S, et al. Chronic hepatitis-C and interferon-alfa therapy - predictors of long term response. Med J Aust. 1996;164(3):150-2. [pmid: 8628133].
Johnson P J, Leung N, Cheng P, et al. ‘Hepatoma-specific’ alphafetoprotein may permit preclinical diagnosis of malignant change in patients with chronic liver disease. Br J Cancer. 1997;75(2):236-40. [pmid: 9010032].
Kagawa T, Hosoi K, Takashimizu S, et al. Comparison of two interferon alfa treatment regimens characterized by an early virological response in patients with chronic hepatitis C. American Journal of Gastroenterology. 1998;93(2):192-6. [pmid: 9468240].
Kage M, Fujisawa T, Shiraki K, et al. Pathology of chronic hepatitis C in children. Hepatology. 1997;26(3):771-5. [pmid: 9303511].
Kage M, Shimamatu K, Nakashima E, et al. Long-term evolution of fibrosis from chronic hepatitis to cirrhosis in patients with hepatitis C: morphometric analysis of repeated biopsies. Hepatology. 1997;25(4):1028-31. [pmid: 9096615].
Kageyama F, Kobayashi Y, Murohisa G, et al. Failure to respond to interferon-alpha 2a therapy is associated with increased hepatic iron levels in patients with chronic hepatitis C. Biological Trace Element Research. 1998;64(13):185-96. [pmid: 9845473].
Kaji K, Nakanuma Y, Harada K-I, et al. Hemosiderin deposition in portal endothelial cells is a histologic marker predicting poor response to interferon-alpha therapy in chronic hepatitis. Pathol Int. 1997;47(6):347-52. [pmid: 9211521].
Kakizaki S, Takagi H, Ichikawa T, et al. Histological change after interferon therapy in chronic hepatitis C in view of iron deposition in the liver. Biological Trace Element Research. 2000;73(2):151-62. [pmid: 11049207].
Kakumu S, Aiyama T, Okumura A, et al. Earlier loss of hepatitis C virus RNA in interferon therapy can predict a long-term response in chronic hepatitis C. Journal of Gastroenterology and Hepatology. 1997;12(6):468-72. [pmid: 9195406].
Kakumu S, Okumura A, Ishikawa T, et al. Serum levels of Il-10, Il-15 and soluble tumour necrosis factor-alpha (TNF-alpha) receptors in type C chronic liver disease. Clinical and Experimental Immunology. 1997;109(3):458-63. [pmid: 9328122]. [pmcid: 1904782].
Kameda Y, Asakawa H, Shimomura S, et al. Laparoscopic prediction of hepatocellular carcinoma in cirrhosis patients. Journal of Gastroenterology and Hepatology. 1997;12(8):576-81. [pmid: 9304509].
Kao J H, Chen P J, Lai M Y, et al. Efficacy of consensus interferon in the treatment of chronic hepatitis C. Journal of Gastroenterology and Hepatology. 2000;15(12):1418-23. [pmid: 11197053].
Kao J H, Lai M Y, Chen P J, et al. Serum hepatitis-C virus titers in the progression of type-C chronic liver-disease - with special emphasis on patients with type 1B infection. J Clin Gastroenterol. 1996;23(4):280-3. [pmid: 8957730].
Kaplanski G, Farnarier C, Payan M-J, et al. Increased levels of soluble adhesion molecules in the serum of patients with hepatitis C: correlation with cytokine concentrations and liver inflammation and fibrosis. Digestive Diseases and Sciences. 1997;42(11):2277-84. [pmid: 9398806].
Karim A, Ahmed S, Khan A, et al. Interstitial pneumonitis in a patient treated with alpha-interferon and ribavirin for hepatitis C infection. American Journal of the Medical Sciences. 2001;322(4):233-5. [pmid: 11678522].
Kasahara A, Hayashi N, Mochizuki K, et al. Clinical characteristics of patients with chronic hepatitis C showing biochemical remission, without hepatitis C virus eradication, as a result of interferon therapy. The Osaka Liver Disease Study Group. Journal of Viral Hepatitis. 2000;7(5):343-51. [pmid: 10971822].
Kasahara A, Hayashi N, Mochizuki K, et al. Circulating matrix metalloproteinase-2 and tissue inhibitor of metalloproteinase-1 as serum markers of fibrosis in patients with chronic hepatitis C: relationship to interferon response. Journal of Hepatology. 1997;26(3):574-83. [pmid: 9075665].
Kasahara A, Hayashi N, Mochizuki K, et al. Risk factors for hepatocellular carcinoma and its incidence after interferon treatment in patients with chronic hepatitis C. Hepatology. 1998;27(5):1394-402. [pmid: 9581697].
Kaserer K, Fiedler R, Steindl P, et al. Liver biopsy is a useful predictor of response to interferon therapy in chronic hepatitis C. Histopathology. 1998;32(5):454-61. [pmid: 9639122].
Kato J, Kobune M, Nakamura T, et al. Normalization of elevated hepatic 8-hydroxy-2'-deoxyguanosine levels in chronic hepatitis C patients by phlebotomy and low iron diet. Cancer Research. 2001;61(24):8697-702. [pmid: 11751387].
Keeffe E B, Dusheiko G M, James S P, et al. Utility of hepatitis C virus serotypes in predicting response to treatment of chronic hepatitis C. Consensus Interferon Study Group. Cytokines, Cellular and Molecular Therapy. 1999;5(4):207-10.
Keeffe E B, Dusheiko G M, Tong M J, et al. Genotype does not affect pattern of HCV RNA decrease among responders during interferon treatment of chronic hepatitis C. Consensus Interferon Study Group. Cytokines, Cellular and Molecular Therapy. 1999;5(4):211-6.
Khalili M, Denham C, Perrillo R. Interferon and ribavirin versus interferon and amantadine in interferon nonresponders with chronic hepatitis C. American Journal of Gastroenterology. 2000;95(5):1284-9. [pmid: 10811340].
Kiso S, Kawata S, Tamura S, et al. Efficacy of combination therapy of interferon-alpha with ursodeoxycholic acid in chronic hepatitis C: a randomized controlled clinical trial. Journal of Gastroenterology. 1997;32(1):56-62. [pmid: 9058296].
Kjaergard L L, Krogsgaard K, Gluud C. Interferon alfa with or without ribavirin for chronic hepatitis C: systematic review of randomised trials. BMJ. 2001;323:1151-5. [pmcid: 59848]. [pmid: 11711405].
Kliem V, Van Den Hoff U, Brunkhorst R, et al. The long-term course of hepatitis C after kidney transplantation. Transplantation. 1996;62(10):1417-21. [pmid: 8958266].
Kobayashi M, Ikeda K, Akuta N, et al. Relationship between five-year histological outcome and serial changes in serum alanine aminotransferase in patients with biochemical and virological relapse after interferon treatment for chronic hepatitis C. Intervirology. 2000;43(3):174-9. [pmid: 11044811].
Kobayashi M, Tanaka E, Sodeyama T, et al. The natural course of chronic hepatitis-C - a comparison between patients with genotype-1 and genotype-2 hepatitis-C viruses. Hepatology. 1996;23(4):695-9. [pmid: 8666319].
Komatsu M, Ishii T, Ono T, et al. Pilot study of ofloxacin and interferon-alpha combination therapy for chronic hepatitis C without sustained response to initial interferon administration. Canadian Journal of Gastroenterology. 1997;11(6):507-11. [pmid: 9347166].
Komatsu M, Ishii T, Ono T, et al. A dose-dependent controlled trial of human lymphoblastoid interferon alpha for genotype 1b chronic hepatitis C associated with high HCV-RNA levels. Hepatology Research. 1997;7(2):105-12.
Komatsu M, Ono T, Nakajima K, et al. A multicentre randomized controlled trial of recombinant interferon-alpha-2a in the treatment of patients with chronic hepatitis C. Canadian Journal of Gastroenterology. 1997;11(7):579-82. [pmid: 9395758].
Komine F, Shimojima M, Moriyama M, et al. Telomerase activity of needle-biopsied liver samples: its usefulness for diagnosis and judgment of efficacy of treatment of small hepatocellular carcinoma. Journal of Hepatology. 2000;32(2):235-41. [pmid: 10707863].
Kondo M, Tanaka K, Ikeda M, et al. Hepatic HCV-RNA as a predictor of outcome after interferon therapy in patients with chronic hepatitis-C. Journal of Gastroenterology and Hepatology. 1996;11(3):236-40. [pmid: 8742919].
Kubo S, Nishiguchi S, Hirohashi K, et al. Effects of long-term postoperative interferon-alpha therapy on intrahepatic recurrence after resection of hepatitis C Virus-related hepatocellular carcinoma: a randomized, controlled trial. Annals of Internal Medicine. 2001;134(10):963-7. [pmid: 11352697].
Kubo S, Yamamoto T, Ikebe T, et al. Relationship between multicentric occurrence of hepatocellular carcinoma and histology of noncancerous hepatic tissue in patients with chronic hepatitis C. Japanese Journal of Cancer Research. 1999;90(10):1076-80. [pmid: 10595735].
Kumada T, Nakana S, Takeda I, et al. Long-term administration of natural interferon-alpha in patients with chronic hepatitis-C - relationship to serum RNA concentration, HCV-RNA genotypes, histological-changes and hepatitis-C virus. Journal of Gastroenterology and Hepatology. 1996;11(2):159-65. [pmid: 8672762].
Laghi V, Toccaceli F, Rosati S, et al. Comparison of treatment with two different doses of leukocyte interferon alpha in patients with chronic hepatitis C. Hepatogastroenterology. 1997;44(16):1182-6. [pmid: 9261621].
Landau A, Batisse D, Piketty C, et al. Long-term efficacy of combination therapy with interferon-alpha 2b and ribavirin for severe chronic hepatitis C in HIV-infected patients. AIDS. 2001;15(16):2149-55. [pmid: 11684934].
Larcos G, Sorokopud H, Berry G, et al. Sonographic screening for hepatocellular carcinoma in patients with chronic hepatitis or cirrhosis: an evaluation. AJR. American Journal of Roentgenology. 1998;171(2):433-5. [pmid: 9694470].
Laursen A L, Scheibel E, Ingerslev J, et al. Alpha interferon therapy in Danish haemophiliac patients with chronic hepatitis C: results of a randomized controlled open label study comparing two different maintenance regimens following standard interferon-alpha-2b treatment. Haemophilia. 1998;4(1):25-32.
Le Guen B, Squadrito G, Nalpas B, et al. Hepatitis C virus genome complexity correlates with response to interferon therapy: a study in French patients with chronic hepatitis C. Hepatology. 1997;25(5):1250-4. [pmid: 9141446].
Lee D H, Jamal H, Regenstein F G, et al. Morbidity of chronic hepatitis C as seen in a tertiary care medical center. Digestive Diseases and Sciences. 1997;42(1):186-91. [pmid: 9009136].
Leroy V, De Traversay C, Barnoud R, et al. Changes in histological lesions and serum fibrogenesis markers in chronic hepatitis C patients non-responders to interferon alpha. Journal of Hepatology. 2001;35(1):120-6. [pmid: 11495029].
Lesens O, Deschenes M, Steben M, et al. Hepatitis C virus is related to progressive liver disease in human immunodeficiency virus-positive hemophiliacs and should be treated as an opportunistic infection. J Infect Dis. 1999;179:1254-8. [pmid: 10191232].
Lethagen S, Widell A, Berntorp E, et al. Clinical spectrum of hepatitis C-related liver disease and response to treatment with interferon and ribavirin in haemophilia or Vonwillebrand disease. Br J Haematol. 2001;113(1):87-93. [pmid: 11328286].
Leto G, Tumminello F M, Pizzolanti G, et al. Lysosomal CA thepsin-B and CA thepsin-L and stefin-A blood-levels in patients with hepatocellular-carconoma and or liver-cirrhosis - potential clinical implications. Oncology. 1997;54(1):79-83. [pmid: 8978598].
Libbrecht L, Craninx M, Nevens F, et al. Predictive value of liver cell dysplasia for development of hepatocellular carcinoma in patients with non-cirrhotic and cirrhotic chronic viral hepatitis. Histopathology. 2001;39(1):66-73. [pmid: 11454046].
Lichtinghagen R, Huegel O, Seifert T, et al. Expression of matrix metalloproteinase-2 and-9 and their inhibitors in peripheral blood cells of patients with chronic hepatitis C. Clin Chem. 2000;46(2):183-92. [pmid: 10657374].
Lichtinghagen R, Michels D, Haberkorn C I, et al. Matrix metalloproteinase (MMP)-2, MMP-7, and tissue inhibitor of metalloproteinase-1 are closely related to the fibroproliferative process in the liver during chronic hepatitis C. Journal of Hepatology. 2001;34(2):239-47. [pmid: 11281552].
Lichtinghagen R, Steinmetz C, Pehle B, et al. Matrix metalloproteinases in liver and serum in chronic active hepatitis C and HCV-induced cirrhosis. Hepatology Research. 1999;14(2):119-34.
Lindsay K L, Davis G L, Schiff E R, et al. Response to higher doses of interferon alfa-2b in patients with chronic hepatitis C: a randomized multicenter trial. Hepatology. 1996;24(5):1034-40. [pmid: 8903371].
Lindsay K L, Trepo C, Heintges T, et al. A randomized, double-blind trial comparing pegylated interferon alfa-2b to interferon alfa-2b as initial treatment for chronic hepatitis C. Hepatology. 2001;34(2):395-403. [pmid: 11481625].
Lirussi F, Beccarello A, Bortolato L, et al. Long-term treatment of chronic hepatitis C with ursodeoxycholic acid: influence of HCV genotypes and severity of liver disease. Liver. 1999;19(5):381-8. [pmid: 10533795].
Lo Iacono O, Garcia-Monzon C, Almasio P, et al. Soluble adhesion molecules correlate with liver inflammation and fibrosis in chronic hepatitis C treated with interferon-alpha. Alimentary Pharmacology and Therapeutics. 1998;12(11):1091-9. [pmid: 9845398].
Loguercio C, Caporaso N, Tuccillo C, et al. Alpha-glutathione transferases in HCV-related chronic hepatitis: a new predictive index of response to interferon therapy?. Journal of Hepatology. 1998;28(3):390-5. [pmid: 9551675].
Look M P, Gerard A, Rao G S, et al. Interferon/antioxidant combination therapy for chronic hepatitis C--a controlled pilot trial. Antiviral Research. 1999;43(2):113-22. [pmid: 10517313].
Lopez-Labrador F-X, Ampurdanes S, Gimenez-Barcons M, et al. Relationship of the genomic complexity of hepatitis C virus with liver disease severity and response to interferon in patients with chronic HCV genotype 1b interferon. Hepatology. 1999;29(3):897-903. [pmid: 10051495].
Luo J C, Hwang S J, Lai C R, et al. Relationships between serum aminotransferase levels, liver histologies and virological status in patients with chronic hepatitis C in Taiwan. Journal of Gastroenterology and Hepatology. 1998;13(7):685-90. [pmid: 9715418].
Magrin S, Craxi A, Fabiano C, et al. HCV viremia is more important than genotype as a predictor of response to interferon in Sicily (Southern Italy). Journal of Hepatology. 1996;25(5):583-90. [pmid: 8938531].
Makino Y, Shiraki K, Sugimoto K, et al. Histological features of cirrhosis with hepatitis C virus for prediction of hepatocellular carcinoma development; a prospective study. Anticancer Research. 2000;20(5C):3709-15. [pmid: 11268443].
Makita O, Yamashita Y, Arakawa A, et al. Diagnostic accuracy of helical CT arterial portography and CT hepatic arteriography for hypervascular hepatocellular carcinoma in chronic liver damage. An ROC analysis. Acta Radiologica. 2000;41(5):464-9. [pmid: 11016767].
Makris M, Preston F E, Rosendaal F R, et al. The natural history of chronic hepatitis C in haemophiliacs. Br J Haematol. 1996;94(4):746-52. [pmid: 8826904].
Malaguarnera M, Di Fazio I, Ferlito L, et al. Increase of serum beta2-microglobulin in patients affected by HCV correlated hepatocellular carcinoma. European Journal of Gastroenterology and Hepatology. 2000;12(8):937-9. [pmid: 10958222].
Malaguarnera M, Di Fazio I, Ferlito L, et al. A comparison of four types of interferon alpha in the treatment of chronic hepatitis C. Current Therapeutic Research. 1998;59(1):48-59.
Manesis E K, Papaioannou C, Gioustozi A, et al. Biochemical and virological outcome of patients with chronic hepatitis C treated with interferon alfa-2b for 6 or 12 months: a 4-year follow-up of 211 patients. Hepatology. 1997;26(3):734-9. [pmid: 9303505].
Mangia A, Minerva N, Annese M, et al. A randomized trial of amantadine and interferon versus interferon alone as initial treatment for chronic hepatitis C. Hepatology. 2001a;33(4):989-93. [pmid: 11283865].
Mangia A, Villani M R, Minerva N, et al. Efficacy of 5 MU of interferon in combination with ribavirin for naive patients with chronic hepatitis C virus: a randomized controlled trial. Journal of Hepatology. 2001;34(3):441-6. [pmid: 11322207].
Manns M P, McHutchison J G, Gordon S C, et al. Peginterferon alfa-2b plus ribavirin compared with interferon alfa-2b plus ribavirin for initial treatment of chronic hepatitis C: a randomised trial. Lancet. 2001;358(9286):958-65. [pmid: 11583749].
Marco V D, Almasio P, Vaccaro A, et al. Combined treatment of relapse of chronic hepatitis C with high-dose alpha2b interferon plus ribavirin for 6 or 12 months. Journal of Hepatology. 2000;33(3):456-62. [pmid: 11020002].
Martin-Vivaldi R, Nogueras F, Gonzalez A, et al. Response of chronic hepatitis C to interferon-alpha treatment and relationship with iron metabolism. Revista Espanola De Enfermedades Digestivas. 1997;89(7):527-30.
Martino V, Rufat P, Boyer N, et al. The influence of human immunodeficiency virus coinfection on chronic hepatitis c in injection drug users: a long term retrospective cohort study. Hepatology. 2001;34(6):1193-9. [pmid: 11732009].
Martinot-Peignoux M, Boyer N, Cazals-Hatem D, et al. Prospective study on anti-hepatitis C virus-positive patients with persistently normal serum alanine transaminase with or without detectable serum hepatitis C virus RNA. Hepatology. 2001;34(5):1000-5. [pmid: 11679971].
Marui A, Fukuda Y, Koyama Y, et al. Serum levels of soluble intercellular adhesion molecule-1 and soluble vascular vell adhesion molecular-1 in liver disease, and their changes by treatment with interferon. J Int Med Res. 1996;24(3):258-65. [pmid: 8725986].
Matsumura H, Moriyama M, Goto I, et al. Natural course of progression of liver fibrosis in Japanese patients with chronic liver disease type C - a study of 527 patients at one establishment. Journal of Viral Hepatitis. 2000;7(4):268-75. [pmid: 10886535].
Mazzaro C, Panarello G, Carniello S, et al. Interferon versus steroids in patients with hepatitis C virus-associated cryoglobulinaemic glomerulonephritis. Dig Liver Dis. 2000;32(8):708-15. [pmid: 11142582].
Mazzella G, Accogli E, Sottili S, et al. Alpha-interferon treatment may prevent hepatocellular-carcinoma in HCV-related liver cirrhosis. Journal of Hepatology. 1996;24(2):141-7. [pmid: 8907566].
McCormick S E, Goodman Z D, Maydonovitch C L, et al. Evaluation of liver histology, ALT elevation, and HCV RNA titer in patients with chronic hepatitis C. American Journal of Gastroenterology. 1996;91(8):1516-22. [pmid: 8759653].
McHutchison J G, Blatt L M, de Medina M, et al. Measurement of serum hyaluronic acid in patients with chronic hepatitis C and its relationship to liver histology. Journal of Gastroenterology and Hepatology. 2000a;15(8):945-51. [pmid: 11022838].
McHutchison J G, Gordon S C, Schiff E R, et al. Interferon alfa-2b alone or in combination with ribavirin as initial treatment for chronic hepatitis C. N Engl J Med. 1998;339(21):1485-92. [pmid: 9819446].
McHutchison J G, Poynard T. Combination therapy with interferon plus ribavirin for the initial treatment of chronic hepatitis C. Seminars in Liver Disease. 1999;19(Suppl 1):57-65. [pmid: 10349693].
McHutchison J G, Poynard T, Pianko S, et al. The impact of interferon plus ribavirin on response to therapy in black patients with chronic hepatitis C. The International Hepatitis Interventional Therapy Group. Gastroenterology. 2000;119(5):1317-23. [pmid: 11054390].
McHutchison J G, Ware J E Jr,, Bayliss M S, et al. The effects of interferon alpha-2b in combination with ribavirin on health related quality of life and work productivity. Journal of Hepatology. 2001;34(1):140-7. [pmid: 11211891].
McMahon B J, Alberts S R, Wainwright R B, et al. Hepatitis B-related sequelae. Prospective study in 1400 hepatitis B surface antigen-positive Alaska native carriers. Arch Intern Med. 1990;150(5):1051-4. [pmid: 2158773].
Meijer K, Haagsma E B, Kok T, et al. Natural history of hepatitis C in HIV-negative patients with congenital coagulation disorders. Journal of Hepatology. 1999;31(3):400-6. [pmid: 10488696].
Michielsen P P, Hauben E I, Ramon A M, et al. Serum aminotransferase levels and histological disease in chronic hepatitis C. Acta Gastro-Enterologica Belgica. 1997;60(1):11-4. [pmid: 9144972].
Mihm S, Fayyazi A, Hartmann H, et al. Analysis of histopathological manifestations of chronic hepatitis C virus infection with respect to virus genotype. Hepatology. 1997;25(3):735-9. [pmid: 9049227].
Min A D, Jones J L, Esposito S, et al. Efficacy of high-dose interferon in combination with ribavirin in patients with chronic hepatitis C resistant to interferon alone. American Journal of Gastroenterology. 2001;96(4):1143-9. [pmid: 11316161].
Mitsuda A, Suou T, Ikuta Y, et al. Changes in serum tissue inhibitor of matrix metalloproteinase-1 after interferon alpha treatment in chronic hepatitis C. Journal of Hepatology. 2000;32(4):666-72. [pmid: 10782917].
Mizokami M, Orioto E, Gibo Y, et al. Genotype, serum level of hepatitis-C virus-RNA and liver histology as predictors of response to interferon-alpha 2A therapy in Japanese patients with chronic hepatitis-C. Liver. 1996;16(1):23-7. [pmid: 8868074].
Mohan K V K, Murugavel K G, Rajanikanth, et al. Diagnosis of hepatitis C virus infection by ELISA, RIBA and RT-PCR: a comparative evaluation. Indian J Gastroenterol. 1999;18(2):73-5. [pmid: 10319537].
Mohsen A H, Trent H C V. The epidemiology of hepatitis C in a UK Health Regional Population of 5.12 million. Gut. 2001;48(5):707-13. [pmid: 11302973]. [pmcid: 1728264].
Montalto G, Giannitrapani L, Soresi M, et al. Circulating E-selectin levels in chronic hepatitis C patients with normal or elevated transaminase before and after alpha-interferon treatment. Inflammation. 2001;25(2):101-8. [pmid: 11321356].
Montalto G, Soresi M, Carroccio A, et al. Comparative responses to three different types of interferon-alpha in patients with chronic hepatitis C. Current Medical Research and Opinion. 1998;14(4):235-41. [pmid: 9891196].
Montalto G, Zignego A L, Ruggeri M I, et al. Serum HCV-RNA and liver histologic findings in patients with long-term normal transaminases. Digestive Diseases and Sciences. 1997;42(8):1703-7. [pmid: 9286237].
Monteverde A, Ballare M, Pileri S. Hepatic lymphoid aggregates in chronic hepatitis C and mixed cryoglobulinemia. Springer Semin Immunopath. 1997;19(1):99-110.
Montorsi M, Santambrogio R, Bianchi P, et al. Laparoscopy with laparoscopic ultrasound for pretreatment staging of hepatocellular carcinoma: a prospective study. J Gastrointest Surg. 2001;5(3):312-5. [pmid: 11360055].
Mori H, Yabu K, Yoshizawa K, et al. Lymphocyte proliferative responses to recombinant hepatitis-C virus-antigens in patients with chronic hepatitis-C. Journal of Gastroenterology and Hepatology. 1996;11(8):697-704. [pmid: 8872764].
Morisco F, Marmo R, Iasevoli P, et al. Clinical outcome of chronic hepatitis C in patients treated with interferon: comparison between responders and non-responders. Ital J Gastroenterol and Hepatology. 1999;31(6):454-8.
Morisco F, Mazziotti G, Rotondi M, et al. Interferon-related thyroid autoimmunity and long-term clinical outcome of chronic hepatitis C. Dig Liver Dis. 2001;33(3):247-53. [pmid: 11407670].
Morita K, Tanaka K, Saito S, et al. Expression of interferon receptor genes in the liver as a predictor of interferon response in patients with chronic hepatitis C. Journal of Medical Virology. 1999;58(4):359-65. [pmid: 10421402].
Moussa Y I, Plevris J N, Hayes P C. Plasma nitrites/nitrates in HCV infection and hepatocellular carcinoma. European Journal of Gastroenterology and Hepatology. 2000;12(2):159-63. [pmid: 10741929].
Munoz A E, Levi D, Podesta A, et al. Interferon-alpha 2b combined with daily ketoprofen administration improves virological response in chronic hepatitis C: a prospective and randomised trial. Gut. 2000;46(3):427-31. [pmid: 10673309]. [pmcid: 1727838].
Murakami C, Hino K, Korenaga M, et al. Factors predicting progression to cirrhosis and hepatocellular carcinoma in patients with transfusion-associated hepatitis C virus infection. J Clin Gastroenterol. 1999;28(2):148-52. [pmid: 10078824].
Murawaki Y, Ikuta Y, Okamoto K, et al. Diagnostic value of serum markers of connective tissue turnover for predicting histological staging and grading in patients with chronic hepatitis C. Journal of Gastroenterology. 2001a;36(6):399-406. [pmid: 11428586].
Murawaki Y, Koda M, Okamoto K, et al. Diagnostic value of serum type IV collagen test in comparison with platelet count for predicting the fibrotic stage in patients with chronic hepatitis C. Journal of Gastroenterology and Hepatology. 2001;16(7):777-81. [pmid: 11446886].
Murawaki Y, Yamada S, Ikuta Y, et al. Clinical usefulness of serum matrix metalloproteinase-2 concentration in patients with chronic viral liver disease. Journal of Hepatology. 1999;30(6):1090-8. [pmid: 10406188].
Nagai T, Murota M, Nishioka M, et al. Elevation of cytokeratin 19 fragment in serum in patients with hepatoma: its clinical significance. European Journal of Gastroenterology and Hepatology. 2001;13(2):157-61. [pmid: 11246615].
Nakamura H, Ito H, Kimura Y, et al. The importance of initial daily administration of interferon alpha for the eradication of hepatitis C virus in patients with chronic hepatitis C: a multicenter randomized trial. Hepatogastroenterology. 1998;45(22):1045-55. [pmid: 9756005].
Nakamura H, Ito H, Ogawa H, et al. Initial daily interferon administration can gain more eradication of HCV-RNA in patients with chronic hepatitis C, especially with serum intermediate viral load. Hepatogastroenterology. 1999;46(26):1131-9. [pmid: 10370680].
Nakashima E, Kage M, Fujisawa T, et al. Serum hyaluronate level correlates to the degree of liver fibrosis in pediatric liver diseases. Hepatology Research. 1999;16(1):59-67.
National Institutes of Health Consensus Development Conference Panel statement: management of hepatitis C. Hepatology 1997;26(3 Suppl 1):2S–10S.
Nelson D R, Lauwers G Y, Lau J Y N, et al. Interleukin 10 treatment reduces fibrosis in patients with chronic hepatitis C: a pilot trial of interferon nonresponders. Gastroenterology. 2000;118(4):655-60. [pmid: 10734016].
Neri S, Ierna D, Antoci S, et al. Association of alpha-interferon and acetyl cysteine in patients with chronic C hepatitis. Panminerva Medica. 2000;42(3):187-92. [pmid: 11218623].
Neuman M G, Benhamou J P, Malkiewicz I M, et al. Cytokines as predictors for sustained response and as markers for immunomodulation in patients with chronic hepatitis C. Clinical Biochemistry. 2001;34(3):173-82. [pmid: 11408014].
Neuman M G, Benhamou J P, Martinot M, et al. Predictors of sustained response to alpha interferon therapy in chronic hepatitis C. Clinical Biochemistry. 1999;32(7):537-45. [pmid: 10614716].
Newsome P N, Beldon I, Moussa Y, et al. Low serum retinol levels are associated with hepatocellular carcinomain patients with chronic liver disease. Alimentary Pharmacology and Therapeutics. 2000;14(10):1295-301. [pmid: 11012474].
Nguyen H A, Ho S B. Natural history of chronic hepatitis C: identifying a window of opportunity for intervention. Disease-a-Month. 2001;47(12):593-609.
Ni Y H, Chang G M H, Lin K H, et al. Hepatitis-C viral-infection in thalassemic children - clinical and molecular studies. Pediatr Res. 1996;39(2):323-8. [pmid: 8825807].
Niederau C, Strohmery G, Heintges T, et al. Polyunsaturated phosphatidyl-choline and interferon alpha for treatment of chronic hepatitis B and C: a multi-center, randomized, double-blind, placebo-controlled trial. Hepatogastroenterology. 1998;45(21):797-804. [pmid: 9684137].
NIH Consensus Development Conference on Management of Hepatitis C: Bethesda, MD. Bethesda, MD: National Institutes of Health.
Ninomiya T, Yoon S, Hayashi Y, et al. Clinical significance of serum hyaluronic acid as a fibrosis marker in chronic hepatitis C patients treated with interferon-alpha: histological evaluation by a modified histological activity index scoring system. Journal of Gastroenterology and Hepatology. 1998;13(1):68-74. [pmid: 9737575].
Nishiguchi S, Shiomi S, Nakatani S, et al. Prevention of hepatocellular carcinoma in patients with chronic active hepatitis C and cirrhosis. Lancet. 2001;357(9251):196-7. [pmid: 11213099].
Nomura F, Ishijima M, Horikoshi A, et al. Determination of serum des-gamma-carboxy prothrombin levels in patients with small-sized hepatocellular carcinoma: comparison of the conventional enzyme immunoassay and two modified methods. American Journal of Gastroenterology. 1996;91(7):1380-3. [pmid: 8677999].
Nomura H, Kimura Y, Tada H, et al. Predictive factors of a response to interferon therapy in chronic hepatitis-C. J Clin Gastroenterol. 1996;23(3):185-90. [pmid: 8899499].
Nutt A K, Hassan H A, Lindsey J, et al. Liver biopsy in the evaluation of patients with chronic hepatitis C who have repeatedly normal or near-normal serum alanine aminotransferase levels. American Journal of Medicine. 2000;109(1):62-4. [pmid: 10936480].
O'Brien C B, Moonka D K, Henzel B S, et al. A pilot trial of recombinant interleukin-12 in patients with chronic hepatitis C who previously failed treatment with interferon-alpha. American Journal of Gastroenterology. 2001;96(8):2473-9. [pmid: 11513193].
O'Brien M J, Keating N M, Elderiny S, et al. An assessment of digital image analysis to measure fibrosis in liver biopsy specimens of patients with chronic hepatitis C. Am J Clin Pathol. 2000;114(5):712-8. [pmid: 11068544].
Ohashi Y. Changes of serum markers of hepatic fibrosis after interferon treatment of patients with chronic hepatitis C. Mie Medical Journal. 1998;48(13):19-25.
Ohkawa K, Hayashi N, Yuki N, et al. Disease stage of chronic hepatitis C assessed by both peritoneoscopic and histologic findings and its relationship with response to interferon therapy. Gastrointestinal Endoscopy. 1997;45(2):168-75. [pmid: 9041004].
Ohmiya M, Hayashi J, Ueno K, et al. Effectiveness of interferon treatment for patients with chronic hepatitis C virus infection and normal aminotransferase levels. Digestive Diseases and Sciences. 2000;45(10):1953-8. [pmid: 11117566].
Ohmori S, Shiraki K, Sugimoto K, et al. High expression of CD34-positive sinusoidal endothelial cells is a risk factor for hepatocellular carcinoma in patients with HCV-associated chronic liver diseases. Hum Pathol. 2001;32(12):1363-70. [pmid: 11774170].
Oka H, Tamori A, Kuroki T, et al. Prospective study of alpha -fetoprotein in cirrhotic patients monitored for developmenet of hepatocellular carcinoma. Hepatology. 1994;19:61-6. [pmid: 7506227].
Okanoue T, Daimon Y, Kirishima T, et al. Retreatment with interferon-alpha at dosages or period increased by 1.3 times is effective for treatment for transient responders and non-responders in chronic hepatitis C patients. Hepatology Research. 2001;20(3):348-58. [pmid: 11404194].
Okanoue T, Itoh Y, Minami M, et al. Interferon therapy lowers the rate of progression to hepatocellular carcinoma in chronic hepatitis C but not significantly in an advanced stage: a retrospective study in 1148 patients. Journal of Hepatology. 1999;30(4):653-9. [pmid: 10207807].
Okanoue T, Yasui K, Sakamoto S, et al. Circulating HCV-RNA, HCV genotype, and liver histology in asymptomatic individuals reactive for anti-HCV antibody and their follow-up study. Liver. 1996;16(4):241-7. [pmid: 8877994].
Ong J P, Younossi Z M, Speer C, et al. Chronic hepatitis C and superimposed nonalcoholic fatty liver disease. Liver. 2001;21(4):266-71. [pmid: 11454190].
Ono E, Shiratori Y, Okudaira T, et al. Platelet count reflects stage of chronic hepatitis C. Hepatology Research. 1999;15(3):192-200.
Onodera H, Ukai K, Suzuki M, et al. Incidence of hepatocellular carcinoma after interferon therapy in patients with chronic hepatitis C. Tohoku Exp Med. 1997;181(2):275-83.
Ouzan D, Babany G, Valla D, et al. Comparison of high initial and fixed-dose regimens of interferon-alpha2a in chronic hepatitis C: a randomized controlled trial. French Multicenter Interferon Study Group. Journal of Viral Hepatitis. 1998;5(1):53-9. [pmid: 9493517].
Ozdogan M, Ozgur O, Gur G, et al. Histopathological impacts of hepatitis virus infection in hemodialysis patients: should liver biopsy be performed before renal transplantation?. Artificial Organs. 1997;21(5):355-8. [pmid: 9129765].
Papatheodoridis G V, Delladetsima J K, Katsoulidou A, et al. Significance of IgM anti-HCV core level in chronic hepatitis C. Journal of Hepatology. 1997;27(1):36-41. [pmid: 9252071].
Paradis V, Mathurin P, Kollinger M, et al. In situ detection of lipid peroxidation in chronic hepatitis C: correlation with pathological features. J Clin Pathol. 1997;50(5):401-6. [pmcid: 499942]. [pmid: 9215123].
Paradis V, Mathurin P, Laurent A, et al. Histological features predictive of liver fibrosis in chronic hepatitis C infection. J Clin Pathol. 1996;49(12):998-1004. [pmcid: 499649]. [pmid: 9038738].
Pardo M, Castillo I, Oliva H, et al. A pilot study of recombinant interleukin-2 for treatment of chronic hepatitis C. Hepatology. 1997;26(5):1318-21. [pmid: 9362378].
Park G J-H, Lin B P C, Ngu M C, et al. Aspartate aminotransferase: alanine aminotransferase ratio in chronic hepatitis C infection: is it a useful predictor of cirrhosis?. Journal of Gastroenterology and Hepatology. 2000;15(4):386-90. [pmid: 10824882].
Parking DM, Muir CS, Whelan SL, Gao Y-T, Ferlay J, Powell J. Cancer Incidence in Five Continents. 1994 World Health Statistics Annual (Vol 6) . Lyon IARC Scientific Publications. 117–129World Healt Organization. Geneva WHO; 1995
Payen J L, Izopet J, Galindo-Migeot V, et al. Better efficacy of a 12-month interferon alfa-2b retreatment in patients with chronic hepatitis C relapsing after a 6-month treatment: a multicenter, controlled, randomized trial. Le Groupe D'etude et De Traitement du Virus De L'hepatite C (Get.Vhc). Hepatology. 1998;28(6):1680-6. [pmid: 9828235].
Perez R, Pravia R, Artimez M L, et al. A comparison between two induction regimes for the interferon treatment of chronic hepatitis C. Response related factors. Revista Espanola De Enfermedades Digestivas. 1997;89(3):167-73.
Persico M, Persico E, Suozzo R, et al. Natural history of hepatitis C virus carriers with persistently normal aminotransferase levels. Gastroenterology. 2000;118(4):760-4. [pmid: 10734027].
Piccinino F, Felaco F M, Sagnelli E, et al. Long-term lymphoblastoid interferon-alpha therapy for non-cirrhotic chronic hepatitis C: an Italian multicentre study on dose and duration of IFN alpha treatment. Research in Virology. 1998;149(5):283-91. [pmid: 9879606].
Plevris J N, Haydon G H, Simpson K J, et al. Serum hyaluronan--a non-invasive test for diagnosing liver cirrhosis. European Journal of Gastroenterology and Hepatology. 2000;12(10):1121-7. [pmid: 11057458].
Pockros P J, Tong M, Lee W M, et al. Relationship between biochemical and virological responses to interferon therapy in chronic hepatitis C infection. Consensus Interferon Study Group. Journal of Viral Hepatitis. 1998;5(4):271-6. [pmid: 9751014].
Pol S, Fontaine H, Carnot F, et al. Predictive factors for development of cirrhosis in parenterally acquired chronic hepatitis C: a comparison between immunocompetent and immunocomprimised patients. Journal of Hepatology. 1998;29:12-9. [pmid: 9696487].
Poupon R E, Bonnand A M, Queneau P E, et al. Randomized trial of interferon-alpha plus ursodeoxycholic acid versus interferon plus placebo in patients with chronic hepatitis C resistant to interferon. Scandinavian Journal of Gastroenterology. 2000;35(6):642-9. [pmid: 10912666].
Poynard T, Bedossa P, BioulacSage P, et al. Age and platelet count: A simple index for predicting the presence of histological lesions in patients with antibodies to hepatitis C virus. Journal of Viral Hepatitis. 1997;4(3):199-208. [pmid: 9181529].
Poynard T, Bedossa P, Opolon P. Natural history of liver fibrosis progression in patients with chronic hepatitis C. The OBSVIRC, METAVIR, CLINIVIR, and DOSVIRC groups. Lancet. 1997;349(9055):825-32. [pmid: 9121257].
Poynard T, Daurat V, Chevret S, et al. A short induction regimen of interferon-alpha is not effective for treatment of relapse in chronic hepatitis C: a randomized trial. For the multicentre GER-CYT-01 group. Journal of Viral Hepatitis. 1999;6(5):381-6. [pmid: 10607254].
Poynard T, Marcellin P, Lee SS, et al. Randomised trial of interferon alpha2b plus ribavirin for 48 weeks or for 24 weeks versus interferon alpha2b plus placebo for 48 weeks for treatment of chronic infection with hepatitis C virus. International Hepatitis Interventional Therapy Group (IHIT). Lancet. 1998;352(9138):1426-32. [pmid: 9807989].
Poynard T, Ratziu V, Charlotte F, et al. Rates and risk factors of liver fibrosis progression in patients with chronic hepatitis C. Journal of Hepatology. 2001;34(5):730-9. [pmid: 11434620].
Prati D, Zanella A, Zanuso F, et al. Sustained response to interferon-alpha2a monotherapy of young blood donors with minimal-to-mild chronic hepatitis C. The Donor Surveillance Study Group. Journal of Viral Hepatitis. 2000;7(5):352-60. [pmid: 10971823].
Punyagupta S, Jidpugdeebodin S, Siwadune T. Hepatitis C infection and hepatocellular carcinoma in Thailand: a long term study of 63 HCV patients. J Arch Infect Dis and Antimicrobial Agents. 1999;16(1):1-5.
Puoti C, Magrini A, Stati T, et al. Clinical, histological, and virological features of hepatitis C virus carriers with persistently normal or abnormal alanine transaminase levels. Hepatology. 1997;26(6):1393-8. [pmid: 9397976].
Puoti C, Stati T, Magrini A. Serum HCV RNA titer does not predict the severity of liver damage in HCV carriers with normal aminotransferase levels. Liver. 1999;19(2):104-9. [pmid: 10220739].
Puoti M, Cadeo G P, Putzolu V, et al. Pilot dose-finding trial on interferon alpha in combination with ribavirin for the treatment of chronic hepatitis C in patients not responding to interferon alone. Dig Liver Dis. 2001;33(2):163-72. [pmid: 11346146].
Quan C M, Krajden M, Grigoriew G A, et al. Hepatitis C virus infection in patients infected with the human immunodeficiency virus. Clin Infect Dis. 1993;17(1):117-9. [pmid: 7688986].
Queneau P E, Osaer F, Bronowicki J P, et al. Treatment of mild chronic hepatitis C with interferon alpha-2b: results of a multi-centre randomized study in 80 patients. European Journal of Gastroenterology and Hepatology. 2001;13(2):143-7. [pmid: 11246613].
Rabinovitz M, Block G, Finkelstein S D. Alpha-interferon retreatment of patients with chronic hepatitis C. American Journal of Gastroenterology. 1996;91(8):1523-6. [pmid: 8759654].
Raedle J, Roth W K, Oremek G, et al. Alpha-fetoprotein and p53 autoantibodies in patients with chronic hepatitis C. Digestive Diseases and Sciences. 1995;40(12):2587-94. [pmid: 8536517].
Raymond R S, Fallon M B, Abrams G A. Oral thymic extract for chronic hepatitis C in patients previously treated with interferon. A randomized, double-blind, placebo-controlled trial. Annals of Internal Medicine. 1998;129(10):797-800. [pmid: 9841585].
Reddy K R, Hoofnagle J H, Tong M J, et al. Racial differences in responses to therapy with interferon in chronic hepatitis C. Hepatology. 1999;30(3):787-93. [pmid: 10462387].
Reddy K R, Wright T L, Pockros P J, et al. Efficacy and safety of pegylated (40-kd) interferon alpha-2a compared with interferon alpha-2a in noncirrhotic patients with chronic hepatitis C. Hepatology. 2001;33(2):433-8. [pmid: 11172346].
Reichard O. Short-term versus sustained response to interferon therapy: effect on histology. Digestive Diseases and Sciences. 1996;41(12 SUPPL.):109S-14S. [pmid: 9011467].
Reichen J, Bianchi L, Buhler H, et al. Fixed versus titrated interferon-alpha 2B in chronic hepatitis C. A randomized controlled multicenter trial. The Swiss Association for the Study of the Liver. Journal of Hepatology. 1996;25(3):275-82. [pmid: 8895005].
Resci G, Parisi G, Babnti S, et al. Chronic hepatitis-C - what treatment for nonresponsers to recombinant interferon-alpha. Clin Drug Invest. 1996;11(4):224-8.
Ribavirin and chronic hepatitis C infection. FDA Consumer 2001;35(5):3.
Rodger A J, Thomson J A, Thompson S C, et al. Assessment of long-term outcomes of hepatitis C virus infection in a cohort of patients with acute hepatitis in 1971-1975: results of a pilot study. Journal of Gastroenterology and Hepatology. 1999;14:269-73. [pmid: 10197498].
Rodrigues C M, Brites D, Serejo F, et al. Apoptotic cell death does not parallel other indicators of liver damage in chronic hepatitis C patients. Journal of Viral Hepatitis. 2000;7(3):175-83. [pmid: 10849259].
Romeo R, Colombo M, Rumi M, et al. Lack of association between type of hepatitis C virus, serum load and severity of liver disease. Journal of Viral Hepatitis. 1996;3(4):183-90. [pmid: 8871879].
Rossini A, Ravaggi A, Agostinelli E, et al. Virological characterization and liver histology in HCV positive subjects with normal and elevated ALT levels. Liver. 1997;17(3):133-8. [pmid: 9249727].
Rossini A, Ravaggi A, Biasi L, et al. Virological response to interferon treatment in hepatitis C virus carriers with normal aminotransferase levels and chronic hepatitis. Hepatology. 1997;26(4):1012-7. [pmid: 9328328].
Rostaing L, Rumeau J L, Cisterne J M, et al. Liver histology in renal transplant patients after more than 10 years of hepatitis C virus infection. Transplantation Proceedings. 1996;28(5):2836-7. [pmid: 8908089].
Rumi M, Del Ninno E, Parravicini M L, et al. A prospective, randomized trial comparing lymphoblastoid to recombinant interferon alfa 2a as therapy for chronic hepatitis C. Hepatology. 1996;24(6):1366-70. [pmid: 8938163].
Rumi M G, Santagostino E, Morfini M, et al. A multicenter controlled, randomized, open trial of interferon alpha-2b treatment of anti-human immunodeficiency virus-negative hemophilic patients with chronic hepatitis C. Blood. 1997;89(10):3529-33. [pmid: 9160657].
Sachithanandan S, Clarke G, Crowe J, et al. Interferon-associated thyroid dysfunction in anti-D-related chronic hepatitis C. J Interferon Cytokine Res. 1997;17(7):409-11. [pmid: 9243373].
Saito H, Ebinuma H, Atsukawa K, et al. Disappearance of serum hepatitis C virus RNA within two days after one dose interferon administration is predictive for response to high-dose interferon-alpha-2b treatment for chronic hepatitis C. Keio J Med. 1997;46(2):74-80. [pmid: 9212590].
Saito H, Ebinuma H, Takahashi M, et al. Short-course of interferon-beta for the treatment of chronic hepatitis C: a multicenter trial for evaluating host immunological parameters. International Journal of Immunotherapy. 1998;14(2):115-28.
Sakugawa H, Nakasone H, Kinjo F, et al. Clinical features of patients with chronic liver disease associated with hepatitis C virus genotype 1a/I in Okinawa, Japan. Journal of Gastroenterology and Hepatology. 1997;12(2):176-81. [pmid: 9083921].
Salmeron F J, Palacios A, Perezruiz M, et al. Epidemiology, serological markers, and hepatic-disease of anti-HCV ELISA-2-positive blood-donors. Digestive Diseases and Sciences. 1996;41(10):1933-8. [pmid: 8888703].
Sanchez M G, Palacios A, Caballero T, et al. Efficacy of alpha 2b versus lymphoblastoid interferon in treatment of chronic hepatitis C. A randomized trial. Revista Espanola De Enfermedades Digestivas. 1998;90(8):558-62.
Sanchez-Quijano A, Andreu J, Gavilan F, et al. Influence of human immunodeficiency virus type 1 infection on the natural course of chronic parenterally acquired hepatitis C. European Journal of Clinical Microbiology and Infectious Diseases. 1995;14(11):949-53.
Sanchez-Tapias J M, Forms X, Ampurdanes S, et al. Low dose alpha interferon therapy can be effective in chronic active hepatitis C. Results of a multicentre, randomised trial. Gut. 1996;38(4):603-9. [pmid: 8707096]. [pmcid: 1383123].
Saracco G, Borghesio E, Mesina P, et al. Prolonged treatment (2 years) with different doses (3 versus 6 Mu) of interferon alpha-2b for chronic hepatitis type C: results of a multicenter randomized trial. Journal of Hepatology. 1997;27(1):56-62. [pmid: 9252074].
Saracco G, Ciancio A, Ghisetti V, et al. Treatment with interferon-alpha2b of naive non-cirrhotic patients with chronic hepatitis C according to viraemia and genotype. Results of a randomized multicentre study. The North West Italian Hepatological Group. European Journal of Gastroenterology and Hepatology. 2001;13(2):149-55. [pmid: 11246614].
Saracco G, Ciancio A, Olivero A, et al. A randomized 4-arm multicenter study of interferon alfa-2b plus ribavirin in the treatment of patients with chronic hepatitis C not responding to interferon alone. Hepatology. 2001;34(1):133-8. [pmid: 11431744].
Sartori M, Andorno S, Rigamonti C, et al. Chronic hepatitis C treated with phlebotomy alone: biochemical and histological outcome. Dig Liver Dis. 2001;33(2):157-62. [pmid: 11346145].
Sassa T, Kumada T, Nakano S, et al. Clinical utility of simultaneous measurement of serum high-sensitivity des-gamma-carboxy prothrombin and Lens culinaris agglutinin A-reactive alpha-fetoprotein in patients with small hepatocellular carcinoma. European Journal of Gastroenterology and Hepatology. 1999;11(12):1387-92. [pmid: 10654799].
Sata M, Fukuizumi K, Uchimura Y, et al. Hepatitis-C virus-infection in patients with clinically diagnosed alcoholic liver-diseases. Journal of Viral Hepatitis. 1996;3(3):143-8. [pmid: 8871873].
Sata M, Ide T, Akiyoshi F, et al. Effects of interferon alpha2a on incidence of hepatocellular carcino main chronic active hepatitis without cirrhosis. Kurume Med J. 1997;44(3):171-7. [pmid: 9339647].
Sato A, Kato Y, Nakata K, et al. Relationship between sustained elevation of serum alanine aminotranferase and progression from cirrhosis to hepatocellular-carinoma - comparison in patients with hepatits-B virus-associated and hepatitis C virus-associated cirrhosis. Journal of Gastroenterology and Hepatology. 1996;11(10):944-8. [pmid: 8912132].
Sato Y, Nakata K, Kato Y, et al. Early recognition of hepatocellular carcinoma based on altered profiles of alpha-fetoprotein. New England Journal of Medicine. 1993;328:1802-6. [pmid: 7684823].
Scheim OD, Friedman DS, Fleisher LA, et al. Anesthesia Management During Cataract Surgery. Evidence Report/Technology Assessment No. 16 (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-097-0006.) AHRQ Publication No. 01-E017. Rockville, MDAgency for Healthcare Research and Quality; 2001
Schroder O, Trojan J, Zeuzem S, et al. Limited value of fluorine-18-fluorodeoxyglucose PET for the differential diagnosis of focal liver lesions in patients with chronic hepatitis C virus infection. Nuklearmedizin. 1998;37(8):279-85. [pmid: 9868710].
Schwetz B A. From the Food and Drug Administration. JAMA. 2001;286(10):1166. [pmid: 11559244].
Seeff L B, Miller R N, Rabkin C S, et al. 45-year follow-up of hepatitis C virus infection in healthy young adults. Annals of Internal Medicine. 2000;132(2):105-11. [pmid: 10644270].
Seeff L B. Why is there such difficulty in defining the natural history of hepatitis C?. Transfusion. 2000;40(10):1161-4. [pmid: 11061849].
Serejo F, Costa A, Oliveira A G, et al. Alpha-interferon improves liver fibrosis in chronic hepatitis C: clinical significance of the serum N-terminal propeptide of procollagen type III. Digestive Diseases and Sciences. 2001;46(8):1684-9. [pmid: 11508668].
Serra M A, Ferrandez A, Gilabert M S, et al. Influence of pretreatment lesions on histologic response to interferon therapy in chronic hepatitis C. J Clin Gastroenterol. 1998;26(4):296-9. [pmid: 9649015].
Sheehan M M, Doyle C T, Whelton M, et al. Hepatitis C virus liver disease in women infected with contaminated anti-D immunoglobulin. Histopathology. 1997;30(6):512-7. [pmid: 9205854].
Sherman K E, Sjogren M, Creager R L, et al. Combination therapy with thymosin alpha1 and interferon for the treatment of chronic hepatitis C infection: a randomized, placebo-controlled double-blind trial. Hepatology. 1998;27(4):1128-35. [pmid: 9537454].
Sheth S G, Flamm S L, Gordon F D, et al. AST/ALT ratio predicts cirrhosis in patients with chronic hepatitis C virus infection. American Journal of Gastroenterology. 1998;93(1):44-8. [pmid: 9448172].
Shibata M, Morizane T, Uchida T, et al. Irregular regeneration of hepatocytes and risk of hepatocellular carcinoma in chronic hepatitis and cirrhosis with hepatitis-C-virus infection. Lancet. 1998;351(9118):1773-7. [pmid: 9635950].
Shiffman M L, Hofmann C M, Contos M J, et al. A randomized, controlled trial of maintenance interferon therapy for patients with chronic hepatitis C virus and persistent viremia. Gastroenterology. 1999;117(5):1164-72. [pmid: 10535880].
Shiffman M L, Hofmann C M, Gabbay J, et al. Treatment of chronic hepatitis C in patients who failed interferon monotherapy: effects of higher doses of interferon and ribavirin combination therapy. American Journal of Gastroenterology. 2000a;95(10):2928-35. [pmid: 11051370].
Sherman K E, Lewey S M, Goodman Z D. Talc in the liver of patients with chronic hepatitis C infection. American Journal of Gastroenterology. 1995;90(12):2164-6. [pmid: 8540508].
Shiffman M L, Hofmann C M, Luketic V A, et al. Use of granulocyte macrophage colony stimulating factor alone or in combination with interferon-alpha-2b for treatment of chronic hepatitis C. Journal of Hepatology. 1998;28(3):382-9. [pmid: 9551674].
Shiffman M L, Hofmann C M, Luketic V A C, et al. Improved sustained response following treatment of chronic hepatitis C by gradual reduction in the interferon dose. Hepatology. 1996;24(1):21-6. [pmid: 8707264].
Shiffman ML, Hofmann CM, Sterling RK, Luketic VA, Contos MJ, Sanyal AJ. A randomized controlled trial to determine whether continued ribavirin monotherapy in hepatitis C virus-infected patients who responded to interferon-ribavirin combination therapy will enhance sustained virologic response. 2001;184:405–9.
Shiffman M L, Hofmann C M, Thompson E B, et al. Relationship between biochemical, virological, and histological response during interferon treatment of chronic hepatitis C. Hepatology. 1997;26(3):780-5. [pmid: 9303513].
Shiffman M L, Stewart C A, Hofmann C M, et al. Chronic infection with hepatitis C virus in patients with elevated or persistently normal serum alanine aminotransferase levels: comparison of hepatic histology and response to interferon therapy. J Infect Dis. 2000;182(6):1595-601. [pmid: 11069229].
Shima T, Tada H, Morimoto M, et al. Serum total bile acid level as a sensitive indicator of hepatic histological improvement in chronic hepatitis C patients responding to interferon treatment. Journal of Gastroenterology and Hepatology. 2000;15(3):294-9. [pmid: 10764031].
Shimizu I, Omoya T, Takaoka T, et al. Hepatitis C virus infection: clinical, virologic and pathologic features: serum amino-terminal propeptide of type III procollagen and 7S domain of type IV collagen correlate with hepatic iron concentration in patients with chronic hepatitis C following alpha - interferon therapy. Journal of Gastroenterology and Hepatology. 2001;16(2):196-201. [pmid: 11207901].
Shindo M, Arai K, Okuno T. The clinical value of grading and staging scores for predicting a long-term response and evaluating the efficacy of interferon therapy in chronic hepatitis C. Journal of Hepatology. 1997;26(3):492-7. [pmid: 9075654].
Shindo M, Hamada K, Oda Y, et al. Long-term follow-up study of sustained biochemical responders with interferon therapy. Hepatology. 2001;33(5):1299-302. [pmid: 11343259].
Shinzawa H, Yoshida Y, Masamune O, et al. Analysis of biochemical and virological efficacy of human lymphoblastoid interferon (IFN) in patients with compensated type C liver cirrhosis: comparative study between increase in individual IFN dose and prolonging of treatment period, using a multicenter randomized controlled trial. Digestive Diseases and Sciences. 2000;45(3):575-80. [pmid: 10749335].
Shiratori Y, Imazeki F, Moriyama M, et al. Histologic improvement of fibrosis in patients with hepatitis C who have sustained response to interferon therapy. Annals of Internal Medicine. 2000;132(7):517-24. [pmid: 10744587].
Shiratori Y, Kato N, Yokosuka O, et al. Predictors of the efficacy of interferon therapy in chronic hepatitis C virus infection. Gastroenterology. 1997;113(2):558-66. [pmid: 9247476].
Siciliano R, Carra R, Elia G, et al. Chronic hepatitis C in elderly patients: clinical, histological and virological features. Arch Gerontol Geriatr. 1996;0(SUPPL. 5):327-33. [pmid: 18653052].
Silini E, Bottelli R, Asti M, et al. Hepatitis-C virus gentotypes and risk of hepatocellular-carcinoma in cirrhosis - a case-control study. Gastroenterology. 1996;111(1):199-205. [pmid: 8698200].
Smith B C, Grove J, Guzail M A, et al. Heterozygosity for hereditary hemochromatosis is associated with more fibrosis in chronic hepatitis C. Hepatology. 1998;27(6):1695-9. [pmid: 9620344].
Sobesky R, Mathurin P, Charlotte F, et al. Modeling the impact of interferon alfa treatment on liver fibrosis progression in chronic hepatitis C: a dynamic view. Gastroenterology. 1999;116(2):378-86. [pmid: 9922319].
Solmi L, Primerano A M M, Gandolfi L. Ultrasound follow-up of patients at risk for hepatocellular-carcinoma - results of a prospective study on 360 cases. American Journal of Gastroenterology. 1996;91(6):1189-94. [pmid: 8651169].
Songsivilai S, Dharakul T, Senawong S. Hepatitis B- and hepatitis C-associated hepatocellular carcinoma: evaluation of alpha-fetoprotein as a diagnostic marker. Asian Pacific Journal of Allergy and Immunology. 1995;13(2):167-71. [pmid: 8703246].
Soriano V, Bravo R, Garcia-Samaniego J, et al. A pilot study on the efficacy of escalating dosage of alpha-interferon for chronic hepatitis C in HIV-infected patients. The Hepatitis/HIV Spanish Study Group. Journal of Infection. 1997;35(3):225-30. [pmid: 9459392].
Soriano V, Garcia-Samaniego J, Bravo R, et al. Interferon alpha for the treatment of chronic hepatitis C in patients infected with human immunodeficiency virus. Clin Infect Dis. 1996;23(3):585-91. [pmid: 8879784].
Soto B, Sanchez-Quijano A, Rodrigo L, et al. Human immunodeficiency virus infection modifies the natural history of chronic parenterally-acquired hepatitis C with an unusually rapid progression to cirrhosis. Journal of Hepatology. 1997;26(1):1-5. [pmid: 9147999].
Stanley A J, Haydon G H, Piris J, et al. Assessment of liver histology in patients with hepatitis-C and normal transaminiase levels. Eur J Clin Gastroenterol Hepatol. 1996;8(9):869-72.
Suou T, Mitsuda A, Koda M, et al. Interferon alpha inhibits intrahepatic recurrence in hepatocellular carcinoma with chronic hepatitis C: a pilot study. Hepatology Research. 2001;20(3):301-11. [pmid: 11404190].
Tabon M, Laudi C, Delmastro B, et al. Interferon and amantadine in combination as initial treatment for chronic hepatitis C patients. Journal of Hepatology. 2001;35(4):517-21. [pmid: 11682037].
Takano S, Yokosuka O, Imazeki F, et al. Incidence of hepatocellular carcinoma in chronic hepatitis B and C: a prospective study of 251 patients. Hepatology. 1995;21:650-55. [pmid: 7875662].
Tamai T, Seki T, Shiro T, et al. Effects of alcohol consumption on histological changes in chronic hepatitis C: a clinicopathological study. Alcoholism, Clinical and Experimental Research. 2000;24(4 Suppl):106S-11S.
Tanaka H, Tsukuma H, Kasahara A, et al. Effect of interferon therapy on the incidence of hepatocellular carcinoma and mortality of patients with chronic hepatitis C: a retrospective cohort study of 738 patients. International Journal of Cancer. 2000;87(5):741-9.
Tanaka K, Ikematsu H, Hirohata T, et al. Hepatitis-C virus-infection and risk of hepatocellular-carcinoma among Japanese - possible role of type 1B-(II) infection. J Nat Cancer Inst. 1996;88(11):742-6. [pmid: 8637028].
Tappero G, Farina M, Negro F, et al. Intrahepatic expression of c-fos, c-myb and c-myc oncogenes: correlation with virus-induced chronic liver disease and response to interferon. Ital J Gastroenterol and Hepatology. 1997;29(2):148-54.
Tassopoulos N C, Karvountzis G, Touloumi G, et al. Comparative efficacy of a high or low dose of interferon alpha 2b in chronic hepatitis C: a randomized controlled trial. American Journal of Gastroenterology. 1996;91(9):1734-8. [pmid: 8792690].
Terranova R, Luca S. Preliminary results of beta-interferon treatment in the elderly. Control Clin Trials. 1996;17(2):123-9. [pmid: 8860065].
Teuber G, Berg T, Naumann U, et al. Randomized, placebo-controlled, double-blind trial with interferon-alpha with and without amantadine sulphate in primary interferon-alpha nonresponders with chronic hepatitis C. Journal of Viral Hepatitis. 2001;8(4):276-83. [pmid: 11454179].
Thavarungkul P, Toriyama K, Kusuda M, et al. Clinico-pathological predictive factors of response to interferon therapy in chronic hepatitis C. Southeast Asian Journal of Tropical Medicine and Public Health. 1996;27(1):85-90. [pmid: 9031407].
Thomas D L, Astemborski J, Rai R M, et al. The natural history of hepatitis C virus infection. JAMA. 2000;284(4):450-6. [pmid: 10904508].
Toccaceli F, Russo V, Rosati S, et al. Therapy of chronic hepatitis C with leukocyte interferon- alpha. Mediterranean Journal of Infectious and Parasitic Diseases. 1996;11(1):33-9.
Tong M J, Blatt L M, Kao V W. Surveillance for hepatocellular carcinoma in patients with chronic viral hepatitis in the United States of America. Journal of Gastroenterology and Hepatology. 2001;16(5):553-9. [pmid: 11350553].
Tong M J, Elfarra N S. Clinical sequalae of hepatitis-C acquired from injection-drug use. West J Med. 1996;164(5):399-404. [pmid: 8686295]. [pmcid: 1303536].
Tong M J, Lai L P, MurakamiMori K. Development of hepatocellular carcinoma after clearance of hepatitis C virus with interferon therapy. West J Med. 1997;167(2):103-5. [pmid: 9291751]. [pmcid: 1304438].
Tong M J, Reddy K R, Lee W M, et al. Treatment of chronic hepatitis C with consensus interferon: a multicenter, randomized, controlled trial. Hepatology. 1997;26(3):747-54. [pmid: 9303508].
Toyoda H, Kumada T, Nakano S, et al. Effect of the dose and duration of interferon-alpha therapy on the incidence of hepatocellular carcinoma in noncirrhotic patients with a nonsustained response to interferon for chronic hepatitis C. Oncology. 2001;61(2):134-42. [pmid: 11528252].
Toyoda H, Nakano S, Kumada T, et al. Effect of daily administration period of natural alpha-interferon in patients with chronic hepatitis-C. American Journal of Gastroenterology. 1996;91(4):743-7. [pmid: 8677941].
Tradati F, Colombo M, Mannucci P M, et al. A prospective multicenter study of hepatocellular carcinoma in italian hemophiliacs with chronic hepatitis C. The Study Group of the Association of Italian Hemophilia Centers. Blood. 1998;91(4):1173-7. [pmid: 9454746].
Tran A, Longo F, Ouzan D, et al. Effects of 1-year interferon-alpha 2a treatment in patients with chronic hepatitis C and persistently normal transaminase activity. Scandinavian Journal of Gastroenterology. 2000;35(4):433-7. [pmid: 10831269].
Trevisani F, D'Intino P E, Caraceni P, et al. Etiologic factors and clinical presentation of hepatocellular carcinoma. Cancer. 1995;75:2220-32. [pmid: 7536121].
Tripi S, DiGaetano G, Soresi M, et al. Interferon-alpha alone versus interferon-alpha plus ribavirin in patients with chronic hepatitis C not responding to previous interferon-alpha treatment. Biodrugs. 2000;13(4):299-304. [pmid: 18034536].
Tsai J-F, Chang W Y, Jeng J E, et al. Frequency of raised alpha-fetoprotein level among Chinese patients with hepatocellular carcinoma related to hepatitis B and C. Br J Cancer. 1994;69(6):1157-9. [pmid: 7515263].
Tsai J F, Jeng J E, Chuang L Y, et al. Urinary transforming growth factor beta(1) levels in hepatitis C virus-related chronic liver disease: correlation between high levels and severity of disease. Hepatology. 1997;25(5):1141-6. [pmid: 9141431].
Tsai J F, Jeng J E, Chuang L Y, et al. Clinical evaluation of urinary transforming growth factor-beta 1 and serum alpha-fetoprotein as tumour markers of hepatocellular carcinoma. Br J Cancer. 1997;75(10):1460-6. [pmid: 9166938].
Tsai J F, Jeng J E, Ho M S, et al. Effect of hepatitis C and B virus infection on risk of hepatocellular carcinoma: a prospective study. Br J Cancer. 1997;76(7):968-74. [pmid: 9328161].
Tsai J F, Jeng J E, Ho M S, et al. Clinical evaluation of serum alpha-getoprotein and circulating immune complexes as tumour markers of hepatocellular carcinoma. Br J Cancer. 1995;72:442-6. [pmid: 7543774].
Tsubota A, Kumada H, Arase Y, et al. Combined ursodeoxycholic acid and glycyrrhizin therapy for chronic hepatitis C virus infection: a randomized controlled trial in 170 patients. European Journal of Gastroenterology and Hepatology. 1999;11(10):1077-83. [pmid: 10524635].
Tsubota A, Kumada H, Chayama K, et al. Relationship between pretreatment viermia level and response to interferon-alpha therapy in chronic hepatitis-C differs in viral type-1 and type-2 infections. Digestive Diseases and Sciences. 1996;41(10):1925-32. [pmid: 8888702].
Tsushima H, Kawata S, Tamura S, et al. Reduced plasma transforming growth factor-beta1 levels in patients with chronic hepatitis C after interferon-alpha therapy: association with regression of hepatic fibrosis. Journal of Hepatology. 1999;30(1):1-7. [pmid: 9927144].
Tsuzurahara S, Sata M, Iwamoto O, et al. Detection of MAGE-4 protein in the sera of patients with hepatitis-C virus-associated hepatocellular carcinoma and liver cirrhosis. Japanese Journal of Cancer Research. 1997;88(9):915-8. [pmid: 9369941].
Ueno T, Ide T, Hashimoto O, et al. Long-term follow-up of interferon-treated chronic hepatitis C and serum hepatic fibrosis markers. Hepatogastroenterology. 2001;48(40):1124-8. [pmid: 11490815].
Unoura M, Kaneko S, Matsushita E, et al. High-risk groups and screening strategies for early detection of hepatocellular carcinoma in patients with chronic liver disease. Hepatogastroenterology. 1993;40:305-10. [pmid: 8406298].
Utili R, Zampino R, Bellopede P, et al. Dual or single hepatitis B and C virus infections in childhood cancer survivors: long-term follow-up and effect of interferon treatment. Blood. 1999;94(12):4046-52. [pmid: 10590048].
Valla D C, Chevallier M, Marcellin P, et al. Treatment of hepatitis C virus-related cirrhosis: a randomized, controlled trial of interferon alfa-2b versus no treatment. Hepatology. 1999;29(6):1870-5. [pmid: 10347132].
van Rossum T G, Vulto A G, Hop W C, et al. Intravenous glycyrrhizin for the treatment of chronic hepatitis C: a double-blind, randomized, placebo-controlled phase I/II trial. Journal of Gastroenterology and Hepatology. 1999;14(11):1093-9. [pmid: 10574137].
Van Thiel D H, Friedlander L, Molloy P J, et al. Retreatment of hepatitis C interferon non-responders with larger doses of interferon with and without phlebotomy. Hepatogastroenterology. 1996;43(12):1557-61. [pmid: 8975965].
Vandelli C, Renzo F, Braun H B, et al. Prediction of successful outcome in a randomised controlled trial of the long-term efficacy of interferon alpha treatment for chronic hepatitis C. Journal of Medical Virology. 1999;58(1):26-34. [pmid: 10223542].
VanRoey G, Fevery J, VanSteenbergen W. Hepatocellular carcinoma in Belgium: clinical and virological characteristics of 154 consecutive cirrhotic and non-cirrhotic patients. Eur J Clin Gastroenterol Hepatol. 2000;12(1):61-6.
Verbaan H, Bondeson L, Eriksson S. Non-invasive assessment of inflammatory activity and fibrosis (grade and stage) in chronic hepatitis C infection. Scandinavian Journal of Gastroenterology. 1997;32(5):494-9. [pmid: 9175214].
Villa E, Grottola A, Buttafoco P, et al. High doses of alpha-interferon are required in chronic hepatitis due to coinfection with hepatitis B virus and hepatitis C virus: long term results of a prospective randomized trial. American Journal of Gastroenterology. 2001;96(10):2973-7. [pmid: 11693335].
Villa E, Trande P, Grottola A, et al. Alpha but not beta interferon is useful in chronic active hepatitis due to hepatitis C virus: a prospective, double-blind, randomized study. Digestive Diseases and Sciences. 1996;41(6):1241-7. [pmid: 8654159].
Villeneuve J P, Desrochers M, Infante-Rivard C, et al. A long-term follow-up study of asymptomatic hepatitis B surface antigen-positive carriers in Montreal. Gastroenterology. 1994;106(4):1000-5. [pmid: 8143967].
Wali M, Lewis S, Hubscher S, et al. Histological progression during short-term follow-up of patients with chronic hepatitis C virus infection. Journal of Viral Hepatitis. 1999;6(6):445-52. [pmid: 10607262].
Walsh K M, Fletcher A, MacSween R N, et al. Basement membrane peptides as markers of liver disease in chronic hepatitis C. Journal of Hepatology. 2000;32(2):325-30. [pmid: 10707874].
Walsh K M, Fletcher A, MacSween R N, et al. Comparison of assays for N-amino terminal propeptide of type III procollagen in chronic hepatitis C by using receiver operating characteristic analysis. European Journal of Gastroenterology and Hepatology. 1999;11(8):827-31. [pmid: 10514112].
Walsh K M, Timms P, Campbell S, et al. Plasma levels of matrix metalloproteinase-2 (MMP-2) and tissue inhibitors of metalloproteinases -1 and -2 (TIMP-1 and TIMP-2) as noninvasive markers of liver disease in chronic hepatitis C: comparison using ROC analysis. Digestive Diseases and Sciences. 1999a;44(3):624-30. [pmid: 10080160].
Weiss G, Umlauft F, Urbanek M, et al. Associations between cellular immune effector function, iron metabolism, and disease activity in patients with chronic hepatitis C virus infection. J Arch Infect Dis. 1999;180(5):1452-8.
Wesche B, Jaeckel E, Trautwein C, et al. Induction of autoantibodies to the adrenal cortex and pancreatic islet cells by interferon alpha therapy for chronic hepatitis C. Gut. 2001;48(3):378-83. [pmid: 11171829]. [pmcid: 1760154].
Wong V S, Baglin T, Beacham E, et al. The role for liver biopsy in haemophiliacs infected with the hepatitic virus. Br J Haematol. 1997;97(2):343-7. [pmid: 9163600].
Wong V S, Hughes V, Trull A, et al. Serum hyaluronic acid is a useful marker of liver fibrosis in chronic hepatitis C virus infection. Journal of Viral Hepatitis. 1998;5(3):187-92. [pmid: 9658372].
Wong V S, Wight D G D, Palmer C R, et al. Fibrosis and other histological features in chronic hepatitis C virus infection: a statistical model. J Clin Pathol. 1996;49(6):465-9. [pmcid: 500535]. [pmid: 8763259].
Yabuuchi I, Imai Y, Kawata S, et al. Long-term responders without eradication of hepatitis C virus after interferon therapy: characterization of clinical profiles and incidence of hepatocellular carcinoma. Liver. 2000;20(4):290-5. [pmid: 10959807].
Yagura M, Murai S, Kojima H, et al. Changes of liver fibrosis in chronic hepatitis C patients with no response to interferon-alpha therapy: including quantitative assessment by a morphometric method. Journal of Gastroenterology. 2000;35(2):105-11. [pmid: 10680665].
Yagura M, Murai S, Kojima H, et al. Does the control of alanine aminotransferase levels lead to a regression of liver fibrosis in chronic hepatitis C patients?. Hepatology Research. 2001;19(2):144-57. [pmid: 11164739].
Yamada M, Fukuda Y, Koyama Y, et al. Serum hyaluronic acid reflects the effect of interferon treatment on hepatic fibrosis in patients with chronic hepatitis C. Journal of Gastroenterology and Hepatology. 1996;11(7):646-51. [pmid: 8840240].
Yamada M, Fukuda Y, Nakano I, et al. Serum hyaluronan as a marker of liver fibrosis in hemophiliacs with hepatitis C virus-associated chronic liver disease. Acta Haematologica. 1998;99(4):212-6. [pmid: 9644299].
Yamanaka N, Tanaka T, Tanaka W, et al. Correlation of hepatitis virus serologic status with clinicopathologic features in patients undergoing hepatectomy for hepatocellular carcinoma. Cancer. 1997;79(8):1509-15. [pmid: 9118031].
Yano M, Kumada H, Kage M, et al. The long-term pathological evolution of chronic hepatitis C. Hepatology. 1996;23(6):1334-40. [pmid: 8675148].
Yao G, Ji Y, Yang M, et al. Long-term efficacy of recombinant interferon alpha 2a in the treatment of chronic hepatitis C: a randomized prospective study comparing two dose schedules in Chinese patients. Chinese Medical Journal. 1998;111(10):922-6. [pmid: 11189241].
Yao G B, Fu X X, Tian G S, et al. A multicenter, randomized, controlled trial of interferon alfacon-1 compared with alpha-2a-interferon in Chinese patients with chronic hepatitis C virus infection. Journal of Gastroenterology and Hepatology. 2000;15(10):1165-70. [pmid: 11106097].
Yao G B, Ji Y Y, Xu D Z, et al. Long-term efficacy of recombinant interferon alpha 2a in the treatment of chronic hepatitis C: a randomized prospective study comparing two dose schedules in Chinese patients. Hepatogastroenterology. 1999;46(26):1059-64. [pmid: 10370667].
Yasunami R, Miyamoto T, Kanda T. HLA-DRB1 is related to the pathological changes of the liver in chronic hepatitis C. Hepatology Research. 1997;7(1):3-12.
Yatsuhashi H, Yano M. Natural history of chronic hepatitis C. Journal of Gastroenterology and Hepatology. 2000;15(Suppl):E111-6. [pmid: 10921392].
Yeo A E T, Ghany M, Conry-Cantilena C, et al. Stability of HCV-RNA level and its lack of correlation with disease severity in asymptomatic chronic hepatitis C virus carriers. Journal of Viral Hepatitis. 2001;8(4):256-63. [pmid: 11454176].
Yoshida H, Shiratori Y, Moriyama M, et al. Interferon therapy reduces the risk for hepatocellular carcinoma: national surveillance program of cirrhotic and noncirrhotic patients with chronic hepatitis C in Japan. IHIT Study Group. Inhibition of Hepatocarcinogenesis by Interferon Therapy. Annals of Internal Medicine. 1999;131(3):174-81. [pmid: 10428733].
Yoshimura E, Hayashi J, Kishihara Y, et al. Evaluation of quantitative assay for antibody to hepatitis-C virus score in patients treated with interferon. Digestive Diseases and Sciences. 1996;41(1):155-60. [pmid: 8565749].
Yoshioka K, Yano M, Kusakabe A, et al. Randomized controlled trial of lymphoblastoid interferon alpha for chronic hepatitis C (comparison of 9-MU and 6-MU doses). IFN Treatment Group of Affiliated Hospitals of the Third Department of Internal Medicine at Nagoya University School of Medicine. American Journal of Gastroenterology. 1999;94(1):164-8. [pmid: 9934749].
Younossi Z M, Mullen K D, Zakko W, et al. A randomized, double-blind controlled trial of interferon alpha-2b and ribavirin vs. interferon alpha-2b and amantadine for treatment of chronic hepatitis C non-responder to interferon monotherapy. Journal of Hepatology. 2001;34(1):128-33. [pmid: 11211889].
Zardi E M, Toccaceli F, Russo V, et al. Chronic hepatitis C virus infection: detection of hepatocellular carcinoma by means of contrast-enhanced color doppler liver sonography. American Journal of Gastroenterology. 2000;95(10):2996-8. [pmid: 11051396].
Zarski J P, Bohn B, Bastie A, et al. Characteristics of patients with dual infection by hepatitis B and C viruses. Journal of Hepatology. 1998;28(1):27-33. [pmid: 9537860].
Zarski J P, Maynard-Muet M, Chousterman S, et al. Tenoxicam, a non-steroid anti-inflammatory drug, is unable to increase the response rate in patients with chronic hepatitis C treated by alpha interferon. Hepatology. 1998;27(3):862-7. [pmid: 9500719].
Zeuzem S, Feinman S V, Rasenack J, et al. Peginterferon alfa-2a in patients with chronic hepatitis C. New England Journal of Medicine. 2000a;343(23):1666-72. [pmid: 11106715].
Zeuzem S, Teuber G, Naumann U, et al. Randomized, double-blind, placebo-controlled trial of interferon alfa-2a with and without amantadine as initial treatment for chronic hepatitis C. Hepatology. 2000;32(4 Pt 1):835-41. [pmid: 11003631].
Ziol M, Tran Van N J, Roudot-Thoraval F, et al. A histopathological study of the effects of 6-month versus 12-month interferon alpha-2b therapy in chronic hepatitis C. Journal of Hepatology. 1996;25(6):833-41. [pmid: 9007710].
Zylberberg H, Rimaniol A C, Pol S, et al. Soluble tumor necrosis factor receptors in chronic hepatitis C: a correlation with histological fibrosis and activity. Journal of Hepatology. 1999;30(2):185-91. [pmid: 10068094].