# Reference List

1 Alter M J, Kruszon-Moran D, Nainan O V, et al. The prevalence of hepatitis C virus infection in the United States, 1988 through 1994. New England Journal of Medicine. 1999;341(8):556-2. [pmid: 10451460].
2 Conry-Cantilena C. Hepatitis C virus diagnostics: technology, clinical applications and impacts. Trends in Biotechnology. 1997;15(2):71-6. [pmid: 9081301].
3 National Institutes of Health Consensus Development Conference Panel statement: management of hepatitis C Hepatology 1997;26(3 Suppl 1):2S-10S
4 EASL International Consensus Conference on Hepatitis C Paris, 26–28, February 1999, Consensus Statement. European Association for the Study of the Liver. Journal of Hepatology 1999;30(5);956–61.
5 Fattovich G, Giustina G, Degos F, et al. Effectiveness of interferon alfa on incidence of hepatocellular carcinoma and decompensation in cirrhosis type C. Journal of Hepatology. 1997;27(1):201-5. [pmid: 9252096].
6 Soto B, Sanchez-Quijano A, Rodrigo L et-al. Human immunodeficiency virus infection modifies the natural history of chronic parenterally-acquired hepatitis C with an unusually rapid progression to cirrhosis. Journal of Hepatology 1997;26(1):1–5.Comment in: J Hepatol. 1997 Nov;27(5):953–4.
7 Quan C M, Krajden M, Grigoriew G A, et al. Hepatitis C virus infection in patients infected with the human immunodeficiency virus. Clin Infect Dis. 1993;17(1):117-9. [pmid: 7688986].
8 Darby S C, Ewart D W, Giangrande P L F, et al. Mortality from liver cancer and liver disease in hemophilic men and boys in UK given blood products contaminated with hepatitis C. Lancet. 1997;350:1425-31. [pmid: 9371165].
9 Poynard T, Bedossa P, Opolon P. Natural history of liver fibrosis progression in patients with chronic hepatitis C. The OBSVIRC, METAVIR, CLINIVIR, and DOSVIRC groups. Lancet. 1997;349(9055):825-32. [pmid: 9121257].
10 Sanchez-Quijano A, Andreu J, Gavilan F, et al. Influence of human immunodeficiency virus type 1 infection on the natural course of chronic parenterally acquired hepatitis C. European Journal of Clinical Microbiology and Infectious Diseases. 1995;14(11):949-53.
11 Zarski J P, Bohn B, Bastie A, et al. Characteristics of patients with dual infection by hepatitis B and C viruses. Journal of Hepatology. 1998;28(1):27-33. [pmid: 9537860].
12 Glue P, Rouzier-Panis R, Raffanel C, et al. A dose-ranging study of pegylated interferon alfa-2b and ribavirin in chronic hepatitis C. The Hepatitis C Intervention Therapy Group. Hepatology. 2000;32(3):647-53. [pmid: 10960463].
13 Lindsay K L, Trepo C, Heintges T, et al. A randomized, double-blind trial comparing pegylated interferon alfa-2b to interferon alfa-2b as initial treatment for chronic hepatitis C. Hepatology. 2001;34(2):395-403. [pmid: 11481625].
14 Conferences - Management of Hepatitis C 2002.2001; accessed 2002.Web Page. Available at: http://odp.od.nih.gov/consensus/news/upcoming/hepc/hepc_info.htm.
15 Berlin J. Does blinding of readers affect the results of meta-analyses?. Lancet. 1997;350:185-6. [pmid: 9250191].
16 Garbutt J C, West S L, Carey T S, et al. Pharmacological treatment of alcohol dependence: a review of the evidence. JAMA. 1999;281(14):1318-25. [pmid: 10208148].
17 Scheim OD, Friedman DS, Fleisher LA, et al. Anesthesia Managment During Cataract Surgery. Evidence Report/Technology Assessment No. 16 (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-097-0006.) AHRQ Publication No. 01-E017.Rockville, MD: Agency for Healthcare Research and Quality; 2001
18 Manns M P, McHutchison J G, Gordon S C, et al. Peginterferon alfa-2b plus ribavirin compared with interferon alfa-2b plus ribavirin for initial treatment of chronic hepatitis C: a randomised trial. Lancet. 2001;358(9286):958-65. [pmid: 11583749].
19 Saracco G, Ciancio A, Olivero A, et al. A randomized 4-arm multicenter study of interferon alfa-2b plus ribavirin in the treatment of patients with chronic hepatitis C not responding to interferon alone. Hepatology. 2001;34(1):133-8. [pmid: 11431744].
20 McHutchison J G, Poynard T, Pianko S, et al. The impact of interferon plus ribavirin on response to therapy in black patients with chronic hepatitis C. The International Hepatitis Interventional Therapy Group. Gastroenterology. 2000;119(5):1317-23. [pmid: 11054390].
21 Mangia A, Villani M R, Minerva N, et al. Efficacy of 5 MU of interferon in combination with ribavirin for naive patients with chronic hepatitis C virus: a randomized controlled trial. Journal of Hepatology. 2001;34(3):441-6. [pmid: 11322207].
22 Zeuzem S, Feinman S V, Rasenack J, et al. Peginterferon alfa-2a in patients with chronic hepatitis C. New England Journal of Medicine. 2000a;343(23):1666-72. [pmid: 11106715].
23 Payen J L, Izopet J, Galindo-Migeot V, et al. Better efficacy of a 12-month interferon alfa-2b retreatment in patients with chronic hepatitis C relapsing after a 6-month treatment: a multicenter, controlled, randomized trial. Le Groupe D'etude et De Traitement du Virus De L'hepatite C (Get.Vhc). Hepatology. 1998;28(6):1680-6. [pmid: 9828235].
24 Kumada T, Nakana S, Takeda I, et al. Long-term administration of natural interferon-alpha in patients with chronic hepatitis-C - relationship to serum RNA concentration, HCV-RNA genotypes, histological-changes and hepatitis-C virus. Journal of Gastroenterology and Hepatology. 1996;11(2):159-65. [pmid: 8672762].
25 Zeuzem S, Teuber G, Naumann U, et al. Randomized, double-blind, placebo-controlled trial of interferon alfa-2a with and without amantadine as initial treatment for chronic hepatitis C. Hepatology. 2000;32(4 Pt 1):835-41. [pmid: 11003631].
26 Angelico M, Cepparulo M, Barlattani A, et al. Unfavourable effects of colchicine in combination with interferon-alpha in the treatment of chronic hepatitis C. Alimentary Pharmacology and Therapeutics. 2000;14(11):1459-67. [pmid: 11069317].
27 Shiffman M L, Stewart C A, Hofmann C M, et al. Chronic infection with hepatitis C virus in patients with elevated or persistently normal serum alanine aminotransferase levels: comparison of hepatic histology and response to interferon therapy. J Infect Dis. 2000;182(6):1595-601. [pmid: 11069229].
28 Ascione A, De Luca M, Canestrini C, et al. Efficacy of high dose of recombinant alpha 2b interferon on long term response in chronic hepatitis C and cirrhosis: prospective randomized multicentre study. Ital J Gastroenterol and Hepatology. 1998;30(5):517-23.
29 Saracco G, Borghesio E, Mesina P, et al. Prolonged treatment (2 years) with different doses (3 versus 6 Mu) of interferon alpha-2b for chronic hepatitis type C: results of a multicenter randomized trial. Journal of Hepatology. 1997;27(1):56-62. [pmid: 9252074].
30 Craxi A, Di Marco V, Iacono O L, et al. Transfusion-associated chronic hepatitis C: alpha-N-1 interferon for 6 vs. 12 months. Journal of Hepatology. 1996;24(5):539-46. [pmid: 8773908].
31 Villa E, Grottola A, Buttafoco P, et al. High doses of alpha-interferon are required in chronic hepatitis due to coinfection with hepatitis B virus and hepatitis C virus: long term results of a prospective randomized trial. American Journal of Gastroenterology. 2001;96(10):2973-7. [pmid: 11693335].
32 Shiffman M L, Hofmann C M, Gabbay J, et al. Treatment of chronic hepatitis C in patients who failed interferon monotherapy: effects of higher doses of interferon and ribavirin combination therapy. American Journal of Gastroenterology. 2000a;95(10):2928-35. [pmid: 11051370].
33 Di Bisceglie A M, Thompson J, Smith-Wilkaitis N, et al. Combination of interferon and ribavirin in chronic hepatitis C: re-treatment of nonresponders to interferon. Hepatology. 2001;33(3):704-7. [pmid: 11230751].
34 Mangia A, Minerva N, Annese M, et al. A randomized trial of amantadine and interferon versus interferon alone as initial treatment for chronic hepatitis C. Hepatology. 2001a;33(4):989-93. [pmid: 11283865].
35 Villa E, Trande P, Grottola A, et al. Alpha but not beta interferon is useful in chronic active hepatitis due to hepatitis C virus: a prospective, double-blind, randomized study. Digestive Diseases and Sciences. 1996;41(6):1241-7. [pmid: 8654159].
36 Berg T, Hoffmann R M, Teuber G, et al. Efficacy of a short-term ribavirin plus interferon alpha combination therapy followed by interferon alpha alone in previously untreated patients with chronic hepatitis C: a randomized multicenter trial. Liver. 2000;20(6):427-36. [pmid: 11169056].
37 Heathcote E J, Shiffman M L, Cooksley W G, et al. Peginterferon alfa-2a in patients with chronic hepatitis C and cirrhosis. New England Journal of Medicine. 2000;343(23):1673-80. [pmid: 11106716].
38 Fortunato G, Castaldo G, Oriani G, et al. Multivariate discriminant function based on six biochemical markers in blood can predict the cirrhotic evolution of chronic hepatitis. Clin Chem. 2001;47(9):1696-700. [pmid: 11514405].
39 Poynard T, Bedossa P, BioulacSage P, et al. Age and platelet count: A simple index for predicting the presence of histological lesions in patients with antibodies to hepatitis C virus. Journal of Viral Hepatitis. 1997;4(3):199-208. [pmid: 9181529].
40 Imbert-Bismut F, Ratziu V, Pieroni L, Charlotte, Benhamou Y, Poynard T. Biochemical markers of liver fibrosis in patients with hepatitis C virus infection: a prospective study. Lancet. 2001;357:1069-75. [pmid: 11297957].
41 Choi Y, Putti T, Win K, et al. Correlation of viral RNA, alanine aminotransferase, and histopathology in hepatitis C virus-associated hepatitis. Molecular Diagnosis. 1999;4(3):251-4. [pmid: 10553026].
42 Goldstein N S, Blue D E, Hankin R, et al. Serum alpha-fetoprotein levels in patients with chronic hepatitis C - relationships with serum alanine aminotransferase values, histologic activity index, and hepatocyte MIB-1 scores. Am J Clin Pathol. 1999;111(6):811-6. [pmid: 10361518].
43 Michielsen P P, Hauben E I, Ramon A M, et al. Serum aminotransferase levels and histological disease in chronic hepatitis C. Acta Gastro-Enterologica Belgica. 1997;60(1):11-4. [pmid: 9144972].
44 Stanley A J, Haydon G H, Piris J, et al. Assessment of liver histology in patients with hepatitis-C and normal transaminiase levels. Eur J Clin Gastroenterol Hepatol. 1996;8(9):869-72.
45 Assy N, Minuk G Y. Serum aspartate but not alanine aminotransferase levels help to predict the histological features of chronic hepatitis C viral infections in adults. American Journal of Gastroenterology. 2000;95(6):1545-50. [pmid: 10894594].
46 Barbaro G, Di Lorenzo G, Soldini M/Parrotto S, et al. Hepatic glutathione deficiency in chronic hepatitis C: quantitative evaluation in patients who are HIV positive and HIV negative andcorrelations with plasmatic and lymphocytic concentrations and with the activity of liver disease. American Journal of Gastroenterology. 1996;91(12):2569-73. [pmid: 8946988].
47 Jamal M M, Soni A, Quinn P G, et al. Clinical features of hepatitis C-infected patients with persistently normal alanine transaminase levels in the Southwestern United States. Hepatology. 1999;30(6):1307-11. [pmid: 10534355].
48 Luo J C, Hwang S J, Lai C R, et al. Relationships between serum aminotransferase levels, liver histologies and virological status in patients with chronic hepatitis C in Taiwan. Journal of Gastroenterology and Hepatology. 1998;13(7):685-90. [pmid: 9715418].
49 McCormick S E, Goodman Z D, Maydonovitch C L, et al. Evaluation of liver histology, ALT elevation, and HCV RNA titer in patients with chronic hepatitis C. American Journal of Gastroenterology. 1996;91(8):1516-22. [pmid: 8759653].
50 Murawaki Y, Ikuta Y, Okamoto K, et al. Diagnostic value of serum markers of connective tissue turnover for predicting histological staging and grading in patients with chronic hepatitis C. Journal of Gastroenterology. 2001a;36(6):399-406. [pmid: 11428586].
51 Ono E, Shiratori Y, Okudaira T, et al. Platelet count reflects stage of chronic hepatitis C. Hepatology Research. 1999;15(3):192-200.
52 Walsh K M, Fletcher A, MacSween R N, et al. Comparison of assays for N-amino terminal propeptide of type III procollagen in chronic hepatitis C by using receiver operating characteristic analysis. European Journal of Gastroenterology and Hepatology. 1999;11(8):827-31. [pmid: 10514112].
53 Walsh K M, Fletcher A, MacSween R N, et al. Basement membrane peptides as markers of liver disease in chronic hepatitis C. Journal of Hepatology. 2000;32(2):325-30. [pmid: 10707874].
54 Yeo A E T, Ghany M, Conry-Cantilena C, et al. Stability of HCV-RNA level and its lack of correlation with disease severity in asymptomatic chronic hepatitis C virus carriers. Journal of Viral Hepatitis. 2001;8(4):256-63. [pmid: 11454176].
55 Anderson F H, Zeng L C, Rock N R, et al. An assessment of the clinical utility of serum ALT and AST in chronic hepatitis C. Hepatol Res. 2000;18(1):63-71. [pmid: 10838037].
56 Imperiale T F, Said A T, Cummings O W, et al. Need for validation of clinical decision aids: use of the AST/ALT ratio in predicting cirrhosis in chronic hepatitis C. American Journal of Gastroenterology. 2000;95(9):2328-32. [pmid: 11007237].
57 Park G J-H, Lin B P C, Ngu M C, et al. Aspartate aminotransferase: alanine aminotransferase ratio in chronic hepatitis C infection: is it a useful predictor of cirrhosis?. Journal of Gastroenterology and Hepatology. 2000;15(4):386-90. [pmid: 10824882].
58 Sheth S G, Flamm S L, Gordon F D, et al. AST/ALT ratio predicts cirrhosis in patients with chronic hepatitis C virus infection. American Journal of Gastroenterology. 1998;93(1):44-8. [pmid: 9448172].
59 Giannini E, Caglieris S, Ceppa P, et al. Serum pro-collagen III peptide levels are related to lobular necrosis in untreated patients with chronic hepatitis C. Eur J Clin Gastroenterol Hepatol. 2001;13(2):137-41.
60 Zylberberg H, Rimaniol A C, Pol S, et al. Soluble tumor necrosis factor receptors in chronic hepatitis C: a correlation with histological fibrosis and activity. Journal of Hepatology. 1999;30(2):185-91. [pmid: 10068094].
61 Izzo F, Curley S, Maio P, et al. Correlation of soluble interleukin-2 receptor levels with severity of chronic hepatitis-C virus liver-injury and development of hepatocellular cancer. Surgery. 1996;120(1):100-5. [pmid: 8693411].
62 Bayati N, Silverman A L, Gordon S C. Serum alpha-fetoprotein levels and liver histology in patients with chronic hepatitis C. American Journal of Gastroenterology. 1998;93(12):2452-6. [pmid: 9860408].
63 Chu C W, Hwang S J, Luo J C, et al. Clinical, virologic, and pathologic significance of elevated serum alpha-fetoprotein levels in patients with chronic hepatitis C. J Clin Gastroenterol. 2001;32(3):240-4. [pmid: 11246354].
64 Shima T, Tada H, Morimoto M, et al. Serum total bile acid level as a sensitive indicator of hepatic histological improvement in chronic hepatitis C patients responding to interferon treatment. Journal of Gastroenterology and Hepatology. 2000;15(3):294-9. [pmid: 10764031].
65 Verbaan H, Bondeson L, Eriksson S. Non-invasive assessment of inflammatory activity and fibrosis (grade and stage) in chronic hepatitis C infection. Scandinavian Journal of Gastroenterology. 1997;32(5):494-9. [pmid: 9175214].
66 Kjaergard L L, Krogsgaard K, Gluud C. Interferon alfa with or without ribavirin for chronic hepatitis C: systematic review of randomised trials. BMJ. 2001;323:1151-5. [pmcid: 59848]. [pmid: 11711405].
67 Cummings K J, Lee S M, West E S, et al. Interferon and ribavirin vs interferon alone in the re-treatment of chronic hepatitis C previously nonresponsive to interferon: a meta-analysis of randomized trials. JAMA. 2001;285(2):193-9. [pmid: 11176813].
68 Cheng S J, Bonis P A, Lau J, et al. Interferon and ribavirin for patients with chronic hepatitis C who did not respond to previous interferon therapy: a meta-analysis of controlled and uncontrolled trials. Hepatology. 2001;33(1):231-40. [pmid: 11124841].
69 Fried M W, Shiffman M L, Reddy R K, et al. Pegylated (40 kDa) interferon alfa-2a (PEGASYS) in combination with ribavirin: efficacy and safety results from a phase III, randomized, actively-controlled multicenter study. Gastroenterology. 2001;120(2 Suppl):A289.
70 Reddy K R, Wright T L, Pockros P J, et al. Efficacy and safety of pegylated (40-kd) interferon alpha-2a compared with interferon alpha-2a in noncirrhotic patients with chronic hepatitis C. Hepatology. 2001;33(2):433-8. [pmid: 11172346].
71 el-Zayadi A, Selim O, Haddad S, et al. Combination treatment of interferon alpha-2b and ribavirin in comparison to interferon monotherapy in treatment of chronic hepatitis C genotype 4 patients. Ital J Gastroenterol and Hepatology. 1999;31(6):472-5.
72 Ferenci P, Brunner H, Nachbaur K, et al. Combination of interferon induction therapy and ribavirin in chronic hepatitis C. Hepatology. 2001;34(5):1006-11. [pmid: 11679972].
73 Helbling B, Stamenic I, Viani F, et al. Interferon and amantadine in naive chronic hepatitis C: a double-blind, randomized, placebo-controlled trial. Hepatology. 2002;35(2):447-54. [pmid: 11826422].
74 Tabon M, Laudi C, Delmastro B, et al. Interferon and amantadine in combination as initial treatment for chronic hepatitis C patients. Journal of Hepatology. 2001;35(4):517-21. [pmid: 11682037].
75 Caronia S, Bassendine M F, Barry R, et al. Interferon plus amantadine versus interferon alone in the treatment of naive patients with chronic hepatitis C: a UK multicentre study. Journal of Hepatology. 2001;35(4):512-6. [pmid: 11682036].
76 Younossi Z M, Mullen K D, Zakko W, et al. A randomized, double-blind controlled trial of interferon alpha-2b and ribavirin vs. interferon alpha-2b and amantadine for treatment of chronic hepatitis C non-responder to interferon monotherapy. Journal of Hepatology. 2001;34(1):128-33. [pmid: 11211889].
77 Barbaro G, Di Lorenzo G, Soldini M, et al. Intravenous recombinant interferon-beta versus interferon-alpha-2b and ribavirin in combination for short-term treatment of chronic hepatitis C patients not responding to interferon-alpha. Multicenter Interferon Beta Italian Group Investigators. Scandinavian Journal of Gastroenterology. 1999;34(9):928-33. [pmid: 10522614].
78 Bresci G, Parisi G, Bertoni M, et al. High-dose interferon plus ribavirin in chronic hepatitis C not responding to recombinant alpha-interferon. Dig Liver Dis. 2000;32(8):703-7. [pmid: 11142581].
79 Ferenci P, Stauber R, Steindl-Munda P, et al. Treatment of patients with chronic hepatitis C not responding to interferon with high-dose interferon alpha with or without ribavirin: final results of a prospective randomized trial. Eur J Clin Gastroenterol Hepatol. 2001a;13(6):699-705.
80 Tripi S, DiGaetano G, Soresi M, et al. Interferon-alpha alone versus interferon-alpha plus ribavirin in patients with chronic hepatitis C not responding to previous interferon-alpha treatment. Biodrugs. 2000;13(4):299-304. [pmid: 18034536].
81 Puoti M, Cadeo G P, Putzolu V, et al. Pilot dose-finding trial on interferon alpha in combination with ribavirin for the treatment of chronic hepatitis C in patients not responding to interferon alone. Dig Liver Dis. 2001;33(2):163-72. [pmid: 11346146].
82 Chapman B A, Stace N H, Edgar C L, et al. Interferon-alpha2a/ribaviran versus interferon-alpha2a alone for the retreatment of hepatitis C patients who relapse after a standard course of interferon. New Zealand Medical Journal. 2001;114(1128):103-4. [pmid: 11346153].
83 Marco V D, Almasio P, Vaccaro A, et al. Combined treatment of relapse of chronic hepatitis C with high-dose alpha2b interferon plus ribavirin for 6 or 12 months. Journal of Hepatology. 2000;33(3):456-62. [pmid: 11020002].
84 Cavalletto L, Chemello L, Donada C, et al. The pattern of response to interferon alpha (alpha-IFN) predicts sustained response to a 6-month alpha-IFN and ribavirin retreatment for chronic hepatitis C. TVVH Study Group. Journal of Hepatology. 2000;33(1):128-34. [pmid: 10905596].
85 Enriquez J, Gallego A, Torras X, et al. Retreatment for 24 vs 48 weeks with interferon-alpha2b plus ribavirin of chronic hepatitis C patients who relapsed or did not respond to interferon alone. Journal of Viral Hepatitis. 2000;7(6):403-8. [pmid: 11115050].
86 Min A D, Jones J L, Esposito S, et al. Efficacy of high-dose interferon in combination with ribavirin in patients with chronic hepatitis C resistant to interferon alone. American Journal of Gastroenterology. 2001;96(4):1143-9. [pmid: 11316161].
87 Bonkovsky H L, Stefancyk D, McNeal K, et al. Comparative effects of different doses of ribavirin plus interferon-alpha 2b for therapy of chronic hepatitis C: results of a controlled, randomized trial. Digestive Diseases and Sciences. 2001;46(10):2051-9. [pmid: 11680575].
88 Gaeta G B, Stornaiuolo G, Stanzione M, et al. Interferon-alpha plus amantadine in chronic hepatitis C resistant to interferon alone: a pilot randomized study. Journal of Viral Hepatitis. 2001;8(4):284-6. [pmid: 11454180].
89 Teuber G, Berg T, Naumann U, et al. Randomized, placebo-controlled, double-blind trial with interferon-alpha with and without amantadine sulphate in primary interferon-alpha nonresponders with chronic hepatitis C. Journal of Viral Hepatitis. 2001;8(4):276-83. [pmid: 11454179].
90 Brillanti S, Levantesi F, Masi L, et al. Triple antiviral therapy as a new option for patients with interferonnonresponsive chronic hepatitis C. Hepatology. 2000;32(3):630-4. [pmid: 10960460].
91 Chemello L, Cavalletto L, Donada C, et al. Efficacy of a second cycle of interferon therapy in patients with chronic hepatitis C. Gastroenterology. 1997;113(5):1654-9. [pmid: 9352869].
92 Gaeta G B, DiVirgilio D, Russo G, et al. Human leucocyte interferon-alpha in chronic hepatitis C resistant to recombinant or lymphoblastoid interferon-alpha: a randomized controlled trial. Journal of Viral Hepatitis. 1997;4(3):209-14. [pmid: 9181530].
93 Heathcote EJ, Keeffe EB, Lee SS, et al. Re-treatment of chronic hepatitis C with consensus interferon . Hepatology 1998;27(4):1136–43. Erratum in: Hepatology 1998 Aug;28(2):599.
94 Kagawa T, Hosoi K, Takashimizu S, et al. Comparison of two interferon alfa treatment regimens characterized by an early virological response in patients with chronic hepatitis C. American Journal of Gastroenterology. 1998;93(2):192-6. [pmid: 9468240].
95 Poynard T, Daurat V, Chevret S, et al. A short induction regimen of interferon-alpha is not effective for treatment of relapse in chronic hepatitis C: a randomized trial. For the multicentre GER-CYT-01 group. Journal of Viral Hepatitis. 1999;6(5):381-6. [pmid: 10607254].
96 Shiffman M L, Hofmann C M, Contos M J, et al. A randomized, controlled trial of maintenance interferon therapy for patients with chronic hepatitis C virus and persistent viremia. Gastroenterology. 1999;117(5):1164-72. [pmid: 10535880].
97 Bresci G, Parisi G, Babnti S, et al. Chronic hepatitis-C - what treatment for nonresponsers to recombinant interferon-alpha. Clin Drug Invest. 1996;11(4):224-8.
98 Reddy K R, Hoofnagle J H, Tong M J, et al. Racial differences in responses to therapy with interferon in chronic hepatitis C. Hepatology. 1999;30(3):787-93. [pmid: 10462387].
99 Campistol J M, Esforzado N, Martinez J, et al. Efficacy and tolerance of interferon-alpha(2b) in the treatment of chronic hepatitis C virus infection in haemodialysis patients. Pre- and post-renal transplantation assessment. Nephrology, Dialysis, Transplantation. 1999;14(11):2704-9.
100 Rumi M G, Santagostino E, Morfini M, et al. A multicenter controlled, randomized, open trial of interferon alpha-2b treatment of anti-human immunodeficiency virus-negative hemophilic patients with chronic hepatitis C. Blood. 1997;89(10):3529-33. [pmid: 9160657].
101 Poynard T, Marcellin P, Lee S S, et al. Randomised trial of interferon alpha2b plus ribavirin for 48 weeks or for 24 weeks versus interferon alpha2b plus placebo for 48 weeks for treatment of chronic infection with hepatitis C virus. International Hepatitis Interventional Therapy Group (IHIT). Lancet. 1998;352(9138):1426-32. [pmid: 9807989].
102 McHutchison J G, Gordon S C, Schiff E R, et al. Interferon alfa-2b alone or in combination with ribavirin as initial treatment for chronic hepatitis C. New England Journal of Medicine. 1998;339(21):1485-92. [pmid: 9819446].
103 Horiike N, Fujisawa T, Michitaka K, et al. The effectiveness of interferon therapy on occurrence of hepatocellular carcinoma in chronic hepatitis C. Oncology Reports. 1998;5(5):1171-4. [pmid: 9683829].
104 Bernardinello E, Cavalletto L, Chemello L, et al. Long-term clinical outcome after beta-interferon therapy in cirrhotic patients with chronic hepatitis C. TVVH Study Group. Hepatogastroenterologyogy. 1999;46(30):3216-22.
105 Chemello L, Cavalletto L, Bernardinello E, et al. Comparison of thrice weekly vs daily human leucocyte interferon-alpha therapy for chronic hepatitis C. TVVH Study Group. Journal of Viral Hepatitis. 1999;6(4):321-7. [pmid: 10607247].
106 Cottone M, Turri M, Caltagirone M, et al. Screening for hepatocellular carcinoma in patients with Child's A cirrhosis: an 8-year prospective study by ultrasound and alphafetoprotein. Journal of Hepatology. 1994;21:1029-34. [pmid: 7535323].
107 Shindo M, Hamada K, Oda Y, et al. Long-term follow-up study of sustained biochemical responders with interferon therapy. Hepatology. 2001;33(5):1299-302. [pmid: 11343259].
108 Tanaka H, Tsukuma H, Kasahara A, et al. Effect of interferon therapy on the incidence of hepatocellular carcinoma and mortality of patients with chronic hepatitis C: a retrospective cohort study of 738 patients. International Journal of Cancer. 2000;87(5):741-9.
109 Yabuuchi I, Imai Y, Kawata S, et al. Long-term responders without eradication of hepatitis C virus after interferon therapy: characterization of clinical profiles and incidence of hepatocellular carcinoma. Liver. 2000;20(4):290-5. [pmid: 10959807].
110 Inoue A, Tsukuma H, Oshima A, et al. Effectiveness of interferon therapy for reducing the incidence of hepatocellular carcinoma among patients with type C chronic hepatitis. Journal of Epidemiology. 2000;10(4):234-40. [pmid: 10959605].
111 Nishiguchi S, Shiomi S, Nakatani S, et al. Prevention of hepatocellular carcinoma in patients with chronic active hepatitis C and cirrhosis. Lancet. 2001;357(9251):196-7. [pmid: 11213099].
112 Toyoda H, Kumada T, Nakano S, et al. Effect of the dose and duration of interferon-alpha therapy on the incidence of hepatocellular carcinoma in noncirrhotic patients with a nonsustained response to interferon for chronic hepatitis C. Oncology. 2001;61(2):134-42. [pmid: 11528252].
113 Ikeda K, Saitoh S, Kobayashi M, et al. Long-term interferon therapy for 1 year or longer reduces the hepatocellular carcinogenesis rate in patients with liver cirrhosis caused by hepatitis C virus: a pilot study. Journal of Gastroenterology and Hepatology. 2001;16(4):406-15. [pmid: 11354279].
114 Yatsuhashi H, Yano M. Natural history of chronic hepatitis C. Journal of Gastroenterology and Hepatology. 2000;15 Suppl:E111-6. [pmid: 10921392].
115 Aizawa Y, Shibamoto Y, Takagi I, et al. Analysis of factors affecting the appearance of hepatocellular carcinoma in patients with chronic hepatitis C. A long term follow-up study after histologic diagnosis. Cancer. 2000;89(1):53-9. [pmid: 10897000].
116 Kobayashi M, Ikeda K, Akuta N, et al. Relationship between five-year histological outcome and serial changes in serum alanine aminotransferase in patients with biochemical and virological relapse after interferon treatment for chronic hepatitis C. Intervirology. 2000;43(3):174-9. [pmid: 11044811].
117 Bruno S, Silini E, Crosignani A, et al. Hepatitis C virus genotypes and risk of hepatocellular carcinoma in cirrhosis: A prospective study. Hepatology. 1997;25(3):754-8. [pmid: 9049231].
118 Benvegnu L, Pontisso P, Cavalletto D, et al. Lack of correlation between hepatitis C virus genotypes and clinical course of hepatitis C virus-related cirrhosis. Hepatology. 1997;25(1):211-5. [pmid: 8985292].
119 Shibata M, Morizane T, Uchida T, et al. Irregular regeneration of hepatocytes and risk of hepatocellular carcinoma in chronic hepatitis and cirrhosis with hepatitis-C-virus infection. Lancet. 1998;351(9118):1773-7. [pmid: 9635950].
120 Chiaramonte M, Stroffolini T, Vian A, et al. Rate of incidence of hepatocellular carcinoma in patients with compensated viral cirrhosis. Cancer. 1999;85(10):2132-7. [pmid: 10326690].
121 Gentilini P, Laffi G, Lavilla G, et al. Long course and prognostic factors of virus-induced cirrhosis of the liver. American Journal of Gastroenterology. 1997;92(1):66-72. [pmid: 8995940].
122 Ikeda K, Satoshi S, Koida I, et al. A multivariate analysis of risk factors for hepatocellular carcinogenesis: a prospective observation of 795 patients with viral and alcoholic cirrhosis. Hepatology. 1993;12:47-53. [pmid: 7686879].
123 Takano S, Yokosuka O, Imazeki F, et al. Incidence of hepatocellular carcinoma in chronic hepatitis B and C: a prospective study of 251 patients. Hepatology. 1995;21:650-55. [pmid: 7875662].
124 Persico M, Persico E, Suozzo R, et al. Natural history of hepatitis C virus carriers with persistently normal aminotransferase levels. Gastroenterology. 2000;118(4):760-4. [pmid: 10734027].
125 Hayashi J, Furusyo N, Ariyama I, et al. A relationship between the evolution of hepatitis C virus variants, liver damage, and hepatocellular carcinoma in patients with hepatitis C viremia. J Infect Dis. 2000;181(5):1523-7. [pmid: 10823749].
126 Furusyo N, Hayashi J, Kanamoto-Tanaka Y, et al. Liver damage in hemodialysis patients with hepatitis C virus viremia: a prospective 10-year study. Digestive Diseases and Sciences. 2000;45(11):2221-8. [pmid: 11215743].
127 Kliem V, Van Den Hoff U, Brunkhorst R, et al. The long-term course of hepatitis C after kidney transplantation. Transplantation. 1996;62(10):1417-21. [pmid: 8958266].
128 Rostaing L, Rumeau J L, Cisterne J M, et al. Liver histology in renal transplant patients after more than 10 years of hepatitis C virus infection. Transplantation Proceedings. 1996;28(5):2836-7. [pmid: 8908089].
129 Lesens O, Deschenes M, Steben M, et al. Hepatitis C virus is related to progressive liver disease in human immunodeficiency virus-positive hemophiliacs and should be treated as an opportunistic infection. J Infect Dis. 1999;179:1254-8. [pmid: 10191232].
130 Benhamou Y, Martino V, Bochet M, et al. Factors affecting liver fibrosis in human immunodeficiency virus-and hepatitis C virus-coinfected patients: Impact of protease inhibitor therapy. Hepatology. 2001;34(2):283-7. [pmid: 11481613].
131 Harris H E, Ramsay M E, Andrews N, Eldridge K P. Clinical course of hepatitis C virus during the first decade of infection: cohort study. BMJ. 2002;324:1-6. [pmid: 11777781]. [pmcid: 1121932].
132 Murakami C, Hino K, Korenaga M, et al. Factors predicting progression to cirrhosis and hepatocellular carcinoma in patients with transfusion-associated hepatitis C virus infection. J Clin Gastroenterol. 1999;28(2):148-52. [pmid: 10078824].
133 Thomas D L, Astemborski J, Rai R M, et al. The natural history of hepatitis C virus infection. JAMA. 2000;284(4):450-6. [pmid: 10904508].
134 Rodger A J, Thomson J A, Thompson S C, et al. Assessment of long-term outcomes of hepatitis C virus infection in a cohort of patients with acute hepatitis in 1971-1975: results of a pilot study. Journal of Gastroenterology and Hepatology. 1999;14:269-73. [pmid: 10197498].
135 Kobayashi M, Tanaka E, Sodeyama T, et al. The natural course of chronic hepatitis-C - a comparison between patients with genotype-1 and genotype-2 hepatitis-C viruses. Hepatology. 1996;23(4):695-9. [pmid: 8666319].
136 Matsumura H, Moriyama M, Goto I, et al. Natural course of progression of liver fibrosis in Japanese patients with chronic liver disease type C - a study of 527 patients at one establishment. Journal of Viral Hepatitis. 2000;7(4):268-75. [pmid: 10886535].
137 Yano M, Kumada H, Kage M, et al. The long-term pathological evolution of chronic hepatitis C. Hepatology. 1996;23(6):1334-40. [pmid: 8675148].
138 Meijer K, Haagsma E B, Kok T, et al. Natural history of hepatitis C in HIV-negative patients with congenital coagulation disorders. Journal of Hepatology. 1999;31(3):400-6. [pmid: 10488696].
139 Barrett S, Goh J, Coughlan B, et al. The natural course of hepatitis C virus infection after 22 years in a unique homogenous cohort: spontaneous viral clearance and chronic HCV infection. Gut. 2001;49(3):423-30. [pmid: 11511566]. [pmcid: 1728443].
140 Punyagupta S, Jidpugdeebodin S, Siwadune T. Hepatitis C infection and hepatocellular carcinoma in Thailand: a long term study of 63 HCV patients. J Arch Infect Dis and Antimicrobial Agents. 1999;16(1):1-5.
141 Forns X, Ampurdanes S, Sanchez-Tapias J M, et al. Long-term follow-up of chronic hepatitis C in patients diagnosed at a tertiary-care center. Journal of Hepatology. 2001;35(2):265-71. [pmid: 11580150].
142 Parking DM, Muir CS, Whelan SL, Gao Y-T, Ferlay J, Powell J. Cancer Incidence in Five Continents. 1994 World Health Statistics Annual (Vol 6) . Lyon: IARC Scientific Publications. 117–129: World Healt Organization. Geneva: WHO; 1995
143 Bruix J. Treatment of hepatocellular carcinoma. Hepatology. 1997;25(2):259-62. [pmid: 9021931].
144 Villeneuve J P, Desrochers M, Infante-Rivard C, et al. A long-term follow-up study of asymptomatic hepatitis B surface antigen-positive carriers in Montreal. Gastroenterology. 1994;106(4):1000-5. [pmid: 8143967].
145 McMahon B J, Alberts S R, Wainwright R B, et al. Hepatitis B-related sequelae. Prospective study in 1400 hepatitis B surface antigen-positive Alaska native carriers. Archives of Internal Medicine. 1990;150(5):1051-4. [pmid: 2158773].
146 Sherman K E, Lewey S M, Goodman Z D. Talc in the liver of patients with chronic hepatitis C infection. American Journal of Gastroenterology. 1995;90(12):2164-6. [pmid: 8540508].
147 Solmi L, Primerano A M M, Gandolfi L. Ultrasound follow-up of patients at risk for hepatocellular-carcinoma - results of a prospective study on 360 cases. American Journal of Gastroenterology. 1996;91(6):1189-94. [pmid: 8651169].
148 Larcos G, Sorokopud H, Berry G, et al. Sonographic screening for hepatocellular carcinoma in patients with chronic hepatitis or cirrhosis: an evaluation. AJR. American Journal of Roentgenology. 1998;171(2):433-5. [pmid: 9694470].
149 Tong M J, Blatt L M, Kao V W. Surveillance for hepatocellular carcinoma in patients with chronic viral hepatitis in the United States of America. Journal of Gastroenterology and Hepatology. 2001;16(5):553-9. [pmid: 11350553].
150 Tradati F, Colombo M, Mannucci P M, et al. A prospective multicenter study of hepatocellular carcinoma in italian hemophiliacs with chronic hepatitis C. The Study Group of the Association of Italian Hemophilia Centers. Blood. 1998;91(4):1173-7. [pmid: 9454746].
151 Raedle J, Roth W K, Oremek G, et al. Alpha-fetoprotein and p53 autoantibodies in patients with chronic hepatitis C. Digestive Diseases and Sciences. 1995;40(12):2587-94. [pmid: 8536517].
152 Tsai J F, Jeng J E, Chuang L Y, et al. Clinical evaluation of urinary transforming growth factor-beta 1 and serum alpha-fetoprotein as tumour markers of hepatocellular carcinoma. Br J Cancer. 1997;75(10):1460-6. [pmid: 9166938].
153 Izzo F, Cremona F, Ruffolo F, et al. Outcome of 67 patients with hepatocellular cancer detected during screening of 1125 patients with chronic hepatitis. Annals of Surgery. 1998;227(4):513-8. [pmid: 9563539]. [pmcid: 1191306].
154 Ishii M, Gama H, Chida N, et al. Simultaneous measurements of serum alpha-fetoprotein and protein induced by vitamin K absence for detecting hepatocellular carcinoma. South Tohoku District Study Group. American Journal of Gastroenterology. 2000;95(4):1036-40. [pmid: 10763956].
155 Sassa T, Kumada T, Nakano S, et al. Clinical utility of simultaneous measurement of serum high-sensitivity des-gamma-carboxy prothrombin and Lens culinaris agglutinin A-reactive alpha-fetoprotein in patients with small hepatocellular carcinoma. European Journal of Gastroenterology and Hepatology. 1999;11(12):1387-92. [pmid: 10654799].
156 VanRoey G, Fevery J, VanSteenbergen W. Hepatocellular carcinoma in Belgium: clinical and virological characteristics of 154 consecutive cirrhotic and non-cirrhotic patients. Eur J Clin Gastroenterol Hepatol. 2000;12(1):61-6.
157 Cedrone A, Covino M, Caturelli E, et al. Utility of alpha-fetoprotein (AFP) in the screening of patients with virus-related chronic liver disease: does different viral etiology influence AFP levels in HCC? A study in 350 western patients. Hepatogastroenterologyogyogy. 2000;47(36):1654-8.
158 Trevisani F, D'Intino P E, Caraceni P, et al. Etiologic factors and clinical presentation of hepatocellular carcinoma. Cancer. 1995;75:2220-32. [pmid: 7536121].
159 Tsai J-F, Chang W Y, Jeng J E, et al. Frequency of raised alpha-fetoprotein level among Chinese patients with hepatocellular carcinoma related to hepatitis B and C. Br J Cancer. 1994;69(6):1157-9. [pmid: 7515263].
160 Sato Y, Nakata K, Kato Y, et al. Early recognition of hepatocellular carcinoma based on altered profiles of alpha-fetoprotein. New England Journal of Medicine. 1993;328:1802-6. [pmid: 7684823].
161 Tsai J F, Jeng J E, Ho M S, et al. Clinical evaluation of serum alpha-getoprotein and circulating immune complexes as tumour markers of hepatocellular carcinoma. Br J Cancer. 1995;72:442-6. [pmid: 7543774].
162 Nomura F, Ishijima M, Horikoshi A, et al. Determination of serum des-gamma-carboxy prothrombin levels in patients with small-sized hepatocellular carcinoma: comparison of the conventional enzyme immunoassay and two modified methods. American Journal of Gastroenterol. 1996;91(7):1380-3.
163 Izzo F, Cremona F, Delrio P, et al. Soluble interleukin-2 receptor levels in hepatocellular cancer: a more sensitive marker than alfa fetoprotein. Annals of Surgical Oncology. 1999;6(2):178-85. [pmid: 10082044].
164 Kakumu S, Okumura A, Ishikawa T, et al. Serum levels of Il-10, Il-15 and soluble tumour necrosis factor-alpha (TNF-alpha) receptors in type C chronic liver disease. Clinical and Experimental Immunology. 1997;109(3):458-63. [pmid: 9328122]. [pmcid: 1904782].
165 Nagai T, Murota M, Nishioka M, et al. Elevation of cytokeratin 19 fragment in serum in patients with hepatoma: its clinical significance. European Journal of Gastroenterol and Hepatology. 2001;13(2):157-61.
166 Tsuzurahara S, Sata M, Iwamoto O, et al. Detection of MAGE-4 protein in the sera of patients with hepatitis-C virus-associated hepatocellular carcinoma and liver cirrhosis. Japanese Journal of Cancer Research. 1997;88(9):915-8. [pmid: 9369941].
167 Kasahara A, Hayashi N, Mochizuki K, et al. Risk factors for hepatocellular carcinoma and its incidence after interferon treatment in patients with chronic hepatitis C. Hepatology. 1998;27(5):1394-402. [pmid: 9581697].
168 Colombo M, Franchis R, Del Ninno E, et al. Hepatocellular carcinoma in Italian patients with cirrhosis. New England Journal of Medicine. 1991;325:675. [pmid: 1651452].
169 Walsh K M, Timms P, Campbell S, et al. Plasma levels of matrix metalloproteinase-2 (MMP-2) and tissue inhibitors of metalloproteinases -1 and -2 (TIMP-1 and TIMP-2) as noninvasive markers of liver disease in chronic hepatitis C: comparison using ROC analysis. Digestive Diseases and Sciences. 1999a;44(3):624-30. [pmid: 10080160].
170 Davidoff F, DeAngelis C D, Drazen J M, et al. Sponsorship, authorship, and accountability. New England Journal of Medicine. 2001;345(11):825-6. [pmid: 11556304].