# Preface

The Agency for Healthcare Research and Quality (AHRQ), through its Evidence-Based Practice Centers (EPCs), sponsors the development of evidence reports and technology assessments to assist public- and private-sector organizations in their efforts to improve the quality of health care in the United States. The reports and assessments provide organizations with comprehensive, science-based information on common, costly medical conditions and new health care technologies. The EPCs systematically review the relevant scientific literature on topics assigned to them by AHRQ and conduct additional analyses when appropriate prior to developing their reports and assessments.

To bring the broadest range of experts into the development of evidence reports and health technology assessments, AHRQ encourages the EPCs to form partnerships and enter into collaborations with other medical and research organizations. The EPCs work with these partner organizations to ensure that the evidence reports and technology assessments they produce will become building blocks for health care quality improvement projects throughout the Nation. The reports undergo peer review prior to their release.

AHRQ expects that the EPC evidence reports and technology assessments will inform individual health plans, providers, and purchasers as well as the health care system as a whole by providing important information to help improve health care quality.

We welcome written comments on this evidence report. They may be sent to: Director, Center for Practice and Technology Assessment, Agency for Healthcare Research and Quality, 6010 Executive Blvd., Suite 300, Rockville, MD 20852.

Carolyn M. Clancy, M.D.

Acting Director

Agency for Healthcare Research and Quality

Robert Graham, M.D.

Director, Center for Practice and Technology Assessment

Agency for Healthcare Research and Quality

## Acknowledgments

The Johns Hopkins University Evidence-based Practice Center expresses its appreciation to Carolyn Feuerstein, Steven Leoniak, Leonard Sowah, Josh Schiffer and Simon Chuang; Kristine Scannell and Carolyn Willard at the National Library of Medicine also assisted in the preparation of this report.

We also thank Stuart Ray, Karen Robinson, Steve Goodman, and Neil R. Powe at Johns Hopkins for their contributions.

Finally, we thank the medical student researchers who assisted us: Pennan Barry, Kristin Dasher, Khory Harmon, Beatrice Hong, Catherine Passaretti, Jenny Schneider, Shetal Patel, Irina Sobol, and Amytis Towfighi.