# Appendix C. Literature Search Strategy

## PubMed Core Strategies

Key Questions 1a–1e

Name: Hepatitis C (Ques. 1a–1e)

Date and Time search last updated: 26-Sep-2001 12:59:03

Database: PubMed

Search: (hepatitis c, chronic[mh] OR hepatitis c[mh]) AND liver/pa AND (biopsy[mh] OR fibrosis[mh] OR liver function tests[mh]) NOT (“addresses”[Publication Type] OR “bibliography”[Publication Type] OR “biography”[Publication Type] OR “classical article”[Publication Type] OR “clinical conference”[Publication Type] OR “comment”[Publication Type] OR “congresses”[Publication Type] OR “consensus development conference”[Publication Type] OR “consensus development conference, nih”[Publication Type] OR “dictionary”[Publication Type] OR “directory”[Publication Type] OR “duplicate publication”[Publication Type] OR “editorial”[Publication Type] OR “festschrift”[Publication Type] OR “historical article”[Publication Type] OR “interview”[Publication Type] OR “lectures”[Publication Type] OR “legal cases”[Publication Type] OR “letter”[Publication Type] OR “meeting report”[Publication Type] OR “news”[Publication Type] OR “newspaper article”[Publication Type] OR “overall”[Publication Type] OR “periodical index”[Publication Type] )

Limits: Publication Date from 1996 to 2001, English, Human

Key Questions 2a–2c

Name: Hepatitis C (Ques. 2a–2c)

Date and Time search last updated: 26-Sep-2001 11:44:42

Database: PubMed

Search: (“treatment outcome”[MESH] OR “disease progression”[MESH] OR “disease free survival”[MESH] OR “Carcinoma, Hepatocellular”[MESH] OR pregnancy[MESH] OR demography[MESH] OR “ethnic groups”[MESH] OR “immunologic factors”[MESH] OR “immunologic diseases”[MESH] OR immunosuppression[MESH] OR “organ transplantation”[MESH] OR “drug therapy/adverse effects”[MESH] OR “antiviral agents/adverse effects”[MESH] OR “antiviral agents/therapeutic use”[MESH] OR “mental disorders”[MESH] OR prisoners[MESH] OR institutionalization[MESH] OR Comorbidity[MESH] OR “liver diseases”[MESH] OR “kidney diseases”[MESH] OR genotype[MESH] OR “Drug Therapy, Combination”[MESH]) AND “hepatitis c, chronic/therapy”[MESH] NOT (“addresses”[Publication Type] OR “bibliography”[Publication Type] OR “biography”[Publication Type] OR “classical article”[Publication Type] OR “clinical conference”[Publication Type] OR “comment”[Publication Type] OR “congresses”[Publication Type] OR ”consensus development conference”[Publication Type] OR “consensus development conference, nih”[Publication Type] OR “dictionary”[Publication Type] OR “directory”[Publication Type] OR “duplicate publication”[Publication Type] OR “editorial”[Publication Type] OR “festschrift”[Publication Type] OR “historical article”[Publication Type] OR “interview”[Publication Type] OR “lectures”[Publication Type] OR “legal cases”[Publication Type] OR “letter”[Publication Type] OR “meeting report”[Publication Type] OR “news”[Publication Type] OR “newspaper article”[Publication Type] OR “overall”[Publication Type] OR “periodical index”[Publication Type] OR “published erratum”[Publication Type] OR “retracted publication”[Publication Type])

Limits: Publication Date from 1996 to 2001, English, Human

Key Questions 3a&b

Name: Hepatitis C (Ques. 3a–3b)

Date and Time search last updated: 26-Sep-2001 11:37:20

Database: PubMed

Search: hepatitis c, chronic[mh] AND hepatocellular carcinoma[mh] AND ( diagnosis[mh] OR diagnosis[sh] OR “biological markers” OR ultrasound OR “image interpretation, computer-assisted” OR “alpha-fetoproteins” OR “serologic tests” ) NOT (“addresses”[Publication Type] OR “bibliography”[Publication Type] OR “biography”[Publication Type] OR “classical article”[Publication Type] OR “clinical conference”[Publication Type] OR “comment”[Publication Type] OR “congresses”[Publication Type] OR “consensus development conference”[Publication Type] OR “consensus development conference, nih”[Publication Type] OR “dictionary”[Publication Type] OR “directory”[Publication Type] OR “duplicate publication”[Publication Type] OR“editorial”[Publication Type] OR“festschrift”[Publication Type] OR“historical article”[Publication Type] OR“interview”[Publication Type] OR“lectures”[Publication Type] OR“legal cases”[Publication Type] OR“letter”[Publication Type] OR“meeting report”[Publication Type] OR “news”[Publication Type] OR “newspaper article”[Publication Type] OR “overall”[Publication Type] OR “periodical index”[Publication Type] )

Limits: Publication Date from 1996 to 2001, English, Human