# Appendix B. Priority Journals for Handsearching

Priority Journal Titles | Frequency
AIDS | every three weeks
Annals of Internal Medicine | semi-monthly
British Medical Journal | weekly
Clinical Infectious Diseases | semi-monthly
Gastroentrology | monthly
Hepatology | monthly
Journal of Infectious Diseases | semi-monthly
Journal of the American Medical Association | weekly
Lancet | weekly
New England Journal of Medicine | weekly