# Appendix A. Reviewers

Expert Area and Organization | Name | Home Institution
Representatives of Professional Associations
American Association for the Study of Liver Diseases (AASLD) | Henry C. Bodenheimer, Jr., MD | Mount Sinai School of Medicine
The American College of Physicians-American Society of Internal Medicine (ACP-ASIM) | Harold Fallon, MD | National Academy of Science
The American Academy of Pediatrics (AAP) | Samuel Kocoshis, MD | University of Cincinnati School of Medicine
Infectious Diseases Society of America (IDSA) | David Oldach, MD | University of Maryland School of Medicine
Other Clinical Experts
Infectious diseases | John G. Bartlett | Johns Hopkins University School of Medicine
Infectious disease nursing | Sherilyn Brinkley-Laughton, MSN | Johns Hopkins University School of Nursing
Hepatology | Robert L Carithers Jr, MD | University of Washington, Seattle, WA
Internal medicine and infectious diseases | Lawrence Deyton, MD MSPH | US Department of Veteran Affairs
Adult hepatology | Lorna Dove, MD | Columbia University, New York
Clinical epidemiology and program policy | Roger Gibson, PhD, DVM, MPH | United States Air Force, Richmond, VA
Clinical epidemiology | Murray Krahn | University Health Network, Toronto, Canada
Hepatology | Mark C Mitchell, MD | Carolinas Medical Center
Pediatric hepatology | Kathleen Schwarz, MD | Johns Hopkins University, Baltimore, MD
Hepatology, hepatitis C, intravenous drug abuse and methadone | Diana Sylvestre, MD | University of California, San Francisco, CA
Methodologic Experts
Developing best practice models for hepatitis C | Michael Chapko, PhD | Veterans Administration Health Services, Seattle, WA
Outcomes researcher and decision analyst | Mark Fendrick, MD | University of Michigan Schools of Medicine and Public Health, Ann Arbor, MI
Assessment of diagnostic technologies | Ben Littenberg, M.D. | University of Vermont
Pharmaceutical assessment | John Ticehurst | Department of Pathology, Johns Hopkins University
Payor
Division of medical items and devices, coverage and analysis group | John Whyte, MD MPH | Center for Medicare and Medicaid Services
Consumer Representatives
Hep C Connection | Anne Jesse | Founding Director