# Appendixes

Appendix A. Reviewers

Appendix B. Priority Journals for Handsearching

Appendix C. Literature Search Strategy

Appendix D. Literature Abstract Review Form

Appendix E. Study Quality Review Form - Johns Hopkins Evidence-based Practice Center Hepatitis C Project