# Evidence Tables

## Evidence Table 1: Detection Systems

This Evidence Table presents selected abstracted data for 4 categories of detection systems: Collection Systems, Particulate Counters and Biomass Indicators, Identification Systems, and Integrated Collection and Identification Systems. For each system we include its name, purpose, a description, the biothreat agents it can be used to detect, and, if available, information about the system's accuracy.

### Collection Systems

Name: | BioCapture™
Purpose: | Portable collection system for use by first responders.
Description: | Captures airborne bacteria, spores and other pathogens 0.5 microns and larger into a small volume of liquid. The collector uses rotating impeller arms to impact airborne particles, while simultaneously washing the surface with a fluid. The liquid can then be deposited onto handheld assays, the BTA™ Test Strips (see below, under Identification Systems). Two models are currently available, the BT-500 and the BT-550. The collection systems are identical. The BT-550 has an integrated automatic sample delivery system designed for use with Tetracore BTA™ test strips. It is currently fielded in fire departments in Seattle, Los Angeles, New York City, San Diego, El Paso, Montgomery County, MD, and the 9^th^ WMD Civil Support Team in California.
Flow rate/collection efficiency: | External validation of the BioCapture™ was conducted at the Dugway Proving Ground in December 2000. During these tests, single cell, 1 micron B. globigii was aerosolized. The performance of BioCapture™ was compared with an All Glass Impinger (AGI) that collects into liquid and a slit sampler that impacts bacteria directly onto growth media. In general, the collection efficiency of the BioCapture™ was 50-80% relative to the AGI collection, and 60%-125% relative to slit sampler collection.
Biothreat agents: | Determined by the handheld tests used in conjunction with the collector.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed evaluations. Other Web site.^ 42 ^
Contact information: | MesoSystems 1021 N. Kellogg St. Kennewick, WA 99336 Ph: 509-737-8383; Fax: 509-737-8484 http://www.mesosystems.com (MesoSystems also manufactures the BioVic™, an aerosol collector that serves as the front-end air sampler for biological detection systems. The BioVic™ preconcentrates the air stream, capturing particles into 1 of 3 media: a small volume of liquid, a small air stream, or onto a solid surface for delivery into a sensor.)

Name: | Portable High-Throughput Liquid Aerosol Air Sampler System (PHTLAAS)
Purpose: | Portable system for detection of aerosolized and insect-carried biowarfare agents.
Description: | Per report from the manufacturer, after reducing contaminants from large volumes of air into small volumes of liquid, this handheld device uses "water analyzers" (not otherwise specified) to detect bacteria, viruses, and fungi.^ 44 ^
Flow rate/collection efficiency: | No information available.
Biothreat agents: | Determined by the identification system used.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed evaluations. Government report^ 43 ^ and other Web site.^ 44 ^
Contact information: | Zaromb Research Corp. 9S706 William Drive Hinsdale, IL 60521 http://www.zaromb.com/generic.jhtml?pid=4

Name: | SASS 2000 Plus™ Chem-Bio Air Sampler
Purpose: | Portable system for collecting aerosolized samples.
Description: | Low-power device developed for use with a rapid identification system, manufactured specifically for use with the RAPTOR™ system but can be used with other systems as well (see below, under Identification Systems). The SASS 2000 Plus™ is a multi-stage, wetted-wall cyclone sampler that extracts chemical and particulate-based threat agents from surrounding air and transfers them to a liquid phase for detection and analysis. It concentrates airborne particles by several hundred thousand times into a small amount of water. The system has a total weight of 3.8 kg with a battery and 2.8 kg without battery, and dimensions of 14.2 centimeters (cm) width (W) by 19.8 cm diameter (D) by 30.5 cm height (H).
Flow rate/collection efficiency: | The SASS 2000 Plus™ has a flow rate of 260 L/min and is designed to capture particles ranging in size from 2-10 micrometers.
Biothreat agents: | Determined by the identification system used.
IT or DSS: | Neither when operated as a stand-alone unit. However, it can be connected to other sampling, detection or communication systems using an RS-232 link transforming it into an IT.
Source of information: | No peer-reviewed evaluations. Government report,^ 36 ^ other Web sites,^39, 45, 46^ and other.^ 10 ^
Contact information: | Research International, Inc. 18706 142^nd^ Ave. N.E. Woodinville, WA 98072 Ph: 425-486-7831; Fax: 425-485-9137 http://www.resrchintl.com/raptor_source.htm

Name: | SpinCon^®^ Advanced Air Sampler
Purpose: | Portable collection system for both soluble vapors and particulate matter for use in infectious disease investigations in public buildings, workplace exposure, and clean room monitoring.
Description: | Collects soluble vapors and particulate matter including: volatile compounds (e.g. Sarin), nonvolatile compounds (e.g. acids derived from nerve agents), semi-volatile compounds (e.g. organophosphonates), low and moderate vapor-pressure chemical compounds, hot saturated stack gases from combustion sources, molds, pollen, fungi, bacteria, viruses, and bacteriaphages. The system can be tailored to a specific class of vapors or particulate matter through selection of the sampling fluid. Target particles or chemical compounds are transported in the sampling fluid medium, which can then be analyzed separately. System dimensions: 18"H x 12"W x 8"D; weight approximately 35 pounds and power requirements of 120 VAC +/- 10% 60 Hz, 320 watt maximum.
Flow rate/collection efficiency: | The system is capable of sampling over 1000L/min and can operate in batch or continuous monitoring mode with automatic or manual controls.
Biothreat agents: | Multiple types of agents as above; determined by the identification system used.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed evaluations. Government report,^ 36 ^ other Web sites^39-41^ and other.^ 10 ^
Contact information: | Midwest Research Institute Ph: 816-753-7600, ext. 1507

### Particulate Counters and Biomass Indicators

Name: | AMEBA Biosensor
Purpose: | Uses microorganisms as rapid, flexible sensors for detecting biothreat organisms.
Description: | The AMEBA biosensor monitors physiological response data from microorganisms exposed to aerosolized samples. The manufacturer reports that it can identify the presence of biological organisms in an aerosol sample in 1 second. The basic biosensor can come with a "Physics Package" that includes a collection apparatus. Additionally, the manufacturer produces a "Systems and Electronics Package" to provide signal image processing, decision support and the infrastructure to transmit data from up to 100 sensors to a central controller through either wire, wireless or radio frequency connections.
Sensitivity/specificity: | No information available.
Biothreat agents: | No information available.
IT or DSS: | Neither when operated as a stand-alone unit. However, when combined with the "Systems and Electronics Package," it appears to have both IT and DSS capabilities.
Source of information: | No peer-reviewed evaluations. Other Web sites.^62, 63^
Contact information: | Gensor Inc. 2333 Huntingdon Pike Huntingdon Valley, PA 19006 Ph: 215-938-7800; Fax: 215-938-1551 http://www.gensor.com

Name: | Digital Smell/Electronic Nose
Purpose: | Diagnostic system based on volatile gases given off as metabolites by microorganisms.
Description: | Numerous articles describe different electronic noses. In general, they consist of an array of gas sensors with different selectivity patterns, a signal-collecting unit and pattern recognition software. The identification has been based on either statistical methods or neural networks. Arrays of electronic noses have been used to measure bacterial growth as a function of concentrations of substrates and bacterial metabolites and products. Three devices marketed by Osmetech, Inc. (for use at the laboratory, point of care, and handheld/portable) are commercially available for the detection of microorganisms causing bacterial pharyngitis, pneumonia in ventilated patients, urinary tract infections, and bacterial vaginosis.
Sensitivity/specificity: | Holmberg et al. demonstrated that an array of 15 sensors (including ones for oxygen and carbon dioxide) were able to correctly classify 68 of 90 colonies containing 1 of the following organisms: E. coli, Enterococcus sp, Proteus mirabilis, Pseudomonas aeruginosa, Staphylococcus saprophytica, and an uninoculated control (22 of 90 false positives in this experiment).^ 59 ^
Biothreat agents: | No information available.
IT or DSS: | IT
Source of information: | Peer-reviewed article^ 59 ^ and other Web site.^ 64 ^
Contact information: | Osmetech Inc. 500 West Cummings Park, Suite 4200 Woburn, MA 01801 Ph: 781-759-1112 http://www.aromascan.com

Name: | Interim Biological Agent Detector (IBAD)
Purpose: | Shipboard cyclone sampler that continuously monitors the air for a significant rise in particulate concentrations.
Description: | If a significant rise over background is detected, the instrument automatically collects an aerosol sample and alerts the ship's damage control center so the crew can collect an air sample and screen it with a handheld antigen test. IBAD was first deployed in 1994; 20 are currently in use. IBAD can identify a biothreat agent in 45 minutes.
Sensitivity/specificity: | No information available.
Biothreat agents: | Will be a function of the handheld tests used in conjunction with it.
IT or DSS: | It is neither when operated as a stand-alone unit.
Source of information: | Peer-reviewed article,^ 65 ^ government reports,^36, 66^ other Web site^ 39 ^ and other.^ 10 ^
Contact information: | Naval Research Laboratory (NRL), Washington, D.C.

Name: | Long Range Biological Standoff Detection System (LR-BSDS)
Purpose: | Designed to be flown in helicopters for the detection of aerosol clouds resulting from long-line source attacks.
Description: | This system, which is not currently commercially available, uses infrared lasers to detect an aerosol cloud at a standoff distance of up to 30 kilometers. The objective of this system is to provide early warning in order that potentially exposed individuals may adopt personal protective measures. An improved version is in development to extend the range to 100 kilometers. The LR-BSDS does not discriminate biological material. Therefore other systems must be used in conjunction with the LR-BSDS to determine whether the aerosol contains biologically active particles and if so, to identify them.
Biothreat agents: | Does not specifically identify any agent.
Sensitivity/specificity: | No information available.
IT or DSS: | IT
Source of information: | No peer-reviewed evaluations. Government reports,^36, 67^ other Web site^ 39 ^ and other.^ 10 ^
Contact information: | Los Alamos National Laboratory

Name: | Met One Aerocet 531 Mass/Particle Counter
Purpose: | Low-power aerosol particle sizer and counter that detects statistically significant rises in aerosol concentration over background.
Description: | This particle sizer and counter is the size of a large handheld calculator and is typically used to monitor clean rooms. This device draws an air sample through a laser-illuminated sample volume where airborne particles scatter light. The scattered lighted is detected by a photodiode. Sample times can be set for up to 24 hours. Count data are stored in memory and transferred to a printer or computer.
Biothreat agents: | Determined by the identification system used.
Sensitivity/specificity: | Can detect particles from 0.5 to 10.0 microns.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed evaluations. Government Report^ 43 ^ and other Web site.^ 68 ^
Contact information: | Pacific Scientific Instruments 481 California Ave Grants Pass, OR 97526 Ph: 541-472-6515 http://www.particle.com/home.htm

Name: | Model 3321 Aerodynamic Particle Sizer^®^ Spectrometer (APS^®^ 3321) and Fluorescence Aerodynamic Particle Sizer^®^ (FLAPS-1^®^)
Purpose: | Designed to rapidly distinguish aerosol particles containing living organisms from all other background particles.
Description: | APS^®^ 3321 measures aerodynamic size as well as relative light-scattering intensity. Detectable particle size ranges from 0.37 to 20 mm, with high-resolution sizing from 0.5 to 20 mm aerodynamic diameter. APS^®^ 3321 weighs approximately 10 kg with dimensions of 38 cm H by 30 cm W by 18 cm D. Sampling time is from 1 second to 18 hours per sample, depending on the user's needs. Included with Model 3321 APS^®^ is the Aerosol Instrument Manager software to enable the user to perform computer-controlled operations and data interpretation.
Sensitivity/specificity: | No information available.
Biothreat agents: | Determined by the identification system used.
IT or DSS: | APS 3321 is an IT due to the software discussed above. FLAPS-1^®^ is neither when operated as a stand-alone unit; however, when combined with APS^®^ 3321, it is an IT.
Source of information: | No peer-reviewed evaluations. Government reports,^36, 43^ other Web sites,^39, 57, 69^and other.^ 10 ^
Contact information: | Built by TSI according to DRES specifications. Particle Instruments Division P.O. Box 64394 St. Paul, Minneapolis 55164-0394 Ph: 800-677-2708 particle@tsi.com

Name: | Model 3312A Ultraviolet Aerodynamic Particle Sizer^®^ (UV-APS^®^) and Fluorescence Aerodynamic Particle Sizer-2^®^ (FLAPS-2^®^)
Purpose: | Detection of living organisms in aerosols and nonvolatile liquids.
Description: | The success of the FLAPS-1^®^ project led to a second contract with TSI to construct the UV-APS^®^. The UV-APS^®^ is designed to measure aerodynamic diameter, light-scattering intensity and fluorescence intensity of airborne solids and nonvolatile liquids. The UV-APS^®^ is able to measure these parameters in real-time (programmable from 1 second to 18 hours), providing rapid measurements of aerodynamic size and scattered light for particles ranging in size from 0.5 to 15 mm, in addition to identifying fluorescence characteristics of particles and thereby distinguishing airborne biological particles from most inanimate material. FLAPS-2^®^ adds to this basic particle-sizer the ability to measure the intrinsic fluorescence produced by living organisms which contain the bio-active molecule NADH or other similar flavinoid molecules. By itself, UV-APS^®^ produces raw data without analysis or display capabilities. For FLAPS-2^®^, proprietary display and alarming software was developed by DRES with Dycor (Edmonton, Alberta) to automatically log all particle and fluorescence data and automatically trigger an alarm when an unusual proportion of fluorescent particles are detected.
Sensitivity/specificity: | In field tests, FLAPS-2^®^ was able to detect 39 of 40 blind releases of simulant aerosols at a distance of about a kilometer with no false alarms logged over a 3 week period. In another trial it was able to detect as few as 10 agent-containing particles per liter of air.
Biothreat agents: | Determined by the identification system used.
IT or DSS: | UV-APS^®^ is neither when operated as a stand-alone unit. FLAPS-2^®^ is an IT.
Source of information: | No peer-reviewed evaluations. Government report,^ 36 ^ government Web site,^ 57 ^ other Web sites,^39, 58^ and other.^ 10 ^
Contact information: | TSI Particle Instruments Division P.O. Box 64394 St. Paul, Minneapolis 55164-0394 Ph: 800-677-2708 particle@tsi.com

Name: | Portable Biofluorosensor (PBS)
Purpose: | Identification of the presence of biological compounds in aerosols.
Description: | Used during Operation Desert Storm, this system detects the excitation of airborne aerosols and aerosols dissolved in water. Excitation of the molecules is achieved using ultraviolet light from a xenon flash lamp. The emission of light of particular wavelengths when the molecules return to their unexcited state allows non-specific identification of biological compounds.
Sensitivity/specificity: | Interference is minimized but false positives occasionally occur. Better analysis is achieved with solubilized spores in comparison to airborne samples.
Biothreat agents: | Determined by the identification system used.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed evaluations. Government report^ 43 ^
Contact information: | No information available.

Name: | Program for Response Options and Technology Enhancements for Chemical/Biological Terrorism (PROTECT)
Purpose: | To distinguish between naturally occurring and abnormal aerosols in order to rapidly detect and respond to a chemical or biological attack.
Description: | PROTECT is designed by the DOE specifically for detection of a biological or chemical attack on large, interior public locations (e.g., airports and subway systems) or interior buildings at special events. The system consists of a network of chemical and biological sensors, as well as computer programs that model airflow through the area to determine the possible spread of the contaminant. In addition, it includes tools to enable prompt and effective decision-making during such an attack, training exercises, and decontamination procedures.
Biothreat agents: | Determined by the identification system used.
Sensitivity/specificity: | Determined by the identification system used. Currently under evaluation.
IT or DSS: | IT
Source of information: | No peer-reviewed evaluations. Government Web sites^60, 61^
Contact information: | DOE Argonne National Laboratory, Decision and Information Sciences

Name: | Short-Range Biological Standoff Detection System (SR-BSDS)
Purpose: | Designed to detect biologically active aerosol clouds at distances up to 5 kilometers.
Description: | SR-BSDS is designed to detect and track biological aerosol clouds while discriminating between biological and non-biological aerosols as well as hard targets. The detection is based upon an infrared beam that automatically scans for aerosol clouds and, if a cloud is detected, a laser-induced ultraviolet beam is used for determining the makeup of the cloud. This information is transmitted over a radio to a command post. Once the system is set up it operates autonomously. This scanning procedure continues to operate without any need for additional intervention. One drawback of the system, however, is its large size (50" W, 53" D, and 56" H, weighing approximately 1050 lbs).
Sensitivity/specificity: | No information available.
Biothreat agents: | Determined by the identification system used.
IT or DSS: | IT
Source of information: | No peer-reviewed evaluations. Government report,^ 36 ^ other Web sites,^39, 70^and other.^ 10 ^
Contact information: | Collaborative effort of Fibertek and U.S. Army Fibertek, Inc. 510 Herndon Parkway Herndon, VA 20170 Ph: 703-471-7671 http://www.cbwsymp.foa.se

Name: | Single Particle Fluorescence Counter (SPFC)
Purpose: | Counts airborne particles.
Description: | Employs continuous airflow across a 780 nm laser-diode beam, resulting in scattering from individual aerosol particles in the air. The total intensity of scattered light is measured, and particle size is calculated. This event also triggers a 266 nm UV laser pulse that causes fluorescent particles to emit light at different wavelengths.
Sensitivity/specificity: | No information available. Sensitivity and specificity will also be affected by the identification system.
Biothreat agents: | Determined by the identification system used.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed evaluations. Government report.^ 43 ^
Contact information: | Naval Research Laboratory (NRL), Washington, D.C.

Name: | Spreeta
Purpose: | To detect and quantify biological particles in a sample.
Description: | A rapid surface plasmon resonance biosensor. Alone, the Spreeta sensor only measures the refractive index of non-specific materials using the Kretschmann geometry. However, the presence of a biolayer allows Spreeta to detect and quantify specific biological agents in a manner that is rapid, accurate, and portable. The sensor is inexpensive and can be easily integrated with proprietary hardware and software.
Sensitivity/specificity: | No information available.
Biothreat agents: | No information available.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed information. Other Web site.^ 71 ^
Contact information: | Texas Instruments, Incorporated Ph: 888-438-2214 tisensors@ti.com

Name: | Vertical Cavity Surface Emitting Laser (VCSEL)
Purpose: | Detection of changes in human red blood cells indicative of exposure to biothreat agents.
Description: | Instead of creating beams that pass through blood cells and then yield data, researchers insert blood samples into the laser itself to become part of the generation process of the VCSEL laser beams, altering them as they are formed. Above a specialized semiconductor, a coated glass mirror forms one end of the laser generating area. A blood sample is pumped through etched microgrooves in the glass. This design allows blood components (red cells, white cells, and pathogens) to become part of the lasing process. The components of the blood modify the lasing light as it is created in the tiny laser cavity, thus permitting output light to be analyzed in a spectrometer to detect changes in cell sizes and shapes. For victims of terrorist biological or chemical attacks, the transportable unit is expected to greatly reduce the time needed to analyze dangerous materials invading the blood stream. Diagnosis could be made on the spot, facilitating treatment when speed is crucial.
Sensitivity/specificity: | No information available.
Biothreat agents: | No information available.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed evaluations. Other.^72, 73^
Contact information: | Patented jointly by Sandia National Laboratory and the National Institutes of Health. http://www.sandia.gov/media/vcsel.htm

Name: | XM2 and PM10
Purpose: | Particulate air samplers that can be mounted in high-mobility, multi-purpose wheeled vehicles.
Description: | XM2 is a military biological air sampler and PM10 is its commercial biological air sampler prototype. Both collect airborne particles on a collection plate and alert the operator if the air passing through the system has more particles than the normal calibrated value. During the Gulf War, after a XM2 or PM10 alert, soldiers took a sample from the collection plate and processed it with a Sensitive Membrane Antigen Rapid Test (SMART™) kit (see section 3.2.1.3).
Sensitivity/specificity: | No information available. Sensitivity and specificity will also be affected by the identification system.
Biothreat agents: | Determined by the identification system used.
IT or DSS: | Neither when operated as stand-alone units.
Source of information: | No peer-reviewed evaluations. Government reports,^36, 74^ other Web site,^ 39 ^ and other.^ 10 ^
Contact information: | DOD

### Identification Systems

Name: | Advanced Nucleic Acid Analyzer (ANAA)/Handheld Advanced Nucleic Acid Analyzer (HANAA) (also called mini-PCR)
Purpose: | Portable, rapid, rugged system for field detection of biothreat agents.
Description: | The low-power (for battery operation) ANAA consists of an array of 10 reaction modules and a laptop computer. It uses silicon chip-based spectrofluorometric thermal cyclers with no moving optical components, custom plastic sample tubes with caps, and software tailored for first responders such as emergency medical technicians. When the analysis algorithm determines that the signal is positive, the software automatically informs the user via an audible alert and a green-to-red indicator.
Sensitivity/specificity: | Belgrader et al. report the results of an evaluation in which ANAA was able to detect 500 CFUs of E. herbicola, a vegetative bacterium that they used as a surrogate for Y. pestis, in 15 minutes. In a second analysis, after modifications to the thermal cycling, ANAA was able to detect 500 CFUs of E. herbicola in 7 minutes.
Biothreat agents: | Limited only by the available probes.
IT or DSS: | IT
Source of information: | Peer-reviewed evaluation^ 76 ^ and other.^ 92 ^
Contact information: | Lawrence Livermore National Laboratory Biological and Biotechnology Research Program P.O. Box 808, L-452 7000 East Avenue Livermore, CA 94551

Name: | AK (Adenylate kinase) Phage Biosensor
Purpose: | Provides rapid, automated diagnosis of infectious diseases using the AK Phage technique.
Description: | The AK Phage Biosensor uses bacteriaphages (special viruses that infect particular bacteria) to identify an infectious agent within a few hours. When the correct bacteriaphage is applied to individual bacteria from a patient sample, the bacteria will lyse. This event produces the release of adenylate kinase, which can be detected by measuring the light from the light-emitting enzyme luciferase. In addition to identifying the bacteria, the biosensor can also be used to determine which antibiotics should be used to treat a particular patient.
Sensitivity/specificity: | No information available.
Biothreat agents: | No specific information available.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed information. Other.^99, 100^
Contact information: | Available through a joint effort between the UK's DERA and Acolyte Biomedica Ltd.

Name: | Anthrax Sensor
Purpose: | Highly sensitive, portable detection of biological agents in mere seconds. Currently under development.
Description: | This anthrax sensor combines an optical fiber sensing device with technology designed to purify pharmaceuticals present in blood plasma at trace levels. Due to its high level of sensitivity, hundreds of biological warfare agents that were previously undetectable can now be identified. An additional advantage of the new sensor is that it is able to provide results in a matter of seconds. Currently, only a prototype of the device is available but researchers hope to develop a belt pack size, battery-generated portable device that could be taken into the battlefield or anywhere else this kind of monitoring is required.
Sensitivity/specificity: | Experiments have demonstrated that the prototype biosensor is capable of detecting endotoxins at a level that is 20 times lower than previously achieved by other similar devices.
Biothreat agents: | B. anthracis, other endotoxins.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed information. Other Web site.^ 101 ^
Contact information: | Virginia Tech Pharmaceutical Engineering Institute Chemical Engineering 132 Randolph Hall Blacksburg, VA 24061 Ph: 540-231-7869 http://www.accessexcellence.com/WN/SUA12/anthrax298.html

Name: | Australian Membrane and Biotechnology Research Institute (AMBRI) Biosensor Technology
Purpose: | Highly sensitive and specific detection of a variety of biothreat agents using a cell-based model.
Description: | The AMBRI biosensor technology emulates the natural cell sensory system. It uses a synthetic lipid bilayer membrane containing ion channels that can be switched on and off in response to the presence of an analyte. Artificial membrane components include membrane-forming molecules chemically tethered to a gold coated surface, simple ion channels within the membrane that facilitate the transport of ions like sodium, a reservoir space between the surface and the membrane to store ions, and receptors, such as antibodies, attached to the membrane to recognize target molecules. When a target molecule is present and binds the antibodies, it alters the population of conduction ion channel pairs within the tethered membrane, resulting in a change in membrane conduction of electrical current. The synthesized lipid bilayer membrane is integrated into a microelectrode array, and this system converts the biological event into a digital signal enabling computer technology to analyze and define the biological event. AMBRI expects that by combining the precise structure of the ion channel sensor membrane with micron scale ultra-violet photolithography of membrane components and the reproducibility of silicon fabrication processes, they will suppress interfering signals by at least 2 orders of magnitude compared with any other biosensor technique and, through further modifications and new developments, enhance the stability of the biosensor making it suitable for field conditions. To date, a 32 (4x8) electrode flow cell biosensor has been tested. In addition, a 96-channel silicon chip has been fabricated with 96 onboard amplifiers and 8 A/D converters. Optical patterning of the biosensor binding sites has also been demonstrated. The biosensor technology has applications in bioterrorism detection, food testing, veterinary diagnostics, and environmental monitoring.
Sensitivity/specificity: | Currently the sensor response to bacteria is at 3000 CFU/mL, with further sensitivity enhancement strategies testing down to 100 femtomolars of thyroid stimulating hormone and with a response time of 2 minutes.
Biothreat agents: | Phage display antibodies libraries are available for Y. pestis, in addition to monoclonal and polyclonal antibodies for Y. pestis, F1 antigen, B. anthracis, and C. burnetti.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed information. Government Web site^ 103 ^ and other Web site.^ 102 ^
Contact information: | Australian Membrane and Biotechnology Research Institute (AMBRI) 126 Greville Street Chatswood NSW Australia 2067 info@ambri.com.aum Ph: + 61 2 9422 3000; Fax: + 61 2 9422 3013 http://www.ambri.com.au http://www.darpa.mil/dso/thrust/bwd/advdiag/Programs/AMBRI.html

Name: | Biolog microbiologic identification system
Purpose: | A general identification system for microorganisms, with possible uses for B. anthracis.
Description: | Although B. anthracis is not included in Biolog's system database, the Chemical and Biological Defense Establishment (UK) and the Centre for Applied Microbiology and Research (UK) created an experimental in-house database for B. anthracis. Testing demonstrated a high level of sensitivity, as well as a high level of false-positive results. The system could be used as a preliminary test for B. anthracis, but further analysis would be necessary.
Sensitivity/specificity: | In-house database correctly identified all samples of B. anthracis with readable profiles (19 out of 20). However, it also falsely identified 5 out of 12 closely related Bacillus strains as B. anthracis. For both B. anthracis and related strains, roughly 20% of the samples gave false positive reactions, in which all reaction wells were positive.
Biothreat agents: | B. anthracis not included in Biolog's commercially available database; no information on other biothreat agents.
IT or DSS: | IT
Source of information: | Peer-reviewed article.^ 88 ^
Contact information: | Biolog, Inc. Hayward, CA

Name: | Biosensor for E. coli
Purpose: | Rapid detection of E. coli, using a simple change in color to denote the presence of the bacteria.
Description: | Government documents report that researchers at Lawrence Berkeley National Laboratory are developing a biosensor for E. coli that uses a simple color change to indicate the presence of the bacteria. Made of a thin film of linked diacetylene molecules, the sensor reflects red light when the bacteria are absent. However, when E. coli molecules bind to receptor molecules on the detector, the molecules reorganize and emit a blue light. The report suggests that this sensor will provide a rapid method for detecting E. coli 0157:H7 with future applications for other biothreat agents including cholera toxin.
Sensitivity/specificity: | No information available.
Biothreat agents: | E. coli.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | Peer-reviewed report^ 105 ^ and other.^ 104 ^
Contact information: | Lawrence Berkeley National Laboratory http://www.lbl.gov/ http://www.pnl.gov/er_news/06_97/art1.htm http://www.sciam.com/0397issue/0397techbus4.html

Name: | BioThreat Alert (BTA™) Strips
Purpose: | Portable antigen-antibody test designed for field detection of biothreat agents.
Description: | The BTA™ test strip employs agent-specific antibodies to identify the potential threat. The suspect material, solid or liquid, is mixed with an aqueous solution, the BTA™ Sample Buffer. Five drops of the liquid mix are added to the sample port of the test strip. The sample interacts with the reagents and moves along the test material, inside the test strip's plastic case. Lateral-flow immunochromatography then provides the results. Screening results are produced in 15 minutes. Two solid bands, one in the control area and one in the sample area, indicate a positive result. One solid band (in the control area) indicates negative results. Any other combination of bands indicates an invalid result, indicating the test should be rerun. The results may be read visually, or, for greater accuracy, using the Guardian BTA™ Test Strip Reader. The Test Strip Reader prompts the user through the evaluation procedure (on the LCD display), provides a printout of the test results and time/date stamp. Embedded radio frequency identification technology can be used to document the chain of custody for each individual BTA™ strip test. A separate and specific test strip is required to screen for each biological threat.
Sensitivity/specificity: | Per the manufacturer, the B. anthracis strips do not cross-react with B. thuringensis. They indicate that current specifications for BTA™ test strips are available to emergency response or law enforcement officials upon request by calling 847-419-1507.
Biothreat agents: | Test strips are available for B. anthracis, Ricin toxin, S. enterotoxin B, Botulinum toxin and Y. pestis.
IT or DSS: | Neither when operated as a stand-alone unit. However, it is an IT when its data are transferred to a computer.
Source of information: | No peer-reviewed information. Other Web site.^ 90 ^
Contact information: | Marketed by Alexeter Technologies 830 Seton Court, Suite #6 Wheeling, IL 60090 Ph: 847-419-1507; Toll free: 877-591-5571; http://www.alexeter.com

Name: | CellChip™
Purpose: | Performs a high-throughput and high-content analysis of intact cells; includes the ability to detect anthrax.
Description: | The CellChip™ is a rapid toxin detection and characterization method. It contains 96 different assays within 0.1 cm^2^, one of which is the FRET-based anthrax sensor. High-resolution fluorescence imaging allows the simultaneous detection of 2 or more proteins or pathways in the sample. The data produced by this assay is linked to a domain knowledge base created from both knowledge mining and computational approaches.
Sensitivity/specificity: | No information available.
Biothreat agents: | B. anthracis.
IT or DSS: | IT
Source of information: | No peer-reviewed information. Other Web site^ 107 ^ and other.^ 106 ^
Contact information: | Cellomics Inc. and DARPA http://www.darpa.mil/mto/compcad/workshops/biocad.pdf http://www.cellomics.com/html/technology/high_content.htm

Name: | DNA Biochip
Purpose: | Rapid identification of biothreat agents using microelectro-optical probes such as DNA.
Description: | Under development at Oak Ridge National Laboratory, the DNA biochip is a rapid gene probe-based biosensor. The matchbox-sized biochip offers the promise of high selectivity and sensitivity by mimicking the recognition system used by a living cell. In the future, it is hoped that the chip's ability will be expanded to detect hundreds of different genes, allowing it to identify both bacterial and viral agents.
Sensitivity/specificity: | No information available.
Biothreat agents: | No information available.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed information. Other.^ 93 ^
Contact information: | Oak Ridge National Laboratory The University of Tennessee Department of Comparative Medicine F258 Veterinary Teaching Hospital Knoxville, TN 37996 Ph: 865-974-5576

Name: | DOD Biological Sampling Kit (BSK)
Purpose: | Antigen-antibody test designed for screening of suspicious packages and munitions for biothreat agents.
Description: | The DOD BSK is a simple, pre-packaged kit that contains: a panel of 8 handheld assays, a bottle of buffer solution, 2 sterile cotton swabs, and an instruction card. Each kit is for one time use.
Sensitivity/specificity: | It should not be used with soil samples as they may cause false positives.
Biothreat agents: | Eight assays, not otherwise specified.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | Peer-reviewed article.^ 91 ^
Contact information: | Currently the DOD BSK is available for military use from the Joint Program Office for Biological Detection. It is not clear if these kits will be made available to first responders.

Name: | Fiber Optic Wave Guide (FOWG) and Rapid Automatic and Portable Fluorometer Assay System (RAPTOR™) and Analyte 2000™ Biological Detection
Purpose: | Portable biothreat identification system using antibody probes.
Description: | These systems have antibody probes bound to glass optical fibers that are immersed in a capillary tube containing an aqueous solution of the sample. Other antibodies, tagged with florescent dye, are added to the sample, where they bind to the target antigen. The antigen-labeled antibody complex then binds to the immobilized antibody. Light from a laser travels through the optic fiber. The very small amount of light that escapes from the optic fiber, the evanescent wave, excites the fluorescent tags, whose emission is sent back up the fiber and detected via a photodiode. RAPTOR™, the commercially available version of FOWG, is designed for severe transportation and operating situations and weighs 14 pounds. The breadbox sized biosensor runs specific antibody-based assays in a disposable cartridge the size of a credit card. Up to 4 samples can be simultaneously run with a separate user-defined protocol for each multi-step assay. The Analyte 2000™ includes a fluidics unit that automatically introduces sample, buffer, and fluorescent reagent to the fibers as necessary. Remote identification of airborne bacteria is possible when the Analyte 2000™, its accompanying fluidics system, an air sampler, and a radio transceiver are integrated into a remotely piloted plane. Tests against airborne bacteria demonstrated that the system could effectively collect bacteria, identify it, and radio the data to the ground with a measurement rate of 1 sample per second (although there is a warm-up time of 15 minutes). The Analyte 2000™ is 20 cm length (L) by 8.5 cm H by 11.2 cm W; weighs 1.6 kg; and is controlled by a remote computer. However, the peripheral equipment, including a laptop computer required to operate the system and supplementary buffer and waste bottles contribute some bulk. This instrument was field tested by the U.S. military to identify toxins from Iraq and by first responders of the 1999 World Trade Organization conference in Seattle to screen for potential biothreat agents.
Sensitivity/specificity: | It has the following estimated detection levels (in water): B. anthracis (30-100 CFU/mL), Ricin (less than 10ng/mL), S. enterotoxin (1 ng/mL), F. tularensis (10^5^ CFU/mL), V. cholerae (10 ng/mL) and Y. pestis at levels below 1 ppb from samples of a few hundred mL. Additional sensitivity data are available at: http://www.resrchintl.com/images/raptor_fs_report_010300.pdf.
Biothreat agents: | B. anthracis, Ricin, S. Enterotoxin B, F. tularensis, V. cholerae Y. pestis, E. coli O157:H7, Listeria, Salmonella, and Cryptosporidium.
IT or DSS: | FOWG and RAPTOR™ are neither when used as stand-alone units. However, the Analyte 2000™ is an IT.
Source of information: | Peer-reviewed article,^ 77 ^ government report,^ 36 ^ and other Web sites.^46, 78-81^
Contact information: | Developed by the Naval Research Laboratory. Commercialized under a license to Research International, who markets the portable device as RAPTOR™. 18706 142^nd^ Ave. N.E. Woodinville, WA 98072 Ph: 425-486-7831; Fax: 425-485-9137 http://www.resrchintl.com/raptor_source.htm

Name: | Field Kit for Rapid Detection of Anthrax
Purpose: | Rapid detection of B. anthracis in the field.
Description: | Berkeley Lab researchers have developed what they report to be a rapid and accurate genetic-based assay for the field detection of B. anthracis in environmental or clinical specimens.
Sensitivity/specificity: | Reported to have a low false positive rate even in specimens that contain closely-related Bacillus species and other microorganisms.
Biothreat agents: | B. anthracis.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed information. Government Web site.^ 94 ^
Contact information: | Lawrence Berkeley National Laboratory is seeking an industrial partner to commercialize a field diagnostic kit.

Name: | Fluorescence-based array immunosensor
Purpose: | Simultaneous, antibody-based detection of bioactive analytes in clinical fluids such as whole blood or a nasal swab.
Description: | This planar waveguide immunosensor offers rapid, portable analysis of complex bodily samples. It is capable of detecting multiple analytes in a single sample using antibody-antigen interactions. It is easy to use, even by inexperienced operators, and has sensitivity levels comparable to ELISA methods. No pre-treatment of the sample is needed. Analytes are collected by a patterned array of recognition elements located on the waveguide and then quantified using fluorescent detector molecules. The analyte is identified through computer-aided analysis of fluorescent signals from the antigen-antibody complex. Detection of analytes occurs within 15-35 minutes.
Sensitivity/specificity: | Unable to detect physiologically relevant S. enterotoxin B levels (<125 ng/mL) in experimentally spiked urine, saliva, and blood products; sensitivity for F1 antigen from Y. pestis at 25 ng/mL in body fluids.
Biothreat agents: | Include S. enterotoxin B and F1 antigen from Y. pestis.
IT or DSS: | IT
Source of information: | Peer-reviewed article.^ 89 ^
Contact information: | Center for Bio/Molecular Science and Engineering, Code 6900 Naval Research Laboratory 4555 Overlook Avenue, SW Washington, DC 20375-5348 Geo-Centers, Inc. Rockville, MD

Name: | GeneChip^®^ (LifeChip High-Density Nucleic Acid Microarrays)
Purpose: | Rapid, simultaneous detection of numerous nucleic acids of biothreat or other pathogens.
Description: | GeneChip^®^ is a dime-sized array of 100,000 or more fluorescence-tagged hybridization probes that are read optically to detect gene mutations. The instrumentation is expensive and the chips themselves have a shelf life of only a few months, but the speed and ability to search so many genes at one time would be highly desirable particularly in clinical settings where probes for common pathogens (e.g., influenza) and biothreat agents could be placed on the same chip.
Biothreat agents: | The number of identifiable agents is limited by the development of probes.
Sensitivity/specificity: | No information available.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed information. Other Web site^ 95 ^ and other.^ 10 ^
Contact information: | These chips and probes are being developed in collaboration with Affymetrix, Lawrence Livermore National Laboratory, and USAMRIID. Affymetrix, Inc. 3380 Central Exwy Santa Clara, CA 95051 Ph: 888-DNA-CHIP (888-362-2447); Fax: 408-481-9442

Name: | Handheld Immunochromatographic Assays (HHA)
Purpose: | Handheld antigen-antibody test for rapid detection of biothreat agents.
Description: | A small quantity of solution containing the suspected agent is placed in a well on the assay. A color change provides a positive or negative indication within 15 minutes.
Sensitivity/specificity: | The sensitivity of these assays varies from an order of magnitude below a fatal dose (ricin) to more than an order of magnitude above the infectious dose (anthrax). These devices are strictly screening assays, and the analyses are subject to error from the introduction of contaminants. Therefore, positive results need to be confirmed with standard microbiology assays, conventional immunoassays, or genome detection technology.
Biothreat agents: | Designed to identify 1 agent per assay and can currently identify 8 different threat agents (Y. pestis, F. tularensis, B. anthracis, V. cholerae, S. enterotoxin B, ricin, botulinum toxins, Brucella species) and 4 simulant agents (nonpathogenic agents used to evaluate detection systems for biothreat agents).
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed information. Government report^ 36 ^ and other.^ 10 ^
Contact information: | Currently produced by the Navy Medical Research Institute at Bethesda, Maryland. Similar devices have recently become commercially available through Environmental Technologies Corporation.

Name: | LightCycler™, Ruggedized Advanced Pathogen Identification Device (RAPID™) and Lightweight Epidemiology and Advanced Detection and Emergency Response System (LEADERS)
Purpose: | LightCycler™ is an ultra rapid PCR thermal cycler with built in fluorimetric detection system for real-time quantification of DNA samples. RAPID™ is a rugged, portable system that uses LightCycler™ technology for field detection of biothreat agents. LEADERS is a medical surveillance tool that provides real-time analysis of surveillance data coming from any number of sources (e.g., biosensor data from a system like RAPID™, syndromal surveillance data from emergency rooms, pharmacy sales data) to identify the presence of a biothreat agent.
Description: | LightCycler™ (available through Roche Diagnostics) can carry out 30 cycles in 6 minutes by using tiny glass capillary tubes for the sample and high-velocity hot and cold air. RAPID™, developed as a collaboration between Idaho Technologies and the U.S. Air Force, integrates LightCycler™ technology into a portable, rugged package that is capable of real-time on-line automated analysis of any nucleic acid. Per the manufacture, field personnel with minimal training can prepare the sample, place them in the instrument, and push one button for a result. RAPID™ also provides real-time monitoring via a Web browser so that experts at any remote location can monitor reactions in the field. LEADERS integrates data from any number of surveillance systems (including detectors) for analysis to detect outbreaks and displays these data in a variety of ways for the purposes of outbreak investigation and command and control.
Sensitivity/specificity: | This will be largely a function of the probes use. Per the manufacturer, RAPID™ is reported to be 99.9% specific. The sensitivity is set for each assay for half the infective dose (for example, the infectious dose of Foot and Mouth Disease is 10 virus particles; RAPID™'s sensitivity is set to detect 5 virus particles).
Biothreat agents: | Limited only by the available probes. Can assay for 10 unknown organisms per run.
IT or DSS: | LightCycler™ and RAPID™ are neither when operated as stand-alone units. LEADERS is an IT.
Source of information: | No peer-reviewed information. Other Web site.^ 85 ^
Contact information: | Idaho Technology and Roche Diagnostics Idaho Technology 390 Wakwara Way Salt Lake City, UT 84108 Ph: 801-736-6354 http://www.idahotech.com http://biochem.roche.com/lightcycler/

Name: | Luminometer Rapid Detector
Purpose: | Rapid, portable method of detecting live bacteria on animal carcasses.
Description: | The Luminometer is a handheld device currently being used on poultry and beef carcasses to measure the amount of live bacteria present. It provides an estimate of the total number of bacteria on the carcass by monitoring the amount of light emitted by the sample. Live bacteria release adenosine triphosphate, which leads to the production of light through its effects on luciferin and luciferase. Consequently, the intensity of the light measured by the Luminometer is directly proportional to the amount of live bacteria. The Luminometer is also proposed as a screening tool to detect bacteria in animal feed, although it has not been validated for this use.
Sensitivity/specificity: | Instrument sensitive to low levels of bacteria (1000 organisms)
Biothreat agents: | Not specified.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | Peer-reviewed article.^ 82 ^
Contact information: | New Horizons Diagnostics Corporation 9110 Red Branch Road Columbia, MD 21045 Ph: 410-992-9357, ext. 235 or 232; Fax: 410-992-0328

Name: | MicroArray of Gel Immobilized Compounds on a Chip (MAGIChip™)
Purpose: | Provides rapid screening of drug resistant mutations in Mycobacterium tuberculosis.
Description: | This system uses a microarray of gel-immobilized, fluorescence-labeled nucleic acid. Another application by the same manufacturer (unclear if it is currently available) includes a "Bacillus microchip" to detect B. anthracis, indicate whether it is alive or dead (DNA matches, but no RNA matches), and distinguish it from other related bacteria, such as B. thuringiensis, B. subtilis, and B. cereus. Another array (unclear if it is currently available) uses RNA probes to take advantage of the highly conserved 16S ribosome to provide a tentative taxonomic assignment of unknown bacterial pathogens, including novel or bioengineered organisms.
Sensitivity/specificity: | No information available.
Biothreat agents: | Limited by the probes used on the array.
IT or DSS: | IT
Source of information: | No peer-reviewed information. Government report^ 36 ^ and other.^10, 96^
Contact information: | Developed by Argonne National Laboratory and the Russian Academy of Sciences.

Name: | MiniFlo
Purpose: | Rapid, portable detection of multiple biological agents using an innovative approach to flow cytometry.
Description: | Lawrence Livermore National Laboratory's (LLNL) MiniFlo portable flow cytometer is capable of rapid, simultaneous detection of several biological agents, including viruses, bacteria and proteins. Conventional flow cytometers detect variations in biological cells or their DNA by analyzing the scattered light pattern created when laser beams are directed at a single-file stream of cells in solution. In contrast, MiniFlo uses a unique approach in which the flow stream itself is used as the waveguide for the laser beams, thereby allowing faster, more accurate analysis.
Sensitivity/specificity: | According to the June 1998 volume of Lawrence Livermore National Laboratory's "Science and Technology Review," the rugged cytometer detected 87% of unknown biological agent simulants, including ones for anthrax and plague, with a false positive rate of 0.4% at the Dugway, Utah Field Trials in 1996^ 98 ^.
Biothreat agents: | Y. pestis and B. anthracis, as well as other viruses, bacteria and proteins.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed information. Other.^55, 98^
Contact information: | Lawrence Livermore National Laboratory http://www.llnl.gov/

Name: | Nitric Oxide (NO) Sensor
Purpose: | Sensitive, rapid detection of biothreat agents. Currently under development.
Description: | The University of Maine and the Sensor Research and Development Corporation, under sponsorship from DARPA, are currently collaborating on the development of a "biowarfare breathalyzer" which would monitor NO levels as an early sign of exposure to biological pathogens. According to Stephen Morse of DARPA, exhaled NO levels are higher in symptomatic subjects, sometimes even before changes in self-reported symptoms. A compact, portable NO sensor may be a future option for detection of biological warfare agents.
Sensitivity/specificity: | No information available.
Biothreat agents: | No information available.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed information. Government Web sites.^108, 109^
Contact information: | DARPA http://www.darpa.mil/darpatech99/presentations/dsopdf/dsobwd1.pdf http://www.darpa.mil/dso/thrust/bwd/advdiag/programs/maine.html

Name: | Optical fluorescence biosensor technique
Purpose: | A reagent-free technique for the rapid detection of biological toxins and pathogens.
Description: | Los Alamos National Laboratory has developed a rapid and highly sensitive optical technique based on the unique relationship between cell surface receptors and the biological toxins or pathogens that target them. The presence of the toxin is signified by a 2-color optical fluorescence change that occurs only after the aggregation of receptors within a bilayer membrane, which takes place after the binding of a toxin to such receptors. Changes in fluorescence are easily monitored in a flow cytometer.
Sensitivity/specificity: | Sensitivities down to less than 50 parts per trillion have been demonstrated.
Biothreat agents: | Capable of identifying specific protein toxins, such as the cholera toxin.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | Peer-reviewed report^ 110 ^ and other.^ 111 ^
Contact information: | Los Alamos National Laboratory http://www.newswise.com/articles/1998/11/CHOLERA.LAL.html

Name: | Pyrolysis-gas Chromatography-ion Mobility Spectrometer (PY-GC-IMS)
Purpose: | Portable system for detection and identification of biological aerosols.
Description: | PY-GC-IMS is a rugged, fully self-contained system performing trigger, detection, and classification functions for biological aerosols. Samples are first combusted, then separated by gas chromatography, and finally analyzed using an ion mobility spectrometer; minimal post data processing is required. In recent testing at the Joint Field Trials-6 in DRES, Suffield, Alberta, Canada, the PY-GC-IMS was linked to the XM-2 aerosol concentrator and produced promising results in regards to samples containing simulants for protein toxins, bacteria, and sporulated bacteria. Biodetection takes approximately 3 minutes. It is also capable of chemical warfare agent detection.
Sensitivity/specificity: | No information available. Partially determined by the type of collection system used.
Biothreat agents: | Protein toxins, bacteria, and sporulated bacteria.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed information. Government report^ 43 ^ and other.^ 97 ^
Contact information: | PY-GC-IMS was recently developed in a joint partnership between ECBC and the University of Utah.

Name: | RealTime BioSensor
Purpose: | Automated, rapid detection of a wide variety of biological pathogens.
Description: | The RealTime BioSensor is a portable detector currently being developed by a joint partnership of MesoSystems Technology Inc and DARPA. Combining Mesosystem's cell capture technology and a sensitive immuno-electrochemical sensor system, this technology offers the possibility of automated, real-time detection of biowarfare agents. The sensor can be linked to either fluidic or aerosol samplers. There is a digital output of results.
Sensitivity/specificity: | The current prototype has a high sensitivity, demonstrated by its ability to detect low numbers (100) of bio-contaminants in samples ranging from millimeters to liters.
Biothreat agents: | Includes airborne pathogens, E. coli 0157:H7 and Salmonella.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed information. Other Web site.^ 112 ^
Contact information: | MesoSystems Technology, Inc. http://www.mesosystems.com/bs.htm

Name: | Sensitive Membrane Antigen Rapid Test (SMART™) and the Antibody-based Lateral flow Economical Recognition Ticket (ALERT) system
Purpose: | Rapid, portable antigen-antibody test for the detection of biothreat agents.
Description: | SMART™ is a self-contained, colorimetric, solid-phase immuno-filtration assay designed to be used in conjunction with an aqueous sample. Two types of SMART™ devices have been developed: one for detecting endospore-forming bacteria, and another for proteinaceous toxins or soluble antigens. Antibodies specific to the agent of interest are conjugated to colloidal gold particles. Two steps are involved in the process: first, the sample and reagent must be mixed manually, and, second, the sample must be applied to the test kit, which "tells" if antigen is present in the sample. The mixing step can be automated by using the ALERT system, which uses capillary action to move the sample up a membrane strip over embedded reagent. Both systems require antibody reagent development work before being ready for use. The presence or absence of the target antigen is detected by a small red dot that the user compares to a color chart.
Sensitivity/specificity: | When field tested during the Gulf War, the SMART™ system had an "alarmingly" high false positive rate thought secondary to contamination of sample fluid from fragments of filter fiber from the SMART™ kit and environmental silt particles.^ 74 ^ Apparently, after addressing these issues, no additional false positives were detected.^ 74 ^ Other diagnostic devices also manufactured by New Horizons include: Profile^®^-1, Total ATP, Bengal SMART™, Cholera SMART™, BengalScreen, and CholeraScreen. Profile^®^-1 is specifically designed for detection of bacterial contaminants of pork, beef, and poultry and is used by the United States Department of Agriculture. Bengal SMART™ is a dot-on-a-membrane test for V. cholerae O139 and, per the manufacturer, has a 99% sensitivity and 99% specificity. Cholera SMART™ is reported to be capable of detecting as few as 2x10^3^ organisms of V. cholerae O1. BengalScreen and CholeraScreen are coagglutination tests for V. cholerae O139 and O1, respectively. They both have a sensitivity of 96% and a specificity of 94%. The tests take less than 10 minutes to run.
Biothreat agents: | One report said that the kits can detect B. anthracis or botulinum toxin in a sample in approximately 45 minutes. Another source reported that SMART™ kits were available for B. anthracis, S. enterotoxin B, Y. pestis, botulinum toxins, ricin, Venezuelan Equine Encephalitis, and Brucella species and that the response time was 5 to 15 minutes.^ 84 ^
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | Peer-reviewed article,^ 82 ^ government reports,^36, 74^ and other Web sites.^83, 84^
Contact information: | New Horizons Diagnostics Corporation 9110 Red Branch Road Columbia, MD 21045 Ph: 410-992-9357, ext. 235 or 232; Fax: 410-992-0328 http://www.nhdiag.com/index6.html

Name: | SmartCycler^®^ and GeneXpert™
Purpose: | Real-time nucleic acid-based detection in laboratory and field situations.
Description: | The micro-fluidic circuits automatically process fluid samples, mix reagents, and purify DNA, which then undergoes PCR amplification, providing detection capabilities within an hour. Testable samples include blood, swabs, urine, cell cultures, food and industrial water. The dimensions of the processing block are: 12"W x 12"H x 10" L; weight 22 lbs (the entire kit with processing block, computer and accessories is 65lbs). Sixteen independently programmable channels can run tests without batching. The same manufacturer has developed GeneXpert™, which is designed to integrate automated sample preparation with SmartCycler^®^ amplification and detection technology in a disposable cartridge format (it is unclear when GeneXpert™ will become commercially available).
Sensitivity/specificity: | The system is reported to be specific to 12 B. anthracis strains tested and able to detect 5 genome copies.
Biothreat agents: | Depends on available probes.
IT or DSS: | IT
Source of information: | No peer-reviewed information. Other Web site^ 87 ^ and other.^ 86 ^
Contact information: | Developed by a partnership of USAMRIID and Lawrence Livermore National Laboratory and commercialized by Cepheid, Inc. Cepheid, Inc. 1190 Borregas Ave Sunnyvale, CA 94089-1302 http://www.cepheid.com/pages/contact.html

Name: | Tissue-Based Biological Sensor (TBBS)
Purpose: | Detection of biological pathogens using a technique that mimics the response of the body's own immune response. Capable of detecting new organisms, which have not been identified at the molecular level.
Description: | The CANARY project is developing a TBBS that uses B-cells to detect harmful agents in combination with high-density microarray technology. B-cells are part of the body's immune system and produce exquisitely sensitive antibodies in response to foreign antigens. In the CANARY project, B-cells are engineered to light up when they bind to a specific antigen, allowing the user to detect the event optically. A panel of B-cells, engineered to detect a variety of pathogens, is integrated into a microfluidic chip. When a potential pathogenic sample is introduced into the system it can be rapidly screened for the presence of any of the antigens specific to the engineered B-cells. Preliminary results using several prototype chips have demonstrated high specificity in addition to rapid response. In addition, this technology has been incorporated into prototype portable, handheld devices to determine the feasibility of their use for on-site support. Continued development is also focusing on increasing screening capability for a wider range of chemical and biological threats as well as determining the limits of sensitivity, false alarm rates, and the effects of interferents.
Sensitivity/specificity: | No information available.
Biothreat agents: | No information available.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed information. Other.^113, 114^
Contact information: | DARPA/DSO 3701 North Fairfax Drive Arlington, VA 22203-1714

Name: | Upconverting Phosphor Technology (UPT)
Purpose: | Rapid detection and identification of pathogens in the field while maintaining a high sensitivity and specificity.
Description: | This technology uses a number of rare earth compounds that, in crystal form, have the unique property of emitting a photon of visible light in response to absorbing 2 or 3 photons of lower-energy infrared light of the proper wavelength. Coating the crystals with antibody provides a highly identifiable signal, since no naturally occurring substances upconvert. Ten spectrally unique phosphors have been synthesized to date, making it possible to simultaneously probe with as many as 9 antibodies. Reportedly, a handheld sensor incorporating this technology allows portable, highly sensitive and rapid detection of multiple pathogens (e.g. bacteria, viruses, and toxins) simultaneously. After application of the liquid sample to a disposable test strip, the strip is inserted into the device and read. Results are ready in less than 5 minutes and samples can be archived at room temperature. Reading of the strip takes less than 30 seconds. A compact UPT-based flow cytometer, which is capable of simultaneously detecting and identifying up to 8 antigens, is also available. The system package weighs less than 30 pounds and occupies less than 1.6 cubic feet; however, future envisioned configurations will weigh less than 20 pounds and take-up less than 1 cubic foot while providing at least an order of magnitude more multiplexing capability.
Sensitivity/specificity: | The device can detect picogram levels of small (e.g., virus or toxin) target antigens in a sample of less than 1 ml. The goal for detection of spores and bacteria is sensitivity below 100 organisms/ml. Because no other materials in nature upconvert, there is no optical background and materials can be detected with high sensitivity even in dirty environmental samples.
Biothreat agents: | Based on the antibody probes used.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed information. Other Web site.^ 115 ^
Contact information: | SRI International 333 Ravenswood Avenue Menlo Park, CA 94025-3493 http://www.sri.com/structure/chembio.html

### Integrated Collection and Identification Systems

Name: | Biological Aerosol Sentry and Information System (BASIS)
Purpose: | Early warning of airborne biological incidents for special events such as major sporting events and political meetings through a network of distributed sampling units deployed around the target area.
Description: | Aerosol samples are regularly retrieved from Distributed Sampling Units placed around the field, which collect, store and time-register the samples. The samples are periodically transported to a field laboratory for PCR analysis. If a biothreat agent is detected, authorities are immediately notified through a linked communication system. In addition to information regarding the location and identity of the biothreat agent, BASIS provides estimates on the level and duration of exposure.
Sensitivity/specificity: | No information available.
Biothreat agents: | Agents identifiable via PCR techniques (i.e., limited by availability of reagents).
IT or DSS: | IT
Source of information: | No peer-reviewed information. Government Web site.^ 117 ^
Contact information: | Los Alamos National Laboratory PO Box 1663, MS F607 Los Alamos, NM 87545

Name: | Biological Agent Warning Sensor (BAWS) and Joint Biological Point Detection System (JBPDS)
Purpose: | Detection of biological agents in aerosol samples.
Description: | BAWS uses a laser beam to illuminate a sample air stream and a detector records reflected photons. The current output is compared with that of the past 10 minutes. The sensing algorithm classifies the change as interferent (i.e. dust), unknown, or potential bio-aerosol (which triggers an alarm). The system is intended to detect biological agents in less than 1 minute and identifies the agents in less than 15 minutes. JBPDS is an integrated collection and identification system that uses BAWS as its detector. The next version, scheduled for fielding during FY06, will integrate advances in technologies to decrease size, weight, and power requirements, as well as to detect 26 agents. The systems have numerous sharp edges that can injure users and puncture protective gear. The man-portable units are so heavy that the 4-man crews experienced difficulties in transporting them.
Sensitivity/specificity: | During field-testing, the system experienced "many false positives" and "significant human factors deficiencies: operators in protective gear experienced difficulties, particularly in assembling and disassembling the system."
Biothreat agents: | 10 agents (not otherwise specified).
IT or DSS: | Neither when operated as stand-alone units.
Source of information: | Peer-reviewed article,^ 91 ^ government report,^ 36 ^ government Web site,^ 118 ^ other Web sites,^39, 118, 119^ and other.^ 10 ^
Contact information: | BAWS was developed at the Massachusetts Institute of Technology Lincoln Laboratory. Lockheed Martin currently produces both BAWS and JBPDS.

Name: | Biological Integrated Detection System (BIDS)
Purpose: | Vehicle mounted continuous air sampler to determine the background distribution of aerosol particles.
Description: | Particles with diameters in the 2 to 10 micron range are concentrated and analyzed for biological activity, as indicated by the presence of adenosine 5'-triphosphate. Flow cytometry then separates and concentrates bacterial cells, and antibody-based tests are conducted for specific agents. Currently in use in the Washington, D.C. area (October 2001).
Sensitivity/specificity: | No information available.
Biothreat agents: | B. anthracis, Y. pestis, botulinum toxin A, and S. enterotoxin B.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed information. Government reports,^36, 66^ other Web site,^ 120 ^ and other.^ 10 ^
Contact information: | Battelle 505 King Avenue Columbus, OH 43201 http://www.battelle.org

Name: | Canadian Integrated Biochemical Agent Detection System (CIBADS II) and 4WARN
Purpose: | Networked system designed to detect a broad spectrum of chemical or biological agents.
Description: | CIBADS/4WARN consists of a group of instruments integrated into a portable unit capable of remote, unattended operation. For biological agent detection, a positive response from FLAPS^®^ (Fluorescence Aerodynamic Particle Sizer^®^) (see above under Particle Counters and Biomass Indicators) triggers the collection of a liquid sample for identification by an antigen/antibody system with an automated reader that can identify the agent. The system is radio-linked to a command and control unit which accepts incoming data from numerous sentries, plots the position of positive detection events on field maps, and couples the information to hazard assessment tools which can predict the downwind hazard and source of agent. 4WARN has been integrated into a commercial SUV (GMC Suburban) to reduce recognition by the public and was deployed in Washington, D.C. The goal was to provide a demonstration platform for the 4WARN detection system that would highlight the flexibility of configuration and the performance of the system in a mobile platform.
Sensitivity/specificity: | The system was operated in mobile modes (up to 50 mph) without significant degradation of performance. The impact of weather patterns on performance was also determined to be low. The exception was immediately after a thunderstorm, when the number of particles in the air rose dramatically and reduced the sensitivity of the system.
Biothreat agents: | Determined by the identification system used.
IT or DSS: | IT
Source of information: | No peer-reviewed information. Government Web site^ 57 ^ and other Web site.^ 116 ^
Contact information: | Computing Devices Canada 1020 - 68^th^ Avenue N.E. Calgary, Alberta Canada T2E 8P2 Ph: 403-295-6772

Name: | Joint Biological Remote Early Warning System (JBREWS)
Purpose: | Network of sensors with communication links to a command post.
Description: | JBREWS consists of a network of sensors and communication links. Initially equipped with commercially available sensors, JBREWS is being configured so that improved biodetectors can be incorporated into the system as they become available. Currently, the system includes sample identification units (for continuous sampling of air and checking for biological agent using antibody tickets), SR-BSDS units (Short-Range Biological Standoff Detection System, see above under Particulate Counters and Biomass Indicators), a radio network for transmitting sensor data that is capable of rerouting transmissions that are blocked, and a sensor network command post that collects and processes data to determine if an outbreak has occurred.
Sensitivity/specificity: | No information available. Sensitivity and specificity will also be affected by the identification system.
Biothreat agents: | Determined by the identification system used.
IT or DSS: | IT
Source of information: | No peer-reviewed information. Other.^ 121 ^
Contact information: | Developed in collaboration among Lawrence Livermore Laboratory, Johns Hopkins Applied Physics Laboratory and Los Alamos National Laboratory http://www.llnl.gov/str/Imbro.html

Name: | Joint Service Warning and Reporting Network (JWARN)
Purpose: | An automated nuclear, biological and chemical information system that is designed to integrate the data from detectors and sensors into the Joint Service command.
Description: | JWARN transfers data automatically and provides commanders with analyzed data for decisions. It is currently being developed by the DOD, and will be deployed with nuclear-biologic-chemical sensors in a wide variety of defense situations.
Sensitivity/specificity: | No information available.
Biothreat agents: | No information available.
IT or DSS: | IT
Source of information: | No peer-reviewed information. Government reports.^36, 66^
Contact information: | DOD

Name: | Mobile Atmospheric And Sampling Identification Facility (MASIF)
Purpose: | Collection of aerosol samples for evidence of biothreat agents and transmission of findings to a central command location.
Description: | This system consists of a central command location and a network of self-contained aerosol detectors that continually monitor the particulate content of the air for evidence that a biowarfare agent may be present. After an alarm is sent to the central location indicating that such an event has occurred, samples are collected and analyzed using rapid assay methods in the Mobile Agent Identification Unit. MASIF was used during the Gulf War.
Sensitivity/specificity: | No information available. Sensitivity and specificity will also be affected by the identification system.
Biothreat agents: | Determined by the assay used for identification.
IT or DSS: | IT
Source of information: | No peer-reviewed information. Government Web site.^ 122 ^
Contact information: | DRES http://www.dres.dnd.ca

Name: | Multi-Purpose Integrated Chemical Agent Alarm (MICAD)
Purpose: | Lightweight, automated nuclear-biologic-chemical (NBC) detection, warning and reporting system.
Description: | MICAD requires minimal operator input and is easily mounted in vehicles due to its small size and flexibility. Individual alerts can be transmitted from MICAD via soldier-worn pagers, while NBC reports are automatically prepared and transmitted over local and tactical Internets. Telemetry link radios integrate remote detection and area warning into MICAD's capabilities. Finally, Universal Interface Units allow the connection of 2 peripheral devices, such as detectors or alarms, making MICAD easily adaptable to other systems.
Sensitivity/specificity: | No information available.
Biothreat agents: | No information available.
IT or DSS: | IT
Source of information: | No peer-reviewed information. Other.^ 123 ^
Contact information: | Developed by Lockheed Martin. http://www.lockheedmartin.com/manassas/nbc.html

Name: | Nuclear-biologic-chemical (NBC) Field Laboratory
Purpose: | To detect and identify any kind of biological warfare agent or any other agent of biological origin representing a health risk to soldiers on the battlefield.
Description: | The NBC Field Laboratory contains 4 subsystems, a Chemical Analysis Shelter, a Radiation and HazMat Shelter, 2 Biological Analysis Shelters and a Sampling Vehicle. These shelters are capable of several rapid identification methods including PCR-assisted fluorescence, high performance liquid chromatography, enzyme-linked immunosorbent assay, and gas chromatography/mass spectrometry. The lab has numerous safety features and is reported to be "safety level 3" compliant.^124, 125^
Sensitivity/specificity: | No information available.
Biothreat agents: | No information available.
IT or DSS: | Neither when operated as a stand-alone unit.
Source of information: | No peer-reviewed information. Government report,^ 36 ^ other Web sites,^39, 124^ and other.^10, 125^
Contact information: | Rheinmetall Landsysteme GmbH Henschelplatz 1 D-34127 Kassel, Germany Ph: ++49 561 801-5189 http://www.rheinmetall-detec.com/html/ravele/h-abc.htm

Name: | Portal Shield Air Base/Port Biological Detection System
Purpose: | Rapid, automated system that integrates data from multiple sites for outbreak detection.
Description: | The system is fully automated and composed of 6 or more sensor systems (typically 12-20 sensors per site) linked to a centralized command post computer that monitors the sensors, evaluates networked sensor data to determine if a bioterrorist attack has occurred, and alerts the operator in the event of biothreat detection. The command computer incorporates algorithms that use both aerosol count and meteorological data to determine the presence of a suspicious aerosol cloud. In less than 25 minutes, it can simultaneously detect, identify and report 8 different biological agents.
Sensitivity/specificity: | The algorithm looks for a significant increase in at least 2 sensors before it will sound an alarm, giving the system a theoretical false positive rate of 0.25%. In practice, after having gone through over 10,000 assays, the Portal Shield system has not had any false positives.
Biothreat agents: | Eight agents, not otherwise specified.
IT or DSS: | IT
Source of information: | No peer-reviewed information. Government report.^ 66 ^
Contact information: | Designed by the DOD.

## Evidence Table 2: Other Diagnostic DSSs

For each system discussed in the Other Diagnostic Systems section of Chapter 3, we present selected abstracted information including its name, the purpose, a description, and information about the system's diagnostic accuracy.

Name: | BloodLink
Purpose: | To decrease diagnostic test-ordering by clinicians
Description: | BloodLink provides a computerized test-ordering form with a reduced number of tests (15 compared with 178 on the old form). To order a rarely indicated test, the clinician can type the name of the required test in a section at the bottom of the form. Clinicians can use the BloodLink to suggest diagnostic tests recommended by clinical practice guidelines.
Diagnostic accuracy: | No information available.
IT or DSS: | DSS
Source of information: | Peer-reviewed article.^ 176 ^
Contact information: | Institute of Medical informatics Erasmus University Rotterdam The Netherlands

Name: | Clinical DSS for detection and respiratory isolation of tuberculosis (TB) patients
Purpose: | To automate the detection and respiratory isolation of patients with positive cultures and chest X-rays suspicious for tuberculosis.
Description: | Each time a new patient with an abnormal chest radiograph report is entered into the electronic medical record, a natural language processing system triggers a medical logic module to check the patient's hospital location (i.e., if they are assigned to an isolation bed), evaluate the patient's immune status (i.e., checks an algorithm of laboratory and pharmacy data that suggests HIV infection). An alert message is sent via e-mail to the hospital epidemiologist indicating the date of the abnormal chest X-ray, type of abnormality, level of suspicion of TB, presence of immunocompromised status, and isolation status. This system operates 24 hours per day and requires no additional data entry.
Diagnostic accuracy: | In a retrospective analysis, 171 adult culture positive TB inpatients were used to assess the accuracy of the system: without the DSS 51% (45 of 88) patients were appropriately isolated compared with 75% (62 of 83) patients with the DSS.^ 174 ^ The system would have erroneously recommended isolation of 27 of 171 patients (false positives). In a prospective analysis, clinicians adhering to the hospital's isolation policy correctly and promptly isolated 70% (30 of 43) of patients with TB. The DSSs did not identify 21 of these patients (false negatives). However the DSS identified 4 patients not identified by the clinicians.^ 174 ^ Note, since this DSS identifies patients with positive X-rays, it can never be 100% sensitive since it cannot identify cases of X-ray-negative TB.
IT or DSS: | DSS
Source of information: | Peer reviewed article.^ 174 ^
Contact information: | 630 W. 168^th^ Street New York, NY 1002

Name: | Computer Program for Diagnosing and Teaching Geographic Medicine
Purpose: | To provide a differential diagnosis of infectious diseases matched to 22 clinical parameters for a patient; also to provide general information about infectious diseases, anti-infective agents and vaccines.
Description: | The database is limited to infectious diseases but does not include slow viral illnesses and a number of self-defined and "obvious" conditions such as otitis externa.^ 168 ^ The database includes all critical biological agents (Table 2.1). The user is first requested to indicate the country of disease origin and is then presented with a list of 22 clinical parameters which the user indicates with a + or - sign as being present or absent. The system uses a series of branching questions -- for example, if the user indicates that a rash is present, the system asks additional questions about the nature and location of the skin lesions. A Bayesian matrix processes user input and a list of possible diagnoses is presented in order of likely probability. Additional information about each disease and antimicrobial agents is also provided. For example, a user may request a list of all parasitic disease likely to be acquired in Togo from mosquitoes.
Diagnostic accuracy: | In a study to evaluate the diagnostic accuracy of this system, 6 infectious disease specialists (blinded to the patients' actual diagnoses) were asked to record all positive and negative clinical data for 295 consecutive patients with established diagnoses and 200 hypothetical cases. The computer program correctly identified 75% (222 of 295) actual cases and 64% (128 of 200) hypothetical cases. The clinical diagnosis was included in the computer differential diagnosis list in 94.7% of cases. Among the cases included in this evaluation, several were for biothreat-related organisms: anthrax, brucellosis, cholera, cryptosporidiosis, Hantavirus respiratory distress syndrome, Lassa fever, Plague, Q fever, Rocky Mountain spotted fever, shigellosis, and tularemia. However, this system was only tested on cases for which the diagnosis was known; therefore, there is no information on how it would perform for cases with unknown outcomes.
IT or DSS: | DSS
Source of information: | Peer reviewed article.^ 168 ^
Contact information: | Dept. of Microbiology Tel-Aviv Medical Center 6 Weitzman Street Tel Aviv 64239, Israel

Name: | DERMIS
Purpose: | To provide a differential diagnosis of skin lesions
Description: | DERMIS is a computerized skin disease diagnosis assistance system designed for use by general practitioners. It matches the signs of a new case with a database of signs from 5203 cases with 221 separate diagnoses collected from a single dermatology clinic. The user is led through the process of describing a rash or lesion in a structured way. Once the signs are entered, the program produces a differential diagnosis list based on these signs and a Bayesian analysis.
Diagnostic accuracy: | In a 1992 evaluation of DERMIS using descriptions of lesions by a dermatologist, the system correctly diagnosed a lesion 76% of the time and included the correct diagnosis among its top 3 choices 95% of the time (out of a total of 5203 cases).^ 177 ^ In a subsequent evaluation, DERMIS gave the correct diagnosis 51% of the time when given a description of a skin lesion by general practitioners and 80% when given a description by dermatologists (out of 100 cases). It listed the correct diagnosis in the top 3 of its differential list 70% of the time when given a description by general practitioners and 93% of the time for dermatologists.^ 178 ^
IT or DSS: | DSS
Source of information: | Peer reviewed articles.^177, 178^
Contact information: | Firm 3, St. John's Institute of Dermatology St. Thomas' Hospital Lambeth Palace Road London, SE1 7EH

Name: | Fuzzy logic program to predict source of bacterial infection
Purpose: | To use age, blood type, gender and race to predict the etiology bacterial infections.
Description: | The authors developed and evaluated a fuzzy logic program that predicts class of bacterial organism responsible for infection based on age, blood type, gender, and race. A dataset of demographic variables for 187 patients with a known bacterial infection was randomly divided into training data (155 patients) and test data (32 patients). 159 rules were kept from the training set and applied to the test set. Using the training data, a set of fuzzy rules was generated to model the system. The system generated 4 classifications of infections: "staphylococci" (S. aureus and S. epidermidis), "streptococci" (S. pneumoniae, groups B and D streptococci), "E. coli", and "non-E. coli gram negative rods" (Klebsiella, Serratia, Proteus, Morganella, Prevotella, Pseudomonas, and Bateroides species).
Diagnostic accuracy: | The program was able to correctly classify 27 of 32 patients into 1 of these 4 groups based on demographic data alone. Note, because the program was established from the data of patients with infections and then tested on patients with known infections, it is difficult to know how this system performs in detecting those patients without 1 of the 4 disease categories.
IT or DSS: | DSS
Source of information: | Peer-reviewed article.^ 171 ^
Contact information: | School of Science and Health Philadelphia University Philadelphia, PA 19144 Ph: 215-951-2664

Name: | Global Infectious Disease and Epidemiology Network (GIDEON)
Purpose: | Provide differential diagnoses for patients with diseases of infectious etiology.
Description: | GIDEON is a computer program with an extensive infectious disease database that uses Bayes' theorem to generate a list of possible diseases for a given case. No information is available regarding which biothreat agents are in the GIDEON database.
Diagnostic accuracy: | The diagnostic accuracy of GIDEON was compared with that of medical house officers admitting 86 febrile adults to the Boston Medical Center. The house officers listed the correct diagnosis first in their admission note 87% (75/86) of the time compared with 33% (28/86) for GIDEON.
IT or DSS: | DSS
Source of information: | Peer reviewed article.^ 169 ^
Contact information: | C.Y. Informatics; Ramat Hasharon; Israel

Name: | Neural Network for Diagnosing Tuberculosis (TB)
Purpose: | To use an artificial neural network that incorporates clinical and radiographic information to predict active pulmonary TB at the time of presentation at a health care facility so that patients may be appropriately isolated.
Description: | Several episodes of nosocomial transmission of Mycobacterium tuberculosis have been reported as a result of missed or delayed diagnosis, usually as a result of failure to consider the diagnosis, atypical radiographic presentation, delayed recognition of drug resistance, and lack of adequate respiratory protection.^ 175 ^ Neural networks are computation systems that process information in parallel and excel in tasks involving pattern recognition. Authors from the State University of New York at Buffalo used the medical record information of 563 patients isolated for suspicion of TB to create a general regression neural network which they tested on 119 patients. The data input included demographic variables (e.g., age and purified protein derivative (PPD) test status), symptoms (e.g., weight loss, fever, night sweats and cough), and radiographic findings (e.g., presence and location of infiltrates, cavities, and pleural effusions).
Diagnostic accuracy: | For the derivation set of 563 patients, the neural network achieved a sensitivity of 100% (95% CI: 91% to 100%) and specificity of 72% (95% CI: 65% to 77%). Clinicians correctly diagnosed active pulmonary TB in 22 of 47 patients (sensitivity of 47% (95% CI: 32% to 62%) and specificity of 75% (95% CI: 71% to 79%). For the validation set of 119 patients, the neural network correctly identified 11 of 11 patients with active TB (sensitivity of 100% (95% CI: 72% to 100%) and specificity of 69% (95% CI: 61% to 78%). Clinicians correctly diagnosed 7 of 11 patients with active TB (sensitivity of 64% (95% CI: 31% to 89%) and specificity of 79% (95% CI: 72% to 87%). The interpretation of these results are limited by the initial use of only those patients who were isolated for suspected active pulmonary TB -- therefore, the neural network does not include patients whom clinicians incorrectly chose not to isolate.
IT or DSS: | DSS
Source of information: | Peer reviewed article.^ 175 ^
Contact information: | The artificial neural network described here is available at: http://bgrant.med.buffalo.edu/activetb/

Name: | PNEUMON-IA
Purpose: | To diagnose community-acquired pneumonia from clinical, radiologic and laboratory data.
Description: | Information about cases is input into the DSS with a knowledge base that includes 22 pneumonia etiologies (including Q fever). For each of the 22 possible diagnoses, the system assigns a probability to each of the following 8 labels for each case: impossible, almost impossible, slightly possible, somewhat possible, possible, quite possible, very possible, and sure.
Diagnostic accuracy: | Reports of 76 cases of adult community-acquired pneumonia were analyzed by PNEUMON-IA and by 5 clinician experts. Ten of these 76 cases had confirmed diagnoses from microbiology data. The DSS correctly identified the diagnosis in 4 of these 10 cases compared with between 3 and 6 cases for the clinician experts.
IT or DSS: | DSS
Source of information: | Peer-reviewed article.^ 179 ^
Contact information: | Departament d'Informática Biomèdica Institut Municipal d' Investigació Mèdica Passeig Marítim 25-29 08003 Barcelona, Spain Fax: 343-485-49-52

Name: | Texas Infectious Disease Diagnostic DSS
Purpose: | To provide a weighted differential diagnosis based on manually entered patient information.
Description: | Users manually enter case-specific information, which is compared with a knowledge base containing 223 infectious and parasitic diseases with associated symptoms, treatment protocols, geographic associations, and occupational associations, among other features. The user sets a "closeness-of-fit" parameter that determines how tight the relationship between cases signs/findings and diseases must be before a disease can become a candidate for the differential diagnosis list. On average, it took 3 minutes to enter relevant patient information into the DSS.
Diagnostic accuracy: | Records of 342 cases of brucellosis were obtained from the Texas Department of Health. Ninety-eight patients had been diagnosed more than 11 days after presentation and were considered missed diagnoses. In 86 of the 98 patients defined as missed diagnoses, the DSS listed brucellosis in the top 5 diagnoses on the differential diagnosis list, and in 69 of these 98 patients, brucellosis was the only disease suggested. The DSS missed the diagnosis in 12 of 98 patients. The mean number of days to suspect the correct diagnosis without the DSS was 17.9 days and with the DSS was 4.5 days (an improvement of 12.9 days; p=0.0001).
IT or DSS: | DSS
Source of information: | Peer-reviewed article.^ 173 ^
Contact information: | Texas A&M University

## Evidence Table 3. Management and Prevention Systems

We present the following information on each of the systems described in the Management and Prevention Section of Chapter 3: its name, purpose, a description, and any information from evaluations of the system. We present systems in the same order as Table 13: first, systems that provide antibiotic recommendations; next, systems that provide intensive care management recommendations; then, systems that provide pneumonia management recommendations; and, finally, other management DSSs.

### Antibiotic recommendation programs

Name: | ABIX
Purpose: | To advise doctors with suggested management plans for various infectious diseases.
Description: | ABIX is an antibiotic information database designed to help non-specialist physicians treat patients with infectious diseases. The system runs on a PC that communicates with a server either remotely via modem or locally via a network connection. As of 2000, the database contained 136 different drugs, listed by generic name. However, the database is continually updated. Dosage, drug administration, and risk information is provided along with the recommended antibiotics.
Evaluation data: | A survey of 50 doctors from a pilot evaluation of ABIX reported that the system is easy to understand and use. In addition, 85% indicated that the information included and the system's classifications were satisfactory.^ 217 ^
IT or DSS: | DSS
Source of information: | Peer-reviewed article.^ 217 ^
Contact information: | Institute of Social and Preventive Medicine, Athens Department of Hygiene and Epidemiology, Medical School, University of Athens Evagelismos Hospital, Athens

Name: | Antibiotic Assistant™
Purpose: | To provide physicians with patient- and disease-specific decision support on antibiotic treatments.
Description: | An easy-to-use system, Antibiotic Assistant™ uses an inference engine and syndrome-specific evidence-based knowledge bases to help physicians determine the appropriate dose, duration, and choice of antibiotics. Only a limited number of syndromal knowledge bases are currently integrated into Antibiotic Assistant™, including one on meningitis. TheraDoc plans to release 2 to 3 new modules each year.
Evaluation data: | Not available.
IT or DSS: | DSS
Source of information: | No peer-reviewed information. Other Web site.^ 218 ^
Contact information: | TheraDoc 127 South 500 East, Suite 600 Salt Lake City, UT 84102 Ph: 801-415-4400; Fax: 801-415-4444 http://www.theradoc.com/

Name: | Pneumonia Therapy Advisor (PTA)
Purpose: | To advise ICU physicians on the diagnosis and initial treatment of ventilator-associated pneumonia.
Description: | This expert system is designed to support clinicians in prescribing empirical therapy to mechanically ventilated patients with pneumonia in the ICU. Using the C2000-Eclipsys commercial clinical information system as its foundation, it uses both decision analytic and Bayesian models. Diagnostic recommendations are made based on variables such as the patient's symptoms and signs, duration of hospitalization and ventilation, and relevant laboratory data. Cost, side effects, and expected efficacy are taken into consideration for therapy recommendations. A total of 32 different therapy regimes are offered.
Evaluation data: | A comparison of PTA's treatment recommendations for 12 ICU patients with those of an infectious disease specialist demonstrated that 100% (12 out of 12) of the model's choices were considered "acceptable" or "second-best choice." However, in 66% (8 out of 12) of the cases, PTA recommended a therapy that covered more pathogens than the expert-recommended therapy, due to the model's lack of knowledge regarding the broadness of the antimicrobial spectrum.^ 220 ^ Preliminary evaluations suggest that this issue may be partially alleviated with the addition of a function that only includes pathogens with a posterior marginal probability of 31% or greater, as well as a utility function that discourages the prescription of broad-spectrum antibiotics.^ 219 ^
IT or DSS: | DSS
Source of information: | Peer-reviewed articles.^219, 220^
Contact information: | Department of Computer Science, Utrecht University, The Netherlands Department of Internal Medicine, University Medical Centre Utrecht, The Netherlands

Name: | QID
Purpose: | To provide physicians with patient- and disease-specific decision support on antibiotic treatments. Uses an inference engine and syndrome-specific evidence-based knowledge bases.
Description: | The QID program runs on Iliad's inference engine and is able to calculate a differential diagnosis from an infectious disease knowledge base before culture results are available. Once it has determined the differential diagnosis, QID then calculates the maximum "Good days of life saved" (GDS) for each of the most likely disease/organisms assuming optimal antibiotic coverage. QID uses local ravelersid epidemiology from the last 15 months to determine the effectiveness of each antibiotic for each of the most likely disease/organisms. The basic QID algorithm formula is: Antibiotic GDS = Sum across most likely diseases/organisms x Optimal GDS score x Antibiotic Susceptibility. The algorithm generates a list of antibiotics ordered by GDS and displayed along with the toxicity and cost per 24 hours of treatment for each drug.
Evaluation data: | To test whether physicians' would make more appropriate antibiotic choices with the aid of QID, University of Utah physicians were asked to evaluate 4 infectious disease cases abstracted from existing medical records of infectious disease cases. Immediately after their initial review and selection of antibiotic therapy for each case, participants were presented with QID's antibiotic recommendations for the same case to determine if this information would change the physician's initial drug choice. QID had a greater impact on the most difficult cases but statistically improved scores overall by a mean increase of 6.8% correct (p < 0.001).
IT or DSS: | DSS
Source of information: | Peer-reviewed article.^ 221 ^
Contact information: | Sunquest Information Systems, Inc. Salt Lake City, UT

Name: | Rabin Medical Center Antibiotic DSS
Purpose: | To assist in the selection of empiric antibiotics in suspected moderate to severe bacterial infections.
Description: | This DSS combines site-specific information regarding pathogen prevalence and susceptibility to antibiotics, with prediction models derived from large pools of data and validated in other sites. It is targeted at cases involving inappropriate empirical antibiotic treatment, notably ones in which there is a high risk for infections caused by 7 pathogens (S. aureus, coagulase-negative staphylococci, Pseudomonas aeruginosa, Acinetobacter sp., enterococci, anaerobes and Candida sp.) Patient-specific data used by the DSS include demographic information, underlying disorders, presentation of the infectious episode, and laboratory test results.
Evaluation data: | A study comparing the recommendations of the system with those of a physician for 219 patients with positive cultures or serological tests demonstrated that the system recommended treatment to which the pathogen was shown to be susceptible in 77% of patients, compared with 58% for physicians. The DSS made inappropriate drug recommendations for 23% of the patients (compared with 42% for the physicians) and recommendations for antibiotics that were either unneeded or too broad-spectrum in 11% of the patients (compared to 15% for the physicians). Use of the system would have reduced the rate of inappropriate treatments in patients with a known pathogen by 19%.^ 222 ^
IT or DSS: | DSS
Source of information: | Peer-reviewed article.^ 222 ^
Contact information: | Rabin Medical Centre, Israel Tel-Aviv University, Israel

### Intensive Care Management Systems

Name: | Eindhoven Automated Knowledge Acquisition Tool
Purpose: | To provide decision support to health care workers in clinical care and emergency care environments.
Description: | The developers designed and implemented a knowledge acquisition tool for the ICU consisting of: 1) a graphical knowledge acquisition tool, 2) tools that perform logical and semantic tests on proposed guidelines, 3) an electronic medical record of patient information, 4) an expert system that reminds ICU health care workers of inconsistencies between a treatment plan and implemented guidelines. Physicians enter the guidelines using the knowledge acquisition tool. The guidelines are checked for accuracy and exported to the reminder system used in daily practice.
Evaluation data: | ICU physicians used the knowledge acquisition tool to enter 58 guidelines into the reminder system's knowledge base. These guidelines were tested on a database of 803 previously admitted patients. During this test, 27 of the 58 guidelines generated at least 1 reminder; a total of 406 reminders were generated. Of the 406 reminders, 356 (88%) were issued correctly and 50 (12%) were considered false alarms.^ 223 ^ The false alarms were attributed to lack of specificity in the underlying guideline. This realization led to improvements in the guidelines.
IT or DSS: | DSS
Source of information: | Peer reviewed article.^ 223 ^
Contact information: | Eindhoven University of Technology, Room EH 3.08 P.O. Box 513 5600 MB Eindhoven The Netherlands

Name: | ICONS
Purpose: | To provide rapid antibiotic recommendations for ICU patients with hospital-acquired infections.
Description: | ICONS is a case-based reasoning system that provides therapy advice to physicians before microbiological data are available. It uses the patient's medical background and known resistances to determine a spectrum of possible agents. The system retrieves the case histories of former patients with a similar presentation to the current patient. These similar former cases and prototypes are retrieved from the system's hierarchically generalized storage base, and the effective treatment strategies from these cases are adapted to the current patient's medical situation. Additional medical knowledge is represented with a context-sensitive background knowledge base, which can be easily revised through a programmed knowledge acquisition tool. For each of the therapy options presented, information on side effects and costs may be obtained; dosage is provided once a particular therapeutic agent is prescribed. ICONS was developed using a Macintosh computer and requires operating system 7.0 or higher, 4 Mb RAM and hard disk occupation of less than 10 Mb. According to available literature, it cannot yet be transferred to other operating systems.
Evaluation data: | Not available.
IT or DSS: | DSS
Source of information: | Peer-reviewed articles.^224, 225^
Contact information: | Computer Centre of the Medical Facility, Ludwig-Maximilians University of Munich Institute of Anaesthesiology, Ludwig-Maximilians University of Munich, Germany

Name: | Intelligent Decision Aid System (IDEAS) for ICU and IDEAS for NICU
Purpose: | To make treatment recommendations for new patients admitted to the ICU/NICU based on similarity to former ICU/NICU patients.
Description: | For each new patient admitted to the ICU or NICU, this system provides a list of the 10 closest matching patients from a database of thousands of adult or neonatal intensive care patients. Each entry in the database contains 98 fields of clinical and administrative information, with up to 7 medical diagnoses and multiple lines for procedural information. Certain fields are weighted more heavily in the matching process. The expert-system reasoning shells used by the developers of this system include ART-IM, Version 2.5 (Inference Corporation, El Segundo, CA) and The Easy Reasoner™ (The Haley Enterprise, Sewickley, PA).
Evaluation data: | After a 3-week study involving a prototype version of IDEAS for ICUs and 27 patients, 5 evaluation forms submitted by physicians indicated that the system would be beneficial to clinicians, while 22 said that no benefit was currently foreseeable. Comments regarding improvements were incorporated into a newer version of the system. In a separate preliminary study, IDEAS for NICUs was rated highly in terms of usability by 5 neonatologists but not considered very clinically useful in its current form.
IT or DSS: | DSS
Source of information: | Peer-reviewed article.^ 226 ^
Contact information: | School of Information Technology and Engineering, University of Ottawa, Canada Department of Systems and Computer Engineering, Carleton University, Canada Division of Neonatology, 401 Smyth Rd, Ottawa, ON, Canada

### Pneumonia Management System

Name: | Severity Scores for Community-acquired Pneumonia
Purpose: | To classify patients using a published prediction rule by calculating a severity score based on laboratory, radiographic, and historical data (from electronic medical records) to make severity-based management recommendations for patients with community-acquired pneumonia.
Description: | This system automatically determines a severity score for patients with community-acquired pneumonia using a published prediction rule for the prognosis of community-acquired pneumonia. It uses the MedLEE medical language processor for extraction and encoding of electronic medical records. Severity score calculation is based on a total of 18 variables, including laboratory, radiographic and historical data collected from electronic discharge summaries. The rule assigns patients to 1 of 5 risk categories and makes treatment recommendations based on risk class.
Evaluation data: | In comparison with a reference standard obtained manually by an independent expert for 79 patients with community-acquired pneumonia cases, the system achieved an accuracy of 93%, a sensitivity of 92%, and a specificity of 93% for processing discharge summaries. For chest x-rays, it demonstrated an accuracy of 96%, a sensitivity of 87%, and a specificity of 98%. It was 80% accurate in assigning the exact risk class, with the remaining 20% differing by only 1 class, and 85% accurate with vital sign values.^ 216 ^
IT or DSS: | DSS
Source of information: | Peer-reviewed article.^ 216 ^
Contact information: | Department of Computer Science Queens College CUNY

### Other Management DSSs

Name: | ABDX
Purpose: | To aid the Naval Independent Duty Corpsman in the diagnosis and treatment of patients with acute abdominal pain aboard Navy ships.
Description: | ABDX is designed to help health care personnel at sea make appropriate decisions regarding patients with abdominal pain. It was originally designed for use with the Tektronix 4051 machine, but was modified to run on an IBM PC or compatible computer. Gynecological data was incorporated into the program in FY89, thereby leading to ABDX Version 3.0.
Evaluation data: | None available.
IT or DSS: | DSS
Source of information: | No peer-reviewed information. Other.^ 227 ^
Contact information: | Naval Submarine Medical Research Laboratory

Name: | Columbia-Presbyterian Clinical Event Monitor
Purpose: | To monitor a patient database in order to generate alerts, interpretations, and screening messages for clinicians throughout the Columbia-Presbyterian Medical Center.
Description: | This automated DSS, which has been in clinical use since March 1992, is triggered by clinical events throughout the medical center by reading a centralized patient database of administrative data, laboratory results, radiology findings (via natural language processing - See Section 3.4.3 for additional information on this feature), medication orders, and text reports from most ancillary departments. Based on the events and data, the system generates emergent alerts (about 50 per day), informational interpretations (about 2000 per day), and screening messages for clinical research, quality assurance, and administration (e.g., billing rules). The system runs for all the medical center's patients, and all clinicians have access to the generated messages. There are about 100 rules at present, which concentrate on laboratory alerts, lab-drug interactions, health maintenance protocols, tuberculosis follow-up, administrative rules, and screening messages for research and quality assurance.
Diagnostic accuracy: | Formal studies are in progress. No information is currently available.
IT or DSS: | DSS
Source of information: | Peer-reviewed article.^ 157 ^
Contact information: | Department of Medical Informatics Columbia-Presbyterian Medical Center 161 Fort Washington Avenue, AP-1310 New York, NY 10032

Name: | Déjà Vu
Purpose: | The automatic recognition and monitoring of time-dependent medical scenarios.
Description: | The Déjà Vu system is a conceptual model for representing physiological processes. It uses temporal reasoning to model medical scenarios such as the management of mechanical ventilation and pulmonary edema. The system takes information from a number of sources (e.g. sensor, laboratory, and clinical staff data) to generate recognition of the patient's clinical scenario. On the basis of the scenario, an action plan is generated. The system is iterative and changes with incoming data.
Evaluation data: | None available.
IT or DSS: | DSS
Source of information: | Peer-reviewed article.^ 228 ^
Contact information: | Institut National de la Santé et de la Recherche Médicale, France Université de Technologie de Compiégne, France

Name: | Emergency Medical Alert Network (EMAN)
Purpose: | To provide early detection of adverse health events and dissemination of health information regarding disease treatment and personal protection.
Description: | EMAN is a Web-based program developed by San Diego County, California to aid in surveillance and detection of adverse health events and to disseminate appropriate health information to public health and safety agencies. The system was developed using the CDC's HAN architectural standards; however, state and local resources funded it. Participants in the San Diego County EMAN include: directors of hospital emergency departments, directors of clinical microbiology laboratories, physicians specializing in infectious disease, the Medical Examiner's Office, Emergency Medical Services (EMS) Office and 9-1-1 Center, San Diego County Department of Environmental Health Services, and the San Diego County Veterinarian's office. EMAN is also linked to the San Diego Quality Assurance Network, a live, real-time Wide-Area-Network hospital resource status indicator that provides information regarding emergency department and ICU saturation and hospital bed availability. Standard alerts are sent via e-mail; whereas, more urgent matters are sent via fax. Recent alerts will also be posted on the Web site. In a major emergency, the network would include more rapid communication methods such as mass paging (it is unclear whether or not this is currently under development).
Evaluation data: | None available.
IT or DSS: | DSS
Source of information: | Other Web site^ 229 ^ and other.^ 230 ^
Contact information: | Emergency Medical Alert Network (EMAN) County of San Diego, Health and Human Services Agency Community Epidemiology Division MS: P511C-A P.O. Box 85222 San Diego, CA 92186-5222 Ph: 619-515-6620; Urgent ph: 858-565-5255; Fax: 619-515-6644 E-mail: epidivhe@co.san-diego.ca.us

Name: | Health Evaluation through Logical Processing (HELP)
Purpose: | To monitor a patient database in order to generate alerts, interpretations, and screening messages for clinicians.
Description: | Please see text (Chapter 3, Management and Prevention Systems).
Evaluation data: | Please see text (Chapter 3, Management and Prevention Systems).
IT or DSS: | DSS
Source of information: | Peer-reviewed articles.^156, 158, 180-215^
Contact information: | LDS Hospital 8^th^ Avenue and C Street Salt Lake City, Utah 84143-0001 Ph: 801-408-1100

Name: | MEDTRAK
Purpose: | To track the location of patients in a hospital, assign patient treatment priorities, maintain the in-house patient medical database, communicate laboratory request/results, generate patient status reports, and set patient movement priorities such as the patient queue for X-rays or the OR.
Description: | The MEDTRAK system is a computerized patient-tracking prototype for a medical treatment facility that is designed to assemble and monitor casualty location data in order to support time-sensitive decisions critical to the success of appropriate medical treatment. The system integrates a network of handheld, touch screen personal computers placed in each of the patient treatment areas (e.g., triage, X-ray, wards). Each computer is equipped with internal wireless radios to maintain communication with the central computer located at the medical treatment facility. The central computer automatically monitors the network of remote PC stations. The central computer uses data continually supplied by the treatment area PCs to automatically maintain patient tracking functions, assign patient treatment priorities, maintain the patient medical record database, communicate laboratory reports/requests and automatically generate status reports (e.g. bed status, blood inventory, patient lists). In addition, each of the treatment station PCs incorporates an internal reader/writer device to electronically transfer patient data using a personnel carried smart card (e.g. Multi-technology Automated Reader Card). Once the information is entered into the remote PC, it is forwarded to the central computer where the patient is assigned a patient number and an electronic medical record is generated and available throughout the system.
Evaluation data: | MEDTRAK was tested in a side-by-side comparative evaluation with the current method of manual patient tracking during a simulated casualty event. Out of 181 sets of observations recorded, 37 total patient tracking errors were recorded by the manual system compared to 14 errors recorded by the MEDTRAK system. The evaluation demonstrated that MEDTRAK system admitted, identified, and tracked patients within a medical treatment facility significantly more accurately than the manual system currently in place. In comparison to the MEDTRAK system, tracking errors that occurred within the manual system were found to be more detrimental to effective operation of the medical facility as well as to the discharge of theater evacuation policy. In addition, the MEDTRAK system reduced the administrative burden that patient tracking placed on medical personnel, allowing them to perform more clinical duties.
IT or DSS: | DSS
Source of information: | Peer-reviewed article.^ 231 ^
Contact information: | Naval Health Research Center P.O. Box 85122 San Diego, CA 92186-5122

Name: | NexProfiler
Purpose: | To provide easily accessible disease- and patient-specific treatment information to patients and physicians.
Description: | NexProfiler is a system that compares individual patient information with a database of peer-reviewed scientific articles to produce a customized list of treatment options and outcomes. Patient data entered into the system includes diagnosis, medical history, and treatment preferences.
Evaluation data: | None available.
IT or DSS: | DSS
Source of information: | No peer-reviewed information. Other Web site.^ 232 ^
Contact information: | NexCura, Inc. 1725 Westlake Avenue North, Suite 300 Seattle, WA 98109 Ph: 877-422-3228; Fax: 206-270-0229 http://www.nexcura.com

Name: | Testing COMpetency (TECOM)
Purpose: | To teach medical decision making to medical students.
Description: | TECOM teaches and evaluates students on management decision-making, on tasks such as choosing appropriate antibiotic therapies, through medical cases stored on a computer. Cases include real patient data and optimal treatment plans validated by a hospital antibiotic center. The program was created in Turbo Pascal and contains 3 parts: an editor, in which new student problems and data regarding patients and features can be entered; a program guide; and the program for student use. Students are evaluated based on the error rate, e.g. the proportion of predictions in which an error is made.
Evaluation data: | None available.
IT or DSS: | IT
Source of information: | Peer-reviewed article.^ 233 ^
Contact information: | Faculty Hospital II, Antibiotic Center, Czechoslovakia Charles University, Prague, Czechoslovakia

Name: | Utrecht Emergency Hospital Patient Barcode Registration (PBR) System
Purpose: | To track medical, nursing and logistic information for patients admitted to the Utrecht Emergency Hospital during mass casualty incidents.
Description: | The PBR System is designed to supply continuously updated group and patient data using bar-coded identifiers to represent patients, injuries, facilities, and locations, with the goal of minimizing errors and facilitating the exchange of data. The system communicates through an already existing hospital information system and requires minimal training. A bar-code system was chosen because of the proven reliability of bar-codes, their cost effectiveness, and the use of similar technology in the hospital. Medical charts, wristbands and stickers were prepared with unique bar-coded patient numbers. Injury codes were based on the WHO ICD-9-CM diagnostic codes and treatment stations, nursing ward locations and routing received alphanumeric bar-coded labels. The computer hardware consists of 20 stations using IBM-compatible computers with hand-held bar-code readers that are connected to a server, facilitating the collection and dissemination of information throughout the hospital in real-time. When a patient arrives in the ambulance receiving area s/he receives an activated bar-coded patient number, which is linked to data entered regarding EMS triage indications, any treatment initiated, patient's clinical triage class and destination(s). As the patient passes through the hospital, additional treatment bar-code entries are indexed to the patient number, location, and time entered. All of the information is incorporated into the hospital information system in real-time, becoming part of the patient's medical record.
Evaluation data: | For 4 experimental exercises performed between 1993 and 1994, each of which involved 30 patients, both the amount and accuracy of data recorded increased with the PBR system (p<.05 and p<.01, respectively), as compared to medical charts completed by an experienced administrative assistant. Specifically, inaccuracy decreased by 25% as compared to handwritten medical charts.^ 235 ^ During 12 mass casualty admissions at the Utrecht Emergency Hospital, personal data for the patients were entered into the system within 30 minutes of admission for 58.1% (161 out of 277) of the cases and 60 minutes for 80.5% (223 out of 277) of the cases.^ 234 ^
IT or DSS: | IT
Source of information: | Peer-reviewed articles.^234, 235^
Contact information: | Utrecht Emergency Hospital Utrecht, The Netherlands

## Evidence Table 4. Quality Evaluation of Peer-reviewed Articles for Systems for Detection, Diagnosis, Management or Communication

This table presents a quality evaluation for each of the peer-reviewed articles describing an IT/DSS. If the article did not specifically discuss a given quality criterion, if it was not applicable to the material presented in that article, or if we were unsure about whether or not the article met the criterion, we denoted this with a " -- ". We did not attempt to independently evaluate any system; instead, we relied exclusively on the authors' descriptions.

### Table legend

Quality criterion | Symbol | Description
Method of allocation to study groups | [image] [image] [image] | Random Selected concurrent controls None of the above
Unit of allocation | C D P | Clinic Physician Patients
Baseline differences between groups that were potentially linked to the study outcome | [image] [image] | There were no baseline differences between study groups or the authors performed appropriate statistical adjustments There were baseline differences present but no statistical adjustments were made
Type of outcome measures (If a study reported more than 1 outcome, we gave the highest rating possible (e.g., if there was 1 objective measure and several subjective measures, we classified that study as having an objective measure)) | [image] [image] [image] [image] | Objective outcome measure Subjective outcome measure with blinded assessment Subjective outcome measure that had explicit criteria Subjective outcome measure without explicit criteria
Completeness of followup (exact numbers and percentages are also given if available) | [image] [image] [image] | Greater than 90% 80-90% Less than 80%

Evidence Table 4. Quality evaluation of peer-reviewed articles for systems for detection, diagnosis, management or communication

Reference | System name | Purpose of study | Method of allocation | Unit of allocation | Baseline differences | Type of outcome measures | Completeness of followup
Anderson^ 478 ^ | Medcast | To describe the implementation of Medcast, a service for clinicians that delivers medical information on topics of interest to the clinician, and to evaluate the acceptance and the benefits of the system for users. | [image] Complete sample of all users of the system | -- | -- | [image] | [image] 73/195=39%
Arene^ 141 ^ | Quick Medical Reference (QMR) | To determine if QMR could help improve internal medicine residents' diagnostic capabilities or enhance their learning experience. | -- | -- | -- | [image] | --
Aronsky^ 181 ^ | Health Evaluation through Logical Processing (HELP) | To present the development and evaluation of a Bayesian network for the diagnosis of community-acquired pneumonia in the emergency room. | -- | -- | -- | [image] | --
Aronsky^ 184 ^ | Health Evaluation through Logical Processing (HELP) | To assess the ability of an integrated real-time diagnostic system (Bayesian Network) to identify patients with community-acquired pneumonia who are eligible for a computerized pneumonia guideline without requiring clinicians to enter additional data. | -- | -- | -- | [image] | --
Ashizawa^ 155 ^ | University of Chicago - Computer Aided Diagnosis of Interstitial Lung Disease | To evaluate the effect of the output from an artificial neural network on radiologists' diagnostic accuracy. | -- | -- | -- | [image] | --
Baille^ 88 ^ | Biolog | To evaluate the use of the Biolog microbiologic identification system for the diagnosis of B. anthracis. | -- | -- | -- | -- | --
Berger^ 168 ^ | Computer program for diagnosing and teaching geographic medicine | To evaluate the diagnostic accuracy of a system to help with the diagnoses of infectious diseases. | -- | -- | -- | [image] | [image] 100%
Berner^ 126 ^ | DXplain™, Iliad, Quick Medical Reference (QMR) | To evaluate the ability of various computer programs to suggest appropriate diagnoses. | -- | -- | -- | [image] | --
Berner^ 145 ^ | Quick Medical Reference (QMR) | To examine whether case difficulty, DSS information quality, and physician characteristics relate to the physicians' perception of the usefulness of the system. | -- | -- | -- | [image] | --
Berner^ 144 ^ | Quick Medical Reference (QMR) | To explore how QMR influences physicians' performance, how physicians use the system, and how they react to the information provided. | -- | -- | -- | [image] | [image] 108/190 = 57%
Bouman^ 234 ^ | Utrecht Emergency Hospital Patient Barcode Registration System | To test a patient barcode system for patient registration and tracking during real and experimental mass casualty incidents at an emergency hospital. | [image] No controls. | -- | -- | [image] | --
Carter^ 173 ^ | Texas Infectious Disease Diagnostic DSS | To describe the development and laboratory testing of a medical DSS. | -- | -- | -- | [image] | --
Chapman^ 159 ^ | SymText (part of HELP) | To compare performance of 4 computerized methods in identifying chest X-ray reports that support the diagnosis of acute bacterial pneumonia. | -- | -- | [image] | [image] | --
Cundell^ 171 ^ | Fuzzy logic program to predict source of bacterial infection | To develop and evaluate a fuzzy logic program that predicts class of bacterial organism responsible for infection based on age, blood type, gender, and race. | -- | -- | -- | [image] | --
De Bruijn^ 220 ^ | Pneumonia Therapy Advisor (PTA) | To describe and evaluate a system that provides antibiotic advice for ICU patients. | -- | -- | -- | [image] | [image] 100%
Dojat^ 228 ^ | Déjà Vu | To develop and apply a system using temporal reasoning to model medical scenarios such as pulmonary edema. | -- | -- | -- | [image] | --
El-Solh^ 175 ^ | Neural Network for Diagnosing Tuberculosis | To compare diagnostic performance of an artificial neural network with that of physicians in predicting patients with active pulmonary tuberculosis. | -- | -- | [image] | [image] | --
Evans^ 194 ^ | Health Evaluation through Logical Processing (HELP) | To evaluate an automated antibiotic consultant, which assists physicians in selection of empiric antibiotics. | [image] | D Randomization of MDs to never, previous, and current use of system | -- | [image] | [image] 100%
Evans^ 196 ^ | Health Evaluation through Logical Processing (HELP) | To determine the effect of anti-infective clinical decision support tools on the quality of patient care. | [image] Pre-post | -- | [image] | [image] | [image] 100%
Fiszman^ 156 ^ | SymText (part of HELP) | To test whether SymText is able to identify acute bacterial pneumonia related concepts in chest X-ray reports. | -- | -- | [image] | [image] | --
Fiszman^ 158 ^ | SymText (part of HELP) | To assess the ability of a medical language processing system to encode information from chest x-ray reports. | -- | -- | [image] | -- | --
Friedman^ 216 ^ | Severity Scores for Community-acquired Pneumonia | To compare the accuracy of assessment of community-acquired pneumonia severity scores by an automated system employing medical language processing with assessment by an expert. | -- | -- | [image] | [image] | [image] 100%
Frize^ 226 ^ | Intelligent Decision Aid System (IDEAS) for Intensive Care Units (ICU) | To describe the development and evaluation of several versions of a case-based reasoning system for ICU patients that provides a list of the 10 closest matching patients from a database of ICU or NICU patients. | -- | -- | -- | [image] | [image] 23/27 = 85%
Galarneau^ 231 ^ | MEDTRAK | To evaluate if a computerized patient tracking system performed better than the traditional, manual method of tracking patients as they move through a forward military medical facility. | [image] | -- | -- | [image] | [image] 100%
Greenes^ 467 ^ | Automated Late-Arriving Results Monitoring (ALARMS) | To describe the rationale for and performance of a newly developed alert system (ALARMS) for improving followup for late arriving lab data in ER patients. | -- | -- | -- | [image] | --
Holmberg^ 59 ^ | Digital Smell/Electronic Nose | To determine the sensitivity and specificity of some features available from an array of gas sensors in classifying microorganisms in order to differentiate between bacterial species. | -- | -- | -- | [image] | --
Knirsch^ 174 ^ | Clinical DSS for detection and respiratory isolation of tuberculosis (TB) patients | To develop and evaluate an automated clinical DSS for detecting and isolating patients with a positive culture for TB, chest x-ray suspicious for TB, or, if immuno-compromised, with abnormal chest x-ray. | -- | -- | -- | [image] | --
Kuperman^ 468 ^ | Brigham Integrated Computer System (BICS) | To evaluate an automated alerting system for abnormal laboratory values. | [image] No controls | D | -- | [image] | --
Kuperman^ 469 ^ | Brigham Integrated Computer System (BICS) | To evaluate the effect of an automatic alerting system on the time until treatment is ordered for patients with critical lab results. | [image] | -- | [image] | [image] | [image] 100%
Lagor^ 180 ^ | Health Evaluation through Logical Processing (HELP) | To compare a Bayesian network and artificial neural network in the diagnosis of community-acquired pneumonia. | -- | -- | -- | -- | --
Leibovici^ 222 ^ | Rabin Medical Center Antibiotic DSS | To present the design and effectiveness of a DSS for the prescription of empiric antibiotics in cases of suspected infection. | [image] | -- | [image] | [image] | [image] 100%
Lemaire^ 129 ^ | Quick Medical Reference (QMR) | To evaluate the effectiveness of QMR as a clinical diagnostic tool. | -- | -- | -- | [image] | --
Lucas^ 219 ^ | Pneumonia Therapy Advisor (PTA) | To describe the design of a decision-theoretic model aimed at supporting clinicians in prescribing antibiotic therapy to mechanically ventilated patients with pneumonia at the ICU. | -- | -- | -- | [image] | --
Modai^ 471 ^ | Computerized Lab Alert System (CLAS) | To examine the contribution of a computerized alerting system to patient care. | -- | -- | -- | [image] | [image] 100%
Monnier-Cholley^ 153 ^ | University of Chicago - Computer Aided Diagnosis of Interstitial Lung Disease | To assess the impact of a computer-aided diagnostic aid for the detection of interstitial opacities on chest x-rays by analyzing ROC curves. | -- | -- | [image] | -- | [image] 100%
Noorder-graaf^ 235 ^ | Utrecht Emergency Hospital Patient Barcode Registration System | To evaluate the use of a patient barcode registration system during real and experimental incidents. | -- | -- | -- | [image] | --
Pestotnik^ 203 ^ | Health Evaluation through Logical Processing (HELP) | To describe clinical and financial outcomes of computer-assisted decision support for antibiotic usage. | -- | -- | -- | -- | --
Ross^ 169 ^ | Global Infectious Disease and Epidemiology Network (GIDEON) | To evaluate the use of GIDEON for the diagnosis of infectious fever. | -- | -- | -- | [image] | --
Rowe^ 89 ^ | Fluorescence-based Array Immunosensor | To describe and evaluate an array immunosensor for rapid, quantitative simultaneous detection of multiple analytes such as S. enterotoxin B, plague F1 antigen, and D-dimer. | -- | -- | -- | [image] | --
Smith^ 178 ^ | DERMIS | To determine the effect of accuracy of the clinical description on system performance. | -- | -- | -- | [image] | [image] 20/24 = 83%
Smith^ 178 ^ | DERMIS | To design and test the diagnostic accuracy of a dermatologic diagnostic tool for primary care and to compare terms used by primary care doctors and dermatologists in describing skin lesions. | [image] Convenience | -- | -- | -- | [image] 20/24 = 83%
Tountas^ 217 ^ | ABIX | To describe and pilot trial results of an antibiotic information database. | -- | -- | -- | [image] | [image] 100%
Vassallo^ 164 ^ | Mobile Operational Support System (MOSS) | To describe and document the utility of a military telemedicine unit. | [image] Convenience | -- | -- | [image] | [image] 100%
Von Bredow^ 82 ^ | Luminometer and Sensitive Membrane Antigen Rapid Test (SMART™)/Antibody-based Lateral Flow Economical Recognition Ticket (ALERT) | To describe the threat of agroterrorism and methods to detect animal feed bacterial contamination. | -- | -- | -- | [image] | --
Walters^ 161 ^ | Walter Reed Army Medical Center (WRAMC) Telemedicine Service | To evaluate the experience of the Army in conducting telemedicine consultation. | [image] Convenience | -- | -- | [image] | [image] 100%
Warner^ 470 ^ | Clinical Event Manager (CEM) | To evaluate a system that pages or e-mails critical patient information to clinicians and to compare this system with other methods of receiving data. | [image] Convenience | -- | -- | [image] | [image] 63/99=63.6%
Warner^ 221 ^ | QID | To evaluate whether physicians would make better empiric antibiotic choices using the DSS. | [image] | -- | -- | [image] | [image] 100%
Willard^ 472 ^ | Minnesota Microbiology Information System | To evaluate the performance of a novel computerized system for reporting clinical microbiology results. | [image] Crossover | D MDs/pharma-cists/nursesHalf started with old system, other half with new. | [image] | [image] | [image] 100%
Woodall^ 441 ^ | Program for Monitoring Emerging Infectious Diseases (ProMED) | To evaluate the timeliness and accuracy of an early outbreak reporting system as compared to other major reporting systems. | -- | -- | -- | [image] | --

## Evidence Table 5. Quality Evaluation of Reports of Surveillance Systems

If the reference specifically described the characteristic, it is denoted with a darkened circle. If no mention of the characteristic could be found in the article, it is denoted with an open circle. We did not attempt to independently evaluate any system; instead, we relied exclusively on the authors' descriptions.

Reference | System name | Importance | Usefulness | Simplicity | Flexibility | Acceptability | Sensitivity | Representativeness | Timeliness
[No author]^ 366 ^ | Foodborne Diseases Active Surveillance Network (FoodNet) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
[No author]^ 367 ^ | Foodborne Diseases Active Surveillance Network (FoodNet) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Bernard^ 413 ^ | Peace Corps Surveillance | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Birkhead^ 264 ^ | National Electronic Telecommunications System for Surveillance (NETSS) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Bouam^ 353 ^ | Henri Mondor University Hospital Clinical Information System | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Brossette^ 213 ^ | University of Alabama Data Mining Surveillance System (DMSS) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Brossette^ 214 ^ | University of Alabama Data Mining Surveillance System (DMSS) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Burken^ 351 ^ | Decentralized hospital computer program (DHCP) of the VA Hospitals | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Carrat^ 262 ^ | French Communicable Diseases Computer Network (FCDN) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Chauvin^ 280 ^ | French Communicable Diseases Computer Network (FCDN) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Corwin^ 246 ^ | Early Warning Outbreak Recognition System (EWORS) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Costagliola^ 261 ^ | French Communicable Diseases Computer Network (FCDN) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
de Neeling^ 320 ^ | Netherlands National Institute of Public Health and the Environment Surveillance System | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Evans^ 186 ^ | LDS Data Mining Surveillance System (DMSS) (part of HELP) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Evans^ 190 ^ | Health Evaluation through Logical Processing (HELP) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Evans^ 191 ^ | LDS Data Mining Surveillance System (DMSS) (part of HELP) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Flahault^ 277 ^ | French Communicable Diseases Computer Network (FCDN) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Flahault^ 301 ^ | WHO Influenza Surveillance (also known as FluNet) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Fleming^ 296 ^ | European Influenza Surveillance Scheme (EISS) (formerly CareTelematics) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Gardner^ 208 ^ | Health Evaluation through Logical Processing (HELP) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Garnerin^ 276 ^ | French Communicable Diseases Computer Network (FCDN) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Garnerin^ 278 ^ | French Communicable Diseases Computer Network (FCDN) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Gilchrist^ 302 ^ | Laboratory Response Network | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Heininger^ 350 ^ | Computer-Assisted Infection (CAI) Monitoring Program | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Hung^ 403 ^ | Medical Historian | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Hutwagner ^ 307 ^ | Public Health Laboratory Information System (PHLIS) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Joch^ 354 ^ | Knowledge-based Information Network Giessen (WING) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Johnson^ 287 ^ | AAH Meditel United Kingdom General Practitioner Reporting | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Kahn^ 340 ^ | GermWatcher | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Kahn^ 341 ^ | GermWatcher | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Madsen^ 344 ^ | Danish National Hospital Discharge Registry | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Martin^ 321 ^ | Public Health Laboratory Information System (PHLIS) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
McLaws^ 346 ^ | Hospital Infection Standardized Surveillance (HISS) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
O'Brien^ 337 ^ | WHONET | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Osaka^ 414 ^ | Traveler's Diarrhea Network (TDN) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Parsons^ 279 ^ | French Communicable Diseases Computer Network (FCDN) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Powell^ 383 ^ | New York State Department of Health's Bureau of Community Sanitation and Food Protection (BCSFP) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Quenel^ 289 ^ | Regional Influenza Surveillance Group (GROG) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Ramphal^ 332 ^ | SENTRY | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Rasley^ 359 ^ | University of Iowa Hospitals and Clinics (UIHC) Program of Hospital Epidemiology (PHE) Surveillance System | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Rundio^ 348 ^ | BOSS™ Computerized Surveillance System | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Rypka^ 314 ^ | Detection Algorithm using Syndromal Classification | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Sahm^ 308 ^ | The Surveillance Network™ (TSN™) Database-USA | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Sahm^ 335 ^ | The Surveillance Network™ (TSN™) Database-USA | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Samore^ 349 ^ | Clinical Data Repository (CDR) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Sanson^ 396 ^ | EpiMAN-FMD | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Schifman^ 345 ^ | Tucson VA Nosocomial Infection Surveillance System | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Smyth^ 352 ^ | Haemsept | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Smyth^ 357 ^ | The Royal Hospitals' Automated Infection Surveillance System | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Smyth^ 358 ^ | The Royal Hospitals' Automated Infection Surveillance System | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Snacken^ 295 ^ | European Influenza Surveillance Scheme (EISS) (formerly CareTelematics) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Snacken^ 297 ^ | European Influenza Surveillance Scheme (EISS) (formerly CareTelematics) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Sprenger^ 290 ^ | Dutch Medimatica Influenza System | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Stark^ 398 ^ Stern^ 306 ^ | EpiMAN-SF Salmonella Potential Outbreak Targeting System (SPOT), also known as the National Enteric Pathogens Surveillance Scheme (NEPSS) and formerly known as the National Salmonella Surveillance Scheme | [image] [image] | [image] [image] | [image] [image] | [image] [image] | [image] [image] | [image] [image] | [image] [image] | [image] [image]
Talan^ 271 ^ | EMERGEncy ID NET | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Talan^ 272 ^ | EMERGEncy ID NET | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Valleron^ 257 ^ | French Communicable Diseases Computer Network (FCDN) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
van Casteren^ 263 ^ | Eurosentinel | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Vatopoulos^ 336 ^ | WHONET | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Wallace^ 370 ^ | Foodborne Diseases Active Surveillance Network (FoodNet) | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]