# Bibliography

Allen B. Light ways to debug food. Pacific Northwest National Laboratory, 1997. Available at: http://www.pnl.gov/er_news/06_97/art1.htm. Accessed October 17, 2001.
Altmann M The deterministic limit of infectious disease models with dynamic partners Math Biosci 1998 150(2):153 75 9656648
Anderson JG, Casebeer LL, Kristofco RE. Medcast: evaluation of an intelligent pull technology to support the information needs of physicians. Proceedings of the AMIA Annual Symposium. 1999:466-70.
Section 5.2: control of other communicable diseases. World Health Organization, 2000. Available at: http://www.emro.who.int/Rd/AnnualReports/2000/chapter5-2.htm. Accessed November 4, 2001.
Anogianakis G, Maglavera S, Pomportsis A, et al Medical emergency aid through telematics: design, implementation guidelines and analysis of user requirements for the MERMAID project Int J Med Inf 1998 52(1-3):93 103
Anogianakis G, Maglavera S. Medical emergency aid through telematics (MERMAID). Stud Health Technol Inform. 1996;29:255-64. [pmid: 10163758].
Anogianakis G, Maglavera S MERMAID rescuses those in peril on the sea European Hospital Management Journal 1996 3(1).
Arene I, Ahmed W, Fox M, et al Evaluation of quick medical reference (QMR) as a teaching tool MD Comput 1998 15(5):323 6 9753979
Arnon SS, Schechter R, Inglesby TV, et al Botulinum toxin as a biological weapon: medical and public health management JAMA 2001 285(8):1059 70 11209178
Aronsky D, Haug PJ. An integrated decision support system for diagnosing and managing patients with community-acquired pneumonia. Proceedings of the AMIA Annual Symposium. 1999:197-201.
Aronsky D, Haug PJ Assessing the quality of clinical data in a computer-based record for calculating the pneumonia severity index J Am Med Inform Assoc 2000 7(1):55 65 61455 10641963
Aronsky D, Haug PJ. Automatic identification of patients eligible for a pneumonia guideline. Proceedings of the AMIA Annual Symposium. 2000:12-6.
Aronsky D, Haug PJ. Diagnosing community-acquired pneumonia with a Bayesian network. Proceedings of the AMIA Annual Symposium. 1998:632-6.
Ashizawa K, MacMahon H, Ishida T, et al Effect of an artificial neural network on radiologists' performance in the differential diagnosis of interstitial lung disease using chest radiographs AJR Am J Roentgenol 1999 172(5):1311 5 10227508
Bacchus CM, Quiston C, O'Rourke K, et al. A randomized crossover trial of QMR as a teaching tool for medical interns. J Gen Intern Med. 1994;9:616-21. [pmid: 7853070].
Baillie LW, Jones MN, Turnbull PC, et al Evaluation of the Biolog system for the identification of Bacillus anthracis Lett Appl Microbiol 1995 20(4):209 11 7766114
Baker EL, Friede A, Moulton AD, et al CDC's Information Network for Public Health Officials (INPHO): a framework for integrated public health information and practice Journal of Public Health Management & Practice 1995 1(1):43 7 10186591
Bankowitz RA, Blumenfeld BH, Giuse BN. User variability in abstracting and entering printed case histories with Quick Medical Reference (QMR). Proceedings of the Annual Symposium on Computer Applications in Medical Care. 1987:68-73.
Bankowitz RA, McNeil MA, Challinor SM, et al A computer-assisted medical diagnostic consultation service. Implementation and prospective evaluation of a prototype Ann Intern Med 1989 110(10):824 32 2653156
Bankowitz RA, McNeil MA, Challinor SM, et al Effect of a computer-assisted general medicine diagnostic consultation service on housestaff diagnostic strategy Methods Inf Med 1989 28(4):352 6 2695785
Bankowitz RA, Miller JK, Janosky J. A prospective analysis of inter-rater agreement between a physician and a physician's assistant in selecting QMR vocabulary terms. Proceedings of the Annual Symposium on Computer Applications in Medical Care. 1991:609-13.
Barnett GO, Cimino JJ, Hupp JA, et al DXplain. An evolving diagnostic decision-support system JAMA 1987 258(1):67 74 3295316
Barrera R, Grillet ME, Rangel Y, et al Temporal and spatial patterns of malaria reinfection in northeastern Venezuela Am J Trop Med Hyg 1999 61(5):784 90 10586913
Belgrader P, Benett W, Hadley D, et al PCR detection of bacteria in seven minutes Science 1999 284(5413):449 50 10232992
Berger SA, Blackman U Computer program for diagnosing and teaching geographic medicine J Travel Med 1995 2(3):199 203 9815388
Bernard KW, Graitcer PL, van der Vlugt T, et al Epidemiological surveillance in Peace Corps volunteers: a model for monitoring health in temporary residents of developing countries Int J Epidemiol 1989 18(1):220 6 2722368
Berner ES, Maisiak RS, Cobbs CG, et al Effects of a decision support system on physicians' diagnostic performance J Am Med Inform Assoc 1999 6(5):420 7 61384 10495101
Berner ES, Maisiak RS Influence of case and physician characteristics on perceptions of decision support systems J Am Med Inform Assoc 1999 6(5):428 34 61385 10495102
Berner ES, Webster GD, Shugerman AA, et al Performance of four computer-based diagnostic systems N Engl J Med 1994 330(25):1792 6 8190157
Recommendations of the Centers for Disease Control and Prevention Strategic Planning Workgroup Mor Mortal Wkly Rep 2000 49(RR-4):1 14
California State Senate Committee on Health and Human Services, 2001. Available at: http://www.sen.ca.gov/ftp/SEN/COMMITTEE/STANDING/HEALTH/_home/BIOTERRORISM_BACKGROUND.DOC. Accessed February 13, 2002.
Association for Professionals in Infection Control and Epidemiology Inc. and Centers for Disease Control and Prevention ED Manag 1999 11(11 suppl):1 16
Birkhead G, Chorba TL, Root S, et al Timeliness of national reporting of communicable diseases: the experience of the National Electronic Telecommunications System for Surveillance Am J Public Health 1991 81(10):1313 5 1928531 1405326
Blajan L, Chillaud T The OIE world animal disease information system Rev Sci Tech 1991 10(1):51 87 1760577
Bouam S, Girou E, Brun-Buisson C, et al Development of a Web-based clinical information system for surveillance of multiresistant organisms and nosocomial infections Proceedings of the AMIA Annual Symposium 1999 101(2):696 700
Bouhaddou O, Lambert JG, Miller S. Consumer health informatics: knowledge engineering and evaluation studies of medical HouseCall. Proceedings of the AMIA Annual Symposium. 1998:612-6.
Bouman JH, Schouwerwou RJ, Van der Eijk KJ, et al Computerization of patient tracking and tracing during mass casualty incidents Eur J Emerg Med 2000 7(3):211 6 11142274
Boussard E, Flahault A, Vibert JF, et al SentiWeb: French communicable disease surveillance on the World Wide Web BMJ 1996 313(7069):1381 2 discussion 1382-4 8956709
Brennan PF, Ripich S Use of a home-care computer network by persons with AIDS Int J Technol Assess Health Care 1994 10(2):258 72 8034405
Brooks GJ, Ashton RE, Pethybridge RJ DERMIS: a computer system for assisting primary-care physicians with dermatological diagnosis Brit J Dermatol 1992 127(6):614 9 1476920
Brossette SE, Sprague AP, Hardin JM, et al Association rules and data mining in hospital infection control and public health surveillance J Am Med Inform Assoc 1998 5(4):373 81 61314 9670134
Brossette SE, Sprague AP, Jones WT, et al A data mining system for infection control surveillance Methods Inf Med 2000 39(4-5):303 10 11191698
Brown MH, Davies KW, Billon CM, et al Quantitative microbiological risk assessment: principles applied to determining the comparative risk of salmonellosis from chicken products J Food Prot 1998 61(11):1446 53 9829183
Bruckner G. Monitoring and surveillance systems for animal diseases, taking as models the following diseases: myobacterial infections in animals, Newcastle disease, foot and mouth disease and rabies. In: Comprehensive reports on technical items presented to the International Committee or to Regional Commissions. Paris, France: Office International des Epizooties. 1995:45-53. [pmcid: 162482].
Burke JP, Classen DC, Pestotnik SL, et al The HELP system and its application to infection control J Hosp Infect 1991 18 Suppl A(6):424 31 1679811
Burke JP, Pestotnik SL Antibiotic use and microbial resistance in intensive care units: impact of computer-assisted decision support J Chemother 1999 11(6):530 5 10678796
Burken MI, Zaman AF, Smith FJ Semi-automated infection control surveillance in a Veterans' Administration Medical Center Infect Control Hosp Epidemiol 1990 11(8):410 2 2212582
Bush E, Gardner I. Animal health surveillance in the United States via the national animal health monitoring system (NAHMS). Epidemiol Sante anim. 1995;27:113-26.
Campbell J, Francesconi S, Boyd J, et al Environmental air sampling to detect biological warfare agents Mil Med 1999 164(8):541 2 10459261
Camus A. The Plague. 1991 ed. New York: Vintage International; 1948.
Canas LC, Lohman K, Pavlin JA, et al The Department of Defense laboratory-based global influenza surveillance system Mil Med 2000 165(7 Suppl 2):52 6 10920641
Carrat F, Flahault A, Boussard E, et al Surveillance of influenza-like illness in France. The example of the 1995/1996 epidemic J Epidemiol Community Health 1998 52 Suppl 1(4):32S 38S 9764269
Carter CN, Ronald NC, Steele JH, et al Knowledge-based patient screening for rare and emerging infectious/parasitic diseases: a case study of brucellosis and murine typhus Emerg Infect Dis 1997 3(1):73 6 9126449
Catlett C, Perl T, Jenckes M, et al. Training of clinicians for public health events relevant to bioterrorism preparedness. Washington, DC: Agency for Healthcare Research and Quality, 2002.
FoodNet surveillance report for 1999 (Final Report). Atlanta, GA: Foodborne Diseases Active Surveillance Network, Centers for Disease Control and Prevention's Emerging Infections Program; November, 2000.
Preliminary FoodNet data on the incidence of foodborne illnesses - selected sites, United States, 2000 MMWR Morb Mortal Wkly Rep 2001 50(13):241 246 11310569
Chadee DD, Kitron U Spatial and temporal patterns of imported malaria cases and local transmission in Trinidad Am J Trop Med Hyg 1999 61(4):513 7 10548282
Chandrasekaran B, Johnson T. Generic tasks and task structure: history, critique and new directions. In: David J, Krivine J, Simmons R, eds. Second-Generation Expert Systems. New York: Springer-Verlag; 1993. 232-72.
Chapman KA, Moulton AD The Georgia Information Network for Public Health Officials (INPHO): a demonstration of the CDC INPHO concept J Public Health Manag Pract 1995 1(2):39 43 10186607
Chapman WW, Haug PJ. Comparing expert systems for identifying chest x-ray reports that support pneumonia. Proceedings of the AMIA Annual Symposium. 1999:216-20.
Chauvin P, Valleron AJ Monitoring the compliance of sentinel general practitioners in public health surveillance: which GPs persevere? Int J Epidemiol 1997 26(1):166 72 9126517
Washington, D. C.: National Academy Press; 1999.
Cherkasskiy BL A national register of historic and contemporary anthrax foci J Appl Microbiol 1999 87(2):192 5 10475946
Chyba CF Biological terrorism and public health Survival 2001 43(1):93 106
Classen DC, Burke JP, Pestotnik SL, et al Surveillance for quality assessment: IV. Surveillance using a hospital information system Infect Control Hosp Epidemiol 1991 12(4):239 44 2061582
Clayton PD, Haug PJ, Shelton P, et al. Automated decision-making in radiology: advantages of an integrated system. Medinfo. 1986;5:624-8.
Cornell BA, Braach-Maksvytis VL, King LG, et al A biosensor that uses ion-channel switches Nature 1997 387(6633):580 3 9177344
Corwin A. Developing regional outbreak response capabilities: Early Warning Outbreak Recognition System (EWORS). Navy Med. 2000;Sept/Oct:1-5.
Costagliola D, Flahault A, Galinec D, et al A routine tool for detection and assessment of epidemics of influenza-like syndromes in France Am J Public Health 1991 81(1):97 9 1983924 1404927
Crook P, Fisher I. Developments in E. U.-wide surveillance of Salmonella and V.T.E.C. Eurosurveillance Weekly 2000(48).
Cundell DR, Silibovsky RS, Sanders R, et al Using fuzzy sets to analyze putative correlates between age, blood type, gender and/or race with bacterial infection Artif Intell Med 2001 21(1-3):235 9 11154891
Dale PE, Ritchie SA, Territo BM, et al An overview of remote sensing and GIS for surveillance of mosquito vector habitats and risk assessment J Vector Ecol 1998 23(1):54 61 9673930
ANSER, and Memorial Institute for the Prevention of Terrorism, 2001. Available at: http://www.hopkins-biodefense.org/participants.html. Accessed November 8, 2001.
Davis SR The state of antibiotic resistance surveillance: an overview of existing activities and new strategies Mil Med 2000 165(7 Suppl 2):35 9 10920636
De Bruijn N, Lucas P, Schurink K, et al A probabilistic approach to improved antibiotic therapy Stud Health Technol Inform 1999 68(7):690 5 10724980
De Clercq PA, Blom JA, Hasman A, et al. A strategy for development of practice guidelines for the ICU using automated knowledge acquisition techniques. Intl J Clin Monit Comput. 1999;15:109-17.
De Neeling AJ, van Leeuwen WJ, Schouls LM, et al Resistance of staphylococci in The Netherlands: surveillance by an electronic network during 1989-1995 J Antimicrob Chemother 1998 41(1):93 101
Dennis DT, Inglesby TV, Henderson DA, et al Tularemia as a biological weapon: medical and public health management JAMA 2001 285(21):2763 73 11386933
Washington, D. C.: Department of Defense; March, 2000.
Atlanta, GA: Centers for Disease Control and Prevention, American Medical Association, The Food and Drug Administration, USDA's Food Safety & Inspection Service; January, 2001.
Diamond LW, Nguyen DT, Jouault H, et al An expert system for the interpretation of flow cytometric immunophenotyping data J Clin Comput 1994 22(2-3):50 8 10172182
Dojat M, Ramaux N, Fontaine D Scenario recognition for temporal reasoning in medical domains Artif Intell Med 1998 14(1-2):139 55 9779887
Washington, D. C.: Booz-Allen Inc. and Science Applications International Corp., 1998.
Doyle T, Bryan R Infectious disease morbidity in the US region bordering Mexico, 1990-1998 J Infect Dis 2000 182(5):1503 10 11010841
Dufour B, Audige L A proposed classification of veterinary epidemiosurveillance networks Rev Sci Tech 1997 16(3):746 58 9567300
Effler P, Ching-Lee M, Bogard A, et al Statewide system of electronic notifiable disease reporting from clinical laboratories: comparing automated reporting with conventional methods JAMA 1999 282(19):1845 50 10573276
In: Conference on Electronic Reporting of Laboratory Information for Public Health, Centers for Disease Control and Prevention; January 7-8, 1999: Atlanta, GA: Centers for Disease Control and Prevention.
El-Solh AA, Hsiao CB, Goodnough S, et al Predicting active pulmonary tuberculosis using an artificial neural network Chest 1999 116(4):968 73 10531161
Emanuel PA, Dang J, Gebhardt JS, et al Recombinant antibodies: a new reagent for biological agent detection Biosens Bioelectron 2000 14(10-11):751 9 10945449
Emerging Pathogens Initiative: an automated surveillance system Emerg Infect Dis 1999 5(2):31 4
Emori TG, Culver DH, Horan TC, et al National Nosocomial Infections Surveillance system (NNIS): description of surveillance methods Am J Infect Control 1991 19(1):19 35 1850582
Evans RS, Burke JP, Classen DC, et al Computerized identification of patients at high risk for hospital-acquired infection Am J Infect Control 1992 20(1):4 10 1554148
Evans RS, Burke JP, Pestotnik SL, et al. Prediction of hospital infections and selection of antibiotics using an automated hospital data base. Proceedings of the Annual Symposium on Computer Applications in Medical Care. 1990:663-7.
Evans RS, Classen DC, Pestotnik SL, et al. A decision support tool for antibiotic therapy. Proceedings of the Annual Symposium on Computer Applications in Medical Care. 1995:651-5.
Evans RS, Classen DC, Pestotnik SL, et al Improving empiric antibiotic selection using computer decision support Arch Intern Med 1994 154(8):878 84 8154950
Evans RS, Gardner RM, Burke JP, et al. A computerized approach to monitor prophylactic antibiotics. Proceedings of the Annual Symposium on Computer Applications in Medical Care. 1987:241-5.
Evans RS, Gardner RM, Bush AR, et al Development of a computerized infectious disease monitor (CIDM) Comput Biomed Res 1985 18(2):103 13 3921308
Evans RS, Larsen RA, Burke JP, et al Computer surveillance of hospital-acquired infections and antibiotic use JAMA 1986 256(8):1007 11 3735626
Evans RS, Pestotnik SL, Burke JP, et al Reducing the duration of prophylactic antibiotic use through computer monitoring of surgical patients DICP 1990 24(4):351 4 2327113
Evans RS, Pestotnik SL, Classen DC, et al A computer-assisted management program for antibiotics and other antiinfective agents N Engl J Med 1998 338(4):232 8 9435330
Evans RS, Pestotnik SL, Classen DC, et al Development of an automated antibiotic consultant MD Comput 1993 10(1):17 22 8418386
Evans RS, Pestotnik SL, Classen DC, et al Evaluation of a computer-assisted antibiotic-dose monitor Ann Pharmacother 1999 33(10):1026 31 10534212
Evans RS, Pestotnik SL Applications of medical informatics in antibiotic therapy Adv Exp Med Biol 1994 349(2):87 96 8209811
Evans RS The HELP system: a review of clinical applications in infectious diseases and antibiotic use MD Comput 1991 8(5):282 8, 315 1749338
2006 plan for combating bioterrorism. Washington, DC: U.S. Dept. of Health and Human Services, Office of the Assistant Secretary for Planning and Evaluation, Office of Science Policy; 2001.
Fatah A, Barrett J, Arcilesi J, Jr, et al. WORKING DRAFT: An introduction to biological agent detection for emergency first responders. Washington, DC: National Institute of Justice; October 2001, 2001. NIJ-101-00.
Fiszman M, Chapman WW, Evans SR, et al. Automatic identification of pneumonia related concepts on chest x-ray reports. Proceedings of the AMIA Annual Symposium. 1999:67-71.
Fiszman M, Haug PJ Using medical language processing to support real-time evaluation of pneumonia guidelines Proceedings of the AMIA Annual Symposium 2000 27(4):235 9
Flahault A, Dias-Ferrao V, Chaberty P, et al FluNet as a tool for global monitoring of influenza on the Web JAMA 1998 280(15):1330 2 9794312
Flahault A, Garnerin P, Chauvin P, et al Sentinelle traces of an epidemic of acute gastroenteritis in France Lancet 1995 346(8968):162 3 7603234
Fleming DM, Cohen JM Experience of European collaboration in influenza surveillance in the winter of 1993-1994 J Public Health Med 1996 18(2):133 42 8816310
Emerg Infect Dis 1997 3(4):581 3 9368789
Foodborne Diseases Active Surveillance Network, 1996 Mor Mortal Wkly Rep 1997 46(12):258 61
Frank GR, Salman MD, MacVean DW Use of a disease reporting system in a large beef feedlot J Am Vet Med Assoc 1988 192(8):1063 7 3372332
Fraser HS, Naimi S, Long WJ. New approaches to measuring the performance of programs that generate differential diagnoses using ROC curves and other metrics. Proceedings of the AMIA Annual Symposium. 2000:255-9.
Fraser M, Fisher V. Elements of effective bioterrorism preparedness: a planning primer for local public health agencies. Washington, D.C.: National Association of City and County Health Officials; January, 2001.
Frazer L Go with the flow: an updated tool for detecting molecules Environ Health Perspect 2000 108(9):A412 4 11017903
Frazier TW. Natural and bioterrorist/biocriminal threats to food and agriculture. Ann N Y Acad Sci. 1999;894:1-8. [pmid: 10681962].
Friede A, Reid JA, Ory HW CDC WONDER: a comprehensive on-line public health information system of the Centers for Disease Control and Prevention Am J Public Health 1993 83(9):1289 94 8395776 1694976
Friede A, Rosen DH, Reid JA CDC WONDER: a cooperative processing architecture for public health J Am Med Inform Assoc 1994 1(4):303 12 116209 7719813
Friedman C, Knirsch C, Shagina L, et al Automating a severity score guideline for community-acquired pneumonia employing medical language processing of discharge summaries Proceedings of the AMIA Annual Symposium 1999 101(2):256 60
Friedman CP, Wyatt JC. Evaluation Methods in Medical Informatics. New York: Springer-Verlag; 1997.
Frize M, Walker R Clinical decision-support systems for intensive care units using case-based reasoning Med Eng Phys 2000 22(9):671 7 11259936
Galarneau MR, Wilcox WW A system for tracking patients at forward medical treatment facilities Mil Med 1996 161(7):369 74 8754708
Gardner RM, Golubjatnikov OK, Laub RM, et al Computer-critiqued blood ordering using the HELP system Comput Biomed Res 1990 23(6):514 28 2276262
Gardner RM, Lundsgaarde HP Evaluation of user acceptance of a clinical expert system J Am Med Inform Assoc 1994 1(6):428 38 116226 7850568
Gardner RM, Pryor TA, Warner HR The HELP hospital information system: update 1998 Int J Med Inf 1999 54(3):169 82
Garner M, Nunn M. The Australian national animal health information system. Epidemiol Sante anim. 1995;27:143-60.
Garnerin P, Saidi Y, Valleron AJ. The French Communicable Diseases Computer Network. A seven-year experiment. Ann N Y Acad Sci. 1992;670:29-42. [pmid: 1309100].
Garnerin P, Valleron AJ The French Communicable Diseases Computer Network: a technical view Comput Biol Med 1992 22(3):189 200 1617953
Gilchrist MJ A national laboratory network for bioterrorism: evolution from a prototype network of laboratories performing routine surveillance Mil Med 2000 165(7 Suppl 2):28 31 10920634
Silver Spring, MD: U. S. Department of Defense, 1999.
Washington, DC: U. S. General Accounting Office; August 31, 2001. Report No. G.A.O.-01-722.
Geneva, Switzerland: World Health Organization; April 26-28, 2000. Report No. WHO/CDS/CSR/2000.3.
Gobar GM, Case JT, Kass PH Program for surveillance of causes of death of dogs, using the Internet to survey small animal veterinarians J Am Vet Med Assoc 1998 213(2):251 6 9676598
Gonzalez-Guzman J An epidemiological model for direct and indirect transmission of typhoid fever Math Biosci 1989 96(1):33 46 2520190
Graitcer PL, Burton AH The Epidemiologic Surveillance Project: a computer-based system for disease surveillance Am J Prev Med 1987 3(3):123 7 2838060
Grant AD, Eke B Application of information technology to the laboratory reporting of communicable disease in England and Wales Commun Dis Rep CDR Rev 1993 3(6):R75 8 7693156
Greenes DS, Fleisher GR, Kohane I Potential impact of a computerized system to report late-arriving laboratory results in the emergency department Pediatr Emerg Care 2000 16(5):313 5 11063357
Gruninger M, Fox M. Methodology for the design and evaluation of ontologies. Technical Report. Toronto, ON, Canada: Department of Industrial Engineering; April 13, 1995.
Guidelines for evaluating surveillance systems MMWR Morb Mortal Wkly Rep 1988 37(Suppl 5):1 18
Gustafson DH, Bosworth K, Hawkins RP, et al CHESS: a computer-based system for providing information, referrals, decision support and social support to people facing medical and other health-related crises Proceedings of the Annual Symposium on Computer Applications in Medical Care 1992 50(6-7):161 5
Halstrup B. The NBC Field Laboratory as a mobile biological identification system [abstract]. Seventh Annual Symposium on Protection Against Chemical and Biological Warfare Agents, 2001. Available at: http://www.cbwsymp.foa.se. Accessed September 20, 2001.
Hammersley JR, Cooney K. Evaluating the utility of available different diagnosis systems. Proceedings of the Annual Symposium on Computer Applications in Medical Care. 1988:229-31.
Hannoun C, Dab W, Cohen JM A new influenza surveillance system in France: the Ile-de-France "GROG." 1: Principles and methodology Eur J Epidemiol 1989 5(3):285 93 2792306
Hanson G, Pezzino G. A guide to the implementation of the NEDSS in state public health agencies. Lessons learned: Kansas system (HAWK). Available at: http://www.cste.org/NNDSSSurvey/Downloads/NEDSS_Book_Final.pdf. Accessed November 27, 2001.
Harvey A, Koopman SJ Structural time series models in medicine Stat Methods Med Res 1996 5(1):23 49 8743077
Harvey I Infectious disease notification -- a neglected legal requirement Health Trends 1991 23(2):73 4 10116897
Haynes RB, Walker CJ Computer-aided quality assurance. A critical appraisal Arch Intern Med 1987 147(7):1297 301 3606287
Atlanta, GA: Centers for Disease Control and Prevention; October 1, 1997.
Heindl B, Schmidt R, Schmid G, et al A case-based consiliarius for therapy recommendation (ICONS): computer-based advice for calculated antibiotic therapy in intensive care medicine Comput Methods Programs Biomed 1997 52(2):117 27 9034676
Heininger A, Niemetz AH, Keim M, et al Implementation of an interactive computer-assisted infection monitoring program at the bedside Infect Control Hosp Epidemiol 1999 20(6):444 7 10395153
Henderson DA, Inglesby TV, Bartlett JG, et al Smallpox as a biological weapon: medical and public health management. Working Group on Civilian Biodefense JAMA 1999 281(22):2127 37 10367824
Henderson DA Bioterrorism as a public health threat Emerg Infect Dis 1998 4(3):488 92 9716981
Hendrickx G, Napala A, Slingenbergh JH, et al The spatial pattern of trypanosomosis prevalence predicted with the aid of satellite imagery Parasitology 2000 120(Pt 2)(3):121 34 10726274
Hersh WR, Wallace JA, Patterson PK, et al. Telemedicine for the Medicare population. Evidence Report/Technology Assessment. Rockville, MD: Agency for Healthcare Research and Quality; July, 2001. Report No. 290-97-0018.
Heymann DL, Rodier GR Global surveillance of communicable diseases Emerging Infectious Diseases 1998 4(3):362 5 9716946
Hoban DJ, Doern GV, Fluit AC, et al Worldwide prevalence of antimicrobial resistance in Streptococcus pneumoniae, Haemophilus influenzae, and Moraxella catarrhalis in the SENTRY Antimicrobial Surveillance Program, 1997-1999 Clin Infect Dis 2001 32(Suppl 2):S81 93 11320449
Hoffman RE, Norton JE Lessons learned from a full-scale bioterrorism exercise Emerg Infect Dis 2000 6(6):652 3 11203432
Holmberg M, Gustafsson F, Hornsten EG, et al. Bacteria classification based on feature extraction from sensor data. Biotechnol Techni. 1998;12:319-24.
Hripcsak G, Friedman C, Alderson PO, et al Unlocking clinical data from narrative reports: a study of natural language processing Ann Intern Med 1995 122(9):681 8 7702231
Hueston WD The National Animal Health Monitoring System: addressing animal health information needs in the U.S.A Prev Vet Med 1990 8(2-3):97 102
Hung J, Posey J, Freedman R, et al. Electronic surveillance of disease states: a preliminary study in electronic detection of respiratory diseases in a primary care setting. Proceedings of the AMIA Annual Symposium. 1998:688-92.
Hunt DL, Haynes RB, Hanna SE, et al Effects of computer-based clinical decision support systems on physician performance and patient outcomes: a systematic review JAMA 1998 280(15):1339 46 9794315
Huth TS, Burke JP Infections and antibiotic use in a community hospital, 1971-1990 Infect Control Hosp Epidemiol 1991 12(9):525 34 1940275
Hutwagner LC, Maloney EK, Bean NH, et al Using laboratory-based surveillance data for prevention: an algorithm for detecting Salmonella outbreaks Emerg Infect Dis 1997 3(3):395 400 9284390
Influenza-like diseases Surveillance of influenza-like diseases through a national computer network, 1984-1989 Wkly Epidemiol Rec 1990 65(14):103 4 2386673
EuroTB Newsletter: Surveillance of tuberculosis in Europe. 2000/1;16-17:2-3.
Inglesby T, Grossman R, O'Toole T. A Plague on Your City: Observations from TOPOFF. Center for Civilian Biodefense Studies, Johns Hopkins University, 2000. Available at: http://www.hopkins-biodefense.org/pages/news/quarter.html#Anchor-8398. Accessed December 20, 2000.
Inglesby TV, Dennis DT, Henderson DA, et al Plague as a biological weapon: medical and public health management. Working Group on Civilian Biodefense JAMA 2000 283(17):2281 90 10807389
Inglesby TV, Henderson DA, Bartlett JG, et al Anthrax as a biological weapon: medical and public health management. Working Group on Civilian Biodefense JAMA 1999 281(18):1735 45 10328075
Iqbal SS, Mayo MW, Bruno JG, et al A review of molecular recognition technologies for detection of biological threat agents Biosens Bioelectron 2000 15(11-12):549 78 11213217
Jacobson JT, Johnson DS, Ross CA, et al Adapting disease-specific isolation guidelines to a hospital information system Infect Control 1986 7(8):411 8 3017880
Jaykus LA The application of quantitative risk assessment to microbial food safety risks Crit Rev Microbiol 1996 22(4):279 93 8989514
Jernigan JA, Stephens DS, Ashford DA, et al Bioterrorism-related inhalational anthrax: the first 10 cases reported in the United States Emerg Infect Dis 2001 7(6):933 44 11747719
Joch J, Burkle T, Dudeck J Decision support for infectious diseases -- a working prototype Stud Health Technol Inform 2000 77(12):812 6 11187666
Johnson N, Mant D, Jones L, et al Use of computerised general practice data for population surveillance: comparative study of influenza data BMJ 1991 302(6779):763 5 2021767 1669527
Jones ME, Thornsberry C, Livermore DM, et al Prevalence of Acinetobacter spp. Isolates with reduced susceptibility to imipenem, as determined by a USA-wide electronic surveillance network J Antimicrob Chemother 1999 43(3):429 31 10223607
Kahn MG, Bailey TC, Steib SA, et al Statistical process control methods for expert system performance monitoring J Am Med Inform Assoc 1996 3(4):258 69 116308 8816348
Kahn MG, Steib SA, Dunagan WC, et al Monitoring expert system performance using continuous user feedback J Am Med Inform Assoc 1996 3(3):216 23 116303 8723612
Kahn MG, Steib SA, Fraser VJ, et al An expert system for culture-based infection control surveillance Proceedings of the Annual Symposium on Computer Applications in Medical Care 1993 3(4):171 5
Kahn MG, Steib SA, Spitznagel EL, et al Improvement in user performance following development and routine use of an expert system Medinfo 1995 8 Pt 2(5 Suppl):1064 7 8591368
Karras DJ Update on emerging infections from the Centers for Disease Control and Prevention Ann Emerg Med 2000 35(1):92 95 10613949
Katsuragawa S, Doi K, MacMahon H Image feature analysis and computer-aided diagnosis in digital radiography: classification of normal and abnormal lungs with interstitial disease in chest images Med Phys 1989 16(1):38 44 2646516
Kello D Epidemiological aspects in food safety Food Addit Contam 1990 7 Suppl 1(4):S5 11 2262040
Kimball AM, Horwitch CA, O'Carroll PW, et al The Asian Pacific Economic Cooperation Emerging Infections Network Am J Prev Med 1999 17(2):156 8 10490062
King KD, Anderson GP, Bullock KE, et al Detecting staphylococcal enterotoxin B using an automated fiber optic biosensor Biosens Bioelectron 1999 14(2):163 70 10101838
Knirsch CA, Jain NL, Pablos-Mendez A, et al Respiratory isolation of tuberculosis patients using clinical guidelines and an automated clinical decision support system Infect Control Hosp Epidemiol 1998 19(2):94 100 9510106
Kouba V EPIZOO: a computer software package of methods for animal population health analysis and programming Rev Sci Tech 1994 13(3):637 50 7949341
Kouba V EPIZOO: software for veterinary epidemiology training and problem-solving Bull World Health Organ 1995 73(1):77 83 7704930
Kralovic SM, Kelly AA, Danko LH, et al. Penicillin-resistant Streptococcus pneumoniae (PRSP) in the Department of Veterans Affairs, a 33 month review. In: Annual Meeting of Infectious Diseases Society of America; October 25-28. San Francisco. 2001. [pmcid: 369639].
Krawchuk BD. Networking the health community of New York State. Annals of the New York Academy of Sciences. 1992;670:101-8. [pmid: 1309077].
Kuperman GJ, Teich JM, Bates DW, et al. Detecting alerts, notifying the physician, and offering action items: a comprehensive alerting system. Proceedings of the AMIA Annual Fall Symposium. 1996:704-8.
Kuperman GJ, Teich JM, Tanasijevic MJ, et al Improving response to critical laboratory results with automation: results of a randomized controlled trial J Am Med Inform Assoc 1999 6(6):512 22 61393 10579608
Lagor C. Comparing diagnostic decision support systems for pneumonia. Proceedings of the AMIA Annual Symposium 2000.
Langmuir AA. The surveillance of communicable diseases of national importance. New Engl J Med. 1963;288:182-92.
Lederberg J, ed. Biological Weapons: Limiting the Threat. Cambridge, Massachusetts: The MIT Press; 1999.
Leibovici L, Gitelman V, Yehezkelli Y, et al Improving empirical antibiotic treatment: prospective, nonintervention testing of a decision support system J Intern Med 1997 242(5):395 400 9408069
Lemaire JB, Schaefer JP, Martin LA, et al Effectiveness of the Quick Medical Reference as a diagnostic tool CMAJ 1999 161(6):725 8 10513280 1230623
Levine BA, Cleary KR, Norton GS, et al Experience implementing a DICOM 3.0 multivendor teleradiology network Telemed J 1998 4(2):167 75 9710649
Los Alamos National Laboratory Annual Report. Los Alamos, NM: Los Alamos National Laboratory, 1999. LA-UR-99-5554.
Losinger WC, Bush EJ, Hill GW, et al Design and implementation of the United States National Animal Health Monitoring System 1995 National Swine Study Prev Vet Med 1998 34(2-3):147 59 9604264
Lowe CR Chemoselective biosensors Curr Opin Chem Biol 1999 3(1):106 11 10021414
Lucas PJ, de Bruijn NC, Schurink K, et al A probabilistic and decision-theoretic approach to the management of infectious disease at the ICU Artif Intell Med 2000 19(3):251 79 10906615
Ma JZ, Ackerman E, Yang JJ Parameter sensitivity of a model of viral epidemics simulated with Monte Carlo techniques. I. Illness attack rates Int J Biomed Comput 1993 32(3-4):237 53 8514439
Ma JZ, Ackerman E Parameter sensitivity of a model of viral epidemics simulated with Monte Carlo techniques. II. Durations and peaks Int J Biomed Comput 1993 32(3-4):255 68 8514440
Ma JZ, Peterson DR, Ackerman E Parameter sensitivity of a model of viral epidemics simulated with Monte Carlo techniques. IV. Parametric ranges and optimization Int J Biomed Comput 1993 33(3-4):297 311 8307660
MacKenzie WR, Schell WL, Blair KA, et al Massive outbreak of waterborne ravelersidium infection in Milwaukee, Wisconsin: recurrence of illness and risk of secondary transmission Clin Infect Dis 1995 21(1):57 62 7578760
Madsen KM, Schonheyder HC, Kristensen B, et al Can hospital discharge diagnosis be used for surveillance of bacteremia? A data quality study of a Danish hospital discharge registry Infect Control Hosp Epidemiol 1998 19(3):175 80 9552185
Maggini M, Salmaso S, Alegiani SS, et al Epidemiological use of drug prescriptions as markers of disease frequency: an Italian experience J Clin Epidemiol 1991 44(12):1299 307 1753261
Martin SM, Bean NH Data management issues for emerging diseases and new tools for managing surveillance and laboratory data Emerg Infect Dis 1995 1(4):124 8 8903181
Massari V, Maison P, Desenclos JC, et al Six years of sentinel surveillance of hepatitis B in general practice in France Eur J Epidemiol 1998 14(8):765 7 9928870
Mayer TA, Bersoff-Matcha S, Murphy C, et al Clinical presentation of inhalational anthrax following bioterrorism exposure: report of 2 surviving patients JAMA 2001 286(20):2549 53 11722268
McClure PJ, Blackburn CW, Cole MB, et al Modelling the growth, survival and death of microorganisms in foods: the UK food micromodel approach Int J Food Microbiol 1994 23(3-4):265 75 7873330
McLaws ML, Caelli M Pilot testing standardized surveillance: Hospital Infection Standardised Surveillance (HISS) On behalf of the HISS Reference Group Am J Infect Control 2000 28(6):401 5 11114609
McLaws ML, Murphy C, Whitby M Standardising surveillance of nosocomial infections: the HISS program. Hospital Infection Standardised Surveillance J Qual Clin Pract 2000 20(1):6 11 10821448
3 ed. Fort Detrick, Frederick, MD: U.S. Army Medical Research Institute of Infectious Diseases; 1998.
Michel P, Wilson JB, Martin SW, et al Temporal and geographical distributions of reported cases of Escherichia coli O157:H-7 infection in Ontario Epidemiol Infect 1999 122(2):193 200 10355782
Miller R, Masarie FE, Myers JD Quick medical reference (QMR) for diagnostic assistance MD Comput 1986 3(5):34 48 3537611
Miller RA, McNeil MA, Challinor SM, et al The INTERNIST-1/Quick Medical Reference project - status report West J Med 1986 145(6):816 22 3544509 1307155
Modai I, Sigler M, Kurs R The computerized lab alert system for patient management in clinical care Psychiatr Serv 1999 50(7):869 70, 885 10402605
Monnier-Cholley L, MacMahon H, Katsuragawa S, et al Computer-aided diagnosis for detection of interstitial opacities on chest radiographs Am J Roentgenol 1998 171(6):1651 6 9843307
Moore DA, Carpenter TE Spatial analytical methods and geographic information systems: use in health research and epidemiology Epidemiol Rev 1999 21(2):143 61 10682254
Morris RS Information systems for animal health: objectives and components Rev Sci Tech 1991 10(1):13 23 1760570
Morrison AC, Getis A, Santiago M, et al Exploratory space-time analysis of reported dengue cases during an outbreak in Florida, Puerto Rico, 1991-1992 Am J Trop Med Hyg 1998 58(3):287 98 9546405
Morse SS, Rosenberg BH, Woodall J ProMED global monitoring of emerging diseases: design for a demonstration program Health Policy 1996 38(3):135 53 10162418
Murphy GC, Friedman CP, Elstein AS, et al. The influence of a decision support system on the differential diagnosis of medical practitioners at three levels of training. Proceedings of the AMIA Annual Fall Symposium. 1996:219-23.
Myers MF, Rogers DJ, Cox J, et al Forecasting disease risk for increased epidemic preparedness in public health Adv Parasitol 2000 47(13):309 30 10997211
MMWR Morb Mortal Wkly Rep 1991 40(29):502 3 1649378
Emerging infectious disease task force, annual report. Washington, D.C.: Office of Science and Technology Policy, 1997.
Nobre FF, Stroup DF A monitoring system to detect changes in public health surveillance data Int J Epidemiol 1994 23(2):408 18 8082970
Noordergraaf GJ, Bouman JH, van den Brink EJ, et al Development of computer-assisted patient control for use in the hospital setting during mass casualty incidents Am J Emerg Med 1996 14(3):257 61 8639196
O'Brien TF, Stelling JM WHONET: an information system for monitoring antimicrobial resistance Emerg Infect Dis 1995 1(2):6 6
O'Brien TF, Stelling JM WHONET: removing obstacles to the full use of information about antimicrobial resistance Diagn Microbiol Infect Dis 1996 25(4):162 8 8937840
Osaka K, Inouye S, Okabe N, et al Electronic network for monitoring travellers' diarrhoea and detection of an outbreak caused by Salmonella enteritidis among overseas travelers Epidemiol Infect 1999 123(3):431 6 10694153
MMWR Morb Mortal Wkly Rep 1999 48(38):845 9 10563521
Overhage JM, Suico J, McDonald CJ Electronic laboratory reporting: barriers, solutions and findings J Pub Health Manage Pract 2001 7(6):60 66
Owens DK, Bravata DM Computer-based decision support: wishing on a star? Eff Clin Pract 2001 4(1):34 8 11234184
Owens DK, Nease RF A normative analytic framework for development of practice guidelines for specific clinical populations Med Decis Making 1997 17(4):409 26 9343799
Owens DK, Nease RF. Development of outcome-based practice guidelines: a method for structuring problems and synthesizing evidence. Jt Comm J Qual Improv. 1993;19:248-63. [pmid: 8401810].
Owens DK, Shachter RD, Nease RF Representation and analysis of medical decision problems with influence diagrams Med Decis Making 1997 17(3):241 62 9219185
Parsons DF, Garnerin P, Flahault A, et al Status of electronic reporting of notifiable conditions in the United States and Europe Telemed J 1996 2(4):273 84 10165364
Patrick W. Biological Warfare Scenarios. In: Layne SP, Beugelskijk TJ, Patel CKN, eds. Firepower in the Lab: Automation in the Fight Against Infectious Diseases and Bioterrorism. Washington, D.C.: Joseph Henry Press. 2001:215-223. [pmcid: 203017].
Pavlin JA, Kelley PW. ESSENCE: Electronic Surveillance System for the Early Notification of Community-based Epidemics. Silver Spring, MD: U.S. Department of Defense, Global Emerging Infections Surveillance and Response System; October 4, 2001.
Pestotnik SL, Classen DC, Evans RS, et al Implementing antibiotic practice guidelines through computer-assisted decision support: clinical and financial outcomes Ann Intern Med 1996 124(10):884 90 8610917
Pestotnik SL, Evans RS, Burke JP, et al Therapeutic antibiotic monitoring: surveillance using a computerized expert system Am J Med 1990 88(1):43 8 2294764
Petersen B, Welz M, Rosendaal EA, et al Microsensors and mobile laboratory as instruments for computer-based health management in a pork-production chain Vet Res 1994 25(2-3):179 84 8038781
Pingree S, Hawkins RP, Gustafson DH, et al Will HIV-positive people use an interactive computer system for information and support? A study of CHESS in two communities Proceedings of the Annual Symposium on Computer Applications in Medical Care 1993 3(4):22 6
Powell SC, Attwell RW An evaluation of the collection and analysis of epidemiological data for support of food safety control systems J Food Prot 1998 61(9):1170 4 9766070
Arlington, Virginia, USA. February 16-17, 1999 Emerg Infect Dis 1999 5(4):491 592 10458947
Pryor TA, Clayton PD, Haug PJ, et al. Design of a knowledge driven HIS. Proceedings of the Annual Symposium on Computer Applications in Medical Care. 1987:60-3.
Pryor TA The HELP medical record system MD Comput 1988 5(5):22 33 3231033
Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service; July, 2000.
Quenel P, Dab W Influenza A and B epidemic criteria based on time-series analysis of health services surveillance data Eur J Epidemiol 1998 14(3):275 85 9663521
Ramphal R, Hoban DJ, Pfaller MA, et al Comparison of the activity of two broad-spectrum cephalosporins tested against 2,299 strains of Pseudomonas aeruginosa isolated at 38 North American medical centers participating in the SENTRY Antimicrobial Surveillance Program, 1997-1998 Diagn Microbiol Infect Dis 2000 36(2):125 9 10705055
Rasley D, Wenzel RP, Massanari RM, et al Organization and operation of the hospital-infection-control program of the University of Iowa Hospitals and Clinics Infection 1988 16(6):373 8 3220585
Relman DA Detection and identification of previously unrecognized microbial pathogens Emerg Infect Dis 1998 4(3):382 9 9716951
Available at: http://www.kdhe.state.ks.us/epi. Accessed February 1, 2002.
MMWR Morb Mortal Wkly Rep 1999 48(15):305 12 10227798
Richet HM, Mohammed J, McDonald LC, et al Building communication networks: international network for the study and prevention of emerging antimicrobial resistance Emerg Infect Dis 2001 7(2):319 22 11294732
Riviere JE, Craigmill AL, Sundlof SF. Food animal residue avoidance databank (FARAD): an automated pharmacologic data-base for drug and chemical residual avoidance. J Food Prot. 1986;49:826-30.
Rocha BH, Christenson JC, Pavia A, et al Computerized detection of nosocomial infections in newborns Proceedings of the Annual Symposium on Computer Applications in Medical Care 1994 3(2):684 8
Rogers DJ, Williams BG Monitoring trypanosomiasis in space and time Parasitology 1993 106 Suppl(1):S77 92 8488074
Ross JJ, Shapiro DS Evaluation of the computer program GIDEON (Global Infectious Disease and Epidemiology Network) for the diagnosis of fever in patients admitted to a medical service Clin Infect Dis 1998 26(3):766 7 9524864
Rostker B. Close-out report: biological warfare investigation. Washington, D.C.: Department of Defense; October 23, 2000.
Rowe CA, Scruggs SB, Feldstein MJ, et al An array immunosensor for simultaneous detection of clinical analytes Anal Chem 1999 71(2):433 9 9949731
Rundio A Understanding microbiological concepts and computerized surveillance: enhancing professional practice Health Care Superv 1994 12(3):20 7 10132239
Rypka EW, Madar DA Enhancing laboratory detection of disease. Part 2: amplifying information and requisite variety Am Clin Lab 1997 16(2):14 7
Rypka EW, Madar DA Enhancing laboratory detection of disease. Part 3: detecting a hantavirus disease event: a case study Am Clin Lab 1997 16(4):6 7
Saatkamp HW, Dijkhuizen AA, Geers R, et al Economic evaluation of national identification and recording systems for pigs in Belgium Prev Vet Med 1997 30(2):121 35 9234416
Sahm DF, Critchley IA, Kelly LJ, et al Evaluation of current activities of fluoroquinolones against gram-negative bacilli using centralized in vitro testing and electronic surveillance Antimicrob Agents Chemother 2001 45(1):267 74 90271 11120976
Sahm DF, Marsilio MK, Piazza G Antimicrobial resistance in key bloodstream bacterial isolates: electronic surveillance with the Surveillance Network Database -- USA Clin Infect Dis 1999 29(2):259 63 10476722
Samore M, Lichtenberg D, Saubermann L, et al A clinical data repository enhances hospital infection control Proceedings of the AMIA Annual Symposium 1997 21(5):56 60
Sanson R. EpiMan - A decision support system for managing a foot and mouth disease epidemic. Surveillance. 1994;21:22-4.
Sanson RL, Morris RS, Stern MW EpiMAN-FMD: a decision support system for managing epidemics of vesicular disease Rev Sci Tech 1999 18(3):593 605 10588003
Schifman RB, Palmer RA Surveillance of nosocomial infections by computer analysis of positive culture rates J Clin Microbiol 1985 21(4):493 5 271703 3988895
Schmidt R, Pollwein B, Filipovici L, et al Adaptation and abstraction as steps towards case-based reasoning in the real medical world: case-based selection strategies for antibiotics therapy Medinfo 1995 8 Pt 2(5 Suppl):947 51 8591594
Schwoebel V, Antoine D, Veen J Surveillance of tuberculosis in Europe Med Arh 1999 53(3 Suppl 1):9 10
Atlanta, GA: Centers for Disease Control and Prevention, Agency for Toxic Substances and Disease Registry; July 15, 1999.
Sim I, Owens D, Lavori P, et al Electronic trial banks: a complementary method for reporting randomized trials Med Decis Making 2000 20(4):440 50 11059477
Sischo WM, Norman HS, Kiernan NE Use of the Food Animal Residue Avoidance Databank (FARAD) J Am Vet Med Assoc 1999 214(3):344 50 10023394
Smith HR, Ashton RE, Brooks GJ Initial use of a computer system for assisting dermatological diagnosis in general practice Med Inform Internet Med 2000 25(2):103 8 10901273
Smithson AE, Levy L. Ataxia: The Chemical and Biological Terrorism Threat and the U. S. Response. Washington, D.C.: The Henry L. Stimson Center, 1999.
Smyth ET, Barr JG, Bamford KB Surveillance and management of infection in a haematology unit: use of an in-house clinical database J Hosp Infect 1993 25(2):137 44 7903087
Smyth ET, Emmerson AM Survey of infection in hospitals: use of an automated data entry system J Hosp Infect 1996 34(2):87 97 8910750
Smyth ET, McIlvenny G, Barr JG, et al Automated entry of hospital infection surveillance data Infect Control Hosp Epidemiol 1997 18(7):486 91 9247831
Snacken R, Bensadon M, Strauss A The CARE telematics network for the surveillance of influenza in Europe Methods Inf Med 1995 34(5):518 22 8713768
Snacken R, Manuguerra JC, Taylor P European Influenza Surveillance Scheme on the Internet Methods Inf Med 1998 37(3):266 70 9787627
Song X, Nolan J, Swanson B. Optical biosensor based on fluorescence resonance energy transfer: ultrasensitive and specific detection of protein toxins. J Am Chem Soc. 1998;120:11514-5.
Sprenger MJ, Kempen BM, Hannoun C, et al Electronic influenza surveillance Lancet 1992 339(8797):87 4
Stark KD, Morris RS, Benard HJ, et al EpiMAN-SF: a decision-support system for managing swine fever epidemics Rev Sci Tech 1998 17(3):682 90 9850539
Sacramento, CA: Department of Health Services; State of California Health and Human Services Agency, 2002.
Stelling JM, O'Brien TF Surveillance of antimicrobial resistance: the WHONET program Clin Infect Dis 1997 24(Suppl 1):S157 68 8994799
Stenger DA, Gross GW, Keefer EW, et al Detection of physiologically active compounds using cell-based biosensors Trends Biotechnol 2001 19(8):304 9 11451472
Stephenson J New approaches for detecting and curtailing foodborne microbial infections JAMA 1997 277(17):1337, 1339 40
Stern L, Lightfoot D, Forsyth JRL. Automated detection of Salmonella outbreaks. In: Witten M, ed. Proceedings of the First World Congress on Computational Medicine, Public Health, and Biotechnology. Singapore: World Scientific. 1996:1395-404. [pmcid: 145829].
Stern L, Lightfoot D Automated outbreak detection: a quantitative retrospective analysis Epidemiol Infect 1999 122(1):103 10 10098792
Strausbaugh LJ, Liedtke LA The Emerging Infections Network electronic mail conference and Web page Clin Infect Dis 2001 32(2):270 6 11170917
Stroup DF, Williamson GD, Herndon JL, et al Detection of aberrations in the occurrence of notifiable diseases surveillance data Stat Med 1989 8(3):323 9 discussion 331-2 2540519
MMWR Morb Mortal Wkly Rep 1989 38(49):855 7 2511415
Swaminathan B, Barrett TJ, Hunter SB, et al PulseNet: the molecular subtyping network for foodborne bacterial disease surveillance, United States Emerg Infect Dis 2001 7(3):382 9 11384513
Szecsenyi J, Uphoff H, Ley S, et al Influenza surveillance: experiences from establishing a sentinel surveillance system in Germany J Epidemiol Community Health 1995 49(Suppl 1):9 13 7561670
Talan DA, Moran GJ, Mower WR, et al EMERGEncy ID NET: an emergency department-based emerging infections sentinel network Clin Infect Dis 1999 28(2):401 2 10064261
Talan DA, Moran GJ, Mower WR, et al EMERGEncy ID NET: an emergency department-based emerging infections sentinel network The EMERGEncy ID NET Study Group Ann Emerg Med 1998 32(6):703 11 9832668
Talaska T A Salmonella data bank for routine surveillance and research Bull World Health Organ 1994 72(1):69 72 8131252
Tate KE, Gardner RM, Weaver LK A computerized laboratory alerting system MD Comput 1990 7(5):296 301 2243545
Thacker SB, Redmond S, Rothenberg RB, et al A controlled trial of disease surveillance strategies Am J Prev Med 1986 2(6):345 50 3453201
Thomson MC, Connor SJ, D'Alessandro U, et al Predicting malaria infection in Gambian children from satellite data and bed net use surveys: the importance of spatial correlation in the interpretation of results Am J Trop Med Hyg 1999 61(1):2 8 10432046
Torassa U. Patients press doctors for e-mail visits, but not all providers are signing on. San Francisco Chronicle; Science Section; November 11, 2001.
Tountas Y, Saroglou G, Frissiras S, et al Remote access to an expert system for infectious diseases J Telemed Telecare 2000 6(6):339 42 11265103
Update: Investigation of anthrax associated with intentional exposure and interim public health guidelines MMWR Morb Mortal Wkly Rep 2001 50(41):889 93 11686472
Vallancourt MM, Boissinot M, Picard FJ, et al. Development of a multiplex PCR assay for the specific detection of Bacillus anthracis using the Smart Cycler. In: 101^st^ General Meeting, ASM; May. 2001. Orlando, Florida. [pmcid: 369639].
Valleron AJ, Bouvet E, Garnerin P, et al A computer network for the surveillance of communicable diseases: the French experiment Am J Public Health 1986 76(11):1289 92 3766824 1646722
Valleron AJ, Garnerin P. Computer networking as a tool for public health surveillance: the French experiment. MMWR Morb Mortal Wkly Rep. 1992;41 Suppl:101-10.
Valleron AJ, Garnerin P Computerised surveillance of communicable diseases in France Commun Dis Rep CDR Rev 1993 3(6):R82 7 7693158
Van Casteren V, Leurquin P Eurosentinel: development of an international sentinel network of general practitioners Methods Inf Med 1992 31(2):147 52 1635466
Van Gerwen SJ, de Wit JC, Notermans S, et al An identification procedure for foodborne microbial hazards Int J Food Microbiol 1997 38(1):1 15 9498132
Van Gerwen SJ, te Giffel MC, van't Riet K, et al Stepwise quantitative risk assessment as a tool for characterization of microbiological food safety J Appl Microbiol 2000 88(6):938 51 10849169
Van Wijk M, Mosseveld M, van der Lei J Design of a decision support system for test ordering in general practice: choices and decisions to make Methods Inf Med 1999 38(4-5):355 61 10805028
Vasiliskov V, Stomakhim A, Strizhkov B, et al. Research Abstracts 2000 DOE Human Genome Program #45: Microarray of gel immobilized compounds on a chip [abstract]. Human Genome Project Information Web site. Available at: http://www.ornl.gov/hgmis/publicat/00santa/45.html. Accessed October 16, 2001.
Vassallo DJ, Buxton PJ, Kilbey JH, et al The first telemedicine link for the British Forces J R Army Med Corps 1998 144(3):125 30 9819718
Vatopoulos AC, Kalapothaki V, Legakis NJ An electronic network for the surveillance of antimicrobial resistance in bacterial nosocomial isolates in Greece. The Greek Network for the Surveillance of Antimicrobial Resistance Bull World Health Organ 1999 77(7):595 601 10444883
Verdaguer A, Patak A, Sancho JJ, et al Validation of the medical expert system PNEUMON-IA Comput Biomed Res 1992 25(6):511 26 1458855
Vine MF, Degnan D, Hanchette C Geographic information systems: their use in environmental epidemiologic research Environ Health Perspect 1997 105(6):598 605 9288494 1470069
Von Bredow J, Myers M, Wagner D, et al. Agroterrorism: agricultural infrastructure vulnerability. Ann N Y Acad Sci. 1999;894:168-80. [pmid: 10681987].
Voysey PA, Brown M Microbiological risk assessment: a new approach to food safety control Int J Food Microbiol 2000 58(3):173 9 10939267
Wallace DJ, Van Gilder T, Shallow S, et al Incidence of foodborne illnesses reported by the foodborne diseases active surveillance network (FoodNet)-1997 FoodNet Working Group J Food Prot 2000 63(6):807 9 10852576
Walters TJ Deployment telemedicine: the Walter Reed Army Medical Center experience Mil Med 1996 161(9):531 6 8840793
Wang J Amperometric biosensors for clinical and therapeutic drug monitoring: a review Journal of Pharmaceutical & Biomedical Analysis 1999 19(1-2):47 53 10698567
Wang J. Peptide nucleic acid probes for sequence-specific DNA biosensors. J Am Chem Soc. 1996;118:7667-70.
Warner H, Jr., Blue SR, Sorenson D, et al. New computer-based tools for empiric antibiotic decision support. Proceedings of the AMIA Annual Symposium. 1997:238-42.
Warner H, Jr., Reimer L, Suvinier D, et al. Modeling empiric antibiotic therapy evaluation of QID. Proceedings of the AMIA Annual Symposium. 1999:440-4.
Warner HR, Jr Iliad: moving medical decision-making into new frontiers Methods of Information in Medicine 1989 28(4):370 2 2695788
Warner HR, Jr., Miller S, Jennings K, et al. Clinical event management using push technology -- implementation and evaluation at two health care centers. Proceedings of the AMIA Annual Symposium. 1998:106-10.
Wehner TR, Stroud PD, May WL. Lidar detection of biological aerosols. LAUR-96-2321: Los Alamos National Laboratory; August, 1996. SPIE Proc. Vol.2833.
Willard KE, Connelly DP, Johnson JR Radical improvements in the display of clinical microbiology results: a Web-based clinical information system Am J Med 1996 101(5):541 9 8948279
Williams RJ, Cox NJ, Regnery HL, et al Meeting the challenge of emerging pathogens: the role of the United States Air Force in global influenza surveillance Mil Med 1997 162(2):82 6 9038023
Woodall J Official versus unofficial outbreak reporting through the Internet Int J Med Inf 1997 47(1-2):31 4
Woodall JP Global surveillance of emerging diseases: the ProMED-mail perspective Cad Saude Publica/Reports Pub Health 2001 17(Suppl):147 54
Zajtchuk R, Dasey C, Clyburn C. The Department of Defense telemedicine testbed: research, practice, opportunities. In: Lemke HU, ed. Computer Assisted Radiology: Elsevier Science. 1996:511-514. [pmcid: 157746].
Zelicoff A, Brillman J, Forslund DW, et al. The Rapid Syndrome Validation Project (RSVP). Albuquerque, NM: Sandia National Laboratory, 2001.
Zvarova J, Jedlickova A, Zvara K Computer-based evaluation of antibiotic therapy predictions Intl J Bio-Med Comput 1991 29(3-4):207 13