# Future Research

Many of the IT/DSSs included in this Report have not been subjected to critical evaluations. Moreover, the quality evaluations we performed demonstrate that the evaluations of the included systems that have been performed rarely meet published criteria for the high-quality evidence that decision makers ideally require in deciding which systems best meet their needs. Throughout Chapter 3 (Results) of this Report, in the summary comments on each of the sections we discussed the gaps in the available literature. In this section, each of the 4 types of systems is discussed briefly in turn, identifying critical areas for additional systems. We then discuss other expansions of the research described in this Report.

## Detection and diagnosis

Users of these systems require a comprehensive understanding of the test characteristics of these systems to be able to interpret their results. Therefore, studies that compare similar systems with each other and with a gold standard are required. First responders, clinicians, food safety inspectors, and veterinarians need rapid, portable detection systems, preferably with the capacity to electronically report test results to decision makers at a remote location. Studies are needed that demonstrate successful translation of the use of some of the laboratory-based systems into portable devices for use in the field. Additional tests for biothreat agents are needed, as are sensitive and specific probes for nucleic acid tests; tests that facilitate the evaluation of a given sample for more than one biothreat agent; and integration of these test results into systems that directly analyze samples and communicate results to decision makers.

## Management and prevention

Additional research is required to evaluate the utility of systems based on electronic medical records to make patient-specific recommendations for management decisions. A further understanding of the most effective means of improving inference engines, updating knowledge bases, and presenting recommendations to clinicians will be useful as these systems are developed.

## Surveillance

There are several ongoing efforts to integrate disparate sources of data into a single system, thereby maximizing the use of routinely collected data supplemented by reports from experienced sentinel clinicians, syndromal surveillance tools, laboratories, and pharmacies. Critical evaluations of these systems are complicated by the fact that there is no gold standard by which to compare such a system. Moreover, there is no available evidence to confirm the hypothesis that the integration of multiple data sources is actually more sensitive, specific, or timely than the collection and analysis of a single source of data. Studies evaluating the characteristics of different sources of surveillance data and alternative means of integrating them are required to test this fundamental hypothesis. Additional methods for the analyses of these data in both space and time will facilitate interpretation of the data collected by these systems.

## Reporting and communication

Recent events suggest that systems for the effective communication of secure data among all levels of public health officials, and between public health and the media, are urgently needed. This Report focused on the reporting and communication needs of clinicians and public health officials, only a few of the many essential decision makers in a bioterrorism response. Additional research is required to develop and evaluate an integrated communication system that includes all parties responsible for bioterrorism preparations and response, including the FBI, Federal Emergency Management Agency (FEMA), the National Security Council, the Office of Emergency Preparedness, the Office of the Secretary of HHS, and the Office of Homeland Security, among many others. These systems will require additional methods for the secure transfer of patient-specific information and will have to comply with standards developed through HIPAA. The assumption that systems that actively send data to the recipient (i.e., that call, e-mail, or fax the recipient directly) are more effective than passive systems in communicating critical information remains to be formally tested. A better understanding of the barriers to mandated clinician reporting of communicable diseases in this era of increasing use of computers in the routine care of patients could help in the design of systems for this purpose.

In this Report, we developed a conceptual model of the decisions and tasks clinicians and public health officials would have to make in the event of a bioterrorism event. The influence diagram and task decomposition serve as the framework by which we evaluated IT/DSSs for bioterrorism preparedness and response. We defined clinicians as all personnel who would be directly involved in the care of patients resulting from a bioterrorist event in a clinic or hospital. These include physicians, nurses, nurse practitioners and respiratory therapists. We used the term public health official (unless otherwise specified) to refer to all professionals at the local, state, national and international levels responsible for preparing for and responding to acts of bioterrorism to ensure the public health. Because each of these groups includes many different types of decision makers, the influence diagram, and task decomposition could be expanded to describe these differences in detail. Similarly, our conceptual model could be expanded to evaluate the decisions and tasks of other groups of relevant decision makers (e.g., laboratory personnel, first responders, veterinarians, and hospital administrators).

The purpose of this project was to perform a comprehensive review of the available literature of IT/DSSs for clinicians and public health officials in the event of a bioterrorism event. Methodologies other than systematic review would provide additional valuable insight into the answers of the Key Questions addressed in this Report. Specifically, surveys of clinicians and public health officials could be used to better describe the information needs of these groups in preparing for and responding to bioterrorist events, the IT/DSSs currently in use, and the performance of these systems in routine use and times of crisis. There is also the need for additional research on how to provide effective training in the use of IT/DSSs and how to maintain the security and availability of systems in times of crisis.

In conclusion, from our systematic review of the literature, we have identified the important decisions and tasks of clinicians and public health officials in preparing for and responding to bioterrorism. The IT/DSSs described in this Report may assist with these decisions, but most were designed for purposes other than a response to bioterrorism and have not been evaluated even for their intended purpose. Many of these systems are reasonable candidates for further evaluation. Such evaluations would clarify their value both for response to bioterrorism, and for the other purposes for which they were designed.