# Conclusions

This Report describes 217 IT/DSSs identified in our searches because they may be useful for responding to a bioterrorism attack. Our goal was to delineate the information needs of clinicians and public health officials, and to assess whether available IT/DSSs have potential utility, relative to those needs. We used a formal approach to describe the decisions that clinicians and public health officials would make during a response, and thereby elucidated their information needs. In devising our framework for the evaluation of IT/DSSs, we focused on critical decisions that must be made by clinicians and public health officials. For clinicians, these decisions relate to diagnosis and detection, management, prevention of further exposure or illness, and communication with public health officials. For public health officials, they include decisions relating to surveillance (such as how to interpret surveillance data, when to initiate outbreak investigations, and how to track the extent and spread of the epidemic during the crisis), when to alert clinicians and the public about a potential outbreak, what type of measures to take to control the outbreak or epidemic.

To further understand the information needs of clinicians and public health officials, we used an approach called task decomposition to specify the individual tasks and data required to make each of the specified decisions. For example, for diagnostic decisions, clinicians require information about history of exposure, risk factors, host susceptibility, the signs and symptoms of diseases caused by biothreat agents, and the sensitivity, specificity and timeliness of diagnostic tests. As detailed in Table 2, the data and information required to make these decisions are extensive.

This framework guided both our search for, and evaluation of systems. We anticipated that many potentially useful systems would not have been described in the peer-reviewed literature, and therefore performed extensive searches of the Internet. In fact, about 20 percent of the 217 systems that we found were described only on the Web. Some of the information that we found on the Internet is no longer available because the authors of Web sites removed the information after the bioterrorism attacks in Fall 2001.

The anthrax attacks in Fall 2001 created enormous interest in systems that could be used for surveillance, detection and diagnosis, in both the public and private sector. Intensive research funded by the CDC, DOD, DOE, WHO, and the private sector is ongoing. Because some of the information is proprietary, and because developers are concerned about publicizing some of the more sensitive information, it will be increasingly difficult for potential users to identify the available systems and to understand their capabilities.

The vast majority of systems that we found, both from the peer-reviewed literature and from other sources, have not been rigorously evaluated. Very few of the systems have been specifically evaluated for use in response to a bioterrorism event or threat. Thus, overall, there is a lack of evidence to indicate whether these IT/DSSs would be helpful. We emphasize that lack of evidence about effectiveness is not evidence for lack of effectiveness. We recognize that this may be a particular difficulty for systems designed for use by public health departments since public health officials are not likely to have the incentive to publish the results of their experiences with a given system. Many of the systems seem promising; careful evaluation of the systems could determine whether this promise is realized.

Increasingly, bioterrorism preparedness efforts are underway to create integrated "meta-systems" that combine surveillance, laboratory, and communication functionalities for both naturally-occurring and bioterrorism-related illness. An example of this is the RHEACT project, which is intended to provide standard Web portals that serve as the consistent interface to integrate multiple users, multiple sources of NEDSS compliant surveillance data (including reports from the Laboratory Response Network) with communication and alerting capabilities. It may be useful to the developers and evaluators of these "meta-systems" if the efficacy of each of its components has been rigorously evaluated.

The efficacy of any system will, in part, be dependent on the task it is expected to perform during a bioterrorism response. For a covert release of biothreat agents, the initial purpose of information systems will be the early detection of agents and bioterrorism-related illness. After the bioterrorist event has been made known, systems will be required to treat exposed people and to minimize additional exposures. In the sections that follow, we discuss examples of systems that could be used during covert and known bioterrorist attacks. However, we emphasize that the publicly available evidence on these systems is quite limited.

## Systems for Detecting a Covert Bioterrorist Attack

The detection of a covert bioterrorist attack on human or animal populations or food or water supplies requires the capacity to collect surveillance data and communicate this information to decision makers in a sufficiently timely manner that actions may be taken to prevent resulting morbidity or mortality. These surveillance data are not just from laboratories and clinicians but include information from the FBI and other members of the intelligence community that may suggest the possibility of a bioterrorist attack. Surveillance systems have the additional role of tracking the extent of an outbreak once they have been discovered. Here, we briefly describe surveillance systems that could contribute to surveillance efforts for the detection of and then monitoring the extent of a covert bioterrorist event. We do not specifically describe the necessary communication systems that facilitate the secure and timely transmission of surveillance information to the public health decision makers but recognize that this is a critical component of any surveillance system for the detection of a covert bioterrorist attack.

### Integrated surveillance systems

For the early detection of a covert release of biothreat agents, integrated surveillance systems that collect, analyze, and communicate data from multiple sources would be useful. There is no evidence that any currently available technology can perform all of these functions. However, efforts like the Program for Response Options and Technology Enhancements for Chemical/Biological Terrorism (PROTECT) project of the DOE hold promise with respect to integrating data from multiple detection systems in locations of likely attack. Networks of disparately deployed collection systems, particulate counters and biomass indicators (with or without the identification systems described in the next section) sending electronic reports of their results to a central surveillance analysis center could provide the earliest possible evidence of a bioterrorist attack -- even before the first patient becomes ill.

### Syndromal surveillance systems

There are a number of syndromal surveillance systems in use. Devices such as Health Buddy^®^ and the Patient Encounter Module of LEADERS can be used in multiple settings (e.g., clinics, airports, sporting events) to present questions to multiple users (e.g., clinicians, patients, teachers, immigration officers, food inspectors) for input into a surveillance system. The Rapid Syndrome Validation Project (RSVP^®^) is a Web-based surveillance tool that enables clinicians to report data on patients presenting with one or more of the syndromes of interest. The Early Warning Outbreak Recognition System (EWORS) of the DOD-GEIS has demonstrated that personnel with limited training can use a simple computer program to collect demographic and syndromal data in remote regions of the world, and then transfer this data to analysis centers on a daily basis. A program like the Electronic Surveillance System for the Early Notification of Community-based Epidemics (ESSENCE) requires administrative data in an electronic format, but has the advantage of minimizing the burden of collection by using routinely collected data for syndromal surveillance. ESSENCE has demonstrated remarkable scalability, performs the most comprehensive analysis of syndromal data of all the syndromal systems, and, as is true for many of these systems, is currently under evaluation to determine its sensitivity, specificity, and timeliness in detecting infectious disease outbreaks.

### Clinician networks

Because clinicians may be the first to recognize unusual or suspicious illnesses, reports from clinician networks are an essential source of surveillance data for detection of bioterrorism-related diseases. In particular, because individuals exposed to a variety of biothreat agents may present with influenza-like illness initially, sentinel clinicians in the U.S. and around the world, already experienced in the reporting of influenza cases in accordance with case definitions provided by public health officials, may be useful for the detection of a bioterrorism event. None of the surveillance systems collecting clinician reports has been evaluated specifically with respect to biothreat agents. However, the evaluations of these systems for other purposes have demonstrated their ability to detect outbreaks more quickly than the manual reporting systems that they replaced.

### Laboratory surveillance

Laboratories are critical to the rapid detection of a covert biothreat agent release. Bioterrorism surveillance in the U.S. is limited by the lack of coordination among the many types of laboratories, reporting and communication systems for laboratory surveillance data, and personnel and equipment for rapid detection of biothreat agents. Therefore, the plans for the Laboratory Response Network, with its use of NEDSS-compliant reporting, address many of the current gaps in U.S. laboratory response capabilities. In addition, efforts such as those of the DOD-GEIS to make laboratory services and training available in developing nations and at U.S. military facilities worldwide respond to the needs for global laboratory surveillance.

### Antimicrobial resistance surveillance

The dissemination of a common organism with uncommon antimicrobial resistance could be highly desirable by bioterrorists interested in minimizing the likelihood of detection of the release, and in reducing the efficacy of available therapies. Surveillance systems that collect antimicrobial resistance data could potentially detect bacterial bioterrorism agents with unusual resistance patterns. However, none of these systems has been evaluated for such use.

### Foodborne disease surveillance

The contamination of salad bars in The Dalles, Oregon with Salmonella typhimurium by followers of Bhagwan Shree Rajneesh was intended to be a covert attack on the U.S. food supply. Technologies like the Salmonella Outbreak Detection Algorithm (SODA), the National Molecular Subtyping Network for Foodborne Disease Surveillance (PulseNet), and the Foodborne Diseases Active Surveillance Network (FoodNet) have all been used to detect and track foodborne outbreaks, but they are all limited to the detection of fewer than 10 species. Moreover, none of the foodborne illness surveillance systems that collect disease incidence data were specifically designed for the early detection of bioterrorist attacks on the food supply, nor has any been evaluated for that purpose.

## Systems for Responding to a Known Bioterrorist Attack

For the management of a known attack, first responders will require portable detection systems to evaluate suspicious materials or potentially contaminated environments. Clinicians will require rapid diagnostic tests to evaluate patients with potential exposures; diagnostic systems to aid in the recognition of bioterrorism-related disease; and management systems for advice regarding triage, treatment, and prevention measures. Public health officials will require information systems to help them conduct ongoing outbreak investigations in the midst of the response, manage the results from public health laboratories, and implement epidemiologic control measures to prevent the further spread of disease. Finally, there will be a need for flexible, secure communication tools that can facilitate the transmission of information among geographically separated decision makers, the media, and the public.

### Collection systems

Of the available portable collection systems for use by first responders, only the BioCapture™ device has reports in the publicly available literature of controlled evaluations of its flow rate and collection efficiency. Even if collection and rapid identification systems could be deployed widely, they would still be constrained by the inherent limitations of currently available detection systems: the lack of tests for many biothreat agents (e.g., smallpox); the lack of available probes for many nucleic acid tests; and the lack of tests that facilitate the evaluation of a given sample for multiple biothreat agents. Moreover, given the inadequacy of sensitivity and specificity data, decision makers may have difficulty determining the appropriate action to take given an environmental sample with either a positive or negative result.

### Diagnostic systems

Of the available DSSs for diagnosis, only 2 systems (GIDEON and The Computer Program for Diagnosing and Teaching Geographic Medicine) were specifically described to have knowledge bases that contain the most worrisome potential biothreat agents. Several evaluations of diagnostic DSSs suggest that the differential diagnosis produced by the DSS is highly dependent on the terms entered about the patient. The need for clinicians to manually enter patients' signs and symptoms into diagnostic DSSs may be eliminated by systems that automatically collect patient data from an electronic medical record -- although none of the systems currently available have this capability.

### Management and prevention systems

The management and prevention systems identified have diverse functions and purposes. None has been evaluated with respect to usefulness in response to bioterrorism. However, systems like Health Evaluation through Logical Processing (HELP) at the LDS Hospital in Salt Lake City and the Clinical Event Monitor at Columbia-Presbyterian Medical Center, which combine rich electronic medical record data with robust inference methodologies and detailed knowledge bases of infectious diseases, may be modifiable to better serve the needs of clinicians faced with management decisions. In particular, these systems use many elements of the medical record (e.g., laboratory results, clinical information, demographic data, pharmacy data and radiology reports) to generate patient-specific recommendations about antibiotic therapies, hospital infection control measures, the admission of patients with community-acquired pneumonia, and the isolation of patients with suspected active pulmonary tuberculosis. These systems would be more useful for bioterrorism response planning if their knowledge bases were updated to reflect current information about biothreat agents.

### Reporting and communication systems

As was demonstrated in the Dark Winter tabletop exercise and in the months since the first inhalational anthrax cases in the U.S., communication systems are a critical element in the response to bioterrorism. In particular, effective communication is needed among levels of public health officials, between public health officials and the media, and among all decision makers responding to a bioterrorist crisis. The Web-based and other communication systems commonly used among public health officials at local, state, and federal levels have not been critically evaluated. Several promising efforts to improve reporting and communication include the RHEACT project in California to integrate the public health communication infrastructure. The Urban Security Initiative project of the Los Alamos National Laboratory is piloting a project to use Web-based technology to facilitate communication among 20 agencies. The Indianapolis Network for Patient Care (INPC), currently under evaluation, is a mechanism for communication between local hospitals and public health officials.^ 477 ^

## Limitations

We have evaluated IT/DSSs that affect the information needs of clinicians and public health officers in response to a bioterrorism attack. Therefore, systems designed for other decision makers (e.g., hazardous materials personnel or incident commanders) that could not also be used by clinicians or public health officers were excluded. Additionally, our focus was on detection and response to biological events; we did not include those IT/DSSs for response to chemical or nuclear weapons unless they could also be of use against biothreat agents.

Our search strategy was designed to identify all potentially relevant articles in the peer-reviewed medical literature, in government reports and on the Internet. We recognize that there are articles from other disciplines (e.g., biology and computer science) that likely contain relevant literature that were not identified by our search. We surmise that the literature we did not capture may pertain primarily to detection systems and communication systems. Additionally, all material presented in this Report was publicly available. There may be systems directly relevant to this Report that have only been described in classified documents.

We limited our literature searches to exclude reports of IT/DSSs from before 1985 on the advice of our informatics experts, who suggested that those systems were not likely to be relevant today. However, many of our references are from the late 1980s and early 1990s, and the information on systems presented in them is likely to have changed considerably. In particular, it was difficult to determine which systems are currently available. Also, many systems have had multiple names as they evolved. We have made every effort to combine reports of the same system; however, if we could not trace the name changes, we may have included duplicate reports on the same IT/DSS.

There are many details of the features of the systems included in this Report that we were not able to obtain from the readily available published information about the systems. For example, cost will greatly affect which systems public health officials, municipal leaders, hospitals and others will consider using. Unfortunately, the cost of a system was almost never mentioned in the reports that we reviewed. Similarly, information regarding the security measures of systems was rarely included in the available descriptions. Certainly, some of the missing information could have been obtained by directly contacting the developer or manufacturer of each system; however, a survey of that nature was outside the scope of this project.