# Methods

We began the project by identifying advisors with wide-ranging technical expertise in bioterrorism preparedness and response, public health, and IT/DSSs. With the advice of these experts and input from the Agency for Healthcare Research and Quality (AHRQ), we refined the research questions and created a conceptual framework of the decisions likely to be faced by clinicians and public health officials during a bioterrorist attack. We used this framework to develop a list of tasks that IT/DSSs would have to perform to assist the decision-making process of clinicians and public health officials. We used this list and previously published reports to develop a framework for evaluating IT/DSSs. We conducted searches of peer-reviewed literature, government documents, and the Internet for reports of potentially relevant IT/DSSs, which we evaluated for their possible utility. Appendix A provides a complete listing of the acronyms and abbreviations used in this Report.

## Technical Expert Advisory Panels

For advice on the scope of the project, we consulted technical experts (Appendix B) in the following fields: bioterrorism/biodefense, emerging infectious diseases, IT/medical informatics, public health, evidence synthesis/meta-analysis, and clinical medicine. These experts assisted us in refining the research questions, developing the conceptual model, and preparing the Report.

## Target Population

The targeted decision makers addressed in this Report are clinicians and public health officials. For the purpose of this Report, clinicians include all clinical health providers, such as physicians, nurses, and community health workers. Public health officials include those at the local, state, federal, and international levels.

## Identification of Key Questions

The Key Questions that we developed in collaboration with AHRQ and the expert advisory panel were based on the premise that during a bioterrorism event, clinicians would have 4 major tasks and public health officials would have 3 major tasks. Clinicians would have to: (1) correctly diagnose the clinical manifestations of biothreat agents; (2) rapidly manage the care of potentially exposed patients; (3) take effective action to prevent the further spread of disease; and (4) report suspicious or confirmed cases to local, regional, and national public health officials. Public health officials would have to: (1) communicate with first responders (i.e., fire, police, and hazardous materials personnel), clinicians, and the public; (2) manage and interpret surveillance data to determine when to perform outbreak investigation; and (3) determine when to take epidemiologic control measures, such as quarantine, to prevent the spread of disease.

Therefore, the Key Questions to be addressed in this Report are:

Key Question 1: What are the information needs of clinicians and public health officials in the event of a bioterrorist attack?

Key Question 2: Based on the information needs identified for these decision makers, what are the criteria by which IT/DSSs should be evaluated with respect to usefulness during a bioterrorism event?

Key Question 3: When assessed by these criteria, in what ways could existing IT/DSSs be useful during a bioterrorism event? In what ways are they limited?

Key Question 4: In areas where existing IT/DSSs do not meet the information needs of clinicians or public health officials, what functional and technical considerations are important in the design of future IT/DSSs to support response to bioterrorism events?

We present detailed information about the Key Questions throughout the Results section and summarize our answers to these Key Questions at the end of Chapter 3.

## Conceptual Model

To describe the information needs of clinicians and public health officials (Key Question 1), we evaluated the decisions they would have to make while preparing for and responding to a bioterrorism event. To determine these key decisions of clinicians and public health officials, we reviewed reports of their participation in naturally occurring outbreaks of infectious diseases (including infections due to Cryptosporidium parvum contamination of the water supply in Milwaukee during March and April 1993^ 14 ^ and West Nile Virus in New York City in late August 1999^ 15 ^), TOPOFF and Dark Winter bioterrorism preparedness exercises,^9, 11, 16^ emergency preparedness plans,^17-20^ standards for reporting public health surveillance data,^21-23^ and standards for maintaining the security of electronic data.^ 24 ^ We obtained additional information about the information needs of public health officials and the types of information systems that have been helpful to them in managing infectious disease outbreaks by soliciting input from public health officials working in the health departments of the 5 most populous states and 4 most populous counties in the U.S. We asked them to describe the surveillance and communication systems currently in use in their health departments and any new systems or initiatives instituted since the events of September 11, 2001. They reported that limitations in personnel and other resources prevented significant increases in preparation and response efforts; surveillance systems are largely dependent on voluntary clinician and laboratory reports; communication with clinicians and other members of the public is primarily by fax; syndromal surveillance systems are perceived to be costly and the data difficult to interpret; and few had instituted specific changes after September 11^th^ but many had pilot projects ongoing.

We developed a conceptual model to specify the decisions made by clinicians and public health officials in the event of a bioterrorist attack. We then created an influence diagram to represent our conceptual model of the key decisions made by clinicians and public health officials during a bioterrorism event. Influence diagrams are graphical representations of formal mathematical models that facilitate the compact representation of the probabilistic structures of complex problems.^25-27^ A detailed description of the representation and analysis of medical decisions with influence diagrams is beyond the scope of this project. For a complete discussion of this topic, we direct interested readers to Owens et al.^ 25 ^ The influence diagram allowed us to assess the relationships between the decisions made by the 2 types of decision makers, to identify the uncertain events that affect these decisions, and to evaluate the information that is observable by the decision makers at the time they make their decisions.

We adopted standard influence diagram notation such that decisions are represented by rectangular nodes.^25-27^ Arrows between decision nodes indicate that at the time of the second decision, the decision maker has knowledge of the previous decision. Probabilistic events are represented by elliptical (chance) nodes. Arrows between chance nodes indicate that a probabilistic relationship may exist. That is, the outcome of the first chance event may change the probability of the outcome of the second. Arrows from a chance node to a decision node indicate that the outcome of the uncertain event is known at the time the decision is made.

The complexities of the processes involved in clinicians and public health officials responding to a bioterrorist attack created unique challenges to the standard method of using an influence diagram to represent the relevant decisions. Specifically, our conceptual model required the incorporation of different decision makers, different time horizons, and different value functions.

## Task Decomposition

We used a process called task decomposition to describe the characteristics of IT/DSSs that would be required for these systems to assist clinicians and public officials as they make the decisions described in our conceptual model. Task decomposition provides a framework for specifying, documenting, and evaluating what types of data an IT/DSS should contain in order to serve its purpose.^28-30^ Task decomposition starts with the identification of the database's main purpose (or target task).^28-30^ This target task is then hierarchically decomposed into 3 components: (1) subtasks; (2) the methods to be used for accomplishing those subtasks; and (3) the necessary and sufficient information to complete those subtasks according to the specified methods.^28-30^ A database that models all the data required for completing a task is deemed competent for that task.^28-30^ For example, performing syndromal surveillance may be a target task of public health officials. Monitoring hospital-discharge diagnoses for the ICD9 codes associated with fever and rash (i.e., subtask) is one way to implement a syndromal surveillance system. For such a syndromal surveillance system to work, it is necessary to have a method for collecting ICD9 codes (i.e., method and data necessary to accomplish this subtask). Using this framework, the data requirements for other information needs can be similarly specified.

We decomposed the information needs of clinicians and public health officials into top-level tasks and subtasks. We then considered the key concepts driving each task and the data requirements for an IT/DSS to assist in that task. We used this task decomposition as well as our Key Questions to create a data abstraction form (Appendix C).

## Development of Inclusion and Exclusion Criteria

Based on input from our expert advisory panel, the conceptual model, task decomposition, and practical considerations, we developed an inclusion/exclusion strategy to identify articles that described or evaluated IT/DSSs that could be useful currently, or with potential adaptation, to clinicians and public health officials in the event of a bioterrorism attack. We included IT/DSSs designed for responding to naturally occurring outbreaks if such systems are potentially useful for a bioterrorist response. Similarly, potentially dual use diagnostic and management IT/DSSs are included. We also considered other technologies, such as detection devices, that are not IT/DSSs per se, but collect data for surveillance systems or otherwise enable the IT/DSSs to perform diagnosis, management, prevention, surveillance, reporting, and communication functions. Because the focus of our analysis was on systems for use by clinicians and public health officials, we did not include IT/DSSs designed for other decision makers unless clinicians or public health officials could also use them. Similarly, we did not include those IT/DSSs for response to chemical or nuclear weapons unless they could also be of use against biothreat agents.

Before developing our inclusion and exclusion criteria for information describing IT/DSSs for bioterrorism, we established the following guidelines:

1. Articles reporting descriptions of systems must at a minimum include a statement of the purpose of the system;
2. Articles reporting clinical evaluations of systems must at a minimum include a report of the results of an evaluation using either actual or simulated patient data. Outcomes of these evaluations may include, but are not limited to, those that relate to the system's effectiveness; sensitivity and specificity; implementation, usability and acceptability; cost; or timeliness. By sensitivity (also called true positive rate), we mean the likelihood that a system provides a positive response when a bioterrorism event has occurred. By specificity (also called true negative rate), we mean the likelihood that a system provides a negative response in the absence of a bioterrorism event. The false positive rate is equal to 1 minus the specificity and the false negative rate is equal to 1 minus the sensitivity.
3. Bioterrorism-relevant diseases are all conditions resulting from the biothreat agents as defined by the Department of Health and Human Services (HHS).^ 31 ^ Specifically, HHS has identified the following organisms as having the highest bioterrorist threat potential: Variola major (smallpox), B. anthracis (anthrax), Y. pestis(plague), Clostridium botulinum toxin (botulism), Francisella tularensis (tularemia), Filoviruses (Ebola hemorrhagic fever and Marburghemorrhagic fever), Arenaviruses (Lassafever, Junin/Argentine hemorrhagic fever) and related viruses.^ 31 ^ The next highest priority agents include: Coxiella burnetti (Q fever), Brucella species (brucellosis), Burkholderia mallei (glanders), Alphaviruses (Venezuelan encephalomyelitis, eastern and western equine encephalomyelitis), Ricin toxin from Ricinus communis (castor beans), Epsilon toxin of Clostridium perfringens, Staphylococcus enterotoxin B, and food or waterborne pathogens such as Salmonella species, Shigella dysenteriae, Escherichia coli O157:H7, Vibrio cholerae, and C. parvum. ^ 31 ^ The third highest priority agents are Nipah virus, Hanta virus, tickborne hemorrhagic feverviruses, tickborne encephalitis viruses, yellow fever, and multidrug-resistant tuberculosis.^ 31 ^ Because these agents primarily cause flu-like illness, acute respiratory distress, gastrointestinal symptoms, febrile hemorrhagic syndromes, and febrile illnesses with either dermatologic or neurologic findings, these syndromes will be considered bioterrorism-relevant syndromes.

### Inclusion and Exclusion Criteria for Diagnostic and Detection Systems

We included systems specifically designed to support the diagnosis of bioterrorism-relevant diseases or syndromes (e.g., systems that make recommendations about ordering diagnostic tests for a bioterrorism-relevant organism). We also included general diagnostic systems (e.g., systems that provide differential diagnoses based on a patient's signs or symptoms), automated diagnostic test analysis systems, microbiologic test analysis systems for bioterrorism-specific agents, rapid detection technologies for use in the field or at the bedside, and automated radiologic diagnostic systems for the evaluation of bioterrorism-related illnesses or syndromes. We included radiologic diagnostic systems that automatically make the diagnosis of, or evaluate radiology reports for, the diagnosis of pulmonary infiltrate or widened mediastinum but excluded those systems that automatically read mammograms or pulmonary nodules.

We excluded systems designed for the diagnosis of non-bioterrorism-related diseases that could not be readily modified for diagnosis of bioterrorism-related diseases (e.g., DSSs for hypertension or automated laboratory systems for interpreting Pap smears). We also excluded those systems designed to improve general laboratory functions (e.g., BACTEC™ systems for positive blood culture detection).

### Inclusion and Exclusion Criteria for Management and Prevention Systems

We included systems designed for the management, treatment, prevention or guideline implementation of bioterrorism-related diseases or syndromes, as well as systems that facilitate outbreak management for bioterrorism-related diseases or syndromes.

We excluded systems designed for the management of non-bioterrorism-related diseases that could not be readily modified for applicability to a bioterrorism-related disease. Whereas we included systems designed to provide management recommendations about initiating or changing antibiotic therapy, we excluded general drug dosing or monitoring systems designed to reduce costs or side effects. We also excluded general reminder systems for routine medical care (e.g., systems that provide vaccination recommendations).

### Inclusion and Exclusion Criteria for Surveillance Systems

We included reports of systems designed for surveillance and reporting of bioterrorism-related diseases or syndromes. We also included systems for surveillance of the clinical epidemiology and antimicrobial resistance patterns of specific bioterrorism-related diseases or syndromes (e.g., systems that track Ebolacases or the resistance patterns of Salmonella, but not those that monitor measles or hospital-acquired intravenous catheter infections).

If an article described a surveillance system and presented only disease incidence or prevalence data, but did not evaluate the system's timeliness, sensitivity, specificity or any of the other outcomes of interest as described in the guidelines for articles reporting clinical evaluations, we abstracted only the information about the description of the surveillance system.

### Inclusion and Exclusion Criteria for Reporting and Communication Systems

We included reporting and communication technologies that allow decision makers (e.g., clinicians and public health officials) to give or receive patient-specific information (e.g., systems that facilitate physician reports of communicable diseases, enable communication between ambulance personnel and emergency room staff, send hospital capacity information to command and control centers, and automatically send public health information from national authorities to local public health officials, clinicians, and the public). Additionally, we included IT/DSSs that facilitate communication between clinicians and their patients, public health officials and the public, laboratories and clinicians (e.g., systems that alert clinicians about abnormal laboratory tests), and laboratories and public health officials (e.g., systems that automatically send laboratory surveillance data to public health officials), and systems that disseminate verified public health information among interested parties.

We excluded general listserves, e-mail distribution lists, chat rooms, electronic versions of textbooks or Web sites that provide information on infectious diseases or bioterrorism-related diseases without a moderator or peer-review process.

## Literature Sources

Given the multidisciplinary nature of preparedness for and response to acts of bioterrorism, we believed that much of the information required to answer our Key Questions would fall outside the peer-reviewed medical literature. We therefore used literature sources that included medical, governmental, political science, informatics, and engineering references that were both peer-reviewed and non-peer-reviewed. We designed a search strategy for 3 sources of reports of IT/DSSs: (1) peer-reviewed articles and government documents from databases such as MEDLINE^®^; (2) government documents obtained from the Web sites of national and international agencies; and (3) descriptions of IT/DSSs available from other Internet sources.

### Peer-reviewed Articles

In consultation with professional research librarians, we identified 5 databases of medical, scientific, and governmental references likely to contain reports of relevant IT/DSSs: MEDLINE^®^, The Catalog of U.S. Government Publications, GrayLIT, Library of Congress, and National Technical Information Service (NTIS). We considered articles peer-reviewed if they were published in a peer-reviewed journal.

### Government Web Sites

Through recommendations from our expert advisory panel, conference material, and Department of Veterans Affairs (VA) publications, we identified the government agencies most likely to fund, develop, or use IT/DSSs that could also be used by clinicians or public health officials (Table 1).^ 32 ^

Table 1. Government agencies included in Web-based search

Agency | Organization within agency
Centers for Disease Control and Prevention (CDC)
Department of Defense (DOD) | Defense Advanced Research Projects Agency (DARPA); Global Emerging Infections System (GEIS) ^a^
Department of Energy (DOE) | Sandia National Laboratory; Lawrence Livermore National Laboratory; Argonne National Laboratory; Los Alamos National Laboratory ^a^
Department of Veterans Affairs (VA) Environmental Protection Agency (EPA) Federal Bureau of Investigation (FBI) Federal Emergency Management Agency (FEMA) Public Health Service (PHS) National Technical Information Service (NTIS) World Health Organization (WHO)

a The Web sites of the Los Alamos National Laboratory and the DOD Global Emerging Infections System (GEIS) did not permit systematic searches using the same terms that we applied to the other government agencies. Therefore, we manually searched these sites for relevant information.

### Non-government Web Sites

We conducted Internet searches to retrieve reports of potentially relevant IT/DSSs from sites other than those operated by government agencies (e.g., academic institutions and commercial enterprises).

## Search Terms and Strategies

We performed a series of initial literature searches and asked our expert advisory panel to provide us with relevant articles to develop a preliminary library of potentially relevant articles available in each of the 4 primary IT/DSS categories (detection and diagnosis, management and prevention, surveillance, and reporting and communication). In consultation with professional research librarians, we then developed 3 separate search strategies: one for MEDLINE^®^, one for all other databases of peer-reviewed articles and the government Web sites, and one for all other Web-based information.

### MEDLINE^®^ Search Strategy

We developed 4 subsearches that we combined into the final search strategy for articles referenced in MEDLINE^®^ for the period January 1985-April 2001. An asterisk instructs the search engine to find all words that begin with a given text string. For example, bacter* will find all terms that begin with the root bacter such as bacteria, bacterium, and bacteriophage. The MeSH, or Medical Subject Heading, maps the search word to related concepts that MEDLINE^®^ indexers use for categorizing articles.

Subsearch 1: "artificial intelligence"[MESH] NOT "robotics"[MESH] OR "decision making, computer-assisted"[MESH] OR "decision techniques"[MESH] OR "clinical laboratory informatics systems"[MESH] OR "decision support systems, clinical"[MESH] OR "hospital information systems"[MESH] OR "integrated advanced information management systems"[MESH] OR "ambulatory care information systems"[MESH] OR "clinical laboratory information systems"[MESH] OR "clinical pharmacy information systems"[MESH] OR "decision support systems, management"[MESH] OR "radiology information systems"[MESH] OR "medical records systems, computerized"[MESH] OR "reminder systems"[MESH] OR decision*[All Fields] OR expert*[All Fields] OR computer*[All Fields] OR informatic*[All Fields] OR information system*[All Fields] OR reminder*[All Fields] OR artificial intelligence*[All Fields]

Subsearch 2: "diagnosis, computer-assisted"[MESH] OR "therapy, computer-assisted"[MESH] OR "drug therapy, computer-assisted"[MESH] OR "epidemiologic methods"[MESH] OR "disease outbreaks"[MESH] OR "disease reservoirs"[MESH] OR "disease transmission"[MESH] OR "drug contamination"[MESH] OR "endemic diseases"[MESH] OR "environmental medicine"[MESH] OR "environmental microbiology"[MESH] OR "environmental monitoring"[MESH] OR "inhalation exposure"[MESH] OR "food contamination"[MESH] OR "communicable disease control"[MESH] OR "mandatory reporting"[MESH] OR "mortuary practice"[MESH] OR "disease management"[MESH] OR diagnos*[All Fields] OR therap*[All Fields] OR drug*[All Fields] OR surveillance*[All Fields] OR manag*[All Fields] OR detect*[All Fields] OR outbreak*[All Fields] OR transmission*[All Fields] OR monitor*[All Fields] OR quarantine*[All Fields] OR isolat*[All Fields] OR exposure*[All Fields] OR contaminat*[All Fields] OR alert*[All Fields] OR emergency*[All Fields] OR report*[All Fields] OR decision making*[All Fields]

Subsearch 3: "bioterrorism"[MESH] OR "biological warfare"[MESH] OR "chemical warfare"[MESH] OR "bacterial infections and mycoses"[MESH] OR "virus diseases"[MESH] OR "parasitic diseases"[MESH] OR veterinar*[All Fields] OR coroner*[All Fields] OR military*[All Fields] OR bioterror*[All Fields] OR biowar*[All Fields] OR bacter*[All Fields] OR viral*[All Fields] OR virus*[All Fields] OR parasit*[All Fields] OR infectio*[All Fields] OR communicable*[All Fields]

Subsearch 4: "randomized controlled trial"[pt] OR "randomized controlled trials"[MESH] OR "Random allocation"[MESH] OR "double blind method"[MESH] OR "single blind method"[MESH] OR "comparative study"[MESH] OR "evaluation studies"[MESH] OR "follow up studies"[MESH] OR "prospective studies"[MESH] OR "longitudinal studies"[MESH] OR control*[Title/Abstract Word] OR prospectiv*[Title/Abstract Word] OR volunteer*[Title/Abstract Word] OR evaluation* [All Fields] OR stud* [All Fields] OR trial* [All Fields]

Final MEDLINE^®^ Search Strategy: Subsearch 1 AND Subsearch 2 AND Subsearch 3 AND Subsearch 4.

### Other Databases of Peer-reviewed Articles and Government Agency Web Site Search Strategy

We searched the NTIS database, The Catalog of U.S. Government Publications, GrayLIT, the Library of Congress database, and the Web sites of the government agencies listed in Table 1 with the following search terms:

1. bioterror* OR biological terror* OR biological warfare OR biodefense
2. database AND (1)
3. information technology AND (1)
4. decision support system
5. diagnosis AND (1)
6. public health AND (1)
7. surveillance AND (syndrome OR infectious disease)
8. communication AND (1)

If a search term returned more than 600 "hits," these Web sites were not screened because, on preliminary review, few "hits" were relevant in these cases.

### Internet Search Strategy

In our preliminary Internet searches for potentially relevant IT/DSSs using individual general search engines such as Google and Alta Vista, we found a great deal of redundancy in the retrieved sites. Therefore, our final Web-based search strategy used a metasearch engine that simultaneously searched multiple search engines with the purpose of ensuring a comprehensive search while minimizing overlap in retrieved Web sites. We tested a variety of potential metasearch engines including MetaCrawler^®^, Dogpile^®^, C4 TotalSearch^SM^ and Copernic^®^ 2001. We found that Copernic^®^ 2001 returned the greatest number of relevant Web sites for each search term. Copernic^®^ 2001 is a publicly available, Web-based metasearch engine (Copernic Technologies Inc., Québec, Canada) that is easily downloaded onto the user's computer. Its database feature facilitates saving multiple searches retrieved from over 80 general search engines. We used the same terms in our Copernic^®^ 2001 search as we did in our directed search of government agencies (see previous section).

## Abstract Review

One investigator reviewed each title to identify potentially relevant articles. If an article could not be excluded on the basis of its title, we then reviewed its abstract. We checked for agreement between reviewers after abstracting an initial set of titles and abstracts. We discussed all apparent systematic differences between the reviewers, and reached consensus on how to proceed with the kinds of articles that had caused the discrepancy. The reviewers then completed their independent reviews, meeting periodically to discuss articles about which they were uncertain.

## Data Abstraction

All retrieved articles were reviewed by one or more investigators to determine if they met inclusion criteria. All peer-reviewed articles meeting inclusion criteria were independently abstracted by 2 investigators blinded to study authors. Data abstracted from each article included whether the article presented an evaluation of the IT/DSS or just a description, information about the study design, information about the purpose of the IT/DSS, whether it was in clinical use at the time of the publication of the article, what modifications might enhance the IT/DSS's usefulness for bioterrorism response, and technical aspects of the IT/DSS's design including what kind of hardware platform it uses, whether it uses standard vocabularies, what kind of reasoning it uses, what security measures it has, and whether access to the system is restricted by user type. Appendix C contains the complete abstraction form.

For each article, one abstracter entered data onto an abstraction form created in Microsoft^®^ Access 2000 (form available upon request from authors) and the other abstracter entered the data onto a paper version of the abstraction form (Appendix C). The 2 abstracters then reviewed each datum entered and made corrections in the Microsoft^®^ Access database. Bibliographies of obtained articles were screened for additional, potentially relevant references. Given the large number of Web sites screened, information abstracted from materials obtained via Web searches was abstracted by only a single investigator directly onto the Access abstraction form. We frequently conferred about the information abstracted from the Web sites to ensure consistency of data abstraction from the Web-based sources.

## Development of Quality Evaluation Systems

We sought published criteria by which to evaluate the evidence collected from our searches. We found 2 systems: one set of criteria for evaluations of IT/DSSs used in clinical practice, and one set of criteria specifically for surveillance systems.

### Quality Evaluation for Reports of Evaluations of IT/DSSs for Detection, Diagnosis, Management, and Communication

The systematic reviews of the effects of IT/DSSs in clinical practice written by researchers at McMaster University used a scale that assessed 5 potential sources of bias in each of their included articles:^33, 34^

1. The method of allocation to study groups
  a. Random
  b. Quasi-random
  c. Selected concurrent controls
2. The unit of allocation
  a. Clinic
  b. Physician
  c. Patient
3. The presence of baseline differences between groups that were potentially linked to the study outcome
  a. No baseline differences or appropriate statistical adjustments made for differences
  b. Baseline difference present and no statistical adjustments made versus unable to assess
4. The type of outcome measure
  a. Objective outcome or subjective outcome with blinded assessment
  b. Subjective outcome with no blinding but clearly defined and explicit criteria for each outcome
  c. Subjective outcome with no blinding of assessors and no explicit criteria for each outcome
5. Completeness of followup
  a. Greater than 90 percent
  b. 80 to 90 percent
  c. Less than 80 percent

This scale includes all the relevant measures for evaluating the use of IT/DSSs in clinical practice. We included all of the McMaster criteria in our abstraction form (Appendix C).

### Quality Evaluation for Reports of Evaluations of Surveillance Systems

The Centers for Disease Control and Prevention (CDC) has published a guideline for evaluation of surveillance systems.^ 35 ^ It recommends that an evaluation of surveillance systems include the following:

1. A description of the public health importance of the health event
2. A description of the system under evaluation
3. An indication of the level of usefulness of the system
4. An evaluation of the system's simplicity
5. An evaluation of the system's flexibility
6. An evaluation of the system's acceptability
7. An evaluation of the system's sensitivity
8. An evaluation of the system's positive predictive value
9. An evaluation of the system's representativeness
10. An evaluation of the system's timeliness
11. A description of the direct costs needed to operate the system

This guideline is widely regarded as the standard by which surveillance systems should be evaluated. We included all of the CDC criteria in our abstraction form with the exception of cost because our preliminary reading of the literature suggested that almost none of the articles included in our systematic review included cost data (Appendix C).

## Reviews and Revisions of Draft Evidence Report

In December 2001, we sent a draft of the Report to our expert advisory panel (Appendix B) and to 17 additional reviewers (Appendix D) with expertise in nursing, clinical medicine, public health, hospital management, informatics, epidemiology, national security, toxicology, and food safety. We requested comments on all aspects of the Report, using a structured format developed by the University of California at San Francisco (UCSF) Cochrane Center. The submitted Report reflects revisions made based on this input.