# Appendix I. Index of Systems

In this table, we describe where in Chapter 3 (Results) and, if applicable, in which Evidence Table each system is discussed.

System name | Abbreviation | Section of Chapter 3: Results | Evidence table(s)
121 Cities Mortality Reporting System | | Surveillance Systems for Influenza
4WARN | | Integrated Collection and Identification Systems | 1
AAH Meditel United Kingdom General Practitioner Reporting System | | Surveillance Systems for Influenza | 5
ABDX | | Management/Treatment-Related Systems | 3
ABIX | | Management/Treatment-Related Systems | 3, 4
Active Bacterial Core Surveillance | ABCs | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data
Adenylate Kinase Phage Biosensor | AK Phage Biosensor | Rapid Identification Systems | 1
Advanced Nucleic Acid Analyzer/Handheld Advanced Nucleic Acid Analyzer | ANAA/HANAA | Rapid Identification Systems | 1
AMEBA biosensor | | Particulate Counters and Biomass Indicators | 1
Analyte 2000 | | Rapid Identification Systems | 1
Anthrax Sensor | | Rapid Identification Systems | 1
Antibiotic Assistant™ | | Management/Treatment-Related Systems | 3
Antibody-based Lateral Flow Economical Recognition Ticket | ALERT | Rapid Identification Systems | 1, 4
Arbeitsgemeinschaft Influenza Sentinel Surveillance System | AGI Sentinel Surveillance System | Surveillance Systems for Influenza
Associate for Public Health | | General Diagnostic DSSs
Australian Membrane and Biotechnology Research Institute Biosensor Technology | AMBRI Biosensor Technology | Rapid Identification Systems | 1
Australian National Animal Health Information System | Australian NAHIS | Zoonotic and Animal Disease Surveillance Systems
Automated Decision Aid System for Hazardous Incidents | ADASHI | Integrated Surveillance, Communication, Command and Control Systems
Automated Late-Arriving Results Monitoring System | ALARMS | Communication Systems | 4
BioCapture BT-550 | | Collection Systems | 1
Biolog | | Rapid Identification Systems | 1, 4
Biological Aerosol Sentry Information System | BASIS | Integrated Collection and Identification Systems | 1
Biological Agent Warning Sensor | BAWS | Integrated Collection and Identification Systems | 1
Biological Integrated Detection System | BIDS | Integrated Collection and Identification Systems | 1
Biosensor for E. coli | | Rapid Identification Systems | 1
Biothreat Active Surveillance Integrated Information and Communication System | BASIICS | Surveillance Systems Collecting Syndromal Reports
BioThreat Alert Strips | BTA™ Strips | Rapid Identification Systems | 1
BloodLink | | Other Diagnostic Systems | 2
Border Infectious Disease Surveillance Project | BIDS | Surveillance Systems Collecting Syndromal Reports
BOSS™ Computerized Surveillance System | | Surveillance Systems Collecting Hospital Infections Data | 5
Brigham Integrated Computing System | BICS | Communication Systems | 4
California Electronic Laboratory Disease Alert and Reporting System | (CELDAR) | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data
California Encephalitis Program | | Zoonotic and Animal Disease Surveillance Systems
California Influenza Surveillance Project | CISP | Surveillance Systems for Influenza
Canadian Integrated Biochemical Agent Detection System | CIBADS II | Integrated Collection and Identification Systems | 1
CDC Wonder/PC | | Communication Systems
CellChip™ | | Rapid Identification Systems | 1
Chemical/Biological Operational Decision Aid | CODA | Integrated Surveillance, Communication, Command and Control Systems
Clinical Data Repository | CDR | Surveillance Systems Collecting Hospital Infections Data | 5
Clinical DSS for detection and respiratory isolation of tuberculosis patients | | Other Diagnostic Systems | 2, 4
Clinical Event Manager | CEM | Communication Systems | 4
Columbia-Presbyterian Clinical Event Monitor | CEM | Management/Treatment-Related Systems | 3
Columbia-Presbyterian Medical Center Natural Language Processor | | Natural Language Processing System
Comprehensive Health Enhancement Support System | CHESS | Communication Systems
Computer program for diagnosing and teaching geographic medicine | | Other Diagnostic Systems | 2, 4
Computer-Assisted Infection Monitoring Program | CAI Monitoring Program | Surveillance Systems Collecting Hospital Infections Data | 5
Computerized Information System for Infectious Diseases | CISID | Communication Systems
Computerized Lab Alert System | CLAS | Communication Systems | 4
ComputerLink | | Communication Systems
Danish National Hospital Discharge Registry | | Surveillance Systems Collecting Hospital Infections Data | 5
Data Web | | Surveillance Systems Collecting Other Kinds of Data
Decentralized hospital computer program of the Veterans Administration Hospitals | DHCP of the VA Hospitals | Surveillance Systems Collecting Hospital Infections Data | 5
Déjà Vu | | Management/Treatment-Related Systems | 3, 4
DOD Biological Sampling Kit | DOD BSK | Rapid Identification Systems | 1
DOD Influenza Surveillance Program (formerly known as Project Gargle) | | Surveillance Systems for Influenza
Deployable Radiology System | DEPRAD | Diagnostic Systems Using Telemedicine
DERMIS | | Other Diagnostic Systems | 2, 4
Detection Algorithm using Syndromal Classification | | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data | 5
DiagnosisPro^®^ | | General Diagnostic DSSs
Dialysis Surveillance Network | DSN | Surveillance Systems Collecting Other Kinds of Data
Digital Smell/Electronic Nose | | Particulate Counters and Biomass Indicators | 1, 4
Disease Early Warning System | DEWS | Surveillance Systems Collecting Other Kinds of Data
DNA Biochip | | Rapid Identification Systems | 1
Dutch Medimatica Influenza System | | Surveillance Systems for Influenza | 5
DXplain™ | | General Diagnostic DSSs | 4
Early Warning Outbreak Recognition System | EWORS | Surveillance Systems Collecting Syndromal Reports | 5
Eindhoven Automated Knowledge Acquisition Tool | | Management/Treatment-Related Systems | 3
Electronic Communicable Disease Reporting System | ECDRS | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data
Electronic Foodborne Outbreak Reporting System | EFORS | Communication Systems
Electronic Surveillance System for the Early Notification of Community-Based Epidemics | ESSENCE | Surveillance Systems Collecting Syndromal Reports
EMERGEncy ID NET | | Surveillance Systems Collecting Clinical Reports | 5
Emergency Medical Alert Network | EMAN | Management/Treatment-Related Systems | 3
Emerging Infections Network | EIN | Communication Systems
Emerging Pathogens Initiative | EPI | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data
EMSystem/EMSurvey | | Communication Systems
Enter-Net (formerly known as Salm-Net) | | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data
Epidemic Information Exchange | EPI-X | Communication Systems
EPIFAR | | Surveillance Systems Collecting Other Kinds of Data
EpiMAN-FMD | | Zoonotic and Animal Disease Surveillance Systems | 5
EpiMAN-SF | | Zoonotic and Animal Disease Surveillance Systems | 5
ePocrates Rx/ePocrates ID | | Communication Systems
European Influenza Surveillance Scheme (formerly CareTelematics) | EISS | Surveillance Systems for Influenza | 5
Eurosentinel | | Surveillance Systems Collecting Clinical Reports | 5
EUROTB | | Surveillance Systems Collecting Clinical Reports
Fiber Optic Wave Guide | FOWG | Rapid Identification Systems | 1
Field Kit for Rapid Detection of Anthrax | | Rapid Identification Systems | 1
Fluorescence Aerodynamic Particle Sizer-1 | FLAPS-1 | Particulate Counters and Biomass Indicators | 1
Fluorescence Aerodynamic Particle Sizer-2 | FLAPS-2 | Particulate Counters and Biomass Indicators | 1
Fluorescence-based Array Immunosensor | | Rapid Identification Systems | 1, 4
Food and Animal Residue Avoidance Databank | FARAD | Disease Surveillance of Foodborne Illnesses
Foodborne Diseases Active Surveillance Network | FoodNet | Disease Surveillance of Foodborne Illnesses | 5
French Communicable Diseases Computer Network, also known as the French Sentinel System or SentiWeb | FCDN | Surveillance Systems Collecting Clinical Reports | 5
Fuzzy logic program to predict source of bacterial infection | | Other Diagnostic Systems | 2, 4
GeneChip^®^ | | Rapid Identification Systems | 1
GeneXpert™ | | Rapid Identification Systems | 1
GermWatcher | | Surveillance Systems Collecting Hospital Infections Data | 5
Global Emerging Infections Sentinel Network | GeoSentinel | Surveillance Systems Collecting Clinical Reports
Global Infectious Disease and Epidemiology Network | GIDEON | Other Diagnostic Systems | 2, 4
Global Public Health Information Network | GPHIN | Surveillance Systems Collecting Other Kinds of Data
Global Salm-Surv | GSS | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data
Haemsept | | Surveillance Systems Collecting Hospital Infections Data | 5
Handheld Immunochromatographic Assays | HHA | Rapid Identification Systems | 1
HAWK | | Surveillance Systems Collecting Other Kinds of Data
Healinx | | Communication Systems
Health Alert Network | HAN | Communication Systems
Health Buddy^®^ | | Surveillance Systems Collecting Syndromal Reports
Health Evaluation through Logical Processing | HELP | Management/Treatment-Related Systems; also Natural Language Processing Systems (as SymText) and Surveillance Systems Collecting Hospital Infections Data (as LDS DMSS) | 3, 4, 5
HEALTHCOM | | Communication Systems
Henri Mondor University Hospital Clinical Information System | | Surveillance Systems Collecting Hospital Infections Data | 5
Hospital Infection Standardized Surveillance | HISS | Surveillance Systems Collecting Hospital Infections Data | 5
ICONS | | Management/Treatment-Related Systems | 3
Iliad | | General Diagnostic DSSs | 4
Indianapolis Network for Patient Care | INPC | Communication Systems
Information Network for Public Health Officials | INPHO | Communication Systems
Intelligent Decision Aid System for ICU/NICU | IDEAS for ICU/NICU | Management/Treatment-Related Systems | 3, 4
Intensive Care Antimicrobial Resistance Epidemiology | ICARE | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data
Interim Biological Agent Detector | IBAD | Particulate Counters and Biomass Indicators | 1
International Network for the Study and Prevention of Emerging Antimicrobial Resistance | INSPEAR | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data
International Office of Epizootics | International OIE | Zoonotic and Animal Disease Surveillance Systems
Joint Biological Point Detection System | JBPDS | Integrated Collection and Identification Systems | 1
Joint Biological Remote Early Warning System | JBREWS | Integrated Collection and Identification Systems | 1
Joint Service Warning And Reporting Network | JWARN | Integrated Collection and Identification Systems | 1
Joint United Nations Environment Programme (UNEP)/Food and Agriculture Group of the United Nations (FAO)/WHO Food Contamination Monitoring Programme | | Disease Surveillance of Foodborne Illnesses
Knowledge-based information network Giessen | WING | Surveillance Systems Collecting Hospital Infections Data | 5
Laboratory Information Tracking System | LITS | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data
Laboratory Response Network | | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data | 5
LandScan | | Integrated Surveillance, Communication, Command and Control Systems
LDS Data Mining Surveillance System (part of HELP) | LDS DMSS | Surveillance Systems Collecting Hospital Infections Data; also Management/Treatment-Related Systems (as part of HELP) | 5
LightCycler™ | | Rapid Identification Systems | 1
Lightweight Epidemiology and Advanced Detection and Emergency Response System (formerly known as the Enhanced Surveillance Project (ESP) or ENCOMPASS) | LEADERS | Rapid Identification Systems; Surveillance Systems Collecting Syndromal Reports | 1
Long Range Biological Standoff Detection System | LR-BSDS | Particulate Counters and Biomass Indicators | 1
Luminometer | | Rapid Identification Systems | 1, 4
Medcast | | Communication Systems | 4
Medical Historian | | Surveillance Systems Collecting Other Kinds of Data | 5
Medical HouseCall | | Diagnostic | 5
MEDTRAK | | Management/Treatment-Related Systems | 3, 4
MERMAID | | Diagnostic Systems Using Telemedicine
Meteorological Information and Dispersion Assessment System Anti-Terrorism | MIDAS-AT | Integrated Surveillance, Communication, Command and Control Systems | 1
Met One Aerocet 531 Mass/Particle Counter | | Particulate Counters and Biomass Indicators | 1
MicroArray of Gel Immobilized Compounds on a Chip | MAGIChip™ | Rapid Identification Systems | 1
Military Public Health Laboratories | | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data
MiniFlo | | Rapid Identification Systems | 1
Minnesota Microbiology Information System | | Communication Systems | 4
Mobile Atmospheric And Sampling Identification Facility | MASIF | Integrated Collection and Identification Systems | 1
Mobile Operational Support System | MOSS | Diagnostic Systems Using Telemedicine | 4
Model 3312A Ultraviolet Aerodynamic Particle Sizer (UV-APS) | UV-APS | Particulate Counters and Biomass Indicators | 1
Model 3321 Aerodynamic Particle Sizer Spectrometer (APS 3321) | APS 3321 | Particulate Counters and Biomass Indicators | 1
Motorola Emergency Medical Communications System | | Communication Systems
Multi-Purpose Integrated Chemical Agent Alarm | MICAD | Integrated Collection and Identification Systems | 1
National Animal Health Monitoring System | NAHMS | Zoonotic and Animal Disease Surveillance Systems
National Antimicrobial Resistance Monitoring System | NARMS | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data
National Electronic Telecommunications System for Surveillance (formerly known as the Epidemiologic Surveillance Project (ESP)) | NETSS | Surveillance Systems Collecting Clinical Reports | 5
National Flu Surveillance Network | NFSN | Surveillance Systems for Influenza
National Guideline Clearinghouse™ | NGC | Communication Systems
National Molecular Subtyping Network for Foodborne Disease Surveillance | PulseNet | Disease Surveillance of Foodborne Illnesses
National Nosocomial Infections Surveillance System | NNIS System | Surveillance Systems Collecting Hospital Infections Data
National Respiratory and Enteric Virus Surveillance System | NREVSS | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data
National Surveillance System for Healthcare Workers | NaSH | Surveillance Systems Collecting Other Kinds of Data
National Tuberculosis Genotyping and Surveillance Network | | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data
National West Nile Virus Surveillance System | ArboNet | Zoonotic and Animal Disease Surveillance Systems
Netherlands National Institute of Public Health and the Environment Surveillance System | | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data | 5
Neural Network for Diagnosing Tuberculosis | | Other Diagnostic Systems | 2, 4
New York State Department of Health's Bureau of Community Sanitation and Food Protection | N. Y. State Department of Health's BCSFP | Disease Surveillance of Foodborne Illnesses | 5
NexProfiler | | Management/Treatment-Related Systems | 3
Nitric Oxide Sensor | NO sensor | Rapid Identification Systems | 1
Nuclear-biological-chemical Analysis | NBC Analysis | Integrated Surveillance, Communication, Command and Control Systems
Nuclear-biological-chemical Command and Control | NBC Command and Control | Integrated Surveillance, Communication, Command and Control Systems
Nuclear-biologic-chemical Field Laboratory | NBC Field Laboratory | Integrated Collection and Identification Systems | 1
Optical fluorescence biosensor technique | | Rapid Identification Systems
Peace Corps Surveillance | | Surveillance Systems Collecting Other Kinds of Data | 5
PM10 | | Particulate Counters and Biomass Indicators | 1
PNEUMON-IA | | Other Diagnostic Systems | 2
Pneumonia Therapy Advisor | PTA | Management/Treatment-Related Systems | 3, 4
Portable Biofluorosensor | PBS | Particulate Counters and Biomass Indicators | 1
Portable High-Throughput Liquid Aerosol Air Sampler System | PHTLAAS | Collection Systems | 1
Portal Shield Air Base/Port Biological Detection System | | Integrated Collection and Identification Systems | 1
Problem-Knowledge Couplers^®^ | | General Diagnostic DSSs
Program for Monitoring Emerging Infectious Diseases | ProMED | Communication Systems | 4
Program for Response Options and Technology Enhancements for Chemical/Biological Terrorism | PROTECT | Particulate Counters and Biomass Indicators | 1
Public Health Laboratory Information System | PHLIS | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data | 5
Public Health Laboratory Service Communicable Disease Surveillance Centre | PHLS CDSC | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data
Pyrolysis-gas Chromatography-ion Mobility Spectrometer | PY-GC-IMS | Rapid Identification Systems | 1
QID | | Management/Treatment-Related Systems | 3, 4
Quick Medical Reference | QMR | General Diagnostic DSSs | 3, 4
Rabin Medical Center Antibiotic DSS | | Management/Treatment-Related Systems | 3, 4
Rapid Automatic and Portable Fluorometer Assay System | RAPTOR | Rapid Identification Systems | 1
Rapid Emergency Digital Data Information Network | ReddiNet^®^ | Communication Systems
Rapid Syndrome Validation Project | RSVP^®^ | Surveillance Systems Collecting Syndromal Reports
RealTime BioSensor™ | | Rapid Identification Systems | 1
Regional Influenza Surveillance Group | GROG | Surveillance Systems for Influenza | 5
RHEACT | | Communication Systems
Ruggedized Advanced Pathogen Identification Device | RAPID™ | Rapid Identification Systems | 1
Systematic Approach for Emergency Response Real-Time System | SAFER^®^ Real-Time System | Integrated Surveillance, Communication, Command and Control Systems
Salmonella Data Bank | SDB | Disease Surveillance of Foodborne Illnesses
Salmonella Outbreak Detection Algorithm | SODA | Disease Surveillance of Foodborne Illnesses
Salmonella Potential Outbreak Targeting System, also known as the National Enteric Pathogens Surveillance Scheme (NEPSS) and formerly known as the National Salmonella Surveillance Scheme | SPOT | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data | 5
Sensitive Membrane Antigen Rapid Test | SMART™ | Rapid Identification Systems | 1, 4
SENTRY | | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data | 5
Severity Scores for Community-acquired Pneumonia | | Management/Treatment-Related Systems | 3, 4
Short-range Biological Standoff Detection System | SR-BSDS | Particulate Counters and Biomass Indicators | 1
Single Particle Fluorescence Counter | SPFC | Particulate Counters and Biomass Indicators | 1
Smart Air Sampler 2000 Plus Chem-Bio Air Sampler | SASS 2000 | Collection Systems | 1
SmartCycler^®^ | | Rapid Identification Systems | 1
SpinCon^®^ | | Collection Systems | 1
Spreeta | | Particulate Counters and Biomass Indicators | 1
Stepwise and Interactive Evaluation of Food safety by an Expert System | SIEFE | Disease Surveillance of Foodborne Illnesses
Surveillance for Emerging Antimicrobial Resistance Connected to Healthcare | SEARCH | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data
SymText (part of HELP) | | Natural Language Processing System | 4
Syndromal Surveillance Tally Sheet | | Surveillance Systems Collecting Syndromal Reports
TEsting COMpetency | TECOM | Management/Treatment-Related Systems | 3
Texas Infectious Disease Diagnostic DSS | | Other Diagnostic Systems | 2, 4
The Royal Hospitals' Automated Infection Surveillance System | | Surveillance Systems Collecting Hospital Infections Data | 5
The Surveillance Network™ Database-USA | TSN™ Database-USA | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data | 5
Tissue-Based Biological Sensor | TBBS | Rapid Identification Systems | 1
Traveler's Diarrhea Network | | Surveillance Systems Collecting Other Kinds of Data | 5
Tucson VA Nosocomial Infection Surveillance System | | Surveillance Systems Collecting Hospital Infections Data | 5
U.K. Food Micromodel | | Disease Surveillance of Foodborne Illnesses
Unexplained Deaths and Critical Illnesses Surveillance System | | Surveillance Systems Collecting Other Kinds of Data
University of Alabama Data Mining Surveillance System | University of Alabama DMSS | Surveillance Systems Collecting Hospital Infections Data | 5
University of Chicago - Artificial Neural Network for Interstitial Lung Disease | | Radiologic Interpretation Systems
University of Chicago - Computer Aided Diagnosis of Interstitial Lung Disease | | Radiologic Interpretation Systems | 4
University of Iowa Hospitals and Clinics Program of Hospital Epidemiology Surveillance System | UIHC PHE Surveillance System | Surveillance Systems Collecting Hospital Infections Data | 5
Upconverting Phosphor Technology | UPT | Rapid Identification Systems | 1
U.S. Influenza Sentinel Physicians Surveillance Network | | Surveillance Systems for Influenza
Utrecht Emergency Hospital Patient Barcode Registration System | PBR | Management/Treatment-Related Systems | 3, 4
Vertical Cavity Surface Emitting Laser | VCSEL | Particulate Counters and Biomass Indicators | 1
Walter Reed Army Medical Center Telemedicine Service | WRAMC Telemedicine Service | Diagnostic Systems Using Telemedicine | 4
WHO Influenza Surveillance (also known as FluNet) | | Surveillance Systems for Influenza | 5
WHO Surveillance Program for the Control of Foodborne Infections and Intoxicants in Europe | | Disease Surveillance of Foodborne Illnesses
WHONET | | Surveillance Systems Collecting Laboratory Data and Antimicrobial Data | 5
XM2 | | Particulate Counters and Biomass Indicators | 1
Your Practice Online | | Communication Systems