# Appendix H. Sources of Information for Included IT/DSSs

System name | Type of system | Peer-reviewed articles | | Government reports | Web sites | | Other ^a^
System name | Type of system | Evaluation | Description | Government reports | Government | Non-government | Other ^a^
121 Cities Mortality Reporting System | Surveillance (Influenza) | 0 | 0 | 0 | 2 | 0 | 0
4WARN - PLEASE SEE Canadian Integrated Biochemical Agent Detection System (CIBADS II)
AAH Meditel United Kingdom General Practitioner Reporting System | Surveillance (Influenza) | 1 | 0 | 0 | 0 | 0 | 0
ABDX | Management | 0 | 0 | 0 | 0 | 0 | 1
ABIX | Management | 1 | 0 | 0 | 0 | 0 | 0
Active Bacterial Core Surveillance (ABCs) | Surveillance (Laboratory) | 0 | 0 | 0 | 3 | 0 | 0
Adenylate Kinase (AK) Phage Biosensor | Identification | 0 | 0 | 0 | 0 | 0 | 2
Advanced Nucleic Acid Analyzer (ANAA)/Handheld Advanced Nucleic Acid Analyzer (HANAA) | Identification | 0 | 1 | 0 | 0 | 0 | 0
AMEBA biosensor | Particulate Counters and Biomass Indicators | 0 | 0 | 0 | 0 | 2 | 0
Analyte 2000: PLEASE SEE Fiber Optic Wave Guide (FOWG)
Anthrax Sensor | Identification | 0 | 0 | 0 | 0 | 1 | 0
Antibiotic Assistant | Management | 0 | 0 | 0 | 0 | 1 | 0
Antibody-based Lateral Flow Economical Recognition Ticket (ALERT) - PLEASE SEE Sensitive Membrane Antigen Rapid Test (SMART™)
Arbeitsgemeinschaft (AGI) Influenza Sentinel Surveillance System | Surveillance (Influenza) | 0 | 1 | 0 | 0 | 0 | 0
Associate for Public Health | Diagnostic | 0 | 0 | 0 | 0 | 1 | 0
Australian Membrane and Biotechnology Research Institute (AMBRI) Biosensor Technology | Identification | 0 | 0 | 0 | 1 | 1 | 0
Australian National Animal Health Information System (NAHIS) | Surveillance (Zoonotic/Animal Disease) | 0 | 1 | 0 | 0 | 0 | 0
Automated Decision Aid System for Hazardous Incidents (ADASHI) | Integrated surveillance, communication, and command and control | 0 | 0 | 0 | 1 | 0 | 0
Automated Late-Arriving Results Monitoring System (ALARMS) | Communication | 1 | 0 | 0 | 0 | 0 | 0
BioCapture BT-550 | Collection | 0 | 0 | 0 | 0 | 1 | 0
Biolog | Identification | 1 | 0 | 0 | 0 | 0 | 0
Biological Aerosol Sentry Information System | Integrated Collection/Identification | 0 | 0 | 0 | 1 | 0 | 0
Biological Agent Warning Sensor (BAWS)/Joint Biological Point Detection System (JBPDS) | Integrated Collection/Identification | 0 | 1 | 1 | 1 | 2 | 1
Biological Integrated Detection System (BIDS) | Integrated Collection/Identification | 0 | 0 | 2 | 0 | 1 | 1
Biosensor for E. coli | Identification | 0 | 1 | 0 | 0 | 0 | 1
Biothreat Active Surveillance Integrated Information and Communication System (BASIICS) - PLEASE SEE Health Buddy
BioThreat Alert (BTA) Strips | Identification | 0 | 0 | 0 | 0 | 1 | 0
BloodLink | Diagnostic | 0 | 1 | 0 | 0 | 0 | 0
Border Infectious Disease Surveillance Project (BIDS) | Surveillance (Syndromal) | 0 | 1 | 0 | 1 | 0 | 0
BOSS™ Computerized Surveillance System | Surveillance (Hospital) | 0 | 1 | 0 | 0 | 0 | 0
Brigham Integrated Computing System (BICS) | Communication | 2 | 0 | 0 | 0 | 0 | 0
California Electronic Laboratory Disease Alert and Reporting System (CELDAR) | Surveillance (Laboratory) | 0 | 0 | 1 | 0 | 0 | 0
California Encephalitis Program | Surveillance (Zoonotic/Animal disease) | 0 | 0 | 1 | 0 | 0 | 0
California Influenza Surveillance Project | Surveillance (Influenza) | 0 | 0 | 0 | 1 | 0 | 0
Canadian Integrated Biochemical Agent Detection System (CIBADS II)/4WARN | Integrated Collection/Identification | 0 | 0 | 0 | 1 | 1 | 0
CDC Wonder/PC | Communication | 0 | 2 | 0 | 1 | 0 | 0
CellChip | Identification | 0 | 0 | 1 | 0 | 1 | 1
Chemical/Biological Operational Decision Aid (CODA) | Integrated surveillance, communication, and command and control | 0 | 0 | 0 | 0 | 1 | 0
Clinical Data Repository (CDR) | Surveillance (Hospital) | 1 | 0 | 0 | 0 | 0 | 0
Clinical DSS for detection and respiratory isolation of tuberculosis patients | Diagnostic | 1 | 0 | 0 | 0 | 0 | 0
Clinical Event Manager (CEM) | Communication | 1 | 0 | 0 | 0 | 0 | 0
Columbia-Presbyterian Clinical Event Monitor (CEM) | Management | 0 | 1 | 0 | 0 | 0 | 0
Columbia-Presbyterian Medical Center Natural Language Processor | Diagnostic | 0 | 1 | 0 | 0 | 0 | 0
Comprehensive Health Enhancement Support System (CHESS) | Communication | 0 | 2 | 0 | 0 | 0 | 0
Computer program for diagnosing and teaching geographic medicine | Diagnostic | 1 | 0 | 0 | 0 | 0 | 0
Computer-Assisted Infection (CAI) Monitoring Program | Surveillance (Hospital) | 1 | 0 | 0 | 0 | 0 | 0
Computerized Information System for Infectious Diseases (CISID) | Communication | 0 | 0 | 0 | 0 | 1 | 0
Computerized Lab Alert System (CLAS) | Communication | 1 | 0 | 0 | 0 | 0 | 0
ComputerLink | Communication | 0 | 1 | 0 | 0 | 0 | 0
Danish National Hospital Discharge Registry | Surveillance (Hospital) | 1 | 0 | 0 | 0 | 0 | 0
Data Web | Surveillance (Other) | 0 | 0 | 0 | 1 | 0 | 0
Decentralized hospital computer program (DHCP) of the VA Hospitals | Surveillance (Hospital) | 0 | 1 | 0 | 0 | 0 | 0
Déjà Vu | Management | 1 | 0 | 0 | 0 | 0 | 0
DOD Biological Sampling Kit (BSK) | Identification | 0 | 1 | 0 | 0 | 0 | 0
DOD Influenza Surveillance Program (formerly known as Project Gargle) | Surveillance (Influenza) | 0 | 1 | 1 | 1 | 0 | 0
Deployable Radiology System (DEPRAD) | Diagnostic | 0 | 1 | 0 | 0 | 0 | 0
DERMIS | Diagnostic | 1 | 1 | 0 | 0 | 0 | 0
Detection Algorithm using Syndromal Classification | Surveillance (Laboratory) | 1 | 1 | 0 | 0 | 0 | 0
DiagnosisPro | Diagnostic | 0 | 0 | 0 | 0 | 2 | 0
Dialysis Surveillance Network (DSN) | Surveillance (Other) | 0 | 0 | 0 | 1 | 0 | 0
Digital Smell/Electronic Nose | Particulate Counters and Biomass Indicators | 1 | 0 | 0 | 0 | 1 | 0
Disease Early Warning System (DEWS) | Surveillance (Other) | 0 | 0 | 0 | 0 | 0 | 2
DNA Biochip | Identification | 0 | 0 | 0 | 0 | 0 | 1
Dutch Medimatica Influenza System | Surveillance (Influenza) | 1 | 0 | 0 | 0 | 0 | 0
DXplain™ | Diagnostic | 1 | 2 | 0 | 0 | 1 | 1
Early Warning Outbreak Recognition System (EWORS) | Surveillance (Syndromal) | 0 | 1 | 1 | 0 | 0 | 0
Eindhoven Automated Knowledge Acquisition Tool | Management | 0 | 1 | 0 | 0 | 0 | 0
Electronic Communicable Disease Reporting System (ECDRS) | Surveillance (Laboratory) | 1 | 0 | 0 | 0 | 0 | 0
Electronic Foodborne Outbreak Reporting System (EFORS) | Communication | 0 | 0 | 0 | 1 | 0 | 0
Electronic Surveillance System for the Early Notification of Community-Based Epidemics (ESSENCE) | Surveillance (Syndromal) | 0 | 0 | 1 | 0 | 0 | 0
EMERGEncy ID NET | Surveillance (Clinical) | 0 | 2 | 0 | 0 | 0 | 0
Emergency Medical Alert Network (EMAN) | Management | 0 | 0 | 0 | 1 | 0 | 1
Emerging Infections Network (EIN) | Communication | 0 | 2 | 0 | 0 | 0 | 0
Emerging Pathogens Initiative (EPI) | Surveillance (Laboratory) | 0 | 0 | 1 | 0 | 0 | 2
EMSystem/EMSurvey | Communication | 0 | 0 | 0 | 0 | 1 | 0
Enter-Net (formerly known as Salm-Net) | Surveillance (Antimicrobial) | 0 | 0 | 0 | 1 | 0 | 1
Epidemic Information Exchange (EPI-X) | Communication | 0 | 0 | 0 | 1 | 0 | 0
EPIFAR | Surveillance (Other) | 0 | 1 | 0 | 0 | 0 | 0
EpiMAN-FMD/EpiMAN-SF | Surveillance (Zoonotic/Animal disease) | 0 | 3 | 0 | 0 | 0 | 0
EpiMAN-SF: PLEASE SEE EpiMAN-FMD
EPOCRATES Rx/ID | Communication | 0 | 0 | 0 | 0 | 1 | 0
European Influenza Surveillance Scheme (EISS) (formerly CareTelematics) | Surveillance (Influenza) | 0 | 3 | 0 | 0 | 0 | 0
Eurosentinel | Surveillance (Clinical) | 0 | 1 | 0 | 0 | 0 | 0
EUROTB | Surveillance (Clinical) | 0 | 1 | 0 | 0 | 1 | 1
Fiber Optic Wave Guide (FOWG)/Rapid Automatic and Portable Fluorometer Assay System (RAPTOR)/Analyte 2000 | Identification | 0 | 1 | 1 | 0 | 5 | 0
Field Kit for Rapid Detection of Anthrax | Identification | 0 | 0 | 0 | 1 | 0 | 0
Fluorescence Aerodynamic Particle Sizer (FLAPS-1): PLEASE SEE Model 3321 Aerodynamic Particle Sizer Spectrometer
Fluorescence Aerodynamic Particle Sizer-2 (FLAPS-2): PLEASE SEE Model 3312A Ultraviolet Aerodynamic Particle Sizer (UV-APS)
Fluorescence-based Array Immunosensor | Identification | 1 | 0 | 0 | 0 | 0 | 0
Food and Animal Residue Avoidance Databank (FARAD) | Surveillance (Foodborne Illnesses) | 0 | 2 | 0 | 0 | 0 | 0
Foodborne Diseases Active Surveillance Network (FoodNet) | Surveillance (Foodborne Illnesses) | 3 | 3 | 1 | 0 | 0 | 0
French Communicable Diseases Computer Network (FCDN), also known as the French Sentinel System or SentiWeb | Surveillance (Clinical) | 4 | 8 | 0 | 0 | 1 | 0
Fuzzy logic program to predict source of bacterial infection | Diagnostic | 1 | 0 | 0 | 0 | 0 | 0
GeneChip^®^ | Identification | 0 | 0 | 0 | 0 | 1 | 1
GeneXpert™: PLEASE SEE SmartCycler
GermWatcher | Surveillance (Hospital) | 1 | 3 | 0 | 0 | 0 | 0
Global Emerging Infections Sentinel Network (GeoSentinel) | Surveillance (Clinical) | 0 | 0 | 0 | 0 | 2 | 0
Global Infectious Disease and Epidemiology Network (GIDEON) | Diagnostic | 1 | 0 | 0 | 0 | 0 | 0
Global Public Health Information Network (GPHIN) | Surveillance (Other) | 0 | 1 | 0 | 0 | 0 | 0
Global Salm-Surv (GSS) | Surveillance (Antimicrobial) | 0 | 0 | 0 | 0 | 1 | 1
Haemsept | Surveillance (Hospital) | 1 | 0 | 0 | 0 | 0 | 0
Handheld Advanced Nucleic Acid Analyzer (HANAA): PLEASE SEE Advanced Nucleic Acid Analyzer (ANAA)
Handheld Immunochromatographic Assays (HHA) | Identification | 0 | 0 | 1 | 0 | 0 | 1
HAWK | Surveillance (Other) | 0 | 0 | 0 | 1 | 0 | 1
Healinx | Communication | 0 | 0 | 0 | 0 | 1 | 0
Health Alert Network (HAN) | Communication | 0 | 0 | 0 | 2 | 0 | 0
Health Buddy/Biothreat Active Surveillance Integrated Information and Communication System (BASIICS) | Surveillance (Syndromal) | 0 | 0 | 0 | 0 | 1 | 0
Health Evaluation through Logical Processing (HELP) | Management | 27 | 12 | 0 | 0 | 0 | 0
HEALTHCOM | Communication | 0 | 2 | 0 | 0 | 0 | 0
Henri Mondor University Hospital Clinical Information System | Surveillance (Hospital) | 0 | 2 | 0 | 0 | 0 | 0
Hospital Infection Standardized Surveillance (HISS) | Surveillance (Hospital) | 1 | 1 | 0 | 0 | 0 | 0
ICONS | Management | 0 | 2 | 0 | 0 | 0 | 0
Iliad | Diagnostic | 1 | 3 | 0 | 0 | 1 | 0
Indianapolis Network for Patient Care (INPC) | Communication | 0 | 1 | 0 | 0 | 0 | 0
Information Network for Public Health Officials (INPHO) | Communication | 0 | 2 | 0 | 0 | 0 | 0
Intelligent Decision Aid System (IDEAS) for ICU/NICU | Management | 1 | 0 | 0 | 0 | 0 | 0
Intensive Care Antimicrobial Resistance Epidemiology (ICARE) | Surveillance (Antimicrobial) | 0 | 0 | 0 | 0 | 1 | 0
Interim Biological Agent Detector (IBAD) | Particulate Counters and Biomass Indicators | 0 | 1 | 2 | 0 | 1 | 1
International Network for the Study and Prevention of Emerging Antimicrobial Resistance (INSPEAR) | Surveillance (Antimicrobial) | 0 | 1 | 0 | 1 | 0 | 0
International Office of Epizootics (OIE) | Surveillance (Zoonotic/Animal disease) | 0 | 2 | 0 | 0 | 0 | 0
Joint Biological Point Detection System (JBPDS): PLEASE SEE Biological Agent Warning Sensor (BAWS)
Joint Biological Remote Early Warning System (JBREWS) | Integrated Collection/Identification | 0 | 0 | 0 | 0 | 0 | 1
Joint Service Warning And Reporting Network (JWARN) | Integrated Collection/Identification | 0 | 0 | 2 | 0 | 0 | 0
Joint UNEP/FAO/WHO Food Contamination Monitoring Programme | Surveillance (Foodborne Illnesses) | 0 | 1 | 0 | 0 | 0 | 0
Knowledge-based information network Giessen (WING) | Surveillance (Hospital) | 0 | 1 | 0 | 0 | 0 | 0
Laboratory Information Tracking System (LITS) | Surveillance (Antimicrobial) | 0 | 1 | 0 | 0 | 0 | 0
Laboratory Response Network | Surveillance (Laboratory) | 0 | 1 | 0 | 0 | 0 | 0
LandScan | Integrated surveillance, communication, and command and control | 0 | 0 | 0 | 1 | 0 | 1
LDS Data Mining Surveillance System (DMSS) (part of HELP) | Surveillance (Hospital) (see Management) | 1 | 1 | 0 | 0 | 0 | 0
LightCycler™/Ruggedized Advanced Pathogen Identification Device (RAPID™)/Lightweight Epidemiology and Advanced Detection and Emergency Response System (LEADERS) | Identification | 0 | 0 | 0 | 0 | 1 | 0
Lightweight Epidemiology and Advanced Detection and Emergency Response System (LEADERS) (formerly known as the Enhanced Surveillance Project (ESP) or ENCOMPASS) | Surveillance (Syndromal) | 0 | 0 | 0 | 0 | 1 | 0
Long Range Biological Standoff Detection System (LR-BSDS) | Particulate Counters and Biomass Indicators | 0 | 0 | 2 | 0 | 1 | 1
Luminometer | Identification | 1 | 0 | 0 | 0 | 0 | 0
Medcast | Communication | 1 | 0 | 0 | 0 | 0 | 0
Medical Historian | Surveillance (Other) | 1 | 0 | 0 | 0 | 0 | 0
MEDTRAK | Management | 1 | 0 | 0 | 0 | 0 | 0
MERMAID | Diagnostic | 0 | 3 | 0 | 0 | 0 | 0
Meteorological Information and Dispersion Assessment System Anti-Terrorism (MIDAS-AT) | Integrated surveillance, communication, and command and control | 0 | 0 | 0 | 1 | 1 | 0
Met One Aerocet 531 Mass/Particle Counter | Particulate Counters and Biomass Indicators | 0 | 0 | 1 | 0 | 1 | 0
MicroArray of Gel Immobilized Compounds on a Chip (MAGIChip) | Identification | 0 | 0 | 1 | 0 | 0 | 2
Military Public Health Laboratories | Surveillance (Antimicrobial) | 0 | 1 | 0 | 0 | 0 | 0
MiniFlo | Identification | 0 | 0 | 0 | 0 | 0 | 2
Minnesota Microbiology Information System | Communication | 1 | 0 | 0 | 0 | 0 | 0
Mobile Atmospheric And Sampling Identification Facility (MASIF) | Integrated Collection/Identification | 0 | 0 | 0 | 1 | 0 | 0
Mobile Operational Support System (MOSS) | Diagnostic | 1 | 0 | 0 | 0 | 0 | 0
Model 3312A Ultraviolet Aerodynamic Particle Sizer (UV-APS)/Fluorescence Aerodynamic Particle Sizer-2 (FLAPS-2) | Particulate Counters and Biomass Indicators | 0 | 0 | 1 | 1 | 2 | 1
Model 3321 Aerodynamic Particle Sizer Spectrometer/Fluorescence Aerodynamic Particle Sizer (APS 3321/FLAPS-1) | Particulate Counters and Biomass Indicators | 0 | 0 | 2 | 0 | 3 | 1
Motorola Emergency Medical Communications System | Communication | 0 | 0 | 0 | 0 | 1 | 0
Multi-Purpose Integrated Chemical Agent Alarm (MICAD) | Integrated Collection/Identification | 0 | 0 | 0 | 0 | 0 | 1
National Animal Health Monitoring System (NAHMS) | Surveillance (Zoonotic/Animal disease) | 0 | 4 | 0 | 0 | 0 | 0
National Antimicrobial Resistance Monitoring System (NARMS) | Surveillance (Antimicrobial) | 0 | 0 | 0 | 1 | 0 | 0
National Electronic Telecommunications System for Surveillance (NETSS) (formerly known as the Epidemiologic Surveillance Project (ESP)) | Surveillance (Clinical) | 1 | 3 | 0 | 0 | 0 | 0
National Flu Surveillance Network (NFSN) | Surveillance (Influenza) | 0 | 0 | 0 | 0 | 1 | 0
National Guideline Clearinghouse™ (NGC) | Communication | 0 | 0 | 0 | 0 | 1 | 0
National Molecular Subtyping Network for Foodborne Disease Surveillance (PulseNet) | Surveillance (Foodborne Illnesses) | 0 | 1 | 0 | 0 | 0 | 0
National Nosocomial Infections Surveillance System (NNIS) | Surveillance (Hospital) | 0 | 1 | 0 | 1 | 0 | 0
National Respiratory and Enteric Virus Surveillance System (NREVSS) | Surveillance (Laboratory) | 0 | 0 | 0 | 1 | 0 | 0
National Surveillance System for Healthcare Workers (NaSH) | Surveillance (Other) | 0 | 0 | 0 | 1 | 0 | 1
National Tuberculosis Genotyping and Surveillance Network | Surveillance (Laboratory) | 0 | 0 | 0 | 1 | 0 | 0
National West Nile Virus Surveillance System (ArboNet) | Surveillance (Zoonotic/Animal disease) | 0 | 0 | 0 | 1 | 0 | 0
Netherlands National Institute of Public Health and the Environment Surveillance System | Surveillance (Laboratory) | 0 | 1 | 0 | 0 | 0 | 0
Neural Network for Diagnosing Tuberculosis | Diagnostic | 1 | 0 | 0 | 0 | 0 | 0
New York State Department of Health's Bureau of Community Sanitation and Food Protection (BCSFP) | Surveillance (Foodborne Illnesses) | 1 | 0 | 0 | 0 | 0 | 0
NexProfiler | Management | 0 | 0 | 0 | 0 | 1 | 0
Nitric Oxide (NO) sensor | Identification | 0 | 0 | 0 | 1 | 0 | 1
Nuclear-biological-chemical (NBC) Analysis | Integrated surveillance, communication, and command and control | 0 | 0 | 0 | 0 | 1 | 0
Nuclear-biological-chemical (NBC) Command and Control | Integrated surveillance, communication, and command and control | 0 | 0 | 0 | 0 | 0 | 1
Nuclear-biologic-chemical (NBC) Field Laboratory | Integrated Collection/Identification | 0 | 0 | 1 | 0 | 2 | 2
Optical fluorescence biosensor technique | Identification | 0 | 1 | 0 | 0 | 0 | 1
Peace Corps Surveillance | Surveillance (Other) | 1 | 0 | 0 | 0 | 0 | 0
PM10: SEE XM2
PNEUMON-IA | Diagnostic | 0 | 1 | 0 | 0 | 0 | 0
Pneumonia Therapy Advisor (PTA) | Management | 2 | 0 | 0 | 0 | 0 | 0
Portable Biofluorosensor (PBS) | Particulate Counters and Biomass Indicators | 0 | 0 | 1 | 0 | 0 | 0
Portable High-Throughput Liquid Aerosol Air Sampler System (PHTLAAS) | Collection | 0 | 0 | 1 | 0 | 1 | 0
Portal Shield | Integrated Collection/Identification | 0 | 0 | 1 | 0 | 0 | 0
Problem-Knowledge Couplers | Diagnostic | 0 | 0 | 0 | 0 | 1 | 0
Program for Monitoring Emerging Infectious Diseases (ProMED) | Communication | 1 | 2 | 0 | 0 | 0 | 0
Program for Response Options and Technology Enhancements for Chemical/Biological Terrorism (PROTECT) | Particulate Counters and Biomass Indicators | 0 | 0 | 0 | 2 | 0 | 0
Public Health Laboratory Information System (PHLIS) | Surveillance (Laboratory) | 1 | 1 | 0 | 0 | 0 | 0
Public Health Laboratory Service Communicable Disease Surveillance Centre (PHLS CDSC) | Surveillance (Laboratory) | 0 | 1 | 0 | 0 | 0 | 0
Pyrolysis-gas Chromatography-ion Mobility Spectrometer (PY-GC-IMS) | Identification | 0 | 0 | 1 | 0 | 0 | 1
QID | Management | 1 | 0 | 0 | 0 | 0 | 0
Quick Medical Reference (QMR) | Diagnostic | 5 | 7 | 0 | 0 | 1 | 0
Rabin Medical Center Antibiotic DSS | Management | 1 | 0 | 0 | 0 | 0 | 0
Rapid Automatic and Portable Fluorometer Assay System (RAPTOR): PLEASE SEE Fiber Optic Wave Guide (FOWG)
Rapid Emergency Digital Data Information Network (ReddiNet) | Communication | 0 | 0 | 0 | 0 | 0 | 1
Rapid Syndrome Validation Project (RSVP) | Surveillance (Syndromal) | 0 | 0 | 1 | 0 | 0 | 0
RealTime BioSensor | Identification | 0 | 0 | 0 | 0 | 1 | 0
Regional Influenza Surveillance Group (GROG) | Surveillance (Influenza) | 1 | 1 | 0 | 0 | 0 | 0
RHEACT | Communication | 0 | 0 | 1 | 0 | 0 | 2
Ruggedized Advanced Pathogen Identification Device (RAPID™): PLEASE SEE LightCycler™
Systematic Approach for Emergency Response (SAFER^®^) Real-Time System | Integrated surveillance, communication, and command and control | 0 | 0 | 0 | 0 | 1 | 0
Salmonella Data Bank (SDB) | Surveillance (Foodborne Illnesses) | 0 | 1 | 0 | 0 | 0 | 0
Salmonella Outbreak Detection Algorithm (SODA) | Surveillance (Foodborne Illnesses) | 0 | 1 | 0 | 0 | 0 | 0
Salmonella Potential Outbreak Targeting System (SPOT), also known as the National Enteric Pathogens Surveillance Scheme (NEPSS) and formerly known as the National Salmonella Surveillance Scheme | Surveillance (Laboratory) | 1 | 1 | 0 | 0 | 0 | 0
Sensitive Membrane Antigen Rapid Test (SMART™) | Identification | 1 | 0 | 2 | 0 | 2 | 0
SENTRY | Surveillance (Antimicrobial) | 0 | 2 | 0 | 0 | 0 | 0
Severity Scores for Community-acquired Pneumonia | Management | 1 | 0 | 0 | 0 | 0 | 0
Short-range Biological Standoff Detection System (SR-BSDS) | Particulate Counters and Biomass Indicators | 0 | 0 | 1 | 0 | 2 | 1
Single Particle Fluorescence Counter (SPFC) | Particulate Counters and Biomass Indicators | 0 | 0 | 1 | 0 | 0 | 0
Smart Air Sampler 2000 Plus Chem-Bio Air Sampler (SASS 2000) | Collection | 0 | 0 | 1 | 0 | 3 | 1
SmartCycler/GeneXpert™ | Identification | 0 | 0 | 0 | 0 | 1 | 1
SpinCon | Collection | 0 | 0 | 1 | 0 | 3 | 1
Spreeta | Particulate Counters and Biomass Indicators | 0 | 0 | 0 | 0 | 1 | 0
Stepwise and Interactive Evaluation of Food safety by an Expert System (SIEFE) | Surveillance (Foodborne Illnesses) | 0 | 2 | 0 | 0 | 0 | 0
Surveillance for Emerging Antimicrobial Resistance Connected to Healthcare (SEARCH) | Surveillance (Antimicrobial) | 0 | 0 | 0 | 1 | 0 | 0
SymText (part of HELP) | Diagnostic | 3 | 0 | 0 | 0 | 0 | 0
Syndromal Surveillance Tally Sheet | Surveillance (Syndromal) | 0 | 0 | 0 | 0 | 0 | 1
Testing COMpetency (TECOM) | Management | 0 | 1 | 0 | 0 | 0 | 0
Texas Infectious Disease Diagnostic DSS | Diagnostic | 1 | 0 | 0 | 0 | 0 | 0
The Royal Hospitals' Automated Infection Surveillance System | Surveillance (Hospital) | 2 | 0 | 0 | 0 | 0 | 0
The Surveillance Network™ (TSN™) Database-USA | Surveillance (Antimicrobial) | 1 | 1 | 0 | 0 | 0 | 0
Tissue-Based Biological Sensor (TBBS) | Identification | 0 | 0 | 0 | 0 | 0 | 2
Traveler's Diarrhea Network (TDN) | Surveillance (Other) | 0 | 1 | 0 | 0 | 0 | 0
Tucson VA Nosocomial Infection Surveillance System | Surveillance (Hospital) | 1 | 0 | 0 | 0 | 0 | 0
U.K. Food Micromodel | Surveillance (Foodborne Illnesses) | 0 | 1 | 0 | 0 | 0 | 0
Unexplained Deaths and Critical Illnesses Surveillance System | Surveillance (Other) | 0 | 0 | 0 | 2 | 0 | 1
University of Alabama Data Mining Surveillance System (DMSS) | Surveillance (Hospital) | 2 | 0 | 0 | 0 | 0 | 0
University of Chicago Artificial Neural Network for Interstitial Lung Disease | Diagnostic | 0 | 1 | 0 | 0 | 0 | 0
University of Chicago Computer Aided Diagnosis of Interstitial Lung Disease | Diagnostic | 2 | 1 | 0 | 0 | 0 | 0
University of Iowa Hospitals and Clinics (UIHC) Program of Hospital Epidemiology (PHE) Surveillance System | Surveillance (Hospital) | 0 | 1 | 0 | 0 | 0 | 0
Upconverting Phosphor Technology (UPT) | Identification | 0 | 0 | 0 | 0 | 1 | 0
U.S. Influenza Sentinel Physicians Surveillance Network | Surveillance (Influenza) | 0 | 0 | 0 | 2 | 0 | 0
Utrecht Emergency Hospital Patient Barcode Registration System | Management | 2 | 0 | 0 | 0 | 0 | 0
Vertical Cavity Surface Emitting Laser (VCSEL) | Particulate Counters and Biomass Indicators | 0 | 0 | 0 | 0 | 0 | 2
Walter Reed Army Medical Center (WRAMC) Telemedicine Service | Diagnostic | 1 | 1 | 0 | 0 | 0 | 0
WHO Influenza Surveillance (also known as FluNet) | Surveillance (Influenza) | 0 | 3 | 0 | 0 | 0 | 0
WHO Surveillance Program for the Control of Foodborne Infections and Intoxicants in Europe | Surveillance (Foodborne Illnesses) | 0 | 1 | 0 | 0 | 0 | 0
WHONET | Surveillance (Antimicrobial) | 0 | 4 | 0 | 0 | 0 | 0
XM2/PM10 | Particulate Counters and Biomass Indicators | 0 | 0 | 2 | 0 | 1 | 1
Your Practice Online | Communication | 0 | 0 | 0 | 0 | 1 | 0

a Other sources of information include conference proceedings, books, and newspaper articles.Wendy: shouldn't the reference for this should just be the DOE website.