# Appendix G. Results of Copernic^®^ Internet Searches

Search terms | Number of systems found/sites reviewed | Names of systems found using this search term that had not been found in MEDLINE^®^ search
(1) bioterror* OR biological terror* OR biological warfare OR biodefense | 6/223 | DOD Biological Sampling Kit (BSK) Joint Biological Point Detection System (JBPDS) Lightweight Epidemiology and Advanced Detection and Emergency Response System (LEADERS) MicroArray of Gel Immobilized Compounds on a Chip (MAGIChip™) Pyrolysis-Gas Chromatography-Ion Mobility Spectrometer (PY-GC-IMS) SpinCon^®^
(2) database AND (1) | 1/163 | National Molecular Subtyping Network for Foodborne Disease Surveillance (PulseNet)
(3) information technology AND (1) | 11/120 | BioCapture BT 550 Chemical/Biological Operational Decision Aid (CODA) Emergency Medical Alert Network (EMAN) Global Public Health Information Network (GPHIN) BioThreat Alert (BTA™) Strips Multi-Purpose Integrated Chemical Agent Alarm (MICAD) Nuclear-biological-chemical (NBC) Command and Control Ruggedized Advanced Pathogen Identification Device (RAPID) RealTime BioSensor™ Sensitive Membrane Antigen Rapid Test (SMART™) Upconverting Phosphor Technology (UPT)
(4) decision support system | 0/58 | -
(5) diagnosis AND (1) | 0/181
(6) public health AND (1) | 3/175 | Biological Aerosol Warning System (BAWS) Nuclear-biologic-chemical (NBC) Field Laboratory Short-Range Biological Stand-off Detection System (SRBSDS)
(7) surveillance AND (syndrome or infectious disease) | 6/57 | Associate for Public Health Disease Early Warning Network (DEWS) Enter-Net EuroTB HAWK Health Buddy^®^
(8) communication AND (1) | 0/130 | -
Total | 27/1107