# Appendix F. Results of Searches of Other Databases of Peer-Reviewed Articles and Selected Government Agency Web Sites

Government agency | Search terms | Hits | IT/DSSs retrieved from that search term
DOE | bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense | 1,489,000 ^*^ | -
| database AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 27 | Rapid Syndrome Validation Project (RSVP)
| information technology AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 54 | Biological Aerosol Sentry and Information System (BASIS)
| decision support system | 2,264,913 ^*^ | -
| diagnosis AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 49 | Emerging Pathogens Initiative (EPI)
| public health AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 418 | LandScan Global Population Database
| | | DNA Biochip
| | | Field kit for Rapid Detection of Anthrax
| surveillance AND (syndrome OR infectious disease) | 148 | -
| communication and (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 79 | Long-Range Biological Stand-off Detection System (LRBDSD)
Sandia National Laboratory | bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense | 84 | Vertical-cavity surface-emitting laser (VCSEL)
| database AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 14 | -
| information technology AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 14 | -
| decision support system | 74 | -
| diagnosis AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 24 | -
| public health AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 29 | -
| surveillance AND (syndrome OR infectious disease) | 22 | -
| communication and (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 33 | -
Lawrence Livermore National Laboratory | bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense | 104 | Advanced Nucleic Acid Analyzer (ANAA)/Handheld Advanced Nucleic Acid Analyzer (HANAA)
| database AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 25 | -
| information technology AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 12 | MiniFlo
| decision support system | 10 | -
| diagnosis AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 17 | -
| surveillance AND (syndrome OR infectious disease) | 27 | -
| public health AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 36 | Joint Biological Remote Early Warning System (JBREWS)
| communication AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 71 | -
Argonne National Laboratory | bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense | 31 | -
| database AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 10 | -
| information technology AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 24 | -
| decision support system | 12 | -
| diagnosis AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 3 | -
| surveillance AND (syndrome OR infectious disease) | 1 | -
| public health AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 15 | -
| communication AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 11 | -
DOD | bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense | 1413 | (1413 sites were displayed, however the DOD Web site only permitted screening of first 250 selections)
| database AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 10 | -
| information technology AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 4 | -
| decision support system | 17 | -
| diagnosis AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 238 | Biological Integrated Detection Systems (BIDS)
| | | Interim Biological Agent Detector System (IBAD)
| | | Joint Service Warning and Reporting Network (JWARN)
| | | Portal Shield
| | | XM2/PM10
| surveillance AND (syndrome OR infectious disease) | 235 | -
| public health AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 182 | -
| communication AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 340 | -
DARPA | bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense | 308 | Electronic Surveillance System for the Early Notification of Community-Based Epidemics (ESSENCE)
| | | Australian Membrane and Biotechnology Research Institute (AMBRI) Biosensor Technology
| | | Tissue-Based Biological Sensor (TBBS)
| | | Nitric oxide (NO) sensor
| database AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 0 | -
| information technology AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 0 | -
| decision support system | 23 | -
| diagnosis AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 0 | -
| surveillance AND (syndrome OR infectious disease) | 0 | -
| public health AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 0 | -
| communication AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 0 | -
FBI | bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense | 5 | -
| database AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | | -
| information technology AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 1 | -
| decision support system | 0 | -
| diagnosis AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 0 | -
| surveillance AND (syndrome OR infectious disease) | 0 | -
| public health AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 2 | -
| communication AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 3 | -
FEMA | bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense | 462 | -
| database AND (bioterror^*^ OR "biological terror^*^ OR biological warfare OR biodefense) | 1 | -
| information technology AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 49 | -
| decision support system | 2 | -
| diagnosis AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 14 | -
| surveillance AND (syndrome OR infectious disease) | 11 | -
| public health AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 70 | -
| communication AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 49 | -
PHS | bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense | 5 | -
| database AND (bioterror^*^ OR biological terror^*^ OR biological warfare" OR biodefense) | 0 | -
| information technology AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 0 | -
| decision support system | 0 | -
| diagnosis AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 1 | -
| surveillance AND (syndrome OR infectious disease) | 4 | -
| public health AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 5 | -
| communication AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 1 | -
EPA | bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense | 85 | Automated Decision Aid System for Hazardous Incidents (ADASHI)
| database AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 3 | -
| information technology AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 0 | -
| decision support system | 1 | -
| diagnosis AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 1 | -
| surveillance AND (syndrome OR infectious disease) | 249 | -
| public health AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 55 | -
| communication AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 29 | Meteorological Information and Dispersion Assessment System Anti-Terrorism (MIDAS-AT)
| | | Systematic Approach for Emergency Response (SAFER^®^) Real-Time System
NTIS | bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense | 200 | -
| database AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 19 | -
| information technology AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 300 | -
| decision support system | 156 | ABDX
| diagnosis AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 3 | -
| surveillance AND (syndrome OR infectious disease) | 14 | -
| public health AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 12 | -
| communication AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 0 | -
WHO | bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense | 58 | Global Salm Surv (GSS)
| database AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 19 | -
| information technology AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 24 | -
| decision support system | 1593 ^*^ | -
| diagnosis AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 36 | -
| surveillance AND (syndrome OR infectious disease) | 1011 ^*^ | -
| public health AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 55 | -
| communication AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 47 | -
CDC | bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense | 579 | Data Web Epidemic Information Exchange (Epi-X)
| | | Health Alert Network (HAN)
| database AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 135 | -
| information technology AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 340 | -
| decision support system | 22 | -
| diagnosis AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 199 | -
| surveillance AND (syndrome OR infectious disease) | 4145 ^*^ | -
| public health AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 499 | -
| communication AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 315 | -
VA | bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense | 65 | -
| database AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 16 | -
| information technology AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 3 | -
| decision support system | 317 | (317 sites were displayed, however the VA Web site only permitted screening of first 200 selections)
| diagnosis AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 23 | -
| surveillance AND (syndrome OR infectious disease) | 107 | -
| public health AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 25 | -
| communication AND (bioterror^*^ OR biological terror^*^ OR biological warfare OR biodefense) | 21 | -
Total Web sites screened | | 7,685 | 29

* If a search term returned more than 600 "hits," these Web sites were not screened.