# Appendix E. Results of MEDLINE^®^ Search

Search term(s) | Number of citations from search term(s) | Total number of citations from hedge
Subsearch 1: | | 374,448
artificial intelligence [MESH] NOT robotics [MESH] | 8,142 | 374,448
decision making, computer-assisted [MESH] | 18,564 | 374,448
decision support systems, clinical [MESH] | 518 | 374,448
decision support techniques [MESH] | 22,876 | 374,448
hospital information systems [MESH] | 10,508 | 374,448
integrated advanced information management systems [MESH] | 213 | 374,448
ambulatory care information systems [MESH] | 591 | 374,448
clinical laboratory information systems [MESH] | 1,155 | 374,448
clinical pharmacy information systems [MESH] | 408 | 374,448
decision support systems, management [MESH] | 595 | 374,448
radiology information systems [MESH] | 2,518 | 374,448
medical records systems, computerized [MESH] | 6,105 | 374,448
reminder systems [MESH] | 466 | 374,448
decision* [All Fields] | 83,128 | 374,448
expert* [All Fields] | 30,813 | 374,448
computer* [All Fields] | 215,237 | 374,448
computer [All Fields] | 188,661 | 374,448
informatic*[All Fields] | 7,276 | 374,448
information system*[All Fields] | 27,958 | 374,448
information system [All Fields] | 52,623 | 374,448
artificial intelligence*[All Fields] | 2,981 | 374,448
artificial intelligence [All Fields] | 9,660 | 374,448
reminder*[All Fields] | 2,205 | 374,448
decision mak*[All Fields] | 40,749 | 374,448
decision making [All Fields] | 52,934 | 374,448
Subsearch 2: | | 8,151,489
diagnosis, computer-assisted [MESH] | 11,818 | 8,151,489
therapy, computer-assisted [MESH] | 5,972 | 8,151,489
drug therapy, computer-assisted [MESH] | 511 | 8,151,489
epidemiologic methods [MESH] | 1,567,464 | 8,151,489
disease outbreaks [MESH] | 28,412 | 8,151,489
disease reservoirs [MESH] | 7,548 | 8,151,489
disease transmission [MESH] | 22,121 | 8,151,489
drug contamination [MESH] | 4,953 | 8,151,489
endemic diseases [MESH] | 915 | 8,151,489
environmental medicine [MESH] | 139 | 8,151,489
environmental microbiology [MESH] | 34,822 | 8,151,489
environmental monitoring [MESH] | 13,100 | 8,151,489
inhalation exposure [MESH] | 609 | 8,151,489
food contamination [MESH] | 22,615 | 8,151,489
communicable disease control [MESH] | 110,214 | 8,151,489
mandatory reporting [MESH] | 368 | 8,151,489
mortuary practice [MESH] | 654 | 8,151,489
disease management [MESH] | 1,789 | 8,151,489
diagnos* [All Fields] | 1,441,410 | 8,151,489
diagnosis [All Fields] | 3,892,626 | 8,151,489
therap* [All Fields] | 276,518 | 8,151,489
therapy [All Fields] | 3,317,981 | 8,151,489
drug* [All Fields] | 855,049 | 8,151,489
drug [All Fields] | 988,769 | 8,151,489
surveillance* [All Fields] | 43,318 | 8,151,489
surveillance [All Fields] | 653,565 | 8,151,489
manag* [All Fields] | 345,561 | 8,151,489
detect* [All Fields] | 674,221 | 8,151,489
outbreak* [All Fields] | 36,456 | 8,151,489
transmi* [All Fields] | 193,173 | 8,151,489
monitor* [All Fields] | 227,779 | 8,151,489
monitor [All Fields] | 32,308 | 8,151,489
quarantine* [All Fields] | 1,409 | 8,151,489
isolat* [All Fields] | 524,876 | 8,151,489
isolation [All Fields] | 499,350 | 8,151,489
isolation* [All Fields] | 104,354 | 8,151,489
expos* [All Fields] | 354,348 | 8,151,489
contaminat* [All Fields] | 62,611 | 8,151,489
alert* [All Fields] | 10,570 | 8,151,489
emergenc* [All Fields] | 108,687 | 8,151,489
report* [All Fields] | 1,673,448 | 8,151,489
decision mak* [All Fields] | 40,749 | 8,151,489
decision making [All Fields] | 52,934 | 8,151,489
Subsearch 3: | | 1,924,990
Bioterrorism [MESH] | 56 | 1,924,990
biological warfare [MESH] | 649 | 1,924,990
chemical warfare [MESH] | 428 | 1,924,990
bacterial infections and mycoses [MESH] | 584,351 | 1,924,990
virus diseases [MESH] | 351,285 | 1,924,990
parasitic diseases [MESH] | 167,378 | 1,924,990
veterinar* [All Fields] | 211,603 | 1,924,990
coroner* [All Fields] | 1,609 | 1,924,990
militar* [All Fields] | 36,341 | 1,924,990
bioterror* [All Fields] | 180 | 1,924,990
biowar* [All Fields] | 20 | 1,924,990
bacter* [All Fields] | 409,681 | 1,924,990
bacteria* [All Fields] | 403,252 | 1,924,990
bacteria [All Fields] | 771,849 | 1,924,990
viral*[All Fields] | 263,658 | 1,924,990
viral [All Fields] | 262,143 | 1,924,990
virus*[All Fields] | 322,438 | 1,924,990
virus [All Fields] | 418,821 | 1,924,990
parasit* [All Fields] | 69,423 | 1,924,990
parasitic [All Fields] | 26,613 | 1,924,990
infect* [All Fields] | 446,157 | 1,924,990
infectious [All Fields] | 115,967 | 1,924,990
infectious* [All Fields] | 116,185 | 1,924,990
infection [All Fields] | 541,049 | 1,924,990
infectio*[All Fields] | 625,191 | 1,924,990
communicable* [All Fields] | 16,058 | 1,924,990
Subsearch 4: | | 4,037,934
randomized controlled trial [pt] | 146,510 | 4,037,934
randomized controlled trials [MESH] | 19,461 | 4,037,934
random allocation [MESH] | 42,733 | 4,037,934
double blind method [MESH] | 64,638 | 4,037,934
single blind method [MESH] | 5,848 | 4,037,934
comparative study [MESH] | 944,038 | 4,037,934
evaluation studies [MESH] | 393,255 | 4,037,934
follow up studies [MESH] | 238,367 | 4,037,934
prospective studies [MESH] | 133,565 | 4,037,934
longitudinal studies [MESH] | 376,629 | 4,037,934
control* [Title/Abstract Word] | 866,813 | 4,037,934
prospectiv* [Title/Abstract Word] | 137,802 | 4,037,934
volunteer* [Title/Abstract Word] | 70,193 | 4,037,934
evaluation* [All Fields] | 497,577 | 4,037,934
evaluation [All Fields] | 685,806 | 4,037,934
studi* [All Fields] | 1,536,028 | 4,037,934
study [All Fields] | 2,316,042 | 4,037,934
trial* [All Fields] | 267,471 | 4,037,934
clinical trial* [All Fields] | 371,023 | 4,037,934
Total number of potentially relevant references from this final search Total number of citations already reviewed from preliminary searches | | 16,688 5,173
Total number of new references obtained from this search | | 11,515