# Appendix D. Alphabetical List of Peer-Reviewers

## Peer-reviewer

- Eric Bass, M.D., M.P.H.
- Associate Professor of Medicine, Johns Hopkins School of Medicine,Health Policy & Management, Bloomberg School of Public Health

- Roger Breeze, B.V.M.S., Ph.D., M.R.C.V.S.
- Agricultural Research ServiceU.S. Department of Agriculture

- Suephy C. Chen, M.D., M.S.
- Department of Dermatology, Emory UniversityEmory Center for Outcomes Research, Emory UniversityHealth Services Research and Development, Atlanta Veterans Administration Medical Center

- John T. Finn, Ph.D.
- Systems Research DepartmentSandia National Laboratories

- Deborah Hurley
- Director, Harvard Information Infrastructure Project, John F. Kennedy School of Government, Harvard UniversityAmerican Association for the Advancement of Science (AAAS)

- David G. Jarrett
- Colonel, U.S. ArmyU.S. Army Medical Research Institute of Infectious Diseases (USAMRIID), Operational Medicine Division

- Dawn Kataoka, Ph.D.
- Sandia National Laboratories

- Patrick Kelley, M.D., Dr.P.H.
- Colonel, Medical CorpsDirector, Department of Defense, Global Emerging Infections System (GEIS)

- Philip Lee, M.D.
- Consulting Professor in Human BiologyStanford University

- Gianfranco Pezzino, M.D., M.P.H.
- State Epidemiologist, Kansas Department of Health and EnvironmentCouncil of State and Territorial Epidemiologists (CSTE)

- Patricia Quinlisk, M.D., M.P.H.
- State Epidemiologist, Iowa Department of HealthCouncil of State and Territorial Epidemiologists (CSTE)

- Gary Roselle, M.D.
- Program Director for Infectious Diseases, Central OfficeProfessor of Medicine, University of Cincinnati College of MedicineDepartment of Veterans Affairs (VA)

- Jay Schauben, Pharm.D.
- Director, Florida Poison Control CenterAmerican Association of Poison Control Centers (AAPCC)

- Kathleen Schrader, R.N., D.N.S.C., C.E.N.
- Clinical Practice SpecialistAmerican Association of Critical-Care Nurses

- Bettina Stopford, R.N.
- Chair, Weapons of Mass Destruction Working-groupEmergency Nurses Association

- Michael Wagner, M.D., Ph.D.
- Assistant Professor of Medicine and Intelligent Systems, University of Pittsburgh, Center for Biomedical Informatics American Medical InformaticsAssociation (AMIA)

- John (Jack) Woodall, Ph.D.
- ProMED Mail