# Appendix C. Abstraction Form: Peer-Reviewed Articles

ABSTRACTION INFORMATION

Abstracter #1:
Abstracter #2:
Abstraction date:

CITATION INFORMATION

Reference number:
Title
Journal | | Year
Institution #1 | | Developer of IT/DSS? | [image] Yes [image] No [image] Can't Tell
Institution #2 | | Evaluator of IT/DSS? | [image] Yes [image] No [image] Can't Tell
Does this article present data from an abstract only? | | [image] No [image] Yes
Are there relevant references cited in this article? If so, please circle them in the bibliography | | [image] No [image] Yes
Source of funding: | | [image] Government agency [image] Private company [image] Not Stated [image] Other

ARTICLE INCLUSION/EXCLUSION RATIONALE

Does this article present a clinical evaluation of a DSS/IT? (Definition: Clinical evaluations report the results of an evaluation of the system using either actual or simulated patient data) | [image] No [image] Yes
Does this article present a description of a DSS/IT? (Definition: Descriptions must at least report the purpose of the IT/DSS) | [image] No [image] Yes

If the answer to BOTH of the preceding two questions is NO, then answer only the following question, but do not abstract this article.

What are the reference numbers of additional descriptions of this system?
If the article does not meet inclusion criteria for other reasons, please explain why. Do not abstract this article.

STUDY DESIGN INFORMATION

What is the purpose of the study? (In other words, what research question was the study attempting to answer? The answer is often found in the last paragraph of the introduction.)
Does this study compare advice from experts with the system but not evaluate clinical outcomes? | [image] No [image] Yes
Does the system use actual patient data? | [image] Uses simulated cases/data [image] Uses real patient data [image] Other
Are system outputs (e.g. decision support, reports, diagnoses) generated in real time for use by decision makers? | [image] Provide outputs in real time [image] Outputs not in real time [image] Can't tell extent of delay between input & output
Is this study randomized? | [image] No [image] Yes → If yes, describe randomization:
Is this study controlled? | [image] No [image] Yes → If yes, describe control groups:
What was the duration of the study period (e.g. 5/1995-8/1998)? If the end date is unclear, use date article was submitted.
Other comments or description of the study design:

IT/DSS DESIGN INFORMATION

What is the name of the IT/DSS?
Is this system bioterrorism specific? | | [image] No [image] Yes
Is this system infectious disease specific? | | [image] No [image] Yes
Is the system currently in clinical use? | | [image] No [image] Yes [image] Can't Tell
How could this IT/DSS be modified to make it useful to clinicians or public health officials in the event of a bioterrorism event? (Feel free to speculate here or to give your opinion.)
What is the purpose of the IT/DSS?
Is this system for surveillance? | [image] No [image] Yes | Is this system for disease management or treament? | [image] No [image] Yes
Is this system for diagnosis? | [image] No [image] Yes | Is this system for communication or reporting? | [image] No [image] Yes
Is this system designed for use by the Public Health officials? | | | [image] No [image] Yes
Where is the IT/DSS used? | | [image] Outpatient clinics, not ER [image] ER/Urgent care [image] Inpatient hospital [image] Both inpatient & outpatient areas [image] Other
What hardware platform does it use? | | [image] Stand alone PC [image] Hospital-based network [image] Web-based [image] Handheld [image] Can't Tell [image] Other
Does the system use standard vocabularies? | | [image] No [image] Yes [image] Can't Tell
What kind of reasoning does the system use? | | [image] Bayesian, probability-based [image] Rules-based, implied [image] Rules-based, explicitly stated [image] Can't Tell [image] Other
What kind of variable information is input into the system? | | [image] Demographic data [image] Vital signs/physical findings [image] Symptoms [image] Electronic medical record for individual patients [image] Hospital laboratory data [image] State/Public health laboratory data [image] Pharmacy data [image] Radiology data [image] EMT Runs [image] Probabilistic information (likelihood of particular infection) [image] Clinicians reports of cases [image] Other
What kind of information is provided by the system? | | [image] A single diagnosis [image] List of findings associated with a disease [image] List of differential diagnoses for a given case [image] Report to the public health officials [image] Report to clinicians from public health [image] Drug dosing recommendation [image] Management recommendation (specify) [image] Not stated [image] Other
Who performs the data analysis and synthesis? | | [image] System automatically analyzes & presents data [image] System collects data, synthesis by staff [image] Not stated [image] Other
Is a password required for access to the system? | | [image] No [image] Yes [image] Not Stated
Is information output by the system restricted by user type? | | [image] No [image] Yes [image] Not Stated
Describe other measures to keep data secure:
Other comments on the design of the IT/DSS:

SUBJECT INFORMATION

Who are the study subjects? | [image] Clinics [image] Physicians [image] Patients [image] Both Physicians and Patients [image] Other
Inclusion criteria:
Exclusion criteria:
Physician subjects: | Total number physician subjects: Number physicians in experimental group: Number physicians in control group:
Patient subjects: | Total number patient subjects: Number patients in experimental group: Number patients in control group:
Method of subject allocation: | [image] Random [image] Quasi-random [image] Selected concurrent controls [image] Not Stated
Baseline group differences: | [image] No baseline differences in experimental and control groups [image] Appropriate statistical adjustments were made for differences in experimental and control groups [image] No statistical adjustments were made for differences in experimental and control groups [image] Unable to assess
Describe methods to handle potential contamination of physicians learning from DSS:
Other comments about the subjects:

Results

Describe Outcome #1:
If pre-post design, use this: | Pre-intervention | | | Post-intervention
Intervention Group | | +/ - SD | | | +/ - SD
Control Group | | +/ - SD | | | +/ - SD
| p value: difference between pre- and post-intervention groups | | | p value: difference between intervention and control groups
If odds ratio, use this: | Positive Outcome | | | Negative Outcome
Intervention Group
Control Group
Odds Ratio | | 95% CI
If other formats of data, just describe the results:

Describe Outcome #2:
If pre-post design, use this: | Pre-intervention | | | Post-intervention
Intervention Group | | +/ - SD | | | +/ - SD
Control Group | | +/ - SD | | | +/ - SD
| p value: difference between pre- and post-intervention groups | | | p value: difference between intervention and control groups
If odds ratio, use this: | Positive Outcome | | | Negative Outcome
Intervention Group
Control Group
Odds Ratio | | 95% CI
If other formats of data, just describe the results:

Describe Outcome #3:
If pre-post design, use this: | Pre-intervention | | | Post-intervention
Intervention Group | | +/ - SD | | | +/ - SD
Control Group | | +/ - SD | | | +/ - SD
| p value: difference between pre- and post-intervention groups | | | p value: difference between intervention and control groups
If odds ratio, use this: | Positive Outcome | | | Negative Outcome
Intervention Group
Control Group
Odds Ratio | | 95% CI
If other formats of data, just describe the results:

Describe other outcomes:

What proportion of subjects completed the trial (i.e. completeness of followup)?
Which best describes the outcome measures used in this study? If there were more than one outcome, give the highest rating possible (e.g., if there was one objective measure and several subjective measures, check the box for the objective measure). | [image] Objective measure [image] Subjective measure; blinded assessment [image] Subjective measure no blinding; explicit criteria [image] Subjective measure; no explicit criteria
Were test statistics and levels of significance reported for all outcomes? | [image] No [image] Yes
Were confidence intervals or a measure of variance reported for all outcomes? | [image] No [image] Yes
Describe barriers to use of the system:

QUALITY OF SURVEILLANCE SYSTEMS

Abstracters: Does the article specifically describe these characteristics of the system? Do not attempt to rate the system on this quality, just answer whether or not the article describes this characteristic.

The public health importance of the events affected by this system? Important health events potentially affect many people, or have high mortality rate, or require large health expenditures. | [image] No [image] Yes
The usefulness of the system? Useful systems provide one or more decision makers with the essential information they need to take important actions. | [image] No [image] Yes
The flexibility of the system? Flexible systems can adapt to changes in case definitions, operating conditions, and variations in data sources with little additional time, personnel, or funds. | [image] No [image] Yes
The acceptability of the system? A system with good acceptability means that potential users of the system quickly adopt the use of the system into their routine practice; participation rates are high. | [image] No [image] Yes
The timeliness of the system? Timely systems have little delay between steps in the system; data input in a timely manner; reports and recommendations are generated quickly. | [image] No [image] Yes
The representativeness of the system? This refers to systems that use multiple sources of data to corroborate the findings or recommendations or diagnosis of the system; the quality of data input into the system is high and generally free of bias and error. | [image] No [image] Yes
The simplicity of the system? Complex systems may require significant staff training requirements, include many complex types of input data, use a variety of complex methods for outputting data to a variety of end users. Complex systems have more components that can fail; lead to time delays or introduce bias. | [image] No [image] Yes
The sensitivity of the system? Sensitive systems detect high proportions of patients with a given disease. | [image] No [image] Yes
The specificity of the system? Specific systems are able to rule out patients who do not have the disease in question. | [image] No [image] Yes

What additional comments do you have about this article?

Thank you.