# Appendix B. Alphabetical List of Expert Advisors

Expert advisor | Area of expertise
Michael S. Ascher, M.D., F.A.C.P. Office of Public Health Preparedness Department of Health and Human Services | Public Health Preparedness
Claire V. Broome, M.D. Centers for Disease Control and Prevention | Public Health Preparedness
Margaret A. Hamburg, M.D. Nuclear Threat Initiative | Public Health Preparedness
Jerome M. Hauer, M.P.H Kroll Associates | Emergency Management
Joshua Lederberg, Ph.D. Raymond and Beverly Sackler Foundation Scholar | Bioterrorism
Scott R. Lillibridge, M.D. Department of Health and Human Services | Public Health Preparedness
Tom McDonald, M.D. Palo Alto Medical Foundation | Clinical Medicine
Blackford Middleton, M.D., M.P.H, M.Sc. Clinical & Quality Analysis, Partners Healthcare System | Information Technology
Gregory J. Moran, M.D. Department of Emergency Medicine, Olive View-UCLA Medical Center | Clinical Medicine
Ingram Olkin, Ph.D. Professor of Statistics and Education, Stanford University | Meta-analysis and Evidence Synthesis
Michael T. Osterholm, Ph.D., M.P.H. University of Minnesota | Bioterrorism Preparedness
David A. Relman, M.D. Departments of Microbiology/Immunology and Medicine, VA Palo Alto Health Care System and Stanford University | Emerging Infectious Diseases
John Silva, M.D. National Cancer Institute | Information Technology
Peter Szolovits, Ph.D. Massachusetts Institute of Technology, Laboratory for Computer Science | Information Technology
Jonathan Tucker, Ph.D. Monterey Institute | Bioterrorism
Alan P. Zelicoff, M.D. Sandia National Laboratories, New Mexico | Syndromal Surveillance