# Appendix A. Acronyms and Abbreviations

Abbreviation | Full Name
AHRQ | Agency for Healthcare Research and Quality
AMBRI | Australian Membrane and Biotechnology Research Institute
APHL | Association of Public Health Laboratories
CDC | Centers for Disease Control and Prevention
CFU | Colony forming unit
CIA | Central Intelligence Agency
CNN | Cable News Network
CSTE | Council of State and Territorial Epidemiologists
DARPA | Defense Advanced Research Projects Agency
DERA | Defense Evaluation and Research Agency
DOD | Department of Defense
DOE | Department of Energy
DRES | Defense Research Establishment Suffield
DSS | Decision support system
ECBC | Edgewood Chemical Biological Center
EPA | Environmental Protection Agency
FBI | Federal Bureau of Investigation
FDA | Food and Drug Administration
FEMA | Federal Emergency Management Agency
GEIS | Global Emerging Infections System
GIS | Geographic Information Systems
HHS | Department of Health and Human Services
HIPAA | Health Insurance Portability and Accountability Act of 1996
ICU | Intensive care unit
INSERM | Institut National de la Sant? et de la Recherche Médicale
ISTM | International Society of Travel Medicine
IT | Information technology
LDS | Latter Day Saints
MeSH | Medical Subject Heading
MMWR | Morbidity and Mortality Weekly Report
NPV | Negative predictive value
NTIS | National Technical Information Service
PCR | Polymerase chain reaction
PDA | Personal digital assistant
PHS | Public Health Service
PPB | Parts per billion
PPV | Positive predictive value
ROC | Receiver operating characteristic
ROI | Regions of interest
SP | Specificity
UNHCR | United Nations High Commissioner for Refugees
UNICEF | United Nations Children's Fund
USAMRIID | U.S. Army Medical Research Institute of Infectious Diseases
VA | Department of Veterans Affairs
WHO | World Health Organization
WMD | Weapons of Mass Destruction