# Appendixes

Appendix A. Acronyms and Abbreviations

Appendix B. Alphabetical List of Expert Advisors

Appendix C. Abstraction Form: Peer-Reviewed Articles

Appendix D. Alphabetical List of Peer-Reviewers

Appendix E. Results of MEDLINE^®^ Search

Appendix F. Results of Searches of Other Databases of Peer-Reviewed Articles and Selected Government Agency Web Sites

Appendix G. Results of Copernic^®^ Internet Searches

Appendix H. Sources of Information for Included IT/DSSs

Appendix I. Index of Systems