# References

1 Cabot R C. Diagnostic pitfalls identified during a study of three thousand autopsies. JAMA. 1912;59:2295-2298.
2 Tai D Y, El-Bilbeisi H, Tewari S, Mascha E J, Wiedemann H P, Arroliga A C. A study of consecutive autopsies in a medical ICU : a comparison of clinical cause of death and autopsy diagnosis. Chest. 2001;119(2):530-536. [pmid: 11171734].
3 Twigg S J, McCrirrick A, Sanderson P M. A comparison of post mortem findings with post hoc estimated clinical diagnoses of patients who die in a United Kingdom intensive care unit. Intensive Care Med. 2001;27(4):706-710. [pmid: 11398697].
4 Roberts W C. The autopsy: its decline and a suggestion for its revival. N Engl J Med. 1978;299(7):332-338. [pmid: 683266].
5 Geller SA. Autopsy.Sci Am.1983;248(3):124–129, 132, 135–126.
6 Lundberg G D. Medicine without the autopsy. Arch Pathol Lab Med. 1984;108(6):449-454. [pmid: 6428374].
7 Yesner R, Robinson M J, Goldman L, Reichert C M, Engel L A. symposium on the autopsy. Pathology Annual. 1985;20(Pt 110):441-477. [pmid: 3991241].
8 Nemetz P N, Beard C M, Ballard D J, et al. Resurrecting the autopsy: benefits and recommendations. Mayo Clin Proc. 1989;64(9):1065-1076. [pmid: 2509828].
9 Hill R B, Anderson R E. The uses and value of autopsy in medical education as seen by pathology educators. Acad Med. 1991;66(2):97-100. [pmid: 1993112].
10 Hanzlick R, Parrish R G. The role of medical examiners and coroners in public health surveillance and epidemiologic research. Annu Rev Public Health. 1996;17:383-409. [pmid: 8724233].
11 Jordan J M, Bass M J. Errors in death certificate completion in a teaching hospital. Clin Invest Med. 1993;16(4):249-255. [pmid: 8306533].
12 Modelmog D, Rahlenbeck S, Trichopoulos D. Accuracy of death certificates: a population-based, complete-coverage, one-year autopsy study in East Germany. Cancer Causes Control. 1992;3(6):541-546. [pmid: 1420857].
13 Kircher T. The autopsy and vital statistics. Hum Pathol. 1990;21(2):166-173. [pmid: 2307444].
14 Kircher T, Nelson J, Burdo H. The autopsy as a measure of accuracy of the death certificate. N Engl J Med. 1985;313(20):1263-1269. [pmid: 4058507].
15 Schottenfeld D, Eaton M, Sommers S C, Alonso D R, Wilkinson C. The autopsy as a measure of accuracy of the death certificate. Bull N Y Acad Med. 1982;58(9):778-794. [pmid: 6963186].
16 Death certification and epidemiological research. Medical Services Study Group of the Royal College of Physicians of London. BMJ. 1978;2(6144):1063–1065.
17 Rakar S, Sinagra G, Di L A, et al. Epidemiology of dilated cardiomyopathy. A prospective post-mortem study of 5252 necropsies. The Heart Muscle Disease Study Group. Eur Heart J. 1997;18(1):117-123. [pmid: 9049523].
18 McFarlane M J. The epidemiologic necropsy for abdominal aortic aneurysm. JAMA. 1991;265(16):2085-2088. [pmid: 2013928].
19 Simonovis N J, Wells C K, Feinstein A R. In-vivo and post-mortem gallstones: support for validity of the “epidemiologic necropsy” screening technique. Am J Epidemiol. 1991;133:922-931. [pmid: 1827567].
20 Mollo F, Bellis D, Delsedime L, et al. Autopsy indicators of exposure to asbestos and lung cancer.IARC Sci Publ.1991(112):141–147.
21 McFarlane M J, Feinstein A R, Wells C K, Chan C K. The ‘epidemiologic necropsy’. Unexpected detections, demographic selections, and changing rates of lung cancer. JAMA. 1987;258(3):331-338. [pmid: 3599325].
22 Sampson R J, Key C R, Buncher C R, Iijima S. Thyroid carcinoma in Hiroshima and Nagasaki. I. Prevalence of thyroid carcinoma at autopsy. JAMA. 1969;209(1):65-70. [pmid: 5819259].
23 Nolte K B, Feddersen R M, Foucar K, et al. Hantavirus pulmonary syndrome in the United States: a pathological description of a disease caused by a new agent. Hum Pathol. 1995;26(1):110-120. [pmid: 7821907].
24 Moskowitz L B, Kory P, Chan J C, Haverkos H W, Conley F K, Hensley G T. Unusual causes of death in Haitians residing in Miami. High prevalence of opportunistic infections. JAMA. 1983;250(9):1187-1191. [pmid: 6348327].
25 Welch K, Finkbeiner W, Alpers C E, et al. Autopsy findings in the acquired immune deficiency syndrome. JAMA. 1984;252(9):1152-1159. [pmid: 6471338].
26 Fay D, Baird I M, Aguirre A, Haegren V, Werling K, Bell T W. Unrecognized Legionnaires' disease as a cause of fatal illness. JAMA. 1980;243(22):2311-2313. [pmid: 6990037].
27 Fox RC. The autopsy: it's place in the attitude-learning of second year medical students.Essays in medical sociology : journeys into the field. New York: Wiley; 1979.
28 Sinard J H. Factors affecting autopsy rates, autopsy request rates, and autopsy findings at a large academic medical center. Exp Mol Pathol. 2001;70(3):333-343. [pmid: 11418012].
29 Smith A E, Hutchins G M, Hanzlick R. Case of the month: making amends. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1998;158(16):1739-1740. [pmid: 9738602].
30 Havlik D M, Irvine R, Hanzlick R. Case of the month: allaying apprehension. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1998;158(18):1971-1972. [pmid: 9778195].
31 McPhee S J, Bottles K, Lo B, Saika G, Crommie D. To redeem them from death. Reactions of family members to autopsy. Am J Med. 1986;80(4):665-671. [pmid: 3963043].
32 Burton EC, Nemetz PN. Medical error and outcomes measures: where have all the autopsies gone?Medscape General Medicine.April 28 2000;2000(Apr. 28):E8. Available at:http://www.medscape.com/medscape/GeneralMedicine/journal/2000/v2002.n2002/mgm0428.burt/mgm0428.burt.html.
33 Burton E C, Nemetz P N, Fisher W P J, Newman W P I. Institutional characteristics associated with hospital autopsy performance: A survey of Louisiana hospitals [Abstract]. Am J Clin Pathol. 2001;116:590.
34 Hill R B. The current status of autopsies in medical care in the USA. Qual Assur Health Care. 1993;5(4):309-313. [pmid: 8018888].
35 Rosenbaum G E, Burns J, Johnson J, Mitchell C, Robinson M, Truog R D. Autopsy consent practice at US teaching hospitals: results of a national survey. Arch Intern Med. 2000;160(3):374-380. [pmid: 10668840].
36 Stolman C J, Castello F, Yorio M, Mautone S. Attitudes of pediatricians and pediatric residents toward obtaining permission for autopsy. Arch Pediatr Adolesc Med. 1994;148(8):843-847. [pmid: 8044262].
37 Grunberg S M, Sherrod A, Muellenbach R, Renshaw M, Zaretsky S, Levine A M. Analysis of physician attitudes concerning requests for autopsy. Cancer Investigation. 1994;12(5):463-468. [pmid: 7922701].
38 Berlin A, Wagstaff R, Bhopal R, Spencer J. Postmortem examinations: general practitioners' knowledge, behaviour, and attitudes. BMJ. 1994;308(6936):1080-1081. [pmid: 8173429].
39 Heckerling P S, Williams M J. Attitudes of funeral directors and embalmers toward autopsy. Arch Pathol Lab Med. 1992;116(11):1147-1151. [pmid: 1444743].
40 Waldron T, Vickerstaff L. The role of the autopsy in medical care. In: McLachlan G, ed.A Question of quality? : Roads to assurance in medical care. London: Published for the Nuffield Provincial Hospitals Trust by Oxford University Press; 1976.
41 Gardner R, Peskin L, Katz J L. The physician, the autopsy request, and the consent rate. J Med Educ. 1973;48(7):636-644. [pmid: 4708421].
42 Bordage G. Where are the history and the physical?. CMAJ. 1995;152(10):1595-1598. [pmid: 7743445]. [pmcid: 1337855].
43 Gordon P R, Senf J. Is the annual complete physical examination necessary?. Arch Intern Med. 1999;159(9):909-910. [pmid: 10326933].
44 Roshan M, Rao A P. A study on relative contributions of the history, physical examination and investigations in making medical diagnosis. J Assoc Physicians India. 2000;48(8):771-775. [pmid: 11273467].
45 Peterson M C, Holbrook J H, Von Hales D, Smith N L, Staker L V. Contributions of the history, physical examination, and laboratory investigation in making medical diagnoses. West J Med. 1992;156(2):163-165. [pmid: 1536065]. [pmcid: 1003190].
46 Hampton J R, Harrison M J, Mitchell J R, Prichard J S, Seymour C. Relative contributions of history-taking, physical examination, and laboratory investigation to diagnosis and management of medical outpatients. Br Med J. 1975;2(5969):486-489. [pmid: 1148666]. [pmcid: 1673456].
47 Sackett D L. A primer on the precision and accuracy of the clinical examination. JAMA. 1992;267(19):2638-2644. [pmid: 1573753].
48 Stevenson L W, Perloff J K. The limited reliability of physical signs for estimating hemodynamics in chronic heart failure. JAMA. 1989;261(6):884-888. [pmid: 2913385].
49 Pryor D B, Shaw L, McCants C B, et al. Value of the history and physical in identifying patients at increased risk for coronary artery disease. Ann Intern Med. 1993;118(2):81-90. [pmid: 8416322].
50 Koran L M. The reliability of clinical methods, data and judgments (second of two parts). N Engl J Med. 1975;293(14):695-701. [pmid: 1160937].
51 Goldman L, Sayson R, Robbins S, Cohn L H, Bettmann M, Weisberg M. The value of the autopsy in three medical eras. N Engl J Med. 1983;308(17):1000-1005. [pmid: 6835306].
52 Anderson R E, Hill R B, Key C R. The sensitivity and specificity of clinical diagnostics during five decades. Toward an understanding of necessary fallibility. JAMA. 1989;261(11):1610-1617. [pmid: 2645451].
53 Veress B, Alafuzoff I. Clinical diagnostic accuracy audited by autopsy in a university hospital in two eras. Qual Assur Health Care. 1993;5(4):281-286. [pmid: 8018882].
54 Kirch W, Schafii C. Misdiagnosis at a university hospital in 4 medical eras. Medicine (Baltimore). 1996;75(1):29-40. [pmcid: 126225]. [pmid: 8569468].
55 Sonderegger-Iseli K, Burger S, Muntwyler J, Salomon F. Diagnostic errors in three medical eras: a necropsy study. Lancet. 2000;355(9220):2027-2031. [pmid: 10885353].
56 Alafuzoff I, Veress B. The selection for post-mortem examination: a retrospective analysis of 74 deceased surgical cases. Qual Assur Health Care. 1993;5(4):345-349. [pmid: 8018894].
57 McFarlane M J. Clinical diagnosis is not a source of bias in selection for necropsy. Arch Pathol Lab Med. 1989;113(1):64-67. [pmid: 2910228].
58 Saracci R. Problems with the use of autopsy results as a yardstick in medical audit and epidemiology. Qual Assur Health Care. 1993;5(4):339-344. [pmid: 8018893].
59 Druss B G, Bruce M L, Jacobs S C, Hoff R A. Trends over a decade for a general hospital psychiatry unit. Adm Policy Ment Health. Mar. 1998;25(4):427-435. [pmid: 10582385].
60 Kominski GF, Witsberger C. Trends in length of stay for Medicare patients: 1979-87. Health Care Financ Rev. Winter 1993;15(2):121–135.
61 Irwin D, Jessop E G. Severity of sickness at admission to hospital in Colchester 1985 and 1990. Public Health. May. 1993;107(3):171-175. [pmid: 8511236].
62 Ashby JL, Jr., Altman SH. The trend in hospital output and labor productivity, 1980-1989. Inquiry. Spring 1992;29(1):80–91.
63 Basu J. An analysis of trends in average length of stay in Maryland Hospitals, 1980-1988. J Health Soc Policy. 1992;4(1):77-95. [pmid: 10125175].
64 Epstein AM, Bogen J,Dreyer P, Thorpe KE. Trends in length of stay and rates of readmission in Massachusetts: implications for monitoring quality of care. Inquiry Spring 1991;28(1):19–28.
65 Latta VB, Helbing C. Medicare short-stay hospital services by diagnosis-related groups. Health Care Financ Rev. Summer 1991;12(4):105–140.
66 Helbing C, Keene R. Use and cost of short-stay hospital inpatient services under Medicare, 1986. Health Care Financ Rev. Summer 1989;10(4):93–109.
67 Latta VB, Helbing C. Medicare: short-stay hospital services, by leading diagnosis-related groups, 1983 and 1985. Health Care Financ Rev. Winter 1988;10(2):79–107.
68 Saracci R. Is necropsy a valid monitor of clinical diagnosis performance?. BMJ. 1991;303(6807):898-900. [pmid: 1933005]. [pmcid: 1671185].
69 Saracci R. Autopsy as the yardstick for diagnosis: an epidemiologist's remarks.IARC Sci Publ; 1991:185–196.
70 Battle R M, Pathak D, Humble C G, et al. Factors influencing discrepancies between premortem and postmortem diagnoses. JAMA. 1987;258(3):339-344. [pmid: 3599326].
71 Hjorth L, Noer H, Rasmussen K S, Sorensen I M. [Importance of the autopsy rate. A comparison between clinical assessment and findings at autopsies during the periods: 1 July 1908-30 June 1981 and 1 July 1990-30 June 1991]. Ugeskr Laeger. 1994;156(31):4459-4461. [pmid: 8066951].
72 Wright C, Cameron H, Lamb W. A study of the quality of perinatal autopsy in the former northern region. The Northern Perinatal Mortality Survey Steering Group. Br J Obstet Gynaecol. 1998;105(1):24-28. [pmid: 9442157].
73 Cartlidge P H, Dawson A T, Stewart J H, Vujanic G M. Value and quality of perinatal and infant postmortem examinations: cohort analysis of 400 consecutive deaths. BMJ. 1995;310(6973):155-158. [pmid: 7833753].
74 Vujanic G M, Cartlidge P H, Stewart J H, Dawson A J. Perinatal and infant postmortem examinations: how well are we doing?. J Clin Pathol. 1995;48(11):998-1001. [pmcid: 503001]. [pmid: 8543645].
75 Vujanic G M, Cartlidge P H, Stewart J H. Improving the quality of perinatal and infant necropsy examinations: a follow up study. J Clin Pathol. 1998;51(11):850-853. [pmcid: 500981]. [pmid: 10193328].
76 Zarbo R J, Baker P B, Howanitz P J. Quality assurance of autopsy permit form information, timeliness of performance, and issuance of preliminary report. A College of American Pathologists Q-Probes study of 5434 autopsies from 452 institutions. Arch Pathol Lab Med. 1996;120(4):346-352. [pmid: 8619745].
77 Fowler E F, Nicol A G, Reid I N. Evaluation of a teaching hospital necropsy service. J Clin Pathol. 1977;30(6):575-578. [pmcid: 476471]. [pmid: 874115].
78 Schned A R, Mogielnicki R P, Stauffer M E. A comprehensive quality assessment program on the autopsy service. Am J Clin Pathol. 1986;86(2):133-138. [pmid: 3739967].
79 Fessel W J, Van Brunt E E. Assessing quality of care from the medical record. N Engl J Med. 1972;286(3):134-138. [pmid: 5007152].
80 Romm F J, Putnam S M. The validity of the medical record. Med Care. 1981;19(3):310-315. [pmid: 7218896].
81 Gerbert B, Hargreaves W A. Measuring physician behavior. Med Care. 1986;24(9):838-847. [pmid: 3762247].
82 Beers M H, Munekata M, Storrie M. The accuracy of medication histories in the hospital medical records of elderly persons. J Am Geriatr Soc. 1990;38(11):1183-1187. [pmid: 2246454].
83 Patel A G, Mould T, Webb P J. Inadequacies of hospital medical records. Ann R Coll Surg Engl. 1993;75(1 Suppl):7-9. [pmid: 8422161].
84 van Walraven C, Weinberg A L. Quality assessment of a discharge summary system. CMAJ. 1995;152(9):1437-1442. [pmid: 7728692]. [pmcid: 1337907].
85 Sulmasy D P, Dwyer M, Marx E. Do the ward notes reflect the quality of end-of-life care?. J Med Ethics. 1996;22(6):344-348. [pmid: 8961119].
86 Williams H R, Templeton P A, Smith R M. An audit of trauma documentation. Injury. 1997;28(3):165-167. [pmid: 9274730].
87 Jeannot J G, Vader J P, Porchet F, Larequi-Lauber T, Burnand B. Can the decision to operate be judged retrospectively? A study of medical records. Eur J Surg. 1999;165(6):516-521. [pmid: 10433132].
88 Lau H S, Florax C, Porsius A J, De Boer A. The completeness of medication histories in hospital medical records of patients admitted to general internal medicine wards. Br J Clin Pharmacol. 2000;49(6):597-603. [pmid: 10848724].
89 Solomon D H, Schaffer J L, Katz J N, et al. Can history and physical examination be used as markers of quality? An analysis of the initial visit note in musculoskeletal care. Med Care. 2000;38(4):383-391. [pmid: 10752970].
90 Wilson R R. In defense of the autopsy. JAMA. 1966;196(11):193-194.
91 Meier P R, Manchester D K, Shikes R H, Clewell W H, Stewart M. Perinatal autopsy: its clinical value. Obstet Gynecol. 1986;67(3):349-351. [pmid: 3945446].
92 Hagerstrand I, Lundberg L M. The importance of post-mortem examinations of abortions and perinatal deaths. Qual Assur Health Care. 1993;5(4):295-297. [pmid: 8018885].
93 Saller D N Jr, Lesser K B, Harrel U, Rogers B B, Oyer C E. The clinical utility of the perinatal autopsy. JAMA. 1995;273(8):663-665. [pmid: 7844878].
94 Zehr K J, Liddicoat J R, Salazar J D, et al. The autopsy: still important in cardiac surgery. Ann Thorac Surg. 1997;64(2):380-383. [pmid: 9262579].
95 Phelps C E. The methodologic foundations of studies of the appropriateness of medical care. N Engl J Med. 1993;329(17):1241-1245. [pmid: 8413392].
96 Stoler M H, Schiffman M. Interobserver reproducibility of cervical cytologic and histologic interpretations: realistic estimates from the ASCUS-LSIL Triage Study. JAMA. 2001;285(11):1500-1505. [pmid: 11255427].
97 Grenko R T, Abendroth C S, Frauenhoffer E E, Ruggiero F M, Zaino R J. Variance in the interpretation of cervical biopsy specimens obtained for atypical squamous cells of undetermined significance. Am J Clin Pathol. 2000;114(5):735-740. [pmid: 11068547].
98 Allsbrook W C Jr, Mangold K A, Johnson M H, Lane R B, Lane C G, Epstein J I. Interobserver reproducibility of Gleason grading of prostatic carcinoma: general pathologist. Hum Pathol. 2001;32(1):81-88. [pmid: 11172299].
99 Allsbrook W C Jr, Mangold K A, Johnson M H, et al. Interobserver reproducibility of Gleason grading of prostatic carcinoma: urologic pathologists. Hum Pathol. 2001;32(1):74-80. [pmid: 11172298].
100 Wells W A, Carney P A, Eliassen M S, Grove M R, Tosteson A N. Pathologists' agreement with experts and reproducibility of breast ductal carcinoma-in-situ classification schemes. Am J Surg Pathol. 2000;24(5):651-659. [pmid: 10800983].
101 Younossi Z M, Boparai N, Gramlich T, Goldblum J, George P, Mayes J. Agreement in pathologic interpretation of liver biopsy specimens in posttransplant hepatitis C infection. Arch Pathol Lab Med. 1999;123(2):143-145. [pmid: 10050788].
102 Riber C, Tonnesen H, Aru A, Bjerregaard B. Observer variation in the assessment of the histopathologic diagnosis of acute appendicitis. Scand J Gastroenterol. 1999;34(1):46-49. [pmid: 10048732].
103 Wells W A, Carney P A, Eliassen M S, Tosteson A N, Greenberg E R. Statewide study of diagnostic agreement in breast pathology. J Natl Cancer Inst. 1998;90(2):142-145. [pmid: 9450574].
104 Raab S S, Geisinger K R, Silverman J F, Thomas P A, Stanley M W. Interobserver variability of a Papanicolaou smear diagnosis of atypical glandular cells of undetermined significance. Am J Clin Pathol. 1998;110(5):653-659. [pmid: 9802352].
105 Jones B A, Novis D A. Cervical biopsy-cytology correlation. A College of American Pathologists Q-Probes study of 22 439 correlations in 348 laboratories. Arch Pathol Lab Med. 1996;120(6):523-531. [pmid: 8651852].
106 Jones B A. Rescreening in gynecologic cytology. Rescreening of 8096 previous cases for current low-grade and indeterminate-grade squamous intraepithelial lesion diagnoses--a College of American Pathologists Q-Probes study of 323 laboratories. Arch Pathol Lab Med. 1996;120(6):519-522. [pmid: 8651851].
107 Lind A C, Bewtra C, Healy J C, Sims K L. Prospective peer review in surgical pathology. Am J Clin Pathol. 1995;104(5):560-566. [pmid: 7572817].
108 Veress B, Gadaleanu V, Nennesmo I, Wikstrom B M. The reliability of autopsy diagnostics: inter-observer variation between pathologists, a preliminary report. Qual Assur Health Care. 1993;5(4):333-337. [pmid: 8018892].
109 Corley D E, Kirtland S H, Winterbauer R H, et al. Reproducibility of the histologic diagnosis of pneumonia among a panel of four pathologists: analysis of a gold standard. Chest. 1997;112(2):458-465. [pmid: 9266884].
110 James G, Patton R E, Heslin A S. Accuracy of cause-of-death statements on death certificates. Public Health Reports. 1955;70(1):39-51. [pmid: 13224799].
111 Johanson W G Jr, Seidenfeld J J, Gomez P, de los Santos R, Coalson J J. Bacteriologic diagnosis of nosocomial pneumonia following prolonged mechanical ventilation. Am Rev Respir Dis. 1988;137(2):259-264. [pmid: 3341619].
112 Cohen J. A coefficient of agreement for nominal scales. Education and Psychological Measurement. 1960;20:37-46.
113 Cohen J. A coefficient of agreement for nominal scales. Pscychological Bulletin. 1960;70:213-220.
114 Goodin J, Hanzlick R. Mind your manners. Part II: General results from the National Association of Medical Examiners Manner of Death Questionnaire, 1995. Am J Forensic Med Pathol. 1997;18(3):224-227. [pmid: 9290868].
115 Hanzlick R, Goodin J. Mind your manners. Part III: Individual scenario results and discussion of the National Association of Medical Examiners Manner of Death Questionnaire, 1995. Am J Forensic Med Pathol. 1997;18(3):228-245. [pmid: 9290869].
116 Bernicker E H, Atmar R L, Schaffner D L, Greenberg S B. Unanticipated diagnoses found at autopsy in an urban public teaching hospital. Am J Med Sci. 1996;311(5):215-220. [pmid: 8615396].
117 Blosser S A, Zimmerman H E, Stauffer J L. Do autopsies of critically ill patients reveal important findings that were clinically undetected?. Crit Care Med. 1998;26(8):1332-1336. [pmid: 9710090].
118 Boers M, Nieuwenhuyzen Kruseman A C, Eulderink F, Hermans J, Thompson J. Value of autopsy in internal medicine: a 1-year prospective study of hospital deaths. Eur J Clin Invest. 1988;18(3):314-320. [pmid: 3138134].
119 Bordin P, Da Col P G, Peruzzo P, Stanta G, Guralnik J M, Cattin L. Causes of death and clinical diagnostic errors in extreme aged hospitalized people: a retrospective clinical-necropsy survey. J Gerontol A Biol Sci Med Sci. 1999;54(11):M554-559. [pmid: 10619317].
120 Burke M C, Aghababian R V, Blackbourne B. Use of autopsy results in the emergency department quality assurance plan. Ann Emerg Med. 1990;19(4):363-366. [pmid: 2321819].
121 Britton M. Clinical diagnostics: experience from 383 autopsied cases. Acta Med Scand. 1974;196(3):211-219. [pmid: 4421018].
122 Britton M. Diagnostic errors discovered at autopsy. Acta Med Scand. 1974;196(3):203-210. [pmid: 4422553].
123 Cameron H M, McGoogan E, Watson H. Necropsy: a yardstick for clinical diagnoses. BMJ. 1980;281(6246):985-988. [pmid: 7427553]. [pmcid: 1714385].
124 Dhar V, Perlman M, Vilela M I, Haque K N, Kirpalani H, Cutz E. Autopsy in a neonatal intensive care unit: utilization patterns and associations of clinicopathologic discordances. J Pediatr. 1998;132(1):75-79. [pmid: 9470004].
125 Fernandez-Segoviano P, Lazaro A, Esteban A, Rubio J M, Iruretagoyena J R. Autopsy as quality assurance in the intensive care unit. Crit Care Med. 1988;16(7):683-685. [pmid: 3371045].
126 Goldstein B, Metlay L, Cox C, Rubenstein J S. Association of pre mortem diagnosis and autopsy findings in pediatric intensive care unit versus emergency department versus ward patients. Crit Care Med. 1996;24(4):683-686. [pmid: 8612423].
127 Heasman MA, Lipworth L.Accuracy of certification of cause of death. London: HMSO; 1966.
128 Kumar P, Taxy J, Angst D B, Mangurten H H. Autopsies in children: are they still useful?. Arch Pediatr Adolesc Med. 1998;152(6):558-563. [pmid: 9641709].
129 Landefeld C S, Chren M M, Myers A, Geller R, Robbins S, Goldman L. Diagnostic yield of the autopsy in a university hospital and a community hospital. N Engl J Med. 1988;318(19):1249-1254. [pmid: 3362177].
130 Middleton K, Clarke E, Homann S, et al. An autopsy-based study of diagnostic errors in geriatric and nongeriatric adult patients. Arch Intern Med. 1989;149(8):1809-1812. [pmid: 2764653].
131 Papadakis M A, Mangione C M, Lee K K, Kristof M. Treatable abdominal pathologic conditions and unsuspected malignant neoplasms at autopsy in veterans who received mechanical ventilation. JAMA. 1991;265(7):885-887. [pmid: 1992186].
132 Stambouly J J, Kahn E, Boxer R A. Correlation between clinical diagnoses and autopsy findings in critically ill children. Pediatrics. 1993;92(2):248-251. [pmid: 8337024].
133 Stolman C J, Castello F, Holland B K, et al. Lessons learned from autopsies at a pediatric teaching hospital. N J Med. 1995;92(12):794-797. [pmid: 8545068].
134 Brennan T A, Leape L L, Laird N M, et al. Incidence of adverse events and negligence in hospitalized patients. Results of the Harvard Medical Practice Study I. N Engl J Med. 1991;324(6):370-376. [pmid: 1987460].
135 Dubois R W, Brook R H. Preventable deaths: who, how often, and why?. Ann Intern Med. 1988;109(7):582-589. [pmid: 3421565].
136 Thomas E J, Studdert D M, Burstin H R, et al. Incidence and types of adverse events and negligent care in Utah and Colorado. Med Care. 2000;38(3):261-271. [pmid: 10718351].
137 Hayward R A, Hofer T P. Estimating hospital deaths due to medical errors: preventability is in the eye of the reviewer. JAMA. 2001;286(4):415-420. [pmid: 11466119].
138 Thornton A, Lee P. Publication bias in meta-analysis: its causes and consequences. J Clin Epidemiol. 2000;53(2):207-216. [pmid: 10729693].
139 Montori V M, Smieja M, Guyatt G H. Publication bias: a brief review for clinicians. Mayo Clin Proc. 2000;75(12):1284-1288. [pmid: 11126838].
140 Pham B, Platt R, McAuley L, Klassen T P, Moher D. Is there a “best” way to detect and minimize publication bias? An empirical evaluation. Eval Health Prof. 2001;24(2):109-125. [pmid: 11523382].
141 Macaskill P, Walter S D, Irwig L. A comparison of methods to detect publication bias in meta-analysis. Stat Med. 2001;20(4):641-654. [pmid: 11223905].
142 Sutton AJ, Duval SJ, Tweedie RL, Abrams KR, Jones DR. Empirical assessment of effect of publication bias on meta-analyses. BMJ. June 10, 2000 2000;320(7249):1574–1577.
143 Egger M, Davey Smith G, Schneider M, Minder C. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629-634. [pmid: 9310563].
144 Copas J B, Shi J Q. A sensitivity analysis for publication bias in systematic reviews. Stat Methods Med Res. 2001;10(4):251-265. [pmid: 11491412].
145 Goldman L. Diagnostic advances v the value of the autopsy. 1912-1980. Arch Pathol Lab Med. 1984;108(6):501-505. [pmid: 6375622].
146 Wanzel K R, Jamieson C G, Bohnen J M. Complications on a general surgery service: incidence and reporting. Can J Surg. 2000;43(2):113-117. [pmid: 10812345].
147 Kohn L, Corrigan J, Donaldson M, eds.To Err Is Human: Building a Safer Health System.Washington, D.C.: Committee on Quality of Health Care in America, Institute of Medicine. National Academy Press; 2000.
148 Shojania KG, Duncan BW, McDonald KM, Wachter RM, eds.Making health care safer: a critical analysis of patient safety practices.Evidence Report/Technology Assessment No. 43 from the Agency for Healthcare Research and Quality: AHRQ Publication No. 01-E058; 2001.
149 Kiesel E, Hanzlick R. Case of the month. The autopsy and new technology: all that glitters is not a gold standard. Arch Intern Med. 2000;160(13):1901-1902. [pmid: 10888963].
150 Hutchins G M, Hanzlick R. Case of the month: Speculation and competing causes of death. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1998;158(15):1593-1594. [pmid: 9701092].
151 Baker P B, Hanzlick R. Case of the month: death and devices. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1999;159(1):21-22. [pmid: 9892325].
152 Nichols L, Aronica P, Babe C. Are autopsies obsolete?. Am J Clin Pathol. 1998;110(2):210-218. [pmid: 9704620].
153 Juvin P, Teissiere F, Brion F, Desmonts J, Durigon M. Postoperative death and malpractice suits: is autopsy useful?. Anesth Analg. 2000;91(2):344-346. [pmid: 10910845].
154 Valaske M J. Loss control/risk management. A survey of the contribution of autopsy examination. Arch Pathol Lab Med. 1984;108(6):462-468. [pmid: 6547297].
155 Cameron H M, McGoogan E. A prospective study of 1152 hospital autopsies: I. Inaccuracies in death certification. J Pathol. 1981;133(4):273-283. [pmid: 7241267].
156 Cameron H M, McGoogan E. A prospective study of 1152 hospital autopsies: II. Analysis of inaccuracies in clinical diagnoses and their significance. J Pathol. 1981;133(4):285-300. [pmid: 7241268].
157 Rossman I, Rodstein M, Bornstein A. Undiagnosed diseases in an aging population. Pulmonary embolism and bronchopneumonia. Arch Intern Med. 1974;133(3):366-369. [pmid: 4283736].
158 Bedell S E, Fulton E J. Unexpected findings and complications at autopsy after cardiopulmonary resuscitation (CPR). Arch Intern Med. 1986;146(9):1725-1728. [pmid: 3753112].
159 Gross J S, Neufeld R R, Libow L S, Gerber I, Rodstein M. Autopsy study of the elderly institutionalized patient. Review of 234 autopsies. Arch Intern Med. 1988;148(1):173-176. [pmid: 3337592].
160 McKelvie P A, Rode J. Autopsy rate and a clinicopathological audit in an Australian metropolitan hospital--cause for concern?. Med J Aust. 1992;156(7):456-462. [pmid: 1556972].
161 Goldhaber S Z, Hennekens C H, Evans D A, Newton E C, Godleski J J. Factors associated with correct antemortem diagnosis of major pulmonary embolism. Am J Med. 1982;73(6):822-826. [pmid: 7148876].
162 Rubinstein I, Murray D, Hoffstein V. Fatal pulmonary emboli in hospitalized patients. An autopsy study. Arch Intern Med. 1988;148(6):1425-1426. [pmid: 3377625].
163 Karwinski B, Svendsen E. Comparison of clinical and postmortem diagnosis of pulmonary embolism. J Clin Pathol. 1989;42(2):135-139. [pmcid: 1141815]. [pmid: 2921354].
164 Macintyre I M, Ruckley C V. Pulmonary embolism--a clinical and autopsy study. Scott Med J. 1974;19(1):20-24. [pmid: 4820007].
165 Mandelli V, Schmid C, Zogno C, Morpurgo M. “False negatives” and “false positives” in acute pulmonary embolism: a clinical-postmortem comparison. Cardiologia. 1997;42(2):205-210. [pmid: 9090162].
166 Mesquita C T, Morandi Junior J L, Perrone F T, et al. Fatal pulmonary embolism in hospitalized patients. Clinical diagnosis versus pathological confirmation. Arq Bras Cardiol. 1999;73(3):251-258. [pmid: 10752164].
167 Morpurgo M, Schmid C, Mandelli V. Factors influencing the clinical diagnosis of pulmonary embolism: analysis of 229 postmortem cases. Int J Cardiol. 1998;65(Suppl 1):S79-82. [pmid: 9706833].
168 Morrell M T, Dunnill M S. The post-mortem incidence of pulmonary embolism in a hospital population. Br J Surg. 1968;55(5):347-352. [pmid: 5648012].
169 Sandler D A, Martin J F. Autopsy proven pulmonary embolism in hospital patients: are we detecting enough deep vein thrombosis?. J R Soc Med. 1989;82(4):203-205. [pmid: 2716016]. [pmcid: 1292084].
170 Ryu J H, Olson E J, Pellikka P A. Clinical recognition of pulmonary embolism: problem of unrecognized and asymptomatic cases. Mayo Clin Proc. 1998;73(9):873-879. [pmid: 9737225].
171 Morgenthaler T I, Ryu J H. Clinical characteristics of fatal pulmonary embolism in a referral hospital. Mayo Clin Proc. 1995;70(5):417-424. [pmid: 7731250].
172 Stein P D, Henry J W. Prevalence of acute pulmonary embolism among patients in a general hospital and at autopsy. Chest. 1995;108(4):978-981. [pmid: 7555172].
173 Pineda L A, Hathwar V S, Grant B J. Clinical suspicion of fatal pulmonary embolism. Chest. 2001;120(3):791-795. [pmid: 11555511].
174 Stein P D, Hull R D, Saltzman H A, Pineo G. Strategy for diagnosis of patients with suspected acute pulmonary embolism. Chest. 1993;103(5):1553-1559. [pmid: 8486043].
175 Wells P S, Ginsberg J S, Anderson D R, et al. Use of a clinical model for safe management of patients with suspected pulmonary embolism. Ann Intern Med. 1998;129(12):997-1005. [pmid: 9867786].
176 Value of the ventilation/perfusion scan in acute pulmonary embolism. Results of the prospective investigation of pulmonary embolism diagnosis (PIOPED). The PIOPED Investigators. JAMA 1990;263(20):2753–2759.
177 Goldhaber S Z, Visani L, De Rosa M. Acute pulmonary embolism: clinical outcomes in the International Cooperative Pulmonary Embolism Registry (ICOPER). Lancet. 1999;353(9162):1386-1389. [pmid: 10227218].
178 Zarling E J, Sexton H, Milnor P J. Failure to diagnose acute myocardial infarction: the clinicopathologic experience at a large community hospital. JAMA. 1983;250:1177-1181. [pmid: 6876356].
179 Cocchi A, Franceschini G, Antonelli Incalzi R, Farina G, Vecchio F M, Carbonin P U. Clinico-pathological correlations in the diagnosis of acute myocardial infarction in the elderly. Age Ageing. 1988;17(2):87-93. [pmid: 3369341].
180 Kannel W B, Abbott R D. Incidence and prognosis of unrecognized myocardial infarction. An update on the Framingham study. N Engl J Med. 1984;311(18):1144-1147. [pmid: 6482932].
181 Rosenman R H, Friedman M, Jenkins C D, Straus R, Wurm M, Kositchek R. Clinically unrecognized myocardial infarction in the Western Collaborative Group Study. Am J Cardiol. 1967;19(6):776-782. [pmid: 6026145].
182 Medalie J H, Goldbourt U. Unrecognized myocardial infarction: five-year incidence, mortality, and risk factors. Ann Intern Med. 1976;84(5):526-531. [pmid: 132128].
183 Yano K, MacLean C J. The incidence and prognosis of unrecognized myocardial infarction in the Honolulu, Hawaii, Heart Program. Arch Intern Med. 1989;149(7):1528-1532. [pmid: 2742427].
184 Nadelmann J, Frishman W H, Ooi W L, et al. Prevalence, incidence and prognosis of recognized and unrecognized myocardial infarction in persons aged 75 years or older: The Bronx Aging Study. Am J Cardiol. 1990;66(5):533-537. [pmid: 2392974].
185 Sigurdsson E, Thorgeirsson G, Sigvaldason H, Sigfusson N. Unrecognized myocardial infarction: epidemiology, clinical characteristics, and the prognostic role of angina pectoris. The Reykjavik Study. Ann Intern Med. 1995;122(2):96-102. [pmid: 7993002].
186 Jonsdottir L S, Sigfusson N, Sigvaldason H, Thorgeirsson G. Incidence and prevalence of recognised and unrecognised myocardial infarction in women. The Reykjavik Study. Eur Heart J. 1998;19(7):1011-1018. [pmid: 9717035].
187 Sheifer S E, Gersh B J, Yanez N D 3rd, Ades P A, Burke G L, Manolio T A. Prevalence, predisposing factors, and prognosis of clinically unrecognized myocardial infarction in the elderly. J Am Coll Cardiol. 2000;35(1):119-126. [pmid: 10636269].
188 Sheifer S E, Manolio T A, Gersh B J. Unrecognized Myocardial Infarction. Ann Intern Med. 2001;135(9):801-811. [pmid: 11694105].
189 Pope J H, Aufderheide T P, Ruthazer R, et al. Missed diagnoses of acute cardiac ischemia in the emergency department. N Engl J Med. 2000;342(16):1163-1170. [pmid: 10770981].
190 McCarthy B D, Beshansky J R, D'Agostino R B, Selker H P. Missed diagnoses of acute myocardial infarction in the emergency department: results from a multicenter study. Ann Emerg Med. 1993;22(3):579-582. [pmid: 8442548].
191 Lee T H, Rouan G W, Weisberg M C, et al. Clinical characteristics and natural history of patients with acute myocardial infarction sent home from the emergency room. Am J Cardiol. 1987;60(4):219-224. [pmid: 3618483].
192 Schor S, Behar S, Modan B, Barell V, Drory J, Kariv I. Disposition of presumed coronary patients from an emergency room. A follow-up study. JAMA. 1976;236(8):941-943. [pmid: 988893].
193 Addiss D G, Shaffer N, Fowler B S, Tauxe R V. The epidemiology of appendicitis and appendectomy in the United States. Am J Epidemiol. 1990;132(5):910-925. [pmid: 2239906].
194 Graff L, Russell J, Seashore J, et al. False-negative and false-positive errors in abdominal pain evaluation: failure to diagnose acute appendicitis and unnecessary surgery. Acad Emerg Med. 2000;7(11):1244-1255. [pmid: 11073473].
195 Rao P M, Rhea J T, Novelline R A. Sensitivity and specificity of the individual CT signs of appendicitis: experience with 200 helical appendiceal CT examinations. J Comput Assist Tomogr. 1997;21(5):686-692. [pmid: 9294553].
196 Rao P M, Rhea J T, Novelline R A, Mostafavi A A, McCabe C J. Effect of computed tomography of the appendix on treatment of patients and use of hospital resources. N Engl J Med. 1998;338(3):141-146. [pmid: 9428814].
197 Flum D R, Morris A, Koepsell T, Dellinger E P. Has misdiagnosis of appendicitis decreased over time? A population-based analysis. JAMA. 2001;286(14):1748-1753. [pmid: 11594900].
198 Rao P M, Rhea J T, Rattner D W, Venus L G, Novelline R A. Introduction of appendiceal CT: impact on negative appendectomy and appendiceal perforation rates. Ann Surg. 1999;229(3):344-349. [pmid: 10077046]. [pmcid: 1191699].
199 Asnaes S, Frederiksen V, Fenger C. The value of the hospital autopsy. A study of causes and modes of death estimated before and after autopsy. Forensic Sci Int. 1983;21(1):23-32. [pmid: 6826118].
200 Baer S. Varied manifestations of dissecting aneurysm of the aorta. JAMA. 1956;161:689-692.
201 Levinson D C, Edmeades D T, Griffith G C. Dissecting aneurysm of aorta: its clinical, electrocardiographic, and laboratory features; report of 58 autopsied cases. Circulation. 1950;1:360. [pmid: 15405705].
202 Hirst A E, Johns V J, Kime S W. Dissecting aneurysm of the aorta: a review of 505 cases. Medicine (Baltimore). 1958;37:217-279. [pmcid: 126225]. [pmid: 13577293].
203 Slater E E, DeSanctis R W. The clinical recognition of dissecting aortic aneurysm. Am J Med. 1976;60(5):625-633. [pmid: 1020750].
204 Spittell P C, Spittell J A Jr, Joyce J W, et al. Clinical features and differential diagnosis of aortic dissection: experience with 236 cases (1980 through 1990). Mayo Clin Proc. 1993;68(7):642-651. [pmid: 8350637].
205 Fradet G, Jamieson W R, Janusz M T, Ling H, Miyagishima R T, Munro A I. Aortic dissection: current expectations and treatment. Experience with 258 patients over 20 years. Can J Surg. 1990;33(6):465-469. [pmid: 2253124].
206 Sullivan P R, Wolfson A B, Leckey R D, Burke J L. Diagnosis of acute thoracic aortic dissection in the emergency department. Am J Emerg Med. 2000;18(1):46-50. [pmid: 10674531].
207 Jamieson W R, Munro A I, Miyagishima R T, Allen P, Tyers G F, Gerein A N. Aortic dissection: early diagnosis and surgical management are the keys to survival. Can J Surg. 1982;25(2):145-149. [pmid: 7066774].
208 Munck W. Autopsy Findings and Clinical Diagnosis. A Comparative Study of 1000 Cases. Acta Med Scand. 1952;266(Suppl):775-781.
209 Gough J Correlation between clinical and autopsy diagnoses in a community hospital. Can Med Assoc J. Vol 133; 1985:420–422.
210 Mitchell M L. Interdepartmental quality assurance using coded autopsy results. Mod Pathol. 1993;6(1):48-52. [pmid: 8426856].
211 Tse G M, Lee J C. A 12-month review of autopsies performed at a university-affiliated teaching hospital in Hong Kong. Hong Kong Med J. 2000;6(2):190-194. [pmid: 10895143].
212 Linell F, Ostberg G. Tuberculosis in autopsy material, with special reference to cases not discovered until necropsy. Scand J Respir Dis. 1966;47(3):200-208. [pmid: 5180860].
213 Proudfoot AT, Akhtar AJ, Douglas AC, Horne NW. Miliary tuberculosis in adults. BMJ.Vol 2; 1969:273–276.
214 Ashba J K, Boyce J M. Undiagnosed tuberculosis in a general hospital. Chest. 1972;61(5):447-451. [pmid: 4625794].
215 Edlin G P. Active tuberculosis unrecognised until necropsy. Lancet. 1978;1(8065):650-652. [pmid: 76179].
216 Bobrowitz I D. Active tuberculosis undiagnosed until autopsy. Am J Med. 1982;72(4):650-658. [pmid: 7072745].
217 Lee J K, Ng T H. Undiagnosed tuberculosis in hospitalized patients--an autopsy survey. J R Soc Health. 1990;110(4):141-143. [pmid: 2121983].
218 Rieder H L, Kelly G D, Bloch A B, Cauthen G M, Snider D E Jr. Tuberculosis diagnosed at death in the United States. Chest. 1991;100(3):678-681. [pmid: 1889256].
219 DeRiemer K, Rudoy I, Schecter G F, Hopewell P C, Daley C L. The epidemiology of tuberculosis diagnosed after death in San Francisco, 1986-1995. Int J Tuberc Lung Dis. 1999;3(6):488-493. [pmid: 10383061].
220 Espinosa J A, Nolan T W. Reducing errors made by emergency physicians in interpreting radiographs: longitudinal study. BMJ. 2000;320(7237):737-740. [pmcid: 27314]. [pmid: 10720354].
221 Wolff A M, Bourke J, Campbell I A, Leembruggen D W. Detecting and reducing hospital adverse events: outcomes of the Wimmera clinical risk management program. Med J Aust. 2001;174(12):621-625. [pmid: 11480681].
222 Burton E C, Troxclair D A, Newman W P 3rd. Autopsy diagnoses of malignant neoplasms: how often are clinical diagnoses incorrect?. JAMA. 1998;280(14):1245-1248. [pmid: 9786374].
223 Eberhart C G, Morrison A, Gyure K A, Frazier J, Smialek J E, Troncoso J C. Decreasing incidence of sudden death due to undiagnosed primary central nervous system tumors. Arch Pathol Lab Med. Aug. 2001;125(8):1024-1030. [pmid: 11473451].
224 Nationwide Inpatient Sample (NIS). Agency for Healthcare Research and Quality, Rockville, MD. Available at:http://www.ahrq.gov/data/hcup/hcupnis.htm.Accessed November 21, 2001.
225 Deaths from 282 Selected Causes by 5-Year Age Groups, Race, and Sex: Each State and the District of Columbia, 1995, 1996, 1997, and 1998. National Center for Health Statistics. Available at:http://www.cdc.gov/nchs/datawh/statab/unpubd/mortabs/gmwkiii.htm.Accessed November 21, 2001.
226 Mortality data from the National Vital Statistics System.National Center for Health Statistics.Available at:http://www.cdc.gov/nchs/about/major/dvs/desc.htm.Accessed November 21, 2001.
227 Goraya T Y, Jacobsen S J, Belau P G, Weston S A, Kottke T E, Roger V L. Validation of death certificate diagnosis of out-of-hospital coronary heart disease deaths in Olmsted County, Minnesota. Mayo Clin Proc. 2000;75(7):681-687. [pmid: 10907382].
228 Cina S J, Selby D M, Clark B. Accuracy of death certification in two tertiary care military hospitals. Mil Med. 1999;164(12):897-899. [pmid: 10628165].
229 Perneger T V, Klag M J, Whelton P K. Cause of death in patients with end-stage renal disease: death certificates vs registry reports. Am J Public Health. 1993;83(12):1735-1738. [pmid: 8259805]. [pmcid: 1694925].
230 Cragle D L, Fetcher A. Risk factors associated with the classification of unspecified and/or unexplained causes of death in an occupational cohort. Am J Public Health. 1992;82(3):455-457. [pmid: 1536370]. [pmcid: 1694382].
231 Greb A E, Pauli R M, Kirby R S. Accuracy of fetal death reports: comparison with data from an independent stillbirth assessment program. Am J Public Health. 1987;77(9):1202-1206. [pmid: 3618855]. [pmcid: 1647003].
232 Corwin L E, Wolf P A, Kannel W B, McNamara P M. Accuracy of death certification of stroke: the Framingham Study. Stroke. 1982;13(6):818-821. [pmid: 7147296].
233 Percy C, Stanek E 3rd, Gloeckler L. Accuracy of cancer death certificates and its effect on cancer mortality statistics. Am J Public Health. 1981;71(3):242-250. [pmid: 7468855]. [pmcid: 1619811].
234 Gittelsohn A, Senning J. Studies on the reliability of vital and health records: I. Comparison of cause of death and hospital record diagnoses. Am J Public Health. 1979;69(7):680-689. [pmid: 453395]. [pmcid: 1619100].
235 Du Florey C, Senter M G, Acheson R M. A study of the validity of the diagnosis of stroke in mortality data. II. Comparison by computer of autopsy and clinical records with death certificates. Am J Epidemiol. 1969;89(1):15-24. [pmid: 5762816].
236 Ducic S. [Accuracy in reporting the causes of death. A comparison with diagnosis at autopsy in a series of mesotheliomas and other malignant tumors of the lung]. Can J Public Health. 1971;62(5):395-402. [pmid: 5137622].
237 Barclay T, Phillips A. The accuracy of cancer diagnosis on death certificates. Cancer. 1962;15:5-9. [pmid: 13864927].
238 Alderson M R, Meade T W. Accuracy of diagnosis on death certificates compared with that in hospital records. Br J Prev Soc Med. 1967;21(1):22-29. [pmid: 6032061].
239 Asnaes S, Paaske F. Uncertainty of determining cause of death in medicolegal material without autopsy, an autopsy study. Forensic Sci Int. 1980;15(2):103-114. [pmid: 7358323].
240 Gobbato F, Vecchiet F, Barbierato D, Melato M, Manconi R. Inaccuracy of death certificate diagnoses in malignancy: an analysis of 1,405 autopsied cases. Hum Pathol. 1982;13(11):1036-1038. [pmid: 7152507].
241 Mollo F, Bertoldo E, Grandi G, Cavallo F. Reliability of death certifications for different types of cancer. An autopsy survey. Pathol Res Pract. 1986;181(4):442-447. [pmid: 3763482].
242 Mackenbach J P, Van Duyne W M, Kelson M C. Certification and coding of two underlying causes of death in The Netherlands and other countries of the European Community. J Epidemiol Community Health. 1987;41(2):156-160. [pmid: 3655636].
243 Samphier M L, Robertson C, Bloor M J. A possible artefactual component in specific cause mortality gradients. Social class variations in the clinical accuracy of death certificates. J Epidemiol Community Health. 1988;42(2):138-143. [pmid: 3221162].
244 Nielsen G P, Bjornsson J, Jonasson J G. The accuracy of death certificates. Implications for health statistics. Virchows Arch A Pathol Anat Histopathol. 1991;419(2):143-146. [pmid: 1871957].
245 Delendi M, Riboli E, Peruzzo P, et al. Comparison of diagnoses of cancers of the respiratory system on death certificates and at autopsy.IARC Sci Publ.1991(112):55–62.
246 Di Bonito L, Stanta G, Delendi M, et al. Comparison between diagnoses on death certificates and autopsy reports in Trieste: gynaecological cancers.IARC Sci Publ.1991(112):63–71.
247 Riboli E, Stanta G, Delendi M, et al. Comparison between diagnoses of cancers of the stomach, colon, rectum, gall-bladder, liver and pancreas on death certificates and at autopsy in Trieste, 1970-84.IARC Sci Publ.1991(112):45–54.
248 Weeramanthri T S. A medical cause of death validation study of adult aboriginal deaths in the Northern Territory of Australia in 1992. Public Health. 1997;111(6):429-433. [pmid: 9392977].
249 Maclaine GD, Macarthur EB, Heathcote CR. A comparison of death certificates and autopsies in the Australian Capital Territory.Med J Aust.1992;156(7):462–463, 466–468.
250 Green A, Donald K J. Necropsy as a control of death certification: some unexpected findings. Med J Aust. 1976;2(4):131-132. [pmid: 979826].
251 Gwynne J F. Death certification in Dunedin hospitals. N Z Med J. 1977;86(592):77-81. [pmid: 271879].
252 Accuracy of death certificates in bronchial asthma. Accuracy of certification procedures during the confidential inquiry by the British Thoracic Association. A subcommittee of the BTA Research Committee. Thorax. 1984;39(7): 505–509
253 Moussa M A, Shafie M Z, Khogali M M, et al. Reliability of death certificate diagnoses. J Clin Epidemiol. 1990;43(12):1285-1295. [pmid: 2254765].
254 Engel L W, Strauchen J A, Chiazze L Jr, Heid M. Accuracy of death certification in an autopsied population with specific attention to malignant neoplasms and vascular diseases. Am J Epidemiol. 1980;111(1):99-112. [pmid: 7352463].
255 Davies SM, Geppert J, McClellan M, McDonald KM, Romano PS, Shojania KG.Refinement of the HCUP Quality Indicators. (Technical Review Number 4 from the UCSF-Stanford Evidence-based Practice Center).Rockville, MD: Agency for Healthcare Research and Quality; 2001.
256 Maynard C, Chapko M K, Every N R, Martin D C, Ritchie J L. Coronary angioplasty outcomes in the Healthcare Cost and Utilization Project, 1993-1994. Am J Cardiol. 1998;81(7):848-852. [pmid: 9555773].
257 Lanska D J, Kryscio R J. In-hospital mortality following carotid endarterectomy. Neurology. 1998;51(2):440-447. [pmid: 9710016].
258 Ritchie J L, Maynard C, Chapko M K, Every N R, Martin D C. Association between percutaneous transluminal coronary angioplasty volumes and outcomes in the Healthcare Cost and Utilization Project 1993-1994. Am J Cardiol. 1999;83(4):493-497. [pmid: 10073849].
259 Williams G R, Jiang J G, Matchar D B, Samsa G P. Incidence and occurrence of total (first-ever and recurrent) stroke. Stroke. 1999;30(12):2523-2528. [pmid: 10582972].
260 Howard T S, Hoffman L H, Stang P E, Simoes E A. Respiratory syncytial virus pneumonia in the hospital setting: length of stay, charges, and mortality. J Pediatr. 2000;137(2):227-232. [pmid: 10931416].
261 Bentham W D, Cai L, Schulman K A. Characteristics of hospitalizations of HIV-infected patients: an analysis of data from the 1994 healthcare cost and utilization project. J Acquir Immune Defic Syndr. 1999;22(5):503-508. [pmid: 10961613].
262 Astor B C, Kaczmarek R G, Hefflin B, Daley W R. Mortality after aortic valve replacement: results from a nationally representative database. Ann Thorac Surg. 2000;70(6):1939-1945. [pmid: 11156099].
263 Kim W R, Gross J B Jr, Poterucha J J, Locke G R 3rd, Dickson E R. Outcome of hospital care of liver disease associated with hepatitis C in the United States. Hepatology. 2001;33(1):201-206. [pmid: 11124837].
264 Ball J K, Elixhauser A. Treatment differences between blacks and whites with colorectal cancer. Med Care. 1996;34(9):970-984. [pmid: 8792784].
265 Gross C P, Steiner C A, Bass E B, Powe N R. Relation between prepublication release of clinical trial results and the practice of carotid endarterectomy. JAMA. 2000;284(22):2886-2893. [pmid: 11147985].
266 Romano P S, Zach A, Luft H S, Rainwater J, Remy L L, Campa D. The California Hospital Outcomes Project: using administrative data to compare hospital performance. Jt Comm J Qual Improv. 1995;21(12):668-682. [pmid: 8688923].
267 Committee on NIH Research Priority-Setting Process. Scientific opportunities and public needs: improving priority setting and public input at the National Institutes of Health.Washington, D.C.: National Academy Press; 1998.
268 Working Group on Priority Setting. Setting research priorities at the National Institutes of Health.Bethesda, Md: National Institutes of Health; 1997.
269 Gross C P, Anderson G F, Powe N R. The relation between funding by the National Institutes of Health and the burden of disease. N Engl J Med. 1999;340(24):1881-1887. [pmid: 10369852].
270 Varmus H. Evaluating the burden of disease and spending the research dollars of the National Institutes of Health. N Engl J Med. 1999;340(24):1914-1915. [pmid: 10369857].
271 Lamarre-Cliche M, Castilloux A M, LeLorier J. Association between the burden of disease and research funding by the Medical Research Council of Canada and the National Institutes of Health. A cross-sectional study. Clin Invest Med. 2001;24(2):83-89. [pmid: 11368150].
272 Welch HG, Black WC. Using autopsy series to estimate the disease “reservoir” for ductal carcinoma in situ of the breast: how much more breast cancer can we find?Ann Intern Med.Vol 127; 1997:1023–1028.
273 Chan C K, Josephy B R, Wells C K, Feinstein A R. An analysis of gastric and oesophageal cancers found with “epidemiological necropsy” during 1953-1982. Intl J Epidemiol. 1989;18:315-319.
274 Kimura W, Nagai H, Kuroda A, Morioka Y. Clinicopathologic study of asymptomatic gallbladder carcinoma found at autopsy. Cancer. 1989;64(1):98-103. [pmid: 2731127].
275 Schwartz D A, Herman C J. The importance of the autopsy in emerging and reemerging infectious diseases. Clin Infect Dis. 1996;23(2):248-254. [pmid: 8842258].
276 Frenkel J K, Baker L H, Chonko A M. Autopsy diagnosis of Legionnaires' disease in immunosuppressed patients. A paleodiagnosis using Giemsa stain (Wohlbach modification). Ann Intern Med. 1979;90(4):559-562. [pmid: 373545].
277 Hernandez F J, Kirby B D, Stanley T M, Edelstein P H. Legionnaires' disease. Postmortem pathologic findings of 20 cases. Am J Clin Pathol. 1980;73(4):488-495. [pmid: 7369172].
278 Morgello S, Cho E S, Nielsen S, Devinsky O, Petito C K. Cytomegalovirus encephalitis in patients with acquired immunodeficiency syndrome: an autopsy study of 30 cases and a review of the literature. Hum Pathol. 1987;18(3):289-297. [pmid: 3028930].
279 D'Agati V, Suh J I, Carbone L, Cheng J T, Appel G. Pathology of HIV-associated nephropathy: a detailed morphologic and comparative study. Kidney Int. 1989;35(6):1358-1370. [pmid: 2770114].
280 Foucar K, Nolte K B, Feddersen R M, et al. Outbreak of Hantavirus pulmonary syndrome in the southwestern United States. Response of pathologists and other laboratorians. Am J Clin Pathol. 1994;101(4 Suppl 1):S1-5. [pmid: 8154449].
281 Schwarcz S K, Shefer A M, Zaki S R. Retrospective diagnosis of a fatal case of the hantavirus pulmonary syndrome, 1980. West J Med. 1996;164(4):348-350. [pmid: 8732742]. [pmcid: 1303518].
282 Cabana M D, Rand C S, Powe N R, et al. Why don't physicians follow clinical practice guidelines? A framework for improvement. JAMA. 1999;282(15):1458-1465. [pmid: 10535437].
283 Shortell S M, Zazzali J L, Burns L R, et al. Implementing evidence-based medicine: the role of market pressures, compensation incentives, and culture in physician organizations. Med Care. 2001;39(7 Suppl 1):I62-78. [pmid: 11488265].
284 Oxman A D, Thomson M A, Davis D A, Haynes R B. No magic bullets: a systematic review of 102 trials of interventions to improve professional practice. CMAJ. 1995;153(10):1423-1431. [pmid: 7585368]. [pmcid: 1487455].
285 Davis D. Does CME work? An analysis of the effect of educational activities on physician performance or health care outcomes. Int J Psychiatry Med. 1998;28(1):21-39. [pmid: 9617647].
286 Davis D A, Taylor-Vaisey A. Translating guidelines into practice. A systematic review of theoretic concepts, practical experience and research evidence in the adoption of clinical practice guidelines. CMAJ. 1997;157(4):408-416. [pmcid: 1227916]. [pmid: 9275952].
287 Davis D, O'Brien M A, Freemantle N, Wolf F M, Mazmanian P, Taylor-Vaisey A. Impact of formal continuing medical education: do conferences, workshops, rounds, and other traditional continuing education activities change physician behavior or health care outcomes?. JAMA. 1999;282(9):867-874. [pmid: 10478694].
288 A controlled trial to improve care for seriously ill hospitalized patients. The study to understand prognoses and preferences for outcomes and risks of treatments (SUPPORT). The SUPPORT Principal Investigators. JAMA. 1995;274(20): 1591–1598.
289 Thomson O'Brien MA, Oxman AD, Davis DA, Haynes RB, Freemantle N, Harvey EL. Audit and feedback: effects on professional practice and health care outcomes.Cochrane Library.Oxford: Update Software; 2000.
290 Thomson O'Brien MA, Oxman AD, Davis DA, Haynes RB, Freemantle N, Harvey EL. Educational outreach visits: effects on professional practice and health care outcomes.Cochrane Library.Oxford: Update Software; 2000.
291 Thomson MA, Oxman AD, Haynes RB, Davis DA, Freemantle N, Harvey EL. Local opinion leaders to improve health professional practice and health care outcomes (Cochrane Review).The Cochrane Library.Oxford: Update Software; 1999.
292 Stenback F, Paivarinta H. Relation between clinical and autopsy diagnoses, especially as regards cancer. Scand J Soc Med. 1980;8(2):67-72. [pmid: 7209450].
293 Hartveit F. Clinical and post-mortem assessment of the cause of death. J Pathol. 1977;123(4):193-210. [pmid: 592024].
294 Veress B, Alafuzoff I. A retrospective analysis of clinical diagnoses and autopsy findings in 3,042 cases during two different time periods. Hum Pathol. 1994;25(2):140-145. [pmid: 8119713].
295 Puxty J A, Horan M A, Fox R A. Necropsies in the elderly. Lancet. 1983;1(8336):1262-1264. [pmid: 6134049].
296 Tsujimura T, Yamada Y, Kubo M, Fushimi H, Kameyama M. Why couldn't an accurate diagnosis be made? An analysis of 1044 consecutive autopsy cases. Pathol Int. 1999;49(5):408-410. [pmid: 10417683].
297 Gerain J, Sculier J P, Malengreaux A, Rykaert C, Themelin L. Causes of deaths in an oncologic intensive care unit: a clinical and pathological study of 34 autopsies. Eur J Cancer. 1990;26(3):377-381. [pmid: 2141496].
298 Zarbo R J, Baker P B, Howanitz P J. The autopsy as a performance measurement tool--diagnostic discrepancies and unresolved clinical questions: a College of American Pathologists Q-Probes study of 2479 autopsies from 248 institutions. Arch Pathol Lab Med. 1999;123(3):191-198. [pmid: 10086506].
299 Thurlbeck W M. Accuracy of clinical diagnosis in a Canadian teaching hospital. Can Med Assoc J. 1981;125(5):443-447. [pmid: 7284926]. [pmcid: 1862466].
300 Peacock S J, Machin D, Duboulay C E, Kirkham N. The autopsy: a useful tool or an old relic?. J Pathol. 1988;156(1):9-14. [pmid: 3193305].
301 Stevanovic G, Tucakovic G, Dotlic R, Kanjuh V. Correlation of clinical diagnoses with autopsy findings: a retrospective study of 2,145 consecutive autopsies. Hum Pathol. 1986;17(12):1225-1230. [pmid: 3793085].
302 West J G, Trunkey D D, Lim R C. Systems of trauma care. A study of two counties. Arch Surg. 1979;114(4):455-460. [pmid: 435058].
303 Gloth F Md, Burton J R. Autopsies and death certificates in the chronic care setting. J Am Geriatr Soc. 1990;38(2):151-155. [pmid: 2299120].
304 Mort T C, Yeston N S. The relationship of pre mortem diagnoses and post mortem findings in a surgical intensive care unit. Crit Care Med. 1999;27(2):299-303. [pmid: 10075053].
305 Stothert J C Jr, Gbaanador G. Autopsy in general surgery practice. Am J Surg. 1991;162(6):585-588. [pmid: 1670230].
306 Shanks JH, Anderson NH, McCluggage G, Toner PG. Use of the autopsy in Northern Ireland and its value in perioperative deaths.IARC Sci Publ.1991(112):115–124.
307 Whitehouse S R, Kissoon N, Singh N, Warren D. The utility of autopsies in a pediatric emergency department. Pediatr Emerg Care. 1994;10(2):72-75. [pmid: 8029113].
308 Barr P, Hunt R. An evaluation of the autopsy following death in a level IV neonatal intensive care unit. J Paediatr Child Health. 1999;35(2):185-189. [pmid: 10365358].
309 Sarode V R, Datta B N, Banerjee A K, et al. Autopsy findings and clinical diagnoses: a review of 1,000 cases. Hum Pathol. 1993;24(2):194-198. [pmid: 8432514].
310 Harris M D, Blundell J W. Audit of necropsies in a British district general hospital. J Clin Pathol. 1991;44(10):862-865. [pmcid: 496676]. [pmid: 1960222].
311 Kajiwara J K, Zucoloto S, Manco A R, Muccillo G, Barbieri M A. Accuracy of clinical diagnoses in a teaching hospital: a review of 997 autopsies. J Intern Med. 1993;234(2):181-187. [pmid: 8340741].
312 Ebbesen J, Buajordet I, Erikssen J, et al. Drug-related deaths in a department of internal medicine. Arch Intern Med. 2001;161(19):2317-2323. [pmid: 11606147].
313 Walsh C J. Autopsy rates in U.S. hospitals. PAS Rep. 1972;12(6):1-4.
314 Hasson J, Gross H. The autopsy and quality assessment of medical care. Am J Med. 1974;56(2):137-140. [pmid: 4812070].
315 Burnand B, Feinstein A R. The role of diagnostic inconsistency in changing rates of occurrence for coronary heart disease. J Clin Epidemiol. 1992;45(9):929-940. [pmid: 1432022].
316 Arthaud J B. Autopsies in the United States--frequency by states. JAMA. 1970;213(7):1195. [pmid: 5468274].
317 Lowe J A, Davis C J. Need we revive falling autopsy rates? Time trends in PAS hospitals in the United States. PAS Rep. 1977;15(12):1-7. [pmid: 10307292].
318 Nakhleh R E, Baker P B, Zarbo R J. Autopsy result utilization: a College of American Pathologists Q-probes study of 256 laboratories. Arch Pathol Lab Med. 1999;123(4):290-295. [pmid: 10320139].
319 Kabra N S, Udani R H. Correlation between clinical diagnoses at the time of death and autopsy findings in critically sick neonates at a regional neonatal intensive care unit in India. J Trop Pediatr. 2001;47:295-300. [pmid: 11695730].
320 Podbregar M, Voga G, Krivec B, Skale R, Pareznik R, Gabrscek L. Should we confirm our clinical diagnostic certainty by autopsies?. Intensive Care Med. 2001;27:1750-1755. [pmid: 11810118].
321 Ong A W, Cohn S M, Cohn K A, et al. Unexpected findings in trauma patients dying in the intensive care unit: results of 153 consecutive autopsies. J Am Coll Surg. 2002;194:401-406. [pmid: 11949744].
322 Brodlie M, Laing I A, Keeling J W, McKenzie K J. Ten years of neonatal autopsies in tertiary referral centre: retrospective study. BMJ. 2002;324:761-763. [pmcid: 100315]. [pmid: 11923158].
323 Nemetz P N, Ballard D J, Beard C M, et al. An anatomy of the autopsy, Olmstead County, 1935 through 1985. Mayo Clinic Proc. 1989;64:1055-1064.