# Appendix G: Acknowledgments

The authors gratefully acknowledge the guidance provided by members of the project advisory panel listed below. In addition, Preetha A. Basaviah, MD, Thomas E. Baudendistel, MD, and Chad Roach, BA performed many of the article abstractions/reviews, while Susan B. Nguyen, BA assisted with development and organization of the literature database and numerous other technical aspects of the project.

[underlined: Pathologist Advisors]

Richard E. Horowitz, MD—Clinical Professor of Pathology, University of Southern California and UCLA Schools of Medicine; project representative from the College of American Pathologists

George Lundberg, MD— Executive Vice-President and Editor-in-Chief, Medscape

Jean Olson, MD—Professor of Pathology and Director of the Autopsy Service at Moffitt-Long Hospitals, University of California San Francisco

[underlined: Methodologist Advisors & Quantitative Analysis]

Lisa A. Bero, PhD—Associate Professor of Clinical Pharmacy and Health Policy, University of California San Francisco; Co-Director, San Francisco Cochrane Center

Alan Bostrom, PhD - Department of Epidemiology & Biostatistics, University of California San Francisco

Gordon Guyatt, MD—Professor, Departments of Medicine and Clinical Epidemiology & Biostatistics, McMaster University

Charles E. McCulloch, PhD - Professor of Biostatistics, Department of Epidemiology & Biostatistics, University of California San Francisco

[underlined: Surgeon Advisor]

Thomas Russell, MD— Executive Director, American College of Surgeons

[underlined: Healthcare Economist]

Peter Nemetz, PhD—Professor, Faculty of Commerce and Business Administration, University of British Columbia; Senior Visiting Scientist, Department of Health Sciences Research, Mayo Clinic

[underlined: Patient Perspective (Including Impact of race/Ethnicity)]

Eliseo Perez-Stable, MD—Professor of Medicine and Chief, Division of General Internal Medicine, University of California San Francisco

Ellen Shaffer, PhD—Director of Policy, Robert Wood Johnson Patient-Provider Relationship Initiative; Consultant, Consumer Health Concerns

[underlined: Peer Reviewers]

Three of the advisors listed above (Richard Horowitz, MD, George Lundberg, MD, and Peter Nemetz, PhD) participated in the peer review process, but we also solicited reviews from the individuals listed below, whom we gratefully acknowledge for their thoughtful comments.

Stephen A. Geller, MD - Professor and Chairman, Pathology and Laboratory Medicine, Cedars Sinai Medical Center, Los Angeles, CA

Randy L. Hanzlick, MD - Chief Medical Examiner, Fulton County Medical Examiner,Atlanta, Georgia

Richard J. Hausner, MD - Medical Director, Clinical Laboratory, Cypress Fairbanks Medical Center Hospital, Houston, TX

Lee H. Hilborne, MD, MPH - Professor of Pathology and Laboratory Medicine, Director, UCLA Center for Patient Safety and Quality, University of California Los Angeles, Los Angeles, CA

Grover M. Hutchins, MD - Professor of Pathology, Johns Hopkins University School of Medicine

Joanne Lynn, MD - Director, RAND-Center to Improve Care of the Dying, Arlington, VA.

A number of Fellows of the College of American Pathologists (CAP), in addition to those already listed above, also provided very helpful comments, including Paul A. Raslavicus, MD, President, CAP, Kevin Bove, MD, Chair, CAP Autopsy Committee, Victor Weedn, MD, JD, Co-Chair Forensic Pathology/Forensic Identity Committee, and Patricia Styer, PhD of the CAP biostatistics department.