# Appendix F: Bibliography

1 Death certification and epidemiological research. Medical Services Study Group of the Royal College of Physicians of London. BMJ. 1978;2:1063–5
2 Medical aspects of death certification. A joint report of the Royal College of Physicians and the Royal College of Pathologists. J R Coll Physicians Lond. 1982;16:206–18.
3 Accuracy of death certificates in bronchial asthma. Accuracy of certification procedures during the confidential inquiry by the British Thoracic Association. A subcommittee of the BTA Research Committee. Thorax. 1984;39:505–9.
4 Autopsy. A comprehensive review of current issues. Council on Scientific Affairs. JAMA. 1987;258:364-9. [pmid: 3474424].
5 Leads from the MMWR. Autopsy frequency--United States, 1980-1985. JAMA.1988;259:2357, 62.
6 Recommendations on quality control and quality assurance in surgical pathology and autopsy pathology. The Association of Directors of Anatomic and Surgical Pathology. Mod Pathol. 1992;5:567–8.
7 Death of a child in the emergency department. American Academy of Pediatrics Committee on Pediatric Emergency Medicine. Pediatrics. 1994;93:861–2.
8 Autopsy and the use of tissues removed at autopsy. The Royal College of Pathologists of Australasia. Med J Aust. 1994;160:442–4.
9 Research after death Lancet. 1994;344:1517–8
10 Consensus recommendations for the postmortem diagnosis of Alzheimer's disease. The National Institute on Aging, and Reagan Institute Working Group on Diagnostic Criteria for the Neuropathological Assessment of Alzheimer's Disease. Neurobiol Aging. 1997;18:S1–2.
11 ACOG committee opinion. Genetic evaluation of stillbirths and neonatal deaths. Number 178, November 1996. Committee on Genetics. American College of Obstetricians and Gynecologists. Int J Gynaecol Obstet. 1997;56:287–9.
12 Working Group on Priority Setting. Setting research priorities at the National Institutes of Health. Bethesda, Md: National Institutes of Health; 1997
13 Committee on NIH Research Priority-Setting Process. Scientific opportunities and public needs: improving priority setting and public input at the National Institutes of Health. Washington, D.C.: National Academy Press; 1998
14 Collaborative overview (‘meta-analysis’) of prospective observational studies of the associations of usual blood pressure and usual cholesterol levels with common causes of death: protocol for the second cycle of the Prospective Studies Collaboration. J Cardiovasc Risk. 1999;6:315–20.
15 ACGME Internal Medicine Program requirements Accreditation Council for Graduate Medical Education. Available at: http://www.acgme.org/.Accessed November 2, 2000.
16 ACGME Pathology Program requirements Accreditation Council for Graduate Medical Education. Available at: http://www.acgme.org/.Accessed November 2, 2000.
17 CO: nurse reviews autopsy report on child: concludes artery sutured shut by surgeon. Regan Rep Nurs Law.1999;39:3.
18 Recommendation no. R (99) 3 of the Committee of Ministers to member states on the harmonization of medico-legal autopsy rules. Forensic Sci Int. 2000;111:5–58.
19 Medscape Instant Polling Medscape, Inc. Available at: http://www.medscape.com/Home/InstantPolling/QueryAPollResult.cfm?pollid=18. Accessed February 07, 2001.
20 American Academy of Pediatrics: Distinguishing sudden infant death syndrome from child abuse fatalities. Pediatrics. 2001;107:437–41.
21 Deaths from 282 Selected Causes by 5-Year Age Groups, Race, and Sex: Each State and the District of Columbia, 1995, 1996, 1997, and 1998 National Center for Health Statistics. Available at: http://www.cdc.gov/nchs/datawh/statab/unpubd/mortabs/gmwkiii.htm.Accessed November 21, 2001.
22 Abdel-Dayem H M, Naddaf S, Aziz M, Mina B, Turoglu T, Akisik M F, et al. Sites of tuberculous involvement in patients with AIDS. Autopsy findings and evaluation of gallium imaging. Clin Nucl Med. 1997;22:310-4. [pmid: 9152531].
23 Abrahams C, D'Cruz I, Kathpalia S. Abnormalities in the mitral valve apparatus in patients undergoing long-term hemodialysis. Autopsy and echocardiographic correlation. Arch Intern Med. 1982;142:1796-800. [pmid: 7125766].
24 Adams V, Carrubba C. The Abbreviated Injury Scale: application to autopsy data. Am J Forensic Med Pathol. 1998;19:246-51. [pmid: 9760090].
25 Addiss D G, Shaffer N, Fowler B S, Tauxe R V. The epidemiology of appendicitis and appendectomy in the United States. Am J Epidemiol. 1990;132:910-25. [pmid: 2239906].
26 Adickes E D, Sims K L. Enhancing autopsy performance and reporting. A system for a 5-day completion time. Arch Pathol Lab Med. 1996;120:249-53. [pmid: 8629899].
27 Agusti C, Ramirez J, Picado C, Xaubet A, Carreras E, Ballester E, et al. Diffuse alveolar hemorrhage in allogeneic bone marrow transplantation. A postmortem study. Am J Respir Crit Care Med. 1995;151:1006-10. [pmid: 7697223].
28 Ahronheim J C, Bernholc A S, Clark W D. Age trends in autopsy rates. Striking decline in late life. JAMA. 1983;250:1182-6. [pmid: 6876357].
29 Aiba I, Hashizume Y, Yoshida M, Okuda S, Murakami N, Ujihira N. Relationship between brainstem MRI and pathological findings in progressive supranuclear palsy--study in autopsy cases. J Neurol Sci. 1997;152:210-7. [pmid: 9415543].
30 Alafuzoff I, Veress B. The selection for post-mortem examination: a retrospective analysis of 74 deceased surgical cases. Qual Assur Health Care. 1993;5:345-9. [pmid: 8018894].
31 Alderson M R, Meade T W. Accuracy of diagnosis on death certificates compared with that in hospital records. Br J Prev Soc Med. 1967;21:22-9. [pmid: 6032061].
32 Ali M, Fayemi A O, Rigolosi R, Frascino J, Marsden T, Malcolm D. Hemosiderosis in hemodialysis patients. An autopsy study of 50 cases. JAMA. 1980;244:343-5. [pmid: 7392125].
33 Allard P, Yankaskas B C, Fletcher R H, Parker L A, Halvorsen R A Jr. Sensitivity and specificity of computed tomography for the detection of adrenal metastatic lesions among 91 autopsied lung cancer patients. Cancer. 1990;66:457-62. [pmid: 2163745].
34 Allsbrook W C Jr, Mangold K A, Johnson M H, Lane R B, Lane C G, Epstein J I. Interobserver reproducibility of Gleason grading of prostatic carcinoma: general pathologist. Hum Pathol. 2001;32:81-8. [pmid: 11172299].
35 Allsbrook W C Jr, Mangold K A, Johnson M H, Lane R B, Lane C G, Amin M B, et al. Interobserver reproducibility of Gleason grading of prostatic carcinoma: urologic pathologists. Hum Pathol. 2001;32:74-80. [pmid: 11172298].
36 Amador E, Li T K, Crane C. Ligation of inferior vena cava for thromboembolism. Clinical and autopsy correlations in 119 cases. JAMA. 1968;206:1758-60. [pmid: 5754825].
37 Amato D. Autopsies in Papua New Guinea. Papua New Guinea Medical Journal. 1977;20:53-6. [pmid: 271429].
38 Ambrus J L, Ambrus C M, Mink I B, Pickren J W. Causes of death in cancer patients. J Med. 1975;6:61-4. [pmid: 1056415].
39 Andaker L, Morales O, Hojer H, Backstrand B, Borch K, Larsson J. Evaluation of preoperative computed tomography in gastric malignancy. Surgery. 1991;109:132-5. [pmid: 1992545].
40 Andersen HR, Falk E, Nielsen D. Right ventricular infarction: diagnostic accuracy of electrocardiographic right chest leads V3R to V7R investigated prospectively in 43 consecutive fatal cases from a coronary care unit. Br Heart J.1989;61:514–20. Published erratum appears in Br Heart J 1989;62:328.
41 Anderson R E, Ishida K, Li Y, Ishimaru T, Nishiyama H. Geographic aspects of malignant lymphoma and multiple myeloma. Select comparisons involving Japan, England and the United States. Am J Pathol. 1970;61:85-97. [pmid: 4922952].
42 Anderson R E, Key C R, Yamamoto T, Thorslund T. Aging in Hiroshima and Nagasaki atomic bomb survivors. Speculations based upon the age-specific mortality of persons with malignant neoplasms. Am J Pathol. 1974;75:1-11. [pmid: 4825615]. [pmcid: 1910816].
43 Anderson R E, Hill R B, Goodale F. Combined or separate academic departments of clinical and morphologic pathology: a pragmatic approach. Hum Pathol. 1976;7:489-92. [pmid: 964976].
44 Anderson R E, Weston J T, Craighead J E, Lacy P E, Wissler R W, Hill R B. The autopsy. Past, present, and future. JAMA. 1979;242:1056-9. [pmid: 470046].
45 Anderson R E, Hill R B. The autopsy: instrument of quality assessment. Pathologist. 1979;33:629-30. [pmid: 10244390].
46 Anderson J R. Too few necropsies. BMJ. 1979;2:13.
47 Anderson R E. The autopsy as an instrument of quality assessment. Classification of premortem and postmortem diagnostic discrepancies. Arch Pathol Lab Med. 1984;108:490-3. [pmid: 6547301].
48 Anderson R E. Autopsy-related initiatives in the United States: current status and suggestions for the future. Hum Pathol. 1987;18:977-9. [pmid: 3653881].
49 Anderson R E, Hill R B. The autopsy in academic medical centers in the United States. Hum Pathol. 1988;19:1369-71. [pmid: 3192204].
50 Anderson R E. How autopsy can be used in quality assessment. QA Rev. 1989;1:2-3. [pmid: 10313582].
51 Anderson R E, Hill R B. The current status of the autopsy in academic medical centers in the United States. Am J Clin Pathol. 1989;92:S31-7. [pmid: 2801621].
52 Anderson R E, Hill R B, Key C R. The sensitivity and specificity of clinical diagnostics during five decades. Toward an understanding of necessary fallibility. JAMA. 1989;261:1610-7. [pmid: 2645451].
53 Anderson R E, Hill R B, Gorstein F. A model for the autopsy-based quality assessment of medical diagnostics. Hum Pathol. 1990;21:174-81. [pmid: 2307445].
54 Anderson R E, Fox R C, Hill R B. Medical uncertainty and the autopsy: occult benefits for students. Hum Pathol. 1990;21:128-35. [pmid: 2307439].
55 Anderson R E, Hill R B, Broudy D W, Key C R, Pathak D. A population-based autopsy study of sudden, unexpected deaths from natural causes among persons 5 to 39 years old during a 12-year period. Hum Pathol. 1994;25:1332-40. [pmid: 8001928].
56 Andersson R E, Hugander A P, Ghazi S H, Ravn H, Offenbartl S K, Nystrom P O, et al. Why does the clinical diagnosis fail in suspected appendicitis?. Eur J Surg. 2000;166:796-802. [pmid: 11071167].
57 Andrion A, Magnani C, Betta P G, Donna A, Mollo F, Scelsi M, et al. Malignant mesothelioma of the pleura: interobserver variability. J Clin Pathol. 1995;48:856-60. [pmcid: 502876]. [pmid: 7490321].
58 Angrist A. What Remedies for the Ailing Autopsy?. JAMA. 1965;193:806-08. [pmid: 14329980].
59 Applegate K E, Sivit C J, Salvator A E, Borisa V J, Dudgeon D L, Stallion A E, et al. Effect of cross-sectional imaging on negative appendectomy and perforation rates in children. Radiology. 2001;220:103-7. [pmid: 11425980].
60 Arnett E N, Isner J M, Redwood D R, Kent K M, Baker W P, Ackerstein H, et al. Coronary artery narrowing in coronary heart disease: comparison of cineangiographic and necropsy findings. Ann Intern Med. 1979;91:350-6. [pmid: 475165].
61 Aronsohn R S. The “routine” autopsy -- community hospital pathologist's view. J Fla Med Assoc. 1981;68:345-6. [pmid: 7264588].
62 Arthaud J B. Cause of death in 339 Alaskan natives as determined by autopsy. Arch Pathol. 1970;90:433-8. [pmid: 5476239].
63 Arthaud J B. Autopsies in the United States--frequency by states. JAMA. 1970;213:1195. [pmid: 5468274].
64 Ashba J K, Boyce J M. Undiagnosed tuberculosis in a general hospital. Chest. 1972;61:447-51. [pmid: 4625794].
65 Ashton-Key M, Gallagher P J. The value of simple morphometric techniques in the diagnosis of osteoporosis. Pathol Res Pract. 1992;188:616-9. [pmid: 1409099].
66 Asnaes S, Paaske F. Uncertainty of determining cause of death in medicolegal material without autopsy, an autopsy study. Forensic Sci Int. 1980;15:103-14. [pmid: 7358323].
67 Asnaes S. Uncertainty of determining mode and cause of death without autopsy: an autopsy study of medically unattended non-medicolegal deaths. Forensic Sci Int. 1980;15:191-6. [pmid: 7390344].
68 Asnaes S. The importance of medico-legal autopsies. An analysis of the complex problems regarding damages. Forensic Sci Int. 1983;23:123-7. [pmid: 6662439].
69 Asnaes S, Frederiksen V, Fenger C. The value of the hospital autopsy. A study of causes and modes of death estimated before and after autopsy. Forensic Sci Int. 1983;21:23-32. [pmid: 6826118].
70 Association AM. Program requirements for residency education in internal medicine. Grad Med Educ Dir.1996-1997:72–84.
71 Avrahami R, Watemberg S, Hiss Y, Deutsch A A. Laparoscopic vs conventional autopsy. A promising perspective. Arch Surg. 1995;130:407-9. [pmid: 7710341].
72 Avrahami R, Watemberg S, Daniels-Philips E, Kahana T, Hiss J. Endoscopic autopsy. Am J Forensic Med Pathol. 1995;16:147-50. [pmid: 7572871].
73 Avrahami R, Watemberg S, Hiss Y. Thoracoscopy vs conventional autopsy of the thorax. A promising perspective. Arch Surg. 1995;130:956-8. [pmid: 7661679].
74 Awotedu A A, Igbokwe E O, Akang E E, Aghadiuno P O. Pulmonary embolism in Ibadan, Nigeria: five years autopsy report. Cent Afr J Med. 1992;38:432-5. [pmid: 1308838].
75 Baer S. Varied manifestations of dissecting aneurysm of the aorta. JAMA. 1956;161:689-92.
76 Baglin T P, White K, Charles A. Fatal pulmonary embolism in hospitalised medical patients. J Clin Pathol. 1997;50:609-10. [pmcid: 500077]. [pmid: 9306945].
77 Baker P B, Hanzlick R. Case of the month: death and devices. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1999;159:21-2. [pmid: 9892325].
78 Baldessarini RJ, Hegarty JD, Bird ED, Benes FM. Meta-analysis of postmortem studies of Alzheimer's disease-like neuropathology in schizophrenia. Am J Psychiatry.1997;154:861–3. Published erratum appears in Am J Psychiatry 1997;154(8):1180.
79 Balic V, Rumboldt Z, Sanner M. Public attitudes toward autopsy, organ donation, and dissection. JAMA. 1995;273:1907. [pmid: 7783296].
80 Balthazar E J, Rofsky N M, Zucker R. Appendicitis: the impact of computed tomography imaging on negative appendectomy and perforation rates. Am J Gastroenterol. 1998;93:768-71. [pmid: 9625125].
81 Banker D D. Importance of autopsy in prevention of epidemics. Indian J Med Sci. 1999;53:228-30. [pmid: 10695234].
82 Barbant S D, Eisenberg M J, Schiller N B. The diagnostic value of imaging techniques for aortic dissection. Am Heart J. 1992;124:541-3. [pmid: 1636607].
83 Barclay T, Phillips A. The accuracy of cancer diagnosis on death certificates. Cancer. 1962;15:5-9. [pmid: 13864927].
84 Barendregt W B, de Boer H H, Kubat K. Autopsy analysis in surgical patients: a basis for clinical audit. Br J Surg. 1992;79:1297-9. [pmid: 1486423].
85 Barendregt W B, de Boer H H, Kubat K. The results of autopsy of patients with surgical diseases of the digestive tract. Surg Gynecol Obstet. 1992;175:227-32. [pmid: 1514156].
86 Barendregt W B, de Boer H H, Kubat K. Quality control in fatally injured patients: the value of the necropsy. Eur J Surg. 1993;159:9-13. [pmid: 8095812].
87 Barr P, Hunt R. An evaluation of the autopsy following death in a level IV neonatal intensive care unit. J Paediatr Child Health. 1999;35:185-9. [pmid: 10365358].
88 Barth P, Rossberg C, Koch S, Ramaswamy A. Pulmonary aspergillosis in an unselected autopsy series. Pathol Res Pract. 2000;196:73-80. [pmid: 10707362].
89 Barton L, Hodgman J E, Pavlova Z. Causes of death in the extremely low birth weight infant. Pediatrics. 1999;103:446-51. [pmid: 9925839].
90 Basilio-De-Oliveira C. Infectious and Neoplastic Disorders of the Thyroid in AIDS Patients: An Autopsy Study. Braz J Infect Dis. 2000;4:67-75. [pmid: 10795071].
91 Battle R M, Pathak D, Humble C G, Key C R, Vanatta P R, Hill R B, et al. Factors influencing discrepancies between premortem and postmortem diagnoses. JAMA. 1987;258:339-44. [pmid: 3599326].
92 Bauer F W, Robbins S L. An autopsy study of cancer patients. I. Accuracy of the clinical diagnoses (1955 to 1965) Boston City Hospital. JAMA. 1972;221:1471-4. [pmid: 5068646].
93 Beadenkopf W G, Abrams M, Daoud A, Marks R U. An assessment of certain medical aspects of death certificate data for epidemiologic study of arteriosclerotic heart disease. J Chronic Dis. 1963;16:249-62. [pmid: 13969915].
94 Beadenkopf W G. Some demographic characteristics of an autopsied population. J Chron Dis. 1965;18:333-51. [pmid: 14273697].
95 Beanum E, Child M A. Autopsy rates in hospitals. PAS Rep. 1972;10:1-4.
96 Bedell S E, Fulton E J. Unexpected findings and complications at autopsy after cardiopulmonary resuscitation (CPR). Arch Intern Med. 1986;146:1725-8. [pmid: 3753112].
97 Belzberg H, Rivkind A I. It always pays to make a diagnosis: to autopsy or not to autopsy?. Crit Care Med. 1998;26:1299-300. [pmid: 9710078].
98 Benbow E W. Medical students' views on necropsies. J Clin Pathol. 1990;43:969-76. [pmcid: 502967]. [pmid: 2266182].
99 Benbow E W. Autopsy demonstrations to medical students: audit by questionnaire. J Pathol. 1990;162:177-9. [pmid: 2250196].
100 Benbow E W. Why show autopsies to medical students?. J Pathol. 1990;162:187-8. [pmid: 2133987].
101 Benbow E W. The attitudes of second- and third-year medical students to the autopsy. A survey by postal questionnaire. Arch Pathol Lab Med. 1991;115:1171-6. [pmid: 1747039].
102 Bengtsson H, Sonesson B, Bergqvist D. Incidence and prevalence of abdominal aortic aneurysms, estimated by necropsy studies and population screening by ultrasound. Ann N Y Acad Sci. 1996;800:1-24. [pmid: 8958978].
103 Bennett A T, Collins K A, Hanzlick R. Outcome analysis and quality assessment. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1999;159:1399-400. [pmid: 10399890].
104 Berg J W, Downing A, Lukes R J. Prevalence of undiagnosed cancer of the large bowel found at autopsy in different races. Cancer. 1970;25:1076-80. [pmid: 5443730].
105 Berger J T. Culture and ethnicity in clinical care. Arch Intern Med. 1998;158:2085-90. [pmid: 9801174].
106 Bergqvist D, Lindblad B. A 30-year survey of pulmonary embolism verified at autopsy: an analysis of 1274 surgical patients. Br J Surg. 1985;72:105-8. [pmid: 3971113].
107 Berlin A, Wagstaff R, Bhopal R, Spencer J. Postmortem examinations: general practitioners' knowledge, behaviour, and attitudes. BMJ. 1994;308:1080-1. [pmid: 8173429].
108 Berman J J, Moore G W, Hutchins G M. Internet autopsy database. Hum Pathol. 1997;28:393-4. [pmid: 9104935].
109 Bernicker E H, Atmar R L, Schaffner D L, Greenberg S B. Unanticipated diagnoses found at autopsy in an urban public teaching hospital. Am J Med Sci. 1996;311:215-20. [pmid: 8615396].
110 Berthrong M. The autopsy as a vehicle for the lifetime education of pathologists. Arch Pathol Lab Med. 1984;108:506-9. [pmid: 6547304].
111 Berzlanovich A, Muhm M, Sim E, Bauer G. Foreign body asphyxiation--an autopsy study. Am J Med. 1999;107:351-5. [pmid: 10527037].
112 Bhatia S, Ranadive N, Manek R, Deodhar K. Autopsy study of patients dying of bleeding diathesis. Indian J Pathol Microbiol. 1998;41:71-6. [pmid: 9581080].
113 Bierig J R. A potpourri of legal issues relating to the autopsy. Arch Pathol Lab Med. 1996;120:759-62. [pmid: 8718902].
114 Bierig J R. Actions for damages against medical examiners and the defense of sovereign immunity. Clinics in Laboratory Medicine. 1998;18:139-50. [pmid: 9523069].
115 Birdi K S, Bunce D J, Start R D, Cotton D W. Clinician beliefs underlying autopsy requests. Postgrad Med J. 1996;72:224-8. [pmid: 8733531].
116 Bisi H, Ruggeri G, Longatto F A, de CR, Fernandes V, Abdo A. Neoplastic and non-neoplastic thyroid lesions in autopsy material: historical review of six decades in Sao Paulo, Brazil. Tumori. 1998;84:499-503. [pmid: 9825004].
117 Bjornsson J, Hanzlick R. Case of the month: “Negative” results of autopsy and elusive cause of death. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1998;158:1399-400. [pmid: 9665347].
118 Black W C, Nease R F Jr, Welch H G. Determining transition probabilities from mortality rates and autopsy findings. Medical Decision Making. 1997;17:87-93. [pmid: 8994155].
119 Blackhall L J, Murphy S T, Frank G, Michel V, Azen S. Ethnicity and attitudes toward patient autonomy. JAMA. 1995;274:820-5. [pmid: 7650806].
120 Blackhall L J, Frank G, Murphy S T, Michel V, Palmer J M, Azen S P. Ethnicity and attitudes towards life sustaining technology. Soc Sci Med. 1999;48:1779-89. [pmid: 10405016].
121 Blackmon J A, Harley R A, Hicklin M D, Chandler F W. Pulmonary sequelae of acute Legionnaires' disease pneumonia. Ann Intern Med. 1979;90:552-4. [pmid: 434633].
122 Blankenhorn D H, Curry P J. The accuracy of arteriography and ultrasound imaging for atherosclerosis measurement. A review. Arch Pathol Lab Med. 1982;106:483-9. [pmid: 6896977].
123 Bleggi-Torres L F, de Medeiros B C, Werner B, Neto J Z, Loddo G, Pasquini R, et al. Neuropathological findings after bone marrow transplantation: an autopsy study of 180 cases. Bone Marrow Transplant. 2000;25:301-7. [pmid: 10673702].
124 Blosser S A, Zimmerman H E, Stauffer J L. Do autopsies of critically ill patients reveal important findings that were clinically undetected?. Crit Care Med. 1998;26:1332-6. [pmid: 9710090].
125 Bobrowitz I D. Active tuberculosis undiagnosed until autopsy. Am J Med. 1982;72:650-8. [pmid: 7072745].
126 Boers M, Nieuwenhuyzen Kruseman A C, Eulderink F, Hermans J, Thompson J. Value of autopsy in internal medicine: a 1-year prospective study of hospital deaths. Eur J Clin Invest. 1988;18:314-20. [pmid: 3138134].
127 Bohrod M G. Uses of the Autopsy. JAMA. 1965;193:810-12. [pmid: 14329982].
128 Bombi J A, Cardesa A. The clinical autopsy. Medicina Clinica. 1986;86:328-31. [pmid: 3713357].
129 Bonfiglio T, Atwater E C. Heart disease in patients with seropositive rheumatoid arthritis; a controlled autopsy study and review. Arch Intern Med. 1969;124:714-9. [pmid: 4901063].
130 Bonner G J, Darkwa O K, Gorelick P B. Autopsy recruitment program for African Americans. Alzheimer Dis Assoc Disord. 2000;14:202-8. [pmid: 11186597].
131 Bordin P, Da Col P G, Peruzzo P, Stanta G, Guralnik J M, Cattin L. Causes of death and clinical diagnostic errors in extreme aged hospitalized people: a retrospective clinical-necropsy survey. J Gerontol A Biol Sci Med Sci. 1999;54:M554-9. [pmid: 10619317].
132 Bosman F T. The status of autopsies; the analysis of clinical pathology. Nederlands Tijdschrift voor Geneeskunde. 1990;134:1340-3. [pmid: 2374621].
133 Botega N J, Metze K, Marques E, Cruvinel A, Moraes Z V, Augusto L, et al. Attitudes of medical students to necropsy. J Clin Pathol. 1997;50:64-6. [pmcid: 499716]. [pmid: 9059360].
134 Bove K E. Practice guidelines for autopsy pathology: the perinatal and pediatric autopsy. Autopsy Committee of the College of American Pathologists. Arch Pathol Lab Med. 1997;121:368-76. [pmid: 9140305].
135 Bowman H E, Williams M J. Revitalizing the ultimate medical consultation. College of American Pathologists Foundation Conference on the Autopsy. Snowmass, Colo., July 20–23, 1983. Arch Pathol Lab Med. 1984;108:437-512. [pmid: 6547291].
136 Boyd J C, Marr J J. Decreasing reliability of acid-fast smear techniques for detection of tuberculosis. Ann Intern Med. 1975;82:489-92. [pmid: 1091188].
137 Brand I R, Kaminopetros P, Cave M, Irving H C, Lilford R J. Specificity of antenatal ultrasound in the Yorkshire Region: a prospective study of 2261 ultrasound detected anomalies. Br J Obstet Gynaecol. 1994;101:392-7. [pmid: 8018609].
138 Brennan T A, Leape L L, Laird N M, Hebert L, Localio A R, Lawthers A G, et al. Incidence of adverse events and negligence in hospitalized patients. Results of the Harvard Medical Practice Study I. N Engl J Med. 1991;324:370-6. [pmid: 1987460].
139 Brenner H. Effects of misdiagnoses on disease monitoring with capture--recapture methods. J Clin Epidemiol. 1996;49:1303-7. [pmid: 8892499].
140 Brenner H. How independent are multiple ‘independent’ diagnostic classifications?. Statistics in Medicine. 1996;15:1377-86. [pmid: 8841648].
141 Briggs R C. Quality of death certificate as compared to autopsy findings. Ariz Med. 1975;32:617-9. [pmid: 1164197].
142 Brinkmann B. Harmonization of medico-legal autopsy rules. Committee of Ministers. Council of Europe. Int J Legal Med. 1999;113:1-14. [pmid: 10654232].
143 Britton M. The consequences of informing relatives of intended autopsy in conjunction with death in hospital. Acta Sociomed Scand. 1972;4:37-58. [pmid: 5081884].
144 Britton M. Should relatives be informed that autopsy is intended? Opinions of relatives with recent experience. Scand J Soc Med. 1973;1:81-90. [pmid: 4771125].
145 Britton M. Clinical diagnostics: experience from 383 autopsied cases. Acta Med Scand. 1974;196:211-9. [pmid: 4421018].
146 Britton M. Diagnostic errors discovered at autopsy. Acta Med Scand. 1974;196:203-10. [pmid: 4422553].
147 Britton M. The role of autopsy findings in multicenter treatment evaluations as exemplified by two aspirin trials. Qual Assur Health Care. 1993;5:299-302. [pmid: 8018886].
148 Britton M. The role of autopsies in medical audit: examples from a department of medicine. Qual Assur Health Care. 1993;5:287-90. [pmid: 8018883].
149 Brodlie M, Laing I A, Keeling J W, McKenzie K J. Ten years of neonatal autopsies in tertiary referral centre: retrospective study. BMJ. 2002;324:761-763. [pmcid: 100315]. [pmid: 11923158].
150 Brody JE. A Price to Pay as Autopsies Lose Favor. New York Times January 9 2001.
151 Brookes J A, Hall-Craggs M A, Sams V R, Lees W R. Non-invasive perinatal necropsy by magnetic resonance imaging. Lancet. 1996;348:1139-41. [pmid: 8888168].
152 Brookes J S, Hall-Craggs M A. Postmortem perinatal examination: the role of magnetic resonance imaging. Ultrasound Obstet Gynecol. 1997;9:145-7. [pmid: 9165676].
153 Brooks J P, Dempsey J. How can hospital autopsy rates be increased?. Arch Pathol Lab Med. 1991;115:1107-11. [pmid: 1747028].
154 Brown H G. Lay perceptions of autopsy. Arch Pathol Lab Med. 1984;108:446-8. [pmid: 6547294].
155 Brown H G. Perceptions of the autopsy: views from the lay public and program proposals. Hum Pathol. 1990;21:154-8. [pmid: 2307442].
156 Bubendorf L, Schopfer A, Wagner U, Sauter G, Moch H, Willi N, et al. Metastatic patterns of prostate cancer: an autopsy study of 1,589 patients. Hum Pathol. 2000;31:578-83. [pmid: 10836297].
157 Bullock M, Diniz D. Suffocation using plastic bags: a retrospective study of suicides in Ontario, Canada. J Forensic Sci. 2000;45:608-13. [pmid: 10855966].
158 Burchfield D J, Rawlings D J. Sudden deaths and apparent life-threatening events in hospitalized neonates presumed to be healthy. Am J Dis Child. 1991;145:1319-22. [pmid: 1842214].
159 Burgess B L, Roberts P, Boguski J, Lovell D, Chase D C, Goldman M H. Occult disease in tissue and organ donors--a case for routine autopsy. Transplantation. 1994;58:734-5. [pmid: 7940699].
160 Burke M C, Aghababian R V, Blackbourne B. Use of autopsy results in the emergency department quality assurance plan. Ann Emerg Med. 1990;19:363-6. [pmid: 2321819].
161 Burke A P, Farb A, Sessums L, Virmani R. Causes of sudden cardiac death in patients with replacement valves: an autopsy study. J Heart Valve Dis. 1994;3:10-6. [pmid: 8162204].
162 Burnand B, Feinstein A R. The role of diagnostic inconsistency in changing rates of occurrence for coronary heart disease. J Clin Epidemiol. 1992;45:929-40. [pmid: 1432022].
163 Burns R J. A review of failure to obtain autopsy. Aust Clin Rev. 1983;10:16-8. [pmid: 6661107].
164 Burrow G N, Wortzman G, Rewcastle N B, Holgate R C, Kovacs K. Microadenomas of the pituitary and abnormal sellar tomograms in an unselected autopsy series. N Engl J Med. 1981;304:156-8. [pmid: 7442734].
165 Burrows S. The postmortem examination. Scientific necessity or folly?. JAMA. 1975;233:441-3. [pmid: 1173855].
166 Burton E C, Troxclair D A, Newman W P 3rd. Autopsy diagnoses of malignant neoplasms: how often are clinical diagnoses incorrect?. JAMA. 1998;280:1245-8. [pmid: 9786374].
167 Burton EC. The dying autopsy: time to resuscitate Hospital Practice (Office Edition).1999;34:15–6, 23.
168 Burton EC, McPhee SJ. Autopsy Overview. Chapter to appear in forthcoming publication of:. In: Collins KA, Hutchins GM, editors. Autopsy Performance and Reporting. 2nd ed. Northfield, Ill: College of American Pathologists; 2000
169 Burton EC, Nemetz PN Medscape, Inc. Medical error and outcomes measures: where have all the autopsies gone? Available at: http://www.medscape.com/medscape/GeneralMedicine/journal/2000/v02.n02/mgm0428.burt/mgm0428.burt.html.Accessed May 1, 2000.
170 Burton E C, Nemetz P N, Fisher W P J, Newman W P I. Institutional characteristics associated with hospital autopsy performance: A survey of Louisiana hospitals [Abstract]. Am J Clin Pathol. 2001;116:590.
171 Busby W, Bayer A, Pathy J. Pulmonary embolism in the elderly. Age Ageing. 1988;17:205-9. [pmid: 3389249].
172 Byard R W, MacKenzie J, Beal S M. Formal retrospective case review and sudden infant death. Acta Paediatr. 1997;86:1011-2. [pmid: 9343287].
173 Cabot R C. Diagnostic pitfalls identified during a study of three thousand autopsies. JAMA. 1912;59:2295-8.
174 Cameron H M, McGoogan E, Clarke J, Wilson B A. Trends in hospital necropsy rates: Scotland 1961-74. BMJ. 1977;1:1577-80. [pmid: 871672]. [pmcid: 1607308].
175 Cameron H M, McGoogan E, Watson H. Necropsy: a yardstick for clinical diagnoses. BMJ. 1980;281:985-8. [pmid: 7427553]. [pmcid: 1714385].
176 Cameron H M, McGoogan E. A prospective study of 1152 hospital autopsies: I. Inaccuracies in death certification. J Pathol. 1981;133:273-83. [pmid: 7241267].
177 Cameron H M. The autopsy as a clinical investigation. J R Soc Med. 1981;74:713-5. [pmid: 7288778]. [pmcid: 1439241].
178 Cameron H M, McGoogan E. A prospective study of 1152 hospital autopsies: II. Analysis of inaccuracies in clinical diagnoses and their significance. J Pathol. 1981;133:285-300. [pmid: 7241268].
179 Cameron H M. Future of the hospital autopsy. Br J Hosp Med. 1988;40:335. [pmid: 3233445].
180 Cameron HM. The role of the autopsy in assessing clinical diagnoses. IARC Scientific Publications (Lyon).1991:75–9.
181 Campman S C. A piece of my mind A ‘novel’ idea?. JAMA. 1994:272-990.
182 Carroll S G, Porter H, Abdel-Fattah S, Kyle P M, Soothill P W. Correlation of prenatal ultrasound diagnosis and pathologic findings in fetal brain abnormalities. Ultrasound Obstet Gynecol. 2000;16:149-53. [pmid: 11117085].
183 Carson S C, Hertzberg B S, Bowie J D, Burger P C. Value of sonography in the diagnosis of intracranial hemorrhage and periventricular leukomalacia: a postmortem study of 35 cases. AJR Am J Roentgenol. 1990;155:595-601. [pmid: 2117361].
184 Cartlidge P H, Dawson A T, Stewart J H, Vujanic G M. Value and quality of perinatal and infant postmortem examinations: cohort analysis of 400 consecutive deaths. BMJ. 1995;310:155-8. [pmid: 7833753].
185 Cartlidge P H, Stewart J H. Effect of changing the stillbirth definition on evaluation of perinatal mortality rates. Lancet. 1995;346:486-8. [pmid: 7637485].
186 Carvalho F M, Widmer M R, Cruz M, Palomo V, Cruz C. Clinical diagnosis versus autopsy. Bull Pan Am Health Organ. 1991;25:41-6. [pmid: 2054551].
187 Castensson A, Emilsson L, Preece P, Jazin a E. High-resolution Quantification of Specific mRNA Levels in Human Brain Autopsies and Biopsies. Genome Res. 2000;10:1219-29. [pmcid: 310892]. [pmid: 10958640].
188 Catheline J M, Turner R, Guettier C, Champault G. Autopsy can be performed laparoscopically. Surg Endosc. 1999;13:1163-4. [pmid: 10556463].
189 Cechner R L, Chamberlain W, Carter J R, Milojkovic-Mirceta L, Nash N P. Misdiagnosis of bronchogenic carcinoma: the role of cigarette smoking, surveillance bias, and other factors. Cancer. 1980;46:190-9. [pmid: 7388760].
190 Champ C, Tyler X, Andrews P S, Coghill S B. Improve your hospital autopsy rate to 40–50 per cent, a tale of two towns. J Pathol. 1992;166:405-7. [pmid: 1517894].
191 Chan C K, Wells C K, McFarlane M J, Feinstein A R. More lung cancer but better survival. Implications of secular trends in “necropsy surprise” rates. Chest. 1989;96:291-6. [pmid: 2787730].
192 Chan C K, Josephy B R, Wells C K, Feinstein A R. An analysis of gastric and oesophageal cancers found with “epidemiological necropsy” during 1953-1982. Intl J Epidemiol. 1989;18:315-19.
193 Chana J, Rhys-Maitland R, Hon P, Scott P, Thomas C, Hopkins A. Who asks permission for an autopsy?. J R Coll Physicians Lond. 1990;24:185-8. [pmid: 2213673].
194 Chandrasekar P H, Weinmann A, Shearer C. Autopsy-identified infections among bone marrow transplant recipients: a clinico-pathologic study of 56 patients. Bone Marrow Transplantation Team. Bone Marrow Transplant. 1995;16:675-81. [pmid: 8547865].
195 Chariot P, Witt K, Pautot V, Porcher R, Thomas G, Zafrani E S, et al. Declining autopsy rate in a French hospital: physicians' attitudes to the autopsy and use of autopsy material in research publications. Arch Pathol Lab Med. 2000;124:739-45. [pmid: 10782159].
196 Charlton R. Autopsy and medical education: a review. J R Soc Med. 1994;87:232-6. [pmid: 8182683]. [pmcid: 1294451].
197 Chau K Y, Yuen S T, Ng T H, Ng W F. An autopsy study of pulmonary thromboembolism in Hong Kong Chinese. Pathology. 1991;23:181-4. [pmid: 1780185].
198 Chau K Y, Yuen S T, Wong M P. Seasonal variation in the necropsy incidence of pulmonary thromboembolism in Hong Kong. J Clin Pathol. 1995;48:578-9. [pmcid: 502694]. [pmid: 7665706].
199 Chau K Y, Yuen S T, Wong M P. Clinicopathological pattern of pulmonary thromboembolism in Chinese autopsy patients: comparison with Caucasian series. Pathology. 1997;29:263-6. [pmid: 9271012].
200 Cheng CT, Tai GK. Sudden, unexpected deaths in adults: clinical-pathological correlations and legal considerations. Legal Medicine.1992:31–48.
201 Chernof D. The role of managed health care organizations in autopsy reimbursement. Arch Pathol Lab Med. 1996;120:771-2. [pmid: 8718905].
202 Chescheir N C, Reitnauer P J. A comparative study of prenatal diagnosis and perinatal autopsy. J Ultrasound Med. 1994;13:451-6. [pmid: 8083945].
203 Chiswick M. Perinatal and infant postmortem examination. BMJ. 1995;310:141-2. [pmid: 7833738].
204 Christie R W. The ultimate audit. JAMA. 1985;253:11.
205 Chute CG, Ballard DJ, Nemetz PN. Contributions of autopsy to population-based cancer epidemiology: targetted intervention to improve ascertainment. IARC Scientific Publications (Lyon).1991:207–16.
206 Cina S, Thompson W, Fischer J J, Brown D, Titus J, Smialek J. A study of various morphologic variables and troponin I in pericardial fluid as possible discriminators of sudden cardiac death. Am J Forensic Med Pathol. 1999;20:333-7. [pmid: 10624925].
207 Cina S J, Selby D M, Clark B. Accuracy of death certification in two tertiary care military hospitals. Mil Med. 1999;164:897-9. [pmid: 10628165].
208 Clark M A. The value of the hospital autopsy. Is it worth the cost?. American Journal of Forensic Medicine & Pathology. 1981;2:231-7. [pmid: 7325133].
209 Clark C G. A surgeon's expectations of the autopsy. J R Coll Physicians Lond. 1985;19:72-3. [pmid: 3999053].
210 Clarke C, Whitfield A G. The autopsy in deaths under fifty. J R Coll Physicians Lond. 1982;16:152-8. [pmid: 7108823].
211 Clayton S A, Sivak S L. Improving the autopsy rate at a university hospital. Am J Med. 1992;92:423-8. [pmid: 1558088].
212 Cline M K, Baxley E G, Montgomery R P. Papanicolaou smear discrepancy: resolution by review. J Am Board Fam Pract. 1994;7:9-13. [pmid: 8135142].
213 Clyman R I, Green C, Rowe J, Mikkelsen C, Ataide L. Issues concerning parents after the death of their newborn. Critical Care Medicine. 1980;8:215-8. [pmid: 7357875].
214 Cocchi A, Vecchio FM, Pahor M, Antico L, Franceschini G, Farina G, et al. Autopsy rate in younger and older hospitalized patients. Eur J Epidemiol.1986;2:151–7. Published erratum appears in Eur J Epidemiol 1986;2(3):242.
215 Cocchi A, Franceschini G, Antonelli Incalzi R, Farina G, Vecchio F M, Carbonin P U. Clinico-pathological correlations in the diagnosis of acute myocardial infarction in the elderly. Age Ageing. 1988;17:87-93. [pmid: 3369341].
216 Coffield K S, Speights V O, Brawn P N, Riggs M W. Ultrasound detection of prostate cancer in postmortem specimens with histological correlation. J Urol. 1992;147:822-6. [pmid: 1538483].
217 Cohen A T, Edmondson R A, Phillips M J, Ward V P, Kakkar V V. The changing pattern of venous thromboembolic disease. Haemostasis. 1996;26:65-71. [pmid: 9119284].
218 Colby T V, Hoppe R T, Warnke R A. Hodgkin's disease at autopsy: 1972-1977. Cancer. 1981;47:1852-62. [pmid: 7226080].
219 Coldiron V R, Ward J R J, Trieff N M, Janssen H E J, Smith J H. Occupational exposure to formaldehyde in a medical center autopsy service. J Occup Med. 1983;25:544-8. [pmid: 6886860].
220 Collins K A, Nichols C A, Hanzlick R. Case of the month: not-so-obvious uses of the autopsy. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1998;158:2429-30. [pmid: 9855380].
221 Collins K A, Lee C J, Hanzlick R. Case of the month: death and distraction. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1998;158:2183-4. [pmid: 9818796].
222 Collins C H, Grange J M. Tuberculosis acquired in laboratories and necropsy rooms. Commun Dis Public Health. 1999;2:161-7. [pmid: 10491868].
223 Collins K A, Bennett A T, Hanzlick R. The autopsy and the living. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1999;159:2391-2. [pmid: 10665884].
224 Collins K A, Bennett A T, Hanzlick R. Elder abuse and neglect. Arch Intern Med. 2000;160:1567-68. [pmid: 10847248].
225 Comino A, Ciravegna G, Mollo F. Aortic dissection at autopsy: a fifty-four year survey in Torino. G Ital Cardiol. 1986;16:510-5. [pmid: 3758585].
226 Connell C M, Avey H, Holmes S B. Attitudes about autopsy: implications for educational interventions. Gerontologist. 1994;34:665-73. [pmid: 7959135].
227 Connors A F Jr, Castele R J, Farhat N Z, Tomashefski J F Jr. Complications of right heart catheterization. A prospective autopsy study. Chest. 1985;88:567-72. [pmid: 4042709].
228 Conran P, Nowacek G, Adams T, Smith L. Medical students' attitudes toward the autopsy. Academic Medicine. 1996;71:681-3. [pmid: 9125929].
229 Conwell Y, Forbes N T, Cox C, Caine E D. Validation of a measure of physical illness burden at autopsy: the Cumulative Illness Rating Scale. J Am Geriatr Soc. 1993;41:38-41. [pmid: 8418120].
230 Coon W W. The spectrum of pulmonary embolism: twenty years later. Arch Surg. 1976;111:398-402. [pmid: 1259577].
231 Cooper E S, Cooper J W, Schnabel T G Jr. Pitfalls in the diagnosis of bacterial endocarditis. A review of 159 patients, with emphasis on 96 with autopsy. Arch Intern Med. 1966;118:55-61. [pmid: 5940195].
232 Corbett E L, Murray J, Churchyard G J, Herselman P C, Clayton T C, De Cock K M, et al. Use of miniradiographs to detect silicosis. Comparison of radiological with autopsy findings. Am J Respir Crit Care Med. 1999;160:2012-7. [pmid: 10588622].
233 Corbie-Smith G, Thomas S B, Williams M V, Moody-Ayers S. Attitudes and beliefs of African Americans toward participation in medical research. J Gen Intern Med. 1999;14:537-46. [pmid: 10491242]. [pmcid: 1496744].
234 Corey T S, McCloud L C, Nichols G Rd, Buchino J J. Infant deaths due to unintentional injury. An 11-year autopsy review. Am J Dis Child. 1992;146:968-71. [pmid: 1636667].
235 Corley D E, Kirtland S H, Winterbauer R H, Hammar S P, Dail D H, Bauermeister D E, et al. Reproducibility of the histologic diagnosis of pneumonia among a panel of four pathologists: analysis of a gold standard. Chest. 1997;112:458-65. [pmid: 9266884].
236 Corwin L E, Wolf P A, Kannel W B, McNamara P M. Accuracy of death certification of stroke: the Framingham Study. Stroke. 1982;13:818-21. [pmid: 7147296].
237 Cottreau C, McIntyre L, Favara B E. Professional attitudes toward the autopsy. A survey of clinicians and pathologists. Am J Clin Pathol. 1989;92:673-6. [pmid: 2816821].
238 Cowie R L, Sharpe J W. Extra-pulmonary tuberculosis: a high frequency in the absence of HIV infection. Int J Tuberc Lung Dis. 1997;1:159-62. [pmid: 9441081].
239 Cox D E, Sadler D W, Pounder D J. Alcohol estimation at necropsy: epidemiology, economics, and the elderly. J Clin Pathol. 1997;50:197-201. [pmcid: 499812]. [pmid: 9155668].
240 Craft H, Brazy J E. Autopsy. High yield in neonatal population. Am J Dis Child. 1986;140:1260-2. [pmid: 3776943].
241 Cragle D L, Fetcher A. Risk factors associated with the classification of unspecified and/or unexplained causes of death in an occupational cohort. Am J Public Health. 1992;82:455-7. [pmid: 1536370]. [pmcid: 1694382].
242 Craig J R, Johnson L, Lundberg G D, Tatter D, Edmondson H A, McGah S. An autopsy survey of clinical and anatomic diagnoses associated with alcoholism. Arch Pathol Lab Med. 1980;104:452-5. [pmid: 6893398].
243 Craven C M, Dempsey S, Carey J C, Kochenour N K. Evaluation of a perinatal autopsy protocol: influence of the Prenatal Diagnosis Conference Team. Obstet Gynecol. 1990;76:684-8. [pmid: 2216205].
244 Cullen J H, Kaemmerlen J T, Daoud A, Katz H L. A prospective clinical-pathologic study of the lungs and heart in chronic obstructive lung disease. Am Rev Respir Dis. 1970;102:190-204. [pmid: 5431875].
245 Cullen S A, Turk E P. The value of postmortem examination of passengers in fatal aviation accidents. Aviat Space Environ Med. 1980;51:1071-3. [pmid: 7417182].
246 Cullen D J, Nemeskal A R. The autopsy incidence of acute pulmonary embolism in critically ill surgical patients. Intensive Care Med. 1986;12:399-403. [pmid: 3794056].
247 Curran W J. Law-medicine notes; Damage suits against medical examiners for authorized autopsies. N Engl J Med. 1977;297:1220-1. [pmid: 917057].
248 Curtis J J, Walls J T, Boley T M, Schmaltz R A, Demmy T L. Autopsy findings in patients on postcardiotomy centrifugal ventricular assist. Asaio J. 1992;38:M688-90. [pmid: 1457950].
249 Cutrone J A, Georgiou D, Khan S, Fischer H, Belardinelli R, Laks M M, et al. Comparison of electron beam computed tomography scanning and magnetic resonance imaging quantification of right ventricular mass: validation with autopsy weights. Acad Radiol. 1996;3:395-400. [pmid: 8796691].
250 Dada M A, Ansari N A. Origins of .... the postmortem examination in diagnosis. J Clin Pathol. 1996;49:965-6. [pmcid: 499641]. [pmid: 9038730].
251 Dada M A, Ansari N A. Post-mortem cytology: a reappraisal of a little used technique. Cytopathology. 1997;8:417-20. [pmid: 9439894].
252 D'Agati V, Suh J I, Carbone L, Cheng J T, Appel G. Pathology of HIV-associated nephropathy: a detailed morphologic and comparative study. Kidney Int. 1989;35:1358-70. [pmid: 2770114].
253 Dalen J E. The moribund autopsy. DNR or CPR?. Arch Intern Med. 1997;157:1633. [pmid: 9250221].
254 Dallasta L M, Martinez J, Nichols L, Hanzlick R. Case of the month: Pathologic findings in a transplant donor. Arch Intern Med. 1999;159:2115-16. [pmid: 10527287].
255 Dandekar C P, Mysorekar V V, Rao S G, Anupama V. Perinatal autopsy--a six year study. Indian Pediatr. 1998;35:545-8. [pmid: 10216651].
256 Datta B N, Ramesh K, Bhusnurmath B. Autopsy incidence of pulmonary vascular episodes. A study of 218 cases. Angiology. 1986;37:744-50. [pmid: 3767065].
257 Davidson C S. The Autopsy in the Age of Molecular Biology. JAMA. 1965;193:813-14. [pmid: 14329984].
258 Davies T. Requesting necropsies. Health care must be both evidence based and humanity based. BMJ. 1997;315:11.
259 Davis C J. Autopsy rates: the decline with age. PAS Rep. 1979;16:31-41. [pmid: 10245248].
260 Davis G J, Peterson B R. Dilemmas and solutions for the pathologist and clinician encountering religious views of the autopsy. South Med J. 1996;89:1041-4. [pmid: 8903284].
261 Davis G J, Hanzlick R. Case of the month. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1997;157:2296. [pmid: 9361569].
262 Davis G G. Mind your manners. Part I: History of death certification and manner of death classification. American Journal of Forensic Medicine & Pathology. 1997;18:219-23. [pmid: 9290867].
263 Davis A, Fields A, Hill C, Hanzlick R. Unavoidable outcomes vs misadventures. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1999;159:646-7. [pmid: 10218742].
264 De Lone D R, Goldstein R A, Petermann G, Salamat M S, Miles J M, Knechtle S J, et al. Disseminated aspergillosis involving the brain: distribution and imaging characteristics. AJNR Am J Neuroradiol. 1999;20:1597-604. [pmid: 10543627].
265 de Pangher Manzini V, Revignas M G, Brollo A. Diagnosis of malignant tumor: comparison between clinical and autopsy diagnoses. Hum Pathol. 1995;26:280-3. [pmid: 7890278].
266 Deeks J J. Systematic reviews of evaluations of diagnostic and screening tests. BMJ. 2001;323:157-62. [pmid: 11463691].
267 Del B M, Cardoso E, Halliday W. Neuropathological changes in chronic adult hydrocephalus: cortical biopsies and autopsy findings. Can J Neurol Sci. 1997;24:121-6. [pmid: 9164688].
268 Delendi M, Riboli E, Peruzzo P, Stanta G, Cocchi A, Gardiman D, et al. Comparison of diagnoses of cancers of the respiratory system on death certificates and at autopsy. IARC Sci Publ.1991:55–62.
269 DeRiemer K, Rudoy I, Schecter G F, Hopewell P C, Daley C L. The epidemiology of tuberculosis diagnosed after death in San Francisco, 1986-1995. Int J Tuberc Lung Dis. 1999;3:488-93. [pmid: 10383061].
270 Desai M H, Linares H A, Herndon D N. Pulmonary embolism in burned children. Burns. 1989;15:376-80. [pmid: 2624693].
271 Devers K J. The changing role of the autopsy: a social environmental perspective. Hum Pathol. 1990;21:145-53. [pmid: 2307441].
272 Dhar V, Perlman M, Vilela M I, Haque K N, Kirpalani H, Cutz E. Autopsy in a neonatal intensive care unit: utilization patterns and associations of clinicopathologic discordances. J Pediatr. 1998;132:75-9. [pmid: 9470004].
273 Di Bonito L, Stanta G, Delendi M, Peruzzo P, Gardiman D, Cocchi A, et al. Comparison between diagnoses on death certificates and autopsy reports in Trieste: gynaecological cancers. IARC Sci Publ.1991:63–71.
274 Di Furia L, Piga A, Marmili S, Breccia R, Rubini C, Beltrami C A, et al. The value of necropsy in oncology. Eur J Cancer. 1991;27:559-61. [pmid: 1828961].
275 Dickens P, Knight B H, Ip P, Fung W S. Fatal pulmonary embolism: a comparative study of autopsy incidence in Hong Kong and Cardiff, Wales. Forensic Sci Int. 1997;90:171-4. [pmid: 9493332].
276 Diebold J, Lohrs U. Venous thrombosis and pulmonary embolism. A study of 5039 autopsies. Pathol Res Pract. 1991;187:260-6. [pmid: 2068009].
277 Diegbe I, Idaewor P, Igbokwe U. Autopsy audit in a teaching hospital in Nigeria--the Benin experience. West Afr J Med. 1998;17:213-6. [pmid: 9814096].
278 Dismuke S E, VanderZwaag R. Accuracy and epidemiological implications of the death certificate diagnosis of pulmonary embolism. J Chronic Dis. 1984;37:67-73. [pmid: 6690461].
279 Dismuke S E, Wagner E H. Pulmonary embolism as a cause of death. The changing mortality in hospitalized patients. JAMA. 1986;255:2039-42. [pmid: 3959287].
280 Djaldetti M, Hart J, Yarmolovsky A, Zeidman A, Floru S, Gardyn J, et al. Is it possible to improve the autopsy rate?. Isr J Med Sci. 1995;31:436-8. [pmid: 7607872].
281 Dollar A L, Roberts W C. Usefulness of total 12-lead QRS voltage compared with other criteria for determining left ventricular hypertrophy in hypertrophic cardiomyopathy: analysis of 57 patients studied at necropsy. Am J Med. 1989;87:377-81. [pmid: 2529761].
282 Donald KJ, Collie JP. The autopsy in quality assurance. Clinical practice in a teaching hospital. Aust Clin Rev.1981:16–21.
283 Dorsey D B. A perspective on the autopsy. Am J Clin Pathol. 1978;69:217-9. [pmid: 343574].
284 Dorsey D B. Limited autopsies. Defined benefits, limited costs. Arch Pathol Lab Med. 1984;108:469-72. [pmid: 6428375].
285 Douketis J D, Kearon C, Bates S, Duku E K, Ginsberg J S. Risk of fatal pulmonary embolism in patients with treated venous thromboembolism. JAMA. 1998;279:458-62. [pmid: 9466640].
286 Dressler F A, Miller L W. Necropsy versus angiography: how accurate is angiography?. J Heart Lung Transplant. 1992;11:S56-9. [pmid: 1623001].
287 Du Florey C, Senter M G, Acheson R M. A study of the validity of the diagnosis of stroke in mortality data. II. Comparison by computer of autopsy and clinical records with death certificates. Am J Epidemiol. 1969;89:15-24. [pmid: 5762816].
288 du Moulin G C, Paterson D G. Clinical relevance of postmortem microbiologic examination: a review. Hum Pathol. 1985;16:539-48. [pmid: 3888815].
289 Dubois R W, Brook R H. Preventable deaths: who, how often, and why?. Ann Intern Med. 1988;109:582-9. [pmid: 3421565].
290 Ducatman B S, McMichan J C, Edwards W D. Catheter-induced lesions of the right side of the heart. A one-year prospective study of 141 autopsies. JAMA. 1985;253:791-5. [pmid: 3968816].
291 Durning S, Cation L. The educational value of autopsy in a residency training program. Arch Intern Med. 2000;160:997-9. [pmid: 10761965].
292 Ebbesen J, Buajordet I, Erikssen J, Brors O, Hilberg T, Svaar H, et al. Drug-related deaths in a department of internal medicine. Arch Intern Med. 2001;161:2317-23. [pmid: 11606147].
293 Eberhart C G, Morrison A, Gyure K A, Frazier J, Smialek J E, Troncoso J C. Decreasing incidence of sudden death due to undiagnosed primary central nervous system tumors. Arch Pathol Lab Med. 2001;125:1024-30. [pmid: 11473451].
294 Ebert R V, Porterfield J D, Trump B F, Angevine D M, Bloodworth J M, Foraker A G. Open forum: A debate on the autopsy: its quality control function in medicine. Hum Pathol. 1974;5:605-18. [pmid: 4853473].
295 Edlin G P. Active tuberculosis unrecognised until necropsy. Lancet. 1978;1:650-2. [pmid: 76179].
296 Egervary M, Szende B, Roe F J, Lee P N. Accuracy of clinical diagnosis of lung cancer in Budapest in an institute specializing in chest diseases. Pathol Res Pract. 2000;196:761-6. [pmid: 11186171].
297 el-Ebiary M, Torres A, Fabregas N, de la Bellacasa J P, Gonzalez J, Ramirez J, et al. Significance of the isolation of Candida species from respiratory samples in critically ill, non-neutropenic patients. An immediate postmortem histologic study. Am J Respir Crit Care Med. 1997;156:583-90. [pmid: 9279244].
298 Elfawal M A, Wheatley D J. Diagnosis of sudden coronary death in the autopsy room: guidelines for forensic pathologists. Med Sci Law. 1989;29:64-8. [pmid: 2747465].
299 Elmore J G, Wells C K, Lee C H, Howard D H, Feinstein A R. Variability in radiologists' interpretations of mammograms. N Engl J Med. 1994;331:1493-9. [pmid: 7969300].
300 Emson H E, Messenger O J. Patients don't sue pathologists--or do they? Risk management in laboratory medicine. CMAJ. 1989;141:1133-5. [pmid: 2819632]. [pmcid: 1451260].
301 Engel L W, Strauchen J A, Chiazze L Jr, Heid M. Accuracy of death certification in an autopsied population with specific attention to malignant neoplasms and vascular diseases. Am J Epidemiol. 1980;111:99-112. [pmid: 7352463].
302 Eriksson L, Sundstrom C. Decreasing autopsy rate in Sweden reflects changing attitudes among clinicians. Qual Assur Health Care. 1993;5:319-23. [pmid: 8018890].
303 Erkinjuntti T, Haltia M, Palo J, Sulkava R, Paetau A. Accuracy of the clinical diagnosis of vascular dementia: a prospective clinical and post-mortem neuropathological study. J Neurol Neurosurg Psychiatry. 1988;51:1037-44. [pmid: 3216206].
304 Ermenc B. Discrepancies between clinical and post-mortem diagnoses of causes of death. Med Sci Law. 1999;39:287-92. [pmid: 10581907].
305 Ermenc B. Minimizing mistakes in clinical diagnosis. J Forensic Sci. 1999;44:810-3. [pmid: 10432615].
306 Escoffery C, Shirley S. Autopsy rates at the University Hospital of the West Indies, 1968-1997. West Indian Med J. 2000;49:164-68. [pmid: 10948859].
307 Escoffery C T, Shirley S E. Autopsy rates at the University Hospital of the West Indies, 1968-1997. West Indian Med J. 2000;49:164-8. [pmid: 10948859].
308 Espinosa J A, Nolan T W. Reducing errors made by emergency physicians in interpreting radiographs: longitudinal study. BMJ. 2000;320:737-40. [pmcid: 27314]. [pmid: 10720354].
309 Essex-Sorlie D, Penning C L, Freund G G. Impact of qualified (indeterminate) diagnoses on the accuracy of renal, thyroid, and breast fine-needle aspiration biopsy. Am J Clin Pathol. 2000;114:571-5. [pmid: 11026103].
310 Esteban A, Fernandez-Segoviano P. The autopsy as a tool to monitor diagnostic error. Intensive Care Med. 1999;25:343-4. [pmid: 10342503].
311 Ewigman B, Kivlahan C, Land G. The Missouri child fatality study: underreporting of maltreatment fatalities among children younger than five years of age, 1983 through 1986. Pediatrics. 1993;91:330-7. [pmid: 8424006].
312 Ezdinli E Z, O'Sullivan D D, Wasser L P, Kim U, Stutzman L. Oral amphotericin for candidiasis in patients with hematologic neoplasms. An autopsy study. JAMA. 1979;242:258-60. [pmid: 376883].
313 Fabregas N, Ewig S, Torres A, El-Ebiary M, Ramirez J, de La Bellacasa J P, et al. Clinical diagnosis of ventilator associated pneumonia revisited: comparative validation using immediate post-mortem lung biopsies. Thorax. 1999;54:867-73. [pmid: 10491448].
314 Fausto N. Atherosclerosis in young people: the value of the autopsy for studies of the epidemiology and pathobiology of disease. Am J Pathol. 1998;153:1021-2. [pmid: 9777933]. [pmcid: 1853041].
315 Fay D, Baird I M, Aguirre A, Haegren V, Werling K, Bell T W. Unrecognized Legionnaires' disease as a cause of fatal illness. JAMA. 1980;243:2311-3. [pmid: 6990037].
316 Faye-Petersen O, Guinn D, Wenstrom K. Value of perinatal autopsy. Obstet Gynecol. 1999;94:915-20. [pmid: 10576175].
317 Feinleib M, Kannel W B, Tedeschi C G, Landau T K, Garrison R J. The relation of antemortem characteristics to cardiovascular findings at necropsy--The Framingham Study. Atherosclerosis. 1979;34:145-57. [pmid: 518733].
318 Feinstein A R. Epidemiologic and clinical challenges in reviving the necropsy. Arch Pathol Lab Med. 1996;120:749-52. [pmid: 8718900].
319 Feldman D M. Rabbinic comment: Autopsy. Mount Sinai J of Med. 1984;51:82-5.
320 Felix W R Jr, Stahlgren L H. Death by undiagnosed perforated peptic ulcer: analysis of 31 cases. Ann Surg. 1973;177:344-51. [pmid: 4540287]. [pmcid: 1355538].
321 Fender D, Harper W M, Thompson J R, Gregg P J. Mortality and fatal pulmonary embolism after primary total hip replacement. Results from a regional hip register. J Bone Joint Surg Br. 1997;79:896-9. [pmid: 9393900].
322 Ferencic Z, Belicza M. Autopsy and clinical diagnoses in a psychiatric hospital. In: Riboli E, Delendi M, editors. Autopsy in Epidemiology and Medical Research. Lyon: IARC Sci Publ; 1991:109–13
323 Ferencic Z. Autopsy and the internal medicine department. Pathologica. 1992;84:299-303. [pmid: 1465313].
324 Fernandez-Segoviano P, Lazaro A, Esteban A, Rubio J M, Iruretagoyena J R. Autopsy as quality assurance in the intensive care unit. Crit Care Med. 1988;16:683-5. [pmid: 3371045].
325 Fessel W J, Van Brunt E E. Assessing quality of care from the medical record. N Engl J Med. 1972;286:134-8. [pmid: 5007152].
326 Fish J, Hartshorne N, Reay D, Heimbach D. The role of autopsy on patients with burns. J Burn Care Rehabil. 2000;21:339-44. [pmid: 10935816].
327 Flum D R, Morris A, Koepsell T, Dellinger E P. Has misdiagnosis of appendicitis decreased over time? A population-based analysis. JAMA. 2001;286:1748-53. [pmid: 11594900].
328 Foroudi F, Cheung K, Duflou J. A comparison of the needle biopsy post mortem with the conventional autopsy. Pathology. 1995;27:79-82. [pmid: 7603760].
329 Fowler E F, Nicol A G, Reid I N. Evaluation of a teaching hospital necropsy service. J Clin Pathol. 1977;30:575-8. [pmcid: 476471]. [pmid: 874115].
330 Fox RC. The autopsy: it's place in the attitude-learning of second year medical students. Essays in medical sociology : journeys into the field. New York: Wiley; 1979
331 Frable W J. Does a zero error standard exist for the Papanicolaou smear? A pathologist's perspective. Arch Pathol Lab Med. 1997;121:301-10. [pmid: 9111124].
332 Fradet G, Jamieson W R, Janusz M T, Ling H, Miyagishima R T, Munro A I. Aortic dissection: current expectations and treatment. Experience with 258 patients over 20 years. Can J Surg. 1990;33:465-9. [pmid: 2253124].
333 Freedman L R. Chronic pyelonephritis at autopsy. Ann Intern Med. 1967;66:697-710. [pmid: 6023536].
334 Freeman J T. The autopsy in geriatrics. J Am Geriatr Soc. 1975;23:1-10. [pmid: 1109381].
335 Frenkel J K, Baker L H, Chonko A M. Autopsy diagnosis of Legionnaires' disease in immunosuppressed patients. A paleodiagnosis using Giemsa stain (Wohlbach modification). Ann Intern Med. 1979;90:559-62. [pmid: 373545].
336 Frescura C, Basso C, Thiene G, Corrado D, Pennelli T, Angelini A, et al. Anomalous origin of coronary arteries and risk of sudden death: a study based on an autopsy population of congenital heart disease. Hum Pathol. 1998;29:689-95. [pmid: 9670825].
337 Fried T R, Rosenberg R R, Lipsitz L A. Older community-dwelling adults' attitudes toward and practices of health promotion and advance planning activities. J Am Geriatr Soc. 1995;43:645-9. [pmid: 7775723].
338 Friederici H H, Sebastian M. The concordance score. Correlation of clinical and autopsy findings. Arch Pathol Lab Med. 1984;108:515-7. [pmid: 6547307].
339 Friederici H H, Sebastian M. An argument for the attendance of clinicians at autopsy. Arch Pathol Lab Med. 1984;108:522-3. [pmid: 6547309].
340 Friederici H H, Sebastian M. Autopsies in a modern teaching hospital. A review of 2,537 cases. Arch Pathol Lab Med. 1984;108:518-21. [pmid: 6547308].
341 Friederici H H. Reflections on the postmortem audit. JAMA. 1988;260:3461-5. [pmid: 3062196].
342 Froede RC. The medicolegal investigation: evaluation of cases with potential medical litigation. Leg Med Annu.1977:1–14.
343 Fuchs W M. Autopsies and the risk of lawsuits. Hosp Pract (Off Ed). 1999;34:20. [pmid: 10901743].
344 Fulton J D, Peebles S E, Smith G D, Davie J W. Unrecognized viscus perforation in the elderly. Age Ageing. 1989;18:403-6. [pmid: 2629489].
345 Furness M E, Weckert R C, Parker S A, Knowles S. Ultrasound in the perinatal necropsy. J Med Genet. 1989;26:368-72. [pmid: 2661821].
346 Gabel H. New transplant legislation in Sweden. The Transplantation Act and its introduction. Annals of Transplantation. 1996;1:55-9. [pmid: 9869908].
347 Galen R S, Chauhan P, Wietzner H, Navarro C. Fetal pathology and mechanism of fetal death in saline-induced abortion: a study of 143 gestations and critical review of the literature. Am J Obstet Gynecol. 1974;120:347-55. [pmid: 4413460].
348 Gall E A. The necropsy as a tool in medical progress. Bulletin of the New York Academy of Medicine. 1968;44:808-29. [pmid: 5240157].
349 Gallus A S, Hirsh J. Prevention of venous thromboembolism. Semin Thromb Hemost. 1976;2:232-90. [pmid: 798276].
350 Gambino S R. The autopsy. The ultimate audit. Arch Pathol Lab Med. 1984;108:444-5. [pmid: 6547293].
351 Gantner G E. The autopsy and the law. Am J Clin Pathol. 1978;69:235-8. [pmid: 626166].
352 Garcia-Gonzalez R, Pinto J, Val-Bernal J. Testicular metastases from solid tumors: an autopsy study. Ann Diagn Pathol. 2000;4:59-64. [pmid: 10760317].
353 Gardner R, Peskin L, Katz J L. The physician, the autopsy request, and the consent rate. J Med Educ. 1973;48:636-44. [pmid: 4708421].
354 Garg K, Sieler H, Welsh C, Johnston R, Russ P. Clinical validity of helical CT being interpreted as negative for pulmonary embolism: implications for patient treatment. AJR Am J Roentgenol. 1999;172:1627-31. [pmid: 10350303].
355 Garvin A J, Simon R M, Osborne C K, Merrill J, Young R C, Berard C W. An autopsy study of histologic progression in non-Hodgkin's lymphomas.192 cases from the National Cancer Institute. Cancer. 1983;52:393-8. [pmid: 6344979].
356 Gatrad A R. Muslim customs surrounding death, bereavement, postmortem examinations, and organ transplants. BMJ. 1994;309:521-3. [pmid: 7848419].
357 Gawande A. Final Cut Medical arrogance and the decline of the autopsy. The New Yorker. 2001:94–99.
358 Geller S A. To see or not to see: the status of the autopsy at The Mount Sinai Medical Center. Mt Sinai J Med. 1979;46:33-8. [pmid: 312424].
359 Geller SA. Autopsy. Sci Am. 1983;248:124–9, 32, 35–6.
360 Geller S A. Religious attitudes and the autopsy. Arch Pathol Lab Med. 1984;108:494-6. [pmid: 6547302].
361 Geller S A. Autopsy. Mount Sinai J of Med. 1984;51:77-81.
362 Geller S A. The autopsy in acquired immunodeficiency syndrome. How and why Arch Pathol Lab Med. 1990;114:324-9.
363 Gerain J, Sculier J P, Malengreaux A, Rykaert C, Themelin L. Causes of deaths in an oncologic intensive care unit: a clinical and pathological study of 34 autopsies. Eur J Cancer. 1990;26:377-81. [pmid: 2141496].
364 Ghanem I. Permission for performing an autopsy: the pitfalls under Islamic law. Medicine, Science & the Law. 1988;28:241-2.
365 Gibinski K, Hartleb M, Koturbasz D. Comparison between pre- and post-mortem diagnoses in a consecutive series of patients. Scand J Gastroenterol. 1985;20:370-2. [pmid: 4001846].
366 Gilbert R, Logan S, Moyer V A, Elliott E J. Assessing diagnostic and screening tests: Part 1. Concepts. West J Med. 2001;174:405-9. [pmid: 11381009]. [pmcid: 1071430].
367 Gilbert R, Logan S, Moyer V A, Elliott E J. Assessing diagnostic and screening tests: Part 2. How to use the research literature on diagnosis. West J Med. 2001;175:37-41. [pmid: 11431401]. [pmcid: 1071464].
368 Gittelsohn A, Senning J. Studies on the reliability of vital and health records: I. Comparison of cause of death and hospital record diagnoses. Am J Public Health. 1979;69:680-9. [pmid: 453395]. [pmcid: 1619100].
369 Glasser J H. The quality and utility of death certificate data. Am J Public Health. 1981;71:231-3. [pmid: 7468853]. [pmcid: 1619790].
370 Gloth F Md, Burton J R. Autopsies and death certificates in the chronic care setting. J Am Geriatr Soc. 1990;38:151-5. [pmid: 2299120].
371 Gobbato F, Vecchiet F, Barbierato D, Melato M, Manconi R. Inaccuracy of death certificate diagnoses in malignancy: an analysis of 1,405 autopsied cases. Hum Pathol. 1982;13:1036-8. [pmid: 7152507].
372 Goldhaber S Z, Hennekens C H, Evans D A, Newton E C, Godleski J J. Factors associated with correct antemortem diagnosis of major pulmonary embolism. Am J Med. 1982;73:822-6. [pmid: 7148876].
373 Goldhaber S Z, Hennekens C H. Time trends in hospital mortality and diagnosis of pulmonary embolism. Am Heart J. 1982;104:305-6. [pmid: 7102514].
374 Goldhaber S Z, Visani L, De Rosa M. Acute pulmonary embolism: clinical outcomes in the International Cooperative Pulmonary Embolism Registry (ICOPER). Lancet. 1999;353:1386-9. [pmid: 10227218].
375 Goldman L, Sayson R, Robbins S, Cohn L H, Bettmann M, Weisberg M. The value of the autopsy in three medical eras. N Engl J Med. 1983;308:1000-5. [pmid: 6835306].
376 Goldman L. Diagnostic advances v the value of the autopsy.1912-1980. Arch Pathol Lab Med. 1984;108:501-5. [pmid: 6375622].
377 Goldman L. Autopsy: seventy-five years after Cabot. J Am Geriatr Soc. 1986;34:897-8. [pmid: 3537096].
378 Goldstein B, Metlay L, Cox C, Rubenstein J S. Association of pre mortem diagnosis and autopsy findings in pediatric intensive care unit versus emergency department versus ward patients. Crit Care Med. 1996;24:683-6. [pmid: 8612423].
379 González-Villalpando C. The influence of culture in the authorization of an autopsy. J Clin Ethics. 1993;4:192-4. [pmid: 8334292].
380 Goodin J, Hanzlick R. Mind your manners. Part II: General results from the National Association of Medical Examiners Manner of Death Questionnaire, 1995. Am J Forensic Med Pathol. 1997;18:224-7. [pmid: 9290868].
381 Goodwin A T, Goddard M, Taylor G J, Ritchie A J. Clinical versus actual outcome in cardiac surgery: a post-mortem study. Eur J Cardiothorac Surg. 2000;17:747-51. [pmid: 10856871].
382 Goraya T Y, Jacobsen S J, Belau P G, Weston S A, Kottke T E, Roger V L. Validation of death certificate diagnosis of out-of-hospital coronary heart disease deaths in Olmsted County, Minnesota. Mayo Clin Proc. 2000;75:681-7. [pmid: 10907382].
383 Gordin F M, Slutkin G, Schecter G, Goodman P C, Hopewell P C. Presumptive diagnosis and treatment of pulmonary tuberculosis based on radiographic findings. Am Rev Respir Dis. 1989;139:1090-3. [pmid: 2496633].
384 Gordon H L. Autopsies according to the Jewish religious laws. Hebrew Phys. 1937;1:130-40.
385 Gorman T E, Arcot A N, Baker P, Prior T W, Brandt J T. Prevalence of the factor VLeiden mutation among autopsy patients with pulmonary thromboembolic disease using an improved method for factor VLeiden detection. Am J Clin Pathol. 1999;111:413-7. [pmid: 10078118].
386 Gotti E W. Adverse drug reactions and the autopsy. Prevalence and perspective. Arch Pathol. 1974;97:201-4. [pmid: 4814703].
387 Gottlieb J. A review of Jewish opinions regarding postmortem examinations. Boston Med Surg J. 1927;196:726-8.
388 Gough J. Correlation between clinical and autopsy diagnoses in a community hospital. Can Med Assoc J; 1985. p. 420–2.
389 Grafe MR, Press GA, Berthoty DP, Hesselink JR, Wiley CA. Abnormalities of the brain in AIDS patients: correlation of postmortem MR findings with neuropathology. AJNR Am J Neuroradiol. 1990;11:905–11; discussion 12–3.
390 Graff L, Russell J, Seashore J, Tate J, Elwell A, Prete M, et al. False-negative and false-positive errors in abdominal pain evaluation: failure to diagnose acute appendicitis and unnecessary surgery. Acad Emerg Med. 2000;7:1244-55. [pmid: 11073473].
391 Graham A R. Autopsy findings in cardiac transplant patients. A 10-year experience. Am J Clin Pathol. 1992;97:369-75. [pmid: 1543161].
392 Greb A E, Pauli R M, Kirby R S. Accuracy of fetal death reports: comparison with data from an independent stillbirth assessment program. Am J Public Health. 1987;77:1202-6. [pmid: 3618855]. [pmcid: 1647003].
393 Green A, Donald K J. Necropsy as a control of death certification: some unexpected findings. Med J Aust. 1976;2:131-2. [pmid: 979826].
394 Green J, Edwards C. Seasonal variation in the necropsy incidence of massive pulmonary embolism. J Clin Pathol. 1994;47:58-60. [pmcid: 501758]. [pmid: 8132811].
395 Grellner W, Glenewinkel F. Exhumations: synopsis of morphological and toxicological findings in relation to the postmortem interval. Survey on a 20-year period and review of the literature. Forensic Sci Int. 1997;90:139-59. [pmid: 9438373].
396 Grenko R T, Abendroth C S, Frauenhoffer E E, Ruggiero F M, Zaino R J. Variance in the interpretation of cervical biopsy specimens obtained for atypical squamous cells of undetermined significance. Am J Clin Pathol. 2000;114:735-40. [pmid: 11068547].
397 Griffiths R I, Hyman C L, McFarlane S I, Saurina G R, Anderson J E, O'Brien T, et al. Medical-resource use for suspected tuberculosis in a New York City hospital. Infect Control Hosp Epidemiol. 1998;19:747-53. [pmid: 9801282].
398 Gross J S, Neufeld R R, Libow L S, Gerber I, Rodstein M. Autopsy study of the elderly institutionalized patient. Review of 234 autopsies. Arch Intern Med. 1988;148:173-6. [pmid: 3337592].
399 Gross C P, Anderson G F, Powe N R. The relation between funding by the National Institutes of Health and the burden of disease. N Engl J Med. 1999;340:1881-7. [pmid: 10369852].
400 Grossi C, Mangano S, Zani M B, Tettamanzi F, Scalia P. Tesio catheters: findings in post-mortem examination. Nephrol Dial Transplant. 1996;11:1363-4. [pmid: 8672042].
401 Grunberg S M, Sherrod A, Muellenbach R, Renshaw M, Zaretsky S, Levine A M. Analysis of physician attitudes concerning requests for autopsy. Cancer Investigation. 1994;12:463-8. [pmid: 7922701].
402 Grundmann E, Menke GG. Autopsy diagnosis versus clinical diagnosis, particularly in malignant disease. Comparison of two periods: 1961-70 and 1978-87. IARC Sci Publ. 1991:81–90.
403 Grundmann E. Autopsy as clinical quality control: a study of 15,143 autopsy cases. In Vivo. 1994;8:945-52. [pmid: 7727742].
404 Grunert I, Grubwieser G, Ulmer H. Bilateral investigation of the temporomandibular joint. An autopsy study of edentulous individuals. J Oral Rehabil. 2000;27:671-81. [pmid: 10931262].
405 Gruver R H, Freis E D. A Study of Diagnostic Errors. Ann Intern Med. 1957;47:108-20. [pmid: 13435683].
406 Guariglia P, Abrahams C. The impact of autopsy data on DRG reimbursement. Hum Pathol. 1985;16:1184-6. [pmid: 3934064].
407 Guly H R. A scale for measuring the severity of diagnostic errors in accident and emergency departments. J Accid Emerg Med. 1997;14:290-2. [pmid: 9315928].
408 Guptill C S. How autopsy data are biased by age factors. Geriatrics. 1976;31:78-82. [pmid: 939426].
409 Gut A L, Ferreira A L, Montenegro M R. Autopsy: quality assurance in the ICU. Intensive Care Med. 1999;25:360-3. [pmid: 10342508].
410 Gwynne J F. Death certification in Dunedin hospitals. N Z Med J. 1977;86:77-81. [pmid: 271879].
411 Haas J E, Taylor J A, Bergman A B, van Belle G, Felgenhauer J L, Siebert J R, et al. Relationship between epidemiologic risk factors and clinicopathologic findings in the sudden infant death syndrome. Pediatrics. 1993;91:106-12. [pmid: 8416472].
412 Hagerstrand I, Lundberg L M. The importance of post-mortem examinations of abortions and perinatal deaths. Qual Assur Health Care. 1993;5:295-7. [pmid: 8018885].
413 Hagler L, Pastore R A, Bergin J J, Wrensch M R. Aplastic anemia following viral hepatitis: report of two fatal cases and literature review. Medicine (Baltimore). 1975;54:139-64. [pmcid: 126225]. [pmid: 1117835].
414 Hallen J, Krook H. Follow-up Studies on an Unselected Ten-year Material of 360 Patients with Liver Cirrhosis in one Community. Acta Medica Scandinavica. 1963;173:479-93. [pmid: 13952160].
415 Hallen J, Norden J. Liver Cirrhosis Unsuspected During Life. A Series of 79 Cases. J Chronic Dis. 1964;17:951-58. [pmid: 14213426].
416 Handler S. The unfortunate decline of the autopsy. Minnesota Medicine. 1998;81:22-4. [pmid: 9842231].
417 Hansen J L, McMeekin R R. Unsuspected tumors in aircraft accident fatalities as a guide to evaluation of physical-examination standards. Aerosp Med. 1974;45:959-62. [pmid: 4367456].
418 Hansson P O, Welin L, Tibblin G, Eriksson H. Deep vein thrombosis and pulmonary embolism in the general population. ‘The Study of Men Born in 1913’. Arch Intern Med. 1997;157:1665-70. [pmid: 9250227].
419 Hanzlick R. On the need for more expertise in death investigation (and a National Office of Death Investigation Affairs?). Arch Pathol Lab Med. 1996;120:329-32. [pmid: 8619742].
420 Hanzlick R. Case of the month. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1997;157:1798. [pmid: 9290538].
421 Hanzlick R. Death registration: history, methods, and legal issues. J Forensic Sci. 1997;42:265-9. [pmid: 9068184].
422 Hanzlick R. Principles for including or excluding ‘mechanisms’ of death when writing cause-of-death statements. Arch Pathol Lab Med. 1997;121:377-80. [pmid: 9140306].
423 Hanzlick R, Goodin J. Mind your manners. Part III: Individual scenario results and discussion of the National Association of Medical Examiners Manner of Death Questionnaire, 1995. Am J Forensic Med Pathol. 1997;18:228-45. [pmid: 9290869].
424 Hanzlick R, Baker P. Case of the month: Institutional autopsy rates. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1998;158:1171-2. [pmid: 9625395].
425 Hanzlick R. Case of the month: Complications of therapy, nursing homes, and the elderly. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1998;158:695-6. [pmid: 9554674].
426 Hanzlick R, Nichols L. Case of the month. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1998;158:426. [pmid: 9508219].
427 Hanzlick R, Combs D. Medical examiner and coroner systems: history and trends. JAMA. 1998;279:870-4. [pmid: 9516003].
428 Hanzlick R L, Parrish R G. Epidemiologic aspects of forensic pathology. Clinics in Laboratory Medicine. 1998;18:23-37. [pmid: 9523062].
429 Hanzlick R. Case of the month: private autopsies. Arch Intern Med. 1998;158:947-8. [pmid: 9588427].
430 Hanzlick R, Hutchins G M. History repeats itself (sometimes). Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1999;159:1837-8. [pmid: 10493313].
431 Hanzlick R, McKenney J K. Case of the month: education of the pathologist. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1999;159:907-8. [pmid: 10326932].
432 Hanzlick R, Mosunjac M I. Autopsy Committee of the College of American P. Case of the month: The rest of the story. Arch Intern Med. 1999;159:1173-76. [pmid: 10371224].
433 Hanzlick R L. The autopsy lexicon: suggested headings for the autopsy report. Arch Pathol Lab Med. 2000;124:594-603. [pmid: 10747319].
434 Haque A K, Cowan W T, Smith J H. The decedent affairs office. A unique centralized service. JAMA. 1991;266:1397-9. [pmid: 1880870].
435 Haque A K, Patterson R C, Grafe M R. High autopsy rates at a university medical center. What has gone right?. Arch Pathol Lab Med. 1996;120:727-32. [pmid: 8718896].
436 Hardy W E, Freeman M G, Thompson J D. A ten-year review of maternal mortality. Obstet Gynecol. 1974;43:65-72. [pmid: 4808966].
437 Harmon J V Jr, Edwards W D. Venous valves in subclavian and internal jugular veins. Frequency, position, and structure in 100 autopsy cases. Am J Cardiovasc Pathol. 1987;1:51-4. [pmid: 3455235].
438 Harrell L E, Callaway R, Powers R. Autopsy in dementing illness: who participates?. Alzheimer Disease & Associated Disorders. 1993;7:80-7. [pmid: 8347331].
439 Harris M D, Blundell J W. Audit of necropsies in a British district general hospital. J Clin Pathol. 1991;44:862-5. [pmcid: 496676]. [pmid: 1960222].
440 Harris A, Ismail I, Dilly S, Maxwell J D. Physicians' attitudes to the autopsy. J R Coll Physicians Lond. 1993;27:116-8. [pmid: 8501665].
441 Harris A. Physicians' attitudes to the autopsy. J R Coll Physicians Lond. 1994;28:Mar-Apr.
442 Harrison P J. Advances in post mortem molecular neurochemistry and neuropathology: examples from schizophrenia research. British Medical Bulletin. 1996;52:527-38. [pmid: 8949255].
443 Hart B L, Dudley M H, Zumwalt R E. Postmortem cranial MRI and autopsy correlation in suspected child abuse. Am J Forensic Med Pathol. 1996;17:217-24. [pmid: 8870872].
444 Hartveit F. Clinical and post-mortem assessment of the cause of death. J Pathol. 1977;123:193-210. [pmid: 592024].
445 Hartveit F. Autopsy findings in cases with a clinically uncertain cancer diagnosis. J Pathol. 1979;129:111-9. [pmid: 529009].
446 Hasson J, Gross H. The autopsy and quality assessment of medical care. Am J Med. 1974;56:137-40. [pmid: 4812070].
447 Hasson J, Schneiderman H. Autopsy training programs. To right a wrong. Arch Pathol Lab Med. 1995;119:289-91. [pmid: 7887788].
448 Hasson J. Medical fallibility and the autopsy in the USA. J Eval Clin Pract. 1997;3:229-34. [pmid: 9406111].
449 Hauch O, Jorgensen L N, Khattar S C, Teglbjaerg C S, Wahlin A B, Rathenborg P, et al. Fatal pulmonary embolism associated with surgery. An autopsy study. Acta Chir Scand. 1990;156:747-9. [pmid: 2075772].
450 Hauck A J, Kearney D L, Edwards W D. Evaluation of postmortem endomyocardial biopsy specimens from 38 patients with lymphocytic myocarditis: implications for role of sampling error. Mayo Clin Proc. 1989;64:1235-45. [pmid: 2593714].
451 Havig O. Deep vein thrombosis and pulmonary embolism. An autopsy study with multiple regression analysis of possible risk factors. Acta Chir Scand Suppl. 1977;478:1-120. [pmid: 146995].
452 Havlik D M, Irvine R, Hanzlick R. Case of the month: allaying apprehension. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1998;158:1971-2. [pmid: 9778195].
453 Havlik DM, Williams WL, Hanzlick R. Case of the month: incidental and not-so-incidental findings. Arch Intern Med. 1999;159:1655–6. Published erratum appears in Arch Intern Med 1999;159(19):2368.
454 Hawass N E, al-Badawi M G, Fatani J A, Meshari A A, Edrees Y B, Jabbar F A. Fetal necrogram: a new technique. Experience with 12,000 contrast examinations. Invest Radiol. 1989;24:711-20. [pmid: 2807825].
455 Hawkins G C, Bonita R, Broad J B, Anderson N E. Inadequacy of clinical scoring systems to differentiate stroke subtypes in population-based studies. Stroke. 1995;26:1338-42. [pmid: 7631333].
456 Hayward R A, Hofer T P. Estimating hospital deaths due to medical errors: preventability is in the eye of the reviewer. JAMA. 2001;286:415-20. [pmid: 11466119].
457 Hazard J B. The Autopsy. JAMA. 1965;193:805-06. [pmid: 14329979].
458 Heasman MA, Lipworth L. Accuracy of certification of cause of death. London: HMSO; 1966
459 Heckerling P S, Williams M J. Attitudes of funeral directors and embalmers toward autopsy. Arch Pathol Lab Med. 1992;116:1147-51. [pmid: 1444743].
460 Hedinger C. Autopsies--valuable or unnecessary?. Schweiz Med Wochenschr (Swiss Journal of Medicine). 1982;112:70-5.
461 Heila H, Isometsa E T, Henriksson M M, Heikkinen M E, Marttunen M J, Lonnqvist J K. Suicide and schizophrenia: a nationwide psychological autopsy study on age- and sex-specific clinical characteristics of 92 suicide victims with schizophrenia. Am J Psychiatry. 1997;154:1235-42. [pmid: 9286182].
462 Helder H, Verbrugh H S, de Vries M J. Toward an holistic education in pathology and medicine. J Med Educ. 1977;52:648-53. [pmid: 886570].
463 Heller J, Friedlander D, Geller S A. Autopsy findings as a modifier of diagnosis-related group classification and hospital reimbursement. Mt Sinai J Med. 1985;52:311-4. [pmid: 3925330].
464 Helweg-Larsen K, Knudsen L B, Gregersen M, Simonsen J. Sudden infant death syndrome (SIDS) in Denmark: evaluation of the increasing incidence of registered SIDS in the period 1972 to 1983 and results of a prospective study in 1987 through 1988. Pediatrics. 1992;89:855-9. [pmid: 1579394].
465 Henson D E. Revisiting the autopsy. Arch Pathol Lab Med. 1990;114:127-8. [pmid: 2302028].
466 Hernandez F J, Kirby B D, Stanley T M, Edelstein P H. Legionnaires' disease. Postmortem pathologic findings of 20 cases. Am J Clin Pathol. 1980;73:488-95. [pmid: 7369172].
467 Hill R B Jr. College of American Pathologists Foundation Conference on the Autopsy. Conference recommendations. Arch Pathol Lab Med. 1984;108:512. [pmid: 6547305].
468 Hill R B, Anderson R E. Is a valid quality assurance program possible without the autopsy?. Hum Pathol. 1988;19:1125-6. [pmid: 3169721].
469 Hill R B. Pathology in the U.S.A., Part I. Pathol Res Pract. 1988;183:656-9. [pmid: 3070516].
470 Hill R B, Anderson R E. The autopsy and affairs of health. Arch Pathol Lab Med. 1989;113:1111-3. [pmid: 2802939].
471 Hill R B, Anderson R E. The evolving purposes of the autopsy: twenty-first-century values from an eighteenth-century procedure. Perspect Biol Med. 1989;32:223-33. [pmid: 2648319].
472 Hill R B, Anderson R E, Vance R P. The autopsy: a professional obligation dissected. Hum Pathol. 1990;21:127. [pmid: 2307438].
473 Hill RB, Anderson RE. The autopsy and health statistics. Leg Med. 1990:57–69.
474 Hill R B, Anderson R E. The autopsy crisis reexamined: the case for a national autopsy policy. Milbank Q. 1991;69:51-78. [pmid: 2034185].
475 Hill R B, Anderson R E. Pathologists and the autopsy. Am J Clin Pathol. 1991;95:S42-9. [pmid: 2008883].
476 Hill R B, Anderson R E. The uses and value of autopsy in medical education as seen by pathology educators. Acad Med. 1991;66:97-100. [pmid: 1993112].
477 Hill R B, Anderson R E. The autopsy in oncology. CA Cancer J Clin. 1992;42:47-56. [pmid: 1728338].
478 Hill R B, Anderson R E. An autopsy-based quality assessment program for improvement of diagnostic accuracy. Qual Assur Health Care. 1993;5:351-9. [pmid: 8018895].
479 Hill R B. The current status of autopsies in medical care in the USA. Qual Assur Health Care. 1993;5:309-13. [pmid: 8018888].
480 Hill R B. Autopsy consent and family resistance: the role of the clinician. South Med J. 1996;89:1125-6. [pmid: 8903307].
481 Hill R B, Anderson R E. The recent history of the autopsy. Arch Pathol Lab Med. 1996;120:702-12. [pmid: 8718895].
482 Hill R. College of American Pathologists Conference XXIX on restructuring autopsy practice for health care reform: Summary. Arch Pathol Lab Med. 1996;120:778-81.
483 Hinchliffe S A, Godfrey H W, Hind C R. Attitudes of junior medical staff to requesting permission for autopsy. Postgrad Med J. 1994;70:292-4. [pmid: 8183776].
484 Hinds S W, Reisner S A, Amico A F, Meltzer R S. Diagnosis of pericardial abnormalities by 2D-echo: a pathology-echocardiography correlation in 85 patients. Am Heart J. 1992;123:143-50. [pmid: 1729817].
485 Hirakata K, Nakata H, Haratake J. Appearance of pulmonary metastases on high-resolution CT scans: comparison with histopathologic findings from autopsy specimens. AJR Am J Roentgenol. 1993;161:37-43. [pmid: 8517317].
486 Hirsch F R, Matthews M J, Yesner R. Histopathologic classification of small cell carcinoma of the lung: comments based on an interobserver examination. Cancer. 1982;50:1360-6. [pmid: 6286092].
487 Hirsch C S. Talking to the family after an autopsy. Arch Pathol Lab Med. 1984;108:513-4. [pmid: 6547306].
488 Hirsch C S. Forensic pathology and the autopsy. Arch Pathol Lab Med. 1984;108:484-9. [pmid: 6547300].
489 Hirst A E, Johns V J, Kime S W. Dissecting aneurysm of the aorta: a review of 505 cases. Medicine (Baltimore). 1958;37:217-79. [pmcid: 126225]. [pmid: 13577293].
490 Hitosugi M. Retrospective analysis of the forensic autopsy cases of psychiatric patients. Med Sci Law. 1999;39:293-301. [pmid: 10581908].
491 Hiyoshi Y, Omae T, Hirota Y, Takeshita M, Ueda K, Katsuki S. Clinicopathological study of the heart and coronary arteries of autopsied cases from the community of Hisayama during a 10-year period. Part V. Comparison of autopsy findings with electrocardiograms--Q.QS items of the Minnesota Code. Am J Epidemiol. 1985;121:906-13. [pmid: 4014182].
492 Hnizdo E, Murray J, Sluis-Cremer G K, Thomas R G. Correlation between radiological and pathological diagnosis of silicosis: an autopsy population based study. Am J Ind Med. 1993;24:427-45. [pmid: 8250062].
493 Hnizdo E, Murray J, Davison A. Correlation between autopsy findings for chronic obstructive airways disease and in-life disability in South African gold miners. Int Arch Occup Environ Health. 2000;73:235-44. [pmid: 10877029].
494 Hodgson N F, Stewart T C, Girotti M J. Autopsies and death certification in deaths due to blunt trauma: what are we missing?. Can J Surg. 2000;43:130-6. [pmid: 10812348].
495 Hofman W I. The pathologist and the geriatric autopsy. J Am Geriatr Soc. 1975;23:11-3. [pmid: 1109382].
496 Hohl U, Tiraboschi P, Hansen L A, Thal L J, Corey-Bloom J. Diagnostic accuracy of dementia with Lewy bodies. Arch Neurol. 2000;57:347-51. [pmid: 10714660].
497 Holler J W, De Morgan N P. A retrospective study of 200 post-mortem examinations. J Med Educ. 1970;45:168-70. [pmid: 5418784].
498 Holmes J, Baer D M. Autopsy diagnoses can increase DRG reimbursement. Pathologist. 1986;40:36-9. [pmid: 10311733].
499 Holmes C, Cairns N, Lantos P, Mann A. Validity of current clinical criteria for Alzheimer's disease, vascular dementia and dementia with Lewy bodies. Br J Psychiatry. 1999;174:45-50. [pmid: 10211150].
500 Horton M D, Counter S F, Florence M G, Hart M J. A prospective trial of computed tomography and ultrasonography for diagnosing appendicitis in the atypical patient. Am J Surg. 2000;179:379-81. [pmid: 10930484].
501 Horwitz R I, Feinstein A R, Horwitz S M, Robboy S J. Necropsy diagnosis of endometrial cancer and detection-bias in case/control studies. Lancet. 1981;2:66-8. [pmid: 6113441].
502 Howell T H. Cardiac murmurs in old age: a clinico-pathological study. J Am Geriatr Soc. 1967;15:509-16. [pmid: 6023761].
503 Howell T H. Morgagni on disease in old age. J Am Geriatr Soc. 1975;23:558-9. [pmid: 1107398].
504 Hui A N, Koss M N, Meyer P R. Necropsy findings in acquired immunodeficiency syndrome: a comparison of premortem diagnoses with postmortem findings. Hum Pathol. 1984;15:670-6. [pmid: 6086491].
505 Hulette C M, Welsh-Bohmer K A, Crain B, Szymanski M H, Sinclaire N O, Roses A D. Rapid brain autopsy. The Joseph and Kathleen Bryan Alzheimer's Disease Research Center experience. Arch Pathol Lab Med. 1997;121:615-8. [pmid: 9199629].
506 Hull R D, Raskob G E, Brant R F, Pineo G F, Elliott G, Stein P D, et al. Low-molecular-weight heparin vs heparin in the treatment of patients with pulmonary embolism. American-Canadian Thrombosis Study Group. Arch Intern Med. 2000;160:229-36. [pmid: 10647762].
507 Hunt A C. The appropriate use of diagnostic services: (XI). The autopsy: a personal view. Health Bulletin. 1986;44:315-8. [pmid: 3818270].
508 Husain A N, Siddiqui M T, Reddy V B, Yeldandi V, Montoya A, Garrity E R. Postmortem findings in lung transplant recipients. Mod Pathol. 1996;9:752-61. [pmid: 8832558].
509 Huston B M, Malouf N N, Azar H A. Percutaneous needle autopsy sampling. Mod Pathol. 1996;9:1101-7. [pmid: 8972468].
510 Hutchins G M, Bulkley B H, Ridolfi R L, Griffith L S, Lohr F T, Piasio M A. Correlation of coronary arteriograms and left ventriculograms with postmortem studies. Circulation. 1977;56:32-7. [pmid: 862169].
511 Hutchins G M. Practice guidelines for autopsy pathology. Autopsy performance. Autopsy Committee of the College of American Pathologists. Arch Pathol Lab Med. 1994;118:19-25. [pmid: 8285830].
512 Hutchins GM. Practice guidelines for autopsy pathology. Autopsy reporting. Autopsy Committee of the College of American Pathologists. Arch Pathol Lab Med; 1995;119:123–30. Published erratum appears in Arch Pathol Lab Med 1995;119:408.
513 Hutchins G M. College of American Pathologists Conference XXIX on restructuring autopsy practice for health care reform: Introduction. Arch Pathol Lab Med. 1996;120:733.
514 Hutchins G M, Hanzlick R. Case of the month: Speculation and competing causes of death. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1998;158:1593-4. [pmid: 9701092].
515 Hutchins G M, Hanzlick R. Case of the month. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1998;158:219-20. [pmid: 9472200].
516 Hutchins G M, Berman J J, Moore G W, Hanzlick R. Practice guidelines for autopsy pathology: autopsy reporting. Autopsy Committee of the College of American Pathologists. Arch Pathol Lab Med. 1999;123:1085-92. [pmid: 10539932].
517 Hutter RV. Quality assurance in cancer care. Cancer. 1989;64(Suppl 1):244–48, 53–57.
518 Hyman B T, Trojanowski J Q. Consensus recommendations for the postmortem diagnosis of Alzheimer disease from the National Institute on Aging and the Reagan Institute Working Group on diagnostic criteria for the neuropathological assessment of Alzheimer disease. J Neuropathol Exp Neurol. 1997;56:1095-7. [pmid: 9329452].
519 Ironside J W, Bell J E. The ‘high-risk’ neuropathological autopsy in AIDS and Creutzfeldt-Jakob disease: principles and practice. Neuropathology & Applied Neurobiology. 1996;22:388-93. [pmid: 8930948].
520 Isaksen C, Eik-Nes S, Blaas H, Torp S. Comparison of prenatal ultrasound and postmortem findings in fetuses and infants with central nervous system anomalies. Ultrasound Obstet Gynecol. 1998;11:246-53. [pmid: 9618846].
521 Isaksen C V, Eik-Nes S H, Blaas H G, Tegnander E, Torp S H. Comparison of prenatal ultrasound and postmortem findings in fetuses and infants with congenital heart defects. Ultrasound Obstet Gynecol. 1999;13:117-26. [pmid: 10079491].
522 Isaksen C, Eik-Nes S, Blaas H, Torp S. Fetuses and infants with congenital urinary system anomalies: correlation between prenatal ultrasound and postmortem findings. Ultrasound Obstet Gynecol. 2000;15:177-85. [pmid: 10846770].
523 Iserson K V. Postmortem procedures in the emergency department: using the recently dead to practise and teach. J Med Ethics. 1993;19:92-8. [pmid: 8331644].
524 Iso H, Jacobs D R Jr, Goldman L. Accuracy of death certificate diagnosis of intracranial hemorrhage and nonhemorrhagic stroke. The Minnesota Heart Survey. Am J Epidemiol. 1990;132:993-8. [pmid: 2239914].
525 Iwai K, Sekiguti M, Hosoda Y, DeRemee R A, Tazelaar H D, Sharma O P, et al. Racial difference in cardiac sarcoidosis incidence observed at autopsy. Sarcoidosis. 1994;11:26-31. [pmid: 8036339].
526 Jacobs L, Kinkel W R, Heffner R R Jr. Autopsy correlations of computerized tomography: experience with 6,000 CT scans. Neurology. 1976;26:1111-8. [pmid: 186726].
527 James G, Patton R E, Heslin A S. Accuracy of cause-of-death statements on death certificates. Public Health Reports. 1955;70:39-51. [pmid: 13224799].
528 Jamieson W R, Munro A I, Miyagishima R T, Allen P, Tyers G F, Gerein A N. Aortic dissection: early diagnosis and surgical management are the keys to survival. Can J Surg. 1982;25:145-9. [pmid: 7066774].
529 Jankovic J, Rajput A H, McDermott M P, Perl D P. The evolution of diagnosis in early Parkinson disease. Parkinson Study Group. Arch Neurol. 2000;57:369-72. [pmid: 10714663].
530 Janssens J P, Herrmann F, MacGee W, Michel J P. Cause of death in older patients with anatomo-pathological evidence of chronic bronchitis or emphysema: a case-control study based on autopsy findings. J Am Geriatr Soc. 2001;49:571-6. [pmid: 11380749].
531 Jason D R, Lantz P E, Preisser J S. A national survey of autopsy cost and workload. J Forensic Sci. 1997;42:270-5. [pmid: 9068185].
532 Jasper J D, Nickerson C A, Hershey J C, Asch D A. The public's attitudes toward incentives for organ donation. Transplant Proc. 1999;31:2181-4. [pmid: 10456008].
533 Jeannot J G, Vader J P, Porchet F, Larequi-Lauber T, Burnand B. Can the decision to operate be judged retrospectively? A study of medical records. Eur J Surg. 1999;165:516-21. [pmid: 10433132].
534 Jellinger K A, Bancher C. Proposals for re-evaluation of current autopsy criteria for the diagnosis of Alzheimer's disease. Neurobiol Aging. 1997;18:S55-65. [pmid: 9330987].
535 Jellinger K, Setinek U, Drlicek M, Bohm G, Steurer A, Lintner F. Neuropathology and general autopsy findings in AIDS during the last 15 years. Acta Neuropathol (Berl). 2000;100:213-20. [pmid: 10963370].
536 Jentzen J M, Rosenberg S. The medical examiner and deaths in the hospital setting. Physician Exec. 1994;20:34-6. [pmid: 10133531].
537 Johanson W G Jr, Seidenfeld J J, Gomez P, de los Santos R, Coalson J J. Bacteriologic diagnosis of nosocomial pneumonia following prolonged mechanical ventilation. Am Rev Respir Dis. 1988;137:259-64. [pmid: 3341619].
538 Jonasson JG, Bjornsson J. Autopsy: clinicopathological concordance and imaging techniques. IARC Sci Publ. 1991:91–8.
539 Jones A M, Weston J T. The examination of the sudden infant death syndrome infant: investigative and autopsy protocols. J Forensic Sci. 1976;21:833-41. [pmid: 972311].
540 Jones B A, Novis D A. Cervical biopsy-cytology correlation. A College of American Pathologists Q-Probes study of 22 439 correlations in 348 laboratories. Arch Pathol Lab Med. 1996;120:523-31. [pmid: 8651852].
541 Jones B A. Rescreening in gynecologic cytology. Rescreening of 8096 previous cases for current low-grade and indeterminate-grade squamous intraepithelial lesion diagnoses--a College of American Pathologists Q-Probes study of 323 laboratories. Arch Pathol Lab Med. 1996;120:519-22. [pmid: 8651851].
542 Jones K, Berrill W T, Bromly C L, Hendrick D J. A confidential enquiry into certified asthma deaths in the North of England, 1994-96: influence of co-morbidity and diagnostic inaccuracy. Respir Med. 1999;93:923-7. [pmid: 10653057].
543 Jonsdottir L S, Sigfusson N, Sigvaldason H, Thorgeirsson G. Incidence and prevalence of recognised and unrecognised myocardial infarction in women. The Reykjavik Study. Eur Heart J. 1998;19:1011-8. [pmid: 9717035].
544 Jordan J M, Bass M J. Errors in death certificate completion in a teaching hospital. Clin Invest Med. 1993;16:249-55. [pmid: 8306533].
545 Jorgensen T, Rossen K, Thorvaldsen P. Are autopsy studies reliable in assessing gallstone prevalence in the community?. Int J Epidemiol. 1994;23:566-9. [pmid: 7960383].
546 Juvin P, Teissiere F, Brion F, Desmonts J, Durigon M. Postoperative death and malpractice suits: is autopsy useful?. Anesth Analg. 2000;91:344-6. [pmid: 10910845].
547 Kabra N S, Udani R H. Correlation between clinical diagnoses at the time of death and autopsy findings in critically sick neonates at a regional neonatal intensive care unit in India. J Trop Pediatr. 2001;47:295-300. [pmid: 11695730].
548 Kairys S W, Alexander R C, Block R W, Everett V D, Hymel K P, Johnson C F, et al. American Academy of Pediatrics. Committee on Child Abuse and Neglect and Committee on Community Health Services. Investigation and review of unexpected infant and child deaths. Pediatrics. 1999;104:1158-60. [pmid: 10545567].
549 Kajiwara J K, Zucoloto S, Manco A R, Muccillo G, Barbieri M A. Accuracy of clinical diagnoses in a teaching hospital: a review of 997 autopsies. J Intern Med. 1993;234:181-7. [pmid: 8340741].
550 Kamal I, Forsyth D, Jones J. Does it matter who requests necropsies? Prospective study of effect of clinical audit on rate of requests. BMJ. 1997;314:1729. [pmid: 9202503].
551 Kannel W B, Abbott R D. Incidence and prognosis of unrecognized myocardial infarction. An update on the Framingham study. N Engl J Med. 1984;311:1144-7. [pmid: 6482932].
552 Kannel W B. Silent myocardial ischemia and infarction: insights from the Framingham Study. Cardiol Clin. 1986;4:583-91. [pmid: 3779719].
553 Kaplan R A. The autopsy-to be or not to be. Hum Pathol. 1978;9:127-9. [pmid: 640637].
554 Kappel T J, Reinartz J J, Schmid J L, Holter J J, Azar M M. The viability of Mycobacterium tuberculosis in formalin-fixed pulmonary autopsy tissue: review of the literature and brief report. Hum Pathol. 1996;27:1361-4. [pmid: 8958312].
555 Karsner H, Rothschild L, Crump E S. Clinical Diagnosis as Compared with Necropsy Findings. JAMA. 1912;73:666-69.
556 Karunaratne S, Benbow E W. A survey of general practitioners' views on autopsy reports. J Clin Pathol. 1997;50:548-52. [pmcid: 500046]. [pmid: 9306932].
557 Karwinski B, Svendsen E. Comparison of clinical and postmortem diagnosis of pulmonary embolism. J Clin Pathol. 1989;42:135-9. [pmcid: 1141815]. [pmid: 2921354].
558 Karwinski B, Svendsen E, Hartveit F. Changes in the cancer spectrum at autopsy: 1975-1984. J Pathol. 1989;157:117-25. [pmid: 2921672].
559 Karwinski B, Svendsen E, Seim S. Pulmonary embolism and heart disease. An autopsy study. Pathol Res Pract. 1993;189:1058-62. [pmid: 8302725].
560 Katsuki S, Hirota Y. Recent trends in incidence of cerebral hemorrhage and infarction in Japan. A report based on death rate, autopsy case and prospective study on cerebrovasuclar disease. Jpn Heart J. 1966;7:26-34. [pmid: 5295641].
561 Katz J L, Gardner R. The intern's dilemma: the request for autopsy consent. Psychiatry in Medicine. 1972;3:197-203. [pmid: 4679773].
562 Katz J L, Gardner R. Request for autopsy consent. Conflict and challenge. NY State J Med. 1973;73:2591-6.
563 Katz P R, Seidel G. Nursing home autopsies. Survey of physician attitudes and practice patterns. Arch Pathol Lab Med. 1990;114:145-7. [pmid: 2302031].
564 Kaufman S R. Autopsy. A crucial component of human clinical investigation. Arch Pathol Lab Med. 1996;120:767-70. [pmid: 8718904].
565 Kay M H, Moodie D S, Sterba R, Murphy D J Jr, Rosenkranz E, Ratliff N, et al. The value of the autopsy in congenital heart disease. Clin Pediatr (Phila). 1991;30:450-4. [pmcid: 358331]. [pmid: 1879103].
566 Kazmers A, Jacobs L, Perkins A, Lindenauer S M, Bates E. Autopsies--VA. Final rule; Abdominal aortic aneurysm repair in Veterans Affairs medical centers. Fed Regist. 1996;61:29293-4. [pmid: 10158601].
567 Kelly T M, Mann J J. Validity of DSM-III-R diagnosis by psychological autopsy: a comparison with clinician ante-mortem diagnosis. Acta Psychiatr Scand. 1996;94:337-43. [pmid: 9124080].
568 Kencian J D, Duflou J, Hilton J M. Medicolegal postmortem examinations in rural New South Wales. Another rural health problem. Med J Aust. 1994;161:366-8. [pmid: 8090113].
569 Kendrey G, Szende B, Lapis K, Marton T, Hargitai B, Roe F J, et al. Misdiagnosis of lung cancer in a 2000 consecutive autopsy study in Budapest. Gen Diagn Pathol. 1996;141:169-78. [pmid: 8705779].
570 Keogh A T, Akhtar T M. Diagnosing brain death: the importance of documenting clinical test results. Anaesthesia. 1999;54:81-5. [pmid: 10209376].
571 Khan K S, Dinnes J, Kleijnen J. Systematic reviews to evaluate diagnostic tests. Eur J Obstet Gynecol Reprod Biol. 2001;95:6-11. [pmid: 11267714].
572 Khong T Y. Ethical considerations of the perinatal necropsy. J Med Ethics. 1996;22:111-4. [pmid: 8731538].
573 Khong TY. A review of perinatal autopsy rates worldwide, 1960s to 1990s Paediatric & Perinatal Epidemiology. 1996;10:97–105; discussion 06–9.
574 Khunti K. Referral for autopsies: analysis of 651 consecutive deaths in one general practice. Postgrad Med J. 2000;76:415-16. [pmid: 10878201].
575 Kiesel E, Hanzlick R. Case of the month. The autopsy and new technology: all that glitters is not a gold standard. Arch Intern Med. 2000;160:1901-2. [pmid: 10888963].
576 Kim H S, Suzuki M, Lie J T, Titus J L. Clinically unsuspected disseminated intravascular coagulation (DIC): an autopsy survey. Am J Clin Pathol. 1976;66:31-9. [pmid: 937273].
577 Kimura W, Nagai H, Kuroda A, Morioka Y. Clinicopathologic study of asymptomatic gallbladder carcinoma found at autopsy. Cancer. 1989;64:98-103. [pmid: 2731127].
578 King D W. Potential of the autopsy. Arch Pathol Lab Med. 1984;108:439-43. [pmid: 6547292].
579 King E M, Smith A, Jobst K A. Autopsy: consent, completion and communication in Alzheimer's disease research. Age and Ageing. 1993;22:209-14. [pmid: 8503318].
580 Kingsford D P. A review of diagnostic inaccuracy. Med Sci Law. 1995;35:347-51. [pmid: 7500860].
581 Kirch W, Schafii C. Reflections on misdiagnosis. J Intern Med. 1994;235:399-404. [pmid: 8182393].
582 Kirch W, Schafii C. Misdiagnosis at a university hospital in 4 medical eras. Medicine (Baltimore). 1996;75:29-40. [pmcid: 126225]. [pmid: 8569468].
583 Kircher T, Nelson J, Burdo H. The autopsy as a measure of accuracy of the death certificate. N Engl J Med. 1985;313:1263-9. [pmid: 4058507].
584 Kircher T, Nelson J, Burdo H. Descriptive epidemiology of the autopsy in Connecticut, 1979-1980. Arch Pathol Lab Med. 1985;109:904-9. [pmid: 3840002].
585 Kircher T, Anderson R E. Cause of death. Proper completion of the death certificate. JAMA. 1987;258:349-52. [pmid: 3599328].
586 Kircher T. The autopsy and vital statistics. Hum Pathol. 1990;21:166-73. [pmid: 2307444].
587 Kircher TL. Autopsy and mortality statistics: making a difference. JAMA. 1992;267:1264, 68.
588 Kirkham N. The autopsy in inner cities. J R Soc Med. 1994;87:645-6. [pmid: 7837178]. [pmcid: 1294923].
589 Kirtland S H, Corley D E, Winterbauer R H, Springmeyer S C, Casey K R, Hampson N B, et al. The diagnosis of ventilator-associated pneumonia: a comparison of histologic, microbiologic, and clinical criteria. Chest. 1997;112:445-57. [pmid: 9266883].
590 Klatt E C, Noguchi T T. The medical examiner and AIDS. Death certification, safety procedures, and future medicolegal issues. Am J Forensic Med Pathol. 1988;9:141-8. [pmid: 3381793].
591 Klatt E C. Diagnostic findings in patients with acquired immune deficiency syndrome (AIDS). J Acquir Immune Defic Syndr. 1988;1:459-65. [pmid: 2851652].
592 Kleiner D E, Emmert-Buck M R, Liotta L A. Necropsy as a research method in the age of molecular pathology. Lancet. 1995;346:945-8. [pmid: 7564732].
593 Kleinschmidt-DeMasters B K, Anderson C A, Rubinstein D. Asymptomatic pontine lesions found by magnetic resonance imaging: are they central pontine myelinolysis?. J Neurol Sci. 1997;149:27-35. [pmid: 9168162].
594 Klima M, Povysil C, Teasdale T. Causes of death in geriatric patients: a cross-cultural study. J Gerontol A Biol Sci Med Sci. 1997;52:M247-53. [pmid: 9224437].
595 Klupp N, Risser D, Heinzl H, Bauer G. Forensic autopsies from 1984 to 1993 in Vienna, Austria. J Forensic Sci. 1997;42:675-7. [pmid: 9280779].
596 Knapp V J. Postmortems and the growth of modern medical knowledge in 19th century Europe. J Okla State Med Assoc. 1983;76:73-6. [pmid: 6341523].
597 Knight B, Zaini M R. Pulmonary embolism and venous thrombosis. A pattern of incidence and predisposing factors over 70 years. Am J Forensic Med Pathol. 1980;1:227-32. [pmid: 7234813].
598 Knight B. The role of the pathologist in the investigation of iatrogenic deaths. Malays J Pathol; 1992. p. 7–11.
599 Ko C W, Gooley T, Schoch H G, Myerson D, Hackman R C, Shulman H M, et al. Acute pancreatitis in marrow transplant patients: prevalence at autopsy and risk factor analysis. Bone Marrow Transplant. 1997;20:1081-6. [pmid: 9466282].
600 Kohn L, Corrigan J, Donaldson M, editors. To Err Is Human: Building a Safer Health System. Washington, D.C.: Committee on Quality of Health Care in America, Institute of Medicine. National Academy Press; 2000
601 Kondo T, Ohshima T. Retrospective investigation of medico-legal autopsy cases involving mentally handicapped individuals. Nippon Hoigaku Zasshi. 1995;49:478-83. [pmid: 8583692].
602 Kondoh T, Westesson P L. Diagnostic accuracy of temporomandibular joint lower-compartment arthroscopy using an ultrathin arthroscope: a postmortem study. J Oral Maxillofac Surg. 1991;49:619-26. [pmid: 2037918].
603 Korner H, Sondenaa K, Soreide J A, Andersen E, Nysted A, Lende T H, et al. Incidence of acute nonperforated and perforated appendicitis: age-specific and sex-specific analysis. World J Surg. 1997;21:313-7. [pmid: 9015177].
604 Koszyca B, Moore L, Toogood I, Byard R W. Is postmortem examination useful in pediatric oncology?. Pediatr Pathol. 1993;13:709-15. [pmid: 8108290].
605 Kukull W A, Larson E B, Reifler B V, Lampe T H, Yerby M S, Hughes J P. The validity of 3 clinical diagnostic criteria for Alzheimer's disease. Neurology. 1990;40:1364-9. [pmid: 2392219].
606 Kumar P, Taxy J, Angst D B, Mangurten H H. Autopsies in children: are they still useful?. Arch Pediatr Adolesc Med. 1998;152:558-63. [pmid: 9641709].
607 Kumar P, Angst D, Taxy J, Mangurten H. Neonatal autopsies: a 10-year experience. Arch Pediatr Adolesc Med. 2000;154:38-42. [pmid: 10632248].
608 Kung H C, Hanzlick R, Spitler J F. Abstracting data from medical examiner/coroner reports: concordance among abstractors and implications for data reporting. J Forensic Sci. 2001;46:1126-31. [pmid: 11569554].
609 Kunitz S J, Edland J F. The epidemiology of autopsies in Monroe County, New York. J Forensic Sci. 1973;18:370-9. [pmid: 4784306].
610 Kupari M, Volin L, Suokas A, Timonen T, Hekali P, Ruutu T. Cardiac involvement in bone marrow transplantation: electrocardiographic changes, arrhythmias, heart failure and autopsy findings. Bone Marrow Transplant. 1990;5:91-8. [pmid: 2138043].
611 Lam K, Tang V. Metastatic tumors to the spleen: a 25-year clinicopathologic study. Arch Pathol Lab Med. 2000;124:526-30. [pmid: 10747308].
612 Lam K Y, Lo C Y. A critical examination of adrenal tuberculosis and a 28-year autopsy experience of active tuberculosis. Clin Endocrinol (Oxf). 2001;54:633-9. [pmcid: 298219]. [pmid: 11380494].
613 Lamarre-Cliche M, Castilloux A M, LeLorier J. Association between the burden of disease and research funding by the Medical Research Council of Canada and the National Institutes of Health. A cross-sectional study. Clin Invest Med. 2001;24:83-9. [pmid: 11368150].
614 Landefeld C S, Chren M M, Myers A, Geller R, Robbins S, Goldman L. Diagnostic yield of the autopsy in a university hospital and a community hospital. N Engl J Med. 1988;318:1249-54. [pmid: 3362177].
615 Landefeld C S, Goldman L. The autopsy in clinical medicine. Mayo Clin Proc. 1989;64:1185-9. [pmid: 2509830].
616 Landefeld C S, Goldman L. The value of autopsy in modern oncology. Eur J Cancer Clin Oncol. 1989;25:607-9. [pmid: 2653844].
617 Landefeld C S, Goldman L. The autopsy in quality assurance: history, current status, and future directions. Qrb. Quality Review Bulletin. 1989;15:42-8. [pmid: 2495500].
618 Landers S, Kirby R, Harvey B, Langston C. Characteristics of infants who undergo neonatal autopsy. J Perinatol. 1994;14:204-7. [pmid: 8064425].
619 Landers S, MacPherson T. Prevalence of the neonatal autopsy: a report of the Study Group for Complications of Perinatal Care. Pediatr Pathol Lab Med. 1995;15:539-45. [pmid: 8597840].
620 Lannin D R, Mathews H F, Mitchell J, Swanson M S, Swanson F H, Edwards M S. Influence of socioeconomic and cultural factors on racial differences in late-stage presentation of breast cancer. JAMA. 1998;279:1801-7. [pmid: 9628711].
621 Lau G. Perioperative deaths: a comparative study of coroner's autopsies between the periods of 1989-1991 and 1992-1994. Ann Acad Med Singapore; 1996. p. 509–15.
622 Lau G. Perioperative deaths: a further comparative review of coroner's autopsies with particular reference to the occurrence of fatal iatrogenic injury. Ann Acad Med Singapore. 2000;29:486-97. [pmid: 11056779].
623 Lauder I. Auditing necropsies. BMJ. 1991;303:1214-5. [pmid: 1747636]. [pmcid: 1671537].
624 Leape L L. A systems analysis approach to medical error. J Eval Clin Pract. 1997;3:213-22. [pmid: 9406109].
625 Lee T H, Rouan G W, Weisberg M C, Brand D A, Acampora D, Stasiulewicz C, et al. Clinical characteristics and natural history of patients with acute myocardial infarction sent home from the emergency room. Am J Cardiol. 1987;60:219-24. [pmid: 3618483].
626 Lee J K, Ng T H. Undiagnosed tuberculosis in hospitalized patients--an autopsy survey. J R Soc Health. 1990;110:141-3. [pmid: 2121983].
627 Lee P N. Comparison of autopsy, clinical and death certificate diagnosis with particular reference to lung cancer. A review of the published data. APMIS Suppl. 1994;45:1-42. [pmid: 7811528].
628 Lee E Y, Cibull M L, Hanzlick R. Case of the month. The Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1997;157:2044. [pmid: 9382658].
629 Lee A, Borek B, Gallagher P, Saunders R, Lamb R, Livesey S, et al. Prospective study of the value of necropsy examination in early death after cardiac surgery. Heart. 1997;78:34-8. [pmid: 9290399]. [pmcid: 484861].
630 Lee A H, Gallagher P J. Post-mortem examination after cardiac surgery. Histopathology. 1998;33:399-405. [pmid: 9839163].
631 Lee S L, Walsh A J, Ho H S. Computed tomography and ultrasonography do not improve and may delay the diagnosis and treatment of acute appendicitis. Arch Surg. 2001;136:556-62. [pmid: 11343547].
632 Leslie K O, Fechner R E, Kempson R L. Second opinions in surgical pathology. Am J Clin Pathol. 1996;106:S58-64. [pmid: 8853058].
633 Levinson D C, Edmeades D T, Griffith G C. Dissecting aneurysm of aorta: its clinical, electrocardiographic, and laboratory features; report of 58 autopsied cases. Circulation. 1950;1:360. [pmid: 15405705].
634 Levy R P, Miraldi F D. The frequency and detection of serious postoperative thromboembolic disease. Surgery, Gynecology and Obstetrics. 1975;140:903-8.
635 Lie J T. Diagnostic histology of myocardial disease in endomyocardial biopsies and at autopsy. Pathology Annual. 1989;24:255-93. [pmid: 2671884].
636 Liedberg J, Westesson P L. Diagnostic accuracy of upper compartment arthroscopy of the temporomandibular joint: correlation with postmortem morphology. Oral Surg Oral Med Oral Pathol. 1986;62:618-24. [pmid: 3467287].
637 Lijmer J G, Mol B W, Heisterkamp S, Bonsel G J, Prins M H, van der Meulen J H, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. 1999;282:1061-6. [pmid: 10493205].
638 Lind A C, Bewtra C, Healy J C, Sims K L. Prospective peer review in surgical pathology. Am J Clin Pathol. 1995;104:560-6. [pmid: 7572817].
639 Lindblad B, Eriksson A, Bergqvist D. Autopsy-verified pulmonary embolism in a surgical department: analysis of the period from 1951 to 1988. Br J Surg. 1991;78:849-52. [pmid: 1873716].
640 Lindblad B, Sternby N H, Bergqvist D. Incidence of venous thromboembolism verified by necropsy over 30 years. BMJ. 1991;302:709-11. [pmid: 2021744]. [pmcid: 1669118].
641 Lindgren A. Autopsy and cause of death in randomized mammography studies. Quality Assurance in Health Care. 1993;5:303-7. [pmid: 8018887].
642 Lindstrom P, Janzon L, Sternby N H. Declining autopsy rate in Sweden: a study of causes and consequences in Malmo, Sweden. J Intern Med. 1997;242:157-65. [pmid: 9279293].
643 Linell F, Ostberg G. Tuberculosis in autopsy material, with special reference to cases not discovered until necropsy. Scand J Respir Dis. 1966;47:200-8. [pmid: 5180860].
644 Lipsky MS. Autopsy: role of the family physician Am Fam Physician. 1993;47:1605–10.
645 Litvan I, Agid Y, Goetz C, Jankovic J, Wenning G, Brandel J, et al. Accuracy of the clinical diagnosis of corticobasal degeneration: a clinicopathologic study. Neurology. 1997;48:119-25. [pmid: 9008506].
646 Litvan I, Agid Y, Sastry N, Jankovic J, Wenning G, Goetz C, et al. What are the obstacles for an accurate clinical diagnosis of Pick's disease? A clinicopathologic study. Neurology. 1997;49:62–9. Published erratum appears in Neurology 1997; 49(6):1755.
647 Litvan I, Goetz C, Jankovic J, Wenning G, Booth V, Bartko J, et al. What is the accuracy of the clinical diagnosis of multiple system atrophy? A clinicopathologic study. Arch Neurol. 1997;54:937-44. [pmid: 9267967].
648 Lo C Y, Lam K Y, Wat M S, Lam K S. Adrenal pheochromocytoma remains a frequently overlooked diagnosis. Am J Surg. 2000;179:212-5. [pmid: 10827323].
649 Long R, O'Connor R, Palayew M, Hershfield E, Manfreda J. Disseminated tuberculosis with and without a miliary pattern on chest radiograph: a clinical-pathologic-radiologic correlation. Int J Tuberc Lung Dis. 1997;1:52-8. [pmid: 9441059].
650 Lotz PR, Ballinger WE, Jr., Quisling RG. Subcortical arteriosclerotic encephalopathy: CT spectrum and pathologic correlation. AJR Am J Roentgenol. 1986;147:1209–14. Published erratum appears in AJR Am J Roentgenol 1987;148(3):659.
651 Lowe J A, Davis C J. Need we revive falling autopsy rates? Time trends in PAS hospitals in the United States. PAS Rep. 1977;15:1-7. [pmid: 10307292].
652 Lowry F. Failure to perform autopsies means some MDs “walking in a fog of misplaced optimism”. CMAJ. 1995;153:811-4. [pmid: 7664234]. [pmcid: 1487286].
653 Lucas S B. HIV and the necropsy. J Clin Pathol. 1993;46:1071-5. [pmcid: 501712]. [pmid: 8282829].
654 Lucas S. The autopsy in the 1990s. Br J Hosp Med. 1998;58:544-5. [pmid: 10193465].
655 Luis C A, Barker W W, Gajaraj K, Harwood D, Petersen R, Kashuba A, et al. Sensitivity and specificity of three clinical criteria for dementia with Lewy bodies in an autopsy-verified sample. Int J Geriatr Psychiatry. 1999;14:526-33. [pmid: 10440972].
656 Lundberg G D, Voigt G E. Reliability of a presumptive diagnosis in sudden unexpected death in adults. The case for the autopsy. JAMA. 1979;242:2328-30. [pmid: 490836].
657 Lundberg G D. Pathology. JAMA. 1979;241:1381-3. [pmid: 430661].
658 Lundberg G D. Medical students, truth, and autopsies. JAMA. 1983;250:1199-200. [pmid: 6876359].
659 Lundberg G D. Medicine without the autopsy. Arch Pathol Lab Med. 1984;108:449-54. [pmid: 6428374].
660 Lundberg G D. The Archives of Pathology and Laboratory Medicine and the autopsy. JAMA. 1984;252:390-2. [pmid: 6737630].
661 Lundberg G D. Futurology in pathology and laboratory medicine. JAMA. 1987;258:378-9. [pmid: 3599333].
662 Lundberg G D. Now is the time to emphasize the autopsy in quality assurance. JAMA. 1988;260:3488. [pmid: 3210289].
663 Lundberg G D. Rescuing that great resource--the autopsy. Am Fam Physician. 1993;47:1569. [pmid: 8503340].
664 Lundberg G D. Attitudes toward autopsy and organ donation in Sweden and the United States. JAMA. 1994;271:317. [pmid: 8295294].
665 Lundberg G D. College of American Pathologists Conference XXIX on restructuring autopsy practice for health care reform. Let's make this autopsy conference matter. Arch Pathol Lab Med. 1996;120:736-8. [pmid: 8718897].
666 Lundberg G D. Low-tech autopsies in the era of high-tech medicine: continued value for quality assurance and patient safety. JAMA. 1998;280:1273-4. [pmid: 9786381].
667 Maasilta P, Vehmas T, Kivisaari L, Tammilehto L, Mattson K. Correlations between findings at computed tomography (CT) and at thoracoscopy/thoracotomy/autopsy in pleural mesothelioma. Eur Respir J. 1991;4:952-4. [pmid: 1783086].
668 Macintyre I M, Ruckley C V. Pulmonary embolism--a clinical and autopsy study. Scott Med J. 1974;19:20-4. [pmid: 4820007].
669 Mackenbach J P, Van Duyne W M, Kelson M C. Certification and coding of two underlying causes of death in The Netherlands and other countries of the European Community. J Epidemiol Community Health. 1987;41:156-60. [pmid: 3655636].
670 MacKenzie J. Are all cardio-embolic strokes embolic? An autopsy study of 100 consecutive acute ischaemic strokes. Cerebrovasc Dis. 2000;10:289-92. [pmid: 10878434].
671 MacKenzie J M. Are all cardio-embolic strokes embolic? An autopsy study of 100 consecutive acute ischaemic strokes. Cerebrovasc Dis. 2000;10:289-92. [pmid: 10878434].
672 Maclaine GD, Macarthur EB, Heathcote CR. A comparison of death certificates and autopsies in the Australian Capital Territory. Med J Aust. 1992;156:462–3, 66–8.
673 Madden S C. How Many Autopsies?. JAMA. 1965;193:812-13. [pmid: 14329983].
674 Maertens J, Verhaegen J, Demuynck H, Brock P, Verhoef G, Vandenberghe P, et al. Autopsy-controlled prospective evaluation of serial screening for circulating galactomannan by a sandwich enzyme-linked immunosorbent assay for hematological patients at risk for invasive Aspergillosis. J Clin Microbiol. 1999;37:3223-8. [pmcid: 85532]. [pmid: 10488181].
675 Mafune K, Tanaka Y, Takubo K. Autopsy findings in patients with esophageal carcinoma: comparison between resection and nonresection groups. J Surg Oncol. 2000;74:196-200. [pmid: 10951416].
676 Maiche A G. Cancer of unknown primary. A retrospective study based on 109 patients. Am J Clin Oncol. 1993;16:26-9. [pmid: 8424399].
677 Majeed A, Lehmann P, Kirby L, Knight R, Coleman M. Extent of misclassification of death from Creutzfeldt-Jakob disease in England 1979-96: retrospective examination of clinical records. BMJ. 2000;320:145-7. [pmcid: 27259]. [pmid: 10634732].
678 Maloney D, Keller S J, Fierro M F. Child deaths in Virginia, 1996: a review of investigations of sudden, unexpected, or unnatural deaths of children less than age 13. Am J Forensic Med Pathol. 2000;21:189-94. [pmid: 10871138].
679 Mandard A M, Chasle J, Marnay J, Villedieu B, Bianco C, Roussel A, et al. Autopsy findings in 111 cases of esophageal cancer. Cancer. 1981;48:329-35. [pmid: 6453643].
680 Mandelli V, Schmid C, Zogno C, Morpurgo M. “False negatives” and “false positives” in acute pulmonary embolism: a clinical-postmortem comparison. Cardiologia. 1997;42:205-10. [pmid: 9090162].
681 Mann J M, Davies M J. Assessment of the severity of coronary artery disease at postmortem examination. Are the measurements clinically valid?. Br Heart J. 1995;74:528-30. [pmid: 8562239]. [pmcid: 484074].
682 Mao C, Domenico D R, Kim K, Hanson D J, Howard J M. Observations on the developmental patterns and the consequences of pancreatic exocrine adenocarcinoma. Findings of 154 autopsies. Arch Surg. 1995;130:125-34. [pmid: 7848081].
683 Markle C D, Evans E C. Adrenal hemorrhage associated with anticoagulant therapy. South Med J. 1970;63:526-9. [pmid: 5446820].
684 Maron B J, Shirani J, Poliac L C, Mathenge R, Roberts W C, Mueller F O. Sudden death in young competitive athletes. Clinical, demographic, and pathological profiles. JAMA. 1996;276:199-204. [pmid: 8667563].
685 Massoud F, Devi G, Stern Y, Lawton A, Goldman J E, Liu Y, et al. A clinicopathological comparison of community-based and clinic-based cohorts of patients with dementia. Arch Neurol. 1999;56:1368-73. [pmid: 10555657].
686 Mathews H F, Lannin D R, Mitchell J P. Coming to terms with advanced breast cancer: black women's narratives from eastern North Carolina. Soc Sci Med. 1994;38:789-800. [pmid: 8184330].
687 Matsubara O, Sato T, Kitagawa M, Kasuga T. Pulmonary thromboembolism: frequency, site, and vascular change in 103 autopsy cases. Am J Cardiovasc Pathol. 1989;2:321-8. [pmid: 2789806].
688 Matsuse T, Oka T, Kida K, Fukuchi Y. Importance of diffuse aspiration bronchiolitis caused by chronic occult aspiration in the elderly. Chest. 1996;110:1289-93. [pmid: 8915236].
689 McCarron K F, Prayson R A. The neuropathology of orthotopic liver transplantation: an autopsy series of 16 patients. Arch Pathol Lab Med. 1998;122:726-31. [pmid: 9701335].
690 McCarthy B D, Beshansky J R, D'Agostino R B, Selker H P. Missed diagnoses of acute myocardial infarction in the emergency department: results from a multicenter study. Ann Emerg Med. 1993;22:579-82. [pmid: 8442548].
691 McFarlane M J, Feinstein A R, Wells C K. Clinical features of lung cancers discovered as a postmortem “surprise”. Chest. 1986;90:520-3. [pmid: 3757562].
692 McFarlane M J, Feinstein A R, Wells C K. Necropsy evidence of detection bias in the diagnosis of lung cancer. Arch Intern Med. 1986;146:1695-8. [pmid: 3753108].
693 McFarlane M J, Feinstein A R, Wells C K, Chan C K. The ‘epidemiologic necropsy’. Unexpected detections, demographic selections, and changing rates of lung cancer. JAMA. 1987;258:331-8. [pmid: 3599325].
694 McFarlane M J. Absence of demographic bias in selection for necropsy. Arch Pathol Lab Med. 1987;111:67-70. [pmid: 3800605].
695 McFarlane M J. Clinical diagnosis is not a source of bias in selection for necropsy. Arch Pathol Lab Med. 1989;113:64-7. [pmid: 2910228].
696 McFarlane M J. Supportive evidence for the validity of the epidemiologic necropsy for gallstones. J Gen Intern Med. 1990;5:495-500. [pmid: 2266431].
697 McFarlane M J. The epidemiologic necropsy for abdominal aortic aneurysm. JAMA. 1991;265:2085-8. [pmid: 2013928].
698 McGoogan E, Cameron H M. Clinical attitudes to the autopsy. Scott Med J. 1978;23:19-22. [pmid: 635534].
699 McGoogan E. The autopsy and clinical diagnosis. J R Coll Physicians Lond. 1984;18:240-3. [pmid: 6502535].
700 McKeith I, Ballard C, Perry R, Ince P, O'Brien J, Neill D, et al. Prospective validation of consensus criteria for the diagnosis of dementia with Lewy bodies. Neurology. 2000;54:1050-8. [pmid: 10720273].
701 McKelvie P A, Rode J. Autopsy rate and a clinicopathological audit in an Australian metropolitan hospital--cause for concern?. Med J Aust. 1992;156:456-62. [pmid: 1556972].
702 McKelvie PA. Medical certification of causes of death in an Australian metropolitan hospital. Comparison with autopsy findings and a critical review. Med J Aust. 1993;158:816–8, 20–1.
703 McKelvie P A. Autopsy evidence of pulmonary thromboembolism. Med J Aust. 1994;160:127-8. [pmid: 8295579].
704 McLarty D G, Unwin N, Kitange H M, Alberti K G. Diabetes mellitus as a cause of death in sub-Saharan Africa: results of a community-based study in Tanzania. The Adult Morbidity and Mortality Project. Diabet Med. 1996;13:990-4. [pmid: 8946159].
705 McLaughlin S A, Valdes M G, Jacobsen R M, Wollan P C, Beard C M, Weissman L, et al. Incidence of sudden infant death syndrome in Olmsted County, Minnesota: 1945 through 1992. Mayo Clin Proc. 1995;70:837-43. [pmid: 7643636].
706 McMahan C A. Age-sex distributions of selected groups of human autopsied cases. Arch Pathol. 1962;73:40-7.
707 McMahan C A. Autopsied cases by age, sex, and “race”. Lab Invest. 1968;18:468-78. [pmid: 5681191].
708 McManus J. The Autopsy as Research. JAMA. 1965;193:808-10. [pmid: 14329981].
709 McManus B A, Beneke J A. The autopsy in medical science and clinical practice: where have we been and where are we going?. Nebr Med J. 1986;71:184-90.
710 McManus B M, Suvalsky S D, Wilson J E. A decade of acceptable autopsy rates. Does concordance of clinician and pathologist views explain relative success?. Arch Pathol Lab Med. 1992;116:1128-36. [pmid: 1444741].
711 McManus B M. The autopsy and the public need. Can medicine respond?. Arch Pathol Lab Med. 1994;118:870-2. [pmid: 8080354].
712 McManus B M, Wood S M. The autopsy. Simple thoughts about the public needs and how to address them. Am J Clin Pathol. 1996;106:S11-4. [pmid: 8853050].
713 McNamara R M, Monti S, Kelly J J. Requesting consent for an invasive procedure in newly deceased adults. JAMA. 1995;273:310-2. [pmid: 7815659].
714 McPhee S J, Bottles K. Autopsy: moribund art or vital science?. Am J Med. 1985;78:107-13. [pmid: 3881019].
715 McPhee S J, Bottles K, Lo B, Saika G, Crommie D. To redeem them from death. Reactions of family members to autopsy. Am J Med. 1986;80:665-71. [pmid: 3963043].
716 McPhee S J. The autopsy. An antidote to misdiagnosis. Medicine (Baltimore). 1996;75:41-3. [pmcid: 126225]. [pmid: 8569469].
717 McPhee S J. Maximizing the benefits of autopsy for clinicians and families. What needs to be done. Arch Pathol Lab Med. 1996;120:743-8. [pmid: 8718899].
718 McWeeny P M, Emery J L. Unexpected postneonatal deaths (cot deaths) due to recognizable disease. Arch Dis Child. 1975;50:191-6. [pmid: 1170812].
719 Meade G M. Prevention of primary tuberculosis infections in medical students; the autopsy as a source of primary infection. Am Rev Tuberc. 1948;58:675-83. [pmid: 18099846].
720 Medalie J H, Goldbourt U. Unrecognized myocardial infarction: five-year incidence, mortality, and risk factors. Ann Intern Med. 1976;84:526-31. [pmid: 132128].
721 Meier P R, Manchester D K, Shikes R H, Clewell W H, Stewart M. Perinatal autopsy: its clinical value. Obstet Gynecol. 1986;67:349-51. [pmid: 3945446].
722 Meister S G, Brooks H L, Szucs M M, Banas J S Jr, Dexter L, Dalen J E. Pulmonary cineangiography in acute pulmonary embolism. Am Heart J. 1972;84:33-7. [pmid: 5080280].
723 Mercer J, Talbot I C. Clinical diagnosis: a post-mortem assessment of accuracy in the 1980s. Postgrad Med J. 1985;61:713-6. [pmid: 4034461].
724 Mesquita C T, Morandi Junior J L, Perrone F T, Oliveira C, Barreira L J, Nascimento S S, et al. Fatal pulmonary embolism in hospitalized patients. Clinical diagnosis versus pathological confirmation. Arq Bras Cardiol. 1999;73:251-8. [pmid: 10752164].
725 Metz E N. Are the case records obsolete?. N Engl J Med. 1980;302:22.
726 Middleton K, Clarke E, Homann S, Naughton B, Neely D, Repasy A, et al. An autopsy-based study of diagnostic errors in geriatric and nongeriatric adult patients. Arch Intern Med. 1989;149:1809-12. [pmid: 2764653].
727 Midelfart J, Aase S. The value of autopsy from a clinical point of view. A survey of 250 general practitioners and hospital clinicians in the county of Sor-Trondelag, Norway. Apmis. 1998;106:693-8. [pmid: 9740507].
728 Mikhael N Z, Kacew S. Monitoring of adverse drug reactions by means of autopsy tissue examination. Hum Toxicol. 1984;3:133-40. [pmid: 6724593].
729 Mikhael N Z, Boggs M, Kacew S, Potvin D L. Autopsy tissue examination: a novel method to estimate adverse reactions to pharmacological agents. J Environ Pathol Toxicol Oncol. 1986;6:345-50. [pmid: 3712249].
730 Mills R C. Means of securing post-mortem examinations. Bull Am Coll Surg. 1930;14:40-57.
731 Mirra S S. The CERAD neuropathology protocol and consensus recommendations for the postmortem diagnosis of Alzheimer's disease: a commentary. Neurobiol Aging. 1997;18:S91-4. [pmid: 9330994].
732 Mitchell R S, Walker S H, Silvers G W, Dart G, Maisel J C. The causes of death in chronic airway obstruction. I. The unreliability of death certificates and routine autopsies. Am Rev Respir Dis. 1968;98:601-10. [pmid: 5677146].
733 Mitchell M L. Interdepartmental quality assurance using coded autopsy results. Mod Pathol. 1993;6:48-52. [pmid: 8426856].
734 Mitchell E K, Prior J T. Where have all the autopsies gone? A proposal for a centralized autopsy service. J Community Health. 1995;20:441-6. [pmid: 8550871].
735 Mitchell E, Krous H F, Donald T, Byard R W. An analysis of the usefulness of specific stages in the pathologic investigation of sudden infant death. Am J Forensic Med Pathol. 2000;21:395-400. [pmid: 11111805].
736 Modan B, Sharon E, Jelin N. Factors contributing to the incorrect diagnosis of pulmonary embolic disease. Chest. 1972;62:388-93. [pmid: 5077995].
737 Modelmog D, Rahlenbeck S, Trichopoulos D. Accuracy of death certificates: a population-based, complete-coverage, one-year autopsy study in East Germany. Cancer Causes Control. 1992;3:541-6. [pmid: 1420857].
738 Mollo F, Bertoldo E, Grandi G, Cavallo F. Reliability of death certifications for different types of cancer. An autopsy survey. Pathol Res Pract. 1986;181:442-7. [pmid: 3763482].
739 Mollo F, Bellis D, Delsedime L, Bernardi P, Ardissone F, Piolatto G, et al. Autopsy indicators of exposure to asbestos and lung cancer. IARC Sci Publ. 1991:141–7.
740 Moore G W, Berman J J, Hanzlick R L, Buchino J J, Hutchins G M. A prototype Internet autopsy database. 1625 consecutive fetal and neonatal autopsy facesheets spanning 20 years. Arch Pathol Lab Med. 1996;120:782-5. [pmid: 8718907].
741 Moore G W, Hutchins G M. The persistent importance of autopsies. Mayo Clin Proc. 2000;75:557-8. [pmid: 10852414].
742 Morales A R, Kulesh M, Valdes-Dapena M. Maximizing the effectiveness of the autopsy in cases of sudden death. Arch Pathol Lab Med. 1984;108:460-1. [pmid: 6547296].
743 Morgello S, Cho E S, Nielsen S, Devinsky O, Petito C K. Cytomegalovirus encephalitis in patients with acquired immunodeficiency syndrome: an autopsy study of 30 cases and a review of the literature. Hum Pathol. 1987;18:289-97. [pmid: 3028930].
744 Morgenthaler T I, Ryu J H. Clinical characteristics of fatal pulmonary embolism in a referral hospital. Mayo Clin Proc. 1995;70:417-24. [pmid: 7731250].
745 Morpurgo M, Schmid C, Mandelli V. Factors influencing the clinical diagnosis of pulmonary embolism: analysis of 229 postmortem cases. Int J Cardiol. 1998;65:S79-82. [pmid: 9706833].
746 Morrell M T, Dunnill M S. The post-mortem incidence of pulmonary embolism in a hospital population. Br J Surg. 1968;55:347-52. [pmid: 5648012].
747 Morris D P, Luff D A, Hargreaves S P, Rothera M P. Bones of contention. The supply of temporal bones for dissection: the legalities, problems and solutions. J Laryngol Otol. 1998;112:1138-41. [pmid: 10209607].
748 Mort T C, Yeston N S. The relationship of pre mortem diagnoses and post mortem findings in a surgical intensive care unit. Crit Care Med. 1999;27:299-303. [pmid: 10075053].
749 Moskowitz L B, Kory P, Chan J C, Haverkos H W, Conley F K, Hensley G T. Unusual causes of death in Haitians residing in Miami. High prevalence of opportunistic infections. JAMA. 1983;250:1187-91. [pmid: 6348327].
750 Moussa M A, Shafie M Z, Khogali M M, el-Sayed A M, Sugathan T N, Cherian G, et al. Reliability of death certificate diagnoses. J Clin Epidemiol. 1990;43:1285-95. [pmid: 2254765].
751 Muckart D J, Thomson S R. Undetected injuries: a preventable cause of increased morbidity and mortality. Am J Surg. 1991;162:457-60. [pmid: 1951909].
752 Mueller R F, Sybert V P, Johnson J, Brown Z A, Chen W J. Evaluation of a protocol for post-mortem examination of stillbirths. N Engl J Med. 1983;309:586-90. [pmid: 6410235].
753 Muller H, Engelsmann F, Nair N, Robitaille Y. Psychogeriatric clinical, electro-encephalographic and autopsy findings. Neuropsychobiology. 1997;35:95-101. [pmid: 9097301].
754 Munck W. Autopsy Findings and Clinical Diagnosis. A Comparative Study of 1000 Cases. Acta Med Scand. 1952;266:775-81.
755 Muraine M, Menguy E, Martin J, Sabatier P, Watt L, Brasseur G. The interview with the donor's family before postmortem cornea procurement. Cornea. 2000;19:12-6. [pmid: 10632001].
756 Murphy M L, Thenabadu P N, Blue L R, Meade J, De Soyza N, Doherty J E, et al. Descriptive characteristics of the electrocardiogram from autopsied men free of cardiopulmonary disease--a basis for evaluating criteria for ventricular hypertrophy. Am J Cardiol. 1983;52:1275-80. [pmid: 6228133].
757 Murphy G K. Therapeutic misadventure. An 11-year study from a metropolitan coroner's office. Am J Forensic Med Pathol. 1986;7:115-9. [pmid: 3740008].
758 Murphy S T, Palmer J M, Azen S, Frank G, Michel V, Blackhall L J. Ethnicity and advance care directives. J Law Med Ethics. 1996;24:108-17. [pmid: 8945188].
759 Murray J, Kielkowski D, Reid P. Occupational disease trends in black South African gold miners. An autopsy-based study. Am J Respir Crit Care Med. 1996;153:706-10. [pmid: 8564121].
760 Nadelmann J, Frishman W H, Ooi W L, Tepper D, Greenberg S, Guzik H, et al. Prevalence, incidence and prognosis of recognized and unrecognized myocardial infarction in persons aged 75 years or older: The Bronx Aging Study. Am J Cardiol. 1990;66:533-7. [pmid: 2392974].
761 Nagy Z, Esiri M M, Hindley N J, Joachim C, Morris J H, King E M, et al. Accuracy of clinical operational diagnostic criteria for Alzheimer's disease in relation to different pathological diagnostic protocols. Dement Geriatr Cogn Disord. 1998;9:219-26. [pmid: 9681644].
762 Nakayama M, Ohkawa S, Tanno M, Yamada H, Mashima S. Myocardial viability in cases with persistent perfusion defects on the dipyridamole thallium-201 scintigram. A comparative study with autopsy findings. Jpn Heart J. 1996;37:301-16. [pmid: 8774623].
763 Nakhleh R E, Jones J, Goswitz J J, Anderson E A, Titus J. Correlation of endomyocardial biopsy findings with autopsy findings in human cardiac allografts. J Heart Lung Transplant. 1992;11:479-85. [pmid: 1610856].
764 Nakhleh R E, Baker P B, Zarbo R J. Autopsy result utilization: a College of American Pathologists Q-probes study of 256 laboratories. Arch Pathol Lab Med. 1999;123:290-5. [pmid: 10320139].
765 Nalbantoglu J, Gilfix B M, Bertrand P, Robitaille Y, Gauthier S, Rosenblatt D S, et al. Predictive value of apolipoprotein E genotyping in Alzheimer's disease: results of an autopsy series and an analysis of several combined studies. Ann Neurol. 1994;36:889-95. [pmid: 7998776].
766 Nayar R, Mannion C, Weisenberg E. American Society of Clinical Pathologists--Resident Physician Section. Results of autopsy survey (Winter 1994-1995). Am J Clin Pathol. 1996;105:144-8. [pmid: 8607436].
767 Nelkin D, Andrews L. Do the dead have interests? Policy issues for research after life. Am J Law Med. 1998;24:261-91. [pmid: 9702275].
768 Nemetz P N, Ludwig J, Kurland L T. Assessing the autopsy. Am J Pathol. 1987;128:362-79. [pmid: 3113257]. [pmcid: 1899625].
769 Nemetz P N, Beard C M, Ballard D J, Ludwig J, Tangalos E G, Kokmen E, et al. Resurrecting the autopsy: benefits and recommendations. Mayo Clin Proc. 1989;64:1065-76. [pmid: 2509828].
770 Nemetz P N, Ballard D J, Beard C M, Ludwig J, Tangalos E G, Kokmen E, et al. An anatomy of the autopsy, Olmsted County, 1935 through 1985. Mayo Clin Proc. 1989;64:1055-64. [pmid: 2811484].
771 Nemetz P N, Leibson C, Naessens J M, Beard M, Tangalos E, Kurland L T. Determinants of the autopsy decision: a statistical analysis. Am J Clin Pathol. 1997;108:175-83. [pmid: 9260758].
772 Neoral L. Forensic medicine, its tasks and duties in medical malpractice and medico-legal litigation. Med Law. 1998;17:283-6. [pmid: 9757741].
773 Nichols L, Balogh K, Silverman M. Bacterial infections in the acquired immune deficiency syndrome. Clinicopathologic correlations in a series of autopsy cases. Am J Clin Pathol. 1989;92:787-90. [pmid: 2556018].
774 Nichols L, Aronica P, Babe C. Are autopsies obsolete?. Am J Clin Pathol. 1998;110:210-8. [pmid: 9704620].
775 Nielsen G P, Bjornsson J, Jonasson J G. The accuracy of death certificates. Implications for health statistics. Virchows Arch A Pathol Anat Histopathol. 1991;419:143-6. [pmid: 1871957].
776 Nigro J F, Gresik M V, Fernbach D J. Value of the postmortem examination in a pediatric population with leukemia. J Pediatr. 1990;116:350-4. [pmid: 2308024].
777 Nimkin K, Teeger S, Wallach M T, DuVally J C, Spevak M R, Kleinman P K. Adrenal hemorrhage in abused children: imaging and postmortem findings. AJR Am J Roentgenol. 1994;162:661-3. [pmid: 8109518].
778 Nolan K A, Lino M M, Seligmann A W, Blass J P. Absence of vascular dementia in an autopsy series from a dementia clinic. J Am Geriatr Soc. 1998;46:597-604. [pmid: 9588373].
779 Nolte K B, Feddersen R M, Foucar K, Zaki S R, Koster F T, Madar D, et al. Hantavirus pulmonary syndrome in the United States: a pathological description of a disease caused by a new agent. Hum Pathol. 1995;26:110-20. [pmid: 7821907].
780 Nordrum I, Eide T J, Jorgensen L. Unexplained and explained natural deaths among persons above 1 year of age in a series of medico-legal autopsies. Forensic Sci Int. 1998;93:89-98. [pmid: 9717261].
781 Nordstrom M, Lindblad B. Autopsy-verified venous thromboembolism within a defined urban population--the city of Malmo, Sweden. APMIS. 1998;106:378-84. [pmid: 9548426].
782 Ohlsson A, Fong K, Rose T, Hannah M, Black D, Heyman Z, et al. Prenatal ultrasonic prediction of autopsy-proven pulmonary hypoplasia. Am J Perinatol. 1992;9:334-7. [pmid: 1418127].
783 O'Leary D S. Relating autopsy requirements to the contemporary accreditation process. Arch Pathol Lab Med. 1996;120:763-6. [pmid: 8718903].
784 Olsen J C, Buenefe M L, Falco W D. Death in the emergency department. Annals of Emergency Medicine. 1998;31:758-65. [pmid: 9624317].
785 Olubuyide I O. Amoebic cases at autopsy and factors that might have contributed to death at Ibadan. Cent Afr J Med. 1990;36:218-21. [pmid: 2285932].
786 Onadeko B, Ogunbiyi J, Pindiga H. The clinicopathological pattern of carcinoma of bronchus and lung in Africa: a 20-year clinical, histopathological, and autopsy study in Ibadan, Nigeria. Afr J Med Med Sci. 1997;26:31-4. [pmid: 10895225].
787 Ong A W, Cohn S M, Cohn K A, et al. Unexpected findings in trauma patients dying in the intensive care unit: results of 153 consecutive autopsies. J Am Coll Surg. 2002;194:401-406. [pmid: 11949744].
788 Onwuanyi A, Hodges D, Avancha A, Weiss L, Rabinowitz D, Shea S, et al. Hypertensive vascular disease as a cause of death in blacks versus whites: autopsy findings in 587 adults. Hypertension; 1998. p. 1070–6.
789 Ooi D S, Isotalo P A, Veinot J P. Correlation of antemortem serum creatine kinase, creatine kinase-MB, troponin I, and troponin T with cardiac pathology. Clin Chem. 2000;46:338-44. [pmid: 10702520].
790 Orlowski J P, Vinicky J K. Conflicting cultural attitudes about autopsies. J Clin Ethics. 1993;4:195-7. [pmid: 8334293].
791 Ormsby A, Kilgore S, Goldblum J, Richter J, Rice T, Gramlich T. The location and frequency of intestinal metaplasia at the esophagogastric junction in 223 consecutive autopsies: implications for patient treatment and preventive strategies in Barrett's esophagus. Mod Pathol. 2000;13:614-20. [pmid: 10874664].
792 Orsini L A. Health insurance and the autopsy. Am J Clin Pathol. 1978;69:248-9. [pmid: 626170].
793 O'sullivan J P. The coroner's necropsy in sudden death: an under-used source of epidemiological information. J Clin Pathol. 1996;49:737-40. [pmcid: 500723]. [pmid: 9038758].
794 Osuntokun B O, Ogunniyi A, Junaid T A, Lekwauwa U G. Autopsy survey for Alzheimer's disease in Nigerian Africans: a preliminary report. Afr J Med Med Sci. 1995;24:75-9. [pmid: 7495204].
795 Otero J, Fresno M F, Escudero D, Seco M, Gonzalez M, Peces R. Detection of occult disease in tissue donors by routine autopsy. Transplant International. 1998;11:152-4. [pmid: 9561683].
796 Palmberg S. Pulmonary embolism as cause of death in geriatric surgery. A retrospective study based on autopsy material. Geron. 1974:44–57.
797 Palmer H, Weston J T. Several unusual cases of child abuse. J Forensic Sci. 1976;21:851-5. [pmid: 972313].
798 Papadakis M A, Mangione C M, Lee K K, Kristof M. Treatable abdominal pathologic conditions and unsuspected malignant neoplasms at autopsy in veterans who received mechanical ventilation. JAMA. 1991;265:885-7. [pmid: 1992186].
799 Papadopoulos I N, Bukis D, Karalas E, Katsaragakis S, Stergiopoulos S, Peros G, et al. Preventable prehospital trauma deaths in a Hellenic urban health region: an audit of prehospital trauma care. J Trauma. 1996;41:864-9. [pmid: 8913218].
800 Paraskos J A, Adelstein S J, Smith R E, Rickman F D, Grossman W, Dexter L, et al. Late prognosis of acute pulmonary embolism. N Engl J Med. 1973;289:55-8. [pmid: 4710405].
801 Park S H, Shub C, Nobrega T P, Bailey K R, Seward J B. Two-dimensional echocardiographic calculation of left ventricular mass as recommended by the American Society of Echocardiography: correlation with autopsy and M-mode echocardiography. J Am Soc Echocardiogr. 1996;9:119-28. [pmid: 8849607].
802 Parker A B 3rd, Waller B F, Gering L E. Usefulness of the 12-lead electrocardiogram in detection of myocardial infarction: electrocardiographic-anatomic correlations--part I. Clin Cardiol. 1996;19:55-61. [pmid: 8903539].
803 Parrish H M, Carr C A, Silberg S L, Goldner J C. Increasing autopsy incidence of coronary heart disease in women. Arch Intern Med. 1966;118:436-45. [pmid: 5922240].
804 Passarino G, Burlo P, Ciccone G, Comino A, Cravello M, Iannicelli P, et al. Prevalence of myocarditis at autopsy in Turin, Italy. Arch Pathol Lab Med. 1997;121:619-22. [pmid: 9199630].
805 Pastores S M, Halpern N A. Autopsies in the ICU: we still need them. Critical Care Medicine. 1999;27:235-6. [pmid: 10075031].
806 Patel A G, Mould T, Webb P J. Inadequacies of hospital medical records. Ann R Coll Surg Engl. 1993;75:7-9. [pmid: 8422161].
807 Patriquin L, Khorasani R, Polak J F. Correlation of diagnostic imaging and subsequent autopsy findings in patients with pulmonary embolism. AJR Am J Roentgenol. 1998;171:347-9. [pmid: 9694449].
808 Patriquin L, Kassarjian A, Barish M, Casserley L, O'Brien M, Andry C, et al. Postmortem whole-body magnetic resonance imaging as an adjunct to autopsy: preliminary clinical experience. J Magn Reson Imaging. 2001;13:277-87. [pmid: 11169835].
809 Patterson R H, Burns W A, Jannotta F S. Complications of external cardiac resuscitation: a retrospective review and survey of the literature. Med Ann Dist Columbia. 1974;43:389-94. [pmid: 4604258].
810 Peacock S J, Machin D, Duboulay C E, Kirkham N. The autopsy: a useful tool or an old relic?. J Pathol. 1988;156:9-14. [pmid: 3193305].
811 Pearl G S, Nelson J S. Continuous quality improvement (CQI) in neuropathology. Journal of Neuropathology & Experimental Neurology. 1996;55:875-9. [pmid: 8759776].
812 Pecorella I, Ciardi A, Credendino A, Marasco A, Di T U, Scaravilli F. Ocular, cerebral and systemic interrelationships of cytomegalovirus infection in a post-mortem study of AIDS patients. Eye. 1999;13:781-5. [pmid: 10707145].
813 Pellegrino E D. The autopsy. Some ethical reflections on the obligations of pathologists, hospitals, families, and society. Arch Pathol Lab Med. 1996;120:739-42. [pmid: 8718898].
814 Penner D W. Cost effectiveness of the autopsy in maintaining and improving the standard of patient care. Am J Clin Pathol. 1978;69:250-2. [pmid: 415597].
815 Percy C, Stanek E 3rd, Gloeckler L. Accuracy of cancer death certificates and its effect on cancer mortality statistics. Am J Public Health. 1981;71:242-50. [pmid: 7468855]. [pmcid: 1619811].
816 Perez J V, Warwick D J, Case C P, Bannister G C. Death after proximal femoral fracture--an autopsy study. Injury. 1995;26:237-40. [pmid: 7649622].
817 Perkins H S. Cultural differences and ethical issues in the problem of autopsy requests. Tex Med. 1991;87:72-7.
818 Perneger T V, Klag M J, Whelton P K. Cause of death in patients with end-stage renal disease: death certificates vs registry reports. Am J Public Health. 1993;83:1735-8. [pmid: 8259805]. [pmcid: 1694925].
819 Peters M, Jancke L, Zilles K. Comparison of overall brain volume and midsagittal corpus callosum surface area as obtained from NMR scans and direct anatomical measures: a within-subject study on autopsy brains. Neuropsychologia. 2000;38:1375-81. [pmid: 10869580].
820 Petersen I S, Aru A, Skodt V, Behrendt N, Bols B, Kiss K, et al. Evaluation of pneumonia diagnosis in intensive care patients. Scand J Infect Dis. 1999;31:299-303. [pmid: 10482061].
821 Petri C N. Decrease in the frequency of autopsies in Denmark after the introduction of a new autopsy act. Qual Assur Health Care. 1993;5:315-8. [pmid: 8018889].
822 Phelps C E. The methodologic foundations of studies of the appropriateness of medical care. N Engl J Med. 1993;329:1241-5. [pmid: 8413392].
823 Phelps S E. Left coronary artery anomaly: an often unsuspected cause of sudden death in the military athlete. Mil Med. 2000;165:157-9. [pmid: 10709380].
824 Pineda L A, Hathwar V S, Grant B J. Clinical suspicion of fatal pulmonary embolism. Chest. 2001;120:791-5. [pmid: 11555511].
825 Podbregar M, Voga G, Krivec B, Skale R, Pareznik R, Gabrscek L. Should we confirm our clinical diagnostic certainty by autopsies?. Intensive Care Med. 2001;27:1750-1755. [pmid: 11810118].
826 Pohlen K, Emerson H. Errors in clinical statements of causes of death. Am J Public Health. 1943;32:251-60.
827 Pohlen K, Emerson H. Errors in clinical statements of causes of death. Second report. Am J Public Health. 1943;33:505-16.
828 Poli L, Pich A, Zanocchi M, Fonte G, Bo M, Fabris F. Autopsy and multiple pathology in the elderly. Gerontology. 1993;39:55-63. [pmid: 8440491].
829 Pollock D A, Boyle C A, Destefano F, Moyer L A, Kirk M L. Underreporting of alcohol-related mortality on death certificates of young US Army veterans. JAMA. 1987;258:345-48. [pmid: 3599327].
830 Pollock D A, O'Neil J M, Parrish R G, Combs D L, Annest J L. Temporal and geographic trends in the autopsy frequency of blunt and penetrating trauma deaths in the United States. JAMA. 1993;269:1525-31. [pmid: 8445815].
831 Pontius E E. Financing mechanisms for autopsy. Am J Clin Pathol. 1978;69:245-7. [pmid: 626169].
832 Pope J H, Aufderheide T P, Ruthazer R, Woolard R H, Feldman J A, Beshansky J R, et al. Missed diagnoses of acute cardiac ischemia in the emergency department. N Engl J Med. 2000;342:1163-70. [pmid: 10770981].
833 Poulose K P, Sahajanandan V K. The incidence and diagnosis of pulmonary embolism. J Assoc Physicians India. 1973;21:45-9. [pmid: 4792700].
834 Pounder D J, Horowitz M, Rowland R, Reid D P. The value of the autopsy in medical audit--a combined clinical and pathological assessment of 100 cases. Aust N Z J Med. 1983;13:478-82. [pmid: 6418127].
835 Powers J. Q & A. What is the estimated cost of an autopsy? CAP Today; 1994.
836 Powers J M. Practice guidelines for autopsy pathology. Autopsy procedures for brain, spinal cord, and neuromuscular system. Autopsy Committee of the College of American Pathologists. Arch Pathol Lab Med. 1995;119:777-83. [pmid: 7668934].
837 Presti B, Berthrong M, Sherwin R M. Chronic thrombosis of major pulmonary arteries. Hum Pathol. 1990;21:601-6. [pmid: 2351389].
838 Prigent F M, Steingart R M. Clinical value of electron-beam computed tomography in the diagnosis and prognosis of coronary artery disease. Current Opinion in Cardiology. 1997;12:561-5. [pmid: 9429828].
839 Proudfoot A T, Akhtar A J, Douglas A C, Horne N W. Miliary tuberculosis in adults. BMJ. 1969:p. 273-6.
840 Provencio M, Espana P, Salas C, Navarro F, Bonilla F. Hodgkin's disease: correlation between causes of death at autopsy and clinical diagnosis. Ann Oncol. 2000;11:59-64. [pmid: 10690388].
841 Prutting J. Lack of correlation between antemortem and postmortem diagnoses. N Y State J Med. 1967;67:2081-4. [pmid: 5232980].
842 Puxty J A, Horan M A, Fox R A. Necropsies in the elderly. Lancet. 1983;1:1262-4. [pmid: 6134049].
843 Quigley M A, Chandramohan D, Rodrigues L C. Diagnostic accuracy of physician review, expert algorithms and data-derived algorithms in adult verbal autopsies. Int J Epidemiol. 1999;28:1081-7. [pmid: 10661651].
844 Quint L E, Glazer G M, Orringer M B, Francis I R, Bookstein F L. Mediastinal lymph node detection and sizing at CT and autopsy. AJR Am J Roentgenol. 1986;147:469-72. [pmid: 3488647].
845 Raab S S, Thomas P A, Lenel J C, Bottles K, Fitzsimmons K M, Zaleski M S, et al. Pathology and probability. Likelihood ratios and receiver operating characteristic curves in the interpretation of bronchial brush specimens. Am J Clin Pathol. 1995;103:588-93. [pmid: 7741104].
846 Raab S S, Geisinger K R, Silverman J F, Thomas P A, Stanley M W. Interobserver variability of a Papanicolaou smear diagnosis of atypical glandular cells of undetermined significance. Am J Clin Pathol. 1998;110:653-9. [pmid: 9802352].
847 Raad II, Luna M, Khalil S A, Costerton J W, Lam C, Bodey G P. The relationship between the thrombotic and infectious complications of central venous catheters. JAMA. 1994;271:1014-6. [pmid: 8139059].
848 Raiford K, Anton-Johnson S, Haycox Z, Nolan K, Schaffer A, Caimano C, et al. CERAD part VII: accuracy of reporting dementia on death certificates of patients with Alzheimer's disease. Neurology. 1994;44:2208-9. [pmid: 7969991].
849 Rakar S, Sinagra G, Di L A, Poletti A, Bussani R, Silvestri F, et al. Epidemiology of dilated cardiomyopathy. A prospective post-mortem study of 5252 necropsies. The Heart Muscle Disease Study Group. Eur Heart J. 1997;18:117-23. [pmid: 9049523].
850 Randall B B, Fierro M F, Froede R C. Practice guideline for forensic pathology. Members of the Forensic Pathology Committee, College of American Pathologists. Arch Pathol Lab Med. 1998;122:1056-64. [pmid: 9870853].
851 Rao MG, Rangwala AF. Diagnostic yield from 231 autopsies in a community hospital. Am J Clin Pathol; 1990. p. 486–90.
852 Rao P M, Rhea J T, Novelline R A, McCabe C J, Lawrason J N, Berger D L, et al. Helical CT technique for the diagnosis of appendicitis: prospective evaluation of a focused appendix CT examination. Radiology. 1997;202:139-44. [pmid: 8988203].
853 Rao V K, Ritter J, Kollef M H. Utility of transbronchial biopsy in patients with acute respiratory failure: a postmortem study. Chest. 1998;114:549-55. [pmid: 9726744].
854 Rao P M, Rhea J T, Novelline R A, Mostafavi A A, McCabe C J. Effect of computed tomography of the appendix on treatment of patients and use of hospital resources. N Engl J Med. 1998;338:141-6. [pmid: 9428814].
855 Rao P M, Rhea J T, Rattner D W, Venus L G, Novelline R A. Introduction of appendiceal CT: impact on negative appendectomy and appendiceal perforation rates. Ann Surg. 1999;229:344-9. [pmid: 10077046]. [pmcid: 1191699].
856 Rasmussen M S, Wille-Jørgensen P, Jorgensen L N. Postoperative fatal pulmonary embolism in a general surgical department. Am J Surg. 1995;169:214-6. [pmid: 7840382].
857 Rasmusson D, Brandt J, Steele C, Hedreen J, Troncoso J, Folstein M. Accuracy of clinical diagnosis of Alzheimer disease and clinical features of patients with non-Alzheimer disease neuropathology. Alzheimer Dis Assoc Disord. 1996;10:180-8. [pmid: 8939276].
858 Ratzan R M, Schneiderman H. AIDS, autopsies, and abandonment. JAMA. 1988;260:3466-9. [pmid: 3062197].
859 Reay D T. Death in custody. Clinics in Laboratory Medicine. 1998;18:1-22. [pmid: 9523061].
860 Reed E, Zerbe C, Brawley O, Bicher A, Steinberg S. Analysis of autopsy evaluations of ovarian cancer patients treated at the National Cancer Institute, 1972-1988. Am J Clin Oncol. 2000;23:107-16. [pmid: 10776968].
861 Reichert C M, O'Leary T J, Levens D L, Simrell C R, Macher A M. Autopsy pathology in the acquired immune deficiency syndrome. Am J Pathol. 1983;112:357-82. [pmid: 6311021]. [pmcid: 1916399].
862 Reichert C M, Kelly V L. Prognosis for the autopsy. Health Affairs. 1985;4:82-92. [pmid: 3930379].
863 Reichert C M. New safety considerations for the acquired immunodeficiency syndrome autopsy. Arch Pathol Lab Med. 1992;116:1109-10. [pmid: 1444736].
864 Reid W A. Cost effectiveness of routine postmortem histology. J Clin Pathol. 1987;40:459-61. [pmcid: 1140983]. [pmid: 3108330].
865 Reid W A, Harkin P J, Jack A S. Continual audit of clinical diagnostic accuracy by computer: a study of 592 autopsy cases. J Pathol. 1987;153:99-107. [pmid: 3694326].
866 Reis M A, Costa R S, Ferraz A S. Causes of death in renal transplant recipients: a study of 102 autopsies from 1968 to 1991. J R Soc Med. 1995;88:24-7. [pmid: 7884765].
867 Reiser S J. The clinical record in medicine. Part 1: Learning from cases. Ann Intern Med. 1991;114:902-7. [pmid: 2014953].
868 Renshaw A A. A practical problem with calculating the false-negative rate of Papanicolaou smear interpretation by rescreening negative cases alone. Cancer. 1999;87:351-3. [pmid: 10603188].
869 Reynen K. Frequency of primary tumors of the heart. Am J Cardiol. 1996;77:107. [pmid: 8540447].
870 Rhatigan R M. Comparing the case materials available from a teaching hospital's autopsies in 1968 and 20 years later. Academic Medicine. 1991;66:158-61. [pmid: 1997026].
871 Riber C, Tonnesen H, Aru A, Bjerregaard B. Observer variation in the assessment of the histopathologic diagnosis of acute appendicitis. Scand J Gastroenterol. 1999;34:46-9. [pmid: 10048732].
872 Ribner H. Jewish law, social prejudice and autopsy. Bull Sch Med Maryland. 1959;44:21-5.
873 Riboli E, Stanta G, Delendi M, Gardiman D, Peruzzo P, Sasco AJ, et al. Comparison between diagnoses of cancers of the stomach, colon, rectum, gall-bladder, liver and pancreas on death certificates and at autopsy in Trieste, 1970-84. IARC Sci Publ. 1991:45–54.
874 Riedel M, Urbanova D, Ruzbarsky V, Widimsky J. Clinico--pathologic correlations in pulmonary thromboembolism. Cor Vasa. 1980;22:176-84. [pmid: 7428380].
875 Rieder H L, Kelly G D, Bloch A B, Cauthen G M, Snider D E Jr. Tuberculosis diagnosed at death in the United States. Chest. 1991;100:678-81. [pmid: 1889256].
876 Rippey J J, Chatgidakis C J. The role of the autopsy in modern medical practice. A review. S Afr Med J. 1975;49:662-4. [pmid: 1094563].
877 Ritchie A C. The autopsy. CMAJ. 1980;122:506-8. [pmid: 7370854]. [pmcid: 1801931].
878 Roberts W C. The autopsy: its decline and a suggestion for its revival. N Engl J Med. 1978;299:332-8. [pmid: 683266].
879 Roberts M E, Fody E P. The therapeutic value in the autopsy request. J Relig Health. 1986;25:161-66.
880 Roberts S B, Hill C A, Dean B, Keks N A, Opeskin K, Copolov D L. Confirmation of the diagnosis of schizophrenia after death using DSM-IV: a Victorian experience. Aust N Z J Psychiatry. 1998;32:73-6. [pmid: 9565186].
881 Roberts W C, Shirani J. Comparison of cardiac findings at necropsy in octogenarians, nonagenarians, and centenarians. Am J Cardiol. 1998;82:627-31. [pmid: 9732892].
882 Roberts I S, Gorodkin L M, Benbow E W. When should a coroner's inquest be held? The Manchester guidelines for pathologists. J Clin Pathol. 2000;53:340-3. [pmid: 10889814]. [pmcid: 1731192].
883 Robinson P J. Radiology's Achilles' heel: error and variation in the interpretation of the Rontgen image. Br J Radiol. 1997;70:1085-98. [pmid: 9536897].
884 Roeske W R, Savage R M, O'Rourke R A, Cloor C M. Myocardial infarction: how representative are autopsied subjects with this clinical entity?. Arch Pathol Lab Med. 1981;105:642-6. [pmid: 6895452].
885 Rogde S, Kerty E, Skullerud K. Significance of inflammatory changes in the brainstem in forensic autopsy cases. Forensic Sci Int. 1999;104:105-15. [pmid: 10581716].
886 Ron E, Carter R, Jablon S, Mabuchi K. Agreement between death certificate and autopsy diagnoses among atomic bomb survivors. Epidemiology. 1994;5:48-56. [pmid: 8117782].
887 Roosen J, Frans E, Wilmer A, Knockaert D C, Bobbaers H. Comparison of premortem clinical diagnoses in critically iII patients and subsequent autopsy findings. Mayo Clin Proc. 2000;75:562-7. [pmid: 10852416].
888 Ros P R, Li K C, Vo P, Baer H, Staab E V. Preautopsy magnetic resonance imaging: initial experience. Magn Reson Imaging. 1990;8:303-8. [pmid: 2366642].
889 Rosai J. The posthumous analysis (PHA). An alternative to the conventional autopsy. Am J Clin Pathol. 1996;106:S15-7. [pmid: 8853051].
890 Rosai J. Pathology: a historical opportunity. Am J Pathol. 1997;151:3-6. [pmid: 9212724]. [pmcid: 1857936].
891 Rose A G, Viviers L, Odell J A. Autopsy-determined causes of death following cardiac transplantation. A study of 81 patients and literature review. Arch Pathol Lab Med. 1992;116:1137-41. [pmid: 1444742].
892 Rosenbaum G E, Burns J, Johnson J, Mitchell C, Robinson M, Truog R D. Autopsy consent practice at US teaching hospitals: results of a national survey. Arch Intern Med. 2000;160:374-80. [pmid: 10668840].
893 Rosenblatt M B, Teng P, Kerpe S, Beck I. Prevalence of lung cancer: disparity between clinical and autopsy certification. Med Counterpoint. 1971;October:53-9.
894 Rosenman R H, Friedman M, Jenkins C D, Straus R, Wurm M, Kositchek R. Clinically unrecognized myocardial infarction in the Western Collaborative Group Study. Am J Cardiol. 1967;19:776-82. [pmid: 6026145].
895 Rosman H S, Patel S, Borzak S, Paone G, Retter K. Quality of history taking in patients with aortic dissection. Chest. 1998;114:793-5. [pmid: 9743168].
896 Rossetti F, Brawner D L, Bowden R, Meyer W G, Schoch H G, Fisher L, et al. Fungal liver infection in marrow transplant recipients: prevalence at autopsy, predisposing factors, and clinical features. Clin Infect Dis. 1995;20:801-11. [pmid: 7795077].
897 Rossi S, Reale D, Grandi E. Correlation of clinical diagnosis with autopsy findings. IARC Sci Publ. 1991:99–108.
898 Rossman I. True incidence of pulmonary embolization and vital statistics. JAMA. 1974;230:1677-9. [pmid: 4479867].
899 Rossman I, Rodstein M, Bornstein A. Undiagnosed diseases in an aging population. Pulmonary embolism and bronchopneumonia. Arch Intern Med. 1974;133:366-9. [pmid: 4283736].
900 Rubenstone A I, et al. Autopsies in hospitals of the Chicago area. Proc Inst Med Chgo. 1981;34:21-3.
901 Rubino GF, Scansetti G, Pira E, Piolatto G, Mollo F, Andrion A, et al. Pleural plaques and lung asbestos bodies in the general population: an autoptical and clinical-radiological survey. IARC Sci Publ. 1980:545–51.
902 Rubinstein I, Murray D, Hoffstein V. Fatal pulmonary emboli in hospitalized patients. An autopsy study. Arch Intern Med. 1988;148:1425-6. [pmid: 3377625].
903 Ruggeri R, Longoni P, Lucchelli P D. Autopsy and image technics. Has the utilization of image modern technics rendered the autopsy very obsolete? The view of the clinicians. Recenti Progressi in Medicina. 1985;76:332-3. [pmid: 4059629].
904 Ruiz G A, Martin H L, Roldan C R. Hepatic tumors in patients with cirrhosis: an autopsy study. Rev Esp Enferm Dig. 1997;89:771-80. [pmid: 9401434].
905 Rushton D I. Prognostic role of the perinatal postmortem. Br J Hosp Med. 1994;52:450-4. [pmid: 7874359].
906 Rushton D I. Should perinatal post mortems be carried out by specialist pathologists?. Br J Obstet Gynaecol. 1995;102:182-5. [pmid: 7794840].
907 Russell R P, Masi A T. The prevalence of adrenal cortical hyperplasia at autopsy and its association with hypertension. Ann Intern Med. 1970;73:195-205. [pmid: 5454256].
908 Rutty G N, Duerden R M, Carter N, Clark J C. Are coroners' necropsies necessary? A prospective study examining whether a “view and grant” system of death certification could be introduced into England and Wales. J Clin Pathol. 2001;54:279-84. [pmid: 11304844]. [pmcid: 1731404].
909 Ryu J H, Olson E J, Pellikka P A. Clinical recognition of pulmonary embolism: problem of unrecognized and asymptomatic cases. Mayo Clin Proc. 1998;73:873-9. [pmid: 9737225].
910 Saber R S, Edwards W D, Bailey K R, McGovern T W, Schwartz R S, Holmes D R Jr. Coronary embolization after balloon angioplasty or thrombolytic therapy: an autopsy study of 32 cases. J Am Coll Cardiol. 1993;22:1283-8. [pmid: 8227781].
911 Saccani G Jotti. The ultimate consultation in modern oncology. Ann Oncol. 1990;1:171–4. Published erratum appears in Ann Oncol. 1990;1(4):305.
912 Sackett D L. Possible risk factors in the development of venous thrombosis. Gastrointestinal disease, infection and dehydration. Milbank Mem Fund Q. 1972;50(Suppl 2):105-22. [pmid: 4555348].
913 Sadler D. The value of a thorough protocol in the investigation of sudden infant deaths. J Clin Pathol. 1998;51:689-94. [pmcid: 500908]. [pmid: 9930075].
914 Saeger W, Genzkow M. Venous thromboses and pulmonary embolisms in post-mortem series: probable causes by correlations of clinical data and basic diseases. Pathol Res Pract. 1994;190:394-9. [pmid: 8078809].
915 Saito K, Thurlbeck W M. Measurement of emphysema in autopsy lungs, with emphasis on interlobar differences. Am J Respir Crit Care Med. 1995;151:1373-6. [pmid: 7735587].
916 Sakr W A, Grignon D J, Crissman J D, Heilbrun L K, Cassin B J, Pontes J J, et al. High grade prostatic intraepithelial neoplasia (HGPIN) and prostatic adenocarcinoma between the ages of 20–69: an autopsy study of 249 cases. In Vivo. 1994;8:439-43. [pmid: 7803731].
917 Salako B L, Kadiri S, Akinkugbe O O. The diagnostic accuracy of resident doctors in the Department of Medicine University College Hospital, Ibadan. West Afr J Med. 1994;13:179-80. [pmid: 7841111].
918 Salib E. Autopsy in geriatric psychiatry. Int J Geriatr Psychiatry. 1998;13:747-8. [pmid: 9850870].
919 Salib E, Tadros G, Ambrose A. Autopsy in elderly psychiatric inpatients: a retrospective review of autopsy findings of deceased elderly psychiatric inpatients in north Cheshire 1980-1996. Med Sci Law. 2000;40:20-7. [pmid: 10689857].
920 Saller D N Jr, Lesser K B, Harrel U, Rogers B B, Oyer C E. The clinical utility of the perinatal autopsy. JAMA. 1995;273:663-5. [pmid: 7844878].
921 Samphier M L, Robertson C, Bloor M J. A possible artefactual component in specific cause mortality gradients. Social class variations in the clinical accuracy of death certificates. J Epidemiol Community Health. 1988;42:138-43. [pmid: 3221162].
922 Sampson R J, Key C R, Buncher C R, Iijima S. Thyroid carcinoma in Hiroshima and Nagasaki. I. Prevalence of thyroid carcinoma at autopsy. JAMA. 1969;209:65-70. [pmid: 5819259].
923 Sandler D A, Martin J F. Autopsy proven pulmonary embolism in hospital patients: are we detecting enough deep vein thrombosis?. J R Soc Med. 1989;82:203-5. [pmid: 2716016]. [pmcid: 1292084].
924 Sandritter W, Staeudinger M, Drexler H. Autopsy and clinical diagnosis. Pathol Res Pract. 1980;168:107-14. [pmid: 7433249].
925 Sanner M. A comparison of public attitudes toward autopsy, organ donation, and anatomic dissection. A Swedish survey. JAMA. 1994;271:284-8. [pmid: 8295287].
926 Sanner M. Attitudes toward organ donation and transplantation. A model for understanding reactions to medical procedures after death. Social Science & Medicine. 1994;38:1141-52. [pmid: 8042059].
927 Sanner M A. In perspective of the declining autopsy rate. Attitudes of the public. Arch Pathol Lab Med. 1994;118:878-83. [pmid: 8080356].
928 Sanner M A. Medical students' attitudes toward autopsy. How does experience with autopsies influence opinion?. Arch Pathol Lab Med. 1995;119:851-8. [pmid: 7668947].
929 Santosh C G, Bell J E, Best J J. Spinal tract pathology in AIDS: postmortem MRI correlation with neuropathology. Neuroradiology. 1995;37:134-8. [pmid: 7761000].
930 Saracci R. Is necropsy a valid monitor of clinical diagnosis performance?. BMJ. 1991;303:898-900. [pmid: 1933005]. [pmcid: 1671185].
931 Saracci R. Autopsy as the yardstick for diagnosis: an epidemiologist's remarks. IARC Sci Publ; 1991. p. 185–96.
932 Saracci R. Problems with the use of autopsy results as a yardstick in medical audit and epidemiology. Qual Assur Health Care. 1993;5:339-44. [pmid: 8018893].
933 Sarfati MR, Hunter GC, Witzke DB, Bebb GG, Smythe SH, Boyan S, et al. Impact of adjunctive testing on the diagnosis and clinical course of patients with acute appendicitis. Am J Surg. 1993;166:660–4; discussion 64–5.
934 Sarma D P. Unsuspected malignant tumors. J La State Med Soc. 1981;133:105-6. [pmid: 6268722].
935 Sarode V R, Datta B N, Banerjee A K, Banerjee C K, Joshi K, Bhusnurmath B, et al. Autopsy findings and clinical diagnoses: a review of 1,000 cases. Hum Pathol. 1993;24:194-8. [pmid: 8432514].
936 Savage R M, Wagner G S, Ideker R E, Podolsky S A, Hackel D B. Correlation of postmortem anatomic findings with electrocardiographic changes in patients with myocardial infarction: retrospective study of patients with typical anterior and posterior infarcts. Circulation. 1977;55:279-85. [pmid: 832343].
937 Sawaguchi T, Fujita T, Sawaguchi A, Nishida H. The epidemiological study on registered cases of sudden infant death syndrome (SIDS) in Tokyo: examination of the effect of autopsy on diagnosis of SIDS and the mortality statistics in Japan. Forensic Sci Int. 2000;109:65-74. [pmid: 10759072].
938 Schiff G. Cascade or facade: focusing or obfuscating the pathogenesis of iatrogenesis?. QRB Qual Rev Bull. 1993;19:196-8. [pmid: 8378074].
939 Schlemper R J, Itabashi M, Kato Y, Lewin K J, Riddell R H, Shimoda T, et al. Differences in diagnostic criteria for gastric carcinoma between Japanese and western pathologists. Lancet. 1997;349:1725-9. [pmid: 9193382].
940 Schmidt S. Consent for autopsies. JAMA. 1983;250:1161-4. [pmid: 6876352].
941 Schned A R, Mogielnicki R P, Stauffer M E. A comprehensive quality assessment program on the autopsy service. Am J Clin Pathol. 1986;86:133-8. [pmid: 3739967].
942 Schneider B, Zienkiewicz T, Jansen V, Hofmann T, Noltenius H, Meinertz T. Diagnosis of patent foramen ovale by transesophageal echocardiography and correlation with autopsy findings. Am J Cardiol. 1996;77:1202-9. [pmid: 8651096].
943 Schneiderman H, Gruhn J. How--and why--to request an autopsy. Postgraduate Medicine. 1985;77:153-6, 60-4. [pmid: 3975184].
944 Schoen F J, Titus J L, Lawrie G M. Autopsy-determined causes of death after cardiac valve replacement. JAMA. 1983;249:899-902. [pmid: 6823042].
945 Schor S, Behar S, Modan B, Barell V, Drory J, Kariv I. Disposition of presumed coronary patients from an emergency room. A follow-up study. JAMA. 1976;236:941-3. [pmid: 988893].
946 Schottenfeld D, Eaton M, Sommers S C, Alonso D R, Wilkinson C. The autopsy as a measure of accuracy of the death certificate. Bull N Y Acad Med. 1982;58:778-94. [pmid: 6963186].
947 Schroder H M, Andreassen M. Autopsy-verified major pulmonary embolism after hip fracture. Clin Orthop. 1993;293:196-203. [pmid: 8339481].
948 Schulte-Altedorneburg G, Droste D, Kollar J, Hegedus C, Gomba S, Ringelstein E, et al. A Novel Method of Macropathologic and Arteriographic Examination of Carotid Specimens Obtained from Autopsy. Cardiovasc Intervent Radiol. 2000;23:312-14. [pmid: 10960549].
949 Schwarcz S K, Shefer A M, Zaki S R. Retrospective diagnosis of a fatal case of the hantavirus pulmonary syndrome, 1980. West J Med. 1996;164:348-50. [pmid: 8732742]. [pmcid: 1303518].
950 Schwartz J N, Kong Y, Hackel D B, Bartel A G. Comparison of angiographic and postmortem findings in patients with coronary artery disease. Am J Cardiol. 1975;36:174-8. [pmid: 1155338].
951 Schwartz D A, Herman C J. The importance of the autopsy in emerging and reemerging infectious diseases. Clin Infect Dis. 1996;23:248-54. [pmid: 8842258].
952 Schwechheimer K, Hashemian A. Neuropathologic findings after organ transplantation. An autopsy study. Gen Diagn Pathol. 1995;141:35-9. [pmid: 8542505].
953 Scottolini A G, Weinstein S R. The autopsy in clinical quality control. JAMA. 1983;250:1192-4. [pmid: 6876358].
954 Scuderi M G, Mayor M B. The value of postmortem retrievals in the analysis of long-term, well-functioning cemented femoral stems. Am J Orthop. 1997;26:826-36. [pmid: 9413586].
945 Sears M R, Rea H H, de Boer G, Beaglehole R, Gillies A J, Holst P E, et al. Accuracy of certification of deaths due to asthma. A national study. Am J Epidemiol. 1986;124:1004-11. [pmid: 3776966].
956 Seckinger D. Our two-day exploration of the autopsy. Arch Pathol Lab Med. 1996;120:719.
957 Segerberg-Konttinen M. Determination of cause and mode of death before and after medicolegal autopsy: a comparative study. J Forensic Sci. 1988;33:441-7. [pmid: 3373160].
958 Sehonanda A, Choi Y J, Blum S. Changing patterns of autopsy findings among persons with acquired immunodeficiency syndrome in an inner-city population. A 12-year retrospective study. Arch Pathol Lab Med. 1996;120:459-64. [pmid: 8639049].
959 Selikoff I J. Use of death certificates in epidemiological studies, including occupational hazards: discordance with clinical and autopsy findings. Am J Ind Med. 1992;22:469-80. [pmid: 1442782].
960 Setlow V P. The need for a national autopsy policy. Arch Pathol Lab Med. 1996;120:773-7. [pmid: 8718906].
961 Seymour K, Charnley R M. Evidence that metastasis is less common in cirrhotic than normal liver: a systematic review of post-mortem case-control studies. Br J Surg. 1999;86:1237-42. [pmid: 10540123].
962 Shanks JH, Anderson NH, McCluggage G, Toner PG. Use of the autopsy in Northern Ireland and its value in perioperative deaths. IARC Sci Publ. 1991:115–24.
963 Shapiro E D, Davis A. Law and pathology through the ages. The coroner and his descendants--legitimate and illegitimate. NY State J Med. 1972;72:805-9.
964 Shapiro M J. Reimbursement for autopsies. A personal view. Arch Pathol Lab Med. 1984;108:473-4. [pmid: 6428376].
965 Sharif D S, Huhta J C, Marantz P, Hawkins H K, Yoon G Y. Two-dimensional echocardiographic determination of ventricular septal defect size: correlation with autopsy. Am Heart J. 1989;117:1333-6. [pmid: 2729060].
966 Sheifer S E, Gersh B J, Yanez N D 3rd, Ades P A, Burke G L, Manolio T A. Prevalence, predisposing factors, and prognosis of clinically unrecognized myocardial infarction in the elderly. J Am Coll Cardiol. 2000;35:119-26. [pmid: 10636269].
967 Sheikh A. Death and dying--a Muslim perspective. J R Soc Med. 1998;91:138-40. [pmid: 9659326]. [pmcid: 1296563].
968 Shen-Schwarz S, Neish C, Hill L M. Antenatal ultrasound for fetal anomalies: importance of perinatal autopsy. Pediatr Pathol. 1989;9:1-9. [pmid: 2654900].
969 Sherwood S J, Start R D. Asking relatives for permission for a post mortem examination. Postgrad Med J. 1995;71:269-72. [pmid: 7596929].
970 Sherwood S J, Start R D, Birdi K S, Cotton D W, Bunce D. How do clinicians learn to request permission for autopsies?. Med Educ. 1995;29:231-4. [pmid: 7623718].
971 Shetty S V. Post operative pulmonary embolism. J Postgrad Med. 1972;18:132-40. [pmid: 4665173].
972 Shojania K G, Showstack J, Wachter R M. Assessing hospital quality: a review for clinicians. Eff Clin Pract. 2001;4:82-90. [pmid: 11329991].
973 Shojania K G, Bero L. Taking advantage of the explosion of systematic reviews: an efficient MEDLINE search strategy. Eff Clin Pract. 2001;4:157-62. [pmid: 11525102].
974 Shope J T, Holmes S B, Hogan J, Tang G, Izenson S, Gilman S, et al. Pathologists' participation in postmortem examinations for patients with dementia. Gerontologist. 1993;33:461-7. [pmid: 8375674].
975 Sibai A M, Fletcher A, Hills M, Campbell O. Non-communicable disease mortality rates using the verbal autopsy in a cohort of middle aged and older populations in Beirut during wartime, 1983-93. J Epidemiol Community Health. 2001;55:271-6. [pmid: 11238583].
976 Siddons H. Deaths in long-term paced patients. Br Heart J. 1974;36:1201-9. [pmid: 4441451]. [pmcid: 458943].
977 Sidorov J. An attempt to motivate internal medicine housestaff to obtain consent for autopsies. Academic Medicine. 1990;65:647-9. [pmid: 2261043].
978 Siegle R L, Baram E M, Reuter S R, Clarke E A, Lancaster J L, McMahan C A. Rates of disagreement in imaging interpretation in a group of community hospitals. Acad Radiol. 1998;5:148-54. [pmid: 9522880].
979 Sigurdsson E, Thorgeirsson G, Sigvaldason H, Sigfusson N. Unrecognized myocardial infarction: epidemiology, clinical characteristics, and the prognostic role of angina pectoris. The Reykjavik Study. Ann Intern Med. 1995;122:96-102. [pmid: 7993002].
980 Silverberg S G. The autopsy and cancer. Arch Pathol Lab Med. 1984;108:476-8. [pmid: 6547298].
981 Simonneau G, Sors H, Charbonnier B, Page Y, Laaban J P, Azarian R, et al. A comparison of low-molecular-weight heparin with unfractionated heparin for acute pulmonary embolism. The THESEE Study Group. Tinzaparine ou Heparine Standard: Evaluations dans l'Embolie Pulmonaire. N Engl J Med. 1997;337:663-9. [pmid: 9278462].
982 Simonovis NJ, Wells CK, Feinstein AR. In-vivo and post-mortem gallstones: support for validity of the “epidemiologic necropsy” screening technique. Am J Epidemiol; 1991. p. 922–31.
983 Sinard J H. Factors affecting autopsy rates, autopsy request rates, and autopsy findings at a large academic medical center. Exp Mol Pathol. 2001;70:333-43. [pmid: 11418012].
984 Singer M M, Wright F, Stanley L K, Roe B B, Hamilton W K. Oxygen toxicity in man. A prospective study in patients after open-heart surgery. N Engl J Med. 1970;283:1473-8. [pmid: 4921728].
985 Sirkia K, Saarinen-Pihkala U, Hovi L, Sariola H. Autopsy in children with cancer who die while in terminal care. Med Pediatr Oncol. 1998;30:284-9. [pmid: 9544224].
986 Sivit C J, Dudgeon D L, Applegate K E, Borisa V J, Berlin S C, Morrison S C, et al. Evaluation of suspected appendicitis in children and young adults: helical CT. Radiology. 2000;216:430-3. [pmid: 10924565].
987 Slater E E, DeSanctis R W. The clinical recognition of dissecting aortic aneurysm. Am J Med. 1976;60:625-33. [pmid: 1020750].
988 Smallwood R. The dead do tell tales. Med J Aust. 1994;160:389-90. [pmid: 8007856].
989 Smirniotopoulos J G, Koeller K K, Nelson A M, Murphy F M. Neuroimaging--autopsy correlations in AIDS. Neuroimaging Clinics of North America. 1997;7:615-37. [pmid: 9376971].
990 Smith L S. Iatrogenesis--a medico-legal problem?. S Afr Med J. 1973;47:2194-6. [pmid: 4758249].
991 Smith J H. Thoughts on the destiny of the autopsy in American medicine. Texas Med. 1980;76:56-7.
992 Smith R D, Zumwalt R E. One department's experience with increasing the autopsy rate. Arch Pathol Lab Med. 1984;108:455-7. [pmid: 6547295].
993 Smith DA. Autopsy. Pennsylvania Medicine. 1988;91.
994 Smith C J, Scott S M, Wagner B M. The necessary role of the autopsy in cardiovascular epidemiology. Hum Pathol. 1998;29:1469-79. [pmid: 9865835].
995 Smith A E, Hutchins G M, Hanzlick R. Case of the month: making amends. Autopsy Committee of the College of American Pathologists. Arch Intern Med. 1998;158:1739-40. [pmid: 9738602].
996 Solberg LA, Strong JP. Risk factors and atherosclerotic lesions: a review of autopsy studies. Arteriosclerosis. 1983;3.
997 Solomon S A, Adams K H. Attitudes of relatives to autopsies of elderly patients. Age and Ageing. 1993;22:205-8. [pmid: 8503317].
998 Sonderegger-Iseli K, Burger S, Muntwyler J, Salomon F. Diagnostic errors in three medical eras: a necropsy study. Lancet. 2000;355:2027-31. [pmid: 10885353].
999 Sons H U, Borchard F, Joel B S. Carcinoma of the gallbladder: autopsy findings in 287 cases and review of the literature. J Surg Oncol. 1985;28:199-206. [pmid: 3974247].
1000 Sorlie P D, Garcia-Palmieri M R, Castillo-Staab M I, Costas R Jr, Oalmann M C, Havlik R. The relation of antemortem factors to atherosclerosis at autopsy. The Puerto Rico Heart Health Program. Am J Pathol. 1981;103:345-52. [pmid: 7234969]. [pmcid: 1903849].
1001 Sorokin Y, Johnson M P, Uhlmann W R, Zador I E, Drugan A, Koppitch F Cd, et al. Postmortem chorionic villus sampling: correlation of cytogenetic and ultrasound findings. Am J Med Genet. 1991;39:314-6. [pmid: 1867283].
1002 Souder E, Trojanowski J Q. Autopsy: cutting away the myths. J Neurosci Nurs. 1992;24:134-9. [pmid: 1645035].
1003 Souza V L, Rosner F. Increasing autopsy rates at a public hospital. J Gen Intern Med. 1997;12:315-7. [pmid: 9159702]. [pmcid: 1497112].
1004 Spain D M, Bradess V A, Mohr C. Coronary atherosclerosis as a cause of unexpected and unexplained death: an autopsy study from 1949-59. JAMA. 1960;174:384-8. [pmid: 13833138].
1005 Sperry K L, Key C R, Anderson R E. Toward a population-based assessment of death due to pulmonary embolism in New Mexico. Hum Pathol. 1990;21:159-65. [pmid: 2307443].
1006 Spittell P C, Spittell J A Jr, Joyce J W, Tajik A J, Edwards W D, Schaff H V, et al. Clinical features and differential diagnosis of aortic dissection: experience with 236 cases (1980 through 1990). Mayo Clin Proc. 1993;68:642-51. [pmid: 8350637].
1007 Stambouly J J, Kahn E, Boxer R A. Correlation between clinical diagnoses and autopsy findings in critically ill children. Pediatrics. 1993;92:248-51. [pmid: 8337024].
1008 Stamler J. Opportunities and pitfalls in international comparisons related to patterns, trends and determinants of CHD mortality. Int J Epidemiol. 1989;18:S3-18. [pmid: 2681022].
1009 Stanta G, Campagner L, Cavallieri F, Giarelli L. Cancer of the oldest old. What we have learned from autopsy studies. Clin Geriatr Med. 1997;13:55-68. [pmid: 8995100].
1010 Start R D, Hector-Taylor M J, Cotton D W, Startup M, Parsons M A, Kennedy A. Factors which influence necropsy requests: a psychological approach. J Clin Pathol. 1992;45:254-7. [pmcid: 495490]. [pmid: 1556237].
1011 Start R D, Cotton D W. The meta-autopsy: changing techniques and attitudes towards the autopsy. Qual Assur Health Care. 1993;5:325-32. [pmid: 8018891].
1012 Start R D, McCulloch T A, Silcocks P B, Cotton W K. Attitudes of senior pathologists towards the autopsy. J Pathol. 1994;172:81-4. [pmid: 7931830].
1013 Start R D, Firth J A, Macgillivray F, Cross S S. Have declining clinical necropsy rates reduced the contribution of necropsy to medical research?. J Clin Pathol. 1995;48:402-4. [pmcid: 502611]. [pmid: 7629282].
1014 Start R D. The autopsy. J Pathol. 1995;175:453-60. [pmid: 7790998].
1015 Start R D. Critical Summaries: The Autopsy. J Pathol. 1995;175:453-60. [pmid: 7790998].
1016 Start R D, Saul C A, Cotton D W, Mathers N J, Underwood J C. Public perceptions of necropsy. J Clin Pathol. 1995;48:497-500. [pmcid: 502676]. [pmid: 7665690].
1017 Start R D. Underwood JC. Funding the clinical autopsy. J Pathol. 1995;177:5-9. [pmid: 7472780].
1018 Start R D, Sherwood S J. Attitudes of junior medical staff to requesting permission for autopsy. Postgrad Med J. 1995;71:60. [pmid: 7708602].
1019 Start R D, Brain S G, McCulloch T A, Angel C A. Analysis of necropsy request behaviour of clinicians. J Clin Pathol. 1996;49:29-33. [pmcid: 1023153]. [pmid: 8666681].
1020 Start R D, Sherwood S J, Kent G, Angel C A. Audit study of next of kin's satisfaction with clinical necropsy service. BMJ. 1996;312:1516. [pmid: 8646145].
1021 Start R, Dube A, Cross S, Underwood J. Does funeral preference influence clinical necropsy request outcome?. Med Sci Law. 1997;37:337-40. [pmid: 9383943].
1022 Stauffer J L, Olson D E, Petty T L. Complications and consequences of endotracheal intubation and tracheotomy. A prospective study of 150 critically ill adult patients. Am J Med. 1981;70:65-76. [pmid: 7457492].
1023 Steer A, Land C E, Moriyama I M, et al. Accuracy of diagnosis of cancer among autopsy cases: JNIH-ABCC population of Hiroshima and Nagasaki. Gann. 1976;67:625-32. [pmid: 1017579].
1024 Stefenelli N, Kugi A, Wintersperger U, Prokop E, Steininger P, Walch E. Effects of confrontation of medical students and hospital physicians with human cadavers. Pathologe. 1993;14:341-5. [pmid: 8121887].
1025 Stehbens W E. Autopsy rates in Australian hospitals and appraisal of the post-mortem examination. Med J Aust. 1974;1:479-88. [pmid: 4598388].
1026 Stehbens W E. Review of the validity of national coronary heart disease mortality rates. Angiology. 1990;41:85-94. [pmid: 2407158].
1027 Stein P D, Henry J W. Prevalence of acute pulmonary embolism among patients in a general hospital and at autopsy. Chest. 1995;108:978-81. [pmid: 7555172].
1028 Stein P D. Diagnosis of pulmonary embolism. Curr Opin Pulm Med. 1996;2:295-9. [pmid: 9363155].
1029 Steinberg A D. Myxedema and coronary artery disease--a comparative autopsy study. Ann Intern Med. 1968;68:338-44. [pmid: 5713917].
1030 Stemmermann G N. Unsuspected cancer in elderly Hawaiian Japanese: an autopsy study. Human Pathology. 1982;13:1039-44. [pmid: 7152508].
1031 Stemmermann G N, Nomura A M, Chyou P H, Yatani R. A prospective comparison of prostate cancer at autopsy and as a clinical event: the Hawaii Japanese experience. Cancer Epidemiol Biomarkers Prev. 1992;1:189-93. [pmid: 1306104].
1032 Stenback F, Paivarinta H. Relation between clinical and autopsy diagnoses, especially as regards cancer. Scand J Soc Med. 1980;8:67-72. [pmid: 7209450].
1033 Stenbygaard L E, Sorensen J B, Olsen J E. Metastatic pattern at autopsy in non-resectable adenocarcinoma of the lung--a study from a cohort of 259 consecutive patients treated with chemotherapy. Acta Oncologica. 1997;36:301-6. [pmid: 9208901].
1034 Sternby N H. The role of autopsy in cancer registration in Sweden, with special reference to findings in Malmo. Quality Assurance in Health Care. 1993;5:291-4. [pmid: 8018884].
1035 Stevanovic G, Tucakovic G, Dotlic R, Kanjuh V. Correlation of clinical diagnoses with autopsy findings: a retrospective study of 2,145 consecutive autopsies. Hum Pathol. 1986;17:1225-30. [pmid: 3793085].
1036 Stoler M H, Schiffman M. Interobserver reproducibility of cervical cytologic and histologic interpretations: realistic estimates from the ASCUS-LSIL Triage Study. JAMA. 2001;285:1500-5. [pmid: 11255427].
1037 Stolman C J, Castello F, Yorio M, Mautone S. Attitudes of pediatricians and pediatric residents toward obtaining permission for autopsy. Arch Pediatr Adolesc Med. 1994;148:843-7. [pmid: 8044262].
1038 Stolman C J, Castello F, Holland B K, DiCarlo F, Sun S, Von Hagen S, et al. Lessons learned from autopsies at a pediatric teaching hospital. N J Med. 1995;92:794-7. [pmid: 8545068].
1039 Stothert JC, Jr., Gbaanador GB, Herndon DN. The role of autopsy in death resulting from trauma. J Trauma. 1990;30:1021–5; discussion 25–6.
1040 Stothert J C Jr, Gbaanador G. Autopsy in general surgery practice. Am J Surg. 1991;162:585-8. [pmid: 1670230].
1041 Streat S J, Civil I D. Injury scaling at autopsy: the comparison with premortem clinical data. Accid Anal Prev. 1990;22:241-52. [pmid: 2393472].
1042 Stubbs F, Start R D, Hector-Taylor M J, Cotton D W. The attitudes of junior pathologists towards the autopsy. J Pathol. 1992;166:413-5. [pmid: 1517896].
1043 Sturner W Q. Common errors in forensic pediatric pathology. Am J Forensic Med Pathol. 1998;19:317-20. [pmid: 9885923].
1044 Styrud J, Eriksson S, Segelman J, Granstrom L. Diagnostic accuracy in 2,351 patients undergoing appendicectomy for suspected acute appendicitis: A retrospective study 1986-1993. Dig Surg. 1999;16:39-44. [pmid: 9949266].
1045 Styrud J, Josephson T, Eriksson S. Reducing negative appendectomy: evaluation of ultrasonography and computer tomography in acute appendicitis. Int J Qual Health Care. 2000;12:65-8. [pmid: 10733085].
1046 Suen K C, Lau L L, Yermakov V. Cancer and old age. An autopsy study of 3,535 patients over 65 years old. Cancer. 1974;33:1164-8. [pmid: 4819217].
1047 Sullivan P R, Wolfson A B, Leckey R D, Burke J L. Diagnosis of acute thoracic aortic dissection in the emergency department. Am J Emerg Med. 2000;18:46-50. [pmid: 10674531].
1048 Sulmasy D P, Dwyer M, Marx E. Do the ward notes reflect the quality of end-of-life care?. J Med Ethics. 1996;22:344-8. [pmid: 8961119].
1049 Suprun H, Rywlin A M. Metastatic carcinoma in histologic sections of aspirated bone marrow: a comparative autopsy study. South Med J. 1976;69:438-9. [pmid: 1265504].
1050 Suvarna S K, Start R D. Cytodiagnosis and the necropsy. J Clin Pathol. 1995;48:443-6. [pmcid: 502621]. [pmid: 7629291].
1051 Svendsen E, Hill R B. Autopsy legislation and practice in various countries. Arch Pathol Lab Med. 1987;111:846-50. [pmid: 3632302].
1052 Svendsen E, Karwinski B. Prevalence of pulmonary embolism at necropsy in patients with cancer. J Clin Pathol. 1989;42:805-9. [pmcid: 1142055]. [pmid: 2475526].
1053 Svendsen E, Karwinski B, Aardal N P. Frequency of pulmonary embolism in patients with circulatory disturbances of the lower limb or intestine. An autopsy study. Pathol Res Pract. 1991;187:267-70. [pmid: 2068010].
1054 Svenes K B, Borgersen A, Haaversen O, Holten K. Parietal pleural plaques: a comparison between autopsy and X-ray findings. Eur J Respir Dis. 1986;69:10-5. [pmid: 3743683].
1055 Sweeney J F, Rosemurgy A S, Gill S, Albrink M H. Is the cervical spine clear? Undetected cervical fractures diagnosed only at autopsy. Ann Emerg Med. 1992;21:1288-90. [pmid: 1416317].
1056 Swerdlow M A. The autopsy. Proceedings of the Institute of Medicine of Chicago. 1982;35:10-3. [pmid: 7079263].
1057 Szende B, Kendrey G, Lapis K, Lee P N, Roe F J. Accuracy of admission and pre-autopsy clinical diagnoses in the light of autopsy findings: a study conducted in Budapest. Hum Exp Toxicol. 1994;13:671-80. [pmid: 7826684].
1058 Szende B, Kendrey G, Lapis K, Roe F J, Lee P N. Accuracy of admission and clinical diagnosis of tumours as revealed by 2000 autopsies. Eur J Cancer. 1996;32A:1102-8. [pmid: 8758238].
1059 Tai D Y, El-Bilbeisi H, Tewari S, Mascha E J, Wiedemann H P, Arroliga A C. A study of consecutive autopsies in a medical ICU : a comparison of clinical cause of death and autopsy diagnosis. Chest. 2001;119:530-6. [pmid: 11171734].
1060 Tapson V F, Carroll B A, Davidson B L, Elliott C G, Fedullo P F, Hales C A, et al. The diagnostic approach to acute venous thromboembolism. Clinical practice guideline. American Thoracic Society. Am J Respir Crit Care Med. 1999;160:1043-66. [pmid: 10471639].
1061 Tasdelen E, Aksoy F, Arvas A, Berk Y, Ataoglu N, Dervisoglu S, et al. Causes of fetal and neonatal death. Turk J Pediatr. 1995;37:201-7. [pmid: 7502356].
1062 Taubman L B, Silverstone F A. Autopsy proven pulmonary embolism among the institutionalized elderly. J Am Geriatr Soc. 1986;34:752-6. [pmid: 3760437].
1063 Tazelaar H D, Schneiderman H, Yaremko L, Weinstein R S. Medical students' attitudes toward the autopsy as an educational tool. J Med Educ. 1987;62:66-8. [pmid: 3795247].
1064 Tedeschi C G. The pathology of Bonet and Morgagni. A historical introduction to the autopsy. Hum Pathol. 1974;5:601-3. [pmid: 4605310].
1065 Templeton G L, Illing L A, Young L, Cave D, Stead W W, Bates J H. The risk for transmission of Mycobacterium tuberculosis at the bedside and during autopsy. Ann Intern Med. 1995;122:922-5. [pmid: 7755227].
1066 Teo C E. A study of coroner's cases from hospitals: a comparison of autopsy and clinical diagnosis. Ann Acad Med Singapore. 1993;22:3-7. [pmid: 8503634].
1067 Teo C E. The autopsy. Singapore Med J. 1997;38:71-5. [pmid: 9269365].
1068 Teramoto A, Hirakawa K, Sanno N, Osamura Y. Incidental pituitary lesions in 1,000 unselected autopsy specimens. Radiology. 1994;193:161-4. [pmid: 8090885].
1069 Thomas E J, Studdert D M, Burstin H R, Orav E J, Zeena T, Williams E J, et al. Incidence and types of adverse events and negligent care in Utah and Colorado. Med Care. 2000;38:261-71. [pmid: 10718351].
1070 Thomsen J, Simonsen K, Felby S, Frohlich B. A prospective toxicology analysis in alcoholics. Forensic Sci Int. 1997;90:33-40. [pmid: 9438363].
1071 Thorndike L. A fifteenth century autopsy by Bernard Tornius. Ann Med Hist. 1928;10:270-7.
1072 Thornton C M, O'Hara M D. A regional audit of perinatal and infant autopsies in Northern Ireland. Br J Obstet Gynaecol. 1998;105:18-23. [pmid: 9442156].
1073 Thurlbeck W M. Accuracy of clinical diagnosis in a Canadian teaching hospital. Can Med Assoc J. 1981;125:443-7. [pmid: 7284926]. [pmcid: 1862466].
1074 Thurlbeck W M. Morphology and clinical-morphologic correlations. State of the art. Chest. 1984;85:32S-35S. [pmid: 6373179].
1075 Tibblin G, Welin L, Larsson B, Ljungberg I L, Svardsudd K. The influence of repeated health examinations on mortality in a prospective cohort study, with a comment on the autopsy frequency. The study of men born in 1913. Scand J Soc Med. 1982;10:27-32. [pmid: 7112052].
1076 Timperley W R. ACP Best Practice No 158. Neuropathology. J Clin Pathol. 2000;53:255-65. [pmid: 10823120]. [pmcid: 1731172].
1077 Torres A, el-Ebiary M, Padro L, Gonzalez J, de la Bellacasa J P, Ramirez J, et al. Validation of different techniques for the diagnosis of ventilator-associated pneumonia. Comparison with immediate postmortem pulmonary biopsy. Am J Respir Crit Care Med. 1994;149:324-31. [pmid: 8306025].
1078 Trask N, Califf R M, Conley M J, Kong Y, Peter R, Lee K L, et al. Accuracy and interobserver variability of coronary cineangiography: a comparison with postmortem evaluation. J Am Coll Cardiol. 1984;3:1145-54. [pmid: 6707366].
1079 Travers H. Quality assurance indicators in anatomic pathology. Arch Pathol Lab Med. 1990;114:1149-56. [pmid: 2241526].
1080 Trelstad R L, Amenta P S, Foran D J, Smilow P C. The role for regional autopsy centers in the evaluation of covered deaths. Survey of opinions of US and Canadian chairs of pathology and major health insurers in the United States. Arch Pathol Lab Med. 1996;120:753-8. [pmid: 8718901].
1081 Trichopoulos D, Mollo F, Tomatis L, Agapitos E, Delsedime L, Zavitsanos X, et al. Active and passive smoking and pathological indicators of lung cancer risk in an autopsy study. JAMA. 1992;268:1697-701. [pmid: 1527879].
1082 Trounce J Q, Fagan D, Levene M I. Intraventricular haemorrhage and periventricular leucomalacia: ultrasound and autopsy correlation. Arch Dis Child. 1986;61:1203-7. [pmid: 3545096].
1083 Tse G M, Lee J C. A 12-month review of autopsies performed at a university-affiliated teaching hospital in Hong Kong. Hong Kong Med J. 2000;6:190-4. [pmid: 10895143].
1084 Tsokos M, Puschel K. Iatrogenic staphylococcus aureus septicaemia following intravenous and intramuscular injections: clinical course and pathomorphological findings. Int J Legal Med. 1999;112:303-8. [pmid: 10460421].
1085 Tsujimura T, Yamada Y, Kubo M, Fushimi H, Kameyama M. Why couldn't an accurate diagnosis be made? An analysis of 1044 consecutive autopsy cases. Pathol Int. 1999;49:408-10. [pmid: 10417683].
1086 Turner J. Analysing the cost of postmortem examinations. Mod Hosp. 1930;35:69-70.
1087 Turner J, Raphael B. Requesting necropsies. BMJ. 1997;314:1499-500. [pmid: 9183189].
1088 Twigg S J, McCrirrick A, Sanderson P M. A comparison of post mortem findings with post hoc estimated clinical diagnoses of patients who die in a United Kingdom intensive care unit. Intensive Care Med. 2001;27:706-10. [pmid: 11398697].
1089 Tyrrel S. Rubbish in, rubbish out- or an irreverent view of death certificates. Public Health. 1981;95:232-4. [pmid: 7267959].
1090 Uemera K, Sternby N, Vanecek R, Vihert A, Kagan A. Grading atherosclerosis in aorta and coronary arteries obtained at autopsy. 1964.
1091 Valask M J. Loss control/risk management. A survey of the contribution of autopsy examination. Arch Pathol Lab Med. 1984;108:462-8. [pmid: 6547297].
1092 Valdes-Dapena M. The postautopsy conference with families. Arch Pathol Lab Med. 1984;108:497-8. [pmid: 6547303].
1093 Valdes-Dapena M. Sudden infant death syndrome: overview of recent research developments from a pediatric pathologist's perspective. Pediatrician. 1988;15:222-30. [pmid: 3068661].
1094 van Burik J H, Leisenring W, Myerson D, Hackman R C, Shulman H M, Sale G E, et al. The effect of prophylactic fluconazole on the clinical spectrum of fungal diseases in bone marrow transplant recipients with special attention to hepatic candidiasis. An autopsy study of 355 patients. Medicine (Baltimore). 1998;77:246-54. [pmcid: 126225]. [pmid: 9715729].
1095 van den Hauwe L, Parizel P M, Martin J J, Cras P, De Deyn P, De Schepper A M. Postmortem MRI of the brain with neuropathological correlation. Neuroradiology. 1995;37:343-9. [pmid: 7477830].
1096 Van Lente F, Martin A, Ratliff N B, Kazmierczak S C, Loop F D. The predictive value of serum enzymes for perioperative myocardial infarction after cardiac operations. An autopsy study. J Thorac Cardiovasc Surg. 1989;98:704-10. [pmid: 2811407].
1097 Vance R P. An unintentional irony: the autopsy in modern medicine and society. Hum Pathol. 1990;21:136-44. [pmid: 2307440].
1098 Vance R P. Autopsies and attitudes. Where do we go from here?. Arch Pathol Lab Med. 1992;116:1111-2. [pmid: 1444737].
1099 VanMarter L J, Taylor F, Epstein M F. Parental and physician-related determinants of consent for neonatal autopsy. Am J Dis Child. 1987;141:149-53. [pmid: 3812381].
1100 Varmus H. Evaluating the burden of disease and spending the research dollars of the National Institutes of Health. N Engl J Med. 1999;340:1914-5. [pmid: 10369857].
1101 Vathesatogkit P, Saenghirunvattana S, Nitiyanant P. Autopsy proven cases of pulmonary thromboembolism: 18-year study at Ramathibodi Hospital. J Med Assoc Thai. 1989;72:271-4. [pmid: 2769121].
1102 Vera-Roman J M. Why bury the autopsy?. Medicina Clinica. 1982;78:458-60. [pmid: 7098613].
1103 Veress B, Gadaleanu V, Nennesmo I, Wikstrom B M. The reliability of autopsy diagnostics: inter-observer variation between pathologists, a preliminary report. Qual Assur Health Care. 1993;5:333-7. [pmid: 8018892].
1104 Veress B, Alafuzoff I. Clinical diagnostic accuracy audited by autopsy in a university hospital in two eras. Qual Assur Health Care. 1993;5:281-6. [pmid: 8018882].
1105 Veress B, Alafuzoff I. A retrospective analysis of clinical diagnoses and autopsy findings in 3,042 cases during two different time periods. Hum Pathol. 1994;25:140-5. [pmid: 8119713].
1106 Volk E E, Prayson R A, Perl J 2nd. Autopsy findings of fatal complication of posterior cerebral circulation angioplasty. Arch Pathol Lab Med. 1997;121:738-40. [pmid: 9240912].
1107 Vujanic G M, Cartlidge P H, Stewart J H, Dawson A J. Perinatal and infant postmortem examinations: how well are we doing?. J Clin Pathol. 1995;48:998-1001. [pmcid: 503001]. [pmid: 8543645].
1108 Vujanic G M, Cartlidge P H, Stewart J H. Improving the quality of perinatal and infant necropsy examinations: a follow up study. J Clin Pathol. 1998;51:850-3. [pmcid: 500981]. [pmid: 10193328].
1109 Waife S O, Lucchesi P F, Sigmond B. The significance of mortality statistics in medical research: an analysis of 1000 deaths at the Philadelphia General Hospitals. Ann Intern Med. 1951;37:332-7.
1110 Walden R, Bass A, Modan R, Adar R. Pulmonary embolism in post-mortem material with clinical correlations in 425 cases. Int Angiol. 1985;4:469-73. [pmid: 3834011].
1111 Waldron H A, Vickerstaff L. Necropsy rates in the United Birmingham Hospitals. BMJ. 1975;2:326-8. [pmid: 1131528]. [pmcid: 1681898].
1112 Waldron T, Vickerstaff L. The role of the autopsy in medical care. In: McLachlan G, editor. A Question of quality? : Roads to assurance in medical care. London: Published for the Nuffield Provincial Hospitals Trust by Oxford University Press; 1976
1113 Walker A E, Diamond E L, Moseley J. The neuropathological findings in irreversible coma. A critque of the “respirator”. J Neuropathol Exp Neurol. 1975;34:295-323. [pmid: 1055791].
1114 Waller B F, Palumbo P J, Lie J T, Roberts W C. Status of the coronary arteries at necropsy in diabetes mellitus with onset after age 30 years. Analysis of 229 diabetic patients with and without clinical evidence of coronary heart disease and comparison to 183 control subjects. Am J Med. 1980;69:498-506. [pmid: 7424939].
1115 Walsh C J. Autopsy rates in U.S. hospitals. PAS Rep. 1972;12:1-4.
1116 Wanzel K R, Jamieson C G, Bohnen J M. Complications on a general surgery service: incidence and reporting. Can J Surg. 2000;43:113-7. [pmid: 10812345].
1117 Warren J W, Muncie H L Jr, Magaziner J, Hall-Craggs M. Organ-limited autopsies. Obtaining permission for postmortem examination of the urinary tract. Arch Pathol Lab Med. 1995;119:440-3. [pmid: 7748072].
1118 Wartman WB. The incidence of heart disease in 2,000 consecutive autopsies.; 1948
1119 Watanabe K, Iwaki H, Satoh M, Ikeda T, Ichimiya S, Suzuki N, et al. Veno-occlusive disease of the liver following bone marrow transplantation: a clinical-pathological study of autopsy cases. Artif Organs. 1996;20:1145-50. [pmid: 8896736].
1120 Webster J R Jr, Derman D, Kopin J, Glassroth J, Patterson R. Obtaining permission for an autopsy: its importance for patients and physicians. Am J Med. 1989;86:325-6. [pmid: 2919615].
1121 Wecht C H. Autopsies. Forensic Sci Int. 1988;38:157-60. [pmid: 3056798].
1122 Wecht C. Medical malpractice suits and autopsies. JAMA. 1991;266:360-1. [pmid: 2056639].
1123 Weeramanthri T S. A medical cause of death validation study of adult aboriginal deaths in the Northern Territory of Australia in 1992. Public Health. 1997;111:429-33. [pmid: 9392977].
1124 Welch K, Finkbeiner W, Alpers C E, Blumenfeld W, Davis R L, Smuckler E A, et al. Autopsy findings in the acquired immune deficiency syndrome. JAMA. 1984;252:1152-9. [pmid: 6471338].
1125 Welch HG, Black WC. Using autopsy series to estimate the disease “reservoir” for ductal carcinoma in situ of the breast: how much more breast cancer can we find? Ann Intern Med; 1997. p. 1023–8.
1126 Wells H G. Relation of clinical to necropsy diagnosis in cancer and value of existing cancer statistics. JAMA. 1923;80:737-40.
1127 Wells P S, Ginsberg J S, Anderson D R, Kearon C, Gent M, Turpie A G, et al. Use of a clinical model for safe management of patients with suspected pulmonary embolism. Ann Intern Med. 1998;129:997-1005. [pmid: 9867786].
1128 Wells W A, Carney P A, Eliassen M S, Tosteson A N, Greenberg E R. Statewide study of diagnostic agreement in breast pathology. J Natl Cancer Inst. 1998;90:142-5. [pmid: 9450574].
1129 Wells W A, Carney P A, Eliassen M S, Grove M R, Tosteson A N. Pathologists' agreement with experts and reproducibility of breast ductal carcinoma-in-situ classification schemes. Am J Surg Pathol. 2000;24:651-9. [pmid: 10800983].
1130 Welsh T S, Kaplan J. The role of postmortem examination in medical education. Mayo Clin Proc. 1998;73:802-5. [pmid: 9703312].
1131 Weman S, Salminen U, Penttila A, Mannikko A, Karhunen P. Post-mortem cast angiography in the diagnostics of graft complications in patients with fatal outcome following coronary artery bypass grafting (CABG). Int J Legal Med. 1999;112:107-14. [pmid: 10048668].
1132 Wernick R M, Smith D L, Houghton D C, Phillips D S, Booth J L, Runckel D N, et al. Reliability of histologic scoring for lupus nephritis: a community-based evaluation. Ann Intern Med. 1993;119:805-11. [pmid: 8379602].
1133 West J G, Trunkey D D, Lim R C. Systems of trauma care. A study of two counties. Arch Surg. 1979;114:455-60. [pmid: 435058].
1134 West J G. An autopsy method for evaluating trauma care. J Trauma. 1981;21:32-4. [pmid: 7463535].
1135 West J G. Validation of autopsy method for evaluating trauma care. Arch Surg. 1982;117:1033-5. [pmid: 7103721].
1136 Westesson P L, Bronstein S L, Liedberg J. Temporomandibular joint: correlation between single-contrast videoarthrography and postmortem morphology. Radiology. 1986;160:767-71. [pmid: 3737916].
1137 Westesson P L, Katzberg R W, Tallents R H, Sanchez-Woodworth R E, Svensson S A. CT and MR of the temporomandibular joint: comparison with autopsy specimens. AJR Am J Roentgenol. 1987;148:1165-71. [pmid: 3495142].
1138 Weston J T. A modern medicolegal investigative system within the framework of a State Division of Health--experience in Utah. J Forensic Sci. 1970;15:461-75. [pmid: 5493582].
1139 Weston JT. The medicolegal investigation of operating room associated deaths. Leg Med Annu. 1977:15–48.
1140 Weston J T. A modern medical examiner facility. J Forensic Sci. 1978;23:201-11. [pmid: 744962].
1141 Weyant M J, Eachempati S R, Maluccio M A, Rivadeneira D E, Grobmyer S R, Hydo L J, et al. Interpretation of computed tomography does not correlate with laboratory or pathologic findings in surgically confirmed acute appendicitis. Surgery. 2000;128:145-52. [pmid: 10922984].
1142 Wheeler M S. One resident's view of the autopsy. Arch Pathol Lab Med. 1982;106:311-3. [pmid: 6896440].
1143 Whitehouse S R, Kissoon N, Singh N, Warren D. The utility of autopsies in a pediatric emergency department. Pediatr Emerg Care. 1994;10:72-5. [pmid: 8029113].
1144 Whitty P, Parker C, Prieto-Ramos F, al-Kharusi S. Communication of results of necropsies in north east Thames region. BMJ. 1991;303:1244-6. [pmid: 1747649]. [pmcid: 1671564].
1145 Wijdicks E F, Scott J P. Pulmonary embolism associated with acute stroke. Mayo Clin Proc. 1997;72:297-300. [pmid: 9121173].
1146 Wilhelmsen L, Hagman M, Werko L. Recurrent pulmonary embolism--incidence, predisposing factors and prognosis. Acta Med Scand. 1972;192:565-75. [pmid: 4640701].
1147 Wilke A, French F. Attitudes toward autopsy refusal by young adults. Psychological Reports. 1990;67:81-2. [pmid: 2236423].
1148 Wilkes M S, Fortin A H, Felix J C, Godwin T A, Thompson W G. Value of necropsy in acquired immunodeficiency syndrome. Lancet. 1988;2:85-8. [pmid: 2898707].
1149 Wilkes M S, Link R N, Jacobs T A, Fortin A H, Felix J C. Attitudes of house officers toward the autopsy. J Gen Intern Med. 1990;5:122-5. [pmid: 2313404].
1150 Wilkes M S, Fortin A H, Jacobs T A. Physicians' attitudes toward the autopsy of patients with AIDS. NY State J Med. 1991;91:386-9.
1151 Williams J, Goddard M, Gresham G, Wyatt B. Audit of necropsy reporting in East Anglia. J Clin Pathol. 1997;50:691-4. [pmcid: 500123]. [pmid: 9301556].
1152 Williamson J. Quality of current diagnostic performance--our most serious health care quality problem?. Am J Med Qual. 1994;9:145-8. [pmid: 7819820].
1153 Wilson R R. In defense of the autopsy. JAMA. 1966;196:193-4.
1154 Wilson R D, Chitayat D, McGillivray B C. Fetal ultrasound abnormalities: correlation with fetal karyotype, autopsy findings, and postnatal outcome--five-year prospective study. Am J Med Genet. 1992;44:586-90. [pmid: 1481814].
1155 Winkelman M D, Galloway P G. Central nervous system complications of thermal burns. A postmortem study of 139 patients. Medicine (Baltimore). 1992;71:271-83. [pmcid: 126225]. [pmid: 1522803].
1156 Wissler R W. The value of the autopsy for understanding cardiovascular disease. Past, present, and future. Arch Pathol Lab Med. 1984;108:479-83. [pmid: 6547299].
1157 Wlodaver CG. Why have autopsies grown so unpopular and what can we do about it? The clinical-pathological conference. J Okla State Med Assoc. 1994;87.
1158 Wolff A P, Kessler S. Iatrogenic injury to the hypopharynx and cervical esophagus: an autopsy study. Ann Otol Rhinol Laryngol. 1973;82:778-83. [pmid: 4761038].
1159 Wolff A M. A review of methods used for medical quality assurance in hospitals: advantages and disadvantages. J Qual Clin Pract. 1994;14:85-97. [pmid: 8049857].
1160 Wolff A M, Bourke J, Campbell I A, Leembruggen D W. Detecting and reducing hospital adverse events: outcomes of the Wimmera clinical risk management program. Med J Aust. 2001;174:621-5. [pmid: 11480681].
1161 Woodward P J, Sohaey R, Harris D P, Jackson G M, Klatt E C, Alexander A L, et al. Postmortem fetal MR imaging: comparison with findings at autopsy. AJR Am J Roentgenol. 1997;168:41-6. [pmid: 8976917].
1162 Woythaler J N, Singer S L, Kwan O L, Meltzer R S, Reubner B, Bommer W, et al. Accuracy of echocardiography versus electrocardiography in detecting left ventricular hypertrophy: comparison with postmortem mass measurements. J Am Coll Cardiol. 1983;2:305-11. [pmid: 6223063].
1163 Wren C, Richmond S, Donaldson L. Temporal variability in birth prevalence of cardiovascular malformations. Heart. 2000;83:414-9. [pmid: 10722540]. [pmcid: 1729354].
1164 Wright C, Cameron H, Lamb W. A study of the quality of perinatal autopsy in the former northern region. The Northern Perinatal Mortality Survey Steering Group. Br J Obstet Gynaecol. 1998;105:24-8. [pmid: 9442157].
1165 Wrzolek M A, Brudkowska J, Kozlowski P B, Rao C, Anzil A P, Klein E A, et al. Opportunistic infections of the central nervous system in children with HIV infection: report of 9 autopsy cases and review of literature. Clin Neuropathol. 1995;14:187-96. [pmid: 8521620].
1166 Wunderink R G, Woldenberg L S, Zeiss J, Day C M, Ciemins J, Lacher D A. The radiologic diagnosis of autopsy-proven ventilator-associated pneumonia. Chest. 1992;101:458-63. [pmid: 1735272].
1167 Yamauchi K, Umeda Y. Symptomatic intracranial haemorrhage in acute nonlymphoblastic leukaemia: analysis of CT and autopsy findings. J Neurol. 1997;244:94-100. [pmid: 9120503].
1168 Yano K, MacLean C J. The incidence and prognosis of unrecognized myocardial infarction in the Honolulu, Hawaii, Heart Program. Arch Intern Med. 1989;149:1528-32. [pmid: 2742427].
1169 Yesner R. Medical center autopsy costs. Am J Clin Pathol. 1978;69:242-4. [pmid: 626168].
1170 Yesner R, Robinson M J, Goldman L, Reichert C M, Engel L. A symposium on the autopsy. Pathology Annual. 1985;20(Pt 1):441-77. [pmid: 3991241].
1171 Yokose T, Ito Y, Ochiai A. High prevalence of atypical adenomatous hyperplasia of the lung in autopsy specimens from elderly patients with malignant neoplasms. Lung Cancer. 2000;29:125-30. [pmid: 10963842].
1172 Young C W, Sternberg S S. The autopsy at a cancer center--1980. Clinical Bulletin. 1980;10:47-8. [pmid: 7398035].
1173 Younossi Z M, Boparai N, Gramlich T, Goldblum J, George P, Mayes J. Agreement in pathologic interpretation of liver biopsy specimens in posttransplant hepatitis C infection. Arch Pathol Lab Med. 1999;123:143-5. [pmid: 10050788].
1174 Zanetto U, do Campo J L. Post-mortem macroscopic examination, the clinician's missing practice. J Pathol. 1994;173:381-2. [pmid: 7965397].
1175 Zarbo R J. Quality assessment in anatomic pathology in the cost-conscious era. Am J Clin Pathol. 1996;106:S3-10. [pmid: 8853049].
1176 Zarbo R J, Baker P B, Howanitz P J. Quality assurance of autopsy permit form information, timeliness of performance, and issuance of preliminary report. A College of American Pathologists Q-Probes study of 5434 autopsies from 452 institutions. Arch Pathol Lab Med. 1996;120:346-52. [pmid: 8619745].
1177 Zarbo R J, Baker P B, Howanitz P J. The autopsy as a performance measurement tool--diagnostic discrepancies and unresolved clinical questions: a College of American Pathologists Q-Probes study of 2479 autopsies from 248 institutions. Arch Pathol Lab Med. 1999;123:191-8. [pmid: 10086506].
1178 Zehr K J, Liddicoat J R, Salazar J D, Gillinov A M, Hruban R H, Hutchins G M, et al. The autopsy: still important in cardiac surgery. Ann Thorac Surg. 1997;64:380-3. [pmid: 9262579].
1179 Zema M J, Collins M, Alonso D R, Kligfield P. Electrocardiographic poor R-wave progression. Correlation with postmortem findings. Chest. 1981;79:195-200. [pmid: 6450668].
1180 Zheng W Q, Fan Y H, Ng A. Public attitudes towards the autopsy in China. Pathology. 1998;30:92-4. [pmid: 9643484].