# Appendix D: Article Abstraction Form for Autopsy Studies

The first half of the form applies to all of the study topics (Appendix C), but the second half (Results section) is tailored to studies addressing the rate of autopsy-detected diagnostic errors. The heterogeneity of studies addressing other topics precluded the development of a practical template. Thus, for these other topics, reviewers summarized the results as free text.