# Appendixes

Appendix A: Additional Tables and Figures

Appendix B: Statistical Analysis

Appendix C: Index of Study Topics

Appendix D: Article Abstraction Form for Autopsy Studies

Appendix E: Interviews and Other Input From Advisory Panel

Appendix F: Bibliography

Appendix G: Acknowledgments