# Evidence Tables

Evidence Table 1. Summary of Rejected Studies

Number of Rejected Studies | Reason for Rejection^1^
96 | Studies published prior to 1990
81 | Studies with less than 24 weeks of follow-up (other than diagnosis)
72 | Studies that are not RCTs (pharmacological treatment only)
52 | Abstracts, letters, comments, reviews, editorials, case reports, or meta-analyses
49 | Studies not including tests to establish or support diagnosis of PD
29 | Studies with less than 10 patients
17 | Outcomes not extractable
24 | Studies not including treatment or diagnosis
13 | No outcome of interest
6 | Cross-over studies
6 | Mixed populations where results for PD patients cannot be separately extracted
10 | Studies not including an objective clinical outcome measure of PD activity
2 | Duplicate studies
2 | In vitro studies
2 | Languages other than English
2 | Pharmacodynamic or pharmacokinetic study
2 | Study populations not including Parkinson's Disease
465 | TOTAL

1 Based on protocol-defined inclusion/exclusion criteria

Evidence Table 2. Study Level Characteristics

| Total | | | Diagnosis | | | Pharmacological | | | Surgical | | | Psychiatric | | | Ancillary
| k | t | n | k | t | n | k | t | n | k | t | n | k | t | n | k | t | n
Totals | 180 | 353 | 16,158 | 59 | 141 | 3,369 | 49 | 111 | 9,968 | 42 | 52 | 1,380 | 10 | 12 | 392 | 20 | 37 | 1,049
Location
Europe | 90 | 186 | 6,327 | 40 | 94 | 1,948 | 25 | 52 | 3,478 | 14 | 20 | 393 | 2 | 3 | 73 | 9 | 17 | 435
North America | 66 | 118 | 6,819 | 12 | 27 | 1,226 | 14 | 38 | 3,902 | 25 | 29 | 831 | 7 | 8 | 292 | 8 | 16 | 568
Other | 15 | 29 | 888 | 5 | 13 | 94 | 5 | 10 | 708 | 1 | 1 | 13 | 1 | 1 | 27 | 3 | 4 | 46
Multi-National | 9 | 20 | 2,124 | 2 | 7 | 101 | 5 | 11 | 1,880 | 2 | 2 | 143 | 0 | 0 | 0 | 0 | 0 | 0
Study Design
RCT | 68 | 151 | 10,996 | 0 | 0 | 0 | 49 | 111 | 9,968 | 4 | 8 | 105 | 2 | 4 | 57 | 13 | 28 | 866
nRCT | 6 | 16 | 273 | 2 | 5 | 83 | - | - | - | 2 | 7 | 117 | 0 | 0 | 0 | 2 | 4 | 73
UCS | 49 | 49 | 1,627 | 5 | 5 | 278 | - | - | - | 35 | 35 | 1,145 | 6 | 6 | 114 | 3 | 3 | 90
XS | 48 | 119 | 2,075 | 46 | 117 | 2,055 | - | - | - | 0 | 0 | 0 | 0 | 0 | 0 | 2 | 2 | 20
Other | 9 | 18 | 1,187 | 6 | 14 | 953 | - | - | - | 1 | 2 | 13 | 2 | 2 | 221 | 0 | 0 | 0
Level of Evidence
I | 28 | 70 | 8,945 | 0 | 0 | 0 | 26 | 65 | 8,454 | 0 | 0 | 0 | 0 | 0 | 0 | 2 | 5 | 491
II | 40 | 79 | 2,051 | 0 | 0 | 0 | 23 | 46 | 1,514 | 4 | 8 | 105 | 2 | 2 | 57 | 11 | 23 | 375
III | 112 | 204 | 5,162 | 59 | 141 | 3,369 | 0 | 0 | 0 | 38 | 44 | 1,275 | 8 | 10 | 335 | 7 | 9 | 183
Quality Score
1 | 7 | 15 | 180 | 0 | 0 | 0 | 1 | 2 | 20 | 0 | 0 | 0 | 0 | 0 | 0 | 6 | 13 | 160
2 | 17 | 35 | 2,241 | 0 | 0 | 0 | 8 | 16 | 1,502 | 1 | 2 | 13 | 1 | 2 | 20 | 7 | 15 | 706
3 | 13 | 28 | 2,014 | 0 | 0 | 0 | 11 | 24 | 1,959 | 2 | 4 | 55 | 0 | 0 | 0 | 0 | 0 | 0
4 | 22 | 51 | 4,147 | 0 | 0 | 0 | 20 | 47 | 4,073 | 1 | 2 | 37 | 1 | 2 | 37 | 0 | 0 | 0
5 | 9 | 22 | 2,414 | 0 | 0 | 0 | 9 | 22 | 2,414 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Industry Sponsorship | 42 | 90 | 7,355 | 1 | 1 | 30 | 29 | 72 | 6,612 | 4 | 4 | 134 | 4 | 5 | 116 | 4 | 8 | 463

k - number of studies

t - number of treatment arms

n - number of patients

Multi-National - on more than one continent

RCT - randomized controlled trial

nRCT - non-randomized controlled trial

UCS - uncontrolled case series

XS - cross-sectional

Evidence Table 3. Overall Treatment Level Characteristics

| Total | | Pharmacological | | Surgical | | Psychiatric | | Ancillary
| t | n | t | n | t | n | t | n | t | n
Patients Randomized/Enrolled | 212 | 12,789 | 111 | 9,968 | 52 | 1,380 | 12 | 392 | 37 | 1,049
Male (n = %) | 164 | 60% | 82 | 60% | 40 | 64% | 10 | 59% | 32 | 62%
Female (n = %) | 164 | 40% | 82 | 40% | 40 | 36% | 10 | 41% | 32 | 38%
Mean Age > 65 | 64 | 2,743 | 17 | 1,225 | 10 | 270 | 11 | 373 | 26 | 875
Mean Age < 65 | 130 | 8,613 | 80 | 7,380 | 41 | 1,066 | 1 | 19 | 8 | 148
Disease Stage
Early* | 80 | 7,505 | 74 | 7,405 | 2 | 28 | NR | NR | 4 | 72
Advanced* | 114 | 4,758 | 37 | 2,563 | 41 | 1,030 | 9 | 344 | 27 | 821
Mean Age of Onset > 50 | 22 | 1,118 | 15 | 928 | 3 | 102 | 1 | 49 | 3 | 39
Mean Age of Onset < 50 | 3 | 49 | NR | NR | 3 | 49 | NR | NR | NR | NR
Race | 11 | 567 | 8 | 506 | NR | NR | 1 | 11 | 2 | 50
Socioeconomic status | 10 | 890 | 6 | 820 | NR | NR | 2 | 20 | 2 | 50

* Early = author defined as “early” or “de novo” or disease duration < 5 years

** Advanced = author defined as “advanced” or disease duration >5 years

t-number of treatment arms

n-number of patients

NR-not reported

Evidence Table 4. Treatment Level Characteristics of Diagnostic Studies

Test Category | Diagnosis Studies
| k | t | n
Apomorphine challenge | 5 | 6 | 229
Autopsy | 6 | 15 | 253
Clinical or laboratory | 10 | 26 | 1,412
Color vision test | 2 | 3 | 35
MRI | 3 | 8 | 140
Olfactory testing | 7 | 21 | 355
PD Test battery | 3 | 7 | 180
PET scans | 8 | 21 | 185
SPECT scans* | 13 | 29 | 460
Other scans | 2 | 5 | 120
Total | 59 | 141 | 3,369

SPECT - single photon emission computed tomography

PET - positron emission tomography

MRI - magnetic resonance imaging

k - number of studies

t - number of treatment arms

n - number of patients

* includes 5 studies that reported SPECT results before and after administration of apomorphine and one study that compared SPECT and PET results

Evidence Table 5. Treatment Level Characteristics of Pharmacological Studies

Treatment class | Total | | Early | | Advanced
| t | n | t | n | t | n
Monotherapy
LD | 41 | 3,927 | 25 | 2,835 | 16 | 1,092
Dopamine Agonist | 6 | 508 | 6 | 508 | 0 | 0
MAO-B inhibitor | 5 | 336 | 5 | 336 | 0 | 0
Combination therapy
LD/DA | 33 | 2,935 | 18 | 1,907 | 15 | 1,028
LD/COMT inhibitor | 8 | 639 | 2 | 196 | 6 | 443
LD/DA/MAO-B inhibitor | 2 | 68 | 2 | 68 | 0 | 0
LD/MAO-B inhibitor | 7 | 700 | 7 | 700 | 0 | 0
DA/MAO-B inhibitor | 1 | 10 | 1 | 10 | 0 | 0
Other Combinations | 4 | 471 | 4 | 471 | 0 | 0
Placebo | 4 | 374 | 4 | 374 | 0 | 0
Total | 111 | 9,968 | 74 | 7,405 | 37 | 2,563

LD - levodopa (always given with peripheral decarboxylase inhibitor)

DA - doamine agonist

MAO-B - monoamine oxidase-B

COMT - catchol O-methyl transferase

other Combinations included 2 studies with LD/Selegiline/Tocopherol and LD/Tocopherol

k - number of studies

t - number of treatment arms

n - number of patients

Evidence Table 6. Statistical Analysis Dopamine Agonists with L-Dopa vs. L-Dopa alone

First Author | Year | Dopamine Agonist Tested | Patients on L-dopa | Patients on DA and L-Dopa | Disease Stage | Time of Evaluation (months) | Mean Age (years) | Change-score Effect Sizes
Alarcon | 1998 | Bromocriptine | 38 | 40 | Early | 36 | 63.8 | 0.137
Allain | 2000 | Lisuride | 41 | 41 | Early | 12 | 59.0 | 0.411
Gimenez-Roldan | 1997 | Bromocriptine | 23 | 27 | Early | 8 | 60.3 | 1.463
Hutton | 1996 | Cabergoline | 65 | 123 | Advanced | 6 | 63.1 | 0.299
Kulisevsky | 2000 | Pergolide | 10 | 10 | Early | 24 | 65.5 | -0.057
Lieberman | 1997 | Pramipexole | 172 | 179 | Advanced | 8 | 63.4 | 0.264
Nakanishi | 1992 | Bromocriptine | 124 | 117 | Early | 60 | 61.4 | 0.257
Olanow | 1994 | Pergolide | 187 | 189 | Advanced | 6 | 63.0 | 0.203
Olanow | 1995 | Bromocriptine | 21 | 19 | Early | 14 | 66.2 | -0.239
Olsson | 1990 | Bromocriptine | 140 | 137 | Early | 12 | 58.5 | 0.230
Parkinson Study Group | 2000 | Pramipexole | 150 | 151 | Early | 24 | 61.2 | -0.398
Przuntek | 1996 | Bromocriptine | 302 | 285 | Early | 48 | 65.0 | 0.240
Rabey | 1990 | Lisuride | 13 | 15 | Advanced | 48 | 65.4 | 0.329
Rascol | 2000 | Ropinirole | 89 | 179 | Early | 60 | 63.0 | -0.418
Rinne | 1998 | Cabergoline | 205 | 208 | Early | 18 | 61.6 | -0.288
Sethi | 1998 | Ropinirole | 77 | 70 | Early | 12 | 61.9 | 0.521
Steiger | 1996 | Cabergoline | 11 | 6 | Advanced | 6 | 62.1 | -0.102
Inzelberg* | 1996 | Cabergoline vs. Bromocriptine | 22 (Caber.) | 22 (Bromo.) | Advanced | 12 | - | 0.167
Korczyn* | 1999 | Ropinirole vs. Bromocriptine | 102 (Ropin.) | 112(Bromo.) | Early | 36 | 62.9 | -0.164

L-dopa = Levodopa

DA = Dopamine Agonisr

Caber = Cabergoline

Bromo = Bromocriptine

Ropin = Ropinirole

* Both groups were on both DA and L-dopa. The names in parentheses indicate which DA was used to treat a particular group.

Evidence Table 7. Statistical Analysis: Selegiline with L-Dopa vs. L-Dopa alone

First Author | Year | Patients on L-dopa | Patients on Selegiline and L-Dopa | Disease Duration (years) | Time of Evaluation (months) | Mean Age (years) | Change-score Effect Sizes
Larsen | 1999 | 81 | 73 | Early | 60 | 64.3 | 0.593
Lees | 1995 | 213 | 233 | Early | 12 | 63.2 | 0.810
Myllyla | 1992 | 25 | 27 | Early | 12 | 61.1 | -0.277
Olanow | 1995 | 21 | 20 | Early | 14 | NR | 0.931
Palhagen | 1998 | 81 | 76 | Early | 12 | 63.8 | -0.343

L-dopa = Levodopa

Evidence Table 8 Statistical Analysis: COMT Inhibitors with L-Dopa vs. L-Dopa alone

First Author | Year | COMT Inhibitor Tested | Patients on L-dopa | Patients on COMT Inhibitors and L-Dopa | Disease Duration (years) | Time of Evaluation (months) | Mean Age (years) | Change-score Effect Sizes
Baas* | 1997 | Tolcapone | 58 | 60 | 9.75 | 3 | 63.0 | 0.263
Baas* | 1997 | Tolcapone | 58 | 59 | 10.25 | 3 | 63.5 | 0.553
Parkinson Study Group | 1997 | Entacapone | 102 | 103 | 11.05 | 7 | 63.3 | 0.278
Rajput* | 1997 | Tolcapone | 66 | 69 | 10.75 | 3 | 64.0 | 0.180
Rajput* | 1997 | Tolcapone | 66 | 67 | 10.80 | 3 | 64.5 | 0.103
Rinne | 1998 | Entacapone | 86 | 85 | 10.75 | 6 | 62.7 | 0.310
Waters* | 1997 | Tolcapone | 102 | 98 | 4.15 | 6 | 67.0 | 0.397
Waters* | 1997 | Tolcapone | 102 | 98 | 3.75 | 6 | 65.0 | 0.471

LD - Levodopa

COMT - Catechol O-Methyl Transferase

* Separate treatment groups (different doses) of the same study

Evidence Table 9. Pharmacological Studies: Adverse Events

Adverse Events | Total | | LD | | DAs | | MAO-B | | LD/DA | | LD/COMT | | LD/DA/MAO-B | | LD/MAO-B | | Other | | Placebo
| % | n | % | n | % | n | % | n | % | n | % | n | % | n | % | n | % | n | % | n
Deaths | 4.8 | 5,635 | 5.0 | 2,342 | 14.0 | 64 | 0.9 | 336 | 3.3 | 1,708 | - | 0 | - | 0 | 13.1 | 634 | 0.0 | 409 | 0.7 | 142
Treatment Related Deaths | 0.0 | 1,232 | 0.0 | 317 | - | 0 | 0.0 | 255 | 0.0 | 557 | - | 0 | - | 0 | 0.0 | 27 | 0.0 | 10 | 0.0 | 66
Withdrawals | 29.2 | 8,961 | 30.4 | 3,605 | 48.4 | 508 | 12.8 | 336 | 28.8 | 2,505 | 39.1 | 384 | 32.4 | 68 | 32.6 | 700 | 9.8 | 481 | 17.4 | 374
Efficacy Withdrawals | 5.1 | 5,840 | 6.1 | 2,597 | 10.0 | 468 | - | 0 | 3.4 | 2,077 | 1.9 | 103 | 0.0 | 41 | 3.8 | 373 | 0.0 | 10 | 4.1 | 171
Safety Withdrawals | 11.2 | 7,444 | 8.3 | 3,268 | 20.6 | 490 | - | 0 | 12.8 | 2,256 | 15.5 | 639 | 9.8 | 41 | 13.0 | 446 | 5.6 | 72 | 4.7 | 232
Adverse Events
Cardiac | 12.2 | 4,332 | 10.8 | 1,637 | 9.6 | 228 | 0.4 | 255 | 16.9 | 1,712 | 4.2 | 119 | - | 0 | 3.7 | 134 | 0.0 | 10 | 4.6 | 237
Cerebrovascular | 0.6 | 345 | 1.2 | 81 | - | 0 | 0.5 | 191 | - | 0 | - | 0 | - | 0 | 0.0 | 73 | - | 0 | - | 0
GI | 23.8 | 6,019 | 22.0 | 2,326 | 30.3 | 228 | 0.8 | 255 | 28.2 | 2,067 | 29.3 | 639 | - | 0 | 22.4 | 134 | 16.7 | 72 | 13.4 | 298
Infections | 9.8 | 1,641 | 8.2 | 451 | - | 0 | - | 0 | 11.4 | 797 | 9.9 | 332 | - | 0 | 0.0 | 61 | - | 0 | - | 0
Musculoskeletal | 8.2 | 1,796 | 5.5 | 990 | - | 0 | - | 0 | 10.9 | 614 | 19.3 | 119 | - | 0 | 5.5 | 73 | - | 0 | - | 0
Pulmonary | 2.8 | 689 | 1.6 | 255 | - | 0 | - | 0 | 3.5 | 315 | 3.4 | 119 | - | 0 | - | 0 | - | 0 | - | 0
Urinary system | 7.8 | 903 | 0.5 | 366 | - | 0 | - | 0 | 5.9 | 17 | 12.9 | 520 | - | 0 | - | 0 | - | 0 | - | 0
Other* | 8.6 | 3,308 | 5.3 | 1,524 | 14.6 | 164 | - | 0 | 11.4 | 1,376 | - | 0 | - | 0 | 8.2 | 73 | - | 0 | 8.8 | 171

n-number of patients

LD- levodopa

DA- dopamine agonist

MAO-B- monoamine oxidase-B

COMT- catechol O-methyl transferase

Gl- gastyro-intenstinal

* Other includes: asthenia, fatigue, pain peripheral edema, pruritis, sweating increased, syncope,weight increased.

Evidence Table 10. Pharmacological Studies: Neurological and Psychiatric Adverse Events

Adverse Events | Total | | LD | | DAs | | LD/DA | | LD/COMT | | LD/DA/MAO-B | | LD/MAO-B | | Other | | Placebo
| % | n | % | n | % | n | % | n | % | n | % | n | % | n | % | n | % | n
Neurological
Akinesia | 20.6 | 413 | 23.9 | 205 | - | 0 | 17.3 | 208 | - | 0 | - | 0 | - | 0 | - | 0 | - | 0
Ataxia | 10.8 | 622 | 6.5 | 245 | - | 0 | 16.1 | 274 | 6.8 | 103 | - | 0 | - | 0 | - | 0 | - | 0
Dizziness | 18.9 | 4,076 | 15.5 | 1,975 | - | 0 | 26.3 | 1,511 | 14.6 | 384 | - | 0 | 9.6 | 73 | 2.8 | 72 | 1.6 | 61
Dyskinesias | 23.1 | 5,828 | 20.2 | 2,522 | 1.9 | 262 | 24.7 | 2,052 | 35.8 | 639 | 4.9 | 41 | 30.1 | 312 | - | 0 | - | 0
Dystonia | 12.0 | 2,640 | 11.4 | 1,303 | 7.4 | 270 | 10.2 | 714 | - | 0 | 12.2 | 41 | 22.4 | 312 | - | 0 | - | 0
Headache | 9.9 | 3,297 | 7.6 | 1,657 | - | 0 | 13.8 | 1,192 | 8.9 | 315 | - | 0 | - | 0 | 8.3 | 72 | 0.0 | 61
PD Aggravated | 24.5 | 1,203 | 31.4 | 328 | - | 0 | 20.2 | 772 | 35.0 | 103 | - | 0 | - | 0 | - | 0 | - | 0
Tremor | 11.1 | 934 | 10.7 | 476 | - | 0 | 11.6 | 458 | - | 0 | - | 0 | - | 0 | - | 0 | - | 0
Other | 5.7 | 724 | 4.1 | 539 | 62.5 | 8 | 13.0 | 92 | 2.4 | 85 | - | 0 | - | 0 | - | 0 | - | 0
Psychiatric
Confusion | 6.5 | 1,548 | 3.7 | 804 | 4.7 | 64 | 10.0 | 680 | - | 0 | - | 0 | - | 0 | - | 0 | - | 0
Depression | 9.6 | 2,576 | 7.8 | 1,351 | - | 0 | 12.0 | 1,152 | - | 0 | - | 0 | 5.4 | 73 | - | 0 | - | 0
Hallucinations | 7.6 | 4,052 | 5.1 | 1,790 | 9.9 | 172 | 10.2 | 1,595 | 10.2 | 324 | - | 0 | - | 0 | - | 0 | 2.3 | 171
Sleeping Disorders | 25.4 | 5,009 | 19.2 | 2,238 | 43.9 | 164 | 30.4 | 1,697 | 31.6 | 639 | - | 0 | 15.0 | 100 | - | 0 | 21.6 | 171
Other | 12.2 | 2,048 | 9.9 | 817 | - | 0 | 10.4 | 769 | 20.2 | 435 | - | 0 | 3.7 | 27 | - | 0 | - | 0

Neurological Other: Chorea, freezing, hemiparesis, hyperkinesia, paresthesia, vertigo

Psychiatric Other: Agitation, amnesia, anorexia, anxiety, appetite increase, dementia, psychosis

n - number of patients

LD - levodopa

DA - dopamine agonist

MAO-B - monoamine oxidase-B

COMT - catechol O-methyl transferase

GI - gastro-intenstinal

Evidence Table 11. Treatment Level Characteristics of Surgical Studies

Type of Surgery | Surgical Studies
| t | n
Pallidotomy | 20 | 764
Thalamotomy | 5 | 134
DBS | 16 | 288
GPi | 4* | 22*
STN | 8* | 135*
thalamic | 4* | 131*
Tissue Transplant | 9 | 165
Adrenal Medulla | 3** | 91**
Human fetal brain cells | 5** | 52**
Porcine fetal brain cells | 1** | 12**
No surgery | 2 | 29
Total | 52 | 1380

DBS - direct brain stimulation

Gpi- globus pallidus

STN- subthalamic nucleus

t- number of treatment arms

n- number of patients

* Subgroups of DBS

** Subgroups of Tissue Transplant

Evidence Table 12. Statistical Analysis: Pallidotomy

First Author | Year | Surgical Intervention | Number of Patients | Time of Evaluation (months) | Mean Age (years) | “Off” score Effect Sizes | “On” score Effect Sizes
Baron | 2000 | Unilateral | 10 | 48 | 58.0 | 0.100 | -0.200
Dalvi | 1999 | Medial | 12 | 12 | 65.3 | 0.870 | 0.140
de Bie | 1999 | Unilateral | 18 | 6 | 60.6 | 0.590 | -0.130
Desaloms | 1998 | Unilateral | 35 | 12 | 60.0 | 1.120 | -
Dewey | 2000 | Unilateral | 32 | 12 | 61.1 | 0.660 | 0.590
Dogali | 1996 | Unilateral | 33 | 12 | 60.3 | 1.660 | -
Eskandar | 2000 | Mixed | 68 | 24 | 61.0 | 0.200 | -0.100
Herrera | 2000 | Unilateral | 13 | 16 | 60.0 | 0.930 | -
Kondziolka | 1999 | Unilateral | 58 | 9 | 67.0 | 0.750 | 0.280
Lang | 1997 | Unilateral | 39 | 6 | 58.8 | 1.360 | 0.310
Masterman | 1998 | Unilateral | 32 | 6 | 65.0 | 0.420 | 0.430
Melnick | 1999 | Medial | 29 | 6 | 66.4 | 0.580 | -
Samii | 1999 | Unilateral | 20 | 12 | 61.0 | 1.430 | -0.170
Samuel | 1998 | Unilateral | 22 | 3 | 55.9 | 0.480 | 0.000
Shannon | 1998 | Unilateral | 22 | 6 | 59.3 | 0.520 | -0.200
Young | 1998 | Mixed | 17 | 6 | 69.2 | - | 0.200

Evidence Table 13. Statistical Analysis: Deep Brain Stimulation

First Author | Year | Surgical Intervention | Number of Patients | Time of Evaluation (months) | Mean Age (years) | “Off” score Effect Sizes | “On” score Effect Sizes
Ardouin | 1999 | GPi | 8 | 3 | 52.0 | 1.550 | -
Ardouin | 1999 | GPi | 5 | 6 | 55.0 | 0.990 | -
Burchiel | 1999 | GPi | 4 | 12 | 46.5 | 0.940 | 0.662
Krack | 1998 | GPi | 5 | 6 | 51.0 | 1.665 | -0.552
Ardouin | 1999 | STN | 41 | 3 | 54.9 | 2.753 | -
Ardouin | 1999 | STN | 8 | 6 | 53.4 | 1.317 | -
Bejjani | 2000 | STN | 10 | 6 | 54.0 | 3.712 | 2.472
Burchiel | 1999 | STN | 5 | 12 | 62.8 | 0.903 | 1.442
Houeto | 2000 | STN | 23 | 6 | 53.0 | 1.644 | 0.795
Krack | 1998 | STN | 8 | 6 | 51.0 | 3.243 | 0.335
Limousin | 1998 | STN | 20 | 12 | 56.0 | 2.945 | 0.077
Molinuevo | 2000 | STN | 15 | 6 | 60.9 | -0.094 | 0.424
Kumar | 1999 | Thal | 11 | 16 | 71.0 | 0.131 | -
Limousin | 1999 | Thal | 73 | 12 | 61.5 | -0.108 | -

GPi = globus pallidus

STN = subthalamic nucleus

Thal = thalamic

Evidence Table 14. Statistical Analysis: Tissue Transplantation

First Author | Year | Number of Patients | Time of Evaluation (months) | Mean Age (years) | “Off” score Effect Sizes | “On” score Effect Sizes
Fink | 2000 | 12 | 12 | 61.0 | 0.740 | -
Henderson | 1991 | 9 | 12 | 56.0 | 0.480 | -0.030
Kopyov | 1996 | 22 | 24 | 55.0 | 0.830 | 0.830
Kopyov | 1997 | 6 | 6 | 53.0 | - | 1.040
Kopyov | 1997 | 7 | 6 | 60.0 | - | 2.380
Lopez-Lozano | 1997 | 10 | 60 | 61.0 | 1.670 | 1.640

Evidence Table 15. Surgical Studies: Adverse Events*

| Total | | Pallidotomy | | Thalamotomy | | DBS | | Transplant
| % | n | % | n | % | n | % | n | % | n
Deaths | 5.4 | 672 | 3.0 | 398 | 1.5 | 65 | 4.8 | 84 | 15.2 | 125
Treatment Related Deaths | 1.9 | 567 | 1.3 | 307 | 0 | 23 | 1.2 | 82 | 8.2** | 73
Adverse Events
Infections | 7.4 | 122 | 3.6 | 56 | - | NR | 4.2 | 24 | 14.3 | 42
Cardiac | 4.0 | 75 | 5.6 | 18 | 0 | 23 | 4.5 | 22 | 8.3 | 12
Neurological | 6.7 | 668 | 5.3 | 488 | 15.3 | 59 | 8.1 | 111 | 10.0 | 10
Gastrointestinal | 5.0 | 80 | 4.3 | 70 | - | NR | - | NR | 10.0 | 10
Musculoskeletal | 6.3 | 96 | 6.3 | 96 | - | NR | - | NR | - | NR
Neoplasm | 4.1 | 48 | 4.1 | 48 | - | NR | - | NR | - | NR
Psychiatric | 6.9 | 404 | 6.0 | 250 | 8.7 | 23 | 8.3 | 60 | 8.5 | 71
Cerebrovascular | 6.4 | 342 | 7.1 | 237 | 0 | 23 | 4.3 | 46 | 8.3 | 36

* Does not include studies in which adverse events were reported in terms of # of events, rather than # of patients

* Does not include short-term, transient, postoperative adverse events.

** All transplant-related deaths occured in adrenal medulla transplant patients.

n - number of patients in treatment groups reporting event

% - % of patients with event in studies reporting the event

NR - Not Reported

0 - no events were reported and one or more studies reported 0 events

DBS - deep brain stimulation

Infections include pncumonica, sepsis, and nonspecific infections.

Cerebrovascular includes hemorrhage and stroke

Evidence Table 16. Treatment Level Characteristics of Ancillary Studies

Author | Year | Study design | Level of Evidence | Quality Score | n | Duration | Intervention
Adams | 1992 | XS | III | NA | 10 | NA | Speech Therapy
Comella | 1996 | XO-RCT | II | 2 | 18 | 1 month | PT
Dam | 1996 | nRCT | III | NA | 40 | 12 months | PT
DeAngelis | 1997 | UCS | III | NA | 20 | 1 month | Speech Therapy
Formisano | 1992 | nRCT | III | NA | 33 | 4 months | PT
Jahanshahi | 1994 | RCT | II | 1 | 40 | 6 months | NP
Katsikitis | 1996 | RCT | II | 1 | 16 | 1 month | OPT
Mally | 1999 | UCS | III | NA | 10 | 10 days | TMS
Mercer | 1996 | RCT | II | 2 | 50 | 12 months | PROPATH
Montgomery | 1994 | RCT | I | 2 | 400 | 6 months | PROPATH
Nagaya | 2000 | XS | III | NA | 10 | NA | Swallowing Therapy
Pacchetti | 2000 | RCT | II | 1 | 32 | 3 months | PT vs MT
Patti | 1996 | RCT | II | 1 | 20 | 6 months | In-patient Rehab
Platz | 1998 | RCT | II | 1 | 15 | < 1 month | PT
Ramig | 1995 | RCT | II | 2 | 45 | 1 month | LSVT
Ramig | 1996 | RCT | II | 2 | 35 | 12 months | LSVT
Reynolds | 2000 | RCT | I | 2 | 185 | 12 months | NP
Schenkman | 1998 | RCT | II | 2 | 51 | 2.5 months | PT
Sitzia | 1998 | nRCT | III | NA | 60 | 1–2 months | In-patient Rehab
Thaut | 1996 | RCT | II | 1 | 37 | < 1 month | PT (RAS)

Level of Evidence - I–V, I is best

Quality Score - 1–5, 5 is best

n = number of patients

PT = physical therapy

RAS = rhythmic auditory stimulation

LSVT = Lee Silverman Voice Treatment

NP = nurse practitioner

PROPATH = a patient education and health promotion program

OPT = orofacial physiotherapeutic treatment

TMS = transcranial magnetic stimulation

MT = music therapy