# References

1 Tanner C M, Golman S M. Epidemiology of Parkinson's Disease. Neurol Clin. 1996;14:317-35. [pmid: 8827174].
2 Mayeux R, Marder K, Cote L J, et al. The frequency of idiopathic Parkinson's Disease by age, ethnic group, and sex in northern Manhattan, 1988-1993. Am J Epidemiol. 1995;142:820-7. [pmid: 7572958].
3 de Rijk M C, Tzourio C, Breteler M M B, et al. Prevalence of parkinsonism and Parkinson's Disease in Europe: The EUROPARKINSON collaborative study. J Neurol Neurosurg Psychiatry. 1997;62:10-5. [pmid: 9010393].
4 Scheife R T, Schumock G T, Burstein A, et al. Impact of Parkinson's Disease and its pharmacologic treatment on quality of life and economic outcomes. Am J Health-Syst Pharm. 2000;57:953-62. [pmid: 10832495].
5 Zhang Z X, Roman G C. Worldwide occurrence of Parkinson's Disease: An updated review. Neuroepidemiology. 1993;12:195-208. [pmid: 8272179].
6 Louis E D, Marder K, Cote L, et al. Mortality from Parkinson Disease. Arch Neurol. 1997;54:260-4. [pmid: 9074394].
7 Berchou R C. Maximizing the benefit of pharmacotherapy in Parkinson's Disease. Pharmacotherapy. 2000;20:33S-42S. [pmid: 10641990].
8 Dodel R C, Singer M, Kohne-Volland R, et al. The economic impact of Parkinson's Disease. Pharmacoeconomics. 1998;14:299-312. [pmid: 10186468].
9 Agid Y, Ruberg M, Javoy-Agid F, et al. Are dopaminergic neurons selectively vulnerable to Parkinson's Disease?. Adv Neurol. 1993;60:148-64. [pmid: 8420132].
10 Prasad K N, Cole W C, Kumar B. Multiple antioxidants in the prevention and treatment of Parkinson's Disease. J Am Coll Nutr. 1999;18:413-23. [pmid: 10511322].
11 Stoof J C, Winogrodzka A, van Muiswinkel F L, et al. Leads for the development of neuroprotective treatment in Parkinson's Disease and brain imaging methods for estimating treatment efficacy. Eur J Pharmacol. 1999;375:75-86. [pmid: 10443566].
12 Riess O, Jakes R, Kruger R. Genetic dissection of familial Parkinson's Disease. Mol Med Today. 1998;4:438-44. [pmid: 9793932].
13 Veldman B A, Wijn A M, Knoers N, et al. Genetic and environmental risk factors in Parkinson's Disease. Clin Neurol Neurosurg. 1998;100:15-26. [pmid: 9637199].
14 Williams A C, Smith M L, Waring R H, et al. Idiopathic Parkinson's Disease: A genetic and environmental model. Adv Neurol. 1999;80:215-8. [pmid: 10410724].
15 Racette B A, McGee-Minnich L, Moerlein S M, et al. Welding-related parkinsonism. Clinical features, treatment, and pathophysiology. Neurology. 2001;56:8-13. [pmid: 11148228].
16 Semchuk K K M, Love E J, Lee R G. Parkinson's Disease and exposure to agricultural work and pesticide chemicals. Neurology. 1992;42:1328-35. [pmid: 1620342].
17 Hellenbrand W, Seidler A, Robra B P, et al. Smoking and Parkinson's Disease: A case-control study in Germany. Int J Epidemiol. 1997;26:328-39. [pmid: 9169168].
18 Morens D M, Grandinetti A, Davis J W, et al. Evidence against the operation of selective mortality in explaining association between cigarette smoking and reduced occurrence of idiopathic Parkinson Disease. Am J Epidemiol. 1996;144:400-4. [pmid: 8712197].
19 Ross G W, Abbott R D, Petrovitch H, et al. Association of coffee and caffeine intake with the risk of Parkinson's Disease. JAMA. 2000;283:2674-9. [pmid: 10819950].
20 Tzourio C, Rocca W A, Breteler M M B, et al. Smoking and Parkinson's Disease: An age-dependent risk effect?. Neurology. 1997;49:1267-72. [pmid: 9371906].
21 Shults C W, Haas R H, Beal M F. A possible role of coenzyme Q_10_ in the etiology and treatment of Parkinson's Disease. Biofactors. 1999;9:267-72. [pmid: 10416040].
22 de Rijk M C, Breteler M M B, den Breeijen J H, et al. Dietary antioxidants and Parkinson Disease: The Rotterdam Study. Arch Neurol. 1997;54:762-5. [pmid: 9193212].
23 Hellenbrand W, Boeing H, Robra B P, et al. Diet and Parkinson's Disease II: A possible role for past intake of specific nutrients. Results from a self administered food-frequency questionnaire in a case-control study. Neurology. 1996;47:644-50. [pmid: 8797457].
24 Logroscino G, Marder K, Cote T, et al. Dietary lipids and antioxidants in Parkinson's Disease: a population-based, case-control study. Ann Neurol. 1996;39:89-94. [pmid: 8572672].
25 Hellenbrand W, Seidler A, Boeing H, et al. Diet and Parkinson's Disease I: A possible role for past intake of specific foods and food groups. Results from a self administered food-frequency questionnaire in a case-control study. Neurology. 1996;47:636-42. [pmid: 8797456].
26 Gelb D J, Oliver E, Gilman S. Diagnostic Criteria for Parkinson Disease. Arch Neurol. 1999;56:33-9. [pmid: 9923759].
27 Calne D B, Snow B J, Lee C. Criteria for diagnosing Parkinson's Disease. Ann Neurol. 1992;32:S125-7. [pmid: 1510370].
28 Hornykiewicz O. Parkinson's Disease and its chemotherapy. Biochem Pharmacol. 1975;24:1061-5. [pmid: 239718].
29 Hely M A, Fung V S C, Morris J G L. Treatment of Parkinson's Disease. J Clin Neurosci. 2000;7:484-94. [pmid: 11029227].
30 Stroudley J, Walsh M. Radiological assessment of dysphagia in Parkinson's Disease. Br J Radiol. 1991;64:890-3. [pmid: 1954529].
31 Ramig L O, Countryman S, O'Brien C, et al. Intensive speech treatment for patients with Parkinson's Disease: Short- and long-term comparison of two techniques. Neurology. 1996;47:1496-504. [pmid: 8960734].
32 Ramig L O, Sapir S, Fox C, et al. Changes in vocal loudness following intensive voice treatment in individuals with Parkinson's Disease: A comparison with untreated patients and normal age-matched controls. Mov Disord. 2001;16:79-83. [pmid: 11215597].
33 Schulz G M, Grant M K. Effects of speech therapy and pharmacologic and surgical treatments on voice and speech in Parkinson's Disease: A review of the literature. J Commun Disord. 2000;33:59-88. [pmid: 10665513].
34 Razmy A, Shapiro C M. Interactions of sleep and Parkinson's Disease. Semin Clin Neuropsychiatry. 2000;5:20-32. [pmid: 10704535].
35 Marsh L. Neuropsychiatric aspects of Parkinson's Disease. Psychosomatics. 2000;41:15-23. [pmid: 10665264].
36 Mindham R H S. The place of dementia in Parkinson's Disease: A methodologic saga. Parkinson's Disease: Advances in Neurology. 1999;80:403-8.
37 Reid W G J, Hely M A, Morris J G L, et al. A longitudinal study of Parkinson's Disease: Clinical and neuropsychological correlates of dementia. J Clin Neurosci. 1996;3:327-33. [pmid: 18638897].
38 Katzen H L, Levin B E, Llabre M L. Age of disease onset influences cognition in Parkinson's Disease. J Int Neuropsychol Soc. 1998;4:285-90. [pmid: 9623003].
39 Gotham A M, Brown R G, Marsden C D. Depression in Parkinson's Disease: A quantitative and qualitative analysis. J Neurol Neurosurg Psychiatry. 1986;49:381-9. [pmid: 3701347].
40 Ward C D, Gibb W R. Research diagnostic criteria for Parkinson's Disease. Adv Neurol. 1990;53:245-9. [pmid: 2239463].
41 Gibb W R G, Lees A J. The relevance of the Lewy body to the pathogenesis of idiopathic Parkinson's Disease. J Neurol Neurosurg Psychiatry. 1988;51:745-52. [pmid: 2841426].
42 Hughes A J, Daniel S E, Kilford L, et al. Accuracy of clinical diagnosis of idiopathic Parkinson's disease: a clinicopathological study of 100 cases. J Neurol Neurosurg Psychiatry. 1992;55:1142-6. [pmid: 1479392].
43 Hughes A J, Ben-Shlomo Y, Daniel S E. What features improve the accuracy of clinical diagnosis in Parkinson's Disease: A clinicopathologic study. Neurology. 1992;42:1142-6. [pmid: 1603339].
44 Rajput A H, Rodzilsky B, Rajput A. Accuracy of clinical diagnosis of Parkinsonism - a prospective study. Can J Neurol Sci. 1991;18:275-8. [pmid: 1913360].
45 Clarke C E, Davies P. Systematic review of acute L-dopa and apomorphine challenge tests in the diagnosis of idiopathic Parkinson's Disease. J Neurol Neurosurg Psychiatry. 2000;69:590-4. [pmid: 11032609].
46 Brooks D J. PET and SPECT studies in Parkinson's Disease. Baillieres Clin Neurol. 1997;6:69-87. [pmid: 9426869].
47 Antonini A, Leenders K L, Meier D, et al. T_2_ relaxation time in patients with Parkinson's Disease. Neurology. 1993;43:697-700. [pmid: 8469325].
48 Wszolek Z K, Markopoulou K. Olfactory dysfunction in Parkinson's Disease. Clin Neurosci. 1998;5:94-101. [pmcid: 497039].
49 Liberini P, Parola S, Spano P F, et al. Olfaction in Parkinson's Disease: Methods of assessment and clinical relevance. J Neurol. 2000;247:88-96. [pmid: 10751109].
50 Mesholam R I, Moberg P J, Mahr R N, et al. Olfaction in neurodegenerative disease: a meta-analysis of olfactory functioning in Alzheimer's and Parkinson's Diseases. Arch Neurol. 1998;55:84-90. [pmid: 9443714].
51 Horstink MW and Morrish PK. Preclinial diagnosis of Parkinson's Disease. Parkinson's Disease: Advances in Neurology. vol 80, 1999, Philadelphia: Lippincott Williams & Wilkins, pp. 327–33.
52 Stacy M, Jankovic J. Differential diagnosis of Parkinson's Disease and the Parkinsonism plus syndromes. Neurol Clin. 1992;10:341-59. [pmid: 1584178].
53 Fahn S, Marsden CD, Calne DB, et al., eds. Recent Developments in Parkinson's Disease. vol 2. Florham Park, NJ. MacMillan Health Care Information 1987; pp 153–63, 293–304.
54 Martinez-Martin P, Fontan C, Payo B F, et al. Parkinson's Disease: Quantification of disability based on the Unified Parkinson's Disease Rating Scale. Neurologia. 2000;15:382-7. [pmid: 11195144].
55 Martinez-Martin P, Gil-Nagel A, Gracia L M, et al. Unified Parkinson's Disease Rating Scale characteristics and structure. Mov Disord. 1994;9:76-83. [pmid: 8139608].
56 Hoehn M M, Yahr M D. Parkinsonism: Onset, progression, and mortality. Neurology. 1967;17:427-442. [pmid: 6067254].
57 Schwab RS, England AC. Projection technique for evaluating surgery in Parkinson's Disease. In Gillingham FJ, Donaldson IML, eds. Third Symposium of Parkinson's Disease. Edinburgh, Scotland: E&S Livingstone; 1969. p 152–7.
58 Lang A E, Lozano A M. Parkinon's Disease: Second of two parts. N Engl J Med. 1998;339:1130-43. [pmid: 9770561].
59 Hauser R A, Zesiewicz T A. Management of early Parkinson's Disease. Med Clin North Am. 1999;83:393-414. [pmid: 10093585].
60 Simon D K, Standaert D G. Parkinson's Disease and parkinsonian syndromes: Neuroprotective therapies. Med Clin North Am. 1999;83:509-23. [pmid: 10093591].
61 Stacy M. Managing late complications of Parkinson's Disease. Med Clin North Am. 1999;83:469-81. [pmid: 10093588].
62 Fehling C. Treatment of Parkinson's syndrome with L-dopa. A double blind study. Acta Neurol Scand. 1966;42:367-72. [pmid: 5327616].
63 Pincus J H, Barry K. Influence of dietary protein on motor fluctuations in Parkinson's Disease. Arch Neurol. 1987;44:270-2. [pmid: 3827678].
64 Schrag A, Quinn N. Dyskinesias and motor fluctuations in Parkinson's Disease. Brain. 2000;123:2297-305. [pmid: 11050029].
65 Rascol O, Brooks D J, Korczyn A D, et al. A five-year study of the incidence of dyskinesia in patients with early Parkinson's Disease who were treated with ropinirole or levodopa. N Engl J Med. 2000;342:1484-91. [pmid: 10816186].
66 Parkinson Study Group. Pramipexole vs. levodopa as initial treatment for Parkinson's Disease: A randomized controlled trial. JAMA. 2000;284:1931-8. [pmid: 11035889].
67 Agid Y, Ahlskog E, Albanese A, et al. Levodopa in the treatment of Parkinson's Disease: A consensus meeting. Mov Disord. 1999;14:911-13. [pmid: 10584663].
68 Jankovic J. New and emerging therapies for Parkinson Disease. Arch Neurol. 1999;56:785-90. [pmid: 10404979].
69 Mendis T, Suchowersky O, Lang A, et al. Management of Parkinson's Disease: A review of current and new therapies. Can J Neurol Sci. 1999;26:89-103. [pmid: 10352867].
70 Fahn S. Parkinson Disease, the effect of levodopa, and the ELLDOPA trial. Arch Neurol. 1999;56:529-35. [pmid: 10328247].
71 Calne D B, Teychenne P F, Leigh P H N, et al. Treatment of parkinsonism with bromocriptine. Lancet. 1974;2:1355-6. [pmid: 4143315].
72 Ramaker C, Johan W T, van de Beek M S. The efficacy and safety of adjunct bromocriptine therapy for levodopa-induced motor complications: A systematic review. Mov Disord. 2000;15:56-64. [pmid: 10634242].
73 van Hilten JJ, Ramaker C, van de Beek WJT, et al. Bromocriptine for levodopa-induced motor complications in Parkinson's Disease (Cochrane Review). In: The Cochrane Library, Issue 4, 2000. Oxford: Update Software.
74 Montastruc J L, Rascol O, Senard J M. Treatment of Parkinson's Disease should begin with a dopamine agonist. Mov Disord. 1999;14:725-30. [pmid: 10495032].
75 Factor S A. Dopamine agonists. Med Clin North Am. 1999;83:415-43. [pmid: 10093586].
76 Clarke CE, Speller JM. Pergolide for levodopa-induced complications in Parkinson's Disease (Cochrane Review). In: The Cochrane Library, Issue 4, 2000. Oxford: Update Software.
77 Clarke CE, Speller JM. Pergolide versus bromocriptine for levodopa-induced motor complications in Parkinson's Disease (Cochrane Review). In: The Cochrane Library, Issue 4, 2000. Oxford: Update Software.
78 Clarke CE, Speller JM. Lisuride versus bromocriptine for levodopa-induced complications in Parkinson's Disease (Cochrane Review). In: The Cochrane Library, Issue 4, 2000. Oxford: Update Software.
79 Clarke CE, Speller JM. Lisuride for levodopa-induced complications in Parkinson's Disease (Cochrane Review). In: The Cochrane Library, Issue 4, 2000. Oxford: Update Software.
80 Snow B J, Macdonald L, Mcauley D, et al. The effect of amantadine of levodopa-induced dyskinesias in Parkinson's Disease: A double-blind, placebo-controlled study. Clin Neuropharmacol. 2000;23:82-5. [pmid: 10803797].
81 Shoulson I. Parkinson Study Group. Deprenyl and tocopherol antioxidative therapy of parkinsonism (DATATOP). Acta Neurol Scand. 1989;126:171-5.
82 Parkinson Study Group. Effects of tocopherol and deprenyl on the progression of disability in early Parkinson's Disease. N Engl J Med. 1993;328:176-83. [pmid: 8417384].
83 Tatton W G, Wadia J S, Ju W Y, et al. Deprenyl reduces neuronal apoptosis and facilitates neuronal outgrowth by altering protein synthesis without inhibiting monoamine oxidase. J Neural Transm. 1996;48:45-59.
84 Magyar K, Haverle D. Neuroprotective and neuronal rescue effects of selegiline. Neurobiology. 1999;7:175-90. [pmid: 10591051].
85 Jorga K, Fotteler B, Sedek G, et al. The effect of tolcapone on levodopa pharmacokinetics is independent of levodopa/carbidopa formulation. J Neurol. 1998;245:223-30. [pmid: 9591224].
86 Rajput A H, Martin W, Saint-Hilaire M H, et al. Tolcapone improves motor function in parkinsonian patients with the “wearing-off” phenomenon: A double-blind, placebo-controlled, multicenter trial. Neurology. 1997;49:1066-71. [pmid: 9339691].
87 Assal F, Spahr L, Hadengue A, et al. Tolcapone and fulminant hepatitis. Lancet. 1998;352:1478. [pmid: 9808028].
88 Olanow C W. Tolcapone and hepatotoxic effects. Tasmar Advisory Panel. Arch Neurol. 2000;57:263-7. [pmid: 10681087].
89 Martin W E, Loewenson R B, Resch J A, et al. A controlled study comparing trihexyphenidyl hydrochloride plus levodopa with placebo plus levodopa in patients with Parkinson's Disease. Neurology. 1974;24:912-9. [pmid: 4606107].
90 Miller E, Berrios G E, Politynska B. The adverse effect of benzhexol on memory in Parkinson's Disease. Acta Neurol Scand. 1987;76:278-82. [pmid: 3687379].
91 Idanpaan-Heikkila J, Alhava E, Olkinuora M, et al. Agranulocytosis during treatment with clozapine. Eur J Clin Pharmacol. 1977;11:193-8. [pmid: 856603].
92 Lieberman J A, Johns C A, Kane J M, et al. Clozapine-induced agranulocytosis: Non-cross-reactivity with other psychotropic drugs. J Clin Psychiatry. 1988;49:271-7. [pmid: 3391979].
93 Selby G. Stereotactic surgery for the relief of Parkinson's Disease. J Neurol Sci. 1967;5:343-75. [pmid: 4862131].
94 Arle J E, Alterman R L. Surgical options in Parkinson's Disease. Med Clin North Am. 1999;83:483-98. [pmid: 10093589].
95 Uitti R J. Surgical treatments for Parkinson's Disease. Can Fam Phys. 2000;46:368-73.
96 Bronstein J M, DeSalles A, DeLong M R. Stereotactic pallidotomy in the treatment of Parkinson's Disease: An expert opinion. Arch Neurol. 1999;56:1064-9. [pmid: 10488806].
97 Hallett M, Litvan I. Evaluation of surgery for Parkinson's Disease: A report of the Therapeutics and Technology Assessment Subcommittee of the American Academy of Neurology. Neurology. 1999;53:1910-21. [pmid: 10599758].
98 Lozano A M, Lang A E, Galvez-Jiminez N, et al. Effect of GPi pallidotomy on motor function in Parkinson's Disease. Lancet. 1995;346:1383-7. [pmid: 7475819].
99 Fields J A, Troster A I. Cognitive outcomes after deep brain stimulation for Parkinson's Disease: A review of initial studies and recommendations for future research. Brain Cogn. 2000;42:268-93. [pmid: 10744924].
100 Schuurman P R, Bosch D A, Bossuyt P M M, et al. A comparison of continuous thalamic stimulation and thalamotomy for suppression of severe tremor. N Eng J Med. 2000;342:461-8.
101 Koller W C, Pahwa R, Lyons K E, et al. Surgical treatment of Parkinson's Disease. J Neurol Sci. 1999;167:1-10. [pmid: 10500254].
102 Backlund E O, Granberg P O, Hamberger B, et al. Transplantation of adrenal medullary tissue to striatum in parkinsonism: First clinical trials. J Neurosurg. 1985;62:169-73. [pmid: 2578558].
103 Freed C R, Greene P E, Breeze R E, et al. Transplantation of embryonic dopamine neurons for severe Parkinson's Disease. N Engl J Med. 2001;344:710-9. [pmid: 11236774].
104 Langston J W, Widner H, Goetz C G, et al. Core Assessment Program for Intracerebral Transplantations. Mov Disord. 1992;7:2-13. [pmid: 1557062].
105 Defer G L, Widner H, Marie R M, et al. Core Assessment Program for Surgical Interventional Therapies in Parkinson's Disease (CAPSIT-PD). Mov Disord. 1999;14:572-84. [pmid: 10435493].
106 Clarke C E, Zobkiw R M. Quality of life and care in Parkinson's Disease. Brit J Clin Pract. 1995;49:288-93. [pmid: 8554950].
107 Hildick-Smith M. Pragmatic physical therapy in Parkinson's Disease: Any scientific basis?. Parkinson's Disease: Advances in Neurology. 1999;80:561-4.
108 Johnson J A, Pring T R. Speech therapy and Parkinson's Disease: A review and further data. Br J Disord Commun. 1990;25:183-94. [pmid: 2206966].
109 Johnson B T, Qun L, Castell J A, et al. Swallowing and esophageal function in Parkinson's Disease. Amer J Gastroenterol. 1995;90:1741-6. [pmid: 7572887].
110 Mulrow C, Cook D J, Davidoff F. Systematic reviews: critical links in the great chain of evidence. Ann Intern Med. 1997;126:389-91. [pmid: 9054284].
111 Sacks H S, Berrier J, Reitman D, et al. Meta-analyses of randomized controlled trials. N Engl J Med. 1987;316:450-5. [pmid: 3807986].
112 Jadad A R, Moore A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: Is blinding necessary?. Controlled Clinical Trials. 1996;17:1-12. [pmid: 8721797].
113 Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. CMAJ 1998: 158.
114 Hely M A, Chey T, Wilson A, et al. Reliability of the Columbia scale for assessing signs of Parkinson's Disease. Mov Disord. 1993;8:466-72. [pmid: 8232356].
115 Canter G J, deLaTorre R, Mier M. A method for evaluating disability in patients with Parkinson's Disease. J Nerv Ment Dis. 1961;133:143-7. [pmid: 13876261].
116 Hedges L, Olkin I. Statistical Methods for Meta-Analysis. 1985. New York: Academic Press.
117 Raudenbush SW. The Handbook of Research Synthesis. New York: Russell Sage Foundation; 1994. Chapter 20, Random Effects Models.
118 Hedges LV. The Handbook of Research Synthesis. New York: Russell Sage Foundation; 1994. Chapter 19, Fixed Effects Models.
119 Bromocriptine Multicentre Trial Group. Bromocriptine as initial therapy in elderly parkinsonian patients. Age Aging. 1990;19:62-7.
120 Irwig L, Tosteson A N A, Gatsonis C, et al. Guidelines for meta-analyses evaluating diagnostic tests. Ann Intern Med. 1994;120:667-76. [pmid: 8135452].
121 D'Costa D F, Abbot R J, Pye I F, et al. The apomorphine test in parkinsonian syndromes. J Neurol Neurosurg Psychiatry. 1991;10:870-2. [pmid: 1744640].
122 Hughes A J, Lees A J, Stern G M. Apomorphine test to predict dopaminergic responsiveness in parkinsonian syndromes. Lancet. 1990;336:32-4. [pmid: 1973218].
123 Hughes A J, Lees A J, Stern G M. Challenge tests to predict the dopaminergic response in untreated Parkinson's Disease. Neurology. 1991;41:1723-5. [pmid: 1944899].
124 Gasser T, Schwarz J, Arnold G, et al. Apomorphine test for dopaminergic responsiveness in patients with previously untreated Parkinson's Disease. Arch Neurol. 1992;49:1131-4. [pmid: 1444878].
125 Bonucelli U, Picini P, Del Dotto P, et al. Apomorphine test for dopaminergic responsiveness: A dose assessment study. Mov Disord. 1993;8:158-64. [pmid: 8474482].
126 Schwarz J, Linke R, Kerner M, et al. Striatal dopamine transporter binding assessed by [I-123_IPT and single photon emission computed tomography in patients with early Parkinson' Disease: Implications for a preclinical diagnosis. Arch Neurol. 2000;57:205-8. [pmid: 10681078].
127 Schwarz J, Kraft E, Vogl T, et al. Relative quantification of signal on T2-weighted images in the basal ganglia: Limited value in differential diagnosis of patients with parkinsonism. Neuroradiology. 1999;41:124-7. [pmid: 10090605].
128 Schwarz J, Tatsch K, Gasser T, et al. ^123^I-IBZM binding compared with long-term clinical follow up in patients with de novo parkinsonism. Mov Disord. 1998;13:16-9. [pmid: 9452320].
129 Schwarz J, Antonini A, Tatsch K, et al. Comparison of ^123^I-IBZM SPECT and ^11^C-raclopride PET findings in patients with parkinsonism. Nucl Med Commun. 1994;15:806-13. [pmid: 7838444].
130 Schwarz J, Tatsch K, Arnold G, et al. ^123^I-iodobenzamide-SPECT in 83 patients with de novo parkinsonism. Neurology. 1993;43:S17-20. [pmid: 8264906].
131 Schwarz J, Tatsch K, Gasser T, et al. [^123^]IBZM binding predicts dopaminergic responsiveness in patients with parkinsonism and previous dopaminomimetic therapy. Mov Disord. 1997;12:898-902. [pmid: 9399212].
132 Schelosky L, Hierholzer J, Wissel J, et al. Correlation of clinical response in apomorphine test with D_2_ receptor status as demonstrated by ^123^I IBZM-SPECT. Mov Disord. 1993;8:453-8. [pmid: 8232354].
133 Booij J, Tissingh G, Boer G J, et al. [^123^I]FP-CIT SPECT shows a pronounced decline of striatal dopamine transporter labelling in early and advanced Parkinson's Disease. J Neurol Neurosurg Psychiatry. 1997;62:133-40. [pmid: 9048712].
134 Tatsch K, Schwarz J, Oertel W H, et al. SPECT imaging of dopamine D2 receptors with ^123^I-IBZM: Initial experience in controls and patients with Parkinson's syndrome and Wilson's disease. Nucl Med Commun. 1991;12:699-707. [pmid: 1838142].
135 Giobbe D, Castellano G C, Podio V. Dopamine D2 receptor imaging with SPECT using IBZM in 16 patients with Parkinson's Disease. Ital J Neurol Sci. 1993;14:165-9. [pmid: 8509271].
136 Pizzolato G, Cagnin A, Rossato A, et al. Striatal dopamine D2 receptor alterations and response to L-dopa in Parkinson's Disease. Adv Neurol. 1996;69:467-73. [pmid: 8615167].
137 Imon Y, Matsuda H, Ogawa M, et al. SPECT image analysis using statistical parametric mapping in patients with Parkinson's Disease. J Nucl Med. 1999;40:1583-9. [pmid: 10520695].
138 Seibyl J P, Marek K L, Quinlan D, et al. Decreased single-photon emission computed tomographic [^123^I]β-CIT striatal uptake correlates with symptom severity in Parkinson's Disease. Ann Neurol. 1995;38:589-98. [pmid: 7574455].
139 Kaasinen V, Nagren K, Hietala J, et al. Extrastriatal dopamine D2 and D3 receptors in early and advanced Parkinson's Disease. Neurology. 2000;54:1482-7. [pmid: 10751262].
140 Rinne J O, Portin R, Ruottinen H, et al. Cognitive impairment and the brain dopaminergic system in Parkinson's Disease: [^18^F]fluorodopa positron emission tomographic study. Arch Neurol. 2000;57:470-5. [pmid: 10768619].
141 Rinne J O, Laihinen A, Ruottinen H, et al. Increased density of dopamine D2 receptors in the putamen, but not in the caudate nucleus in earl Parkinson's Disease: A PET study with [^11^C] raclopride. J Neurol Sci. 1995;132:156-61. [pmid: 8543941].
142 Burn D J, Sawle G V, Brooks D J. Differential diagnosis of Parkinson's Disease, multiple system atrophy, and Steele-Richardson-Olszewski syndrome: discriminant analysis of striatal ^18^F-dopa PET data. J Neurol Neurosurg Psychiatry. 1994;57:278-84. [pmid: 8158173].
143 Morrish P K, Sawle G V, Brooks D J. Clinical and [^18^F] dopa PET findings in early Parkinson's Disease. J Neurol Neurosurg Psychiatry. 1995;59:597-600. [pmid: 7500096].
144 Sawle G V, Playford E D, Burn D J, et al. Separating Parkinson's Disease from normality. Discriminant functin analysis of flurodopa F 18 positron emission tomography data. Arch Neurol. 1994;51:237-43. [pmid: 8129633].
145 Eidelberg D, Moeller J R, Ishikawa T, et al. Early differential diagnosis of Parkinson's Disease with18F-fluorodeoxyglucose and positron emission tomography. Neurology. 1995;45:1995-2004. [pmid: 7501148].
146 Otsuka M, Ichiya Y, Hosokawa S, et al. Striatal blood flow, glucose metabolism and 18F-Dopa uptake: Difference in Parkinson's Disease and atypical parkinsonism. J Neurol Neurosurg Psychiatry. 1991;54:898-904. [pmid: 1744644].
147 Kraft E, Schwarz J, Trenkwalder C, et al. The combination of hypointense and hyperintense signal changes on T_2_-weighted magnetic resonance imaging sequences: A specific marker of multiple system atrophy?. Arch Neurol. 1999;56:225-8. [pmid: 10025428].
148 Ryvlin P, Broussole E, Piollet H, et al. Magnetic resonance imaging evidence of decreased putamenal iron content in idiopathic Parkinson's Disease. Arch Neurol. 1995;52:583-8. [pmid: 7763206].
149 Holshouser B A, Komu M, Moller H E, et al. Localized proton NMR spectroscopy in the striatum of patients with idiopathic Parkinson's Disease: A multicenter pilot study. Magn Reson Med. 1995;33:589-94. [pmid: 7596261].
150 Becker G, Seufert J, Bogdahn U, et al. Degeneration of substantia nigra in chronic Parkinson's Disease visualized by transcranial color-coded real-time sonography. Neurology. 1995;45:182-4. [pmid: 7824114].
151 Meara J, Bhowmick B K, Hobson P. Accuracy of diagnosis in patients with presumed Parkinson's Disease. Age Ageing. 1999;28:99-102. [pmid: 10350403].
152 Jankovic J, Rajput A H, McDermott M P, et al. The evolution of diagnosis in early Parkinson Disease. Arch Neurol. 2000;57:369-72. [pmid: 10714663].
153 Buttner T, Kuhn W, Muller T, et al. Distorted color discrimination in de novo parkinsonian patients. Neurology. 1995;45:386-7. [pmid: 7854545].
154 Buttner T, Kuhn W, Patzold T, et al. L-dopa improves color vision in Parkinson's Disease. J Neural Transm. 1994;7:13-9.
155 Delalande I, Destee A, Hache J C, et al. Visual evoked potentials and spatiotemporal contrast sensitivity changes in idiopathic Parkinson's Disease and multiple system atrophy. Adv Neurol. 1996;69:319-25. [pmid: 8615146].
156 Relja M A, Petravic D, Kolaj M. Quantifying rigidity with a new computerized elbow device. Clin Neuropharmacol. 1996;19:148-56. [pmid: 8777768].
157 Fung V S C, Burne J A, Morris J G L. Objective quantification of resting and activated parkinsonian rigidity: A comparison of angular impulse and work scores. Mov Disord. 2000;15:48-55. [pmid: 10634241].
158 Caronti B, Tanda G, Colosimo C, et al. Reduced dopamine in peripheral blood lymphocytes in Parkinson's Disease. NeuroReport. 1999;10:2907-10. [pmid: 10549795].
159 Arnold G, Bondy B, Bandmann O, et al. 3H-spiperone binding to lymphocytes fails in the differential diagnosis of de novo Parkinson syncromes. J Neral Transm. 1993;5:107-16.
160 Bellomo G, Santambrogio L, Fiacconi M, et al. Plasma profiles of adrenocorticotropic hormone, cortisol, growth hormone and prolactin in patients with untreated Parkinson's Disease. J Neurol. 1991;238:19-22. [pmid: 1851513].
161 Espino A, Calopa M, Ambrosio S, et al. CSF somatostatin increase in patients with early parkinsonian syndrome. J Neural Transm. 1995;9:189-96.
162 Jiminez-Jiminez F J, Rubio J C, Molina J A, et al. Cerebrospinal fluid carnitine levels in patients with Parkinson's Disease. J Neurol Sci. 1997;145:183-5. [pmid: 9094047].
163 Murofushi T, Mizuno M, Osanai R, et al. Olfactory dysfunction in Parkinson's Disease. J Otorhinol Relat Spec. 1991;53:143-6.
164 Sakuma K, Nakashima K, Takahashi K. Olfactory evoked potentials in Parkinson's Disease, Alzheimer's disease, and anosmic patients. Psychiatry Clin Neurosci. 1996;50:35-40. [pmid: 9201769].
165 Doty R L, Stern M B, Pfeiffer C, et al. Bilateral olfactory dysfunction in early stage treated and untreated idiopathic Parkinson's Disease. J Neurol Neurosurg Psychiatry. 1992;55:138-42. [pmid: 1538221].
166 Doty R L, Golbe L I, McKeown B A, et al. Olfactory testing differentiates between progressive supranuclear palsy and idiopathic Parkinson's Disease. Neurology. 1993;43:962-5. [pmid: 8492953].
167 Hawkes C H, Shephard B C. Olfactory evoked responses and identification tests in neurological disease. Ann NY Acad Sci. 1998;855:608-15. [pmid: 9929657].
168 Potagas C, Dellatolas G, Ziegler M, et al. Clinical assessment of olfactory dysfunction in Parkinson's Disease. Mov Disord. 1998;13:394-9. [pmid: 9613727].
169 Lehrner J P, Brucke T, Dal-Bianco P, et al. Olfactory functions in Parkinson's Disease and Alzheimer's Disease. Chem Senses. 1997;22:105-10. [pmid: 9056090].
170 Montgomery E B, Koller W C, LaMantia T J K, et al. Early detection of probable idiopathic Parkinson's Disease: I. Development of a diagnostic test battery. Mov Disord. 2000;15:467-73. [pmid: 10830410].
171 Montgomery E B, Lyons K, Koller W D. Early detection of probable idiopathic Parkinson's Disease: II. A prospective application of a diagnostic test battery. Mov Disord. 2000;15:474-8. [pmid: 10830411].
172 Montgomery E B, Baker K B, Lyons K, et al. Abnormal performance on the PD test battery by asymptomatic first-degree relatives. Neurology. 1999;52:757-62. [pmid: 10078723].
173 Rajput A H, Rozdilsky B, Ang L. Occurrence of resting tremor in Parkinson's Disease. Neurology. 1991;41:1298-9. [pmid: 1866022].
174 Litvan I, MacIntyre A, Goetz C G, et al. Accuracy of the clinical diagnoses of Lewy Body Disease, Parkinson Disease, and dementia with Lewy bodies: A clinicopathologic study. Arch Neurol. 1998;55:969-78. [pmid: 9678315].
175 Louis E K, Klatka L A, Liu Y, et al. Comparison of extrapyramidal features in 31 pathologically confirmed cases of diffuse Lewy body disease and 34 pathologically confirmed cases of Parkinson's Disease. Neurology. 1997;48:376-80. [pmid: 9040725].
176 Wenning G K, Ebersbach G, Verny M, et al. Progression of falls in postmortem-confirmed parkinsonian disorders. Mov Disord. 1999;14:947-50. [pmid: 10584668].
177 Parkinson Study Group. Entcapone improves motor fluctuations in levodopa-treated Parkinson's Disease patients. Ann Neurol. 1997;42:747-55. [pmid: 9392574].
178 Allain H, Destee A, Petit H, et al. Five-year follow-up of early lisuride and levodopa combination therapy versus levodopa monotherapy in de novo Parkinson's Disease. Eur Neurol. 2000;44:22-30. [pmid: 10894991].
179 Baas H, Beiske A G, Ghika J, et al. Catechol-O-methyltransferase inhibition with tolcapone reduces the “wearing off” phenomenon and levodopa requirements in fluctuating parkinsonian patients. J Neurol Neurosurg Psychiatry. 1997;63:421-8. [pmid: 9343116].
180 Kulisevsky J, Garcia-Sanches C, Berthier M L, et al. Chronic effects of dopaminergic replacement on cognitive function in Parkinson's Disease. A two-year follow-up study of previously untreated patients. Mov Disord. 2000;15:613-26. [pmid: 10928571].
181 Larsen J P, Boas J, Erdal J E, et al. Does selegiline modify the progression of early Parkinson's Disease? Results from a five-year study. Eur J Neurol. 1999;6:539-47. [pmid: 10457386].
182 Lieberman A, Ranhosky A, Korts D. Clinical evaluation of pramipexole in advanced Parkinson's Disease: Results of a double-blind, placebo-controlled, parallel-group study. Neurology. 1997;49:162-8. [pmid: 9222185].
183 Olanow C W, Fahn S, Muenter M, et al. A multicenter double-blind placebo-controlled trial of pergolide as an adjunct to Sinemet in Parkinson's Disease. Mov Disord. 1994;9:40-7. [pmid: 8139604].
184 Kunig G, Pogarell O, Moller J C, et al. Pramipexole, a nonergot dopamine agonist, is effective against rest tremor in intermediate to advanced Parkinson's Disease. Clin Neuropharmacol. 1999;22:301-5. [pmid: 10516884].
185 Steiger M J, El-Debas T, Anderson T, et al. Double-blind study of the activity and tolerability of cabergoline versus placebo in parkinsonians with motor fluctuations. J Neurol. 1996;243:68-72. [pmid: 8869390].
186 Guttman M. Double-blind comparison of pramipexole and bromocriptine treatment with placebo in advanced Parkinson's Disease. Neurology. 1997;49:1060-5. [pmid: 9339690].
187 Martignoni E, Pachetti C, Sibilla L, et al. Dihydroergocryptine in the treatment of Parkinson's Disease: A six months' double-blind clinical trial. Clin Neuropharmacol. 1991;14:78-83. [pmid: 1903079].
188 Olsson J E. Bromocriptine and levodopa in early combination in Parkinson's Disease: First results of the collaborative European multicentric trial. Adv Neurol. 1990;53:421-3. [pmid: 2239483].
189 Waters C H, Kurth M, Bailey P, et al. Tolcapone in stable Parkinson's Disease: Efficacy and safety of long-term treatment. Neurology. 1997;49:665-71. [pmid: 9305320].
190 Hutton J T, Koller W C, Ahlskog J E, et al. Multicenter, placebo-controlled trial of cabergoline taken once daily in the treatment of Parkinson's Disease. Neurology. 1996;46:1062-5. [pmid: 8780092].
191 Inzelberg R, Nisipeanu P, Rabey J M, et al. Double-blind comparison of cabergoline aned bromocriptine in Parkinson's Disease patients with motor fluctuations. Neurology. 1996;47:785-8. [pmid: 8797480].
192 MacMahon D G, Overstall P W, Marshall T. Simplification of the initiation of bromocriptine in elderly patients with advanced Parkinson's Disease. Age Ageing. 1991;20:146-51. [pmid: 2053506].
193 Rabey J M, Streifler M, Treves T, et al. The beneficial effect of chronic lisuride administration compared with levodopa in Parkinson's Disease. Adv Neurol. 1990;53:451-5. [pmid: 2122652].
194 Wolters E C, Tesselaar H J. International (NL-UK) double-blind study of Sinemet CR and standard Sinemet (25/100) in 170 patients with fluctuating Parkinson's Disease. J Neurol. 1996;243:235-40. [pmid: 8936353].
195 Alarcon F. Does combined levodopa and bromocriptine therapy in Parkinson's Disease prevent late motor complications?. Eur J Neurol. 1998;5:255-63. [pmid: 10210840].
196 Bergamasco B, Frattola L, Muratorio A, et al. Alpha-dihydroergocryptine in the treatment of de novo parkinsonian patients: Results of a multicentre, randomized, double-blind, placebo-controlled study. Acta Neurol. 2000;101:372-80.
197 Dupont E, Andersen A, Boas J, et al. Sustained-release Madopar HBS compared with standard Madopar in the long-term treatment of de novo parkinsonian patients. Acta Neurol Scand. 1996;93:14-20. [pmid: 8825266].
198 Koller W C, Hutton J T, Tolosa E, et al. Immediate-release and controlled-release carbidopa/levodopa in PD: A 5-year randomized multicenter study. Neurology. 1999;53:1012-9. [pmid: 10496260].
199 Montastruc J L, Rascol O, Senard J M, et al. A randomised controlled study comparing bromocriptine to which levodopa was later added, with levodopa alone in previously untreated patients with Parkinson's Disease: A five year follow up. J Neurol Neurosurg Psychiatry. 1994;57:1034-8. [pmid: 8089666].
200 Myllyla V V, Sotaniemi K A, Vuorinen J A, et al. Selegiline as initial treatment in de novo parkinsonian patients. Neurology. 1992;42:339-43. [pmid: 1736162].
201 Nappi G, Martignoni E, Horowski R, et al. Lisuride plus selegiline in the treatment of early Parkinson's Disease. Acta Neurol Scand. 1991;83:407-10. [pmid: 1909485].
202 Palhagen S, Heinonen E H, Hagglund J, et al. Selegiline delays the onset of disability in de novo parkinsonian patients. Neurology. 1998;51:520-5. [pmid: 9710028].
203 Rinne U K, Bracco F, Chouza C, et al. Early treatment of Parkinson's Disease with cabergoline delays the onset of motor complications. Results of a double-blind levodopa controlled trial. Drugs. 1998;55:23-30. [pmid: 9483167].
204 Weiner W J, Factor S A, Sanchez-Ramos J R, et al. Early combination therapy (bromocriptine and levodopa) does not prevent motor fluctuations in Parkinson's Disease. Neurology. 1993;43:21-7. [pmid: 8423888].
205 Hely M A, Morris J G, Reid W G, et al. The Sydney multicentre study of Parkinson's Disease: A randomised, prospective five-year study comparing low dose bromocriptine with low dose levodopa-carbidopa. J Neurol Neurosurg Psychiatry. 1994;57:903-10. [pmid: 8057111].
206 Korczyn A D, Brunt E R, Larsen J P, et al. A 3-year randomized trial of ropinirole and bromocriptine in early Parkinson's Disease. Neurology. 1999;53:364-70. [pmid: 10430427].
207 Lees A J. Parkinson's Disease Research Group in the United Kingdom. Comparison of therapeutic effects and mortality data of levodopa and levodopa combined with selegiline in patients with early, mild Parkinson's Disease. BMJ. 1995;311:1602-7. [pmid: 8555803].
208 Olanow C W, Hauser R A, Gauger L, et al. The effect of deprenyl and levodopa on the progression of Parkinson's Disease. Ann Neurol. 1995;38:771-7. [pmid: 7486869].
209 Przuntek H, Welzel D, Gerlach M, et al. Early institution of bromocriptine in Parkinson's Disease inhibits the emergence of levodopa-associated motor side effects. Long-term results of the PRADO study. J Neural Transm Park Dis Dement Sect. 1996;103:699-715.
210 Przuntek H, Conrad B, Dichgans J, et al. SELEDO: A 5-year long-term trial on the effect of selegiline in early parkinsonian patients treated with levodopa. Eur J Neurol. 1999;6:141-50. [pmid: 10053226].
211 Parkinson Study Group. Effect of lazabemide on the progression of disability in early Parkinson's Disease. Ann Neurol. 1996;40:99-107. [pmid: 8687199].
212 Sethi K D, O'Brien C F, Hammerstad J P, et al. Ropinirole for the treatment of early Parkinson Disease: A 12-month experience. Arch Neurol. 1998;55:1211-6. [pmid: 9740115].
213 Shannon K M, Bennett J P J, Friedman J H. Efficacy of pramipexole, a novel dopamine agonist, as monotherapy in mild to moderate Parkinson's Disease. Neurology. 1997;49:724-8. [pmid: 9305331].
214 Bakheit A M, Henderson L M, Moore A P, et al. Long-term double masked trial of early treatment with L-dopa plus bromocriptine versus L-dopa alone in Parkinson's Disease. Interim results. Eur Neurol. 1990;30:108-11. [pmid: 2340834].
215 Giminez-Roldan S, Tolosa E, Burguera J A, et al. Early combination of bromocriptine and levodopa in Parkinson's Disease: A prospective randomized study of two parallel groups over a total follow-up period of 44 months including an initial 8-month double-blind stage. Clin Neuropharmacol. 1997;20:67-76. [pmid: 9037575].
216 Nakanishi T, Iwata M, Goto I, et al. Nation-wide collaborative study on the long-term effects of bromocriptine in the treatment of parkinsonian patients. Final report. Eur Neurol. 1992;32:9-22. [pmid: 1425821].
217 Kleedorfer B, Poewe W. Comparative efficacy of two oral sustained-release preparations of L-dopa in fluctuating Parkinson's Disease. Preliminary findings in 20 patients. J Neural Transm [P-D Sect]. 1992;4:173-8.
218 Stocchi F, Bramante L, Monge A, et al. Apomorphine and lisuride infusion. A comparative chronic study. Adv Neurol. 1993;60:653-5. [pmid: 8420205].
219 Lieberman A, Olanow C W, Sethi K, et al. A multicenter trial of ropinirole as adjunct treatment for Parkinson's Disease. Neurology. 1998;51:1057-62. [pmid: 9781529].
220 Rinne U K, Larsen J P, Siden A, et al. Entcapone enhances the response to levodopa in parkinsonian patients with motor fluctuations. Neurology. 1998;51:1309-14. [pmid: 9818851].
221 de Bie R M A, de Haan R J, Nijssen P C G, et al. Unilateral pallidotomy in Parkinson's Disease: A randomised, single-blind, multicentre trial. Lancet. 1999;354:1665-9. [pmid: 10568567].
222 Young R F, Shumway-Cook A, Vermeulen S S, et al. Gamma knife radiosurgery as a lesioning technique in movement disorder surgery. J Neurosurg. 1998;89:183-93. [pmid: 9688111].
223 Baron M S, Vitek J L, Bakay R A E, et al. Treatment of advanced Parkinson's Disease by unilateral posterior GPi pallidotomy: 4-year results of a pilot study. Mov Disord. 2000;15:230-7. [pmid: 10752571].
224 Dalvi A, Winfield L, Yu Q, et al. Stereotactic posteroventral pallidotomy: Clinical methods and results at 1-year follow up. Mov Disord. 1999;14:256-61. [pmid: 10091619].
225 Desaloms J M, Krauss J K, Lai E C, et al. Posteroventral medial pallidotomy for treatment of Parkinson's Disease: Preoperative magnetic resonance imaging features and clinical outcome. J Neurosurg. 1998;89:194-9. [pmid: 9688112].
226 Dewey R B, Giller C A, Broline S K, et al. Clinical outcome of unilateral stereotactic pallidotomy without microelectrode recording for intractable Parkinson's Disease. Parkinsonism Relat. 2000;6:7-16.
227 Dogali M, Sterio D, Fazzini E, et al. Effects of posteroventral pallidotomy on Parkinson's Disease. Adv Neurol. 1996;69:585-90. [pmid: 8615183].
228 Eskandar E N, Shinobu L A, Penney J B, et al. Stereotactic pallidotomy performed without using microelectrode guidance in patients with Parkinson's Disease: Surgical technique and 2-year results. J Neurosurg. 2000;92:375-83. [pmid: 10701522].
229 Herrera E J, Viano J C, Caceres M, et al. Posteroventral pallidotomy in Parkinson's Disease. Acta Neurochir (Wien). 2000;142:169-75. [pmcid: 300905]. [pmid: 10795891].
230 Iacono R P, Shima F, Lonser R R, et al. The results, indications, and physiology of posteroventral pallidotomy for patients with Parkinson's Disease. Neurosurgery. 1995;36:1118-27. [pmid: 7643990].
231 Johansson F, Malm J, Nordh E, et al. Usefulness of pallidotomy in advanced Parkinson's Disease. J Neurol Neurosurg Psychiatry. 1997;62:125-32. [pmid: 9048711].
232 Kondziolka D, Bonaroti E, Baser S, et al. Outcomes after stereotactically guided pallidotomy for advanced Parkinson's Disease. J Neurosurg. 1999;90:197-202. [pmid: 9950488].
233 Lang A E, Lozano A M, Montgomery E, et al. Posteroventral medial pallidotomy in advanced Parkinson's Disease. N Engl J Med. 1997;337:1036-42. [pmid: 9321531].
234 Masterman D, DeSalles A, Baloh R W, et al. Motor, cognitive, and behavioral performance following unilateral ventroposterior pallidotomy for Parkinson Disease. Arch Neurol. 1998;55:1201-8. [pmid: 9740114].
235 Melnick M E, Dowling G A, Aminoff M J, et al. Effect of pallidotomy on postural control and motor function in Parkinson Disease. Arch Neurol. 1999;56:1361-5. [pmid: 10555656].
236 Roberts-Warrior D, Overby A, Jankovic J, et al. Postural control in Parkinsn's Disease after unilateral posteroventral pallidotomy. Brain. 2000;123:2141-9. [pmid: 11004130].
237 Samii A, Turnbull I M, Kishore A, et al. Reassessment of unilateral pallidotomy in Parkinson's Disease. A 2-year follow-up study. Brain. 1999;122:417-25. [pmid: 10094251].
238 Samuel M, Caputo E, Brooks D J, et al. A study of medial pallidotomy for Parkinson's Disease: Clinical outcome, MRI location and complications. Brain. 1998;121:59-75. [pmid: 9549488].
239 Shannon K M, Penn R D, Kroin J S, et al. Stereotactic pallidotomy for the treatment of Parkinson's Disease. Efficacy and adverse effects at 6 months in 26 patients. Neurology. 1998;50:434-8. [pmid: 9484368].
240 Taha J M, Favre J, Baumann T K, et al. Tremor control after pallidotomy in patients with Parkinson's Disease: Correlation with microrecording findings. J Neurosurg. 1997;86:642-7. [pmid: 9120628].
241 Diederich N, Goetz C G, Stebbins G T, et al. Blinded evaluation confirms long-term asymmetric effect of unilateral thalamotomy or subthalamotomy on tremor in Parkinson's Disease. Neurology. 1992;42:1311-4. [pmid: 1620340].
242 Fox M W, Ahlskog J E, Kelly P J. Stereotactic ventrolateralis thalamotomy for medically refractory tremor in post-levodopa era Parkinson's Disease patients. J Neurosurg. 1991;75:723-30. [pmid: 1919694].
243 Jankovic J, Hamilton W J, Grossman R G. Thalamic surgery for movement disorders. Adv Neurol. 1997;74:221-3. [pmid: 9348417].
244 Ardouin C, Pillon B, Peiffer E, et al. Bilateral subthalamic or pallidal stimulation for Parkinson's Disease affects neither memory nor executive functions: A consecutive series of 62 patients. Ann Neurol. 1999;46:217-23. [pmid: 10443887].
245 Bejjani B P, Gervais D, Arnulf I, et al. Axial parkinsonian symptoms can be improved: The role of levodopa and bilateral subthalamic stimulation. J Neurol Neurosurg Psychiatry. 2000;68:595-600. [pmid: 10766889].
246 Burchiel K J, Anderson V C, Favre J, et al. Comparison of pallidal and subthalamic nucleus deep brain stimulation for advanced Parkinson's Disease: Results of a randomized, blinded pilot study. Neurosurgery. 1999;45:1375-82. [pmid: 10598706].
247 Houeto J L, Damier P, Bejjani P B, et al. Subthalamic stimulation in Parkinson Disease: A multidisciplinary approach. Arch Neurol. 2000;57:461-5. [pmid: 10768618].
248 Krack P, Pollak P, Limousin P, et al. Subthalamic nucleus or internal pallidal stimulation in young onset Parkinson's Disease. Brain. 1998;121:451-7. [pmid: 9549521].
249 Limousin P, Krack P, Pollak P, et al. Electrical stimulation of the subthalamic nucleus in advanced Parkinson's Disease. N Engl J Med. 1998;339:1105-11. [pmid: 9770557].
250 Molinuevo J L, Valldeoriola F, Tolosa E, et al. Levodopa withdrawal after bilateral subthalamic nucleus stimulation in advanced Parkinson Disease. Arch Neurol. 2000;57:983-8. [pmid: 10891980].
251 Koller W, Pahwa R, Busenbark K, et al. High-frequency unilateral thalamic stimulation in the treatment of essential and parkinsonian tremor. Ann Neurol. 1997;42:292-9. [pmid: 9307249].
252 Kumar K, Kelly M, Toth C. Deep brain stimulation of the ventral intermediate nucleus of the thalamus for control of tremors in Parkinson's Disease and essential tremor. Stereotact Funct Neurosurg. 1999;72:47-61. [pmid: 10640920].
253 Limousin P, Speelman J D, Gielen F, et al. Multicentre European study of thalamic stimulation in parkinsonian and essential tremor. J Neurol Neurosurg Psychiatry. 1999;66:289-96. [pmid: 10084526].
254 Goetz C G, Stebbins G E, Klawans H L, et al. United Parkinson Foundation Neurotransplantation Registry on adrenal medullary transplants: presurgical, and 1- and 2-year follow-up. Neurology. 1991;41:1719-22. [pmid: 1944898].
255 Lopez-Lozano J J, Bravo G, Abascal J, et al. Grafting of perfused adrenal medullary tissue into the caudate nucleus of patients with Parkinson's Disease. J Neurosurg. 1991;75:234-43. [pmid: 2072160].
256 Velasco F, Velasco M, Rodriguez Cuevas H, et al. Autologous adrenal medullary transplants in advanced Parkinson's Disease with particular attention to the selective improvement in symptoms. Stereotact Funct Neurosurg. 1991;57:195-212. [pmid: 1842977].
257 Henderson B T, Clough C G, Hughes R C, et al. Implantation of human fetal ventral mesencephalon to the right caudate nucleus in advanced Parkinson's Disease. Arch Neurol. 1991;48:822-7. [pmid: 1898256].
258 Kopyov O V, Jacques D, Lieberman A, et al. Clinical study of fetal mesencephalic intracerebral transplants for the treatment of Parkinson's Disease. Cell Transplant. 1996;5:327-37. [pmid: 8689043].
259 Kopyov O V, Jacques D S, Lieberman A, et al. Outcome following intrastriatal fetal mesencephalic grafts for Parkinson's patients is directly related to the volume of grafted tissue. Exp Neurol. 1997;146:536-45. [pmid: 9270065].
260 Lopez-Lozano J J, Bravo G, Brera B, et al. Long-term improvement in patients with severe Parkinson's Disease after implantation of fetal ventral mesencephalic tissue in a cavity of the caudate nucleus: 5-year follow up in 10 patients. J Neurosurg. 1997;86:931-42. [pmid: 9171171].
261 Fink J S, Schumacher J M, Ellias S L, et al. Porcine xenografts in Parkinson's Disease and Huntington's Disease patients: Preliminary results. Cell Transplant. 2000;9:273-8. [pmid: 10811399].
262 Wermuth L, Sorensen P S, Timm B, et al. Depression in idiopathic Parkinson's Disease treated with citalopram. Nord J Psychiatry. 1998;52:163-9.
263 Sano M, Stern Y, Marder K, et al. A controlled trial of piracetam in intellectually impaired patients with Parkinson's Disease. Mov Disord. 1990;5:230-4. [pmid: 2388639].
264 Factor S A, Brown D, Molho E S, et al. Clozapine: A two-year open trial in Parkinson's Disease patients with psychosis. Neurology. 1994;44:544-6. [pmid: 8145929].
265 Kahn N, Freeman A, Juncos J L, et al. Clozapine is beneficial for psychosis in Parkinson's Disease. Neurology. 1991;41:1699-700. [pmid: 1922830].
266 Rabey J M, Treves T A, Neufeld M Y. Low-dose clozapine in the treatment of levodopa-induced mental disturbances in Parkinson's Disease. Neurology. 1995;45:432-4. [pmid: 7898690].
267 Ruggieri S, DePandis M F, Bonamartini A, et al. Low dose of clozapine in the treatment of dopaminergic psychosis in Parkinson's Disease. Clin Neuropharmacol. 1997;20:204-9. [pmid: 9197942].
268 Trosch R M, Friedman J H, Lannon M C, et al. Clozapine use in Parkinson's Disease: A retrospective analysis of a large multicentered clinical experience. Mov Disord. 1998;13:377-82. [pmid: 9613725].
269 Wagner M L, Defilippi J L, Menza M A, et al. Clozapine for the treatment of psychosis in Parkinson's Disease: Chart review of 49 patients. J Neuropsychiatry Clin Neurosci. 1996;8:276-80. [pmid: 8854298].
270 Meco G, Alessandri A, Giustini P, et al. Risperidone in levodopa-induced psychosis in advanced Parkinson's Disease: An open-label, long-term study. Mov Disord. 1997;12:610-2. [pmid: 9251085].
271 Targum S D, Abbott J L. Efficacy of quetiapine in parkinson's patients with psychosis. J Clin Psychopharmacol. 2000;20:54-60. [pmid: 10653209].
272 Dam M, Tonin P, Casson S, et al. Effects of conventional and sensory-enhanced physiotherapy on disability of Parkinson's Disease patients. Adv Neurol. 1996;69:551-5. [pmid: 8615180].
273 Jahanshahi M, Brown R G, Whitehouse C, et al. Contact with a nurse practitioner: A short-term evaluation study in Parkinson's Disease and dystonia. Behav Neurol. 1994;7:189-96.
274 Mally J, Stone T W. Improvement in parkinsonian symptoms after repetitive transcranial magnetic stimulation. J Neurol Sci. 1999;162:179-84. [pmid: 10202984].
275 Mercer B S. A randomized study of the efficacy of the PROPATH program for patients with Parkinson's Disease. Arch Neurol. 1996;53:881-4. [pmid: 8815853].
276 Montgomery E B, Lieberman A, Singh G, et al. Patient education and health promotion can be effective in Parkinson's Disease: A randomized controlled trial. Am J Med. 1994;97:429-35. [pmid: 7977431].
277 Reynolds H, Wilson-Barnett J, Richardson G. Evaluation of the role of the Parkinson's Disease nurse specialist. Int J Nurs Stud. 2000;37:337-49. [pmid: 10760541].
278 Patti F, Reggio A, Nicoleti F, et al. Effects of rehabilitation therapy on parkinsonians' disability and functional independence. J Neuro Rehab. 1996;10:223-31.
279 Adams S G, Lang A E. Can the Lombard effect be used to improve low voice intensity in Parkinson's Disease?. Eur J Disord Commun. 1992;27:121-7. [pmid: 1446099].
280 Comella C L, Stebbins G T, Brown-Toms N, et al. Physical therapy and Parkinson's Disease: A controlled clinical trial. Neurology. 1994;44:376-8. [pmid: 8145901].
281 DeAngelis E C, Mourao L F, Ferraz H B, et al. Effect of voice rehabilitation on oral communication of Parkinson's Disease patients. Acta Neurol Scand. 1997;96:199-205. [pmid: 9325469].
282 Formisano R, Pratesi L, Modarelli F T, et al. Rehabilitation and Parkinson's Disease. Scand J Rehab Met. 1992;24:157-60.
283 Katsikitis M, Pilowsky I. A controlled study of facial mobility treatment in Parkinson's Disease. J Psychosom Res. 1996;40:387-96. [pmid: 8736419].
284 Nagaya M, Kachi T, Yamada T. Effect of swallowing training on swallowing disorders in Parkinson's Disease. Scand J Rehab Med. 2000;32:11-5.
285 Pacchetti C, Mancini F, Agliere R, et al. Active music therapy in Parkinson's Disease: An integrative method for motor and emotional rehabilitation. Psychosom Med. 2000;62:386-93. [pmid: 10845352].
286 Platz T, Brown R G, Marsden C D. Training improves the speed of aimed movements in Parkinson's Disease. Brain. 1998;121:505-14. [pmid: 9549526].
287 Ramig L O, Countryman S, Thompson L L, et al. Comparison of two forms of intensive speech treatment for Parkinson's Disease. J Speech Hear Res. 1995;38:1232-51. [pmid: 8747817].
288 Schenckman M, Cutson T M, Kuchibhatla M, et al. Exercise to improve spinal flexibility and function for people with Parkinson's Disease: A randomized, controlled trial. J Am Geriatr Soc. 1998;46:1207-16. [pmid: 9777901].
289 Sitzia J, Haddrell V, Rice-Oxley M. Evaluation of a nurse-led multidisciplinary neurological rehabilitation programme using the Nottingham Health Profile. Clin Rehabil. 1998;12:389-94. [pmid: 9796929].
290 Thaut M H, McIntosh G C, Rice R R, et al. Rhythmic auditory stimulation in gait training for Parkinson's Disease patients. Mov Disord. 1996;11:193-200. [pmid: 8684391].
291 Pacchetti C, Aglieri R, Mancini F, et al. Active music therapy and Parkinson's Disease: Methods. Funcy Neurol. 1998;13:57-67.
292 Smith M E, Ramig L O, Dromey C, et al. Intensive voice treatment in Parkinson's Disease: Laryngostroboscopic findings. J Voice. 1995;9:453-9. [pmid: 8574314].
293 de Silva H A R, Khan N L, Wood N W. The genetics of Parkinson's Disease. Curr Opin Genet Dev. 2000;10:292-8. [pmid: 10826990].
294 Polymeropoulos M H, Higgins J J, Golbe L I, et al. Mapping of a gene for Parkinson's Disease to chromosome 4q21–q23. Science. 1996;274:1197-8. [pmid: 8895469].
295 Gasser T. Is Parkinson's Disease an inherited condition?. Adv Neurol. 1999;80:143-52. [pmid: 10410714].
296 Tanner C M, Ottman R, Golman S M, et al. Parkinson Disease in twins: an etiologic study. JAMA. 1999;281:341-6. [pmid: 9929087].
297 Piccini P, Burn D J, Ceravolo R, et al. The role of inheritance in sporadic Parkinson's Disease: Evidence from a longitudinal study of dopaminergic function in twins. Ann Neurol. 1999;45:577-82. [pmid: 10319879].
298 Sveinbjornsdottir S, Hicks A A, Jonsson T, et al. Familial aggregation of Parkinson's Disease in Iceland. N Engl J Med. 2000;343:1767-70.
299 Abbas N, Lucking C B, Ricard S, et al. A wide variety of mutations in the parkin gene are responsible for autosomal recessive parkinsonism in Europe. Hum Mol Genet. 1999;8:567-74. [pmid: 10072423].
300 Hattori N, Kitada T, Matsumine H, et al. Molecular genetic analysis of a novel parkin gene in Japanese families with autosomal recessive juvenile parkinsonism: Evidence for variable homozygous deletions in the parkin gene in affected individuals. Ann Neurol. 1998;44:935-41. [pmid: 9851438].
301 Leroy E, Anastasopoulos D, Konitsiotis S, et al. Deletions in the parkin gene and genetic heterogenity in a Greek family with early onset Parkinson's Disease. Hum Genet. 1998;103:424-7. [pmid: 9856485].
302 Lucking C B, Durr A, Bonifati V, et al. Association between early-onset Parkinson's Disease and mutations in the parkin gene. N Engl J Med. 2000;342:1560-7. [pmid: 10824074].
303 Hu C J, Sung S M, Liu H S, et al. Polymorphisms of the parkin gene in sporadic Parkinson's Disease among Chinese in Taiwan. Eur Neurol. 2000;44:90-3. [pmid: 10965160].
304 Freese A. Restorative gene therapy approaches to Parkinson's Disease. Med Clin North Am. 1999;83:537-48. [pmid: 10093593].
305 Latchman D S. Herpes simplex virus vectors for gene therapy in Parkinson's Disease and other diseases of the nervous system. J R Soc Med. 1999;92:566-70. [pmid: 10703493]. [pmcid: 1297431].
306 Little RJA, Rubin DB. Statistical analysis with missing data. New York: John Wiley & Sons; 1987.