# Harnessing the Available Evidence

This systematic review has led to an evidence base that contains a wealth of data regarding diagnosis and management of PD. The relational database could be provided with a navigational software interface that permits easy filtering and exporting for analysis. The evidence base provides a valuable opportunity to develop clinical practice guidelines or evaluate current guidelines against the weight of the best available evidence. Given the large volume of information continuing to be published regarding PD, semi-annual updates are recommended to keep this evidence base current.