# Appendix I. Rejected Studies Log

### Citation Rejection Reason: Abstract, letter comment, review, case report, or meta-analysis

1 Bejjani B P, Damier P, Arnulf I, Papadopoulos S, Bonnet A M, Vidailhet M, et al. Deep brain stimulation in Parkinson's Disease: Opposite effects of stimulation in the pallidum. Mov Disord. 1998;13:969-70. [pmid: 9827624].
2 Bergus G. Treatment of Parkinson's disease. J Fam Pract. 1996;42:457-8. [pmid: 8642360].
3 Caraceni T. A case for early levodopa treatment of Parkinson's disease. Clin Neuropharmacol. 1995;18:S38-42.
4 Chana P, de Marinis A, Barrientos N. Gabapentin and motor fluctuations in Parkinson's disease. Mov Disord. 1997;12:608. [pmid: 9251083].
5 Damiano AM, Snyder C, Strausser B, Willian MK, anne, Health s, et al. a review of health-related quality-of-life concepts and measures for parkinson's disease. Qual 1999; 8:235–43.
6 Damier P, Jaillon C, Clavier I, Arnulf I, Bonnet A M, Bejjani B P, et al. Dyskinesias assessment in Phase II studies. Mov Disord. 1999;14:54-9. [pmid: 10493404].
7 Defer G L, Widner H, Marie R M, Remy P, Levivier M. Core assessment program for surgical interventional therapies in Parkinson's Disease. Mov Disord. 1999;14:572-84. [pmid: 10435493].
8 Di Rocco A, Molinari S P, Kollmeier B, Yahr M D. Parkinson's Disease: Progression and mortality in the L-dopa era. Adv Neurol. 1996;69:3-11. [pmid: 8615142].
9 Driver P S. Depression treatment in Parkinson's Disease. DICP. 1991;25:137-8. [pmid: 2058186].
10 Factor S A, Molho E S. Transient benefit of amantadine in Parkinson's Disease: The facts about the myth. Mov Disord. 1999;14:515-7. [pmid: 10348482].
11 Friedman A. Old-onset Parkinson's Disease compared with young-onset disease: Clinical differences and similarities. Acta Neurol Scand. 1994;89:258-61. [pmid: 8042442].
12 Gottwald M D. Maximizing the benefit: Risk ratio of levodopa therapy in Parkinson's Disease. Pharmacotherapy. 1999;19:S162-8.
13 Guay D R P. Tolcapone, a selective catechol-o-methyltransferase inhibitor for treatment of Parkinson's Disease. Pharmacotherapy. 1999;19:6-20. [pmid: 9917075].
14 Hely M A, Fung V S C, Morris J G L. Treatment of Parkinson's Disease. J Clin Neurosci. 2000;7:484-94. [pmid: 11029227].
15 Hitchon P, Follet K, Schneider P, Rodnitzky R, Ajax T, Dobson J, et al. Surgical treatment of Parkinson's Disease. Iowa Med. 1997;87:323-5. [pmid: 9383922].
16 Hughes A J. Drug treatment of Parkinson's Disease in the 1990s - achievements and future possibilities. Drugs. 1997;53:195-205. [pmid: 9028741].
17 Kanazawa I. Short review on monoamine oxidase and its inhibitors. Eur Neurol. 1994;34:36-9. [pmid: 7821334].
18 Laitinen L V. Ventroposterolateral pallidotomy. Stereotact Funct Neurosurg. 1994;62:41-52. [pmid: 7631088].
19 Lange K W, Rausch W D, Gsell W, Naumann M, Oestreicher E, Reiderer P. Neuroprotection by dopamine agonists. J Neural Transm Suppl. 1994;43:183-201. [pmid: 7884400].
20 LeWitt P A. Deprenyl's effect at slowing progression of parkinsonian disability: The DATATOP study. Acta Neurol Scand Suppl. 1991;136:79-86. [pmid: 1801542].
21 Lieberman A. Dopamine agonists used as monotherapy in de novo PD patients: Comparison with selegiline. Neurology. 1992;42:37-48. [pmid: 1350073].
22 Lieberman A N, Gopinathan G, Pasternack P, Goldstein M. Mesulergine: A dopamine agonist with novel properties in Parkinson's Disease. Adv Neurol. 1990;53:533-7. [pmid: 1978521].
23 Louis E D, Fahn S. Pathologically diagnosed diffuse Lewy body disease and Parkinson's Disease. Do the parkinsonian features differ. Adv Neurol. 1996;69:311-4. [pmid: 8615144].
24 Lozano A M, Hutchison W D, Tasker R R, Lang A E, Junn F, Dostrovsky J O. Microelectrode recordings define the ventral posteromedial pallidotomy target. Stereotact Funct Neurosurg. 1998;71:153-63. [pmid: 10461101].
25 Luer M S. Interventions to achieve tonic exposure to levodopa: Delaying or preventing the onset of motor complications. Pharmacotherapy. 1999;19:169S-79S. [pmid: 10555945].
26 MacMahon D G. Use of apomorphine in clinical practice. Adv Neurol. 1999;80:529-33. [pmid: 10410767].
27 Makela E H. Unforeseen beneficial effects of controlled-release levodopa-carbidopa (Sinemet CR). J Neuropsychiatry Clin Neurosci. 1992;4:234-5. [pmid: 1627988].
28 Marsden C D. Clinical experience with cabergoline in patients with advanced Parkinson's Disease treated with levodopa. Drugs. 1998;55:17-22. [pmid: 9483166].
29 Micek S T, Ernst M E. Tolcapone: A novel approach to Parkinson's Disease. Am J Health Syst Pharm. 1999;56:2195-204. [pmid: 10565698].
30 Mizuno Y, Kondo T. Mortality associated with selegiline in Parkinson's Disease. What do the available data mean. Drug Saf. 1997;16:289-94. [pmid: 9187529].
31 Molina H, Quinones-Molina R, Munoz J, Alvarez L, Alaminos A, Ortega I, et al. Neurotransplantation in Parkinson's Disease: From open microsurgery to bilateral stereotactic approach: First clinical trial using microelectrode recording technique. Stereotact Funct Neurosurg. 1994;62:204-8. [pmid: 7631069].
32 Montastruc J L, Rascol O, Senard J M. Treatment of Parkinson's Disease should begin with a dopamine agonist. Mov Disord. 1999;14:725-30. [pmid: 10495032].
33 Olanow C W, Myllyla V V, Sotaniemi K A, Larsen J P, Palhagen S, Przuntek, et al. Effect of selegiline on mortality in patients with Parkinson's Disease - a meta-analysis. Neurology. 1998;51:825-30. [pmid: 9748034].
34 Parkinson Study Group. A multicenter assesment of dopamine transporter imaging with DOPASCAN/SPECT in parkinsonism. Neurology. 2000;55:1540-7. [pmid: 11094111].
35 Playfer J. Targeting Parkinson's Disease - the case for early referral. Curr Med Res Opin. 2000;16:43-5. [pmid: 16422034].
36 Poewe W. Should treatment of Parkinson's Disease be started with a dopamine agonist. Neurology. 1998;51:S21-4. [pmid: 9711976].
37 Poewe W, Luginger E. Depression in Parkinson's Disease - impediments to recognition and treatment options. Neurology. 1999;52:S2-6. [pmid: 10227602].
38 Ramaker C, van de Beek W J T, Finken M J J, van Hilten B J J. The efficacy and safety of adjunct bromocriptine therapy for levodopa-induced motor complications: A systematic review. Mov Disord. 2000;15:56-64. [pmid: 10634242].
39 Robin D W. Selegiline in the treatment of Parkinson's Disease. Am J Med Sci. 1991;302:392-5. [pmid: 1772127].
40 Saintcyr J A, Taylor A E, Lang A E. Neuropsychological and psychiatric side effects in the treatment of Parkinson's Disease. Neurology. 1993;43:47-52.
41 Sawle G V. The detection of preclinical Parkinson's Disease: What is the role of positron emission tomography. Mov Disord. 1993;8:271-7. [pmid: 8341290].
42 Shoulson I. DATATOP: A decade of neuroprotective inquiry. Ann Neurol. 1998;44:S160-6. [pmid: 9749589].
43 Shoulson I. Where do we stand on neuroprotection? Where do we go from here. Mov Disord. 1998;13:46-8. [pmid: 9613718].
44 Shoulson I. Antioxidative therapeutic strategies for Parkinson's Disease. Ann N Y Acad Sci. 1992;648:37-41. [pmid: 1637072].
45 Simons J A. Fluoxetine in Parkinson's disease. Mov Disord. 1996;11:581-2. [pmid: 8866503].
46 Stacy M. Managing late complications of Parkinson's Disease. Med Clin North Am. 1999;83:469. [pmid: 10093588].
47 Stern M B. Contemporary approaches to the pharmacotherapeutic management of Parkinson's Disease - an overview. Neurology. 1997;49:S2-9. [pmid: 9222270].
48 Thorogood M, Armstrong B, Nichols T, Hollowell J. Mortality in people taking selegiline: Observational study. BMJ. 1998;317:252-4. [pmcid: 28616]. [pmid: 9677215].
49 Ward C D. Does selegiline delay progression of Parkinson's Disease? A critical re-evaluation of the DATATOP study. J Neurol Neurosurg Psychiatry. 1994;57:217-20. [pmid: 8126510].
50 Weiner W J. The initial treatment of Parkinson's Disease should begin with levodopa. Mov Disord. 1999;14:716-24. [pmid: 10495031].
51 Wolters E C. Dopaminomimetic psychosis in Parkinson's Disease patients - diagnosis and treatment. Neurology. 1999;52:S10-3. [pmid: 10227604].
52 Wszolek Z K, Markopoulou K. Olfactory dysfunction in Parkinson's Disease. Clin Neurosci. 1998;5:94-101. [pmid: 10785834].

### Rejection Reason: Cross-over studies

1 Bowes S G, Clark P K, Charlett A, O'Neill C J, Leeman A L, Weller C, et al. Objective outcome criteria in trials of anti-parkinsonian therapy in the elderly: Sensitivity, specificity and reliability of measures of brady- and hypo-kinesia. Br J Clin Pharmacol. 1991;31:295-304. [pmid: 2054270].
2 Cedarbaum J M, Silvestri M, Clark M, Toy L, Harts A, Green-Parsons A, et al. Results of long-term treatment with controlled-release levodopa/carbidopa (Sinemet CR). J Neural Transm [P-D Sect]. 1990;2:205-13.
3 Friedman J H, Koller W C, Lannon M C, Busenbark K, Swanson-Hyland E, Smith D. Benztropine versus clozapine for the treatment of tremor in Parkinson's Disease. Neurology. 1997;48:1077-81. [pmid: 9109903].
4 Laihinen A, Rinne U K, Suchy I. Comparison of lisuride and bromocriptine in the treatment of advanced Parkinson's Disease. Acta Neurol Scand. 1992;86:593-5. [pmid: 1481646].
5 Pfeiffer R F, Wilken K E, Glaeske C S, Hofman R. Sinemet CR in Parkinson's Disease. Nebr Med J. 1991;76:8-10.
6 Uitti R J, Vingerhoets F J G, Hayward M, Cooper S, Snow B J. Positron emission tomography (PET) measurements of striatal D2 receptors in untreated Parkinson's Disease patients with follow-up after 6 and 12 months' treatment with Sinemet or Sinemet CR. Parkinsonism Relat. 1997;3:43-6.

### Rejection Reason: Duplicate Study

1 Baas H, Beiske A G, Ghika J, Jackson M, Oertel W H, Poewe W, et al. Catechol-O-methyltransferase inhibition with tolcapone reduces the “wearing off” phenomenon and levodopa requirements in fluctuating parkinsonian patients. Neurology. 1998;50:S46-53. [pmid: 9591522].
2 Rajput A H, Martin W, Saint-Hilaire M H, Dorflinger E, Pedder S. Tolcapone improves motor function in parkinsonian patients with the “wearing-off” phenomenon: A double-blind, placebo-controlled, multicenter trial. Neurology. 1998;50:S54-9. [pmid: 9591523].

### Rejection Reason: In vitro studies

1 Chiba S, Matsumoto H, Saitoh M, Kasahara M, Matsuya M, Kashiwagi M. A correlation study between serum adenosine deaminase activities and peripheral lymphocyte subsets in Parkinson's Disease. J Neurol Sci. 1995;132:170-3. [pmid: 8543943].
2 Coenen H H, Dutschka K, Muller S P, Geworski L, Farahati J, Reiners C. N.c.a. radiosynthesis of [123,124 I] beta-CIT, plasma analysis and pharmacokinetic studies with SPECT and PET. Nucl Med Biol. 1995;22:977-84. [pmid: 8998475].

### Rejection Reason: Languages other than English

1 Mizuno Y, Mannen T, Iwata M, Ogawa N, Kanazawa I, Goto I, et al. Effects of modified release bromocriptine on Parkinson's Disease and parkinsonism, a double-blind study. Clin Eval. 1990;18:315-39.
2 Nakanishi T, Kowa H, Mizuno Y, Yanagisawa N. The clinical evaluation of b-ht 920 (talipexole hydrochloride) in Parkinson's Disease. A multi-centered double-blind comparative study vs. bromocriptine mesilate. Clin Eval. 1993;21:59-110.

### Rejection Reason: Mixed populations where results for PD patients can not be separately extracted

1 Alesch F, Pinter M M, Helscher R J, Fertl L, Benabid A L, Koos W T, et al. Stimulation of the ventral intermediate thalamic nucleus in tremor dominated Parkinson's Disease and essential tremor. Acta Neurochir (Wien). 1995;136:75-81. [pmcid: 300905]. [pmid: 8748831].
2 Chacko R C, Hurley R A, Harper R G, Jankovic J, Cardoso F. Clozapine for acute and maintenance treatment of psychosis in Parkinson's Disease. J Neuropsychiatry Clin Neurosci. 1995;7:471-5. [pmid: 8555750].
3 Hariz M I, Bergenheim A T. Clinical evaluation of computed tomography-guided versus ventriculography-guided thalamotomy for movement disorders. Acta Neurochir Suppl. 1993;58:53-5.
4 Konagaya M, Konagaya Y, Iida M. Clinical and magnetic resonance imaging study of extrapyramidal symptoms in multiple system atrophy. J Neurol Neurosurg Psychiatry. 1994;57:1528-31. [pmid: 7798985].
5 Tasker R R, DeCarvalho G C, Li C S, Kestle J R. Does thalamotomy alter the course of Parkinson's Disease. Adv Neurol. 1996;69:563-83. [pmid: 8615182].
6 Whitehouse C. A new source of support. The nurse practitioner role in Parkinson's Disease and dystonia. Prof Nurse . 1994; 9:448, 450–48, 451.

### Rejection Reason: No outcome of interest

1 Abbruzzese G, Marchese R, Trompetto C. Sensory and motor evoked potentials in multiple system atrophy: A comparative study with Parkinson's Disease. Mov Disord. 1997;12:315-21. [pmid: 9159725].
2 Gori S, Massetani R, Murri L. Evaluation of olfactory function by topographic EEG analysis in patients with Parkinson's Disease. Ital J Neurol Sci. 1995;16:595-601. [pmid: 8838785].
3 Gross R E, Lombardi W J, Hutchison W D, Narula S, Saint-Cyr J A, Dostrovsky J O, et al. Variability in lesion location after microelectrode-guided pallidotomy for Parkinson's Disease: Anatomical, physiological, and technical factors that determine lesion distribution. J Neurosurg. 1999;90:468-77. [pmid: 10067915].
4 Kirollos C, Charlett A, Bowes S G, Purkiss A G, O'Neill C J, Weller C, et al. Time course of physical and psychological responses to selegiline monotherapy in newly diagnosed, idiopathic parkinsonism. Eur J Clin Pharmacol. 1996;50:7-18. [pmid: 8739805].
5 Kirschman D L, Milligan B, Wilkinson S, Overman J, Wetzel L, Batnitzky, et al. Pallidotomy microelectrode targeting: Neurophysiology-based target refinement. Neurosurgery. 2000;46:613-22. [pmid: 10719858].
6 Kubu C S, Grace G M, Parrent A G. Cognitive outcome following pallidotomy: The influence of side of surgery and age of patient at disease onset. J Neurosurg. 2000;92:384-9. [pmid: 10701523].
7 Kurlan R, Tanner C M, Goetz C, Sutton J, Lichter D, Carvey P, et al. Levodopa drug holiday versus drug dosage reduction in Parkinson's Disease. Clin Neuropharmacol. 1994;17:117-27.
8 Macias R, Teijeiro J, Torres A, Alvarez L. Electrophysiological targeting in stereotaxic surgery for Parkinson's Disease. Adv Neurol. 1997;74:175-82. [pmid: 9348413].
9 Porena M, Parziani S, Costantini E, Vespasiani G, Micali F. Autologous adrenal medullary transplant in Parkinson's Disease: Critical review of our results in 13 patients. Neurourol Urodyn. 1996;15:195-201. [pmid: 8732986].
10 Rodriguez M, Lera G, Vaamonde J, Luquin M R, Obeso J A. Motor response to apomorphine and levodopa in asymmetric Parkinson's Disease. J Neurol Neurosurg Psychiatry. 1994;57:562-6. [pmid: 8201324].
11 Sato Y, Manabe S, Kuno H, Oizumi K. Amelioration of osteopenia and hypovitaminosis D by 1alpha-hydroxyvitamin D3 in elderly patients with Parkinson's Disease. J Neurol Neurosurg Psychiatry. 1999;66:64-8. [pmid: 9886454].
12 Soliveri P, Brown R G, Jahanshahi M, Marsden C D. Effect of practice on preformance of a skilled motor task in patients with Parkinson's Disease. J Neurol Neurosurg Psychiatry. 1992;55:454-60. [pmid: 1619411].
13 Turkka J, Suominen K, Tolonen U, Sotaniemi K, Myllyla V V. Selegiline diminishes cardiovascular autonomic responses in Parkinson's Disease. Neurology. 1997;48:662-7. [pmid: 9065544].

### Rejection Reason: Outcomes not extractable

1 Bayles K A, Tomoeda C K, Wood J A, Montgomery E B, Cruz R F, McGeagh A. Change in cognitive function in idiopathic Parkinson Disease. Arch Neurol. 1996;53:1040-6.
2 Berding G, Gratz K F, Kolbe H, Meyer G J, Dengler R, Knoop B O, et al. 123I-IBZM SPECT: Reconstruction methodology and results in parkinsonism and dystonia. Nuklearmedizin. 1994;33:194-9. [pmid: 7997377].
3 Edwards R, Beuter A. Using time domain characteristics to discriminate physiologic and parkinsonian tremors. J Clin Neurophysiol. 2000;17:87-100. [pmid: 10709814].
4 Guttman M, Burkholder J, Kish S J, Hussey D, Wilson A, DaSilva J, et al. [11C]RTI-32 PET studies of the dopamine transporter in early dopa-naive Parkinson's Disease: Implications for the symptomatic threshold. Neurology. 1997;48:1578-83. [pmid: 9191769].
5 Jankovic J, McDermott M, Carter J, Gauthier S, Goetz C, Golbe L, et al. Variable expression of Parkinson's Disease: A base-line analysis of the DATATOP cohort. Neurology. 1990;40:1529-34. [pmid: 2215943].
6 Jimenez F, Velasco F, Velasco M, Velasco A L. Long-term effects of medical and surgical treatments on Parkinson's Disease. Stereotact Funct Neurosurg. 1994;62:85-9. [pmid: 7631093].
7 Jonsson B, Sernbo I, Johnell O. Rehabilitation of hip fracture patients with Parkinson's Disease. Scand J Rehabil Med. 1995;27:227-30. [pmid: 8650507].
8 Kumar R, Lozano A M, Sime E, Halket E, Lang A E. Comparative effects of unilateral and bilateral subthalamic nucleus deep brain stimulation. Neurology. 1999;53:561-6. [pmid: 10449121].
9 Laitinen L V. Ventroposterolateral pallidotomy. Stereotact Funct Neurosurg. 1994;62:41-52. [pmid: 7631088].
10 Laulumaa V, Kuikka J T, Soininen H, Bergstrom K, Lansimies E, Reikkinen P. Imaging of D2 dopamine receptors of patients with Parkinson's Disease using single photon emission computed tomography and iodobenzamide I 123. Arch Neurol. 1993;50:509-12. [pmid: 8489408].
11 Owen A M. Visuospatial memory deficits at different stages of Parkinson's Disease. Neuropsychologia. 1993;31:627-44. [pmid: 8371837].
12 Pollak P, Benabid A L, Gervason C L, Hoffmann D, Siegneuret E, Perret J. Long-term effects of chronic stimulation of the ventral intermediate thalamic nucleus in different types of tremor. Adv Neurol. 1993;60:408-13. [pmid: 8420163].
13 Pondal M, Del Ser T, Bermejo F. Anticholinergic therapy and dementia in patients with Parkinson's Disease. J Neurol. 1996;243:543-6. [pmid: 8836945].
14 Reid W G. The evolution of dementia in idiopathic Parkinson's Disease: Neuropsychological and clinical evidence in support of subtypes. Int Psychogeriatr. 1992;4:147-60. [pmid: 1288660].
15 Reid W G J, Hely M A, Morris J G L, Broe G A, Adena M, Sullivan D J O, et al. A longitudinal study of Parkinson's Disease - clinical and neuropsychological correlates of dementia. J Clin Neurosci. 1996;3:327-33. [pmid: 18638897].
16 Sharpe M H. Patients with early Parkinson's Disease are not impaired on spatial orientating of attention. Cortex. 1990;26:515-24. [pmid: 2081389].
17 van Hilten J J, van Eerd A A, Wagemans E A, Middelkoop H A, Roos R A. Bradykinesia and hypokinesia in Parkinson's Disease: What's in a name. J Neural Transm. 1998;105:229-37. [pmid: 9660100].

### Rejection Reason: Pharmacodynamic or pharmacokinetic study

1 Brocks D R. Anticholinergic drugs used in Parkinson's Disease: An overlooked class of drugs from a pharmacokinetic perspective. J Pharm Pharm Sci. 1999;2:39-46. [pmid: 10952768].
2 Pahwa R, Lyons K, McGuire D, Silverstein P, Zwiebel F, Robischon M, et al. Comparison of standard carbidopa-levodopa and sustained-release carbidopa-levodopa in Parkinson's Disease: Pharmacokinetic and quality-of-life measures. Mov Disord. 1997;12:677-81. [pmid: 9380047].

### Rejection Reason: Studies not including an objective clinical outcome measure of PD activity

1 Berke G S, Gerratt B, Kreiman J, Jackson K. Treatment of Parkinson hypophonia with percutaneous collagen augmentation. Laryngoscope. 1999;109:1295-9. [pmid: 10443836].
2 Bridgewater K J, Sharpe M H. Aerobic exercise and early Parkinson's Disease. J Neuro Rehab. 1996;10:233-41.
3 Cahill L M, Murdoch B E, Theodoros D G, Triggs E J, Charles B G, Yao A A. Effect of oral levodopa treatment on articulatory function in Parkinson's Disease: Preliminary results. Motor Control. 1998;2:161-72. [pmid: 9644287].
4 Caparros-Lefebvre D, Blond S, Vermersch P, Pecheux N, Guieu J D, Petit H. Chronic thalamic stimulation improves tremor and levodopa induced dyskinesias in Parkinson's Disease. J Neurol Neurosurg Psychiatry. 1993;56:268-73. [pmid: 8459243].
5 Hariz M I. Correlation between clinical outcome and size and site of the lesion in computed tomography guided thalamotomy and pallidotomy. Stereotact Funct Neurosurg. 1990;54–55:172-85.
6 Hurwitz B, Bajekal M, Jarman B. Evaluating community-based Parkinson's Disease nurse specialists: Rationale, methodology, and representativeness of patient sample in a large randomized controlled trial. Adv Neurol. 1999;80:431-8. [pmid: 10410752].
7 Laitinen L V. Pallidotomy for Parkinson's Disease. Neurosurg Clin N Am. 1995;6:105-12. [pmid: 7696867].
8 Laitinen L V, Bergenheim A T, Hariz M I. Leksell's posteroventral pallidotomy in the treatment of Parkinson's Disease. J Neurosurg. 1992;76:53-61. [pmid: 1727169].
9 Laitinen L V, Bergenheim A T, Hariz M I. Ventroposterolateral pallidotomy can abolish all parkinsonian symptoms. Stereotact Funct Neurosurg. 1992;58:14-21. [pmid: 1439331].
10 Wells M R, Giantinoto S, D'Agate D, Areman R D, Fazzini E A, Dowling D, et al. Standard osteopathic manipulative treatment acutely improves gait performance in patients with Parkinson's Disease. J Am Osteopath Assoc. 1999;99:92-8. [pmid: 10079641].

### Rejection Reason: Studies not including tests to establish or support diagnosis of PD

1 Ahlskog J E, Uitti R J, O'Connor M K, Maraganore D M, Matsumoto J Y, Stark K F, et al. The effect of dopamine agonist therapy on dopamine transporter imaging in Parkinson's Disease. Mov Disord. 1999;14:940-6. [pmid: 10584667].
2 Artieda J, Pastor M A, Lacruz F, Obeso J A. Temporal discrimination is abnormal in Parkinson's Disease. Brain. 1992;115:199-210. [pmid: 1559154].
3 Beckley D J, Panzer V P, Remler M P, Ilog L B, Bloem B R. Clinical correlates of motor performance during paced postural tasks in Parkinson's Disease. J Neurol Sci. 1995;132:133-8. [pmid: 8543938].
4 Berardelli A, Rona S, Inghilleri M, Manfredi M. Cortical inhibition in Parkinson's Disease. A study with paired magnetic stimulation. Brain. 1996;119:71-7. [pmid: 8624695].
5 Beric A, Sterio D, Dogali M, Fazzini E, Eidelberg D, Kolodny E. Characteristics of pallidal neuronal discharges in Parkinson's Disease patients. Adv Neurol. 1996;69:123-8. [pmid: 8615119].
6 Bodis-Wollner I, Borod J C, Cicero B, Haywood C S, Raskin S, Mylin L, et al. Modality dependent changes in event-related potentials correlate with specific cognitive functions in nondemented patients with Parkinson's Disease. J Neural Transm Park Dis Dement Sect. 1995;9:197-209. [pmid: 8527004].
7 Brooks D J, Ibanez V, Sawle G V, Playford E D, Quinn N, Mathia C J, et al. Striatal D2 receptor status in patients withParkinson's Disease, striatonigral degeneration, and progressive supranuclear palsy, measured with 11C-raclopride and positron emission tomography. Ann Neurol. 1992;31:184-92. [pmid: 1575457].
8 Buttner T, Muller T, Kuhn W. Effects of apomorphine on visual functions in Parkinson's Disease. J Neural Transm. 2000;107:87-94. [pmid: 10809406].
9 Chang R, Guan L, Burne J A. An automated form of video image analysis applied to classification of movement disorders. Disabil Rehabil. 2000;22:97-108. [pmid: 10661762].
10 Chia L G, Cheng F C, Kuo J S. Monoamines and their metabolites in plasma and lumbar cerebrospinal fluid of Chinese patients with Parkinson's Disease. J Neurol Sci. 1993;116:125-34. [pmid: 8336158].
11 Comella C L, Goetz C G. Akathisia in Parkinson's Disease. Mov Disord. 1994;9:545-9. [pmid: 7990849].
12 Contin M, Riva R, Martinelli P, Procaccianti G, Cortelli P, Avoni P, et al. Response to a standard oral levodopa test in parkinsonian patients with and without motor fluctuations. Clin Neuropharmacol. 1990;13:19-28. [pmid: 2306746].
13 Dexter D T, Carayon A, Javoy-Agid F, Agid Y, Wells F R, Daniel S E, et al. Alterations in the levels of iron, ferritin, and other trace metals in Parkinson's Disease and other neurodegenerative diseases affecting the basal ganglia. Brain. 1991;114:1953-75. [pmid: 1832073].
14 Dexter D T, Carayon A, Vidailhet M, Ruberg M, Agid F, Agid Y, et al. Decreased ferritin levels in brain in Parkinson's Disease. J Neurochem. 1990;55:16-20. [pmid: 2355217].
15 Duncombe M E, Bradshaw J L, Iansek R, Phillips J G. Parkinsonian patients without dementia or depression do not suffer from bradyphrenia as indexed by performance in mental rotation tasks with and without advance information. Neuropsychologia. 1994;32:1383-96. [pmid: 7877746].
16 Durif F, Pollak P, Hommel M, Ardouin C, Le Bas J F, Crouzet G, et al. Relationship between levodopa-independent symptoms and central atrophy evaluated by magnetic resonance imaging in Parkinson's Disease. Eur Neurol. 1992;32:32-6. [pmid: 1563452].
17 Eidelberg D, Moeller J R, Ishikawa T, Dhawan V, Spetsieris P, Chaly T, et al. Assessment of disease severity in parkinsonism with flourine-18-flourodeoxyglucose and PET. J Nucl Med. 1995;36:378-83. [pmid: 7884498].
18 Eidelberg D, Takikawa S, Moeller J R, Dhawan V, Redington K, Chely T, et al. Striatal hypometabolism distinguishes striatonigral degeneration from Parkinson's Disease. Ann Neurol. 1993;33:518-27. [pmid: 8498828].
19 Gnanalingham K K, Byrne E J, Thornton A, Sambrook M A, Bannister P. Motor and cognitive function in Lewy body dementia: Comparison with Alzheimer's and Parkinson's Diseases. J Neurol Neurosurg Psychiatry. 1997;62:243-52. [pmid: 9069479].
20 Hughes A J, Lees A J, Stern G M. The motor response to sequential apomorphine in parkinsonian fluctuations. J Neurol Neurosurg Psychiatry. 1991;54:358-60. [pmid: 2056323].
21 Hutton J T, Morris J L, Elias J W, Varma R, Poston J N. Spatial contrast sensitivity is reduced in bilateral Parkinson's Disease. Neurology. 1991;41:1200-2. [pmid: 1866005].
22 Kakinuma S, Nogaki H, Pramanik B, Morimatsu M. Muscle weakness in Parkinson's Disease: Isokinetic study of the lower limbs. Eur Neurol. 1998;39:218-22. [pmid: 9635472].
23 Karayanidis F, Andrews S, Ward P B, Michie P T. ERP indices of auditory selective attention in aging and Parkinson's Disease. Psychophysiology. 1995;32:335-50. [pmid: 7652110].
24 Kempster P A, Frankel J P, Stern G M, Lees A J. Comparison of motor response to apomorphine and levodopa in Parkinson'sDisease. J Neurol Neurosurg Psychiatry. 1990;53:1004-7. [pmid: 2283512].
25 Klatka L A, Louis E D, Schiffer R B. Psychiatric features in diffuse Lewy body disease: A clinicopathologic study usingAlzheimer's Disease and Parkinson's Disease comparison groups. Neurology. 1996;47:1148-52. [pmid: 8909420].
26 Leentjens A F, Verhey F R, Lousberg R, Spitsbergen H, Wilmink F W. The validity of the Hamilton and Montgomery-Asberg depression rating scales as screening and diagnostic tools for depression in Parkinson's Disease. Int J Geriatr Psychiatry. 2000;15:644-9. [pmid: 10918346].
27 Linazasoro G. The apomorphine test in gait disorders associated with parkinsonism. Clin Neuropharmacol. 1996;19:171-6. [pmid: 8777771].
28 Manfredi L, Garavaglia P, Beretta S, Pellegrini G. Increased cortical inhibition induced by apomorphine in patients with Parkinson's Disease. Neurophysiol Clin. 1998;28:31-8. [pmid: 9562997].
29 Manson A J, Brown P, O'Sullivan J D, Asselman P, Buckwell D, Lees A J. An ambulatory dyskinesia monitor. J Neurol Neurosurg Psychiatry. 2000;68:196-201. [pmid: 10644787].
30 Netten P M, de Vos K, Horstink M W, Hoefnagels W H. Autonomic dysfunction in Parkinson's Disease, tested with a computerized method using a finapres device. Clin Auton Res. 1995;5:85-9. [pmid: 7620298].
31 Peppe A, Stanzione P, Pierantozzi M, Semprini R, Bassi A, Santilli A M, et al. Does pattern electroretinogram spatial tuning alteration in Parkinson's Disease depend on motor disturbances or retinal dopaminergic loss. Electroencephalogr Clin Neurophysiol. 1998;106:374-82. [pmid: 9741766].
32 Peppe A, Stanzione P, Pierelli F, De Angelis D, Pierantozzi M, Bernardi G. Visual alterations in de novo Parkinson's Disease: Pattern electroretinogram latencies are more delayed and more reversible by levodopa than are visual evoked potentials. Neurology. 1995;45:1144-8. [pmid: 7783879].
33 Pizzolato G, Chierichetti F, Rossato A, Briani C, Dam M, Borsato N, et al. Dopamine receptor SPECT imaging in Parkinson's Disease: A [123 I]-IBZM and [99mTc]-HM-PAO study. Eur Neurol. 1993;33:143-8. [pmid: 8467821].
34 Rabey J M, Bass H, Bonuccelli U, Brooks D, Klotz P, Korczyn A D, et al. Evaluation of the short Parkinson's Evaluation Scale: A new friendly scale for the evaluation of Parkinson's Disease in clinical drug trials. Clin Neuropharmacol. 1997;20:322-37. [pmid: 9260730].
35 Ransmayr G, Kunig G, Neubauer M, Wagner M, Falk M. Effect of age and disease duration on parkinsonian motor scores under levodopa therapy. J Neural Transm Park Dis Dement Sect. 1995;9:177-88. [pmid: 8527002].
36 Ring H A, Bench C J, Trimble M R, Brooks D J, Frackowiak R S, Dolan R J. Depression in Parkinson's Disease. A positron emission study. Br J Psychiatry. 1994;165:333-9. [pmid: 7994502].
37 Rossini P M, Bassetti M A, Pasqualetti P. Median nerve somatosensory evoked potentials. Apomorphine-induced transient potentiation of frontal components in Parkinson's Disease and in parkinsonism. Electroencephalogr Clin Neurophysiol. 1995;96:236-47. [pmid: 7750449].
38 Rossini P M, Traversa R, Boccasena P, Martino G, Passardelli F, Pacifici L, et al. Parkinson's Disease and somatosensory evoked potentials: Apomorphine-induced transient potentiation of frontal components. Neurology. 1993;43:2495-500. [pmid: 8255446].
39 Rumbach L, Tranchant C, Viel J F, Warter J M. Event-related potentials in Parkinson's Disease: A 12-month follow-up study. J Neurol Sci. 1993;116:148-51. [pmid: 8336161].
40 Stanzione P, Traversa R, Pierantozzi M, Semprini R, Loberti M, Peppe, et al. SEPs N30 amplitude in Parkinson's Disease and in pharmacologically induced rigidity: Relationship with the clinical status. Eur J Neurol. 1997;4:24-38.
41 Swainson R, Rogers R D, Sahakian B J, Summers B A, Polkey C E, Robbins T W. Probabilistic learning and reversal deficits in patients with Parkinson's Disease or frontal or temporal lobe lesions: Possible adverse effects of dopaminergic medication. Neuropsychologia. 2000;38:596-612. [pmid: 10689037].
42 Tohgi H, Abe T, Takahashi J, Nozaki Y, Ueno M, Kikuchi T. Monoamine metabolism in the cerebrospinal fluid in Parkinson's Disease: Relationship to clinical symptoms and subsequent therapeutic outcomes. J Neural Transm Park Dis Dement Sect. 1993;5:17-26. [pmid: 8094960].
43 Tsuchiya H, Yamaguchi S, Kobayashi S. Impaired novelty detection and frontal lobe dysfunction in Parkinson's Disease. Neuropsychologia. 2000;38:645-54. [pmid: 10689041].
44 van Hilten J J, Wagemans E A, Ghafoerkhan S F, van Laar T. Movement characteristics in Parkinson's Disease: Determination of dopaminergic responsiveness and threshold. Clin Neuropharmacol. 1997;20:402-8. [pmid: 9331516].
45 Vieregge P, Stolze H, Klein C, Heberlein I. Gait quantitation in Parkinson's Disease--locomotor disability and correlation to clinical rating scales. J Neural Transm. 1997;104:237-48. [pmid: 9203085].
46 Vieregge P, Verleger R, Wascher E, Stuven F, Kompf D. Auditory selective attention is impaired in Parkinson's Disease - event-related evidence from EEG potentials. Brain Res Cogn Brain Res. 1994;2:117-29. [pmid: 7833691].
47 Vingerhoets F J, Schulzer M, Calne D B, Snow B J. Which clinical sign of Parkinson's Disease best reflects the nigrostriatal lesion. Ann Neurol. 1997;41:58-64. [pmid: 9005866].
48 Yoshita M, Hayashi M, Hirai S. Decreased myocardial accumulation of I-123-meta-iodobenzyl guanidine in Parkinson's Disease. Nucl Med Commun. 1998;19:137-42. [pmid: 9548197].
49 Zappia M, Montesanti R, Colao R, Quattrone A. Usefulness of movement time in the assessment of Parkinson's Disease. J Neurol. 1994;241:543-50. [pmid: 7799003].

### Rejection Reason: Studies not including treatment or diagnosis

1 Benshlomo Y, Marmot M G. Survival and cause of death in a cohort of patients with parkinsonism - possible clues to aetiology. J Neurol Neurosurg Psychiatry. 1995;58:293-9. [pmid: 7897409].
2 Comella C L, Nardine T M, Diederich N J, Stebbins G T. Sleep-related violence, injury, and REM sleep behavior disorder in Parkinson's Disease. Neurology. 1998;51:526-9. [pmid: 9710029].
3 Cooper J A, Sagar H J, Jordan N, Harvey N S, Sullivan E V. Cognitive impairment in early, untreated Parkinson's Disease and its relationship to motor disability. Brain. 1991;114:2095-122. [pmid: 1933236].
4 Factor S A, Sanchez-Ramos J R, Weiner W J. Vitamin E therapy in Parkinson's Disease. Adv Neurol. 1990;53:457-61. [pmid: 2239484].
5 Fukunaga H, Kasai T, Yoshidome H. Clinical findings, status of care, comprehensive quality of life, daily life therapy and treatment at home in patients with Parkinson's Disease. Eur Neurol. 1997;38:64-9. [pmid: 9387806].
6 Goetz C G, Stebbins G T. Mortality and hallucinations in nursing home patients with advanced Parkinson's Disease. Neurology. 1995;45:669-71. [pmid: 7723953].
7 Goetz C G, Stebbins G T. Risk factors for nursing home placement in advanced Parkinson's Disease. Neurology. 1993;43:2227-9. [pmid: 8232934].
8 Haaland K Y, Harrington D L, O'Brien S, Hermanowicz N. Cognitive-motor learning in Parkinson's Disease. Neuropsychology. 1997;11:180-6. [pmid: 9110325].
9 Ho A K, Iansek R, Bradshaw J L. Regulation of parkinsonian speech volume: The effect of interlocuter distance. J Neurol Neurosurg Psychiatry. 1999;67:199-202. [pmid: 10406989].
10 Horstink M W, Berger H J, van Spaendonck K P, van den Bercken J H, Cools A R. Bimanual simultaneous motor performance and impaired ability to shift attention in Parkinson's Disease. J Neurol Neurosurg Psychiatry. 1990;53:685-90. [pmid: 2213046].
11 Klein C, Kompf D, Pulkowski U, Moser A, Vieregge P. A study of visual hallucinations in patients with Parkinson's Disease. J Neurol. 1997;244:371-7. [pmid: 9249622].
12 Llau M E, Durrieu G, Tran M A, Senard J M, Rascol O, Montastruc J L. A study of dopaminergic sensitivity in Parkinson's Disease: Comparison in “de novo” and levodopa-treated patients. Clin Neuropharmacol. 1996;19:420-7. [pmid: 8889285].
13 Mahieux F, Fenelon G, Flahault A, Manifacier M J, Michelet D, Boller F. Neuropsychological prediction of dementia in Parkinson's Disease. J Neurol Neurosurg Psychiatry. 1998;64:178-83. [pmid: 9489527].
14 Marder K, Tang M X, Cote L, Stern Y, Mayeux R. The frequency and associated risk factors for dementia in patients with Parkinson's Disease. Arch Neurol. 1995;52:695-701. [pmid: 7619026].
15 Menza M A, Golbe L I, Cody R A, Forman N E. Dopamine-related personality traits in Parkinson's Diease. Neurology. 1993;43:505-8. [pmid: 8450991].
16 Mindham R H, Biggins C A, Boyd J L, Harrop F M, Madeley P, Randall J I, et al. A controlled study of dementia in Parkinson'sDisease over 54 months. Adv Neurol. 1993;60:470-4. [pmid: 8420172].
17 Otake K, Oiso Y, Mitsuma T, Hirooka Y, Adachi K. Hypothalamic dysfunction in Parkinson's Disease patients. Acta Med Hung. 1994;50:3-13. [pmid: 7638039].
18 Pappert E J, Goetz C G, Niederman F G, Raman R, Leurgans S. Hallucinations, sleep fragmentation, and altered dream phenomena in Parkinson's Disease. Mov Disord. 1999;14:117-21. [pmid: 9918353].
19 Pinter M M, Alesch F, Murg M, Helscher R J, Binder H. Apomorphine test: A predictor for motor responsiveness to deep brain stimulation of the subthalamic nucleus. J Neurol. 1999;246:907-13. [pmid: 10552237].
20 Schrag A, Ben-Shlomo Y, Brown R, Marsden C D, Quinn N. Young-onset Parkinson's Disease revisited - clinical features, natural history, and mortality. Mov Disord. 1998;13:885-94. [pmid: 9827611].
21 Stern Y, Richards M, Sano M, Mayeux R. Comparison of cognitive changes in patients with Alzheimer's and Parkinson's Disease. Arch Neurol. 1993;50:1040-5. [pmid: 8215961].
22 Stern Y, Tang M X, Jacobs D M, Sano M, Marder K, Bell K, et al. Prospective comparative study of the evolution of probable Alzheimer's Disease and Parkinson's Disease dementia. J Int Neuropsychol Soc. 1998;4:279-84. [pmid: 9623002].
23 Stroudley J, Walsh M. Radiological assessment of dysphagia in Parkinson's Disease. Br J Radiol. 1991;64:890-3. [pmid: 1954529].
24 West R, Ergis A M, Winocur G, Saint-Cyr J. The contribution of impaired working memory monitoring to performance of the self-ordered pointing task in normal aging and Parkinson's Disease. Neuropsychology. 1998;12:546-54. [pmid: 9805324].

### Rejection Reason: Studies published prior to 1990

1 Ahlskog J E, Muenter M D. Treatment of Parkinson's Disease with pergolide: A double-blind study. Mayo Clin Proc. 1988;63:969-78. [pmid: 3050300].
2 Allain H, Denmat J, Bentue-Ferrer D, Milon D, Pignol P, Reymann J M, et al. Randomized, double-blind trial of exifone versus cognitive problems in Parkinson's Disease. Fundam Clin Pharmacol. 1988;2:1-12. [pmid: 3286439].
3 Andersen K, Balldin J, Gottfries C G, Granerus A K, Modigh K, Svennerholm L, et al. A double-blind evaluation of electroconvulsive therapy in Parkinson's Disease with “on-off” phenomena. Acta Neurol Scand. 1987;76:191-9. [pmid: 2446463].
4 Baas H, Schneider E, Fischer P A, Japp G. Mesulergine and bromocriptine in long-term treatment of advanced parkinsonism. J Neural Transm. 1985;64:45-54. [pmid: 4067602].
5 Bermejo F, Calandre L, Molina J A, Martinez P, De Yebenes J G. Long-lasting drug holiday in Parkinson's Disease. Adv Neurol. 1987;45:503-6. [pmid: 3103392].
6 Biary N, Pimental P A, Langenberg P W. A double-blind trial of clonazepam in the treatment of parkinsonian dysarthria. Neurology. 1988;38:255-8. [pmid: 3277083].
7 Birkmayer W, Birkmayer G J. Nicotinamidadenindinucleotide (NADH): The new approach in the therapy of Parkinson's Disease. Ann Clin Lab Sci. 1989;19:38-43. [pmid: 2644889].
8 Birkmayer W, Knoll J, Reiderer P, Youdim M B, Hars V, Marton J. Increased life expectancy resulting from addition of L-deprenyl to Madopar treatment in Parkinson's Disease: A longterm study. J Neural Transm. 1985;64:113-27. [pmid: 3935752].
9 Blin J, Bonnet A M, Agid Y. Does levodopa aggravate Parkinson's Disease. Neurology. 1988;38:1410-6. [pmid: 3412589].
10 Bruno G, Ruggieri S, Chase T N, Bakker K, Tamminga C A. Caerulein treatment of Parkinson's Disease. Clin Neuropharmacol. 1985;8:266-70. [pmid: 3899353].
11 Bush D F, Liss C L, Morton A. An open multicenter long-term treatment evaluation of Sinemet CR. Neurology. 1989;39:101-4. [pmid: 2685646].
12 Cantello R, Aguggia M, Gilli M, Delsedime M, Chiardo C I, Riccio A, et al. Major depression in Parkinson's Disease and the mood response to intravenous methylphenidate: Possible role of the “hedonic” dopamine synapse. J Neurol Neurosurg Psychiatry. 1989;52:724-31. [pmid: 2664088].
13 Cedarbaum J M, Breck L, Kutt H, McDowell F H. Controlled-release levodopa/carbidopa. II. Sinemet CR4 treatment of response fluctuations in Parkinson's Disease. Neurology. 1987;37:1607-12. [pmid: 3658164].
14 Cedarbaum J M, Kutt H, McDowell F H. Clinical significance of the relationship between O-methyldopa levels and levodopa intake. Neurology. 1988;38:533-6. [pmid: 3352906].
15 Chouza C, Caamano J L, de Medina O, Aljanati R, Scaramelli A, Romero S. A combined regimen of subcutaneous lisuride and oral Madopar HBS in Parkinson's Disease. J Neural Transm Suppl. 1988;27:61-70. [pmid: 3042913].
16 Csanda E, Tarczy M. Selegiline in the early and late phases of Parkinson's Disease. J Neural Transm Suppl. 1987;25:105-13. [pmid: 3123597].
17 Deleu D, Jacques M, Michotte Y, Ebinger G. Controlled-release carbidopa/levodopa in parkinsonian patients with response fluctuations on standard levodopa treatment: Clinical and pharmacokinetic observations. Neurology. 1989;39:88-92. [pmid: 2685654].
18 Diamond S G, Markham C H, Hoehn M M, McDowell F H, Muenter M D. Multi-center study of Parkinson mortality with early versus later dopa treatment. Ann Neurol. 1987;22:8-12. [pmid: 3631925].
19 Diamond S G, Markham C H, Treciokas L J. Double-blind trial of pergolide for Parkinson's Disease. Neurology. 1985;35:291-5. [pmid: 3883232].
20 Dupont E, Mikkelsen B, Jakobsen J. Mesulergine in early Parkinson's Disease: A double blind controlled trial. J Neurol Neurosurg Psychiatry. 1986;49:390-5. [pmid: 3517235].
21 Elizan T S, Yahr M D, Moros D A, Mendoza M R, Pang S, Bodian C A. Selegiline use to prevent progression of Parkinson's Disease. Experience in 22 de novo patients. Arch Neurol. 1989;46:1275-9. [pmid: 2511824].
22 Elizan T S, Yahr M D, Moros D A, Mendoza M R, Pang S, Bodian C A. Selegiline as an adjunct to conventional levodopa therapy in Parkinson's Disease. Experience with this type b monoamine oxidase inhibitor in 200 patients. Arch Neurol. 1989;46:1280-3. [pmid: 2511825].
23 Factor S A, Sanchez-Ramos J R, Weiner W J. Parkinson's Disease: An open label trial of pergolide in patients failing bromocriptine therapy. J Neurol Neurosurg Psychiatry. 1988;51:529-33. [pmid: 3288717].
24 Fischer P A, Baas H. Therapeutic efficacy of R-(-)-deprenyl as adjuvant therapy in advanced parkinsonism. J Neural Transm Suppl. 1987;25:137-47. [pmid: 3123600].
25 Gauthier L, Dalziel S, Gauthier S. The benefits of group occupational therapy for patients with Parkinson's Disease. Am J Occup Ther. 1987;41:360-5. [pmid: 3688150].
26 Gawel M, Riopelle R, Libman I, Bouchard S. Bromocriptine in the treatment of Parkinson's Disease: A double-blind study against L-dopa/carbidopa. Adv Neurol. 1987;45:535-8. [pmid: 3548263].
27 Giovannini P, Scigliano G, Piccolo I, Soliveri P, Suchy I, Caraceni T. Lisuride in de novo parkinsonian patients: A four-year follow-up. Acta Neurol Scand. 1988;77:322-7. [pmid: 3291546].
28 Goetz C G, Olanow C W, Koller W C, Penn R D, Cahill D, Morantz R, et al. Multicenter study of autologous adrenal medullary transplantation to the corpus striatum in patients with advanced Parkinson's Disease. N Eng J Med. 1989;320:337-41.
29 Goetz C G, Tanner C M, Shannon K M, Carroll V S, Klawans H L, Carvey P M, et al. Controlled-release carbidopa/levodopa (CR4-Sinemet) in Parkinson's Disease patients with and without motor fluctuations. Neurology. 1988;38:1143-6. [pmid: 3290706].
30 Golbe L I. Long-term efficacy and safety of Deprenyl (selegiline) in advanced Parkinson's Disease. Neurology. 1989;39:1109-11. [pmid: 2503769].
31 Grimes J D, Delgado M R. Bromocriptine: Problems with low-dose de novo therapy in Parkinson's Disease. Clin Neuropharmacol. 1985;8:73-7. [pmid: 3978651].
32 Grundmann M, Schimrigk K. Levodopa and monoamine oxidase inhibitor combination therapy. J Neural Transm Suppl. 1987;25:115-9. [pmid: 3323420].
33 Hely M A, Morris J G, Rail D, O'Sullivan D J, Williamson P M, Genge S, et al. The Sydney multicentre study of Parkinson's Disease. The first 18 months. Med J Aust. 1987;146:195-8. [pmid: 3553878].
34 Hely M A, Morris J G, Rail D, Reid W G, O'Sullivan D J, Williamson P M, et al. The Sydney multicentre study of Parkinson's Disease: A report on the first 3 years. J Neurol Neurosurg Psychiatry. 1989;52:324-8. [pmid: 2647907].
35 Herskovits E, Yorio A, Leston J. Long term bromocriptine treatment in de novo parkinsonian patients. Medicina (B Aires). 1988;48:345-50. [pmcid: 198880]. [pmid: 3076200].
36 Hoehn M M. Result in chronic levodopa therapy and its modification by bromocriptine in Parkinson's Disease. Acta Neurol Scand. 1985;71:97-106. [pmid: 3984685].
37 Hoehn M M, Elton R L. Low dosages of bromocriptine added to levodopa in Parkinson's Disease. Neurology. 1985;35:199-206. [pmid: 3969207].
38 Hutton J T, Morris J L, Bush D F, Smith M E, Liss C L, Reines S. Multicenter controlled study of Sinemet CR vs Sinemet (25/100) in advanced Parkinson's Disease. Neurology. 1989;39:67-72. [pmid: 2685652].
39 Jankovic J, Orman J. Parallel double-blind study of pergolide in Parkinson's Disease. Adv Neurol. 1987;45:551-4. [pmid: 3548265].
40 Jankovic J, Orman J, Jansson B. Placebo-controlled study of mesulergine in Parkinson's Disease. Neurology. 1985;35:161-5. [pmid: 3881692].
41 Jankovic J, Schwartz K, Vander L C. Comparison of Sinemet CR4 and standard Sinemet: Double blind and long-term open trial in parkinsonian patients with fluctuations. Mov Disord. 1989;4:303-9. [pmid: 2682215].
42 Jansen E N, Meerwaldt J D, Heersema T, van Manen J, Speelman J D. Open multicenter trial with Madopar HBS in parkinsonian patients. Preliminary assessment after short-term treatment. Eur Neurol. 1987;27:88-92.
43 Jensen N O, Dupont E, Hansen E, Mikkelsen B, Mikkelsen B O. A controlled release form of Madopar in parkinsonian patients with advanced disease and marked fluctuations in motor performance. Acta Neurol Scand. 1988;77:422-5. [pmid: 3046226].
44 Kurlan R, Miller C, Knapp R, Murphy G, Shoulson I. Double-blind assessment of potential pergolide-induced cardiotoxicity. Neurology. 1986;36:993-5. [pmid: 3520383].
45 Leeman A L, O'Neill C J, Nicholson P W, Deshmukh A A, Denham M J, Royston J P, et al. Parkinson's Disease in the elderly: Response to and optimal spacing of night time dosing with levodopa. Br J Clin Pharmacol. 1987;24:637-43. [pmid: 3325092].
46 Leenders K L, Palmer A J, Quinn N, Clark J C, Firnau G, Garnett E S, et al. Brain dopamine metabolism in patients with Parkinson's Disease measured with positron emission tomography. J Neurol Neurosurg Psychiatry. 1986;49:853-60. [pmid: 3091770].
47 Libman I, Gawel M J, Riopelle R J, Bouchard S. A comparison of bromocriptine (Parlodel) and levodopa-carbidopa (Sinemet) for treatment of “de novo” Parkinson's Disease patients. Can J Neurol Sci. 1987;14:576-80. [pmid: 3319120].
48 Lieberman A, Gopinathan G, Neophytides A, Pasternack P, Goldstein M. Advanced Parkinson's Disease: Use of partial dopamine agonist, ciladopa. Neurology. 1987;37:863-5. [pmid: 3574692].
49 Lieberman A N, Gopinathan G, Neophytides A, Foo S H. Deprenyl versus placebo in Parkinson Disease: A double-blind study. N Y State J Med. 1987;87:646-9. [pmid: 3124027].
50 Lindvall B, Olsson J E. Treatment of early morning akinesia with low-dose bromocriptine. Adv Neurol. 1987;45:543-5. [pmid: 3548264].
51 Ludin H P. Open clinical study of Madopar HBS. Eur Neurol. 1987;27:73-5. [pmid: 3322838].
52 Ludwig C L, Weinberger D R, Bruno G, Gillespie M, Bakker K, LeWitt P A, et al. Buspirone, Parkinson's Disease, and the locus ceruleus. Clin Neuropharmacol. 1986;9:373-8. [pmid: 2873889].
53 Mark M H, Sage J I. Controlled-release carbidopa-levodopa (Sinemet) in combination with standard Sinemet in advanced Parkinson's Disease. Ann Clin Lab Sci. 1989;19:101-6. [pmid: 2665626].
54 Mark M H, Sage J I. Long-term efficacy of controlled-release carbidopa/levodopa in patients with advanced Parkinson's Disease. Ann Clin Lab Sci. 1989;19:415-21. [pmid: 2690730].
55 Markham C H, Diamond S G. Long-term follow-up of early dopa treatment in Parkinson's Disease. Ann Neurol. 1986;19:365-72. [pmid: 3707088].
56 Markham C H, Diamond S G. Modification of Parkinson's Disease by long-term levodopa treatment. Arch Neurol. 1986;43:405-7. [pmid: 3082316].
57 Marti M J, Obeso J A, Carrera N, Martinez-Lage J M. Aggravation of Parkinson's Disease by Cinnarizine. J Neurol Neurosurg Psychiatry. 1987;50:804-5. [pmid: 3302112].
58 Melamed E. Initiation of levodopa therapy in parkinsonian patients should be delayed until the advanced stages of the disease. Arch Neurol. 1986;43:402-5. [pmid: 3082315].
59 Meneghetti G, Bracco F, Giometto B, Ferla S, Schergna E. Therapeutic effect of lisuride in advanced Parkinson's Disease. Eur Neurol. 1986;25:74-80. [pmid: 3510126].
60 Montastruc J L, Rascol O, Rascol A. A randomised controlled study of bromocriptine versus levodopa in previously untreated parkinsonian patients: A 3 year follow-up. J Neurol Neurosurg Psychiatry. 1989;52:773-5. [pmid: 2664089].
61 Myllyla V V, Sotaniemi K A, Tuominen J, Heinonen E H. Selegiline as primary treatment in early phase Parkinson's Disease: An interim report. Acta Neurol Scand. 1989;126:177-82.
62 Nakanishi T, Mizuno Y, Goto I, Iwata M, Kanazawa I, Kowa H, et al. A nation-wide collaborative study on the long-term effects of bromocriptine in patients with Parkinson's Disease. First interim report in Japan. Eur Neurol. 1988;28:3-8. [pmid: 3378560].
63 Nordera G P, Lorizio A, Lion P, Durisotti C, D'Andrea G, Ferro-Milone F. Treatment of parkinsonian conditions with a controlled-release form of levodopa: Preliminary study. Eur Neurol. 1987;27:76-80. [pmid: 3322839].
64 Olanow C W, Alberts M J. Double-blind controlled study of pergolide mesylate in the treatment of Parkinson's Disease. Clin Neuropharmacol. 1987;10:178-85. [pmid: 3332611].
65 Olanow C W, Alberts M J. Double-blind controlled study of pergolide mesylate as an adjunct to Sinemet in the treatment of Parkinson's Disease. Adv Neurol. 1987;45:555-60. [pmid: 3548266].
66 Parkinson Study Group. Effect of deprenyl on the progression of disability in early Parkinson's Disease. N Engl J Med. 1989;321:1364-71. [pmid: 2509910].
67 Parkinson Study Group. DATATOP: A multicenter controlled clinical trial in early Parkinson's Disease. Arch Neurol. 1989;46:1052-60. [pmid: 2508608].
68 Pezzoli G, Tesei S, Ferrante C, Cossutta E, Zecchinelli A, Scarlato G. Madopar HBS in fluctuating parkinsonian patients: Two-year treatment. Mov Disord. 1988;3:37-45. [pmid: 3050471].
69 Pfeiffer R F, Wilken K, Glaeske C, Lorenzo A S. Low-dose bromocriptine therapy in Parkinson's Disease. Arch Neurol. 1985;42:586-8. [pmid: 4004603].
70 Poewe W H, Lees A J, Stern G M. Low-dose L-dopa therapy in Parkinson's Disease: A 6-year follow-up study. Neurology. 1986;36:1528-30. [pmid: 3762973].
71 Pollak P, Mallaret M, Gaio J M, Hommel M, Perret J. Blood pressure effects of apomorphine and domperidone in parkinsonism. Adv Neurol. 1987;45:263-6. [pmid: 3548261].
72 Przuntek H, Kuhn W. The effect of R-(-)-deprenyl in de novo Parkinson patients on combination therapy with levodopa and decarboxylase inhibitor. J Neural Transm Suppl. 1987;25:97-104. [pmid: 3123607].
73 Rinne U K. Lisuride, a dopamine agonist in the treatment of early Parkinson's Disease. Neurology. 1989;39:336-9. [pmid: 2927639].
74 Rinne U K. Early combination of bromocriptine and levodopa in the treatment of Parkinson's Disease: A 5-year follow-up. Neurology. 1987;37:826-8. [pmid: 3574685].
75 Rinne U K. Combined bromocriptine-levodopa therapy early in Parkinson's Disease. Neurology. 1985;35:1196-8. [pmid: 4022354].
76 Riopelle R J. Bromocriptine and the clinical spectrum of Parkinson's Disease. Can J Neurol Sci. 1987;14:455-9. [pmid: 3676920].
77 Riopelle R J, Gawel M J, Libman I, King D B, McLean D R, Paulseth R, et al. A double-blind study of bromocriptine and L-dopa in de novo Parkinson's Disease. Short-term results. Eur Neurol. 1988;28:11-4. [pmid: 3288477].
78 Robertson H A, Robertson G S. Combined L-dopa and bromocriptine therapy for Parkinson's Disease: A proposed mechanism of action. Clin Neuropharmacol. 1987;10:384-7. [pmid: 3503682].
79 Sage J I, Duvoisin R C. Pergolide therapy in Parkinson's Disease: A double-blind, placebo-controlled study. Clin Neuropharmacol. 1985;8:260-5. [pmid: 3899352].
80 Selby G. The addition of bromocriptine to long-term dopa therapy in Parkinson's Disease. Clin Exp Neurol. 1989;26:129-39. [pmid: 2701877].
81 Shoulson I. Deprenyl and tocopherol antioxidative therapy of parkinsonism (DATATOP). Acta Neurol Scand Suppl. 1989;126:171-5. [pmid: 2515723].
82 Sivertsen B, Dupont E, Mikkelsen B, Mogensen P, Rasmussen C, Boesen F, et al. Selegiline and levodopa in early or moderately advanced Parkinson's disease: A double-blind controlled short- and long-term study. Acta Neurol Scand. 1989;126:147-52.
83 Staal-Schreinemachers A L, Wesseling H, Kamphuis D J, Burg W, Lakke J P. Low-dose bromocriptine therapy in Parkinson's Disease: Double-blind, placebo-controlled study. Neurology. 1986;36:291-3. [pmid: 3511405].
84 Suchy I, Rinne U K, Wachtel H. Evaluation of terguride in patients with Parkinson's Disease. Adv Neurol. 1987;45:577-81. [pmid: 3548267].
85 Tetrud J W, Langston J W. The effect of deprenyl (selegiline) on the natural history of Parkinson's Disease. Science. 1989;245:519-22. [pmid: 2502843].
86 Tetrud J W, Langston J W. R-(-)-deprenyl as a possible protective agent in Parkinson's Disease. J Neural Transm Suppl. 1987;25:69-79. [pmid: 3123606].
87 Teychenne P F, Bergsrud D, Elton R L, Racy A. Bromocriptine: Long-term low-dose therapy in Parkinson's Disease. Clin Neuropharmacol. 1986;9:138-45. [pmid: 3708599].
88 Tolosa E, Blesa R, Bayes A, Forcadell F. Low-dose bromocriptine in the early phases of Parkinson's Disease. Clin Neuropharmacol. 1987;10:168-74. [pmid: 3332610].
89 Toyokura Y, Mizuno Y, Kase M, Sobue I, Kuroiwa Y, Narabayashi H, et al. Effects of bromocriptine on parkinsonism. A nation-wide collaborative double-blind study. Acta Neurol Scand. 1985;72:157-70. [pmid: 3901650].
90 UK Bromocriptine Research Group. Bromocriptine in Parkinson's Disease: A double-blind study comparing “low-slow” and “high-fast” introductory dosage regimens in de novo patients. J Neurol Neurosurg Psychiatry. 1989;52:77-82. [pmid: 2651567].
91 Ulm G, Fornadi F. R-(-)-deprenyl in the treatment of end-of-dose akinesia. J Neural Transm Suppl. 1987;25:163-72. [pmid: 3123603].
92 Wallis W E. A progress report on the New Zealand multicentre Parkinson's Disease trial. A comparison of low-dose treatment with bromocriptine or L-dopa. Eur Neurol. 1988;28:9-10. [pmid: 3288479].
93 Weiner W J, Berger J R. Effect of ciladopa on Parkinson's Disease: A preliminary report. Adv Neurol. 1987;45:583-6. [pmid: 3548268].
94 Weiner W J, Factor S A, Sanchez-Ramos J, Berger J. A double-blind evaluation of ciladopa in Parkinson's Disease. Mov Disord. 1987;2:211-7. [pmid: 3332914].
95 Yahr M D, Elizan T S, Moros D. Selegiline in the treatment of Parkinson's Disease: Long term experience. Acta Neurol Scand Suppl. 1989;126:157-61. [pmid: 2515721].
96 Ziegler M, Fournier V, Bathien N, Morselli P L, Rondot P. Therapeutic response to progabide in neuroleptic and L-dopa-induced dyskinesias. Clin Neuropharmacol. 1987;10:238-46. [pmid: 2900682].

### Rejection Reason: Studies that are not RCTs

1 Anderson T J, Ewer T C, Gilchrist N L, Donaldson I M. Trial of Sinemet CR4 in patients with Parkinson's Disease. N Z Med J. 1992;105:81-2. [pmid: 1545941].
2 Bedard M A, Pillon B, Dubois B, Duchesne N, Masson H, Agid Y. Acute and long-term administration of anticholinergics in Parkinson's Disease: Specific effects on the subcortico-frontal syndrome. Brain Cogn. 1999;40:289-313. [pmid: 10413563].
3 Bennett J P, Landow E R, Dietrich S, Schuh L A. Suppression of dyskinesias in advanced Parkinson's Disease: Moderate daily clozapine doses provide long-term dyskinesia reduction. Mov Disord. 1994;9:409-14. [pmid: 7969207].
4 Bergamasco B, Benna P, Scarzella L. Long-term bromocriptine treatment of de novo patients with Parkinson's Disease: A seven-year follow-up. Acta Neurol Scand. 1990;81:383-7. [pmid: 2375237].
5 Bergamasco B, Benna P, Scarzella L. Long-term bromocriptine treatment of de novo patients with Parkinson's Disease. A seven-year follow-up. Acta Neurol Scand. 1990;81:383-7. [pmid: 2375237].
6 Brannan T, Yahr M D. Comparative study of selegiline plus L-dopa-carbidopa versus L-dopa-carbidopa alone in the treatment of Parkinson's Disease. Ann Neurol. 1995;37:95-8. [pmid: 7818264].
7 Brooks D J, Abbott R J, Lees A J, Martignoni E, Philcox D V, Rascol O, et al. A placebo-controlled evaluation of ropinirole, a novel D2 agonist, as sole dopaminergic therapy in Parkinson's Disease. Clin Neuropharmacol. 1998;21:101-7. [pmid: 9579296].
8 Bulling M T, Wing L M, Burns R J. Controlled release levodopa/carbidopa (Sinemet CR4) in Parkinson's Disease: An open evaluation of efficacy and safety. Aust N Z J Med. 1991;21:397-400. [pmid: 1953526].
9 Calzetti S, Negrotti A, Cassio A. L-deprenyl as an adjunct to low-dose bromocriptine in early Parkinson's Disease: A short-term, double-blind, and prospective follow-up study. Clin Neuropharmacol. 1995;18:250-7. [pmid: 8635183].
10 Caraceni T, Scigliano G, Musicco M. The occurence of motor fluctuations in parkinsonian patients treated long term with levodopa: Role of early treatment and disease progression. Neurology. 1991;41:380-4. [pmid: 2006005].
11 Cedarbaum J M, Gandy S E, McDowell F H. “Early” initiation of levodopa treatment does not promote the development of motor response fluctuations, dyskinesias, or dementia in Parkinson's Disease. Neurology. 1991;41:622-9. [pmid: 2027475].
12 Churchyard A, Mathias C J, Boonkongchuen P, Lees A J. Autonomic effects of selegiline: Possible cardiovascular toxicity in Parkinson's Disease. J Neurol Neurosurg Psychiatry. 1997;63:228-34. [pmid: 9285463].
13 Contin M, Riva R, Martinelli P, Albani F, Baruzzi A. Relationship between levodopa concentration, dyskinesias, and motor effect in parkinsonian patients: A 3-year follow-up study. Clin Neuropharmacol. 1997;20:409-18. [pmid: 9331517].
14 Contin M, Riva R, Martinelli P, Cortelli P, Albani F, Baruzzi A. A levodopa kinetic-dynamic study of the rate of progression in Parkinson's Disease. Neurology. 1998;51:1075-80. [pmid: 9781532].
15 Dewey R B J, Maraganore D M, Ahlskog J E, Matsumoto J Y. Intranasal apomorphine rescue therapy for parkinsonian “off” periods. Clin Neuropharmacol. 1996;19:193-201. [pmid: 8726538].
16 Djaldetti R, Melamed E. Levodopa ethylester: A novel rescue therapy for response fluctuations in Parkinson's Disease. Ann Neurol. 1996;39:400-4. [pmid: 8602763].
17 Elizan T S, Yahr M D, Moros D A, Mendoza M R, Pang S, Bodian C A. L-deprenyl, a MAO-B inhibitor, as an adjunct to conventional L-dopa therapy in Parkinson's Disease: Experience in 200 patients. Adv Neurol. 1990;53:431-5. [pmid: 2122649].
18 Emre M, Rinne U K, Rascol A, Lees A, Agid Y, Lataste X. Effects of a selective partial D1 agonist, CY 208–243, in de novo patients with Parkinson Disease. Mov Disord. 1992;7:239-43. [pmid: 1535688].
19 Evidente V G, Adler C H, Caviness J N, Gwinn-Hardy K. A pilot study on the motor effects of rimantadine in Parkinson's Disease. Clin Neuropharmacol. 1999;22:30-2. [pmid: 10047931].
20 Fahn S. A pilot trial of high-dose alpha-tocopherol and ascorbate in early Parkinson's Disease. Ann Neurol. 1992;32:S128-32. [pmid: 1510371].
21 Fahn S. An open trial of high-dosage antioxidants in early Parkinson's Disease. Am J Clin Nutr. 1991;53:S380-2.
22 Fahn S, Chouinard S. Experience with tranylcypromine in early Parkinson's Disease. J Neural Transm Suppl. 1998;52:49-61. [pmid: 9564607].
23 Fischer P A, Baas H, Hefner R. Treatment of parkinsonian tremor with clozapine. J Neural Transm Park Dis Dement Sect. 1990;2:233-8. [pmid: 2257063].
24 Fukuyama H, Kawamura J, Akiguchi I, Kimura J, Imai T. Bromocriptine therapy in early-stage Parkinson's Disease. Eur Neurol. 1996;36:164-70. [pmid: 8738948].
25 Funfgeld E W. Computerised brain electrical activity findings of Parkinson patients suffering from hyperkinetic side effects (hypersensitive dopamine syndrome) and a review of possible sources. J Neural Transm Suppl. 1995;46:351-65. [pmid: 8821071].
26 Furukawa Y, Mizuno Y, Narabayashi H. Early-onset parkinsonism with dystonia. Clinical and biochemical differences from hereditary progressive dystonia or dopa-responsive dystonia. Adv Neurol. 1996;69:327-37. [pmid: 8615147].
27 Ghika J, Gachoud J P, Gasser U. Clinical efficacy and tolerability of a new levodopa/benserazide dual-release formulation in parkinsonian patients. Clin Neuropharmacol. 1997;20:130-9. [pmid: 9099465].
28 Giladi N, Honigman S, Hocherman S. The effect of deprenyl treatment on directional and velocity control of arm movement in patients with early stages of Parkinson's Disease. Clin Neuropharmacol. 1999;22:54-9. [pmid: 10047935].
29 Grandas F, Martinez-Martin P, Linazasoro G. Quality of life in patients with Parkinson's Disease who transfer from standard levodopa to Sinemet CR: The STAR study. J Neurol. 1998;245:S31-3. [pmid: 9617721].
30 Hauser R A, Gauger L, Anderson W M, Zesiewicz T A. Pramipexole-induced somnolence and episodes of daytime sleep. Mov Disord. 2000;15:658-63. [pmid: 10928575].
31 Hubble J P, Koller W C, Cutler N R, Sramek J J, Friedman J, Goetz C, et al. Pramipexole in patients with early Parkinson's Disease. Clin Neuropharmacol. 1995;18:338-47. [pmid: 8665547].
32 Hutton J T, Morris J L. Long-term evaluation of Sinemet CR in parkinsonian patients with motor fluctuations. Can J Neurol Sci. 1991;18:467-71. [pmid: 1782612].
33 Jansen E N. Clozapine in the treatment of tremor in Parkinson's Disease. Acta Neurol Scand. 1994;89:262-5. [pmid: 8042443].
34 Jansen E N, Meerwaldtt J D. Madopar HBS in nocturnal symptoms of Parkinson's Disease. Adv Neurol. 1990;53:527-31. [pmid: 2239493].
35 Jansen S E, Ballering L A. Combined and selective monoamine oxidase inhibition in the treatment of depression in Parkinson's Disease. Adv Neurol. 1999;80:505-8. [pmid: 10410764].
36 Jori M C, Franceschi M, Giusti M C, Canal N, Piolti R, Frattola L, et al. Clinical experience with cabergoline, a new ergoline derivative, in the treatment of Parkinson's Disease. Adv Neurol. 1990;53:539-43. [pmid: 2239494].
37 Koller W C, Block G A, Ahlskog J E, Ahrens S, Cedarbaum J M, Cyhan G, et al. Effect of mk-458 (hpmc) in Parkinson's Disease previously untreated with dopaminergic drugs. A double-blind, placebo-controlled multicenter study. Clin Neuropharmacol. 1991;14:322-9. [pmid: 1913699].
38 Kowa H, Kanazawa I, Goto I, Kuno S, Mizuno Y, Ogawa N, et al. Nine-year follow-up study of bromocriptine monotherapy for Parkinson's Disease. Eur Neurol. 1997;38:23-8. [pmid: 9276197].
39 Kuno S. Progress note on Japanese multicenter bromocriptine monotherapy. Eur Neurol. 1993;33:3-5. [pmid: 8375429].
40 Lees A J. Madopar HBS (hydrodynamically balanced system) in the treatment of Parkinson's Disease. Adv Neurol. 1990;53:475-82. [pmid: 2239487].
41 Lieberman A. Long-term experience with selegiline and levodopa in Parkinson's Disease. Neurology. 1992;42:32-6. [pmid: 1584430].
42 Lieberman A, Fazzini E. Experience with selegiline and levodopa in advanced Parkinson's Disease. Acta Neurol Scand Suppl. 1991;136:66-9. [pmid: 1801539].
43 Linazasoro G, Grandas F, Martinez M P, Bravo J L. Controlled release levodopa in Parkinson's Disease: Influence of selection criteria and conversion recommendations in the clinical outcome of 450 patients. Clin Neuropharmacol. 1999;22:74-9. [pmid: 10202601].
44 Manyam B V, Hare T A, Robbs R, Cubberley V B. Evaluation of equivalent efficacy of sinemet and Sinemet CR in patients with Parkinson's Disease applying levodopa dosage conversion formula. Clin Neuropharmacol. 1999;22:33-9. [pmid: 10047932].
45 Marder K, Tang M X, Alfaro B, Mejia H, Cote L, Jacobs D, et al. Postmenopausal estrogen use and Parkinson's Disease with and without dementia. Neurology. 1998;50:1141-3. [pmid: 9566410].
46 Mestre D R, Blin O, van den Brand C L, Azulay J P, Serratrice G. Effects of L-dopa on spatiotemporal contrast sensitivity in Parkinson's Disease. Adv Neurol. 1996;69:503-11. [pmid: 8615172].
47 Monge A, Barbato L, Nordera G, Stocchi F. An acute and long-term study with a dispersible formulation of levodopa/benserazide (Madopar) in Parkinson's Disease. Eur J Neurol. 1997;4:485-90.
48 Myllyla V V, Sotaniemi K A, Aasly J, Sjaastad O, Rinne U, McIntyre T, et al. An open multicenter study of the efficacy of MDL 72,974A, a monoamine oxidase type b (MAO-B) inhibitor, in Parkinson's Disease. Adv Neurol. 1993;60:676-80. [pmid: 8420209].
49 Nutt J G, Carter J H, Van Houten L, Woodward W R. Short- and long-duration responses to levodopa during the first year of levodopa therapy. Ann Neurol. 1997;42:349-55. [pmid: 9307256].
50 Ogawa N, Kanazawa I, Kowa H, Kuno S, Mizuno Y, Tashiro K, et al. Nationwide multicenter prospective study on the long-term effects of bromocriptine for Parkinson's Disease. Final report of a ten-year follow-up. Eur Neurol. 1997;38:37-49. [pmid: 9387802].
51 Pacchetti C, Martignoni E, Sibilla L, Bruggi P, Turla M, Nappi G. Effectiveness of Madopar HBS plus Madopar standard in patients with fluctuating Parkinson's Disease: Two years of follow-up. Eur Neurol. 1990;30:319-23. [pmid: 2289507].
52 Pahwa R, Koller W C. Treatment of Parkinson's Disease with controlled-release carbidopa/L-dopa. Adv Neurol. 1996;69:487-91. [pmid: 8615169].
53 Pietz K, Hagell P, Odin P. Subcutaneous apomorphine in late stage Parkinson's Disease: A long term follow up. J Neurol Neurosurg Psychiatry. 1998;65:709-16. [pmid: 9810943].
54 Poungvarin N, Viriyavejakul A. L-deprenyl therapy in Thai patients with Parkinson's Disease: Before and after, clinical trial of 50 patients. J Med Assoc Thai. 1990;73:381-6. [pmid: 2123233].
55 Rabey J M, Nissipeanu P, Inzelberg R, Korczyn A D. Beneficial effect of cabergoline, new long-lasting D2 agonist in the treatment of Parkinson's Disease. Clin Neuropharmacol. 1994;17:286-93. [pmid: 9316674].
56 Reardon K A, Shiff M, Kempster P A. Evolution of motor fluctuations in Parkinson's Disease: A longitudinal study over 6 years. Mov Disord. 1999;14:605-11. [pmid: 10435497].
57 Riekkinen M, Riekkinen P J. Alpha 2-adrenergic agonist clonidine for improving spatial working memory in Parkinson's Disease. J Clin Psychopharmacol. 1999;19:444-9. [pmid: 10505586].
58 Ruggieri S, Fabbrini G, Bramante L, DePandis F, Stocchi F, Barbanti P, et al. An open study with reversible MAO-A inhibitors in complicated Parkinson's Disease. Adv Neurol. 1996;69:595-8. [pmid: 8615185].
59 Sampaio C, Coelho T, Castro-Caldas A, Bastos-Lima A, Levy A. The response of “de novo” Parkinson's Disease patients to bromocriptine in a “low and slow” regimen is predictive for prognosis. J Neural Transm Suppl. 1995;45:197-202. [pmid: 8748626].
60 Schneider J S. GM1 ganglioside in the treatment of Parkinson's Disease. Ann N Y Acad Sci. 1998;845:363-73. [pmid: 9668369].
61 Schrag A, Schelosky L, Schloz U, Poewe W. Reduction of parkinsonian signs in patients with Parkinson's Disease by dopaminergic versus anticholinergic single-dose challenges. Mov Disord. 1999;14:252-5. [pmid: 10091618].
62 Schrag A E, Brooks D J, Brunt E, Fuell D, Korczyn A, Poewe W, et al. The safety of ropinirole, a selective nonergoline dopamine agonist, in patients with Parkinson's Disease. Clin Neuropharmacol. 1998;21:169-75. [pmid: 9617508].
63 Shan D E, Yeh S I. Experience of pergolide in the treatment of Chinese parkinsonian patients with dose-related fluctuations. Chin Med J (Taipei). 1995;56:312-8.
64 Sharma J C, Ross I N. Long term role of pergolide as an adjunct therapy in Parkinson's Disease: Influence on disability, blood pressure, weight and levodopa syndrome. Parkinsonism Relat. 1999;5:111-4.
65 Soykan I, Sarosiek I, Shifflett J, Wooten G F, McCallum R W. Effect of chronic oral domperidone therapy on gastrointestinal symptoms and gastric emptying in patients with Parkinson's Disease. Mov Disord. 1997;12:952-7. [pmid: 9399220].
66 Spieker S, Loschmann P, Jentgens C, Boose A, Klockgether T, Dichgans J. Tremorlytic activity of budipine: A quantitative study with long-term tremor recordings. Clin Neuropharmacol. 1995;18:266-72. [pmid: 8635185].
67 Stocchi F, Barbato L, Bramante L, Nordera G, Vacca L, Ruggieri S. Fluctuating parkinsonism: A pilot study of single afternoon dose of levodopa methyl ester. J Neurol. 1996;243:377-80. [pmid: 8741076].
68 Tan E K, Ondo W. Clinical characteristics of pramipexole-induced peripheral edema. Arch Neurol. 2000;57:729-32. [pmid: 10815140].
69 Tashiro K, Goto I, Kanazawa I, Kowa H, Kuno S, Mizuno Y, et al. Eight-year follow-up study of bromocriptine monotherapy for Parkinson's Disease. Eur Neurol. 1996;36:32-7. [pmid: 8791019].
70 Trewin V F, Lawrence C J, Abdulla A J, Pearce V R, Veitch G B, Roach M. Differences in drug prescribing patterns in elderly parkinsonian patients identified at hospital admission. Pharm World Sci. 1997;19:275-8. [pmid: 9443169].
71 Waters C H. Fluoxetine and selegiline--lack of significant interaction. Can J Neurol Sci. 1994;21:259-61. [pmid: 8000982].
72 Zoldan J, Friedberg G, Weizman A, Melamed E. Ondansetron, a 5-HT3 antagonist for visual hallucinations and paranoid delusional disorder associated with chronic L-dopa therapy in advanced Parkinson's Disease. Adv Neurol. 1996;69:541-4. [pmid: 8615178].

### Rejection Reason: Studies with less than 10 patients

1 Alexander G M, Schwartzman R J, Nukes T A, Grothusen J R, Hooker M D. Beta 2-adrenergic agonist as adjunct therapy to levodopa in Parkinson's Disease. Neurology. 1994;44:1511-3. [pmid: 8058159].
2 Bravi D, Davis T L, Mouradian M M, Chase T N. Treatment of Parkinson's Disease with the partial dopamine agonist EMD 49980. Mov Disord. 1993;8:195-7. [pmid: 8097280].
3 Chang M H, Chang T W, Lai P H, Sy C G. Resting tremor only: A variant of Parkinson's Disease or of essential tremor. J Neurol Sci. 1995;130:215-9. [pmid: 8586989].
4 Chen J J, Sun T Y, Lin T H, Lin T S. Spatio-temporal representation of multichannel EMG firing patterns and its clinical applications. Med Eng Phys. 1997;19:420-30. [pmid: 9338882].
5 Contin M, Riva R, Martinelli P, Procaccianti G, Albani F, Baruzzi A. Combined levodopa-anticholinergic therapy in the treatment of Parkinson's Disease. Effect on levodopa bioavailability. Clin Neuropharmacol. 1991;14:148-55. [pmid: 2015611].
6 Dietz M A, Goetz C G, Stebbins G T. Evaluation of a modified inverted walking stick as a treatment for parkinsonian freezing episodes. Mov Disord. 1990;5:243-7. [pmid: 2388642].
7 Eatough V M, Kempster P A, Frankel J P, Curry S H, Rogers D, Lees A J, et al. Effects of L-deprenyl on parkinsonian bradyphrenia. Adv Neurol. 1990;53:441-3. [pmid: 2122651].
8 Factor S A, Brown D. Clozapine prevents recurrence of psychosis in PD. Mov Disord. 1992;7:125-30. [pmid: 1350059].
9 Fischman A J, Bonab A A, Babich J W, Palmer E P, Alpert N M, Elmaleh D R, et al. Rapid detection of Parkinson's Disease by SPECT with altropane: A selective ligand for dopamine transporters. Synapse. 1998;29:128-41. [pmid: 9593103].
10 Frey K A, Koeppe R A, Kilbourn M R, Vander Borght T M, Albin R L, et al. Presynaptic monoaminergic vesicles in Parkinson's Disease and normal aging. Ann Neurol. 1996;40:873-84. [pmid: 9007092].
11 Frost J J, Rosier A J, Reich S G, Smith J S, Ehlers M D, Snyder S H. Positron emission tomographic imaging of the dopamine transporter with 11C-WIN 35,428 reveals marked declines in mild Parkinson's Disease. Ann Neurol. 1993;34:423-31. [pmid: 8363363].
12 Gentil M, Tournier C L, Pollak P, Benabid A L. Effect of bilateral subthalamic nucleus stimulation and dopatherapy on oral control in Parkinson's Disease. Eur Neurol. 1999;42:136-40. [pmid: 10529538].
13 Greene P, Cote L, Fahn S. Treatment of drug-induced psychosis in Parkinson's Disease with clozapine. Adv Neurol. 1993;60:703-6. [pmid: 8420214].
14 Hariz G M, Bergenheim A T, Hariz M I, Lindberg M. Assessment of ability/disability in patients treated with chronic thalamic stimulation for tremor. Mov Disord. 1998;13:78-83. [pmid: 9452330].
15 Innis R B, Seibyl J P, Scanley B E, Laruelle M, Abi-Dargham A, Wallace E, et al. Single proton emission computed tomographic imaging demonstrates loss of striatal dopamine transporters in Parkinson Disease. Proc Natl Acad Sci U S A. 1993;90:11965-9. [pmcid: 48106]. [pmid: 8265656].
16 Klockgether T, Dichgans J. Visual control of arm movement in Parkinson's Disease. Mov Disord. 1994;9:48-56. [pmid: 8139605].
17 Leenders K L, Salmon E P, Tyrrell P, Perani D, Brooks D J, Sager H, et al. The nigrostriatal dopaminergic system assessed in vivo by positron emission tomography in healthy volunteer subjects and patients with Parkinson's Disease. Arch Neurol. 1990;47:1290-8. [pmid: 2123623].
18 LeWitt P A, Bharucha A, Chitrit I, Takis C, Patil S, Schork M A, et al. Perceived exertion and muscle efficiency in Parkinson's Disease: L-dopa effects. Clin Neuropharmacol. 1994;17:454-9. [pmid: 9316695].
19 Limousin P, Pollak P, Hoffmann D, Benazzouz A, Perret J E, Benabid A L. Abnormal involuntary movements induced by subthalamic stimulation in parkinsonian patients. Mov Disord. 1998;11:231-5. [pmid: 8723137].
20 Lindvall O, Brundin P, Widner H, Rehncrona S, Gustavii B, Frackowiak R, et al. Grafts of fetal dopamine neurons survive and improve motor function in Parkinson's Disease. Science. 1990;247:574-7. [pmid: 2105529].
21 Manson A J, Iakovidou E, Lees A J. Idazoxan is ineffective for levodopa-induced dyskinesias in Parkinson's Disease. Mov Disord. 2000;15:336-7. [pmid: 10752589].
22 Morrish P K, Sawle G V, Brooks D J. The rate of progression of Parkinson's Disease. Adv Neurol. 1996;69:427-31. [pmid: 8615162].
23 Pollak P, Benabid A L, Limousin P, Benazzouz A. Chronic intracerebral stimulation in Parkinson's Disease. Adv Neurol. 1997;74:213-20. [pmid: 9348416].
24 Pollak P, Benabid A L, Limousin P, Benazzouz A, Hoffmann D, Le Bas J F, et al. Subthalamic nucleus stimulation alleviates akinesia and rigidity in parkinsonian patients. Adv Neurol. 1996;69:591-4. [pmid: 8615184].
25 Sandor P, Lang A E, Singal S, Angus C. Remoxipride in the treatment of levodopa-induced psychosis. J Clin Psychopharmacol. 1996;16:395-9. [pmid: 8889913].
26 Spieker S, Loschmann P A, Klockgether T. The NMDA antagonist budipine can alleviate levodopa-induced motor fluctuations. Mov Disord. 1999;14:517-9. [pmid: 10348483].
27 Tergau F, Wassermann E M, Paulus W, Ziemann U. Lack of clinical improvement in patients with Parkinson's Disease after low and high frequency repetitive transcranial magnetic stimulation. Electroencephalogr Clin Neurophysiol Suppl. 1999;51:281-8. [pmid: 10590961].
28 Wolters E C, Hurwitz T A, Mak E, Teal P, Peppard F R, Remick R, et al. Clozapine in the treatment of parkinsonian patients with dopaminomimetic psychosis. Neurology. 1990;40:832-4. [pmid: 1970427].
29 Zucco G M, Zaglis D, Wambsganss C S. Olfactory deficits in elderly subjects and Parkinson patients. Percept Mot Skills. 1991;73:895-8. [pmid: 1792139].

### Rejection Reason: Studies with less than 24 weeks of follow-up

1 Alegret M, Vendrell P, Junque C, Valldeoriola F, Nobbe F A, Rumia J, et al. Effects of unilateral posteroventral pallidotomy on ‘on-off’ cognitive fluctuations in Parkinson's Disease. Neuropsychologia. 2000;38:628-33. [pmid: 10689039].
2 Allain H, Cougnard J, Neukirch H C. Selegiline in de novo parkinsonian patients: The French Selegiline Multicenter Trial (FSMT). Acta Neurol Scand. 1991;136:73-8.
3 Allain H, Pollak P, Neukirch H C. Symptomatic effect of selegiline in de novo parkinsonian patients. Mov Disord. 1993;8:S36-40. [pmid: 8302306].
4 Barone P, Bravi D, Bermejo-Pareja F, Marconi R, Kulisevsky J, Malagu S, et al. Pergolide monotherapy in the treatment of early PD: A randomized, controlled study. Neurology. 1999;53:573-9. [pmid: 10449123].
5 Battistin L, Bardin P G, Ferro-Milone F, Ravenna C, Toso V, Reboldi G. Alpha-dihydroergocryptine in Parkinson's Disease: A multicentre randomized double blind parallel group study. Acta Neurol Scand. 1999;99:36-42. [pmid: 9925236].
6 Battistin L, Bardin P G, Ferro-Milone F, Ravenna C, Toso V, Reboldi G. Alpha-dihydroergocryptine in Parkinson's Disease: A multicentre randomized double blind parallel group study. Acta Neurol Scand. 1999;99:36-42. [pmid: 9925236].
7 Bonuccelli U, Ceravolo R, Salvetti S, D'Avino C, Del Dotto P, Rossi G, et al. Clozapine in Parkinson's Disease tremor. Effects of acute and chronic administration. Neurology. 1997;49:1587-90. [pmid: 9409351].
8 Burns J M, Wilkinson S, Kieltyka J, Overman J, Lundsgaarde T, Tollefson T, et al. Analysis of pallidotomy lesion positions using three-dimensional reconstruction of pallidal lesions, the basal ganglia, and the optic tract. Neurosurgery. 1997;41:1303-16. [pmid: 9402582].
9 Churchyard A, Mathias C J, Lees A J. Selegiline-induced postural hypotension in Parkinson's Disease: A longitudinal study on the effects of drug withdrawal. Mov Disord. 1999;14:246-51. [pmid: 10091617].
10 Cole S A, Woodard J L, Juncos J L, Kogos J L, Youngstrom E A, Watts R L. Depression and disability in Parkinson's Disease. J Neuropsychiatry Clin Neurosci. 1996;8:20-5. [pmid: 8845697].
11 Cook R J, Fracchia G, Hoban P, Joffe R, O'Sullivan D. Evolution of a surgical technique for posteroventral pallidotomy using CT/MR fusion and intraoperative macrostimulation. J Clin Neurosci. 1998;5:20-7.
12 Cooper J A, Sagar H J, Doherty S M, Jordan N, Tidswell P, Sullivan E V. Different effects of dopaminergic and anticholinergic therapies on cognitive and motor function in Parkinson's Disease. A follow-up study of untreated patients. Brain. 1992;115:1701-25. [pmid: 1486457].
13 D'Antonio L L, Zimmerman G J, Iacono R P. Changes in health related quality of life in patients with Parkinson's Disease with and without posteroventral pallidotomy. Acta Neurochir (Wien). 2000;142:759-67. [pmcid: 300905]. [pmid: 10955670].
14 Diederich N J, Goetz C G, Raman R, Pappert E J, Leurgans S, Piery V. Poor visual discrimination and visual hallucinations in Parkinson's Disease. Clin Neuropharmacol. 1998;21:289-95. [pmid: 9789709].
15 diPierro C G, Francel P C, Jackson T R, Kamiryo T, Laws E R. Optimizing accuracy in magnetic resonance imaging-guided stereotaxis: A technique with validation based on the anterior commissure-posterior commissure line. J Neurosurg. 1999;90:94-100. [pmid: 10413161].
16 Fernandez H H, Friedman J H, Jacques C, Rosenfeld M. Quetiapine for the treatment of drug-induced psychosis in Parkinson's Disease. Mov Disord. 1999;14:484-7. [pmid: 10348474].
17 Fetoni V, Soliveri P, Monza D, Testa D, Girotti F. Affective symptoms in multiple system atrophy and Parkinson's Disease: Response to levodopa therapy. J Neurol Neurosurg Psychiatry. 1999;66:541-4. [pmid: 10201434].
18 Finali G, Piccirilli M, Rizzuto S. Neuropsychological characteristics of parkinsonian patients with lateralized motor impairment. J Neural Transm Park Dis Dement Sect. 1995;9:165-76. [pmid: 8527001].
19 Friedberg G, Zoldan J, Weizman A, Melamed E. Parkinson psychosis rating scale: A practical instrument for grading psychosis in Parkinson's Disease. Clin Neuropharmacol. 1998;21:280-4. [pmid: 9789707].
20 Friedman J, Lannon M, Comella C, Factor S, Kurlan R, Richard I, et al. Low-dose clozapine for the treatment of drug-induced psychosis in Parkinson's Disease. N Eng J Med. 1999;340:757-63.
21 Friedman J H, Goldstein S, Jacques C. Substituting clozapine for olanzapine in psychiatrically stable Parkinson's Disease patients: Results of an open label pilot study. Clin Neuropharmacol. 1998;21:285-8. [pmid: 9789708].
22 Fukuda M, Kameyama S, Yoshino M, Tanaka R, Narabayashi H. Neuropsychological outcome following pallidotomy and thalamotomy for Parkinson's Disease. Stereotact Funct Neurosurg. 2000;74:11-20. [pmid: 11124660].
23 Goetz C G, Blasucci L M, Leurgans S, Pappert E J. Olanzapine and clozapine: Comparative effects on motor function in hallucinating PD patients. Neurology. 2000;55:789-94. [pmid: 10993997].
24 Goodman S H, Wilkinson S, Overman J, Koller W C, Troster A, Pahwa R, et al. Lesion volume and clinical outcome in stereotactic pallidotomy and thalamotomy. Stereotact Funct Neurosurg. 1998;71:164-72. [pmid: 10461102].
25 Hauser R A, Molho E, Shale H, Pedder S, Dorflinger E E. A pilot evaluation of the tolerability, safety, and efficacy of tolcapone alone and in combination with oral selegiline in untreated Parkinson's Disease patients. Mov Disord. 1998;13:643-7. [pmid: 9686768].
26 Hocherman S, Levin G, Giladi N, Youdim M B. Deprenyl monotherapy improves visuo-motor control in early parkinsonism. J Neural Transm Suppl. 1998;52:63-9. [pmid: 9564608].
27 Horak F B, Frank J, Nutt J. Effects of dopamine on postural control in parkinsonian subjects: Scaling, set, and tone. J Neurophysiol. 1996;75:2380-96. [pmid: 8793751].
28 Hubble J P, Busenbark K L, Wilkinson S, Pahwa R, Paulson G W, Lyons K, et al. Effects of thalamic deep brain stimulation based on tremor type and diagnosis. Mov Disord. 1997;12:337-41. [pmid: 9159728].
29 Iacono R P, Lonser R R, Mandybur G, Yamada S. Stimulation of the globus pallidus in Parkinson's Disease. Br J Neurosurg. 1995;9:505-10. [pmid: 7576277].
30 Italian Parkinson Study Group. A multicenter Italian randomised study on early treatment of Parkinson Disease: Comparison of L-dopa, L-deprenyl and dopaminoagonists. Study design and short term results. Ital J Neurol Sci. 1992;13:735-9. [pmid: 1362394].
31 Jansen E N, Staal-Schreinemachers A, van der Sande J J, Haas J A, Lakke J P. Parlodel SRO in Parkinson's Disease: A double-blind randomized comparison of Parlodel standard and Parlodel SRO. Eur Neurol. 1992;32:318-20. [pmid: 1490497].
32 Kazumata K, Antonini A, Dhawan V, Moeller J R, Alterman R L, Kelly P, et al. Preoperative indicators of clinical outcome following stereotaxic pallidotomy. Neurology. 1997;49:1083-90. [pmid: 9339694].
33 Kopyov O, Jacques D, Duma C, Buckwalter G, Kopyov A, Lieberman A, et al. Microelectrode-guided posteroventral medial radiofrequency pallidotomy for Parkinson's Disease. J Neurosurg. 1997;87:52-9. [pmid: 9202265].
34 Kuhn W, Heye N, Muller T, Kraus P, Klotz P, Friedrich B, et al. The motor performance test series in Parkinson's Disease is influenced by depression. J Neural Transm. 1996;103:349-54. [pmid: 8739846].
35 Kuhn W, Muller T, Gerlach M, Sofic E, Fuchs G, Heye N, et al. Depression in Parkinson's Disease: Biogenic amines in CSF of “de novo” patients. J Neural Transm. 1996;103:1441-5. [pmid: 9029411].
36 Lacritz L H, Cullum C M, Frol A B, Dewey R B, Giller C A. Neuropsychological outcome following unilateral stereotactic pallidotomy in intractable Parkinson's Disease. Brain Cogn. 2000;42:364-78. [pmid: 10753485].
37 Limousin P, Greene J, Pollak P, Rothwell J, Benabid A L, Frackowiak R. Changes in cerebral activity pattern due to subthalamic nucleus or internal pallidum stimulation in Parkinson's Disease. Ann Neurol. 1997;42:283-91. [pmid: 9307248].
38 Lozano A M, Lang A E, Hutchison W D, Dostrovsky J O. Microelectrode recording-guided posteroventral pallidotomy in patients with Parkinson's Disease. Adv Neurol. 1997;74:167-74. [pmid: 9348412].
39 MacMahon D G, Sachdev D, Boddie H G, Ellis C J, Kendal B R, Blackburn N A. A comparison of the effects of controlled-release levodopa (Madopar CR) with conventional levodopa in late Parkinson's Disease. J Neurol Neurosurg Psychiatry. 1990;53:220-3. [pmid: 2182781].
40 Mannen T, Mizuno Y, Iwata M, Goto I, Kanazawa I, Kowa H, et al. A multi-center, double-blind study on slow-release bromocriptine in the treatment of Parkinson's Disease. Neurology. 1991;41:1598-602. [pmid: 1922801].
41 Martinez-Martin P, Grandas F, Linazasoro G, Bravo J L. Conversion to controlled-release levodopa/carbidopa treatment and quality of life as measured by the Nottingham Health Profile. Neurologia. 1999;14:338-43. [pmid: 10570620].
42 Martinez-Martin P, Valldeoriola F, Molinuevo J L, Nobbe F A, Rumia J, Tolosa E, et al. Pallidotomy and quality of life in patients with Parkinson's Disease: An early study. Mov Disord. 2000;15:65-70. [pmid: 10634243].
43 McManus D Q, Arvantis L A, Kowalcyk B B. Quetiapine, a novel antipsychotic: Experience with elderly patients with psychotic disorders. J Clin Psychiatry. 1999;60:292-8. [pmid: 10362435].
44 Meara J, Michelmore E, Hobson P. Use of the GDS-15 geriatric depression scale as a screening instrument for depressive symptomatology in patients with Parkinson's Disease and their carers in the community. Age Ageing. 1999;28:35-8. [pmid: 10203202].
45 Merello M, Nouzeilles M I, Kuzis G, Cammarota A, Sabe L, Betti O, et al. Unilateral radiofrequency lesion versus electrostimulation of posteroventral pallidum: A prospective randomized comparison. Mov Disord. 1999;14:50-6. [pmid: 9918344].
46 Mizuno Y, Kondo T, Narabayashi H. Pergolide in the treatment of Parkinson's Disease. Neurology. 1995;45:S13-21. [pmid: 7715792].
47 Myllyla V V, Jackson M, Larsen J P, Baas H. Efficacy and safety of tolcapone in levodopa-treated Parkinson's disease patients with wearing-off phenomenon: A multicentre, double-blind, randomized, placebo-controlled trial. Eur J Neurol. 1997;4:333-41.
48 Naimark D, Jackson E, Rockwell E, Jeste D V. Psychotic symptoms in Parkinson's Disease patients with dementia. J Am Geriatr Soc. 1996;44:296-9. [pmid: 8600200].
49 Nasser J A, Confort C I, Ferraz A, Bouza A A. Preliminary results in surgery of Parkinson's Disease. Arq Neuropsiquiatr. 1998;56:533-9. [pmid: 9850746].
50 Neufeld M Y, Rabey J M, Orlov E, Korczyn A D. Electroencephalographic findings with low-dose clozapine treatment in psychotic parkinsonian patients. Clin Neuropharmacol. 1996;19:81-6. [pmid: 8867521].
51 Nishiyama K, Sugishita M, Kurisaki H, Sakuta M. Reversible memory disturbance and intelligence impairment induced by long-term anticholinergic therapy. Internal Medicine. 1998;37:514-8. [pmid: 9678684].
52 Ondo W G, Jankovic J, Lai E C, Sankhla C, Khan M, Ben-Arie L, et al. Assessment of motor function after stereotactic pallidotomy. Neurology. 1998;50:266-70. [pmid: 9443490].
53 Parkinson Study Group. A multicenter randomized controlled trial of remacemide hydrochloride as monotherapy for PD. Neurology. 2000;54:1583-8. [pmid: 10762497].
54 Parkinson Study Group. Safety and efficacy of pramipexole in early Parkinson's Disease. A randomized dose-ranging study. JAMA. 1997;278:125-30. [pmid: 9214527].
55 Parkinson Study Group. Cerebrospinal fluid homovanillic acid in the DATATOP study on Parkinson's Disease. Arch Neurol. 1995;52:237-45. [pmid: 7872875].
56 Parkinson Study Group. A controlled trial of lazabemide (ro 19-6327) in levodopa-treated Parkinson's Disease. Arch Neurol. 1994;51:342-7. [pmid: 8155011].
57 Parkinson Study Group. A controlled trial of lazabemide (ro19-6327) in untreated Parkinson's Disease. Ann Neurol. 1993;33:350-6. [pmid: 8489205].
58 Persico A M. Parkinsonian patients report blunted subjective effects of methylphenidate. Exp Clin Psychopharmacol. 1998;6:54-63. [pmid: 9526146].
59 Pfeiffer R F, Hofman R. CQA 206–291 in Parkinson's Disease. Clin Neuropharmacol. 1991;14:170-8. [pmid: 1673089].
60 Pierelli F, Adipietro A, Soldati G, Fattapposta F, Pozzessere G, Scoppetta C. Low dosage clozapine effects on L-dopa induced dyskinesias in parkinsonian patients. Acta Neurol Scand. 1998;97:295-9. [pmid: 9613557].
61 Pillon B, Ertle S, Deweer B, Sarazin M, Agid Y, Dubois B. Memory for spatial location is affected in Parkinson's Disease. Neuropsychologia. 1996;34:77-85. [pmid: 8852695].
62 Piolti R, Appollonio I, Cocco E, Ferrarese C, Frattola L, Rovati L, et al. Treatment of Parkinson's Disease with proglumide, a CCK antagonist. Neurology. 1991;41:749-50. [pmid: 2027496].
63 Rascol O, Lees A J, Senard J M, Pirtosek Z, Brefel C, Montastruc J L, et al. A placebo-controlled study of ropinirole, a new D2 agonist, in the treatment of motor fluctuations of L-dopa-treated parkinsonian patients. Adv Neurol. 1996;69:531-4. [pmid: 8615176].
64 Reber P J, Squire L R. Intact learning of artificial grammars and intact category learning by patients with Parkinson's Disease. Behav Neurosci. 1999;113:235-42. [pmid: 10357448].
65 Schelosky L, Benke T, Poewe W H. Effects of treatment with trihexyphenidyl on cognitive function in early Parkinson's Disease. J Neural Transm Suppl. 1991;33:125-32. [pmid: 1753241].
66 Schneider J S, Roeltgen D P, Mancall E L, Chapas-Crilly J, Rothblat D S, Tatarian G T. Parkinson's Disease: Improved function with GM1 ganglioside treatment in a randomized placebo-controlled study. Neurology. 1998;50:1630-6. [pmid: 9633704].
67 Schneider J S, Roeltgen D P, Rothblat D S, Chapas-Crilly J, Seraydarian L, Rao J. GM1 ganglioside treatment of Parkinson's Disease: An open pilot study of safety and efficacy. Neurology. 1995;45:1149-54. [pmid: 7783880].
68 Spieker S, Breit S, Klockgether T, Dichgans J. Tremorlytic activity of budipine in Parkinson's Disease. J Neural Transm Suppl. 1999;56:165-72. [pmid: 10370910].
69 Spieker S, Eisebitt R, Breit S, Przuntek H, Muller D, Klockgether T, et al. Tremorlytic activity of budipine in Parkinson's Disease. Clin Neuropharmacol. 1999;22:115-9. [pmid: 10202609].
70 Stebbins G T, Gabrieli J D, Masciari F, Monti L, Goetz C G. Delayed recognition memory in Parkinson's Disease: A role for working memory. Neuropsychologia. 1999;37:503-10. [pmid: 10215097].
71 Strafella A, Ashby P, Lozano A, Lang A E. Pallidotomy increases cortical inhibition in Parkinson's Disease. Can J Neurol Sci. 1997;24:133-6. [pmid: 9164690].
72 Temlett J A, Ming A, Saling M, Fritz V U, Blumenfeld A, Bilchik T R, et al. Adjunctive therapy with bromocriptine in Parkinson's Disease. S Afr Med J. 1990;78:680-5. [pmid: 2251616].
73 Teresi J A, Albert S M, Holmes D, Mayeux R. Use of latent class analyses for the estimation of prevalence of cognitive impairment, and signs of stroke and Parkinson's Disease among African-American elderly of central Harlem: Results of the Harlem Aging Project. Neuroepidemiology. 1999;18:309-21. [pmid: 10545783].
74 The Tolcapone Study Group. Efficacy and tolerability of tolcapone compared with bromocriptine in levodopa-treated parkinsonian patients. Mov Disord. 1999;14:38-44. [pmid: 9918342].
75 Thomas V, Reymann J M, Lieury A, Allain H. Assessment of procedural memory in Parkinson's Disease. Prog Neuropsychopharmacol Biol Psychiatry. 1996;20:641-50. [pmid: 8843488].
76 Uitti R J, Wharen R E, Turk M F, Lucas J A, Finton M J, Graff-Radford N R, et al. Unilateral pallidotomy for Parkinson's Disease: Comparison of outcome in younger versus older patients. Neurology. 1997;49:1072-7. [pmid: 9339692].
77 Uitti R J, Wharen R E J, Turk M F. Efficacy of levodopa therapy on motor function after posteroventral pallidotomy for Parkinson's Disease. Neurology. 1998;51:1755-7. [pmid: 9855542].
78 Venneri A, Nichelli P, Modonesi G, Molinari M A, Russo R, Sardini C. Impairment in dating and retrieving remote events in patients with early Parkinson's Disease. J Neurol Neurosurg Psychiatry. 1997;62:410-3. [pmid: 9120464].
79 Vingerhoets G, Lannoo E, van der Linden C, Caemaert J, Vandewalle V, van den Abbeele D, et al. Changes in quality of life following unilateral pallidal stimulation in Parkinson's Disease. J Psychosom Res. 1999;46:247-55. [pmid: 10193915].
80 Welsh M D, Dorflinger E, Chernik D, Waters C. Illness impact and adjustment to Parkinson's Disease: Before and after treatment with Tolcapone. Mov Disord. 2000;15:497-502. [pmid: 10830415].
81 Zipp F, Burklin F, Stecker K, Baas H, Fischer P A. Lamotrigine in Parkinson's Disease: A double blind study. J Neural Transm Park Dis Dement Sect. 1995;10:199-206. [pmid: 9620063].

### Rejection Reason: Study populations not including Parkinson Disease

1 Connor D J, Salmon D P, Sandy T J, Galasko D, Hansen L A, Thal L J. Cognitive profiles of autopsy-confirmed Lewy body variant vs pure Alzheimer Disease. Arch Neurol. 1998;55:994-1000. [pmid: 9678318].
2 Trenkwalder P R. STEPHY II (Starnberg Study on Epidemiology of Parkinsonism and Hypertension). Clin Cardiol. 1998;21:129-30. [pmid: 9491955].