# Appendix H. Accepted Studies Log

### Citation Study Category: Ancillary Treatment

1 Adams S G, Lang A E. Can the Lombard effect be used to improve low voice intensity in Parkinson's Disease. Eur J Disord Commun. 1992;27:121-7. [pmid: 1446099].
2 Comella C L, Stebbins G T, Brown-Toms N, Goetz C G. Physical therapy and Parkinson's Disease: A controlled clinical trial. Neurology. 1994;44:376-8. [pmid: 8145901].
3 Dam M, Tonin P, Casson S, Bracco F, Piron L, Pizzolato G, et al. Effects of conventional and sensory-enhanced physiotherapy on disability of Parkinson's Disease patients. Adv Neurol. 1996;69:551-5. [pmid: 8615180].
4 De Angelis E C, Mourao L F, Ferraz H B, Behlau M S, Pontes P A L, Andrade L A F. Effect of voice rehabilitation on oral communication of Parkinson's Disease patients. Acta Neurol Scand. 1997;96:199-205. [pmid: 9325469].
5 Formisano R, Pratesi L, Modarelli F T, Bonifati V, Meco G. Rehabilitation and Parkinson's Disease. Scand J Rehabil Med. 1992;24:157-60. [pmid: 1411361].
6 Jahanshahi M. Contact with a nurse practitioner: A short-term evaluation study in Parkinson's Disease and dystonia. Behav Pharmacol. 1994;7:189-96.
7 Katsikitis M, Pilowsky I. A controlled study of facial mobility treatment in Parkinson's Disease. J Psychosom Res. 1996;40:387-96. [pmid: 8736419].
8 Mally J, Stone T W. Improvement in parkinsonian symptoms after repetitive transcranial magnetic stimulation. J Neurol Sci. 1999;162:179-84. [pmid: 10202984].
9 Mercer B S. A randomized study of the efficacy of the PROPATH program for patients with Parkinson Disease. Arch Neurol. 1996;53:881-4. [pmid: 8815853].
10 Montgomery E B J, Lieberman A, Singh G, Fries J F. Patient education and health promotion can be effective in Parkinson's Disease: A randomized controlled trial. Am J Med. 1994;97:429-35. [pmid: 7977431].
11 Nagaya M, Kachi T, Yamada T. Effect of swallowing training on swallowing disorders in Parkinson's Disease. Scand J Rehabil Med. 2000;32:11-5. [pmid: 10782935].
12 Pacchetti C, Mancini F, Aglieri R, Fundaro C, Martignoni E, Nappi G, et al. Active music therapy in Parkinson's Disease: An integrative method for motor and emotional rehabilitation. Psychosom Med. 2000;62:386-93. [pmid: 10845352].
Pacchetti C, Aglieri R, Mancini F, Martignoni E, Nappi G H. Active music therapy and Parkinson's Disease: Methods. Funct Neurol. 1998;13:57-67. [pmid: 9584875].
13 Patti F, Reggio A, Nicoletti F, Sellaroli T, Deinite G, Nicoletti Fr. Effects of rehabilitation therapy on parkinsonians' disability and functional independence. J Neuro Rehab. 1996;10:223-31.
14 Platz T, Brown R G, Marsden C D. Training improves the speed of aimed movements in Parkinson's Disease. Brain. 1998;121:505-14. [pmid: 9549526].
15 Ramig L O, Countryman S, O'Brien C, Hoehn M, Thompson L. Intensive speech treatment for patients with Parkinson's Disease: Short-and long-term comparison of two techniques. Neurology. 1996;47:1496-504. [pmid: 8960734].
16 Ramig L O, Countryman S, Thompson L L, Horii Y. Comparison of two forms of intensive speech treatment for Parkinson's Disease. J Speech Hear Res. 1995;38:1232-51. [pmid: 8747817].
Smith M E, Ramig L O, Dromey C, Perez K S, Samandari R H. Intensive voice treatment in Parkinson Disease: Laryngostroboscopic findings. J Voice. 1995;9:453-9. [pmid: 8574314].
17 Reynolds H, Wilson-Barnett J, Richardson G. Evaluation of the role of the Parkinson's Disease nurse specialist. Int J Nurs Stud. 2000;37:337-49. [pmid: 10760541].
18 Schenkman M, Cutson T M, Kuchibhatla M, Chandler J, Pieper C F, Ray L, et al. Exercise to improve spinal flexibility and function for people with Parkinson's Disease: A randomized, controlled trial. J Am Geriatr Soc. 1998;46:1207-16. [pmid: 9777901].
19 Sitzia J, Haddrell V, Rice-Oxley M. Evaluation of a nurse-led multidisciplinary neurological rehabilitation programme using the Nottingham Health Profile. Clin Rehabil. 1998;12:389-94. [pmid: 9796929].
20 Thaut M H, McIntosh G C, Rice R R, Miller R A, Rathbun J, Brault J M. Rhythmic auditory stimulation in gait training for Parkinson's Disease patients. Mov Disord. 1996;11:193-200. [pmid: 8684391].

### Study Category: Diagnosis

1 Antonini A, Leenders K L, Meier D, Oertel W H, Boesiger P, Anliker M. T2 relaxation time in patients with Parkinson's Disease. Neurology. 1993;43:697-700. [pmid: 8469325].
2 Arnold G, Bondy B, Bandmann O, Gasser T, Schwarz J, Trenkwalder C, et al. 3H-spiperone binding to lymphocytes fails in the differential diagnosis of de novo Parkinson syndromes. J Neural Transm Park Dis Dement Sect. 1993;5:107-16. [pmid: 7687443].
3 Becker G, Seufert J, Bogdahn U, Reichmann H, Reiners K. Degeneration of substantia nigra in chronic Parkinson's Disease visualized by transcranial color-coded real-time sonography. Neurology. 1995;45:182-4. [pmid: 7824114].
4 Bellomo G, Santambrogio L, Fiacconi M, Scarponi A M, Ciuffetti G. Plasma profiles of adrenocorticotropic hormone, cortisol, growth hormone and prolactin in patients with untreated Parkinson's Disease. J Neurol. 1991;238:19-22. [pmid: 1851513].
5 Bonuccelli U, Piccini P, Del Dotto P, Rossi G, Corsini G U, Muratorio A. Apomorphine test for dopaminergic responsiveness: A dose assessment study. Mov Disord. 1993;8:158-64. [pmid: 8474482].
6 Booij J, Tissingh G, Boer G J, Speelman J D, Stoof J C, Janssen A G, et al. 123I FP-CIT SPECT shows a pronounced decline of striatal dopamine transporter labelling in early and advanced Parkinson's Disease. J Neurol Neurosurg Psychiatry. 1997;62:133-40. [pmid: 9048712].
7 Burn D J, Sawle G V, Brooks D J. Differential diagnosis of Parkinson's Disease, multiple system atrophy, and Steele-Richardson-Olszewski syndrome: Discriminant analysis of striatal 18F-dopa PET data. J Neurol Neurosurg Psychiatry. 1994;57:278-84. [pmid: 8158173].
Brooks D J, Ibanez V, Sawle G V, Quinn N, Lees A J, Mathias C J, et al. Differing patterns of striatal 18F-dopa uptake in Parkinson's Disease, multiple system atrophy, and progressive supranuclear palsy. Ann Neurol. 1990;28:547-55. [pmid: 2132742].
8 Buttner T, Kuhn W, Muller T, Patzold T, Heidbrink K, Przuntek H. Distorted color discrimination in ‘de novo’ parkinsonian patients. Neurology. 1995;45:386-7. [pmid: 7854545].
9 Buttner T, Kuhn W, Patzold T, Przuntek H. L-dopa improves colour vision in Parkinson's Disease. J Neural Transm Park Dis Dement Sect. 1994;7:13-9. [pmid: 8579766].
10 Caronti B, Tanda G, Colosimo C, Ruggieri S, Calderaro C, Palladini G, et al. Reduced dopamine in peripheral blood lymphocytes in Parkinson's Disease. Neuroreport. 1999;10:2907-10. [pmid: 10549795].
11 D'Costa D F, Abbott R J, Pye I F, Millac P A. The apomorphine test in parkinsonian syndromes. J Neurol Neurosurg Psychiatry. 1991;54:870-2. [pmid: 1744640].
12 Delalande I, Destee A, Hache J C, Forzy G, Bughin M, Benhadjali J. Visual evoked potentials and spatiotemporal contrast sensitivity changes in idiopathic Parkinson's Disease and multiple system atrophy. Adv Neurol. 1996;69:319-25. [pmid: 8615146].
13 Doty R L, Golbe L I, McKeown D A, Stern M B, Lehrach C M, Crawford D. Olfactory testing differentiates between progressive supranuclear palsy and idiopathic Parkinson's Disease. Neurology. 1993;43:962-5. [pmid: 8492953].
14 Doty R L, Stern M B, Pfeiffer C, Gollomp S M, Hurtig H I. Bilateral olfactory dysfunction in early stage treated and untreated idiopathic Parkinson's Disease. J Neurol Neurosurg Psychiatry. 1992;55:138-42. [pmid: 1538221].
15 Eidelberg D, Moeller J R, Ishikawa T, Dhawan V, Spetsieris P, Chaly T, et al. Early differential diagnosis of Parkinson's Disease with F-18-fluorodeoxyglucose and positron emission tomography. Neurology. 1995;45:1995-2004. [pmid: 7501148].
16 Espino A, Calopa M, Ambrosio S, Ortola J, Peres J, Navarro M A. CSF somatostatin increase in patients with early parkinsonian syndrome. J Neural Transm Park Dis Dement Sect. 1995;9:189-96. [pmid: 8527003].
17 Fung V S C, Burne J A, Morris J G L. Objective quantification of resting and activated parkinsonian rigidity: A comparison of angular impulse and work scores. Mov Disord. 2000;15:48-55. [pmid: 10634241].
18 Gasser T, Schwarz J, Arnold G, Trenkwelder C, Oertel W H. Apomorphine test for dopaminergic responsiveness in patients with previously untreated Parkinson's Disease. Arch Neurol. 1992;49:1131-4. [pmid: 1444878].
19 Giobbe D, Castellano G C, Podio V. Dopamine D2 receptor imaging with SPECT using IBZM in 16 patients with Parkinson's Disease. Ital J Neurol Sci. 1993;14:165-9. [pmid: 8509271].
20 Hawkes C H, Shephard B C. Olfactory evoked responses and identification tests in neurological disease. Ann N Y Acad Sci. 1998;855:608-15. [pmid: 9929657].
Hawkes C H, Shephard B C, Daniel S E. Olfactory dysfunction in Parkinson's Disease. J Neurol Neurosurg Psychiatry. 1997;62:436-46. [pmid: 9153598].
21 Holshouser B A, Komu M, Moller H E, Zijlmans J, Kolem H, Hinshaw D B J, et al. Localized proton NMR spectroscopy in the striatum of patients with idiopathic Parkinson's Disease: A multicenter pilot study. Magn Reson Med. 1995;33:589-94. [pmid: 7596261].
22 Hughes A J, Daniel S E, Kilford L, Lees A J. Accuracy of clinical diagnosis of idiopathic Parkinson's Disease: A clinico-pathological study of 100 cases. J Neurol Neurosurg Psychiatry. 1992;55:181-4. [pmid: 1564476].
Hughes A J, Ben-Shlomo Y, Daniel S E, Less A J. What features improve the accuracy of clinical diagnosis in Parkinson's Disease: A clinocopathologic study. Neurology. 1992;42:1142-6. [pmid: 1603339].
Hughes A J, Daniel S E, Blankson S, Lees A J. A clinicopathologic study of 100 cases of Parkinson's Disease. Arch Neurol. 1993;50:140-8. [pmid: 8431132].
23 Hughes A J, Lees A J, Stern G M. Challenge tests to predict the dopaminergic response in untreated Parkinson's Disease. Neurology. 1991;41:1723-5. [pmid: 1944899].
24 Hughes A J, Lees A J, Stern G M. Apomorphine test to predict dopaminergic responsiveness in parkinsonian syndromes. Lancet. 1990;336:32-4. [pmid: 1973218].
25 Imon Y, Matsuda H, Ogawa M, Kogure D, Sunohara N. SPECT image analysis using statistical parametric mapping in patients with Parkinson's Disease. J Nucl Med. 1999;40:1583-9. [pmid: 10520695].
26 Jankovic J, Rajput A H, McDermott M P, Perl D P. The evolution of diagnosis in early Parkinson Disease. Arch Neurol. 2000;57:369-72. [pmid: 10714663].
27 Jimenez-Jimenez F J, Rubio J C, Molina J A, Martin M A, Campos Y, Benito-Leon J, et al. Cerebrospinal fluid carnitine levels in patients with Parkinson's Disease. J Neurol Sci. 1997;145:183-5. [pmid: 9094047].
28 Kaasinen V, Nagren K, Hietala J, Oikonen V, Vilkman H, Farde L, et al. Extrastriatal dopamine D2 and D3 receptors in early and advanced Parkinson's Disease. Neurology. 2000;54:1482-7. [pmid: 10751262].
29 Kraft E, Schwarz J, Trenkwalder C, Vogl T, Pfluger T, Oertel W H. The combination of hypointense and hyperintense signal changes on T2-weighted magnetic resonance imaging sequences: A specific marker of multiple system atrophy. Arch Neurol. 1999;56:225-8. [pmid: 10025428].
30 Lehrner J P, Brucke T, Dal-Bianco P, Gatterer C, Kryspin-Exner I. Olfactory functions in Parkinson's Disease and Alzheimer's Disease. Chem Senses. 1997;22:105-10. [pmid: 9056090].
31 Litvan I, MacIntyre A, Goetz C G, Wenning G K, Jellinger K, Verny M, et al. Accuracy of the clinical diagnoses of Lewy body disease, Parkinson Disease, and dementia with lewy bodies: A clinicopathologic study. Arch Neurol. 1998;55:969-78. [pmid: 9678315].
32 Louis E D, Klatka L A, Liu Y, Fahn S. Comparison of extrapyramidal features in 31 pathologically confirmed cases of diffuse Lewy body disease and 34 pathologically confirmed cases of Parkinson's Disease. Neurology. 1997;48:376-80. [pmid: 9040725].
33 Meara J, Bhowmick B K, Hobson P. Accuracy of diagnosis in patients with presumed Parkinson's Disease. Age Ageing. 1999;28:99-102. [pmid: 10350403].
34 Montgomery E B, Baker K B, Lyons K, Koller W C. Abnormal performance on the PD test battery by asymptomatic first-degree relatives. Neurology. 1999;52:757-62. [pmid: 10078723].
35 Montgomery E B, Koller W C, LaMantia T J K, Newman M C, Swanson-Hyland E, Kaszniak A W, et al. Early detection of probable idiopathic Parkinson's Disease: I. Development of a diagnostic test battery. Mov Disord. 2000;15:467-73. [pmid: 10830410].
36 Montgomery E B, Lyons K, Koller W C. Early detection of probable idiopathic PD: II. A prospective application of a diagnostic test battery. Mov Disord. 2000;15:474-8. [pmid: 10830411].
37 Morrish P K, Sawle G V, Brooks D J. Clinical and [18F] dopa PET findings in early Parkinson's Disease. J Neurol Neurosurg Psychiatry. 1995;59:597-600. [pmid: 7500096].
38 Murofushi T, Mizuno M, Osanai R, Hayashida T. Olfactory dysfunction in Parkinson's Disease. ORL J Otorhinolaryngol Relat Spec. 1991;53:143-6. [pmid: 1852411].
39 Otsuka M, Ichiya Y, Hosokawa S, Kuwabara Y, Tahara T, Fukumura T, et al. Striatal blood flow, glucose metabolism and 18F-dopa uptake: Difference in Parkinson's Disease and atypical parkinsonism. J Neurol Neurosurg Psychiatry. 1991;54:898-904. [pmid: 1744644].
40 Pizzolato G, Cagnin A, Rossato A, Chierichetti F, Fabbri M, Dam M, et al. Striatal dopamine D2 receptor alterations and response to L-dopa in Parkinson's Disease. A [123I]IBZM SPET study. Adv Neurol. 1996;69:467-73. [pmid: 8615167].
41 Potagas C, Dellatolas G, Zeigler M, Leveteau J, Bathien N, Mac Leod P, et al. Clinical assessment of olfactory dysfunction in Parkinson's Disease. Mov Disord. 1998;13:394-9. [pmid: 9613727].
42 Rajput A H, Rozdilsky B, Ang L. Occurence of resting tremor in Parkinson's disease. Neurology. 1991;41:1298-9. [pmid: 1866022].
Rajput A H, Rozdilsky B, Rajput A, Ang L. Levodopa efficacy and pathological basis of Parkinson syndrome. Clin Neuropharmacol. 1990;13:553-8. [pmid: 2276120].
43 Rajput A H, Rozdilsky B, Rajput A. Accuracy of clinical diagnosis in parkinsonism - a prospective study. Can J Neurol Sci. 1991;18:275-8. [pmid: 1913360].
44 Relja M A, Petravic D, Kolaj M. Quantifying rigidity with a new computerized elbow device. Clin Neuropharmacol. 1996;19:148-56. [pmid: 8777768].
45 Rinne J O, Laihinen A, Ruottinen H, Ruotsalainen U, Nagren K, Lehikoinen P, et al. Increased density of dopamine D2 receptors in the putamen, but not in the caudate nucleus in early Parkinson's Disease: A PET study with [11C]raclopride. J Neurol Sci. 1995;132:156-61. [pmid: 8543941].
46 Rinne J O, Portin R, Ruottinen H, Nurmi E, Bergman J, Haaparanta M, et al. Cognitive impairment and the brain dopaminergic system in Parkinson Disease: [18F] Fluorodopa Positron Emission Tomographic study. Arch Neurol. 2000;57:470-5. [pmid: 10768619].
47 Ryvlin P, Broussolle E, Piollet H, Viallet F, Khalfallah Y, Chazot G. Magnetic resonance imaging evidence of decreased putamenal iron content in idiopathic Parkinson's Disease. Arch Neurol. 1995;52:583-8. [pmid: 7763206].
48 Sakuma K, Nakashima K, Takahashi K. Olfactory evoked potentials in Parkinson's Disease, Alzheimer's Disease and anosmic patients. Psychiatry Clin Neurosci. 1996;50:35-40. [pmid: 9201769].
49 Sawle G V, Playford E D, Burn D J, Cunningham V J, Brooks D J. Separating Parkinson's Disease from normality. Discriminant function analysis of fluorodopa F-18 positron emission tomography data. Arch Neurol. 1994;51:237-43. [pmid: 8129633].
50 Schelosky L, Hierholzer J, Wissel J, Cordes M, Poewe W. Correlation of clinical response in apomorphine test with D2-receptor status as demonstrated by 123 I IBZM-SPECT. Mov Disord. 1993;8:453-8. [pmid: 8232354].
51 Schwarz J, Antonini A, Tatsch K, Kirsch C M, Oertel W H, Leenders K L. Comparison of 123I-IBZM SPECT and 11C-raclopride PET findings in patients with parkinsonism. Nucl Med Commun. 1994;15:806-13. [pmid: 7838444].
52 Schwarz J, Kraft E, Vogl T, Arnold G, Tatsch K, Oertel W H, et al. Relative quantification of signal on T2-weighted images in the basal ganglia: Limited value in differential diagnosis of patients with parkinsonism. Neuroradiology. 1999;41:124-7. [pmid: 10090605].
53 Schwarz J, Linke R, Kerner M, Mozley P D, Trenkwalder C, Gasser T, et al. Striatal dopamine transporter binding assessed by [I-123]IPT and single photon emission computed tomography in patients with early Parkinson's Disease: Implications for a preclinical diagnosis. Arch Neurol. 2000;57:205-8. [pmid: 10681078].
54 Schwarz J, Tatsch K, Arnold G, Ott M, Trenkwelder C, Kirsch C M, et al. 123 I-iodobenzamide-SPECT in 83 patients with de novo parkinsonism. Neurology. 1993;43:S17-20. [pmid: 8264906].
Schwarz J, Tatsch K, Arnold G, Gasser T, Trenkwalder C, Kirsch C M, et al. 123 I-iodobenzamide-SPECT predicts dopaminergic responsiveness in patients with ‘de novo’ parkinsonism. Neurology. 1992;42:556-61. [pmid: 1549216].
55 Schwarz J, Tatsch K, Gasser T, Arnold G, Oertel W H. 123-IBZM binding predicts dopaminergic responsiveness in patients with parkinsonism and previous dopaminomimetic therapy. Mov Disord. 1997;12:898-902. [pmid: 9399212].
56 Schwarz J, Tatsch K, Gasser T, Arnold G, Pogarell O, Kunig G, et al. 123I-IBZM binding compared with long-term clinical follow up in patients with de novo parkinsonism. Mov Disord. 1998;13:16-9. [pmid: 9452320].
57 Seibyl J P, Marek K L, Quinlan D, Sheff K, Zoghbi S, Zea-Ponce Y, et al. Decreased single-photon emission computed tomographic [123 I]beta-CIT striatal uptake correlates with symptom severity in Parkinson's Disease. Ann Neurol. 1995;38:589-98. [pmid: 7574455].
58 Tatsch K, Schwarz J, Oertel W H, Kirsch C M. SPECT imaging of dopamine D2 receptors with 123 I- IBZM: Initial experience in controls and patients with Parkinson's syndrome and Wilson's Disease. Nucl Med Commun. 1991;12:699-707. [pmid: 1838142].
59 Wenning G K, Ebersbach G, Verny M, Chaudhuri K R, Jellinger K, McKee A, et al. Progression of falls in postmortem-confirmed parkinsonian disorders. Mov Disord. 1999;14:947-50. [pmid: 10584668].

### Study Category: Pharmacological Treatment

1 Alarcon F. Does combined levodopa and bromocriptine therapy in Parkinson's Disease prevent late motor complications. Eur J Neurol. 1998;5:255-63. [pmid: 10210840].
2 Allain H, Destee A, Petit H, Patay M, Schuck S, Bentue-Ferrer D, et al. Five-year follow-up of early lisuride and levodopa combination therapy versus levodopa monotherapy in de novo Parkinson's Disease. Eur Neurol. 2000;44:22-30. [pmid: 10894991].
3 Baas H, Beiske A G, Ghika J, Jackson M, Oertel W H, Poewe W, et al. Catechol-O-methyltransferase inhibition with tolcapone reduces the “wearing off” phenomenon and levodopa requirements in fluctuating parkinsonian patients. J Neurol Neurosurg Psychiatry. 1997;63:421-8. [pmid: 9343116].
4 Bakheit A M, Henderson L M, Moore A P, Simpson J A, Thomas M. Long-term double masked trial of early treatment with L-dopa plus bromocriptine versus L-dopa alone in Parkinson's Disease. Interim results. Eur Neurol. 1990;30:108-11. [pmid: 2340834].
5 Bergamasco B, Frattola L, Muratorio A, Piccoli F, Mailland F, Parnetti L, et al. Alpha-dihydroergocryptine in the treatment of de novo parkinsonian patients: Results of a multicentre, randomized, double-blind, placebo-controlled study. Acta Neurol. 2000;101:372-80.
6 Bromocriptine Multicentre Trial Group. Bromocriptine as initial therapy in elderly parkinsonian patients. Age Ageing. 1990;19:62-7. [pmid: 2180259].
7 Dupont E, Andersen A, Boas J, Boisen E, Borgmann R, Helgetveit A C, et al. Sustained-release Madopar HBS compared with standard Madopar in the long-term treatment of de novo parkinsonian patients. Acta Neurol Scand. 1996;93:14-20. [pmid: 8825266].
8 Gimenez-Roldan S, Tolosa E, Burguera J A, Chacon J, Liano H, Forcadell F. Early combination of bromocriptine and levodopa in Parkinson's Disease: A prospective randomized study of two parallel groups over a total follow-up period of 44 months including an initial 8-month double-blind stage. Clin Neuropharmacol. 1997;20:67-76. [pmid: 9037575].
9 Guttman M. Double-blind comparison of pramipexole and bromocriptine treatment with placebo in advanced Parkinson's Disease. Neurology. 1997;49:1060-5. [pmid: 9339690].
10 Hely M A, Morris J G, Reid W G, O'Sullivan D J, Williamson P M, Rail D, et al. The Sydney multicentre study of Parkinson's Disease: A randomised, prospective five year study comparing low dose bromocriptine with low dose levodopa-carbidopa. J Neurol Neurosurg Psychiatry. 1994;57:903-10. [pmid: 8057111].
Hely M A, Morris J G, Reid W G, O'Sullivan D J, Williamson P M, Broe G A, et al. Age at onset: The major determinant of outcome in Parkinson's Disease. Acta Neurol Scand. 1995;92:455-63. [pmid: 8750110].
Hely M A, Morris J G, Traficante R, Reid W G, O'Sullivan D J, Williamson P M. The Sydney multicentre study of Parkinson's Disease: Progression and mortality at 10 years. J Neurol Neurosurg Psychiatry. 1999;67:300-7. [pmid: 10449550].
11 Hutton J T, Koller W C, Ahlskog J E, Pahwa R, Hurtig H I, Stern M B, et al. Multicenter, placebo-controlled trial of cabergoline taken once daily in the treatment of Parkinson's Disease. Neurology. 1996;46:1062-5. [pmid: 8780092].
Ahlskog J E, Wright K F, Muenter M D, Adler C H. Adjunctive cabergoline therapy of Parkinson's Disease: Comparison with placebo and assessment of dose responses and duration of effect. Clin Neuropharmacol. 1996;19:202-12. [pmid: 8726539].
Hutton J T, Morris J L, Elias J W. Visual contrast sensitivity in Parkinson's Disease is worsened with cabergoline treatment. Parkinsonism Relat. 1999;5:87-91.
12 Inzelberg R, Nisipeanu P, Rabey J M, Orlov E, Catz T, Kippervasser S, et al. Double-blind comparison of cabergoline and bromocriptine in Parkinson's Disease patients with motor fluctuations. Neurology. 1996;47:785-8. [pmid: 8797480].
13 Kleedorfer B, Poewe W. Comparative efficacy of two oral sustained-release preparations of L-dopa in fluctuating Parkinson's Disease. Preliminary findings in 20 patients. J Neural Transm [P-D Sect]. 1992;4:173-8.
14 Koller W C, Hutton J T, Tolosa E, Capilldeo R. Immediate-release and controlled-release carbidopa/levodopa in PD: A 5-year randomized multicenter study. Neurology. 1999;53:1012-9. [pmid: 10496260].
Block G, Liss C, Reines S, Irr J, Nibbelink D. Comparison of immediate-release and controlled release carbidopa/levodopa in Parkinson's Disease. A multicenter 5-year study. Eur Neurol. 1997;37:23-7. [pmid: 9018028].
Capildeo R. Implications of the 5-year CR FIRST trial. Neurology. 1998;50:S15-7. [pmid: 9633681].
Liss C, Bush D, Last B, Smith B, Block G, Reines S. An interim report of a 5-year clinical study in patients with Parkinson's Disease with no prior levodopa therapy. Clin Drug Invest. 1997;13:15-22.
15 Korczyn A D, Brunt E R, Larsen J P, Nagy Z, Poewe W H, Ruggieri S. A 3-year randomized trial of ropinirole and bromocriptine in early Parkinson's Disease. Neurology. 1999;53:364-70. [pmid: 10430427].
Korczyn A D, Brooks D J, Brunt E R, Poewe W H, Rascol O, Stocchi F. Ropinirole versus bromocriptine in the treatment of early Parkinson's Disease: A 6-month interim report of a 3-year study. Mov Disord. 1998;13:46-51.
16 Kulisevsky J, Garcia-Sanchez C, Berthier M L, Barbanoj M, Pascual-Sedano B, Gironell A, et al. Chronic effects of dopaminergic replacement on cognitive function in Parkinson's Disease: A two-year follow-up study of previously untreated patients. Mov Disord. 2000;15:613-26. [pmid: 10928571].
Kulisevsky J, Lopez-Villegas D, Garcia-Sanchez C, Barbanoj M, Gironell A, Pascual-Sedano B. A six-month study of pergolide and levodopa in de novo Parkinson's Disease patients. Clin Neuropharmacol. 1998;21:358-62. [pmid: 9844794].
17 Kunig G, Pogarell O, Moller J C, Delf M, Oertel W H. Pramipexole, a nonergot dopamine agonist, is effective against rest tremor in intermediate to advanced Parkinson's Disease. Clin Neuropharmacol. 1999;22:301-5. [pmid: 10516884].
18 Larsen J P, Boas J, Erdal J E. the Norwegian-Danish Study Group. Does selegiline modify the progression of early Parkinson's Disease? Results from a five-year study. Eur J Neurol. 1999;6:539-47. [pmid: 10457386].
Larsen J P, Boas J. The effects of early selegiline therapy on long-term levodopa treatment and parkinsonian disability: An interim analysis of a Norwegian-Danish 5-year study. Mov Disord. 1997;12:175-82. [pmid: 9087975].
19 Lees A J. Parkinson's Disease Research Group in the United Kingdom. Comparison of therapeutic effects and mortality data of levodopa and levodopa combined with selegiline in patients with early, mild Parkinson's Disease. BMJ. 1995;311:1602-7. [pmid: 8555803].
Ben-Shlomo Y, Churchyard A, Head J, Hurwitz B, Overstall P, Ockelford J, et al. Investigation by Parkinson's Disease research group of United Kingdom into excess mortality seen with combined levodopa and selegiline treatment in patients with early, mild Parkinson's Disease: Further results of randomised trial and confidential inquiry. BMJ. 1998;316:1191-6. [pmcid: 28519]. [pmid: 9583926].
Parkinson's Disease Research Group in the United Kingdom. Comparisons of therapeutic effects of levodopa, levodopa and selegiline, and bromocriptine in patients with early, mild Parkinson's Disease: Three year interim report. BMJ. 1993;307:469-72. [pmid: 8400928]. [pmcid: 1678739].
20 Lieberman A, Olanow C W, Sethi K, Swanson P, Waters C H, Fahn S, et al. A multicenter trial of ropinirole as adjunct treatment for Parkinson's Disease. Neurology. 1998;51:1057-62. [pmid: 9781529].
21 Lieberman A, Ranhosky A, Korts D. Clinical evaluation of pramipexole in advanced Parkinson's Disease: Results of a double-blind, placebo-controlled, parallel-group study. Neurology. 1997;49:162-8. [pmid: 9222185].
22 MacMahon D G, Overstall P W, Marshall T. Simplification of the initiation of bromocriptine in elderly patients with advanced Parkinson's Disease. Age Ageing. 1991;20:146-51. [pmid: 2053506].
23 Martignoni E, Pacchetti C, Sibilla L, Bruggi P, Pedevilla M, Nappi G. Dihydroergocryptine in the treatment of Parkinson's Disease: A six months' double-blind clinical trial. Clin Neuropharmacol. 1991;14:78-83. [pmid: 1903079].
24 Montastruc J L, Rascol O, Senard J M, Rascol A. A randomised controlled study comparing bromocriptine to which levodopa was later added, with levodopa alone in previously untreated patients with Parkinson's disease: A five year follow up. J Neurol Neurosurg Psychiatry. 1994;57:1034-8. [pmid: 8089666].
25 Myllyla V V, Sotaniemi K A, Vuorinen J A, Heinonen E H. Selegiline as initial treatment in de novo parkinsonian patients. Neurology. 1992;42:339-43. [pmid: 1736162].
Myllyla V V, Heinonen E H, Vuorinen J A, Kilkku O I, Sotaniemi K A. Early selegiline therapy reduces levodopa dose requirement in Parkinson's Disease. Acta Neurol Scand. 1995;91:177-82. [pmid: 7793231].
Myllyla V V, Sotaniemi K A, Hakulinen P, Maki-Ikola O, Heinonen E H. Selegiline as the primary treatment of Parkinson's Disease: A long-term double-blind study. Acta Neurol Scand. 1997;95:211-8. [pmid: 9150811].
Myllyla V V, Sotaniemi K A, Vuorinen J A, Heinonen E H. Selegiline in de novo parkinsonian patients: The Finnish study. Mov Disord. 1993;8:S41-4. [pmid: 8302307].
Myllyla V V, Sotaniemi K A, Vuorinen J A, Heinonen E H. Selegiline as a primary treatment of Parkinson's Disease. Acta Neurol Scand. 1991;84:70-2. [pmid: 1681667].
26 Nakanishi T, Iwata M, Goto I, Kanazawa I, Kowa H, Mannen T, et al. A Nation-wide collaborative study on the long-term effects of bromocriptine in the treatment of parkinsonian patients. Final report. Eur Neurol. 1992;32:9-22. [pmid: 1425821].
Nakanishi T, Kanazawa I, Goto I, Iwata M, Kowa H, Mannen T, et al. Third interim report of the nationwide collaborative study on the long-term effects of bromocriptine in the treatment of parkinsonian patients. Eur Neurol. 1990;30:3-8.
Nakanishi T, Kanazawa I, Iwata M, Goto I, Kowa H, Mannen T, et al. Nation-wide collaborative study on the long-term effects of bromocriptine in the treatment of parkinsonian patients: Analysis on the maintenance and the change of the original mode of treatment. Eur Neurol. 1992;32:23-9. [pmid: 1425818].
Nakanishi T, Mizuno Y, Goto I, Iwata M, Kanazawa I, Kowa H, et al. A nationwide collaborative study on the long-term effects of bromocriptine in patients with Parkinson's Disease The fourth interim report. Eur Neurol. 1991;31:3-16. [pmid: 1906808].
27 Nappi G, Martignoni E, Horowski R, Pacchetti C, Rainer E, Bruggi P, et al. Lisuride plus selegiline in the treatment of early Parkinson's Disease. Acta Neurol Scand. 1991;83:407-10. [pmid: 1909485].
28 Olanow C W, Fahn S, Muenter M, Klawans H, Hurtig H, Stern M, et al. A multicenter double-blind placebo-controlled trial of pergolide as an adjunct to Sinemet in Parkinson's Disease. Mov Disord. 1994;9:40-7. [pmid: 8139604].
29 Olanow C W, Hauser R A, Gauger L, Malapira T, Koller W, Hubble J, et al. The effect of deprenyl and levodopa on the progression of Parkinson's Disease. Ann Neurol. 1995;38:771-7. [pmid: 7486869].
30 Olsson J E. Bromocriptine and levodopa in early combination in Parkinson's Disease: First results of the collaborative European multicentric trial. Adv Neurol. 1990;53:421-3. [pmid: 2239483].
31 Palhagen S, Heinonen E H, Hagglund J, Kaugesaar T, Kontants H, Maki-Ikola O, et al. Selegiline delays the onset of disability in de novo parkinsonian patients. Neurology. 1998;51:520-5. [pmid: 9710028].
32 Parkinson Study Group. Effect of lazabemide on the progression of disability in early Parkinson's Disease. Ann Neurol. 1996;40:99-107. [pmid: 8687199].
33 Parkinson Study Group. Entacapone improves motor fluctuations in levodopa-treated Parkinson's Disease patients. Ann Neurol. 1997;42:747-55. [pmid: 9392574].
34 Parkinson Study Group. Pramipexole vs levodopa as initial treatment for Parkinson Disease. JAMA. 2000;284:1931-8. [pmid: 11035889].
Parkinson Study Group. A randomized controlled trial comparing pramipexole with levodopa in early Parkinson's Disease: Design and methods of the CALM-PD study. Clin Neuropharmacol. 2000;23:34-44. [pmid: 10682229].
35 Parkinson Study Group. Effects of tocopherol and deprenyl on the progression of disability in early Parkinson's Disease. N Eng J Med. 1993;328:176-83.
Parkinson Study Group. Mortality in DATATOP: A multicenter trial in early Parkinson's Disease. Ann Neurol. 1998;43:318-25. [pmid: 9506548].
Parkinson Study Group. The need for levodopa as an end point of Parkinson's Disease progression in a clinical trial of selegiline and alpha-tocopherol. Mov Disord. 1997;12:183-9. [pmid: 9087976].
Parkinson Study Group. Impact of deprenyl and tocopherol treatment on Parkinson's Disease in DATATOP patients not requiring levodopa. Ann Neurol. 1996;39:29-36. [pmid: 8572663].
Parkinson Study Group. Impact of deprenyl and tocopherol treatment on Parkinson's Disease in DATATOP patients requiring levodopa. Ann Neurol. 1996;39:37-45. [pmid: 8572664].
Parkinson Study Group. Factors predictive of the need for levodopa therapy in early, untreated Parkinson's Disease. Arch Neurol. 1995;52:565-70. [pmid: 7763203].
Parkinson Study Group. The effect of deprenyl and tocopherol on cognitive performance in early untreated Parkinson's Disease. Neurology. 1994;44:1756-9. [pmid: 7936311].
Parkinson Study Group. Effect of selegiline (Deprenyl) on the progression of disability in early Parkinson's Disease. Acta Neurol Scand Suppl. 1993;87:36-42.
Parkinson Study Group. An interim report of the effect of selegiline (L-deprenyl) on the progression of disability in early Parkinson's Disease. Eur Neurol. 1992;32:46-53. [pmid: 1425820].
36 Przuntek H, Conrad B, Dichgans J, Kraus P H, Krauseneck P, Pergande G, et al. SELEDO: A 5-year long-term trial on the effect of selegiline in early parkinsonian patients treated with levodopa. Eur J Neurol. 1999;6:141-50. [pmid: 10053226].
37 Przuntek H, Welzel D, Gerlach M, Blumner E, Danielczyk W, Kaiser H J, et al. Early institution of bromocriptine in Parkinson's Disease inhibits the emergence of levodopa-associated motor side effects. Long-term results of the PRADO study. J Neural Transm Park Dis Dement Sect. 1996;103:699-715.
Przuntek H, Welzel D, Blumner E, Danielczyk W, Letzel H, Kaiser H J, et al. Bromocriptine lessens the incidence of mortality in L-dopa-treated parkinsonian patients: PRADO-study discontinued. Eur J Clin Pharmacol. 1992;43:357-63. [pmid: 1451713].
Przuntek H, Welzel D, Schwarzmann D, Letzel H, Kraus P H. Primary combination therapy of early Parkinson's Disease. A long-term comparison between the combined regimen bromocriptine/levodopa and levodopa monotherapy--first interim report. Eur Neurol. 1992;32:36-45. [pmid: 1425819].
38 Rabey J M, Streifler M, Treves T, Korczyn A D. The beneficial effect of chronic lisuride administration compared with levodopa in Parkinson's Disease. Adv Neurol. 1990;53:451-5. [pmid: 2122652].
39 Rajput A H, Martin W, Saint-Hilaire M H, Dorflinger E, Pedder S. Tolcapone improves motor function in parkinsonian patients with the “wearing-off” phenomenon: A double-blind, placebo-controlled, multicenter trial. Neurology. 1997;49:1066-71. [pmid: 9339691].
40 Rascol O, Brooks D J, Korczyn A D, De Deyn P P, Clarke C E, Lang A E. A five-year study of the incidence of dyskinesia in patients with early Parkinson's Disease who were treated with ropinirole or levodopa. N Engl J Med. 2000;342:1484-91. [pmid: 10816186].
Rascol O, Brooks D J, Brunt E R, Korczyn A D, Poewe W H, Stocchi F. Ropinirole in the treatment of early Parkinson's Disease: A 6-month interim report of a 5-year levodopa-controlled study. Mov Disord. 1998;13:39-45.
41 Rinne U K, Bracco F, Chouza C, Dupont E, Gershanik O, Marti M J, et al. Early treatment of Parkinson's Disease with cabergoline delays the onset of motor complications. Results of a double-blind levodopa controlled trial. Drugs. 1998;55:23-30. [pmid: 9483167].
Rinne U K, Bracco F, Chouza C, Dupont E, Gershanik O, Marti M J, et al. Cabergoline in the treatment of early Parkinson's Disease: Results of the first year of treatment in a double-blind comparison of cabergoline and levodopa. Neurology. 1997;48:363-8. [pmid: 9040722].
42 Rinne U K, Larsen J P, Siden A, Worm-Petersen J. Entacapone enhances the response to levodopa in parkinsonian patients with motor fluctuations. Neurology. 1998;51:1309-14. [pmid: 9818851].
43 Sethi K D, O'Brien C F, Hammerstad J P, Adler C H, Davis T L, Taylor R L, et al. Ropinirole for the treatment of early Parkinson Disease: A 12-month experience. Arch Neurol. 1998;55:1211-6. [pmid: 9740115].
Adler C H, Sethi K D, Hauser R A, Davis T L, Hammerstad J P, Bertoni J, et al. Ropinirole for the treatment of early Parkinson's Disease. Neurology. 1997;49:393-9. [pmid: 9270567].
Goetz C G, Leurgans S, Raman R, Stebbins G T. Objective changes in motor function during placebo treatment in PD. Neurology. 2000;54:710-4. [pmid: 10680808].
44 Shannon K M, Bennett J P J, Friedman J H. Efficacy of pramipexole, a novel dopamine agonist, as monotherapy in mild to moderate Parkinson's Disease. Neurology. 1997;49:724-8. [pmid: 9305331].
45 Steiger M J, El-Debas T, Anderson T, Findley L J, Marsden C D. Double-blind study of the activity and tolerability of cabergoline versus placebo in parkinsonians with motor fluctuations. J Neurol. 1996;243:68-72. [pmid: 8869390].
46 Stocchi F, Bramante L, Monge A, Viselli F, Baronti F, Stefano E, et al. Apomorphine and lisuride infusion. A comparative chronic study. Adv Neurol. 1993;60:653-5. [pmid: 8420205].
47 Waters C H, Kurth M, Bailey P, Shulman L M, LeWitt P, Dorflinger E, et al. Tolcapone in stable Parkinson's Disease: Efficacy and safety of long-term treatment. Neurology. 1997;49:665-71. [pmid: 9305320].
48 Weiner W J, Factor S A, Sanchez-Ramos J R, Singer C, Sheldon C, Cornelius L, et al. Early combination therapy (bromocriptine and levodopa) does not prevent motor fluctuations in Parkinson's Disease. Neurology. 1993;43:21-7. [pmid: 8423888].
49 Wolters E C, Tesselaar H J. International (NL-UK) double-blind study of Sinemet CR and standard Sinemet (25/100) in 170 patients with fluctuating Parkinson's Disease. J Neurol. 1996;243:235-40. [pmid: 8936353].
Wolters E C, Horstink M W, Roos R A, Jansen E N. Superior clinical efficacy of Sinement CR 50/200 versus Sinemet 25/100 in patients with fluctuating Parkinson's Disease. An open and a double-blind, double-dummy, multicenter treatment evaluation. Adv Neurol. 1993;60:648-52. [pmid: 8420204].
Wolters E C, Horstink M W, Roos R A, Jansen E N. Clinical efficacy of Sinemet CR 50/200 versus Sinemet 25/100 in patients with fluctuating Parkinson's Disease An open, and a double-blind, double-dummy, multicenter treatment evaluation. Clin Neurol Neurosurg. 1992;94:205-11. [pmid: 1327609].

### Study Category: Psychiatric Treatment

1 Factor S A, Brown D, Molho E S, Podskalny G D. Clozapine: A 2-year open trial in Parkinson's Disease patients with psychosis. Neurology. 1994;44:544-6. [pmid: 8145929].
2 Kahn N, Freeman A, Juncos J L, Manning D, Watts R L. Clozapine is beneficial for psychosis in Parkinson's Disease. Neurology. 1991;41:1699-700. [pmid: 1922830].
3 Meco G, Alessandri A, Giustini P, Bonifati V. Risperidone in levodopa-induced psychosis in advanced Parkinson's Disease: An open-label, long-term study. Mov Disord. 1997;12:610-2. [pmid: 9251085].
4 Rabey J M, Treves T A, Neufeld M Y, Orlov E, Korczyn A D. Low-dose clozapine in the treatment of levodopa-induced mental disturbances in Parkinson's Disease. Neurology. 1995;45:432-4. [pmid: 7898690].
5 Ruggieri S, De Pandis M F, Bonamartini A, Vacca L, Stocchi F. Low dose of clozapine in the treatment of dopaminergic psychosis in Parkinson's Disease. Clin Neuropharmacol. 1997;20:204-9. [pmid: 9197942].
6 Sano M, Stern Y, Marder K, Mayeux R. A controlled trial of piracetam in intellectually impaired patients with Parkinson's Disease. Mov Disord. 1990;5:230-4. [pmid: 2388639].
7 Targum S D, Abbott J L. Efficacy of quetiapine in Parkinson's patients with psychosis. J Clin Psychopharmacol. 2000;20:54-60. [pmid: 10653209].
McManus D Q, Arvanitis L A, Kowalcyk B B. Seroquel Trial 48 Study Group. Seroquel (quetiapine), a novel antipsychotic: Experience in elderly patients with psychotic disorders. J Clin Psychiatry. 1999;60:292-8. [pmid: 10362435].
8 Trosch R M, Friedman J H, Lannon M C, Pahwa R, Smith D, Seeberger L C, et al. Clozapine use in Parkinson's Disease: A retrospective analysis of a large multicentered clinical experience. Mov Disord. 1998;13:377-82. [pmid: 9613725].
9 Wagner M L, Defilippi J L, Menza M A, Sage J I. Clozapine for the treatment of psychosis in Parkinson's Disease: Chart review of 49 patients. J Neuropsychiatry Clin Neurosci. 1996;8:276-80. [pmid: 8854298].
10 Wermuth L. Depression in idiopathic Parkinson's Disease treated with Citalopram. Nord J Psychiatry. 1998;52:163-9.

### Study Category: Surgery

1 Ardouin C, Pillon B, Peiffer E, Bejjani P, Limousin P, Damier P, et al. Bilateral subthalamic or pallidal stimulation for Parkinson's Disease affects neither memory nor executive functions: A consecutive series of 62 patients. Ann Neurol. 1999;46:217-23. [pmid: 10443887].
2 Baron M S, Vitek J L, Bakay R A E, Green J, Mcdonald W M, Cole S A, et al. Treatment of advanced Parkinson's Disease by unilateral posterior GPI pallidotomy: 4-year results of a pilot study. Mov Disord. 2000;15:230-7. [pmid: 10752571].
Baron M S, Vitek J L, Bakay R A E, Green J, Kaneoke Y, Hashimoto T, et al. Treatment of advanced Parkinson's Disease by posterior GPI pallidotomy: 1-year results of a pilot study. Ann Neurol. 1996;40:355-66. [pmid: 8797525].
Vitek J L, Bakay R A, DeLong M R. Microelectrode-guided pallidotomy for medically intractable Parkinson's Disease. Adv Neurol. 1997;74:183-98. [pmid: 9348414].
3 Bejjani B P, Gervais D, Arnulf I, Papadopoulos S, Demeret S, Bonnet A M, et al. Axial parkinsonian symptoms can be improved: The role of levodopa and bilateral subthalamic stimulation. J Neurol Neurosurg Psychiatry. 2000;68:595-600. [pmid: 10766889].
Bejjani B P, Dormont D, Pidoux B, Yelnik J, Damier P, Arnulf I, et al. Bilateral subthalamic stimulation for Parkinson's Disease by using three-dimensional stereotactic magnetic resonance imaging and electrophysiological guidance. J Neurosurg. 2000;92:615-25. [pmid: 10761650].
4 Burchiel K J, Anderson V C, Favre J, Hammerstad J P. Comparison of pallidal and subthalamic nucleus deep brain stimulation for advanced Parkinson's Disease: Results of a randomized, blinded pilot study. Neurosurgery. 1999;45:1375-82. [pmid: 10598706].
5 Dalvi A, Winfield L, Yu Q, Cote L, Goodman R R, Pullman S L. Stereotactic posteroventral pallidotomy: Clinical methods and results at 1-year follow up. Mov Disord. 1999;14:256-61. [pmid: 10091619].
6 de Bie R M, de Haan R J, Nijssen P C, Rutgers A W, Beute G N, Bosch D A, et al. Unilateral pallidotomy in Parkinson's Disease: A randomised, single-blind, multicentre trial. Lancet. 1999;354:1665-9. [pmid: 10568567].
Schmand B, de Bie R M, Koning-Haanstra M, de Smet J S, Speelman J D, van Zomeren A H. Unilateral pallidotomy in PD: A controlled study of cognitive and behavioral effects. Neurology. 2000;54:1058-64. [pmid: 10720274].
7 Desaloms J M, Krauss J K, Lai E C, Jankovic J, Grossman R G. Posteroventral medial pallidotomy for treatment of Parkinson's Disease: Preoperative magnetic resonance imaging features and clinical outcome. J Neurosurg. 1998;89:194-9. [pmid: 9688112].
Krauss J K, Desaloms J M, Lai E C, King D E, Jankovic J, Grossman R G, et al. Microelectrode-guided posteroventral pallidotomy for treatment of Parkinson's Disease: Postoperative magnetic resonance imaging analysis. J Neurosurg. 1997;87:358-67. [pmid: 9285599].
8 Dewey R B, Giller C A, Broline S K, Mendelsohn D B, Lacritz L H, Cullum, et al. Clinical outcome of unilateral stereotactic pallidotomy without microelectrode recording for intractable Parkinson's Disease. Parkinsonism Relat. 2000;6:7-16.
9 Diederich N, Goetz C G, Stebbins G T, Klawans H L, Nittner K, Koulasakis A, et al. Blinded evaluation confirms long-term asymmetric effect of unilateral thalamotomy or subthalamotomy on tremor in Parkinson's Disease. Neurology. 1992;42:1311-4. [pmid: 1620340].
10 Dogali M, Sterio D, Fazzini E, Kolodny E, Eidelberg D, Beric A. Effects of posteroventral pallidotomy on Parkinson's Disease. Adv Neurol. 1996;69:585-90. [pmid: 8615183].
Dogali M, Fazzini E, Kolodny E, Eidelberg D, Sterio D, Devinsky O, et al. Stereotactic ventral pallidotomy for Parkinson's Disease. Neurology. 1995;45:753-61. [pmid: 7723966].
Eidelberg D, Moeller J R, Ishikawa T, Dhawan V, Spetsieris P, Silbersweig D, et al. Regional metabolic correlates of surgical outcome following unilateral pallidotomy for Parkinsons Disease. Ann Neurol. 1996;39:450-9. [pmid: 8619523].
Fazzini E, Dogali M, Sterio D, Eidelberg D, Beric A. Stereotactic pallidotomy for Parkinson's Disease: A long term follow-up of unilateral pallidotomy. Neurology. 1997;48:1273-7. [pmid: 9153456].
Perrine K, Dogali M, Fazzini E, Sterio D, Kolodny E, Eidelberg D, et al. Cognitive functioning after pallidotomy for refractory Parkinson's Disease. J Neurol Neurosurg Psychiatry. 1998;65:150-4. [pmid: 9703163].
11 Eskandar E N, Shinobu L A, Penney J B, Cosgrove G R, Counihan T J. Stereotactic pallidotomy performed without using microelectrode guidance in patients with Parkinson's Disease: Surgical technique and 2-year results. J Neurosurg. 2000;92:375-83. [pmid: 10701522].
12 Fink J S, Schumacher J M, Ellias S L, Palmer E P, Saint-Hilaire M, Shannon K, et al. Porcine xenografts in Parkinson's Disease and Huntington's Disease patients: Preliminary results. Cell Transplant. 2000;9:273-8. [pmid: 10811399].
13 Fox M W, Ahlskog J E, Kelly P J. Stereotactic ventrolateralis thalamotomy for medically refractory tremor in post-levodopa era Parkinson's Disease patients. J Neurosurg. 1991;75:723-30. [pmid: 1919694].
14 Goetz C G, Stebbins G T, Klawans H L, Koller W C, Grossman R G, Bakay R A, et al. United Parkinson Foundation neurotransplantation registry on adrenal medullary transplants: Presurgical, and 1- and 2-year follow-up. Neurology. 1991;41:1719-22. [pmid: 1944898].
Bakay R A, Watts R L, Freeman A, Iuvone P M, Watts N, Graham S D. Preliminary report on adrenal-brain transplantation for parkinsonism in man. Stereotact Funct Neurosurg. 1990;54–55:312-23.
Olanow C W, Koller W, Goetz C G, Stebbins G T, Cahill D W, Gauger L L. Autologous transplantation of adrenal medulla in Parkinson's Disease. 18-month results. Arch Neurol. 1990;47:1286-9. [pmid: 2252446].
15 Henderson B T, Clough C G, Hughes R C, Hitchcock E R, Kenny B G. Implantation of human fetal ventral mesencephalon to the right caudate nucleus in advanced Parkinson's Disease. Arch Neurol. 1991;48:822-7. [pmid: 1898256].
Hitchcock E R, Kenny B G, Clough C G, Hughes R C, Henderson B T, Detta A. Stereotactic implantation of foetal mesencephalon (STIM): The UK experience. Prog Brain Res. 1990;82:723-8. [pmid: 2290976].
16 Herrera E J, Viano J C, Caceres M, Costello G, Suarez M, Suarez J C. Posteroventral pallidotomy in Parkinson's Disease. Acta Neurochir (Wien). 2000;142:169-75. [pmcid: 300905]. [pmid: 10795891].
17 Houeto J L, Damier P, Bejjani P B, Staedler C, Bonnet A M, Arnulf I, et al. Subthalamic stimulation in Parkinson Disease: A multidisciplinary approach. Arch Neurol. 2000;57:461-5. [pmid: 10768618].
18 Iacono R P, Shima F, Lonser R R, Kuniyoshi S, Maeda G, Yamada S. The results, indications, and physiology of posteroventral pallidotomy for patients with Parkinson's Disease. Neurosurgery. 1995;36:1118-27. [pmid: 7643990].
19 Jankovic J, Hamilton W J, Grossman R G. Thalamic surgery for movement disorders. Adv Neurol. 1997;74:221-33. [pmid: 9348417].
Jankovic J, Cardoso F, Grossman R G, Hamilton W J. Outcome after stereotactic thalamotomy for parkinsonian, essential, and other types of tremor. Neurosurgery. 1995;37:680-7. [pmid: 8559296].
20 Johansson F, Malm J, Nordh E, Hariz M. Usefulness of pallidotomy in advanced Parkinson's Disease. J Neurol Neurosurg Psychiatry. 1997;62:125-32. [pmid: 9048711].
21 Koller W, Pahwa R, Busenbark K, Hubble J, Wilkinson S, Lang A, et al. High-frequency unilateral thalamic stimulation in the treatment of essential and parkinsonian tremor. Ann Neurol. 1997;42:292-9. [pmid: 9307249].
22 Kondziolka D, Bonaroti E, Baser S, Brandt F, Kim Y S, Lunsford L D, et al. Outcomes after stereotactically guided pallidotomy for advanced Parkinson's Disease. J Neurosurg. 1999;90:197-202. [pmid: 9950488].
23 Kopyov O V, Jacques D, Lieberman A, Duma C M, Rogers R L. Clinical study of fetal mesencephalic intracerebral transplants for the treatment of Parkinson's Disease. Cell Transplant. 1996;5:327-37. [pmid: 8689043].
24 Kopyov O V, Jacques D S, Lieberman A, Duma C M, Rogers R L. Outcome following intrastriatal fetal mesencephalic grafts for Parkinson's patients is directly related to the volume of grafted tissue. Exp Neurol. 1997;146:536-45. [pmid: 9270065].
25 Krack P, Pollak P, Limousin P, Hoffman D, Xie J, Benazzouz A, Benabid A L. Subthalamic nucleus or internal pallidal stimulation in young onset Parkinson's Disease. Brain. 1998;121:451-7. [pmid: 9549521].
26 Kumar K, Kelly M, Toth C. Deep brain stimulation of the ventral intermediate nucleus of the thalamus for control of tremors in Parkinson's Disease and essential tremor. Stereotact Funct Neurosurg. 1999;72:47-61. [pmid: 10640920].
27 Lang A E, Lozano A M, Montgomery E, Duff J, Tasker R, Hutchinson W. Posteroventral medial pallidotomy in advanced Parkinson's Disease. N Eng J Med. 1997;337:1036-42.
Duff J, Sime E. Surgical interventions in the treatment of Parkinson's Disease (PD) and Essential Tremor (ET): Medial pallidotomy in PD and chronic deep brain stimulation (DBS) in PD and ET. Axone. 1997;18:85-9. [pmid: 9295483].
Fine J, Duff J, Chen R, Hutchinson W, Lozano A, Lang A E. Long-term follow-up of unilateral pallidotomy in advanced Parkinson's Disease. N Engl J Med. 2000;342:1708-14. [pmid: 10841873].
Gross R E, Lombardi W J, Lang A E, Duff J, Hutchison W D, Saint-Cyr J A, et al. Relationship of lesion location to clinical outcome following microelectrode-guided pallidotomy for Parkinson's Disease. Brain. 1999;122:405-16. [pmid: 10094250].
Kumar R, Lozano A M, Montgomery E, Lang A E. Pallidotomy and deep brain stimulation of the pallidum and subthalamic nucleus in advanced Parkinson's Disease. Mov Disord. 1998;13:73-82. [pmid: 9613722].
Lozano A M, Lang A E, Galvez-Jimenez N, Miyasaki J, Duff J, Hutchinson W D, et al. Effect of GPI pallidotomy on motor function in Parkinson's Disease. Lancet. 1995;346:1383-7. [pmid: 7475819].
Trepanier L L, Saint-Cyr J A, Lozano A M, Lang A E. Neuropsychological consequences of posteroventral pallidotomy for the treatment of Parkinson's Disease. Neurology. 1998;51:207-15. [pmid: 9674804].
28 Limousin P, Krack P, Pollak P, Benazzouz A, Ardouin C, Hoffmann D, et al. Electrical stimulation of the subthalamic nucleus in advanced Parkinson's Disease. N Eng J Med. 1998;339:1105-11.
29 Limousin P, Speelman J D, Gielen F, Janssens M. Multicentre European study of thalamic stimulation in parkinsonian and essential tremor. J Neurol Neurosurg Psychiatry. 1999;66:289-96. [pmid: 10084526].
30 Lopez-Lozano J J, Bravo G, Abascal J. Grafting of perfused adrenal medullary tissue into the caudate nucleus of patients with Parkinson's Disease. J Neurosurg. 1991;75:234-43. [pmid: 2072160].
Lopez-Lozano J J, Abascal J, Bravo G. A year follow-up of autoimplants of perfused adrenal medulla into parkinsonian patients. Prog Brain Res. 1990;82:657-63. [pmid: 2290967].
Lopez-Lozano J J, Bravo G, Abascal J. A long-term study of Parkinson's patients subjected to autoimplants of perfused adrenal medulla into the caudate nucleus. Transplant Proc. 1990;22:2243-6. [pmid: 2219358].
31 Lopez-Lozano J J, Bravo G, Brera B, Millan I, Dargallo J, Salmean J, et al. Long-term improvement in patients with severe Parkinson's Disease after implantation of fetal ventral mesencephalic tissue in a cavity of the caudate nucleus: 5-year follow up in 10 patients. J Neurosurg. 1997;86:931-42. [pmid: 9171171].
Lopez-Lozano J J, Bravo G, Brera B, Dargallo J, Salmean J, Uria J, et al. Long-term follow-up in 10 Parkinson's Disease patients subjected to fetal brain grafting into a cavity in the caudate nucleus: The Clinica Puerta de Hierro experience. Transplant Proc. 1995;27:1395-400. [pmid: 7878925].
32 Masterman D, DeSalles A, Baloh R W, Frysinger R, Foti D, Behnke E, et al. Motor, cognitive, and behavioral performance following unilateral ventroposterior pallidotomy for Parkinson Disease. Arch Neurol. 1998;55:1201-8. [pmid: 9740114].
33 Melnick M E, Dowling G A, Aminoff M J, Barbaro N M. Effect of pallidotomy on postural control and motor function in Parkinson Disease. Arch Neurol. 1999;56:1361-5. [pmid: 10555656].
34 Molinuevo J L, Valldeoriola F, Tolosa E, Rumia J, Valls-Sole J, Roldan H, et al. Levodopa withdrawal after bilateral subthalamic nucleus stimulation in advanced Parkinson Disease. Arch Neurol. 2000;57:983-8. [pmid: 10891980].
35 Roberts-Warrior D, Overby A, Jankovic J, Olson S, Lai E C, Krauss J K, et al. Postural control in Parkinson's Disease after unilateral posteroventral pallidotomy. Brain. 2000;123:2141-9. [pmid: 11004130].
36 Samii A, Turnbull I M, Kishore A, Schulzer M, Mak E, Yardley S, et al. Reassessment of unilateral pallidotomy in Parkinson's Disease. A 2-year follow-up study. Brain. 1999;122:417-25. [pmid: 10094251].
Kishore A, Turnbull I M, Snow B J, de la Fuente-Fernandez R, Schulzer M, Mak E, et al. Efficacy stability and predictors of outcome of pallidotomy for Parkinson's Disease. Six-month follow-up with additional 1-year observations. Brain. 1997;120:729-37. [pmid: 9183246].
37 Samuel M, Caputo E, Brooks D J, Schrag A, Scaravilli T, Branston N M, et al. A study of medial pallidotomy for Parkinson's Disease: Clinical outcome, MRI location and complications. Brain. 1998;121:59-75. [pmid: 9549488].
38 Schuurman P R, Bosch D A, Bossuyt P M, Bonsel G J, van Someren E J, de Bie R M, et al. A comparison of continuous thalamic stimulation and thalamotomy for suppression of severe tremor. N Engl J Med. 2000;342:461-8. [pmid: 10675426].
39 Shannon K M, Penn R D, Kroin J S, Adler C H, Janko K A, York M, et al. Stereotactic pallidotomy for the treatment of Parkinson's Disease. Efficacy and adverse effects at 6 months in 26 patients. Neurology. 1998;50:434-8. [pmid: 9484368].
40 Taha J M, Favre J, Baumann T K, Burchiel K J. Tremor control after pallidotomy in patients with Parkinson's Disease: Correlation with microrecording findings. J Neurosurg. 1997;86:642-7. [pmid: 9120628].
41 Velasco F, Velasco M, Rodriguez Cuevas H, Jurado J, Olvera J, Jimenez F. Autologous adrenal medullary transplants in advanced Parkinson's Disease with particular attention to the selective improvement in symptoms. Stereotact Funct Neurosurg. 1991;57:195-212. [pmid: 1842977].
42 Young R F, Shumway-Cook A, Vermeulen S S, Grimm P, Blasko J, Posewitz, et al. Gamma knife radiosurgery as a lesioning technique in movement disorder surgery. J Neurosurg. 1998;89:183-93. [pmid: 9688111].