# Appendix G. Technical Experts and Peer Reviewers

AHRQ Diagnosis and Treatment of Parkinson's Disease Peer Reviewer Panel

Name | Specialty | Affiliation
Bressman, Susan - MD | PD Expert | Beth Israel Medical Center
| | New York, NY
Brooks, Deborah W. | Consumer Advocate | Executive Director, The Michael J. Fox Foundation
| | New York, NY
Brown, Janet - MA CCC-SLP | Speech-Language Pathology | Associate Director
| | Health Care Services in Speech-Language Pathology
| | American Speech-Language-Hearing Association
| | Rockville, MD
Cohen, Perry - MD | Consumer Advocate | Director, Health Services Research
| | Parkinson's Disease Foundation
| | Washington, DC
Cosgrove, G. Rees - MD, FRCS (C.) | Neurosurgeon | Director, Movement Disorders Center
| | Wang Ambulatory Care Center
| | Massachusetts General Hospital
| | Boston, MA
Langston, J William - MD | PD Expert | Founder, The Parkinson's Institute
| | Sunnyvale, CA
Leurgans, Sue - PhD | Statistician | Department of Preventive Medicine & Neurological Sciences
| | Rush-Presbyterian - St. Lukes Medical Center
| | Chicago, IL
Marder, Karen - MD, MPH | PD Expert | Associate Professor of Clinical Neurology
| | Sergievsky Center, Columbia University
| | New York, NY
Neuman, William “Richey” - MD | Internist | Assistant Professor of General Internal Medicine
| | Presbyterian Medical Center
| | Philadelphia, PA
Nutt, John G. - MD | PD Expert | Oregon Health Sciences University
| | Department of Neurology
| | Portland, OR
Oertel, Wolfgang H. - MD | PD Expert | Philipps University
| | Department of Neurology
| | Director, Center for Nervous Diseases
| | Marburg D 35033 Germany
Pfeiffer, Ron - MD | PD Expert | University of Tennessee, Memphis
| | Department of Neurology
| | Memphis, TN
Reno, Janet - JD | Consumer Advocate | The Honorable Janet Reno
| | Former Attorney General
| | United States Department of Justice
Schmid, Christopher H. - PhD | Statistician | Associate Professor
| | Tufts University School of Medicine
| | Boston, MA
Shannon, Kathleen - MD | PD Expert | Rush-Presbyterian-St. Lukes Medical Center
| | Department of Neurology
| | Chicago, IL
Swarztrauber, Kari - MD, PhD | Neurologist | Assistant Professor of Neurology
| | Oregon Health and Science University
| | Portland, OR
Tanner, Caroline M. - MD, PhD | PD Expert | Director of Clinical Research
| | The Parkinson's Institute
| | Sunnyvale, CA
Waters, Cheryl H. - MD | PD Expert | Columbia University Neurological Institute
| | New York, NY
Weiss, Howard - MD | PD Expert | Sinai Hospital
| | Baltimore, MD

AHRQ Diagnosis and Treatment of Parkinson's Disease Technical Expert Panel(TEP)

Name | Specialty | Affiliation
Baime, Michael - MD | Internist | Chief of Internal Medicine
| | PENNCare at Rittenhouse Square
| | Philadelphia, PA
Carter, Julie - RN, PhD | PD Expert | Oregon Health Sciences University
| | Department of Neurology
| | Portland, OR
Factor, Stewart A. - MD | PD Expert | Albany Medical Center
| | Department of Neurology
| | Albany, NY
Kieburtz, Karl D. - MD | PD Expert | Chief, Movement and Inherited Neurological
| | Disorders Unit
| | University of Rochester Medical School
| | Rochester, NY
Levy, Sanford - MD | Neurologist | Department of Neurology
| | North Shore Medical Center
| | Salem, MA
Turner, Dennis - MD | PD Expert | Duke University Medical Center
| | Division of Neurosurgery
| | Durham, Nc
Wistran, Daniel - MD | Consumer Advocate | Cardiology Physicians Inc.
| | North Shore Medical Center
| | Salem, MA
Zesiewicz, Theresa A. - MD | PD Expert | University of South Florida
| | Parkinson's Disease Movement Disorders Center
| | Tampa, FL

## Peer Reviewer Form

AHRQ Task Order: Diagnosis and Treatment of Parkinson's Disease: A Systematic Review of the Literature

Please indicate your level of agreement with each of the following Statements, by placing an “X” in the appropriate column.
Statements | Very much agree | Moderately agree | Not very much in agreement | Do not agree at all
1. This topic is relevant to healthcare decision-making (clinical practice and policy making) in 2001.
2. The criteria used to select articles for inclusion were appropriate.
3. Based on selection criteria used, it is not likely that relevant studies were missed.
4. The validity of the studies was appraised appropriately.
5. The methods are presented in such a way as to be reproducible.
6. The statistical analytic methods are appropriate to the material and the objectives.
7. The results are stated clearly.
8. Given the nature of the topic and the data, all clinically important outcomes were considered.
9. I agree with the conclusions presented in the report.

On the following page, please provide:

a. A brief explanation of both positive and negative answers;
b. Suggestions for improvement of the content or format of this review;
c. Suggestions for additional analyses of this dataset worth including in this report, or in future reports.

**We would prefer that you complete and return this form electronically. However, you may also fax the form back to us, or fax back an annotated version of the draft report if you prefer. Contact information is provided below.

Thank you in advance for your time in completing this form and giving us your feedback. We value your input and greatly appreciate your efforts. Please send the completed form and comments to MetaWorks by July 30, 2001.

Contact:

Rhoda P. Estok, RN, BSN, CNOR

Metaworks Inc.

E-mail: restok@metawork.com

Phone: (781) 395-0700 x254

Fax: (781) 395-7336