# Appendix B. Work Plan

## Objective

To conduct a systematic review of the literature to assess the quantity and quality of available evidence regarding diagnosis and treatment of Parkinson's disease (PD).

The following 12 specific questions will be addressed in the systematic review:

1. What are the results of neuroimaging studies (CT, MRI, PET, SPECT) or other diagnostic tests in determining the diagnosis of PD?
2. What are the results of L-dopa challenge in PD? What is the accuracy, sensitivity and specificity of this test for diagnosing PD?
3. What is the efficacy of medication used to treat early PD? What is the efficacy of initial treatment with L-dopa vs. a dopamine agonist?
4. What is the evidence for neuroprotection with selegiline, Vitamin E, or Vitamin C?
5. What is the efficacy of medication used to treat late PD? What is the efficacy of medication used to treat patients who have an insufficient response to L-dopa? What are the outcomes of treatment of medication-induced side effects?
6. What are the outcomes of treatment for patients who experience motor fluctuations and/or dyskinesias while taking L-Dopa?
7. What serious adverse events are associated with medications used to treat PD?
8. What are the outcomes of treatment of PD patients with psychotic symptoms or non-psychotic behavioral and psychological dysfunction?
9. When is surgery performed on PD patients? What types of surgeries are performed and what are their outcomes?
10. What are the outcomes of rehabilitation in PD?
11. What are the results of recent review articles regarding diagnosis and genetic testing in PD.
12. What is the evidence that PD patients are treated differently or have different outcomes based on the following: age, presentation of symptoms, cognitive status, duration of illness, co-morbidities, gender, race, ethnicity, or income level?

## Background

The topic “Parkinson's Disease” was nominated by the American Academy of Neurology (AAN) to assist in answering several key questions of diagnosis and management of patients with this disease.

PD is a progressive disorder of the central nervous system characterized clinically by tremor, rigidity, and bradykinesia. PD affects 1% of the population over age 60, and up to 2.5% over age 70. ^1^ Mayo Clinic researchers have estimated the lifetime risk of developing PD at 7.5%. ^2^ This could have serious health and economic implications as the baby boom generation ages. Annual societal costs related to PD were estimated in 1994 to be $20 billion, ^1^ and are likely to be much higher now and in the future.

The design and interpretation of all prevention and treatment studies are made more difficult by the fact that PD has a variable and unpredictable clinical course. Furthermore, numerous outcome measures and formats have been developed, which complicate efforts to pool results across studies. ^3^

The twelve key questions can be broken down into 4 basic categories: diagnosis, pharmacological treatment, (early and late), surgical treatment, and other modalities.

Not all “parkinsonism” is PD. The incidence of misdiagnosis has been estimated at up to 24% of patients. ^4^ The goal of this portion of the task order is to establish the evidence base of clinical trials that present sensitivity and specificity data pertaining to clinical and neuroimaging tests that are used to diagnose PD.

Treatment may be subdivided into early, overall, and late treatment, although there is significant overlap between the categories.

The standard treatment for PD has been levodopa (L-DOPA), which, once it reaches the brain, is converted to dopamine to correct the deficiency which characterizes PD. L-DOPA has been a mainstay of therapy since its introduction 40 years ago. However, questions of when to initiate therapy, and long term neurotoxicity, remain chief concerns to patients and practitioners. Several other drugs are often used, either in combination with L-DOPA to enhance its effects, or instead of L-DOPA, when its efficacy wanes or when response fluctuations or toxicity become unmanageable. These can be categorized chiefly as anticholinergics or dopamine agonists. Although there were very few new agents introduced for nearly 3 decades after the introduction of L-DOPA, several new agents, such as new dopamine agonists and the catechol-O-methyl transferase (COMT) inhibitors, with different mechanisms of action have recently been approved by the FDA. None, however, including L-DOPA, have been shown to impact the natural history of PD. They are useful for symptom control only, primarily motor dysfunction.

Research into agents capable of preventing or slowing progression of the disease is currently underway. These include antioxidants such as Vitamin E and coenzyme Q-10, the monoamine oxidase inhibitors selegiline and rasagiline, and glutamate antagonists such as riluzole.

The role of invasive methods such as pallidotomy and deep brain stimulation as additional treatment options require expert assessment. Neural growth factors and neural cell implants (fetal cells from humans or animals, and genetically engineered stem cells) are the focus of increasingly intense research efforts.

The safe and effective use of co-medications to treat depression, psychosis, and cognitive changes of PD is also the subject of considerable new research.

The role of non-pharmacologic interventions, such as physical rehabilitation therapy, remains uncertain.

The goal of this portion of the task order is to review the evidence base of clinical trials pertaining to the treatment of PD. Given that PD is a chronic condition, and that patients stay on medications for years, the most clinically relevant data will come from long-term trials. For this reason, only trials of greater than or equal to 24 weeks duration will be accepted. Furthermore, the most useful data for analysis concerning pharmacological treatment of PD will be in randomized controlled trials (RCTs); therefore, only RCTs will be accepted for studies pertaining to pharmacological treatment. Studies pertaining to surgery and rehabilitation will not be limited to RCTs.

Genetic testing of relatives of patients with early onset PD is another area of current controversy. This is an area where there would be limited information to be derived from RCTs or even clinical trials; therefore, review articles pertaining to Genetics and PD will be reviewed and summarized for the Final Report.

## Methods

MetaWorks will apply the latest and established best methods in the evolving science of review research. ^5–9^

A flow diagram outlining the systematic review process is located in Attachment A.

The following tasks will proceed sequentially, and a project timeline has previously been submitted.

### Topic Assessment & Refinement

A technical expert panel (TEP) will be assembled, in consultation with the Task Order Officer (TOO), through networking with our nominating partner, our academic collaborator, professional organizations, purchasers of health care, and relevant consumer groups.

After a preliminary assessment of the state of the literature, the TEP, in conjunction with the nominating partner (AAN), the TOO and our co-principal investigator at the Leonard Davis Institute of Health Economics (LDI), will assist in determining all primary and secondary objectives of this task order.

After a preliminary review of the literature, MetaWorks will develop two causal pathways that identify the critical diagnostic and treatment interventions in PD:

a. work-up of Parkinson's symptoms (diagnostic testing, treatment initiation, neuroimaging, genetic testing and neuroprotection)
b. pharmacologic and nonpharmacologic (including surgery and rehabilitation) management of patients with PD

These causal pathways will serve as guides during this systematic review, and may be updated during the review process. They are not intended to be clinical practice guidelines or algorithms for decisions in patient care.

A report will be developed in consultation with the TOO which will identify which questions, if any, have insufficient evidence to pursue using literature sources, and will suggest specific areas for future research to fill these gaps. The report will clearly state whether or what evidence exists for diagnosis and management of PD in the adult population and, within that population, evidence related to age, gender, race/ethnicity, and income level.

### Literature Screening

This task involves identifying and retrieving all potentially relevant literature on the diagnosis and treatment of PD, categorizing by study design, test, results and other key study, patient, and treatment level details for each of the thirteen key questions. Studies which meet the eligibility criteria (see below) will undergo data extraction and data entry.

The published literature will be searched from 1990 to 2000, with the following exceptions:

- Literature pertaining to pharmacological treatment of PD will be searched from 1985 to 2000, in an attempt to identify studies pertaining to anticholinergic medications.
- Literature pertaining to genetic testing will be searched from 1997-2000.

The search cut-off date will be November 9, 2000, and the retrieval cut-off date will be determined after all abstracts have been screened. The search will begin with a Medline screening search using the following search strategies:

I. Diagnosis:
  - 1. (PD OR parkinsonism OR Parkinson) AND [diagnosis OR medical errors OR accuracy OR sensitivity OR specificity OR (diagnosis AND antiparkinson agents)]
II. Treatment:
  - 2. (PD OR parkinsonism OR Parkinson) AND (treatment OR Levodopa OR carbidopa OR amantadine OR anticholinergic OR selegiline OR deprenyl OR dopamine agonist OR tolcapone OR entacapone)
  - 3. (PD OR parkinsonism OR Parkinson) AND (selegiline OR Vitamin E OR Vitamin C OR neuroprotective agents)
  - 4. (PD OR parkinsonism OR Parkinson) AND (psychological OR psychotic OR mental disorder) AND (drug therapy OR drug interactions)
  - 5. (PD OR parkinsonism OR Parkinson) AND (surgery OR pallidotomy OR brain tissue transplant OR deep brain stimulation)
  - 6. (PD OR parkinsonism OR Parkinson) AND rehabilitation
  - 7. #1 OR #2 OR #3 OR #4 OR #5 OR #6 AND limit to clinical trials.
III. Genetics:
  (PD OR parkinsonism OR Parkinson) AND genetics AND limit to review articles January 1, 1997-August 1, 2000.

In addition to the MedLine search described above, MetaWorks will search other suitable electronic databases, including Current Contents®, Cochrane Controlled Trials Register (CCTR) as well as a manual search of accepted study references and recent review articles. The Cochrane Library and the National Guidelines Clearinghouse will also be searched for additional information on these topics. In addition, pertinent Internet sites will be checked for potential leads to additional studies.

All citations and abstracts will be printed and screened at MetaWorks for any mention of diagnosis and/or treatment of PD (Level 1 screening) and reviewed for the following exclusion criteria:

#### Exclusion criteria

Abstracts demonstrating any of the following characteristics will be rejected:

- Reviews (except those regarding diagnosis and genetics), meta-analyses, letters, case reports, editorials, and commentaries.
- Crossover studies.
- Unpublished study reports and abstracts.
- Pharmacokinetic and pharmacodynamic studies.
- Animal or in vitro studies.
- Studies where results for PD population cannot be separated from results from other populations.
- Studies not pertaining to diagnosis or treatment of PD.
- Studies written in languages other than English.
- Studies containing < 10 patients as total sample size.
- Pharmacological treatment studies with < 24 weeks of treatment and followup.

While screening for eligibility, abstracts will be sorted and categorized. In some cases, it may not be possible from the abstract alone to determine the relevance of the study. All abstracts lacking obvious exclusion criteria will be included even if the categorization is unclear. Full papers for all studies passing Level 1 screening will be retrieved for second screening (Level 2), where inclusion and exclusion criteria will be applied.

#### Inclusion Criteria

Diagnosis:

- The following study designs will be accepted: observational[prospective, retrospective, and cross sectional (XS)], or interventional[RCTs, non-randomized controlled trials (nRCTs), and uncontrolled case series (UCSs), XS].
- Adult patients with potential diagnosis of PD.
- Studies addressing any diagnostic test to establish or support a diagnosis of PD.

Pharmacological Treatment:

- RCTs only
- ≥ 24 weeks treatment and follow-up duration
- Studies reporting at least one clinical objective outcome measure (efficacy or safety) on at least one of the following drugs or category of drugs:
  - L-DOPA/Carbidopa (Sinemet) - L-DOPA/decarboxylase inhibitor
  - Amantadine (Symmetrel)
  - Dopamine agonists:
    - Bromocriptine (Parlodel)
    - Pergolide (Permax)
    - Ropinirole (Requip)
    - Pramipexole (Mirapex)
    - Andropinole
    - Cabergoline (Dostinex)
    - Apomorphine
    - Lisuride (Dopergin)
  - Monoamine oxidase B (MAO-B) inhibitors:
    - Selegeline (Deprenyl)
    - Rasagiline (TVP-1012)
  - Catechol-O-methyltransferase (COMT) inhibitors:
    - Tolcapone (Tasmar)
    - Entacapone (Comtan)
  - Anticholinergic agents:
    - Trihexylphenidyl (Artane)
    - Benztropine (Cogentin)
    - Procyclidine
    - Other
- Studies involving neuroprotection with selegiline, Vitamine E (tocopherol), or Vitamin C.
- Studies addressing use of antipsychotic medications in conjunction with antiparkinsonian agents.
- Studies addressing the use of atypical antipsychotic medications in management of adult patients with PD.
  - Clozapine (Clozaril)
  - Olanzapine (Zyprexa)
  - Quetiapine (Seroquel)

Nonpharmacological Treatment:

- The following study designs will be accepted: observational[prospective, retrospective, and cross sectional], or interventional (RCTs, nRCTs, and UCSs).
- ≥ 24 weeks study and followup duration
- Must report at least one clinical objective outcome measure.
- Studies addressing surgery in adult patients with PD including:
  - Ablative or destructive surgery (thalmotomy, pallidotomy)
  - Stimulation surgery or Deep Brain Stimulation (DBS)
  - Transplantation or restorative Surgery (cell transplants)
- Studies addressing treatment of non-psychotic behavioral and psychological dysfunction in adult patients with PD.
- Studies addressing treatment of psychotic symptoms in adult patients with PD.
- Studies reporting at least one of the following specific interventions:
  - Allied health interventions
    - Occupational therapy (OT)
    - Physical therapy (PT)
    - Psychotherapy (counseling)
    - Speech therapy
- Studies reporting at least one of the following specific outcomes:
  - Acute hospitalization
  - Rehabilitation hospitalization
  - Nursing home admission
  - Work absenteeism
  - Quality of Life (QoL)
  - Activities of Daily Life (ADL) assessment

Genetics:

- The studsy design will be limited to review articles only.
- Adult patients undergoing genetic testing to establish or support a diagnosis of PD.

Upon completion of Level 2 screening, all accepted articles will be eligible for data extraction.

### Assessment of Quality in the Primary Studies

All studies will be appraised according to a previously published Level of Evidence (Attachment B). Each accepted RCT will also be scored for quality (features of randomization method used, blinding of treatments, and accounting for all patients entered and withdrawn) by the Jadad Quality Score Assessment (Attachment C).

### Data Extraction

Data extraction forms (DEFs) will be created specifically for this project. Data will be extracted onto the DEF independently by one reviewer and the completed DEF will be 100% checked against the original articles by a second reviewer. Any differences will be resolved by consensus; thus, two reviewers must agree on all data. In all cases, at least one physician reviews all data points. The data will then be entered in MetaWorks' relational database, MetaHub™. At this time, it is anticipated that the following data elements will be extracted.

These preliminary selections may change prior to finalization of the DEF as a result of input from the TEP and/or subsequent revisions to this Work Plan.

Study level characteristics

- Publication year
- Geographical location of study
- Study design (observational - retrospective or prospective interventional - RCT, nRCT, UCS, XS)
- Methodological assessment
- - Level of Evidence (I–V) - all studies
  - Jadad Quality Score - RCT's
- Total number of patients enrolled
- If RCT, number of patients randomized
- Primary study objective
- Funding source/industry sponsorship (name if yes or no/NR)
- Diagnostic test or treatment intervention studied
- Study duration
- Follow-up period
- Study type
- - Diagnostic
  - Treatment: pharmacologic or nonpharmacologic
    - Early
    - Late
    - General

Patient characteristics (by group)

- Age: years (mean, median, and range)
- Gender distribution
- Race and/or ethnicity
- Socioeconomic status
- Age at diagnosis
- Family history of PD
- Presenting symptoms (resting tremor, gait disturbance, rigidity, bradykinesia, motor dysfunction, etc.)
- Criteria used for Diagnosis of PD
- Patient exclusion criteria
- Stage of PD (early, moderate, advanced)
- Prior treatments received for PD
- Treatment resistance (# and type of antiparkinsonian agents tried previously)
- Criteria for establishing dementia diagnosis and for documenting presence of psychosis
- - Type of dementia diagnosed
  - Measures of cognitive impairment
- Other co-morbid conditions

Intervention Characteristics (by group)

- Diagnostic interventions
- - History and physical examination
  - Neuroimaging:
  - - Computed tomography (CT)
    - Magnetic resonance imaging (MRI)
    - Fluorodopa positron emission tomography (PET) scans
    - Single proton emission computed tomography (SPECT) scans using dopamine transporter ligands
  - Other
  - - Blood (serum ceruloplasmin concentration)
    - Urine (24 hour copper excretion)
    - Slit lamp examination
    - Liver biopsy (to rule out Wilson's disease)
  - Genetic testing
  - Other tests to rule out coexisting organic disease
  - Response to L-DOPA

Treatment interventions (by group)

- Pharmacological interventions
  - Treatment type, dose, frequency and duration
    - L-DOPA/Carbidopa
    - Dopamine agonists
    - MAO-B inhibitors
    - COMT-inhibitors
    - Anticholinergic Agents
    - Neuroprotective Agents
    - Antipsychotic medications
    - Other
  - Comparison group, if any (placebo or active controls)
  - Comparison group, if any (placebo or active controls)
    - Concomitant medication (protocol prescribed or allowed)
- Nonpharmacological interventions
  - Surgical
    - Indications for surgery
    - Type of surgery performed
  - Other
    - OT
    - PT
    - Psychotherapy
    - Speech Therapy

Outcomes (by group)

Diagnostic tests

- Sensitivity
- Specificity
- Accuracy
- Negative Predictive Value (NPV)
- Positive Predictive Value (PPV)

Treatment Outcomes

Efficacy

- Hospitalizations or admissions to chronic care facilities
- Symptomatic improvement or worsening (documented motor improvement and other manifestations of disease severity)
- Work absenteeism
- Clinical, objective outcome measures
- QoL
- ADL assessment
- Other

Safety

- Adverse Events (related to treatment)
- - Grade 3 and 4
- Deaths (related to treatment)
- Patient withdrawals due to adverse events or lack of efficacy

### Database Development

All consensed data will be entered into the MetaWorks MetaHub™ database. 100% of entered data is checked back to the DEFs after each form is completely entered. In addition, a 20% random sampling of data in the completed database will be checked by the QC group at MetaWorks against the data extraction forms. All discrepancies in data are reconciled by referring back to the original papers. Error rates in excess of 2% of checked data will trigger a 100% check of all data elements in the data base.

Once the accuracy of the database has been verified as described above, it is locked. No further changes are allowed after the data is locked. This is the dataset that will be used by the statisticians for analysis and to create raw data tables displaying key data elements of interest, by study.

All data are maintained in the MetaHub database, in a manner suitable to allow outputs to: a) spreadsheet programs for customized evidence table displays; b) to statistical programs for analysis.

## Statistical Analyses

Statistical analyses will be performed as the data permit. The search criteria for the 12 questions have been restricted to allow us to select only those studies most likely to contribute data that could be analyzable. Further details of analysis will be developed later in an analysis plan.

However, we also note that several questions are related to management of patients with PD. Studies in the literature addressing clinical practice or medical management are typically very limited, and will probably only allow for descriptive analysis.

## Synthesis & Reporting

This task involves bringing together all of the evidence into a coherent report and presenting the raw data in a tabular format as well as performing both qualitative and quantitative data syntheses as data permit and as protocol objectives require.

Meta Works will prepare and submit to the TOO evidence tables for each step in the causal pathways, as data permits.

## Technical Experts

MetaWorks will identify a TEP through networking with our nominating partner, our academic collaborators, professional organizations and relevant consumer groups. The TEP will be composed of six to eight individuals with specific expertise in general neurology, PD, neurosurgery, internal medicine, and at least one consumer representative. The TEP will review and provide timely feedback to all draft Work Plans and deliverables on an ongoing basis. MetaWorks will consult with these individuals as appropriate in carrying out the tasks required under this task order.

## Peer Review

In addition to the TEP described above, MetaWorks will identify up to 12 additional individuals who are experts in the topic area, to serve as peer reviewers of the draft evidence report. These individuals will be chosen from the fields of neurology, general practice and internal medicine, as well as consumers who have experienced PD. These individuals will be sought from professional organizations which have been instrumental in developing guidelines in aspects of PD treatment or diagnosis, such as the American Academy of Neurology. Consumers will be sought from consumer groups such as the National Parkinson Foundation Inc., the Parkinson's Disease Foundation, Inc., the Parkinson's Institute and others active in PD initiatives.

Names of potential reviewers will come from our technical expert panel, the nominating partner, LDI, AHRQ, and from the literature being reviewed by the project team. The profile of the peer review group will be similar to that of the TEP, and may also include representatives from manufacturers of the medications and diagnostics included in the evidence report.

A copy of the draft evidence report will be sent to each peer reviewer, along with a reviewer's form to be completed and returned to MetaWorks. This form will contain a checklist of items to be assessed as well as provide room for free-form text comments. The form will be pre-screened by the TEP and the TOO prior to being sent to the peer reviewers. Reviewers will be given 3 weeks to respond, after which they will be contacted. All feedback will be stored in a project folder at MetaWorks. A statement of response to each reviewer's comments will be prepared and stored with each reviewer's comments. This response will also be returned to the reviewer.

A summary of the main comments and responses will be prepared and shared with the TOO. Reviewer comments and additional analyses and text resulting from the response to reviewer critique will be incorporated into the final iteration of the evidence report.

## Implementation and Dissemination

An implementation plan will be prepared with the nominator, the American Academy of Neurology. Dissemination will occur via AHRQ. MetaWorks/LDI will prepare a manuscript describing key aspects of the work for publication in peer reviewed journals. Abstracts of same may also be submitted for presentation at professional meetings.

## References

1 Marsh L. Neuropsychiatric aspects of Parkinson's disease. Psychosomatics. 2000;41:15-23. [pmid: 10665264].
2 Research Digest: Parkinsonism more common than previously thought. Aug. 24, 1999. Mediconsult.com
3 Clarke CE, Speller JM. Pergolide versus bromocriptine for levodopa-induced motor complications in Parkinson's disease. and Hilten JJ van, Ramaker C, Beek WJT van de, Finken MJJ. Bromocriptine for levodopa-induced motor complications in Parkinson's disease. (Cochrane Review). In: The Cochrane Library, Issue 1, 1999. Oxford: Update Software).
4 Clarke C E. Managing early Parkinson's disease. The Practitioner. 1999;243:41-46.
5 Chalmers T C, Lau J. Meta-analytic stimulus for changes in clinical trials. Statistical Methods in Medical Research. 1993;2:161-72. [pmid: 8261256].
6 Sacks H S, Berrier J, Reitman D, Pagano D, Chalmers T. Meta-analyses of randomized controlled trials. N Engl J Med. 1987;316:450-5. [pmid: 3807986].
7 Sacks HS, Berrier J, Reitman D, Pagano D, Chalmers T. Meta-analyses of randomized control trials: an update of the quality and methodology. In: Bailar JC III, Mosteller F, editors. Medical Uses of Statistics. 2nd Edition. Boston: NEJM Books 1992; 427–42.
8 Cook D J, Mulrow C D, Haynes R B. Systematic reviews: synthesis of best evidence for clinical decisions. Ann Intern Med. 1997;126:376-80. [pmid: 9054282].
9 Mulrow CD, Oxman AD (eds). Cochrane Collaboration Handbook. The Cochrane Library. The Cochrane Collaboration; Issue 1. Oxford: Update Software; 1997. Updated quarterly.

## Work Plan Acceptance

## Attachment A: MetaWorks Flow Diagram

## Attachment B: Levels of Evidence

I. Evidence based on randomized controlled clinical trials (or meta-analysis of such trials) of adequate size to ensure a low risk of incorporating false-positive or false-negative results.
II. Evidence based on randomized controlled trials that are too small to provide level I evidence. These may show either positive trends that are not statistically significant or no trends and are associated with a high risk of false-negative results.
III. Evidence based on nonrandomized, controlled or cohort studies, case series, case-controlled studies or cross-sectional studies.
IV. Evidence based on the opinion of respected authorities or that of expert committees as indicated in published consensus conferences or guidelines.
V. Evidence which expresses the opinion of those individuals who have written and reviewed these guidelines, based on their experience, knowledge of the relevant literature and discussion with their peers.

These 5 levels of evidence do not directly describe the quality or credibility of evidence. Rather, they indicate the nature of the evidence being used. In general, a randomized, controlled trial has the greatest credibility (level I); however, it may have defects that diminish its value, and these should be noted. Evidence that is based on too few observations to give a statistically significant result is classified as level II. In general, level III studies carry less credibility than level I or II studies, but credibility is increased when consistent results are obtained from several level III studies carried out at different times and in different places.

Decisions must often be made in the absence of published evidence. In these situations it is necessary to use the opinion of experts based on their knowledge and clinical experience. All such evidence is classified as “opinion” (levels IV and V). Distinction is made between the published opinion of authorities (level IV) and the opinion of those who have contributed to these guidelines (level V). However, it should be noted that by the time level V evidence has gone through the exhaustive consensus-building process used in the preparation of these guidelines, it has achieved a level of credibility that is at least equivalent to level IV evidence.

from: The Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. CMAJ 1998:158

## Attachment C: Jadad Quality Score Assessment

Please read the articles and try to answer the following questions (see attached instructions):

1. Was the study described as randomized (this includes the use of words such as randomly, random, and randomization)?
2. Was the study described as double-blind?
3. Was there a description of withdrawals and drop outs?

Scoring the items:

Either give a score of 1 point for each ‘yes’ or 0 for each ‘no’. There are no in-between marks.

Give an additional point if: | For question 1, the method to generate the sequence of randomization was described and it was appropriate (table of random numbers, computer generated, coin tossing, etc.)
and/or: | If for question 2 the method of double-blinding was described and it was appropriate (identical placebo, active placebo, dummy, etc.)
Deduct 1 point if: | For question 1, the method to generate the sequence of randomization was described and it was inappropriate (patients were allocated alternately, or according to date of birth, hospital number, etc.)
and/or: | For question 2 the study was described as double-blind but the method was inappropriate (e.g., comparison of tablet vs.injection with no double dummy)

### Guidelines for assessment

1. Randomization:
  A method to generate the sequence of randomization will be regarded as appropriate if it allowed each study participant to have the same chance of receiving each intervention and the investigators could not predict which treatment was next. Methods of allocation using date of birth, date of admission, hospital numbers or alternation should not be regarded as appropriate.
2. Double-blinding:
  A study must be regarded as double-blind if the word double-blind is used. The method will be regarded as appropriate if it is stated that neither the person doing the assessments nor the study participant could identify the intervention being assessed, or if the absence of such a statement the use of active placebos, identical placebos or dummies is mentioned.
3. Withdrawals and drop outs:
  Participants who were included in the study but did not complete the observation period or who were not included in the analysis must be described. The number and the reasons for withdrawal in each group must be stated. If there were no withdrawals, it should be stated in the article. If there is no statement on withdrawals, this item must be given no points.
  from: Jadad AR, Moore A, Carroll D, et al: Assessing the Quality of Reports of Randomized Clinical Trials: Is Blinding Necessary? Controlled Clinical Trials 1996; 17:1–12.