# Appendix K. Acronyms in This Report

AAN = American Academy of Neurology

ACTH = adrenocorticotropic hormone

AD = Alzheimer's Dementia

ADL = activities of daily living

AEs = adverse events

AHRQ = Agency for Healthcare Research and Quality

ASHA = American Speech-Language-Hearing Association

BDI = Beck Depression Inventory

CAPIT = core assessment program for intracerebral transplantations

CAPSIT-PD = core assessment program for surgical interventional therapies in Parkinson's Disease

CBD = corticobasal degeneration

CBF = cerebral blood flow

COMT = catechol O-methyl transferase

CR = controlled release

CSF = cerebrospinal fluid

CT = computerized tomography

DA = dopamine agonist

DATATOP = deprenyl and tocopherol antioxidative therapy for Parkinson's Disease

DBS = deep brain stimulation

DEF = data extraction form

DLBD = diffuse Lewy body disease

EMG = electromyogram

FSMT = French selegiline multicenter trial

GH = growth hormone

GPi = globus pallidus

H&Y = Hoehn & Yahr Disability Scale

HVA = homovanillic acid

IBZM = ^123^I-iodobenzamide

IPD = idiopathic Parkinson's Disease

ITT = intention to treat

L-dopa = levodopa

LFT = liver function tests

LDI = Leonard Davis Institute

LID = L-dopa-induced dyskinesia

LSVT = Lee Silverman Voice Treatment

MAOB = monoamine oxidase B

MRI = magnetic resonance imaging

MSA = multiple system atrophy

MT = music therapy

NHP = Nottingham Health Profile

NMR = nuclear magnetic resonance

NPV = negative predictive value

nRCT = non-randomized controlled trial

NUDS = Northwestern University Disability Score

ODT = odor discrimination test

OIT = odor identification test

OPT = orofacial physiotherapeutic treatment

OT = occupational therapy

PBL - peripheral blood lymphocyte

PD = Parkinson's Disease

PDI = peripheral decarboxylase inhibitor

PET = positron emission tomography

PIGD = postural instability and gait disturbance

PMT = premotor time

PPV = positive predictive value

PRL = prolactin

PROPATH = a patient education and health promotion program

PSP = progressive supranuclear palsy

PSYCLOPS = psychosis and clozapine in Parkinson's Disease

PT = physical therapy

QC = quality control

QoL = quality of life

RAS = rhythmic auditory stimulation

RCT = randomized controlled trial

ROC = receiver operating characteristic

ROI = region of interest

S&E = Schwab and England scale

SLI = somatostatin-like immunoreactivity

SPECT = single photon emission computed tomography

SPM = statistical parametric mapping

SSRI = selectove serotonin reuptake inhibitor

STN = subthalamic nucleus

TCCS = transcranial color-coded real-time sonography

TEP = technical expert panel

TMS = transcranial magnetic stimulation

TOO = task order officer

UCS = uncontrolled case series

UPDRS = Unified Parkinson Disease Rating Scale

UPSIT = University of Pennsylvania Smell Identification Test

VEP = visual evoked potentials

WRS = Webster Rating Scale

XS = cross sectional