# Appendix J. Studies of Interest Excluded from Database

A few studies did not meet inclusion criteria, but the consulting PD experts recommended that they be mentioned in this review. These studies are discussed below, but were not extracted, entered into the database, or included in the statistical analyses.

## Pharmacological Treatment

The Parkinson Study Group conducted a 10-week, multicenter, double-blind RCT comparing placebo with various doses of pramipexole as monotherapy in 264 patients with early PD. ^1^ The trial did not meet the inclusion criteria for this review, due to its short duration; however, only two studies of pramipexole in early PD are included in the database, and this study is mentioned here for comparison. Pramipexole was well tolerated, and resulted in total UPDRS scores that were significantly improved compared with placebo. Studies of longer duration are necessary to confirm these favorable results.

A French, multicenter, open-label RCT compared tolcapone with bromocriptine in 146 PD patients who experienced “wearing-off” or “on/off” fluctuations on L-dopa/PDI. ^2^ As the trial lasted only eight weeks, it did not meet the inclusion criteria for this review, but it is the only direct comparison of tolcapone and bromocriptine, and therefore deserves mention. After eight weeks, patients in both groups had similar degrees of motor disability and “on/off” time. Patients in the tolcapone group were able to reduce their daily L-dopa dose more than were patients in the bromocriptine group. The side effect profile varied between the two groups. Studies of longer duration are necessary before conclusions can be made regarding a comparison of the efficacy and safety of bromocriptine and tolcapone.

Three double-blinded, placebo-controlled RCTs that were rejected because of insufficient study duration were readdressed upon the recommendation of a TEP member. One was the French selegiline multicenter trial (FSMT), a three-month study which showed that selegiline was statistically superior to placebo in improving symptoms in patients with early PD. ^3^ One study reported that pergolide monotherapy had superior efficacy to placebo in a three-month study of patients with early PD. ^4^ One six-week study of patients with “wearing-off” phenomenon on L-dopa assessed different doses of tolcapone in addition to L-dopa. ^5^ The addition of tolcapone reduced the “wearing-off” phenomenon. While all of these studies are important, their short duration precludes our ability to statistically compare the results of these studies to other studies in the database, and they remained in the “unaccepted studies” log.

A few studies have been performed using GM1 ganglioside, a normal constituent of nerve cell membranes, in human PD patients. ^6^ , ^7^ , ^8^ None of the studies met the criteria for acceptance for this review; only one was an RCT, and the study duration was less than 24 weeks. The study is, nevertheless, mentioned in this review, as GM1 represents a new category of pharmacologic treatment for PD that may receive further attention among researchers, although no studies published after 1998 were found.

After an initial intravenous test dose of GM1 1000 mg or placebo, 48 patients with mild to moderate PD were randomized to self-administered GM1 100 mg or placebo subcutaneously twice a day for 16 weeks. ^8^ Forty-five patients completed the study, and no withdrawals were related to the safety or efficacy of GM1. The main adverse events were injection site reaction, including rash, erythema, or swelling, in ten GM1 patients and one placebo patient, and insomnia in five GM1 patients and two placebo patients. Twelve placebo patients and three GM1 patients complained of fatigue. The UPDRS motor scores improved a mean of 7.5 points after 16 weeks of GM1, while remaining essentially unchanged in the placebo patients. Twenty-one patients elected to continue to take GM1 in an open-label extension of the RCT. ^7^ Eighteen of these 21 patients continued to have UPDRS motor scores better than baseline, while three had worse scores. Patients who took GM1 continuously for two years showed the greatest improvement from their baseline UPDRS motor scores. Three patients who were followed after they discontinued GM1 at the end of the double blind trial all developed worsening of their UPDRS motor scores.

## Anticholinergic Drugs

No trials of anticholinergic drugs met the inclusion criteria for this systematic review. In order to present the available information on this category of drugs, eight studies that were rejected for inclusion into the database but are pertinent to anticholinergic drugs in PD are mentioned here. The most recent studies are discussed first.

A cross-sectional study of the prevalence of dementia in PD was performed on 70 consecutive PD outpatients at a clinic of a university hospital. ^9^ Patients with dementia had received anticholinergic drugs for significantly longer than patients who were not mentally impaired, leading the authors to conclude that anticholinergic drugs should be avoided in PD patients with cognitive decline.

One study tested the cognitive function of 13 patients with newly diagnosed PD, before and after two weeks of treatment with trihexyphenidyl. ^10^ No patients were demented at baseline, and no significant change was seen in neuropsychological testing before and after the trihexylphenidyl. Given the short duration of the trial and the lack of cognitive impairment at baseline, it is difficult to draw any conclusions from this study.

In a retrospective analysis of 113 PD patients at a movement disorder clinic, the memory performance of patients taking anticholinergics was not significantly different from that of patients on dopaminergic medications alone. ^11^ This observation held true for patients with early, middle, or advanced disease. The presence of dementia at baseline was not reported, and may confound these findings, as other studies have suggested that anticholinergics impair cognitive function in patients who are already impaired at baseline. ^12^

A study of 78 PD patients showed that patients with PD for > 3 years had memory performance that was worse than controls, and patients on benzhexol had dosage-dependent memory impairment compared to patients on L-dopa alone. ^13^ The authors concluded that memory is impaired in PD, and benzhexol contributes to the memory decline.

Most studies of anticholinergics were published prior to 1990. In a placebo-controlled, double-blind cross-over study published in 1981, 29 men with PD for one year, on stable doses of L-dopa/PDI, were treated with 10 weeks of benztropine or placebo, followed by a five-week washout period, then 10 weeks of the opposite treatment. ^14^ The authors reported that qualitative and quantitative evaluations showed small but statistically significant improvements for rigidity, finger tapping speed, and ADL for patients on benztropine, compared with patients on placebo. No patients had dementia at baseline. Patients on benztropine had a ten percent decrease in one of the five cognitive measures tested, two patients complained of memory problems, poor concentration, irritability and confusion, and two patients experienced hallucinations. All adverse effects were reportedly mild and reversible with decreasing the medication dose. Interpretation of this study is limited by its short duration, the absence of results prior to cross-over, and the difficulty in comparing their evaluations with today's UPDRS scores.

A study published in 1978 evaluated 20 patients with early PD who were taking trihexyphenidyl. ^15^ L-dopa/PDI was openly added for eight weeks. All patients improved in bradykinesia, tremor, rigidity, and disability scale. The authors concluded that adding L-dopa/PDI to anticholinergics improves the therapeutic response in PD. This study is mainly of historic interest, as practitioners at that time were hesitant to use L-dopa, and were often treating PD patients with anticholinergics alone.

A double-blinded RCT comparing L-dopa plus trihexyphenidyl to L-dopa plus placebo was published in 1974. ^16^ There was no significant difference between the two groups, indicating that L-dopa alone was equivalent to L-dopa plus trihexyphenidyl.

The literature contains limited data regarding the efficacy and safety of anticholinergics in PD. Anticholinergics played an important role in the treatment of PD prior to the development of L-dopa, but their current role is limited to young, cognitively intact PD patients who have resting tremor as the predominant symptom. ^17^

## Surgery

One study compared overall effects of unilateral vs. bilateral STN in patients with advanced PD. ^18^ The study was not accepted into the database because no baseline data was reported on the ten patients in the study. They all underwent bilateral STN electrode implants, and the UPDRS scores of nine patients were assessed six months postoperatively, off medication, with stimulation off, on unilaterally, and on bilaterally. For all parameters measured, bilateral stimulation resulted in the greatest improvement, although unilateral STN DBS also led to moderate improvement in all PD symptoms.

One study that was published too late to meet the inclusion criteria for this systematic review was an RCT comparing the outcomes of embryonic tissue transplantation to sham surgery. ^19^ The active group consisted of 20 patients who underwent transplantation of human embryonic mesencephalic tissue containing dopamine neurons into their putamens. A control group of equal size underwent sham surgery, in which burr holes were drilled into their skulls, without penetration of the dura. The mean subjective global rating scores reported by patients one year after surgery were not significantly different between the two groups. The mean total UPDRS “off” scores one year postoperatively improved in the transplantation group compared to the control group, but the difference was not statistically significant (p=0.11). Patients ≤ 60 in the active group had significantly better UPDRS total, motor, rigidity, and bradykinesia scores than patients in the sham surgery group. Patients > 60 in the active group showed mild, not statistically significant improvement in UPDRS total scores, but no improvement in bradykinesia. Tremor did not improve in either age group.

The transplanted embryonic dopamine neurons survived well, as evidenced by 18F-fluorodopa PET scans in 19 transplant recipients, and autopsies in two transplant recipients who died of causes unrelated to their surgeries. Five of the younger patients who initially responded well to transplants developed severe, refractory dystonia and dyskinesia after the first year after transplantation. The researchers postulated that the transplanted embryonic dopamine neurons were producing too much dopamine in these patients.

While the initial results of embryonic tissue transplantation appeared promising in the younger patients, the development of late dystonia and dyskinesia clearly showed that this procedure is not a panacea for PD patients.

## Psychological

ThePSYchosis andCLOzapine inParkinson'S Disease (PSYCLOPS) trial examined the effects of clozapine on dopaminergic-induced psychosis. ^20^ As the trial lasted only four weeks, it did not meet the criteria for acceptance into our database, however, the study is worthy of mention due to the paucity of information on treatment of patients with antiparkinsonian drug-induced psychosis. Sixty PD patients with hallucinations or delusions induced by antiparkinsonian drugs were randomized to receive low-dose clozapine (n=30) or placebo (n=30). Dosage was titrated between 6.25 and 50 mg daily, depending on clinical response. In the treatment of schizophrenia, clozapine is generally prescribed at a much higher dosage of 300 to 900 mg daily.Patients in the clozapine group showed improvement in all measures of psychosis, and had no worsening of motor symptoms. There was a statistically significant improvement in tremor in the patients in the clozapine group. During the four weeks of the trial, one patient on clozapine developed leukopenia, and one discontinued clozapine due to sedation. In an open-label extension of the trial, another patient developed leukopenia, and six patients died. The investigators did not believe that any of the deaths were related to clozapine use. While these results are promising, RCTs of longer duration are needed, particularly to evaluate adverse events.

## Appendix J References

1 Parkinson Study Group. Safety and efficacy of pramipexole in early Parkinson's Disease. JAMA. 1997;278:125-30. [pmid: 9214527].
2 Tolcapone Study Group. Efficacy and tolerability of tolcapone compared with bromocriptine in Levodopa-treated parkinsonian patients. Mov Disord. 1999;14:38-44. [pmid: 9918342].
3 Allain H, Cougnard J, Neukirch H-C, et al. Selegiline in de novo parkinsonian patients: The French selegiline multicenter trial (FSMT). Acta Neurol Scand. 1991;84(Suppl 136):73-8. [pmid: 1927265].
4 Barone P, Bravi D, Bermejo-Pareja F, et al. Pergolide monotherapy in the treatment of early PD: A randomized, controlled study. Neurology. 1999;53:573-9. [pmid: 10449123].
5 Myllyla V V, Jackson M, Larsen J P, et al. Efficacy and safety of tolcapone in levodopa-treated Parkinson's Disease patients with “wearing-off” phenomenon: A multicentre, double-blind, randomized, placebo-controlled trial. Eur J Neurol. 1997;4:333-41.
6 Schneider J S, Roeltgen D P, Rothblat D S, et al. GM1 ganglioside treatment of Parkinson's Disease: An open pilot study of safety and efficacy. Neurology. 1995;45:1149-54. [pmid: 7783880].
7 Schneider J S. GM1 ganglioside in the treatment of Parkinson's Disease. Ann N Y Acad Sci. 1998;845:363-73. [pmid: 9668369].
8 Schneider J S, Roeltgen D P, Mancall E L, et al. Parkinson's Disease: Improved function with GM1 ganglioside treatment in a randomized placebo-controlled study. Neurology. 1998;50:1630-6. [pmid: 9633704].
9 Pondal M, Del Ser T, Bermejo F. Anticholinergic therapy and dementia in patients with Parkinson's Disease. J Neurol. 1996;243:543-6. [pmid: 8836945].
10 Schelosky L, Benke T, Poewe W H. Effects of treatment with trihexyphenidyl on cognitive function in early Parkinson's Disease. J Neural Transm. 1991;33(Suppl):125-32.
11 Levin B E, Llabre M M, Reisman S, et al. A retrospective analysis of the effects of anticholinergic medication on memory performance in Parkinson's Disease. J Neuropsychiatry Clin Neurosci. 1991;3:412-6. [pmid: 1821262].
12 Berchou R C. Maximizing the benefit of pharmacotherapy in Parkinson's Disease. Pharmacotherapy. 2000;20:33S-42S. [pmid: 10641990].
13 Miller E, Berrios G E, Politynska B. The adverse effect of benzhexol on memory in Parkinson's Disease. Acta Neurol Scand. 1987;76:278-82. [pmid: 3687379].
14 Tourtellotte WW, Potvin AR, Syndulko K, et al. Parkinson's Disease: Cogentin with Sinemet, a better response. Prog Neuropsychopharmacol Biol Psychiatry 1982; 51–5.
15 Agnoli A, Ruggieri S, Denaro A, et al. Parkinson's Disease improvement after the addition of levodopa-carbidopa to anticholinergic treatment. An open controlled study. Acta Neurol. 1978;33:436-42.
16 Martin W E, Loewenson R B, Resch J A, et al. A controlled study comparing trihexyphenidyl hydrochloride plus levodopa with placebo plus levodopa in patients with Parkinson's Disease. Neurology. 1974;24:912-9. [pmid: 4606107].
17 Olanow C W, Koller W C. An algorithm (decision tree) for the management of Parkinson's Disease: Treatment guidelines. Neurology. 1998;50(Suppl 3):S1-57. [pmid: 9524552].
18 Kumar R, Lozano A M, Sime E, et al. Comparative effects of unilateral and bilateral subthalamic nucleus deep brain stimulation. Neurology. 1999;53:561-6. [pmid: 10449121].
19 Freed C R, Greene P E, Breeze R E, et al. Transplantation of embryonic dopamine neurons for severe Parkinson's Disease. N Engl J Med. 2001;344:710-9. [pmid: 11236774].
20 Parkinson Study Group. Low-dose clozapine for the treatment of drug-induced psychosis in Parkinson's Disease. N Engl J Med. 1999;340:757-63. [pmid: 10072410].