# Appendixes

Appendix A. Major Parkinson's Disease Rating Scales

Appendix B. Work Plan

Appendix C. Topic Assessment and Refinement

Appendix D. Causal Pathways: Diagnosis and Treatment of Parkinson's Disease

Appendix E. Screening Sheets and Data Extraction Forms

Appendix F. Statistical Reference

Appendix G. Technical Experts and Peer Reviewers

Appendix H. Accepted Studies Log

Appendix I. Rejected Studies Log

Appendix J. Studies of Interest Excluded from Database

Appendix K. Acronyms in This Report