# Evidence Tables

Evidence Table 1. Prevalence of Pathologies of Adrenal Incidentaloma - Part I

Study, Year Identifier^a^ | Demographics | Reason for initial test (Other inclusion criteria) | Initial discovery test | Exclusion criteria | Study design, Enrollment yrs | Mean tumor size (cm)
Russi 1945 | Country: US | Death | Autopsy | Non-adenomas | 9,000 consecutive autopsies | 1.0
| # Centers: 1
| Mean age: 62.4 y
| # Cases: 131
| 54% Male
Kokko 1967 | Country: US | Death | Autopsy | ND | Retrospective 2,000 consecutive necropsis 1960-61. | (0.5–6.0)
67122291 | # Centers: 1
| Mean age: 64 y
| # Cases: 171
| 51% Male
Hedeland 1968 | Country: Sweden | Death | Autopsy | Non-adenomas | 739 consecutive autopsies collected prospectively in 1966 | (0.2 – 4.0)
69085558 | # Centers: 1
| Mean age: ND
| # Cases: 64
| ND % Male
Glazer 1982 | Country: US | ND | Excretory urography (2) CT (14) | ND | ND 1979-1981 | 2.4
82227342 | # Centers: 1
| Mean age: 57 y
| # Cases: 16
| 44% Male
Pagani 1982 | Country: US | Metastases workup | CT | ND | 1000 consecutive cancer patients Dec 1978 to Sept 1980 | ND
82190564 | # Centers: 1
| Mean age: ND
| # Cases: 37
| ND % Male
Abecassis 1985 | Country: Canada | Abdominal pain (6), Intraabdominal sepsis (2), biliary disease (2), hydronephrosis(1), pancreatitis(1), FUO(1), susp. lymphoma(1), Cancer (4), Weight loss (1) | CT (17), US (2) | Non-serendipitous findings | Retrospective 1980-82 | 2.8
85249069 | # Centers: 1
| Mean age: 60.8 y
| # Cases: 19
| 53% Male
Guerrero 1985 | Country: US | Abdominal or back disorders | CT | ND | Prospective? ND on dates | ND
86045544 | # Centers: 2?
| Mean age: 56 y
| # Cases: 13
| 23% Male
Bernardino 1985 | Country: USA | Adrenal biopsy | CT - part of oncologic work-up or incidentaloma | ND | Prospective cohort, 3 ½ years | 1.5 – 9 (n=44)
85069105 | # Centers: 1
| Mean age: ND
| # Cases: 53
| 55% Male
Hussain 1986 | Country: US | Known cancer patients Only included patients whose hospital record allowed for diagnosis of adrenal tumor | CT | See inclusion criteria | Retrospective 1976-83 | 3.6
86247668 | # Centers: 1
| Mean age: ND
| # Cases: 33
| ND % Male
Francis 1988 | Country: US | Known cancer patients, mets workup | CT | ND | Prospective | 1.2 – 10
88098153 | # Centers: 1
| Mean age: (54–75)
| # Cases: 28
| 57 % Male
Chang 1989 | Country: Taiwan | hypertension (1), abdominal pain (5), abdominal mass (2), constipation (1), flank pain (1), staging of a known malignancy (2) | IV urography, abdominal US, abdominal CT | Evidence of abnormal hormone production, adrenal cysts, myelolipomas, tumors in adrenal medulla | Retrospective 1979-1987 | 1 – 20
89274734 | # Centers: 1
| Mean age: (20–73)
| # Cases: 12
| 67% Male
Virkkala 1989 | Country: Finland | (Unsuspected adrenal mass) | US or CT | None had clinical signs of hormonal excess | Prospective 1982-1986 | 2.3 (1.0 – 6.0)
89300119 | # Centers: 4
| Mean age: 59 y (44–74)
| # Cases: 20
| 35% Male
Gaboardi 1991 | Country: Italy | (Adrenal incidentalomas referred to Urology Dept.) | US or CT | ND | Retrospective 1985-1989 | 6.0 (3.0–11.0)
91365585 | # Centers: 1
| Mean age: 51 y (12–71)
| # Cases: 13
| 54% Male
Caplan 1991 | Country: US | (Treated for adrenal disease/incidentaloma, radiologic study without clinical suspicion of adrenal disease) | CT (11), IVP (9), KUB (1), Prenatal US (1), Aortic arteriogram (1) | ND | Retrospective 1976-1988 | ND
92017488 | # Centers: 2
| Mean age: 56 y (Newborn - 82)
| # Cases: 23 (data presented for only 13)
| 57% Male
Chapuis 1991 | Country: France | Non-adrenal illness 16), atypcial pain (11), palpable mass (1, adrenal not considered), ND (6) (Non-secreting, unilateral incidentaloma, treated surgically) | US (22), CT (8), XR (1), MRI (2), Surgery (1) | ND | Retrospective 1981-1990 | 4.0 (1.7–12) Benign: 4 (1.7–12) Malig: 8 (6.8–10)
Sem Hop Paris | # Centers: 1
| Mean age: 58 y (20–71)
| # Cases: 34
| 44% Male
Herrera 1991 | Country: US | Abdominal pain (31%) | CT | History of malignancy | Retrospective? 1985-1989 | 94% were under 5.0
92080986 | # Centers: >1 | Known abdominal disease (19%) | | Adrenal hypersecretion
| Mean age: 61±13 y | Renal Problem (12%) | | Symptoms suggestive of malignant disease
| # Cases: 342 | Back symptoms (8%) | | Local invasion on CT
| 40% Male | Other (30%)
Aso 1992 | Country: Japan | Health exam, unrelated disease, US, CT, other (Pathological confirmation of incidentaloma) | ND | Metastatic CA workup | Retrospective 1980-1988 | ˜4.7 (1–20)
92277727 | # Centers: 116
| Mean age: 53 y (4–82)
| # Cases: 210
| 57% Male
Gillams 1992 | Country: UK | Pre-op for bronchial carcinoma (Adrenal mass; clinician's decision to consider surgical resection) | CT | ND | Retrospective 1985-1990 | 2.6 (1.1–8)
92354233 | # Centers: 1
| Mean age: 66 y (51–74)
| # Cases: 22
| 59% Male
Jockenhovel 1992 | Country: Germany | ND | ND | Lost to follow-up | Retrospective ND on years | 3.1 (1.8–9.0)
92372900 | # Centers: 1
| Mean age: 56 y
| # Cases: 36
| 50% Male
Turton 1992 | Country: US | Abdominal pain (2) | CT | Secreting tumors | Prospective ND on years | 2.0
93179697 | # Centers: 1 | Trauma (1) | | Active infection
| Mean age: 54.8±7.3 y | Abnormal hepatic enzymes | | Cancer not in remission
| # Cases: 12 | Bullous lung disease | | Nodule growth on subsequent CT
| 50% Male | Hematuria | | Life threatening systemic illness
| | Abdominal aortic aneurysm | | Adrenal hyper or hypofunction
| | Old L. Adrenal nodule | | Steroids or oral contraceptives.
| | Hypertension (2)
| | Renal abnormalities
| | Osteoporosis
Corsello 1993 | Country: Italy | US or CT of the abdomen for unrelated disease (incidentally discovered adrenal tumors) | US or CT | ND | Prospective 1991-1992 | 4.8 (1–16)
94039541 | # Centers: 1
| Mean age: 50 y (20–66)
| # Cases: 17
| 35% Male
Kobayashi 1993 | Country: Japan | ND | ND | All patients had non-functioning tumors | ND | 2.5±1.1 (non-malignant) 4.2±2.4 (metastatic)
93287338 | # Centers: 1
| Mean age: 56.7 y
| # Cases: 23
| 61% Male
Nakajo 1993 | Country: Japan | Incidentaloma - adrenal (or juxtaadrenal mass - not included in analysis) | US, CT, radiograph (1) | ND | Retrospective 1986 - 1991
94031431 | # Centers: ND
| Mean age: ND
| # Cases: 33
| % Male ND
Burt 1994 | Country: US | Routine CT staging for operable NSCLC patients with unilaterally enlarged adrenal gland | Abdominal or thoracic CT | Positive CT or MRI scan of brain or bone indicating metastatic disease | Prospective ND | 2.2 (1.2 – 7.1)
94133754 | # Centers: 1
| Median age: 58 y (42–75)
| # Cases: 27
| 41% Male
Boland 1995 | Country: US | Cancer patients with incidentaloma, 56 consecutive patients identified, 36 declined due to terminal nature of disease | CT | ND | Prospective 1993 | 2.8 (1.5 – 10)
95090097 | # Centers: 1
| Median age: 65 y
| # Cases: 20
| 65% Male
Flecchia 1995 | Country: Italy | Imaging for other than suspected adrenal disorder | ND | Sign or symptom or clinical history suggesting adrenal disorder | Consecutive ND | Adenoma & carcinoma: 3.7 (2.0–9.6); Other: ND
95219862 | # Centers: 1
| Mean age: Adenoma & carcinoma 57 y (20–96) Other ND (31–66)
| # Cases: 32
| 44% Male
Ambrosi 1995 | Country: Italy | (Imaging for unrelated diseases) | CT and/or MRI | Specific signs or symptoms of endocrine abnormalities | Unclear ND | 2.0–6.3
95227337 | # Centers: 1
| Median age: Women 49 y Men 67 y (28–74)
| # Cases: 32 (7 with dx)
| 28% Male
Bencsik 1995 | Country: Hungary | (Admission to tertiary care center because of incidentaloma) | ND | Evidence of pheo or primary hyperaldosteronism | Prospective ND | CT: (25–140)
95301995 | # Centers: 1 | | | | | Path: (20–210)
| Mean age: ND (27–85)
| # Cases: 63
| 40% Male
Terzolo 1995 | Country: Italy | Diagnostic workup performed for extraadrenal complaints | US, CT and Xray | Overt endocrine dysfunction | Prospective 1989-1994 | 3.7 (1.0 – 15.0)
95379649 | # Centers: 2
| Mean age: 58 y (19–79)
| # Cases: 45
| 42% Male
Peltier 1996 | Country: France | US or CT for unrelated disease (Unilateral, asymptomatic, incidentally discovered adrenal tumor) | US or CT | Not benign adenoma (for biochemical portion of study) | ? ND | ND
96307324 | # Centers: 12
| Mean age: Adenoma - 61 y (29–77)
| # Cases: 46
| 43% Male (Adenoma)
Aydintug 1996 | Country: Turkey | | Abdominal US or CT (primary non-functioning adrenal tumours) | ND | ? | 3.7 (1.5 – 10.0)
96317091 | # Centers: 1 | | | | 1986-1993
| Mean age: 50 y (24–67)
| # Cases: 20
| 10% Male (Adenoma)
Bastounis 1997 | Country: Greece | Back pain (10), Abdominal pain/bloating (21), GI disease (36), Kidney disease (8), Thoracic disease (6), HTN (2), AAA (2), Spontaneous rib fracture (1) (Adrenal lesions found ‘completely unexpected’; unrelated to tumor signs or symptoms or lab findings) | CT (69), US (9), IVP (5), XR (2), Aortic arteriogram (1) | ND | ? | 4.1 (2–16, all 86)
97244359 | # Centers: 1 | | | | ~1985 - ~1995
| Mean age: 61 y (38–76)
| # Cases: 86 (30 with dx)
| 40% Male
Bondanelli 1997 | Country: Italy | General, urologic, or gastroenterologic evaluations or surgery | US, CT or X-ray | Masses discovered during staging for malignant disease | Cohort or retrospective cohort 1990- | Median 2.55 (2–12)
97158618 | # Centers: 1?
| Mean age: 58±2.3 y
| # Cases: 38
| 42% Male
Mantero 1997 | Country: Italy | Imaging workup performed for extraadrenal complaints | ND | Severe or paroxysmal HTN, hypokalemia, clinical signs of hypercortisolism or hyper androgenism; known malignancies that frequently metastasize to adrenals | Prospective & retrospective 1980-1995 | ND
97311067 | # Centers: 29
| Mean age: ND
| # Cases: 1013
| % Male ND
Kasperlik-Zaluska 1997 | Country: Poland | ND | US (205) CT (3) | Tumors found on US not confirmed by CT (10) Congenital adrenal hyperplasia (2) | Retrospective? 1986-96 | Median 3.0 (0.8–21.0)
97212737 and 1992 94333175 | # Centers: 1
| Mean age: 51.8 y
| # Cases: 208
| 29% Male
Barzon 1998 | Country: Italy | Imaging workup performed for extraadrenal complaints | US, CT, or MRI | Severe or paroxysmal HTN, hypokalemia, clinical signs of hypercortisolism or hyper androgenism; previous or current malignancies | ? ND | 3.6 (0.8 – 18)
98097542 | # Centers: 1
| Mean age: 55 y (14–77)
| # Cases: 202
| 41% Male
Barry 1998 | Country: US | ND | Abdominal or thoracic CT | ‘Patients who underwent adrenalectomy or in whom the diagnosis of incidentaloma was made elsewhere…’ | Ambi-directional 1985-1989 | 2 (1.0 – 6.0)
98260226 | # Centers: 1
| Mean age: 64 y (5–86)
| # Cases: 231
| 44% Male
Xiao 1998 | Country: China | Patients with genitourinary tumor or disease | US or CT | Adrenal hyperplasia; non-adrenal Cushing's; Ectopic ACTH tumor; extraadrenal pheo | Retrospective 1960-1995 | ND
98389978 | # Centers: 1
| Mean age: Total: 39 y (1–77)
| # Cases: 78 (study total-211)
| Total: 55% Male
Masumori 1998 | Country: Japan | General health examination | US followed by CT | None | Retrospective? 1991-1996 | 2.9 (1.5 – 8.2)
98434037 | # Centers: 1
| Mean age: 52.7 y
| # Cases: 11
| 82% Male
Tütüncü 1999 | County: Turkey | Imaging workup performed for extraadrenal complaints | US or CT | ND | Retrospective 1985 - ? | 5.2±4.0
99233405 | # Centers: 1
| Mean age: 50.9 y (23–79)
| # Cases: 33
| 45% Male
Fontana 1999 | Country: Italy | Exam for extraadrenal complaints | US (150) CT (55) MRI, abdominal X-ray or surgery | Severe or paroxysmal hypertension, hypertension resistant to therapy, or associated with hypokalemia. History of lung, breast, kidney CA or melanoma. | Retrospective 1989-1996 | Median 3.1 (0.5 – 25)
99438934 | # Centers: 1 | Abdominal pain (37%)
| Mean age: 55.3±13.7 (Median 57) | Routine screening (20%)
| # Cases: 208 | Post-op follow-up (12%)
| 40% Male
Kudva 1999 | Country: US | Study looked at all patients at Mayo Clinic with Pheo and subset of these who were found incidentally | ND | ND | 1978-1995 | 6.1 (4.0–10.2)
Endocrinologist | # Centers: 1 | Imaging for back pain (2)
| Mean age: 59.7±13 y | Suspicious FNA (1)
| # Cases: 15 | Abdominal pain (5)
| 33% Male | Abnormal chest x-ray (2)
| | Syncope (1)
| | Microhematuria (1)
| | Aortogram (1)
| | Evaluation of hypotonic bladder (1)
Rossi 2000 | Country: Italy | US or CT for unrelated disease or check-up(Subgroup of referrals for adrenal masses, incidentaloma) | US or CT | Extraadrenal malignancy, HTN of possible endocrine origin, signs or symptoms of hormone production excess, Hormonal treatment | Prospective 1992-1998 | Adenoma 3.26 (1.0–6.5)
20230948 | # Centers: 1
| Mean age: 54 y (27–78)
| # Cases: 65
| 37% Male
Luton 2000 | Country: France | Medical check-up for non-endocrine disorder (31%) | US (2), CT or MRI (86) | Patients who did not have surgery (i.e. histological diagnosis). Usually patients with non-secreting tumors, <3.0 cm and homogeneous | Retrospective? 1978-1996 | 5.0±3.0
20329838 | # Centers: 1 | Pain syndrome (16%)
| Mean age: 53±14 y | GI Symptoms (14%)
| # Cases: 88 | Urinary symptoms (11%)
| 45 % Male | Hepatic symptoms (7%)
| | Other (21%)
Hashimoto 2000 | Country: Japan | Non-functioning tumors | ND | See inclusion criteria | ND | 3.2
20370702 | # Centers: 1 | No physical signs of steroid excess other than HTN, glucose metabolic disturbance and obesity.
| Mean age: ND
| # Cases: 11
| % Male ND

a Medline or unique identifying number assigned by EPC

Evidence Table 1: Prevalence of Pathologies of Adrenal Incidentaloma - Part II

Study, Year Identifier | Adenomas N (%) | Pheo- chromocytoma N (%) | Adrenal Carcinoma N (%) | Benign Pathologies N | Malignant Pathologies N | Characteristics of adrenal CA | Pathology of lesions in patients with known cancer
Russi 1945 | 131/9000 prev. = 1.46% | 0 | 0 | 131 | 0 | ND | ND
Kokko 1967 67122291 | 21/2000 prev. = 1.05 | ND | ND | ND | ND | ND | ND
Hedeland 1968 | 64/739 prev. = 8.66% | 0 | 0 | 64 | 0 | ND | ND
69085558
Glazer 1982 | | | | Adenoma (5), focal hyperplasia (1), no change in lesion on CT on avg. 9 months (10) | 0 | ND | ND
82227342
Pagani 1982 | 0 | 1 | 1 | 0 | 27 | ND | breast (4), colon (4), unknown primary (5), melanoma (3), lung (2), others (7)
82190564
Abecassis 1985 | | | | adenomas (2) ganglioneurom (1) alive and well without progression 21.4 mo on ave. (9) no pathology (1) | lymphoma (2) ovarian CA (1) | ND | ND
85249069
Guerrero 1985 | 8 (62%) | 0 | 0 | myelolipoma (1) without change on CT follow-up (3) | SCLC (1) | ND | ND
86045544
Bernardino 1985 | ND | 0 | 0 | ‘normal’ (27) cyst (1) hyperplasia (1) myelolipoma (1) hematoma (1) | Mets (18) | ND | lung (16), melanoma (6), colon (4), renal (3), unknown primary (4) endometrial (2), prostate (2), breast (2)
85069105
Hussain 1986 | 7/33 (21%) | 0 | 0 | 7 adenomas (1 proven) hyperplasia (1) fatty infiltration (1) | Mets (24) (10 proven) | Bilateral lesions were always metastases. Malignant lesions were larger. | All patients with CA. Path as noted in previous columns.
86247668
Francis 1988 | 16 | 0 | 0 | adenoma (16) | Mets (10) | NA | metastases (10) adenoma (16), cyst (2)
88098153 | | | | cyst (2)
Chang 1989 | 2 (17%) | 0 | 2 (17%) | | Metastatic CA unknown origin (2); lymphoma (1); no change after 3–24 mo (5) | 20 yr male abdominal pain 20 cm; 51yr male abdominal pain 6 cm | 61 yr male with transitional cell CA 2 cm lesion shows no change after 6 mo; 63 yr male with renal CA 1 cm lesion shows no change after 3 mo
89274734
Virkkala 1989 | 14 (70%) | 0 | 0 | Adrenal hyperplasia (3), Hematoma (2), (1) renal angiomyolipoma | 0 | None | None
89300119
Gaboardi 1991 | 2 (15%) | 2 (15%) | 2 (15%) | Myelolipoma (3), Hemorrhage (1) | SCLC (2), Lymphoma (1) | 45 yr male, 7.0; 58 yr male, 4.0 | None
91365585
Caplan 1991 | 7 (54%) | 0 | 1 (6%) | Cyst (1) | Metastatic angiosarcoma (1) congenital neuroblastoma (1)
92017488 | | | | Angiolipoma (1)
| | | | Vascular mass (1)
Chapuis 1991 | 17 (50%) | 1 (3%) | 2 (6%) | cystic lymphangioma (5), neurofibroma (2), schwannoma (1), adenoma vs angioma (1), hematoma (4) | Malignant angioperi-cytoma (1) | ND | None
Sem Hop Paris
Herrera 1991 | 330/342 (96%) (presumed) | 5 (1.5%) | 4/342 (1%) | 337 | 5 (one mets) | Larger (All > 5.0 cm) | ND
92080986
Aso 1992 | 69 (33%) | 49 (23%) [2 malignant] | 9 (4%) | Cushing's (7), Aldosteronism (7), cyst (18), lipoma (1), myelolipoma (15), ganglioneuroma (11), cortical hyperplasia (8), angioma (4), hematoma (2), granuloma (2), hamartoma (1), fibroma (1), TB (1), neurofibroma (1), medullary hyperplasia (1) | Metastatic Lung (1), Neuroblastoma (1), Ganglioneuro-blastoma (1) | Age 32–52, 6M, 3F, 7–20 cm | None
92277727
Gillams 1992 | 5 (23%) | 0 | 0 | Other (8); Non-diagnostic FNA (3); Loss to FU (1) | Mets (5) | None | squamous cell lung CA (4); lung adenocarcinoma (1)
92354233
Jockenhovel 1992 | 10 + 18 presumed | 0 | 0 | presumed (18) adenoma (10) Hemangioma, lipoma angiomyelolipoma, hyperplasia, myelolipoma | Lymphoma (1) | ND | ND
92372900
Turton 1992 | ND | ND | ND | 12 assumed benign-no operations performed. No change in size by CT over 4 yrs of FU. | ND | ND | ND
93179697
Corsello 1993 | 13 (76%) | 3 (18%) 1 (6%) | 1 (6%) | Hyperplasia (3), ganglioneuroma (2) | Pheo (1)
94039541
Kobayashi 1993 | 12 (55%) | 0 | 0 | Nodular hyperplasia (2), Medullary hyperplasi (1), Cavernous hemangioma (1), cyst (2). | Metastatic tumor (4) | Larger size 4.2 vs 2.5, Hetertogeneous enhancement on CT 80% vs. 21%. | ND
93287338
Nakajo 1993 | 1 (3%) | 2 (6%) | 3 (9%) | solid mass (16) | Mets 3 | 51 yr male 8 cm, 58 yr female 9.8 cm, 73 yr male 10 cm | Lung (2) Hepatocellular (1)
94031431 | | | | cyst (3)
| | | | myelolipoma (2)
| | | | ganglioneuroma (2)
| | | | calcified adrenal (1)
Burt 1994 | 22 (81%) | 0 | 0 | ND | Mets (5) | NA | Mean size 3.8 cm (2.5 – 7.1)
94133754
Boland 1995 | ND | 0 | 0 | 10/24 lesions 9/20 patients | 14/24 lesions 11/20 patients | NA | 11/20 patients had mets
95090097
Flecchia 1995 | 22 (69%) | 0 | 2 (6%) | Hematoma (2), Ganglio-neuroma (1), Abscess (1), Myelolipoma (1), Accessory Spleen (1) | Mets (2) | 44 yr female 9.6 cm; 55 yr female 5.6 cm | Unknown
95219862
Ambrosi 1995 | 4 (57%) | 0 | 1 (14%) | Hematoma (1), Myelolipoma (1) | 0 | 39 yr female, 6.0 cm | None
95227337
Bencsik 1995 | 14 (44%, 22% overall) No histo/“Benign”: 29 (46% overall) | 0 | 1 (3%, 1.5% overall) | Cyst (2), Myelolipoma (2), Ganglio-neuroma (4), Fatty tissue/pseudo-adrenal mass (1) | Leiomyosarcoma (1), Mets (7) | ND | ND
95301995
Terzolo 1995 | 8 (18%) | 2 (4%) | 3 (7%) | Cyst (1); Myelolipoma (1) | Mets (1), ganglionic neoplasia (1) | Adrenal carcinoma mass - 15, 13, 8 cm; ganglionic neoplasia 10 cm
95379649
Peltier 1996 | 35 (76%) | 2 (4%) | 2 (4%) | Myelolipoma (2), Ganglio-neuroma (1), Leiomyoma (1), Hematoma | Leiomyo-sarcoma (1), Mets (1) | ND | ND
96307324
Aydintug 1996 | 17 (85%) | 0 | 2 (10%) | Nodular hyperplasia (1) | 0 | Adrenal carcinoma mass - 10, 3.5 cm | NA
96317091
Bastounis 1997 | 20 (67%) | 2 (7%) | 1 (3%) | Adrenal pseudocyst (2), Hematoma (1), Myelolipoma (1), Echinococcal cyst (1), | Un-differentiated carcinoma (1), Lung CA mets | ND | None
97244359
Bondanelli 1997 | 5/15 (33%) | 2/15 (13%) | 1/15 (6.7%) | Lymphangiomatous cyst (1) | | Elevated UFC Non-suppressable with high dose DEX Low basal ACTH Mildly cushingoid Died 6 mo. after surgery | N/A
97158618 | | | | Ganglioneuroma (2)
| | | | Myelolipoma (1)
| | | | Hemorrhage (1)
| | | | Adrenal hyperplasia (1)
Mantero 1997 | 138 by histology (53% of those with histology); 680 clinical dx (81% overall) | 26 (or 27) (10% of those with histology; 3% overall) | 32 (12% of those with histology; 3% overall) | Myelolipoma (6) | Mets (12) | ND | None
97311067 | | | | Cyst (13)
| | | | Ganglio-neuroma (7)
| | | | Other with histology (13)
| | | | ND (76)
Kasperlik-Zaluska 1997/1992 | 21/85 (25%) by histology; 171/208 by clinical dx (82%overall) | 13/85 (15%) | 17/85 (20%) | 171 | 37 Adrenal CA (18) mets (19) | Larger size | ND
97212737 94333175
Barzon 1998 | 42 (21%) | 10 | 23 | Cyst (2) | Pheo (1) | ND | ND
98097542 | | | | Ganglio-neuroma (4) | Mets (6)
| | | | Hematoma (1) | Non-Hodgkin's lymphoma (1)
| | | | Myelolipoma (2)
| | | | Nodular hyperplasia (5)
| | | | Cirrhotic nodules (1)
| | | | Cirrhotic nodules (1)
| | | | Cortical adenoma with islets of medulla (1)
| | | | Other masses (104)
Barry 1998 | 224 (97%) | 0 | 0 | NA | 0 | NA | NA
98260226
Xiao 1998 | 9 (12%) | 17 (22%) [2 benign, 1 malignant, 14 ND] | 9 (12%) 2 (3%) | Cyst (4), Myelolipoma (1), Ganglio-neuroma (2), Fibroma (1), ND (22) | Ganglio-neuroblastoma (2), Mets (1), ND (10) | Including 8 “non-incidentaloma”: Mean size (range) = 14.3 (0.8–25) cm | ND
98389978
Masumori 1998 | 8/11 (72%) | 1/11 (9%) | 0 | 11/11 (100%) Ganglio-neuroma (1), cyst (1) | 0 | NA | NA
98434037
Tütüncü 1999 | 7/33 (21%) | 18/33 (18%) | 2/33 (6%) | Adenoma (7) | Met (2) | NA | ND
99233405 | | | | Cushing's synd (2) | Soft tissue neoplasms (7)
| | | | Pheo (6)
Fontana 1999 | 59/115 (51%) | 10/115 (9%) | 15/115 (13%) | 99/115 | 16/115 (14%)
99438934 | | | | Adenoma (59) | Adrenal CA (15)
| | | | Pheo (10) | Mets (1)
| | | | Lipoma/myelo (14)
| | | | Neuronal lineage tumors (8)
| | | | Cysts (7)
| | | | Old TB(1)
Kudva 1999 The Endocrin-ologist | 15/15 (100%) | 15 (100%) | 0 | 15 | 0 | NA | NA
Rossi 2000 | 50 (77%) | 5 (8%) | 2 (3%) | Ganglio-neuroma (2), Schwannoma (1), Cyst (3) | Mets (2) | ND | ND
20230948
Luton 2000 | 36 (41%) | 10 (11%) | 2 (2%) | 74 (84%) | 14 (16%) | Older age 62 vs 52 | ND
20329838 | | | | | | Weight loss 39% vs 7%
| | | | | | Size > 6.0 69% vs. 15%
| | | | | | Bilateral 23% vs 12%
Hashimoto 2000 | 8/11 (73%) | 0 | 0 | Myelolipoma (1) | 0 | Benign adenomas cause a rise in SSPG (glucose intolerance) | ND
20370702 | | | | Endothelioma (1)
| | | | Cyst (1)

Evidence Table 2: Diagnostic Performance of Tests to Evaluate Adrenal Masses - Part I

Study, Year Identifier | Demographics | Inclusion criteria | Exclusion criteria | Study design, Enrollment period | Initial discovery test
INCIDENTALLY FOUND ADRENAL MASS (INCIDENTALOMA)
Terzolo 2000 20292944 | Country: Italy | Adrenal mass found serendipitously | Extraadrenal cancer | Prospective cohort | “Diagnostic procedures performed for extraadrenal complaints”
| Median age (range): 58 (15–61) y | | Pre-treated adrenal cancer | 1990 - 1996
| Enrolled: 107 total
| Evaluated: 84 incidentaloma 23 suspected adrenal mass
| 36% Male
Fontana 1999 99438934 | Country: Italy | Adrenal incidentaloma | Severe or paroxysmal hypertension, resistant to treatment or associated with hypokalemia | Retrospective case series | US, CT, MRI, X-ray, Surgery
| Mean age (range): 55 (18–83) y | Post hoc, included only US-evaluable adenomas and carcinomas. | History of neoplasm known to metastasize to adrenal | 1989 - 1996
| Enrolled: 208
| Evaluated: 54
| 40% Male
Nakajo 1993 94031431 | Country: Japan | Incidental adrenal or juxtaadrenal mass | None described | Retrospective case series | CT, US, X-ray
| Mean age: ND | | | Jan 1986–June 1991
| Enrolled: 43
| Evaluated: 33 with adrenal mass
| % Male: ND
Bondanelli 1997 97158618 | Country: Italy | Unsuspected adrenal mass found during general, urologic, or gastroenterologic evaluations, or surgery | Specific signs or symptoms of hormone excess | Prospective cohort | US, X-ray
| Mean age (range): 58 (24–84) y | | Masses found during staging of malignant disease. | 1990-1996
| Enrolled: 38
| Evaluated: 38
| 42% Male
ADRENAL MASS FOUND DURING EXTRAADRENAL CANCER WORK-UP
Welch 1994 95062966 | Country: USA | Adrenal biopsies (Most were from extraadrenal cancer; 5/277 masses were adrenal gland tumor; unreported number were adrenal infection and hematoma) | Follow-up data could not be obtained | Retrospective chart review; longitudinal follow-up for at least 1 y | ND
| Age range: 31–84 y | | | Enrollment period: ND
| Enrolled: 270
| Evaluated: 270 (277 masses)
| 63% Male
Schwartz 1997 97312288 | Country: USA | New diagnosis of extraadrenal cancer | None described | Retrospective case series | CT
| Mean age (range):65 (39–83) y | Adrenal mass >1 cm on CT | | Nov 1993–Nov 1995
| Enrolled: 54 | MRI and CT-guided biopsy performed
| Evaluated: 54
| 61% Male
Krestin 1991 91100512 | Country: Switzerland | Extraadrenal malignancy | Refusal | Prospective (N=21) and retrospective (N=31) | ND
| Mean age: 54 y | Adrenal mass | Poor condition due to cancer | Enrollment period: ND
| Enrolled: 57 | | Claustrophobia
| Evaluated: 44 (52 masses) | | Pacemaker
| 61% Male
Mayo-Smith 1995 95305173 | Country: USA | Adrenal masses detected by CT | Lesions > 5 cm | Prospective cohort | CT
| Age range: 16–81 y | (Cancer work-up implied) | Pheochromocytoma | Enrollment period: ND
| Enrolled: 43 | | Dissimilar imaging on in-phase and out-of -phase CT
| Evaluated: 43 (46 masses)
| 65% Male
McNicholas 1995 96072697 | Country: USA | Adrenal mass > 1 cm | Evidence of metastatic disease elsewhere | Prospective cohort | CT
| Mean age (range): 63 (19–81) y | Oncologic patient | | Enrollment period: ND
| Enrolled: 33
| Evaluated: 33 (37 masses)
| 67% Male
Francis 1988 88098153 | Country: USA | Known primary malignant extra-adrenal neoplasms | None | Prospective cohort | CT
| Age range: 54–75 y | Unilateral adrenal mass > 1 cm detected by CT | | Enrollment period: ND
| Enrolled: 28 | Normal adrenal function clinically and biochemically
| Evaluated: 28
| 57% Male
Burt 1994 94133754 | Country: USA | Potentially operable non-small cell lunc cancer | Otherwise metastatic disease found on CT or MRI | Prospective cohort | CT
| Median age (range): 58 (54–75) y | Unilaterally enlarged adrenal gland | | Enrollment period: ND
| Enrolled: 27
| Evaluated: 27
| 41% Male
Hussain 1986 86247668 | Country: USA | Extraadrenal malignancy | None described | Retrospective case series | CT
| Mean age: ND | Unsuspected adrenal abnormality found on CT | | Jan 1976 – Dec 1983
| Enrolled: 57 total | Diagnosis available in hospital records
| Evaluated: 26 with mass
| % Male: ND
Boland 1995 95090097 | Country: USA | Extraadrenal malignancy | Diabetes mellitus | Prospective cohort | CT
| Mean age: 64 y | Incidental adrenal mass | Mass < 1 cm | Jan–Dec 1993
| Enrolled: 20
| Evaluated: 20
| 65% Male
BOTH ADRENAL INCIDENTALOMA AND ADRENAL MASS FOUND DURING EXTRAADRENAL CANCER WORK-UP
Gross 1994 94284860 | Country: USA | Adrenal mass found incidentally during CT evaluation -- includes subjects being staged or evaluated for known or suspected extraadrenal cancer (N=101) | Adrenal dysfunction | Prospective cohort | CT
| Mean age (range): 63 (18–90) y | | Bilateral mass | Jan 1976–Dec 1992
| Enrolled: 229
| Evaluated: 229
| 50% Male
Silverman 1993 93268895 | Country: USA | Adrenal mass found during extraadrenal cancer staging (N=83) or | None described | Retrospective case series | ND
| Mean age: ND | Incidental adrenal mass, no known malignancy (N=14) | | 9-year enrollment period
| Enrolled: 97
| Evaluated: 97
| % Male: ND
Bernardino 1985 85069105 | Country: USA | Adrenal mass found during oncologic work-up or | None described | Retrospective case series | CT
| Mean age: ND | Adrenal mass found serendipitously, no known malignancy | | 3½ -year enrollment period
| Enrolled: 53 | (ND on numbers)
| Evaluated: 53 (58 biopsies)
| 55% Male
Dominguez-Gadea 1994 95043883 | Country: Spain | Adrenal masses found during work-up of known or suspected extraadrenal cancer (N=29) or | Signs or symptoms of adrenal dysfunction | Prospective cohort (unclear) | CT
| Mean age: ND | Adrenal mass found incidentally (N=20) | | Oct 1980–Oct 1991
| Enrolled: 42
| Evaluated: 42 (49 masses)
| % Male ND
Gross 1995 95331328 | Country: USA | Incidentally found adrenal mass | Adrenal dysfunction | Prospective cohort | CT
| Mean age: ND | Bilateral masses (includes subjects being staged for known or suspected cancer, ND on N) | | Jan 1976–Jan 1992
| Enrolled: 29
| Evaluated: 29
| % Male: ND
INCIDENTALLY FOUND ADRENAL ADENOMA
Berkman 1984 84156084 | Country: USA | Adrenal mass found in work-up for known or suspected extraadrenal cancer (N=9) or | None described | Prospective cohort (unclear) | CT
| Age range: 31–70 y | Adrenal mass found incidentally (N=5) or | | Enrollment period: ND
| Enrolled: 16 | Adrenal mass suspected for a possibly functional mass (N=1)
| Evaluated: 15
| 56% Male
Bardet 1996 96307324 | Country: France | Incidentally found, unilateral, asymptomatic adrenal mass | Not benign adrenal adenoma (excluded secondarily) | Prospective cohort | CT, US
| Mean age (range): 61 (29–77) y | | Cancer | Enrollment period: ND
| Enrolled: 46 | | Clinical signs of Cushing's syndrome
| Evaluated: 35
| 43% Male
Valli 2001 21172450 | Country: France | Incidentaloma > 10 cm | None described | Prospective cohort | CT
| Mean age (range): 58 (25–80) y | Benign cortical adenoma (as suggested by CT) | | 22 mo enrollment period
| Enrolled: 31
| Evaluated: 31
| 39% Male
ADRENAL MASS
Szolar 1997 97167394 | Country: Austria | Adrenal mass | Neither follow-up nor cytological/histological analysis was possible | Prospective cohort | CT
| Mean age (range): 60 (12–83) y | | Adrenal cyst | Enrollment period: ND
| Enrolled: 72
| Evaluated: 72
| 60% Male
Lee 1991 91195510 | Country: USA | Adrenal mass on CT report | Unreadable or lost tapes | Retrospective case series | CT
| Mean age (range): 52 (30–75) y | | No final diagnosis | 6 mo in 1988
| Enrolled: 55 | | No unenhanced CT
| Evaluated: 55 | | Mass < 1 cm
| 56% Male | | Attenuation values < -50 HU, consistent with myelolipoma
| | | Endocrine hyperfunction
Korobkin 1996 96347844 | Country: USA | Adrenal mass | None described | Prospective cohort | CT
| Mean age (range): 62 (36–79) y | | | Sep 1994–Oct 1995
| Enrolled: 39
| Evaluated: 39 (51 masses)
| 64% Male
van Erkel 1994 94246003 | Country: Netherlands | Adrenal mass | None | Retrospective case series | ND
| Mean age (range): 48 (21–77) y | | | Jan 1985– Jan 1991
| Enrolled: 37
| Evaluated: 37 (44 masses)
| 41% Male
Chezmar 1988 88098154 | Country: USA | Adrenal mass | None described | Unclear | CT
| Mean age: ND | | | Enrollment period: ND
| Enrolled: 28
| Evaluated: 28 (35 masses)
| % Male: ND
Singer 1994 94298222 | Country: USA | CT done in patient found to have adrenal lesion or adrenal mass that was biopsied | Characteristic CT appearance of cyst | Retrospective case series | CT, surgery, possibly others
| Mean age (range): Male: 60 (34–75) y | | No mass seen on CT | Jan 1988 – Oct 1991
| Enrolled: 23 | | CT tape missing
| Evaluated: 23 (24 masses) | | Pheochromocytoma
| 30% Male | | CT-guided biopsy unsatisfactory
Heaston 1982 82208978 | Country: USA | Adrenal biopsy | None reported | Prospective cohort | CT
| Age range: 55–73y y | | | Jan 1980 – July 1981
| Enrolled: 14
| Evaluated: 14
| % Male ND
COMBINED INCIDENTALOMA, ADRENAL MASS FOUND DURING CANCER WORK-UP, AND CLINICALLY-SUSPECTED ADRENAL MASSES
Bilbey 1995 95168077 | Country: Canada | Incidentally found adrenal mass (N=18) or | None described | Prospective cohort | CT, US, possibly others
| Mean age (range): 53 (17–78) y | Adrenal mass found during extraadrenal cancer work-up (N=9) or | | Enrollment period: ND
| Enrolled: 38 | Adrenal mass found during work-up for hormonal dysfunction (N=11)
| Evaluated: 38 (41 masses)
| 45% Male
Karstrup 1991 92054304 | Country: Denmark | Adrenal mass | None reported | Retrospective case series | US
| Median age (range): 56 (30–79) y | Extraadrenal cancer work-up (12) | | 1984-1990
| Enrolled: 28 | Incidental (15)
| Evaluated: 28 | Cushing's disease (1)
| 57% Male
Montali 1984 85019801 | Country: Italy | Solid unilateral adrenal masses detected with US or CT | None reported | Prospective cohort | US, CT
| Age: ND | Extraadrenal cancer work-up (11) | | June 1980 – Dec 1983
| Enrolled: 18 | Incidental (2)
| Evaluated: 18 | Symptomatic (5)
| % Male ND
COMBINED ADRENAL MASS FOUND DURING CANCER WORK-UP AND CLINICALLY-SUSPECTED ADRENAL MASSES
Katz 1984 84226856 | Country: USA | Adrenal mass found during extraadrenal cancer work-up or | No histological confirmation or good clinical and radiologic follow-up for at least 2 y | Retrospective case series | CT, US, angiography
| Age range: 1–82 y | Adrenal mass that were symptomatic | | 1976-1981
| Enrolled: 22 | (ND on numbers)
| Evaluated: 22
| 41% Male

Evidence Table 2: Diagnostic Performance of Tests to Evaluate Adrenal Masses - Part II

Study, Year Identifier | Blinding | Reference test (N) | Funding source | Comments
INCIDENTALLY FOUND ADRENAL MASS (INCIDENTALOMA)
Terzolo 2000 20292944 | ND | Mass excision (20) | ND | Data on test performance of CT based on total sample, both with incidentaloma and clinically suspected adrenal mass.
| | CT with follow-up ≥12 mo (64, N implied) | | Text and data on CT test performance not consistent. Text reports that CT specificity based on inconclusive CT pattern; specificity appears to really be based on either inconclusive or benign CT pattern
| | | | No extractable data for test performance of DHEAS
Fontana 1999 99438934 | ND | Mass excision (115/208; unclear if all included subjects had mass excision) | ND | Analyzed only subjects with carcinoma or adenoma
| | ND on other subjects | | US features evaluable on only 54/72 lesions
| | | | Unclear reporting
Nakajo 1993 94031431 | ND | Mass excision (15/39) | ND | On NP-59 scintigraphy,
| | Clinical and CT follow-up for 6 mo-4 y (24/39) | | 0/2 (0%) hot nodules were malignant;
| | | | 0/10 (0%) hot nodules with adjacent activity were malignant;
| | | | 0/1 (0%) warm nodules were malignant;
| | | | 0/3 (0%) scans with normal pattern were malignant;
| | | | 1/1 (100%) scans with inhomogenous uptake were malignant;
| | | | 0/4 (0%) scans with diffuse decrease were malignant;
| | | | 2/5 (40%) scans with partial defects were malignant;
| | | | 3/7 (43%) scans with complete defects were malignant.
| | | | Test performance not calculated.
| | | | Definitions of positive and negative scans not explicitly stated.
Bondanelli 1997 97158618 | ND | CT and biochemical follow-up for 6–18 mo (14) | Government | Test performance not calculated.
| | Mass excision (24, N implied) | Private | Definitions of positive and negative scans not explicitly stated.
ADRENAL MASS FOUND DURING EXTRAADRENAL CANCER WORK-UP
Welch 1994 95062966 | Not possible | Not clearly defined | ND | All analyses performed on biopsies, not subjects
| | Includes follow-up for 1 y or death | | “Accuracy depended on size of the needle used to perform biopsy but not on the size of the lesion.”
| | | | Incomplete data reporting. Unable to extract data.
| | | | Reference standard unclear. Diagnostic test appears to have been used, in part, for reference standard.
| | | | Positive and negative outcomes not clearly defined.
Schwartz 1997 97312288 | ND | Histology from CT-guided biopsy (54) | ND
Krestin 1991 91100512 | Readers of CT and MRI were blinded to results of prior CT | Histology from biopsy (8) or mass excision (15), | ND | All analyses performed on masses, not subjects
| | Clinical and CT follow-up ≥ 12 mo (29)
Mayo-Smith 1995 95305173 | ND | Histology (21) | ND | New software was introduced at conclusion of study--not all patients were imaged with shortest possible echo times.
| | Imaging F/U (17) | | Transmit power and receive gain were not constant between in-phase and out-of-phase acquisitions--variations in gain reduce the accuracy of quantitative measurements, particularly signal intensity index.
| | CT attenuation values < 0 H (8)
McNicholas 1995 96072697 | ND | Biopsy (27) | ND | All analyses performed on masses, not subjects
| | CT follow-up for ≤ 12 mo (12–72 mo, N=9) | | Text appears to be incorrect in reporting of test performance of unenhanced CT for thresholds of 0 HU.
| | | | Data also reported on test performance for size threshold of 3 cm. Unclear if data are from CT or MRI or both. Error in reporting makes analysis of test performance uncertain.
| | | | Frequent other incorrect or unclear data.
Francis 1988 88098153 | ND | Histology (21) | ND
| | Clinical, CT F/U > 6 mo (7)
Burt 1994 94133754 | Yes | Surgery or biopsy (16–26, unclear) | ND | Text somewhat unclear at points
| | Clinical follow-up 38 mo (1)
| | Not reported (0–10)
Hussain 1986 86247668 | No | Biopsy, mass excision or autopsy (13) | ND | Short follow-up period
| | Clinical follow-up 3–6 mo (20) | | Unclear how criteria for positive CT made (?post hoc)
| | | | 24 potential subjects with adrenal mass and CT not included because “comparison of CT findings with hospital records” not possible. Unclear how this group differed from included subjects
Boland 1995 95090097 | PET and CT initially read separately, but final interpretation made by combined PET and CT reading | Surgery or biopsy (15 masses) | ND | “No correlation existed between the histologic findings of the metastasis and SUV values.”
| | CT follow-up 8–30 mo (9)
BOTH ADRENAL INCIDENTALOMA AND ADRENAL MASS FOUND DURING EXTRAADRENAL CANCER WORK-UP
Gross 1994 94284860 | ND | Adrenalectomy or FNA (99) | Government Hospital | On NP-59 scintigraphy,
| | Serial follow-up with clinical, biochemical, and CT for 6 mo-3y (130) | | 159/171 (93%) subjects with asymmetry, increased uptake or lateralizing activity had adenomas;
| | | | 12/12 (100%) subjects with bilateral symmetry had adenomas;
| | | | 41/41 (100%) subjects with lateralization to side opposite of mass on CT had malignancy or space-occupying lesion;
| | | | 3/3 (100%) subjects with normal scans had metastatic cancers.
| | | | Reporting unclear. Reported numbers do not add up properly.
| | | | Positive reference standard (destructive or space-occupying lesions includes both benign and malignant conditions.
| | | | Multiple other articles apparently included subsets of same group of subjects.
Silverman 1993 93268895 | ND | Surgical or autopsy data (83) | ND | Some incomplete reporting on subgroups by mass size or needle gauge
| | Clinical and or CT follow-up (14)
Bernardino 1985 85069105 | ND | ND (44) | ND | No clear reference standard, with inadequately brief follow-up duration in some.
| | Repeat CT (2) | | No data could be extracted to determine test performance.
| | Clinical follow-up for 1–18 mo (7)
Dominguez-Gadea 1994 95043883 | Readers of scintigraphy knew which gland was abnormal on CT | Histology (18) | ND | All analyses performed on masses, not subjects
| | CT follow-up for ≥ 1 y (24) | | On 6-methyl-75-selenomethyl-19-norcholesterol scintigraphy,
| | | | 18/18 (100%) masses with increased uptake were adenomas,
| | | | 13/14 (93%) with decreased uptake were metastases,
| | | | 7/9 (78%) with decreased uptake were adrenal carcinoma (2), lymphoma (2), TB (2), or myelolipoma (1)
| | | | Test performance not calculated.
| | | | Definitions of positive and negative scans not explicitly stated.
Gross 1995 95331328 | ND | Biopsy (19) | Government Hospital | On NP-59 scintigraphy,
| | CT follow-up for 6 mo - 3 y (10) | | 0/8 (0%) scans with symmetry were metastases
| | | | 5/13 (38%) scans with asymmetric visualization were metastases;
| | | | 8/8 (100%) scans with non-visualization were metastases.
| | | | Only included subjects with bilateral masses.
| | | | Test performance not calculated.
| | | | Definitions of positive and negative scans not explicitly stated.
Berkman 1984 84156084 | ND | FNA (15) | ND | One subject had clinically suspected Cushing's disease
| | CT follow-up (1) | | One subject (with incidentaloma) was not analyzed because FNA was technically unsuccessful
| | | | No reference standard
INCIDENTALLY FOUND ADRENAL ADENOMA
Bardet 1996 96307324 | ND | NP-59 Scintigraphy (35) | Private | No clinical outcomes.
| | | | Reference standard was uptake on scintigraphy (unilateral association with functional autonomy)
Valli 2001 21172450 | ND | NP-59 Scintigraphy (31) | ND | No clinical outcomes.
| | | | Reference standard was uptake on scintigraphy (unilateral association with functional autonomy)
ADRENAL MASS
Szolar 1997 97167394 | Radiologists had no knowledge of clinical, histologic or follow-up findings | Biopsy (28) | ND | All analyses performed on masses, not subjects
| | Mass excision (11)
| | CT and clinical follow-up for 12 mo (33)
Lee 1991 91195510 | Radiologists had no knowledge of histologic or follow-up findings | Biopsy (4 masses) | ND | All analyses performed on masses, not subjects
| | Mass Excision (1 mass) | | Graph of CT values vs mass size appears to be missing one mass
| | CT follow-up for 6 mo (61 masses)
Korobkin 1996 96347844 | Radiologists blinded to final diagnosis | Biopsy (12) | ND | Study of delayed enhanced CT used, in part, delayed CT (?unenhanced) as reference standard
| | Scintigraphy (1)
| | Delayed CT attenuation < 18 HU = adenoma (25)
| | CT follow-up for 8–36 mo (13))
Van Erkel 1994 94246003 | Yes | Histology (23) | ND
| | Clinical, CT F/U > 1 y (21)
Chezmar 1988 88098154 | ND | Biopsy (11 masses) | ND | All analyses performed on masses, not subjects
| | CT follow-up for 6 mo (17 masses) | | Some missing data
Singer 1994 94298222 | Radiologists blinded | Biopsy (13, 13 masses) | ND | All analyses performed on masses, not subjects
| | Mass Excision (10, 11 masses)
Heaston 1982 82208978 | ND | Cytology, culture (9) | ND | No independent reference standard for most subjects
| | Stability over 1 y follow-up (1)
| | Surgery (3)
| | Presumed diagnosis based on later sputum cytology (1 lung cancer)
COMBINED INCIDENTALOMA, ADRENAL MASS FOUND DURING CANCER WORK-UP, AND CLINICALLY-SUSPECTED ADRENAL MASSES
Bilbey 1995 95168077 | Not intentionally blinded, in most cases diagnosis not yet established at time of reading | FNA (11 masses) | ND | All analyses performed on masses, not subjects
| | Mass excision (17 masses) | | Extraadrenal pheochromocytomas (N=2) included with non-adenomas
| | CT follow-up for 12–32 mo (13 masses)
Karstrup 1991 92054304 | ND | ND | ND | Unclearif inconclusive biopsies of “adrenal neoplasia” were adenomas, pheochromocytoma, or both.
Montali 1984 85019801 | ND | Surgery (6) | ND | No independent reference standard for subjects with cancer work-up
| | Autopsy (1)
| | FNA cytology results considered conclusive in the metastatic tumors
COMBINED ADRENAL MASS FOUND DURING CANCER WORK-UP AND CLINICALLY-SUSPECTED ADRENAL MASSES
Katz 1984 84226856 | ND | Cutting needle biopsy (10) | ND | Same patients reported on in multiple other articles
| | Percutaneous needle aspiration, cutting needle biopsy, or open biopsy (8) | | Method of determining reference standard incomplete and, in part, includes FNA.
| | Laparotomy (2)
| | ND (2)

Evidence Table 2: Diagnostic Performance of Tests to Evaluate Adrenal Masses - Part III

Study, Year Identifier | Definition of a Positive reference standard (N) | Definition of a Negative reference standard (N) | Diagnostic test examined | Definition of Positive & Negative tests (N) | Sensitivity | Specificity
INCIDENTALLY FOUND ADRENAL MASS (INCIDENTALOMA)
Terzolo 2000 20292944 | Adrenal carcinoma or mets (12) | Benign (includes pheochromocytoma) (95) | Unenhanced or enhanced CT | + “Malignant” CT pattern: mass size > 4.0 cm, non-homogeneous content with irregular shape and margins, possibly with infiltration of surrounding tissues or distant metastases or both (12) | 92% | 89%
| | | | - “Benign” CT pattern: unenhanced ≤ 10 HU and enhanced ≤30 HU, size 4 cm, round/oval, homogeneous, well-defined margins or "inconclusive CT pattern: not all characteristics of benign pattern were met (95)
| Adrenal carcinoma or mets (ND) | Benign (includes pheochromocytoma) (ND) | DHEAS at 0800 hr | + High or normal value based on age- and gender-adjusted reference ranges (ND) | “100%” | “38%”
| | | | - Low value (ND) | No extractable data provided
Fontana 1999 99438934 | Adrenal carcinoma (12) | Adenoma (42) | CT (implied enhanced) | + Inhomogeneous (30) | 92% | 54%
| | | | - Hypodense (24)
| Adrenal carcinoma (12) | Adenoma (42) | US | + Inhomogenous (28) | 67% | 52%
| | | | - Homogeneous (26)
Nakajo 1993 94031431 | Adrenal carcinoma or Mets (6) | Benign mass (27) | NP-59 Scintigraphy | + Inhomogeneous uptake or partial or complete defect (13) | 100% | 74%
| | | | - Normal pattern or hot or warm nodule or diffuse decrease (20)
| | | | Not defined in report.
Bondanelli 1997 97158618 | Adrenal carcinoma (1) | Other, including pheochromocytoma (25) | NP-59 Scintigraphy | + Cold lesion (4) | 100% | 88%
| Not defined in report. | Not defined in report. | | - Symmetric or asymmetric to side of lesion (22)
| | | | Not defined in report.
| Pheochromocytoma (1) | Other, including malignancy (35) | DHEAS at 0800 hr (fasting) | + <2.5 μmol/L (men < 50 y), < 1.6 μmol/L (men ≥ 50 y), < 1.9 μmol/L (pre-menopaual), < 1.1 μmol/L (post-menopausal) (18) | 100% | 51%
| Not defined in report. | Not defined in report. | | - Other (18)
| | | | Not defined in report.
| Pheochromocytoma (1) | Other, including malignancy (31) | Overnight 1 mg Dexamethasone one suppression test | + Cortisol at 0800 hr not suppressed, > 0.09 μmol/L (4) | 0% | 87%
| Not defined in report. | Not defined in report. | Basal ACTH at 0800 hr | - Suppressed (28)
| | | | Not defined in report.
| Pheochromocytoma (1) | Other, including malignancy (36) | | + < 1.5 pmol/L (7) | 0% | 81%
| Not defined in report. | Not defined in report. | | - ≥ 1.5 pmol/L (30)
| | | | Not defined in report.
ADRENAL MASS FOUND DURING EXTRAADRENAL CANCER WORK-UP
Welch 1994 95062966 | Malignancy -- not explicitly stated (ND) | Benign lesion -- not explicitly stated (ND) | FNA | Not defined | “81%” (biopsies) | “99%” (biopsies)
| | | | | Incomplete extractable data provided
| | | | | Accuracy (TP+TN) = 90% (249/277 biopsies)
| | | | | FP (N=1); FN (N=27)
Schwartz 1997 97312288 | Metastases (23) | Adenoma (31) | MRI | + Adrenal:Spleen signal intensity ratio > 0.55 (25) | 100% | 94%
| | | | - Ratio < 0.55 (29)
Krestin 1991 91100512 | Mets or adrenal cancer(23 and 1 masses, respectively) | Adenoma or unsuspected pheochromocytoma (15 and 1 masses, respectively) | Enhanced (N=38 total) or Unenhanced (N=6 total) CT | + 3 or more of: > 3 cm, > 15 HU, blurred margin, irregular, inhomogeneous (21 masses) | 71% | 75%
| | | | - 3 or more of: < 3 cm, < 10 HU (unenhanced), sharp borders, round or triangular, homogenous (19 masses)
| | | | Equivocal not included
| Mets or adrenal cancer (27 and 1 masses, respectively) | Adenoma or unsuspected pheochromocytoma (23 and 1 masses, respectively) | Enhanced (N=38 total) or Unenhanced (N=6 total) CT | + As above orEquivocal (33 masses) | 75% | 50%
| | | | - As above (19 masses)
| Mets or adrenal cancer (22 and 1 masses, respectively) | Adenoma or unsuspected pheochromocytoma (16 and 1 masses, respectively) | Non-contrast MRI | + Lesion:Fat signal intensity ratio > 2.0 (24 masses) | 96% | 88%
| | | | - Ratio between 0.5 and 1.5 (16 masses)
| | | | Equivocal not included
| Mets or adrenal cancer (27 and 1 masses, respectively) | Adenoma or unsuspected pheochromocytoma (23 and 1 masses, respectively) | Non-contrast MRI | + As above orEquivocal (36 masses) | 96% | 63%
| | | | - As above (16 masses)
| Mets or adrenal cancer (27 and 1 masses, respectively) | Adenoma or unsuspected pheochromocytoma (23 and 1 masses, respectively) | Plain + contrast-enhanced MRI | + As above and a maximal signal intensity increase > 150%, and still visible increase after 10 min > 75% (28 masses) | 100% | 91%
| | | | - As above and maximal increase < 100%, and after 10 min < 30% (20 masses)
| | | | Equivocal not included
| Mets or adrenal cancer (27 and 1 masses, respectively) | Adenoma or unsuspected pheochromocytoma (23 and 1 masses, respectively) | Plain + contrast-enhanced MRI | + As above orEquivocal (32 masses) | 100% | 83%
| | | | - As above (20 masses)
Mayo-Smith 1995 95305173 | Metastasis (18 masses) | Adenoma (28 masses) | MRI | + T1 Mass:Spleen signal intensity ratio ≥ 0.75 (23) | 100% | 82%
| | | | - Ratio > 0.75 (23)
| | | | T1 Mass:Spleen: | AUC = 0.97
| | | | T1 Mass: Liver signal intensity ratio
| | | | T1 Mass:Liver: | AUC = 0.81
| | | | T1 Mass: Muscle signal intensity ratio
| | | | T1 Mass: Muscle: | AUC = 0.91
McNicholas 1995 96072697 | Mets (19 masses) | Adenoma (18 masses) | Unenhanced CT | + Density > 0 HU (24 masses) | 100% | 72%
| | | | - Density < 20 HU (13 masses)
| Mets (19 masses) | Adenoma (18 masses) | Unenhanced CT | + Density > 20 HU (13 masses) | 68% | 100%
| | | | - Density < 20 HU (24 masses)
| Mets (19 masses) | Adenoma (18 masses) | MRI | + Adrenal:Spleen signal intensity ratio > 0.70 (23 masses) | 100% | 78%
| | | | - Ratio < 0.70 (14 masses)
| Mets (19 masses) | Adenoma (18 masses) | MRI | + Adrenal:Spleen signal intensity ratio > 0.75 (21 masses) | 95% | 83%
| | | | - Ratio < 0.75 (16 masses)
| Mets (19 masses) | Adenoma (18 masses) | MRI | + Adrenal:Spleen signal intensity ratio > 0.80 (18 masses) | 84% | 89%
| | | | - Ratio < 0.80 (19 masses)
| Mets (19 masses) | Adenoma (18 masses) | Combined Unenhanced CT and MRI | + CT density > 0 and MRI Adrenal:Spleen ratio > 0.70 (20 masses) | 100% | 94%
| | | | - Other (17 masses)
Francis 1988 88098153 | Mets (10) | Adenoma (16), Cyst (2) | NP-59 Scintigraphy | 7plus; Discordant with CT (11) | 90% | 89%
| | | | - Concordant with CT (14) or Indeterminant (3)
Burt 1994 94133754 | Mets (5) | Benign lesion (21) | MRI | + T1 and T2 | 100% | 24%
| | | | Mass:opposite adrenal signal intensity ratio > 1 or T2 Mass:Liver ratio > 1 (20)
| | | | - Other (5)
| Mets (5) | Benign lesion (22) | FNA | + Malignant tissue (4) | 100% | 100%
| | | | - Benign tissue (6) | Non-diagnostic (50%)
| | | | Non-diagnostic (10) | Not feasible not included
| | | | Not feasible (7)
Hussain 1986 86247668 | Mets (18) | Benign lesion -- adenoma, hyperplasia, fatty infiltrate (8) | Unenhanced CT | + Heterogeneous density (6) | 33% | 100%
| | | | - Other (20)
| Mets (18) | Benign lesion (8) | Enhanced CT | + Contrast enhancement (8) | 44% | 100%
| | | | - No enhancement (18)
| Mets (18) | Benign lesion (8) | CT | + Size > 3 cm (12) | 66% | 100%
| | | | - Size ≤ 3 cm (14)
Boland 1995 95090097 | Mets (11) | Benign lesion (9) | PET | + Increased uptake (11) | 100% | 100%
| | | | - No uptake (9)
BOTH ADRENAL INCIDENTALOMA AND ADRENAL MASS FOUND DURING EXTRAADRENAL CANCER WORK-UP
Gross 1994 94284860 | Destructive or space-occupying lesion (58) | Adenoma (171) | NP-59 Scintigraphy | + Discordant with CT (41) | 71% | 100%
| | | | - Concordant with CT (189)
Silverman 1993 93268895 | Malignancy (44) | Benign lesion (53) | FNA | + Malignant tissue (39) | 93% | 100%
| | | | - Benign tissue (44) | Non-diagnostic (14%) excluded
| | | | Non-diagnostic (2 cancer, 12 benign))
| Masses < 3 cm (30) | | FNA | As above | “80%” | “Accuracy = 90%”
| Masses ≥ 3 cm (42) | | FNA | As above | “100%” | “Accuracy = 100%”
| Needle gauge 20–22 (58) | | FNA | As above | “91%” | “Accuracy = 95%”
| Needle gauge ≤ 19 (11) | | FNA | As above | “100%” | “Accuracy = 100%”
Bernardino 1985 85069105 | Mets (18) | Normal, adenoma, or hyperplasia (30) | FNA | ND | Overall, after repeat biopsies, 48/53 had accurate diagnoses:
| ND on the final diagosis (2) | Myelolipoma (1) | | | Accuracy: 91%
| ND on final diagosis (2) | Hemorrhage (1)
| | Cyst (1)
Dominguez-Gadea 1994 95043883 | Adrenal carcinoma , mets, lymphoma (18 masses) | Adenoma, myelolipoma, tuberculosis (31 masses) | 75-Se-cholesterol Scintigraphy | + Decreased uptake (20 masses) | 94% | 90%
| Not defined in report. | Not defined in report. | | - Increased or normal uptake (29 masses)
| | | | Not defined in report
| Adrenal carcinoma , mets, lymphoma , tuberculosis (20 masses) | Adenoma, myelolipoma (29 masses) | 75-Se-cholesterol Scintigraphy | + Decreased uptake (20 masses) | 95% | 97%
| Not defined in report. | Not defined in report. | | - Increased or normal uptake (29 masses)
| | | | Not defined in report.
Gross 1995 95331328 | Metastasis (13) | Adenoma (16) | NP-59 Scintigraphy | + Asymmetric or no uptake (21) | 100% | 50%
| | | | - Symmetric uptake (8)
| | | | Not defined in report.
Berkman 1984 84156084 | Malignancy (4) | Adenoma (12) | FNA | + Metastatic tissue (4) | 100% | 100%
| | | | - Benign tissue (11)
| | | | Inconclusive (1 benign by follow-up CT) | Inconclusive (6%) excluded
INCIDENTALLY FOUND ADRENAL ADENOMA
Bardet 1996 96307324 | Unilateral uptake on scintigraphy (16) | Bilateral uptake on scintigraphy (19) | Basal Urinary free cortisol | + > 300 nmol/24 hr (4) | 0% | 79%
| | | | - < 300 nmol/24 hr (31)
| Unilateral uptake on scintigraphy (13) | Bilateral uptake on scintigraphy (13) | Basal DHEAS | + < 0.9 μmol/L men and post-menopausal women; < 0.3 μmol/L pre-menopausal women (10) | 38% | 62%
| | | | - Other (16)
| Unilateral uptake on scintigraphy (14) | Bilateral uptake on scintigraphy (15) | Basal ACTH at 0800 hr | + < 2.2 pmol/L (5) | 29% | 93%
| | | | - > 2.2 pmol/L (24)
| Unilateral uptake on scintigraphy (9) | Bilateral uptake on scintigraphy (6) | Urinary free cortisol on day 2 of low dose -- 2 mg per day for 2 days -- dexamethasone suppression test | + > 55 nmol/24 hr (4) | 33% | 83%
| | | | - < 55 nmol/24 hr (11)
| Unilateral uptake on scintigraphy (6) | Bilateral uptake on scintigraphy (5) | Serum cortisol on day 2 of low dose dexamethasone suppression test | + > 55 nmol/L (4) | 50% | 80%
| | | | - < 55 nmol/L (7)
| Unilateral uptake on scintigraphy (13) | Bilateral uptake on scintigraphy (17) | Serum cortisol at 0800 hr after overnight 1 mg dexamethasone suppression test | + > 100 nmol/L (5) | 31% | 94%
| | | | - < 100 nmol/L (25)
Valli 2001 21172450 | Unilateral uptake on scintigraphy (19) | Bilateral uptake on scintigraphy (12) | Serum cortisol at 0800 hr after overnight 1 mg dexamethasone suppression test | + > 60 nmol/L (23) | 100% | 67%
| | | | - < 60 nmol/L (8)
ADRENAL MASS
Szolar 1997 97167394 | Non-adenoma -- including benign lesions (37 masses) | Adenoma (41 masses) | Unenhanced CT | + Density > 11 HU (53) | 100% | 61%
| | | | - Density < 11 HU (25)
| Non-adenoma (37 masses) | Adenoma (41 masses) | Unenhanced CT | + Density > 18 HU (37) | 92% | 93%
| | | | - Density < 18 HU (41)
| Non-adenoma (37 masses) | Adenoma (41 masses) | Unenhanced CT | + Density > 21 HU (33) | 89% | 100%
| | | | - Density < 21 HU (45)
| Non-adenoma (37 masses) | Adenoma (41 masses) | Unenhanced CT | + Size > 2.5 cm (33) | 84% | 66%
| | | | - Size < 2.5 cm (45)
| Non-adenoma (24 masses) | Adenoma (23 masses) | Delayed enhanced CT (180 sec) | + Density > 64 HU (26) | 100% | 91%
| | | | - Density < 64 HU (21)
| Non-adenoma (24 masses) | Adenoma (23 masses) | Delayed enhanced CT (180 sec) | + Density > 68 HU (23) | 92% | 96%
| | | | - Density < 68 HU (24)
| Non-adenoma (24 masses) | Adenoma (23 masses) | Delayed enhanced CT (180 sec) | + Density > 70 HU (20) | 83% | 100%
| | | | - Density < 70 HU (27)
| Non-adenoma (19 masses) | Adenoma (24 masses) | Delayed enhanced CT (30 min) | + Density > 40 HU (19) | 100% | 95%
| | | | - Density < 40 HU (24)
Lee 1991 91195510 | Malignancy (28 masses) | Benign lesion (38 masses) | Unenhanced CT | + Density > 0 HU (48) | 100% | 47%
| | | | - Density < 0 HU (18)
| | | | + Density > 10 HU (35) | 96% | 79%
| | | | - Density < 10 HU (31)
| | | | Density: | AUC = 0.91±0.04
| | | Unenhanced CT | + Size > 1.5 cm (58)
| | | | - Size < 1.5 cm (8) | 93% | 16%
| | | | + Size > 2.5 cm (28)
| | | | - Size < 2.5 cm (38) | 79% | 84%
| | | | Size: | AUC = 0.84±0.05
| | | Unenhanced CT | Best observer interpretation: | AUC = 0.84±0.05
Korobkin 1996 96347844 | Metastasis (10 masses) | Adenoma (41 masses) | Enhanced CT | + Density > 38 HU (36)
| | | | - Densitiy < 38 HU (15) | 100% | 37%
| | | | Enhanced CT: | AUC = 0.78±0.09
| | | Delayed enhanced CT (45-75 min) | + Density > 30 HU (12)
| | | | - Density < 30 HU (39) | 100% | 95%
| | | | Delayed enhanced: | AUC = 0.99±0.01
| | | CT size | Size: | AUC = 0.72±0.09
Van Erkel 1994 94246003 | Non-adenoma (19, 20 masses): | Adenoma (18, 24 masses) | Unenhanced CT | + Density >16.5 HU (19) | 95% | 100%
| Adrenal cancer (8 masses), pheo (4),metastasis (2), cyst (2), TB (2),Neuroblastoma (1), Hemorrhage (1) | | | - Density < 16.5 HU (24)
| | | | Density: | AUC = 0.9935
| | | | + Size > 3.1 cm (21) | 85% | 83%
| | | | - Size < 3.1 cm (23)
| | | | Size: | AUC = 0.8956
| | | MRI | + T2 Mass:Fat signal intensity ratio > 0.85 (20) | 85% | 88%
| | | | - Ratio < 0.85 (24)
| | | | T2 Mass:Fat | AUC = 0.8602
| | | | + T2 Mass:Muscle ratio > 2.7 (25) | 90% | 71%
| | | | - Ratio < 2.7 (19)
| | | | T2 Mass:Muscle: | AUC = 0.8573
| | | | + T2 Mass: Liver ratio > 1.75 (19) | 65% | 75%
| | | | - Ratio < 1.75 (25)
| | | | T2 Mass: Liver: | AUC = 0.6685
Chezmar 1988 88098154 | Metastasis (12 masses) | Adenoma, neuroblastoma, pheochromocytoma (23 masses) | MRI | + T1 Mass:Liver signal intensity ratio < 0.78 (20 masses) | 100% | 65%
| | | | - Ratio 0.78 (15 masses)
| Metastasis (12 masses) | Adenoma, neuroblastoma, pheochromocytoma (23 masses) | MRI | + T1 Mass:Liver ratio 0.71 (9 masses) | 75% | 100%
| | | | - Ratio > 0.71 (15 masses)
| Mets (12 masses) | Adenoma, neuroblastoma (23 masses) | MRI | + T1 Mass:Fat ratio < 0.42 (21 masses) | 100% | 57%
| | | | - Ratio ≥ 0.42 (12 masses)
| Mets (12 masses) | Adenoma, neuroblastoma (23 masses) | MRI | + T1 Mass:Fat ratio ≤ 0.35 (10 masses) | 75%
| | | | - Ratio > 0.35 (23 masses)
| Mets (8 masses) | Adenoma (9 masses) | MRI | + T2 Mass:Fat ratio > 0.63 (11 masses) | 100%
| | | | - Ratio < 0.63 (6 masses)
| Mets (8 masses) | Adenoma (9 masses) | MRI | + T2 Mass:Fat ratio > 0.75 (5 masses) | 50% | 89%
| | | | - Ratio < 0.75 (12 masses)
Singer 1994 94298222 | Mets (12 masses) | Adenoma (12 masses) | Enhanced CT | + Density > 10 HU (8 masses) | 92% | 58%
| | | | - Density < 10 HU (17 masses)
| | | | + Density > 0 HU (4 masses) | 100% | 33%
| | | | - Density < 0 HU (20 masses)
| | | | Density: | AUC = 0.83±0.10
| | | | + Size > 2.5 cm (7 masses) | 100% | 58%
| | | | - Size < 2.5 cm (17 masses)
| | | | Size: | AUC = 0.78±0.09
Heaston 1982 82208978 | Mets (9), Adrenal cancer (2) | Adenoma (2), Infection (1) | FNA | + Malignant (10) | 100% | 100%
| | | | - Benign (3)
| | | | Inconclusive (1 presumed lung cancer mets) | Inconclusive (7%) excluded
COMBINED INCIDENTALOMA, ADRENAL MASS FOUND DURING CANCER WORK-UP, AND CLINICALLY-SUSPECTED ADRENAL MASSES
Bilbey 1995 95168077 | Non-adenoma -- including benign lesions (22 masses) | Adenoma (19 masses) | MRI | + T1 Mass:Liver signal intensity ratio > 0.60 (24 masses) | 100%
| | | | - Ratio ≤ 0.60 (17 masses)
| Non-adenoma (22 masses) | Adenoma (19 masses) | MRI | + T1 Mass:Muscle ratio > 0.58 (24 masses) | 100%
| | | | - Ratio < 0.58 (17 masses)
| Non-adenoma (22 masses) | Adenoma (19 masses) | MRI | + T1 Mass:Spleen ratio 0.80 (22 masses) | 100% | 100%
| | | | - Ratio < 0.80 (19 masses)
Karstrup 1991 92054304 | Mets (18), Adrenal cancer (1) | Adenoma (3), Hematoma (3), Pheochromocytoma (1), Infection (1), Pseudocyst (1) | FNA | + Malignant (18) | 94% | 83%
| | | | - Benign (6)
| | | | Inconclusive (1 adrenal cancer, 3 benign adrenal neoplasm) | Inconclusive (14%) excluded
Montali 1984 85019801 | Metastasis (11), Adrenal cancer (4) | Adenoma (2), Pheochromocytoma (1) | FNA | + Malignant (14) | 100% | 100%
| | | | - Benign (4)
| | | | Inconclusive (1 adrenal cancer) | Inconclusive (6%) excluded
COMBINED ADRENAL MASS FOUND DURING CANCER WORK-UP AND CLINICALLY-SUSPECTED ADRENAL MASSES
Katz 1984 84226856 | Adrenal cancer, neuroblastoma, mets (13) | Benign lesion (9) | FNA | + Malignant tissue (11) | 85% | 100%
| | | | - Benign tissue (9)
| | | | Non-diagnostic (2 benign) | Non-diagnostic (9%) excluded

Evidence Table 3. Risk of complications from fine needle aspiration biopsy of the adrenal gland - Part I

Study, Year Identifier | Demographics | Inclusion criteria | Exclusion criteria | Study design, Enrollment period | Biopsy Procedures
Heaston 1982 | Country: US | Adrenal biopsy | None reported | Prospective cohort | CT-guided (13/14)
82202978 | Age range: 55–73y | | | Jan 1980 - Jul 1981 | Fluoroscopy-guided (1/14)
| Enrolled: 14 | | | | Prone posterior approach (11/14)
| Evaluated: 14 (14 biopsies) | | | | Transperitoneal (1/14)
| % Male ND | | | | Supine (2/14)
| | | | | 20, 21 or 22 gauge needles (14/14)
| | | | | 2 patients had subsequent biopsies through a retained catheter
Montali 1984 | Country: Italy | Solid, unilateral adrenal masses detected with sonography (15) or CT (3); Cushing syndrome (2), palpable flank mass (2) | None reported | Prospective cohort | US-guided (18/18)
85019802 | Mean age: ND | | | Jun 1980 - Dec 1983 | Right adrenal (13/18) Lateral or anterior approach
| Enrolled: 18 | | | | Left adrenal (5/18) Posterior, lateral or anterior approach
| Evaluated: 18 (18 biopsies) | | | | 22 gauge needles (18/18)
| % Male ND
Karstrup 1991 | Country: Denmark | Adrenal mass (cancer work-up, incidentaloma, Cushing's disease) | None reported | Retrospective case series | US-guided (28/28)
92054304 | Median age: 56y | | | 1984 - 1990 | Right adrenal (16–19/28 ^b^) Lateral or anterior approach
| Enrolled: 28 | | | | Left adrenal (9–12/28 ^b^) Lateral approach
| Evaluated: 28 (28 biopsies) | | | | ND on needle size
| 57% Male
Mody 1995 | Country: USA | Imaging guided percutaneous biopsies of adrenal masses | Images no longer available for review | Retrospective case series | CT-guided (79/83 biopsies)
95310560 | Mean age: 61y | | | Nov 1985 - Sep 1993 | US (4/83 biopsies)
| Enrolled: ~91 | | | | Right adrenal (38/83 biopsies)
| Evaluated: 78 (83 biopsies) | | | | Left adrenal (45/83 biopsies)
| 60% Male | | | | Posterior approach (37/83 biopsies)
| | | | | Transhepatic approach (33/83 biopsies), 4 traversed pancreas
| | | | | Transpancreatic approach, left adrenal (9/83 biopsies)
| | | | | Anterior approach (2/83 biopsies)
| | | | | Transsplenic approach (1/83 biopsies)
| | | | | Lateral approach (1/83 biopsies)
| | | | | 22 gauge needle only (42/83 biopsies)
| | | | | 18–21 gauge needle (16/83 biopsies)
| | | | | ND on needle size (25/83 biopsies)
Schwartz 1997 | Country: USA | New diagnosis of extraadrenal cancer | None reported | Retrospective case series | CT guided percutaneous (54/54)
97312288 | Mean age: 65y | Adrenal mass >1 cm on CT | | Nov 1993 - Nov 1995 | 22 gauge needles (54/54)
| Enrolled: 54 | | | | ND on side or approach
| Evaluated: 54 (54 biopsies)
| 61% Male
Kane 1991 | Country: USA | CT-directed percutaneous aspiration biopsies of left adrenal masses | None reported | Retrospective case series | CT-guided (48/48 biopsies)
91368671 | Mean age: ND | | | 1984 - 1989 | Left adrenal (48/48 biopsies)
| Enrolled: 47 | | | | Anterior approach (33/48 biopsies)
| Evaluated: 47 (48 biopsies) | | | | Posterior approach (15/48 biopsies)
| % Male: ND | | | | 22 gauge (20/48 biopsies)
| | | | | 21 gauge (1/48 biopsies)
| | | | | 20 gauge (1/48 biopsies)
| | | | | 20 and 22 gauge (4/48 biopsies)
| | | | | Chiba and spinal needles (47/48 biopsies)
| | | | | 20 gauge Franseen needle (1/48 biopsies)
| | | | | ND on needle size (22/48 biopsies)
Katz 1984 | Country: USA | Symptomatic or incidental adrenal mass | None reported | Retrospective case series | Fluorosocopy-, CT-, or US-guided (22/22)
84226856 | Age range: 1–82y | Histologically confirmed lesion or good clinical and radiologic follow-up for ≥ 2 y | | 1976 - 1979 | ND on side or approach used
| Enrolled: 22 | | | | 18 to 22 gauge needles (21/22)
| Evaluated: 22 (22 biopsies) | | | | Cutting-type needles (10/22)
| 41% Male
Welch 1994 | Country: USA | Adrenal biopsy | Follow up data could not be obtained | Retrospective chart review, longitudinal follow-up at least 1 y | CT-guided (271/277 biopsies)
95062966 | Age range: 31–84y | Follow-up for ≥ 1 y or until death | | 1981 - 1991 | US-guided (6/277 biopsies)
| Enrolled: 270 | | | | Single needle biopsy (192/277 biopsies)
| Evaluated: 270 (277 biopsies) | | | | Coaxial technique (82/277 biopsies)
| 63% Male | | | | Unknown technique (3/277 biopsies)
| | | | | Right adrenal (120/277 biopsies)
| | | | | Transhepatic approach right side (75/120)
| | | | | Direct posterior (37/120)
| | | | | Decubitus right side down (6/120)
| | | | | Pancreatic approach (1/120)
| | | | | Transperitoneal (1/120)
| | | | | Left adrenal (157/277 biopsies)
| | | | | Direct posterior (79/157)
| | | | | Decubitus left side down (55/157)
| | | | | Anterior approach (17/157)
| | | | | Transgastric or lateral (6/157)
| | | | | 16 gauge needles (22/277 biopsies)
| | | | | 17 gauge needles (3/277 biopsies)
| | | | | 18 gauge needles (99/277 biopsies)
| | | | | 19 gauge needles (92/277 biopsies)
| | | | | 20 gauge needles (6/277 biopsies)
| | | | | 21 gauge needles (37/277 biopsies)
| | | | | 22 gauge needles (9/277 biopsies)
| | | | | Unknown needle size (9/277 biopsies)
| | | | | Cutting needle (ND)
| | | | | Biopsy gun (ND)
Bernardino 1985 | Country: USA | Adrenal mass found during oncologic work-up or adrenal mass found serendipitously | None reported | Retrospective case series | CT-guided (58/58 biopsies)
85069105 | Mean age: ND | | | 3½ y enrollment period | Right adrenal (26/53 patients)
| Enrolled: 53 | | | | Transhepatic approach (23/26)
| Evaluated: 53 (58 biopsies) | | | | Posterior approach (3/26)
| 55% Male | | | | Left adrenal (27/53 patients)
| | | | | Posterior approach (21/27)
| | | | | Anterior through hepatic lobe(6/27)
| | | | | 19 or 20 gauge Chiba needles(48/58 biopsies)
| | | | | 18 gauge Chiba needles (6/58)
| | | | | 21 gauge Chiba needle (1/58)
| | | | | 22 gauge Chiba needle (1/58
| | | | | Menghini needle (1/58)
| | | | | Jamshidi needle (1/58)
de Agustin 1999 | Country: Spain | FNA biopsies of adrenal glands | Incomplete clinical information | Retrospective case series | CT-guided (169/169)
99353916 | Mean age: 59y | | | Jan 1988 - Dec 1997 | 22 gauge needles (169/169)
| Enrolled: 177 | | | | ND on side or approach
| Evaluated: 169 (169 biopsies)
| 86% Male
Berkman 1984 | Country: USA | Adrenal mass found in work-up for known or suspected extraadrenal cancer or adrenal mass found incidentally or adrenal mass suspected for a possibly functional mass | None reported | Prospective cohort (unclear) | CT-guided (16/16)
84156084 | Age range: 31–70y | | | Enrollment period: ND | Left adrenal prone position (ND)
| Enrolled: 16 | | | | Right adrenal transhepatic approach, supine (ND)
| Evaluated: 16 (16 biopsies) | | | | 22 gauge needles (2/16)
| 56% Male | | | | 18–20 gauge Chiba needles (14/16)
Silverman 1993 | Country: USA | Adrenal mass found during extraadrenal cancer staging, or incidental adrenal mass, no known malignancy | Insufficient tissue | Retrospective case series | CT-guided (86/101 biopsies)
93268895 | Mean age: ND | | | Enrollment period: 9y | US-guided (15101 biopsies)
| Enrolled: 97 | | | | 20–22 gauge needles (80/101 biopsies)
| Evaluated: 97 (101 biopsies) | | | | ≥ 19 gauge needles (16/101 biopsies)
| % Male: ND | | | | ND on needle size (5/101 biopsies)
| | | | | ND on side or approach

Evidence Table 3. Risk of complications from fine needle aspiration biopsy of the adrenal gland - Part II

Study, Year Identifier | Tumor size Mean (range) | Number of passes used | Final diagnoses (# of patients)
Heaston 1982 | ND (1.5–10) cm | 1 or 2 passes per patient with either single or tandem needles; in 2 patients, an additional pass was made through a catheter, at a different angle | 1° tumors:
82202978 | | | nonfunctioning adenoma (2)
| | | adrenal cortical carcinoma (2)
| | | 2° tumors:
| | | lung (6)
| | | kidney (1)
| | | melanoma (1)
| | | unknown (1)
| | | Non-neoplastic diseases:
| | | blastomycosis (1)
Montali 1984 | ND (2.5–10 cm) | 2 passes per mass | 1° tumors:
85019802 | | | adrenal carcinoma (4)
| | | adenoma (2)
| | | pheochromocytoma (1)
| | | 2° tumors:
| | | lung (6)
| | | hepatoma (1)
| | | hypernephroma (1)
| | | endometrium (1)
| | | sarcoma (2)
Karstrup 1991 | 5 (2–18) cm | ND | 1° tumors:
92054304 | | | cortical adenoma (3)
| | | cortical carcinoma (1)
| | | pheochromocytoma (1)
| | | 2° tumors :
| | | lung (13)
| | | non-Hodgkin's lymphoma (1)
| | | breast carcinoma (1)
| | | renal carcinoma (1)
| | | bladder carcinoma (1)
| | | chorioncarcinoma (1)
| | | Non-neoplastic diseases:
| | | hematoma (3)
| | | infection (1)
| | | pseudocyst (1)
Mody 1995 | 3.5 (ND) cm | 1 to 7 passes for 60 masses; 3 passes in 53 masses | Benign FNA (47/83 biopsies)
95310560 | | | Malignant FNA (31/83 biopsies)
| | | Non-diagnostic FNA (5/83 biopsies)
Schwartz 1997 | Benign: | Additional passes until an adequate specimen was obtained | Benign lesions:
97312288 | 1.8 (1.0 – 4.1) cm | | adenoma (31)
| Malignant: | | 2° tumors:
| 4.2 (1.1 – 7.4) cm | | lung (17)
| | | sarcoma (2)
| | | bladder (1)
| | | prostate (1)
| | | esophagus (1)
| | | contralateral adrenal (1)
Kane 1991 | ND | ND | ND
91368671
Katz 1984 | ND | ND | Benign lesions:
84226856 | | | adrenal cyst (5)
| | | adenoma (2)
| | | nodular hyperplasia (1)
| | | adrenal myelolipoma (1)
| | | Malignant lesions:
| | | adrenal cancer (4)
| | | neuroblastoma (2)
| | | mets (7)
Welch 1994 | 3.8 (1–12) cm | ND | 1° tumors:
95062966 | | | adrenal (5)
| | | 2° tumors:
| | | lung (147)
| | | breast (18)
| | | melanoma (14)
| | | lymphoma (11)
| | | colon (7)
| | | unknown malignant (40)
| | | Other -- including metastases, adrenal infection, and hematoma (35)
Bernardino 1985 | ND (1.5–9 cm) | 3 excursions per needle placement | Benign
85069105 | | 2–3 needle placements per biopsy | normal adrenal/adenoma/hyperplasia (27)
| | | myelolipoma (1)
| | | adrenal hemorrhage (1)
| | | cyst (1)
| | | Metastases (18)
| | | ND (5)
de Agustin 1999 | ND | ND | 1° adrenal tumor (22):
99353916 | | | neuroblastomas (≥5, text unclear)
| | | pheochromocytoma (>1, text unclear)
| | | 2° tumor:
| | | lung (26)
| | | NSCLC (19)
| | | small cell (7)
| | | hepatocellular (2)
| | | colorectal (2)
| | | melanoma (2)
| | | multiple myleoma (2)
| | | unknown 1° (16)
| | | other (6)
| | | ND (91)
Berkman 1984 | (1.7–5 cm) | 2–3 passes made in each patient from different sites with the mass | Benign:
84156084 | | | adenoma (7)
| | | adrenal cyst (1)
| | | hemorrhage (2)
| | | adrenal hyperplasia (1)
| | | Metastases:
| | | melanoma (1)
| | | other metastases (3)
| | | Insufficient tissue for diagnosis, no change on follow-up (1)
Silverman 1993 | ND (1–12) cm | ND | Proven benign (39)
93268895 | | | Managed as benign (14)
| | | Malignant (44)

Evidence Table 3. Risk of complications from fine needle aspiration biopsy of the adrenal gland - Part III

Study, Year Identifier | Complications | Treatment decisions | Comments
Heaston 1982 | No major complications (0/14) | Surgery for primary mass-
82202978 | No significant hemorrhage | benign (1)
| No pneumothorax | malignant (2)
Montali 1984 | No complications (0/18) | 6 of 7 1° tumors were excised
85019802
Karstrup 1991 | No complications (0/28) | ND | 16 masses were right-sided, 9 were left-sided, 3 bilateral. No data on which side was biopsied in patients with bilateral masses.
92054304
Mody 1995 | Total complications (7/83 biopsies) | 3 admissions - | 80 masses, including biopsies in 2 patients with bilateral masses and 3 with repeated biopsies in same mass - total 83 biopsies; 42 procedures with 22 gauge needles
95310560 | Pneumothorax (2/83) | pain
| Pain (2/83) | pneumothorax
| Hematoma (2/83) | subcapsular & hepatic hematoma (transfused)
| Needle tract mets, lung cancer (1/83)
| Posterior approach
| Right, 22 gauge, 3 passes (1 pneumothorax)
| Left, 22 gauge, 4–5 passes (1 pneumothorax; 1 hematoma)
| Transhepatic approach
| Right , 22 gauge, 4–7 passes (1 pain; 1 hematoma)
| Right , 22/19 gauge, coaxial, 2 passes (1 mets)
| Transhepatic & transpancreatic approach
| Left, unknown needle or passes, (1 severe pain)
Schwartz 1997 | Total complications (2/54) | ND
97312288 | 22 gauge needle (2 pneumothorax)
Kane 1991 | Total complications (2/33) | ND
91368671 | Acute pancreatitis (2/33)
| 1 with 20 & 22 gauge needles
| (2 & 1 passes, respectively)
| 1 with 20 gauge needle
| (6 passes)
| Anterior approach (left adrenal) (2/33)
| Posterior approach (left adrenal) (0/15)
Katz 1984 | Total complications (1/22)
84226856 | Pneumothorax (1/22)
Welch 1994 | Total complications (8/277 biopsies) | ND | No significant difference between large or small needles. Rate did not vary according to size of lesion or to how early or late biopsy was done.
95062966 | Adrenal bleed (7/277)
| 1 required adrenalectomy
| Perirenal hematoma (1/277)
| Death (0/277)
| Pneumothorax (0/277)
| Pancreatitis (0/277)
| Sepsis (0/277)
| Needle track seeding (0/277)
| Right adrenal (3/120 biopsies)
| Posterior approach (2/37 biopsies)
| Transhepatic approach (1/75 biopsies)
| Other approach (0/8 biopsies)
| Left adrenal (5/157 biopsies)
| Decubitus approach (3/55 biopsies)
| Anterior transhepatic (1/17 biopsies)
| Direct lateral (1/6 biopsies)
| Direct posterior (0/79 biopsies)
| 16 gauge needle (2/22 biopsies)
| 17 gauge needle (0/3 biopsies)
| 18 gauge needle (2/99 biopsies)
| 19 gauge needle (2/92 biopsies)
| 20 gauge needle (0/6 biopsies)
| 21 gauge needle (2/37 biopsies)
| 22 gauge needle (0/9 biopsies)
Bernardino 1985 | Total complications (7/58 biopsies) | Among 18 patients with histology consistent with metastases, 11 were treated on the basis of biopsy results; 3 had confirmation by clinical follow-up; 2 had confirmation by CT, and 2 had confirmation by surgery
85069105 | Hematocrit drop (5/58)
| Transient bacteremia (1/58)
| Hypotension (1/58)
| Pneumothorax (0/58)
| 1 patient had 2 complications
| 18 gauge needle (1/6 biopsies)
| 19 gauge needle (1) and 20 gauge needle (4) (5/48 biopsies)
| Right adrenal (4/26 patients)
| Left adrenal (2/27 patients)
de Agustin 1999 | No serious complications (0/169) | ND
99353916
Berkman 1984 | No complications (0/15) | ND
84156084
Silverman 1993 | Total complications (9/101 biopsies) | Benign FNA (44): surgical confirmation (7, 3 were malignant), CT follow-up (16), clinical follow-up (8), no follow-up (11), ND (2 myelolipomas)
93268895 | Abdominal discomfort (2/101 biopsies) | Malignant FNA (39): ND (no surgical confirmation)
| Nausea (1/101 biopsies) | Nondiagnostic FNA (14 patients, 18 biopsies): CT follow-up (4), clinical follow-up (3), adrenalectomy (1), autopsy (1 malignant), no follow-up (3), ND (2)
| Mild hematuria (1/101 biopsies)
| Hypotension & bradycardia, asymptomatic (2/101 biopsies)
| Pneumothorax (2/101 biopsies)
| Hemothorax (1/101 biopsies)

Evidence Table 4. Cohort/series of surgical complications of open transperitoneal adrenalectomy

Study, Year Identifier | Demographics | | Inclusion Criteria | Exclusion Criteria | | Study design, Enrollment yrs | Procedure/approach
Malmaeus 1986 | Country: Sweden | | ND | ND | | Consecutive 1976-1984 | Anterior with excision extended to thorax in 2
87123123 | Setting: Academic
| Mean age: 47 y
| Enrolled: 55
| Evaluated: 55
| 64% Male
Study, Year Identifier | Co-morbidities | Mean tumor size (cm) | Pre-operative diagnoses, ASA classification | Pathology | | Operative time (min), Blood loss (ml) (mean) | Complications
Malmaeus 1986 | ND | 4.7^a^ | ND | Primary alosteronism | 14 | ND | Bleeding requiring reoperation | 2
87123123 | | (0.7–8) | | Cushing's syndrome | 13 | | Splenic capsule damage and splenectomy | 3
| | | | Catecholamine excess | 21 | | Wound infection | 2
| | | | Non-functioning tumors | 7 | | Pneumonia | 4
| | | | | | | Subphrenic abscess | 1
Study, Year Identifier | Postoperative analgesia | | Days hospitalized (mean), Days to recovery (how defined) | Mortality | | Comments, Biases or limitations
Malmaeus 1986 | ND | | ND | None | | 58 operations - 3 patients operated twice
87123123

a 37 cases

Evidence Table 5. Cohort/series of surgical complications of open retroperitoneal adrenalectomy - Part I

Study, Year Identifier | Demographics | Inclusion Criteria | Exclusion Criteria | Study design, Enrollment yrs | Procedure/approach
Favia 1992 | Country: Italy | Diagnosis of primary aldosteronism due to adenoma | ND | Unknown 1975 - 1989 | Open/extraperitoneal flank | 48
93033524 | Setting: Academic | | | | Transperitoneal anterior | 4
| Mean age: 42.5 y
| Enrolled: 52
| Evaluated: 52
| 31% Male
| Race:
Proye 1993 | Country: France | ND (Patients deemed suitable for the posterior approach). | ND | 1970-1992 | Posterior
94078258 | Setting: Academic
| Mean age: ND
| Enrolled: 105
| Evaluated: 105
| % Male ND
| Race: ND
Weigel 1994 | Country: US | Evaluated for hyperaldosteronism and operated on or followed at Duke. | Operation for any other reason. No followup at Duke after 1970 (if operated on before 1970) | Retrospective cohort, 1970-1993 (includes patients operated on before 1970 but followed at Duke after 1970). | Posterior/ Chevron
94213545 | Setting: Academic
| Mean age: 44 y
| Enrolled: 40
| Evaluated: 40
| 50% Male
| Race: 83% white 17% black
Fahey 1994 | Country: Australia | All patients undergoing adrenalectomy in the Endocrine Surgical Unit | Adrenalectomies which were part of other procedures | Retrospective cohort 1986-1992 | Posterolateral
94280362 | Setting: Academic
| Mean age: 51 y
| Enrolled: 51
| Evaluated: 51
| 32% Male
| Race: ND
Van Heerden 1995 | Country: US | Adrenal resection for endogenous hypercortisolism | ND | ND, 1981-1991 | 80% Posterior
95232725 | Setting: Academic | | | | 20% Anterior
| Mean age: 45 y
| Enrolled: 91
| Evaluated: 91
| 19% Male
| Race: ND
Nash 1995 | Country: US | Consecutive cases of adrenalectomy for hyperaldosteronism by a single surgeon using the dorsal approach | ND | Retrospective chart review 1984-1994 | Retroperitoneal (posterior)
96008379 | Setting: Academic
| Mean age: 46(25–72) y
| Enrolled: 40
| Evaluated: 40
| 48% Male
| Race: ND
Sand 1997 | Country: Finland | Adrenalectomy by posterior approach | ND | Case series 1983-1993 | Open Posterior
98048258 | Setting: Academic
| Mean age: 46 (16–75) y
| Enrolled: 59
| Evaluated: 59
| 36% Male
| Race: ND
Kolomecki 1999 | Country: Poland | Incidentaloma | | Case series 1977-1998 | Lateral extraperitoneal
99394313 | Setting: Academic
| Mean age: 43 y
| Enrolled: 32
| Evaluated: 32
| 13% Male
| Race: ND

Evidence Table 5. Cohort/series of surgical complications of open retroperitoneal adrenalectomy - Part II

Study, Year Identifier | Co-morbidities | Mean tumor size (cm) | Pre-operative diagnoses, ASA classification | | Pathology | | Operative time (min), Blood loss (ml) (mean) | Complications
Favia 1992 | ND | ND | Primary aldosteronism | | Single adenoma | 43 | ND | Iatrogenic lesion of vena cava | 1
93033524 | | | | | Unilateral multiple Adenoma | 4 | | Incisional hernia | 3
| | | | | Unilateral macronodular hyperpiasia | 2
| | | | | Unilateral micronodular hyperplasia | 1
| | | | | Adenoma & contralateral hyperplasia | 1
| | | | | Bilateral hyperplasia | 1
Proye 1993 | ND | 3.8 (0.5–9.6) | Conn's Disease | 48 | ND | | 132 (45–260). | [underlined: Peri-op]
94078258 | | | Cushing's disease | 19 | | | ND | Minimal Caval tear | 1
| | | Cushing's syndrome | 18 | | | | Bleeding + transfusion | 6
| | | Virilizing Tumor | 2 | | | Operative time is skin-to-skin | Pleural tear | 13
| | | Non-secreting Tumor | 13 | | | | (2 required pleural drains)
| | | Metastases | 3
| | | Cyst | 2 | | | | [underlined: Post-op]
| | | | | | | | Sepsis (died) | 1
| | | | | | | | DVT | 3
| | | | | | | | Retroperitoneal hematoma (without reoperation) | 1
| | | | | | | | Phlebitis | 1
| | | | | | | | UTI | 1
| | | | | | | | Bleeding duodenal ulcer | 1
Weigel 1994 | ND | 1.48 | Hyperaldosteronism (40) | | Adenoma | 35 | ND | Posterior incision (21 patients):
94213545 | | | | | Hyperplasia | 3
| | | | | Adrenal | 1 | | Fever >48 hours | 1
| | | | | Cortical CA | 1 | | Chevron (17 patients):
| | | | | Normal | | | Aspiration | 1
| | | | | | | | UTI | 1
| | | | | | | | Wound infection | 1
Fahey 1994 | ND | ND | Pheo | 16 | Adenoma | 24 | Posterolateral 84 min | Intraop:
94280362 | | | Cushing's syndrome | 6 | Carcinoma | 4 | | Incidental splenectomy | 1
| | | Cushing's disease | 4 | Nodular hyperplasia | | All approaches 95 min
| | | Conn's syndrome | 11 | | 3 | | Post-op:
| | | Virilizing adenom | 2 | Diffuse hyperplasia | | | MI (patient died) | 1
| | | Adrenocortical CA | 3 | | 5 | | Bleeding | 2
| | | Symptomatic retroperitoneal mass | | Pheo | 9 | | Requiring transfusion | 1
| | | | 4 | Medullary hyperplasia | | | Pneumonia | 1
| | | Incidental finding | 5 | | 1 | | Wound infection | 1
| | | | | Extraadrenal paraganglioma | 1 | | UTI | 1
| | | | | Metastases | 2 | | Prolonged lleus | 1
| | | | | Neuroblastoma | 1
| | | | | Gastric Leiomyoma | 1
Van Heerden 1995 | ND | 4.3 | Cushing's Synd | 46 | Adrenal adenoma | | ND, ND | Wound infection | 2
95232725 | | | Cushing's Dis | 24 | | 34 | | Subphrenic abscess | 1
| | | Ectopic ACTH | 21 | Adrenocortical CA | 4
| | | | | Bilateral nodular hyperplasia | 9
Nash 1995 | ND | 1.8 (0.7–2.5) | Hyperaldosteronism | | Solitary adenoma | | 200 (130–355) min | No intraop complications Post-op
96008379 | | | | | | | 232 (30–600) | Urinary retention | 2
| | | | | | | cc | UTI | 1
| | | | | | | No transfusions | Prolonged ileus | 1
| | | | | | | | Prolonged nausea | 1
| | | | | | | | Wound infection | 1
Sand 1997 | ND | 2.5 median (1–7) | Pheo | 7 | Adenoma | 37 | OT ND | 19%
98048258 | | | Cushing's syndrome | 6 | Carcinoma | 1 | BL 237 (30–4500) | Wound infection | 8
| | | Cushing's disease | 8 | Diffuse hyperplasia | | | Pneumonia | 2
| | | Conn's syndrome | 33 | | 12 | | UTI | 1
| | | Virilizing adenoma | 1 | Pheo | 7 | | Post-op bleeding (required re-op in all 3) | 3
| | | Incidental finding | 4 | Mets | 1
| | | | | Cyst | 1 | | Wound hernia needing re-operation | 1
| | | | | | | | Cosmetically unsatisfactory scar formation | 1
Kolomecki 1999 | ND | (1.5–14.0) | Incidentaloma | 20 | Cortical CA | 4 | 90 min | 1/32 = 3.2%
99394313 | | | Pheo | 9 | Pheo | 13 | | Wound suppuration | 1
| | | Cushing's synd | 2 | Cortical | | BL ND
| | | Conn's | 1 | Hyperplasia | 4
| | | | | Cortical adenoma | 4
| | | | | Schwannoma | 1
| | | | | CA clarocellulare | 1
| | | | | Hamartoma | 1
| | | | | Immunocytoma | 1
| | | | | Myolipoma | 1

Evidence Table 5: Cohort/series of surgical complications of open retroperitoneal adrenalectomy - Part III

Study, Year Identifier | Postoperative analgesia | Days hospitalized (mean), Days to recovery (how defined) | Mortality | Comments, Biases or limitations
Favia 1992 93033524 | ND | ND | None | Data from 4 cases of transperitoneal anterior surgery not given separately
93033524
Proye 1993 | ND | 7.6 (1–21), | 1/105 | During the last 3 years of the study, post-op stay dropped to 4.5 days on average. All transfusions took place before 1973.
94078258 | | 1.5 days until walking
Weigel 1994 | ND | 6 (Posterior approach) | 1/40 | Only death caused by gastroduodenal artery aneurysm rupture 5 days post-op. Authors do not believe death was related to surgery.
94213545 | | 10 (Chevron approach)
Fahey 1994 | ND | ND | 1/51 | Operative time is total OR time, not skin-to-skin.
94280362 | | | | Patient who died had severe CAD and was deemed very high risk.
Van Heerden 1995 | ND | 6 (Posterior) | 2/91 | Deaths occurred after discharge, but within 30 days and did not seem related to surgery.
95232725 | | 8–11 (Anterior)
Nash 1995 | Pt controlled analgesia 5.4 mg/kg intrathecal narcotic. Not named. | 4.3 (2–11) | None | Analgesia not specified. Not all patients received intrathecal patient controlled. Not clear what others received.
96008379 | | Ambulation 2.2 days
| | Normal diet 2.5 days
Sand 1997 | Days of narcotics | 8 (5–21) Median | None
98048258 | 2 (0–7) median
Kolomecki 1999 | ND | 7 | None | High level of malignancies in incidentaloma. Tumor size not reported. No information on how decision was made to operate. 12/32 were not really incidentalomas since they were identified to be hormonally active prior to surgery.
99394313

Evidence Table 6. Surgical complications of comparative open adrenalectomy techniques- Part I

Study, Year Identifier | Demographics | Inclusion Criteria | Exclusion Criteria | Study design, Enrollment yrs | Procedure/approach
Russell 1982 82281913 | Country: US | Bilateral cortical hyperplasia or unilateral cortical adenoma < 25 g, no concomitant additional abdominal surgery planned | ND | Retrospective, 1970-1979 | Grp1: Open/anterior transperitoneal (64) bilateral (30)
| Setting: Academic | | | | Grp2: Open/posterior retroperitoneal (39) bilateral (13)
| Mean age: ND
| Enrolled: 103
| Evaluated: 103
| % Male ND
Bruining 1984 84172630 | Country: Netherlands | Patients with benign or malignant growths of adrenal gland | ND | Retrospective, 1968-1982 | Laparotomy (32)
| Setting: Academic | | | | Lumbotomy L (18)
| Mean age: ND | | | | Lumbotomy R (8)
| Enrolled: 90 | | | | Lumbotomy L&R (5)
| Evaluated: 90 | | | | Thoracolumbotomy L (14)
| % Male ND | | | | Thoracolumbotomy R (11)
| | | | | Dorsal L (2)
| | | | | Dorsal R (4)
| | | | | Dorsal L&R (6)
Irvin III 1989 89272298 | Country: US | ND | ND | Consecutive, 1974-1998 | Grp1: open/anterior, intraperitoneal or transabdominal (17)
| Setting: Academic | | | | Grp2: open/lateral, retroperitoneal (20)
| Mean age: 45 y
| Enrolled: 37
| Evaluated: 37
| 41% Male
| Race: White 24
| Black 13
Nagesser 2000 20229356 | Country: Netherlands | All patients undergoing adrenal surgery at Leiden University Hospital | Patients undergoing exploration only or operation for local recurrence of malignancy | Retrospective case review of consecutive cases. 1947-1995 | Grp1: Transperitoneal open 59 (18%)
| Setting: Academic | | | | Grp 2: Retroperitoneal open 267 (82%)
| Mean age:
| Grp1 41.8 y
| p=0.046
| Grp2 37.9 y
| Enrolled: 284 (326)
| Evaluated: 284 (326)
| Grp1 29% Male
| Grp2 29% Male
| Race: ND

Evidence Table 6. Surgical complications of comparative open adrenalectomy techniques - Part II

Study, Year Identifier | Co-morbidities | Mean tumor size (cm) | Pre-operative diagnoses, ASA classification | | Pathology | | | Operative time (min), Blood loss (ml) (mean) | | | Complications
Russell 1982 82281913 (subset of Hamberger 1982) | ND | ND | ND | | Cushing's disease^a^ | 43 | | | Grp | | [underlined: Grp1]
| | | | | Cortical adenoma | 60 | | | [underlined: 1] | [underlined: 2] | Major bleeding | 8
| | | | | | | | [underlined: OT^b^] | | | Thromboembolism | 1
| | | | | | | | Unilateral | 95 | 85 | Hermorrhage & reoperation | 1
| | | | | | | | Bilateral | 135 | 148 | Sepsis^a^ | 1
| | | | | | | | [underlined: BL^c^] | | | Pleural effusion^a^ | 2
| | | | | | | | Unilateral^d^ | 8§ | 0 | Wound Infection^a^ | 2
| | | | | | | | Bilateral^e^ | 11 | 1 | Splenectomy due to iatrogenic injury | 9
| | | | | | | | | | | [underlined: Grp2]
| | | | | | | | | | | Wound infection | 1
| | | | | | | | | | | Pneumothorax^a^ | 1
| | | | | | | | | | | Entry into pleural cavity | 10
Bruining 1984 84172630 | ND | ND | ND | | | [underlined: #Pts] | [underlined: Bilateral] | | [underlined: OT] | [underlined: BL] | Laprarotomy:
| | | | | Cushing's Disease | 32 | 16 | Laparotomy | 105 | 800 | Ruptured spleen | 4
| | | | | Cushing's Syndrome | 14 | | Lumboromy L | 85 | 175 | Pneumonia
| | | | | Pheo | 19 | 3 | Lumbotomy R | 95 | 300 | | 2
| | | | | MEA II | 9 | 9 | Lumbotomy L&R | 160 | 450 | Wound Infection | 3
| | | | | Conn's Disease | 13 | | Thoracolumbotomy L | 115 | 400 | PO Hemorrhage | 3
| | | | | Misc | 3 | 1 | Thoracolumbotomy R | 140 | 850 | Lumbotomy:
| | | | | | | | Dorsal L | <60 | <100 | Ruptured spleen | 1
| | | | | | | | Dorsal R | <60 | <100 | Dorsal:
| | | | | | | | Dorsal L&R | 135 | 475 | Caval vein tear | 1
| | | | | | | | | | | Wound infection | 2
| | | | | | | | | | | Thoracolaparotomy:
| | | | | | | | | | | Pneumonia | 1
| | | | | | | | | | | PO Hemorrhage | 1
Irvin III 1989 89272298 | ND | Grp1: 6.8 | 100% pheo by 24 hr urinary metanephrine and/or catecholamine determinations, ND | | --- | | | OT ND | | | | [underlined: Grp1] | [underlined: Grp2]
| | Grp2: 7 | | | | | | BL | [underlined: units] | | | (n=9) | (n=4)
| | | | | | | | Grp1 (n=8) | 7.6 | | Fever >101°F | 5 | 1
| | | | | | | | Grp2 (n=2) | 1.5 | | Pneumonia | 1 | 0
| | | | | | | | | | | Urinary retention/infection | 1 | 1
| | | | | | | | | | | Pleural effusion | 3 | 2
| | | | | | | | | | | Splenectomy | 2 | 0
Nagesser 2000 20229356 | | Grp1: 160 gm | Aldosteronoma | 15 | | Grp 1 | Grp 2 | OT | | | Grp1 17%
| | Grp2: 12 gm | Cushing's synd | 167 | Adrenal hyperplasia | 12% | 53 | Grp 1 160±54 | | | Grp2 10%
| | p<.001 | Nonfynct aden | 19 | Adenoma | 10% | 14 | Grp2 101±44 | | | P=0.2
| | | Pheo | 61 | Carcinoma | 48% | 6 | P <0.001 | | | Morbidity
| | | Unknown | 4 | Pheo | 24% | 17 | BL (median) | | | Grp1 36%, grp2 20%
| | | Virilizing | 15 | Normal | 5% | 7 | Grp1 1050 Grp2 300 | | | P=0.01 in Univariate analysis.
| | | Feminizing | 3 | Other | 2% | 3 | P <0.001 | | | Correlation did not persist in multivariate analysis.
| | | | | P<0.001 for malignancy and hyperplasia

a All bilateral tumors.

b NS

c Blood transfusion

d p<0.03

e Splenectomy due to iatrogenic injury (4)

Evidence Table 6. Surgical complications of comparative open adrenalectomy techniques - Part III

Study, Year Identifier | Postoperative analgesia | | Days hospitalized (mean), Days to recovery (how defined) | | | Mortality | Comments, Biases or limitations
Russell 1982 82281913 (subset of Hamberger 1982) | ND | | | [underlined: Grp1] | [underlined: Grp2] | At 30 day, grp1 - pulmonary embolism (1) & metastatic medullary thyroid carcinoma contributing factor (1); both with bilateral tumors | -
| | | Unilateral | 9.3 | 5.3
| | | Bilateral | 10.6 | 7.5
| | | p<0.01,
| | | ND
Bruining 1984 84172630 | | [underlined: Opiate injections^f^] | | [underlined: Mobilization^f^] | | No operative related deaths. Complications of hypercortisolism - neglected perforation of sigmoid requiring adrenalectomy (1), cerebral hemorrhage 6 wks po (1); both patients had emergency bilateral adrenalectomy by dorsal approach | 120 adrenal glands removed in 111 operations in 1 or 2 stages for 90 patients
| Laparotomy | 4.2 | Laparotomy | 2.2
| Lumbotomy L | 3.0 | Lumbotomy L | 1.4
| Lumbotomy R | 1.7 | Lumbotomy R | 1.7
| Lumbotomy L&R | 1.9 | Lumbotomy L&R | 1.8
| Thoracolumbotomy L | 2.5 | Thoracolumbotomy L | 1.8
| Thoracolumbotomy R | 3.9 | Thoracolumbotomy R | 2.8
| Dorsal L | 1.0 | Dorsal L | 1.0
| Dorsal R | 1.2 | Dorsal R | 1.0
| Dorsal L&R | 0.8 | Dorsal L&R | 1.0
Irvin III 1989 89272298 | | | Grp 1 9.8 | | | None | Bilateral tumors (11%), extra-adrenal tumors (5%); localization of pheo using CT available after 1977 therefore anterior, intraperitoneal approach
| | | Grp2 6.1
| | | p=0.002,
| | | ND
Nagesser 2000 20229356 | ND | | Grp1: 15.6±8.80 | | | Grp1: 6.8% | Transabdominal more likely to have bilateral operation (p<0.001) or additional operations (p<0.0001). Additional analyses include comparison of the techniques for pheos and large carcinomas. However, tumor size is 3–4 times larger in transabdominal approach. No statistical difference in hospital stay, but shorter operative time(p=0.04), less blood loss (p=0.002) and fewer complications (p=0.008) in univariate analysis. In multivariate analysis, operative time and mortality influenced by tumor size only, blood loss by tumor size and approach, and morbidity and length of stay not correlated with anything.
| | | Grp2: 12.8±6.7 p=0.007 | | | Grp2: 1.5%
| | | | | | p=0.06 in univariate analysis

f ‘Post-operative day of mobilization of patients who were ambulant before surgical tx’

Evidence Table 7. Surgical complications of transperitoneal laparoscopic adrenalectomy - Part I

Study, Year Identifier | Demographics | Inclusion Criteria | Exclusion Criteria | Study design, Enrollment yrs | Procedure/approach
Gagner 1993 94078257 | Country: Canada & US | ND | ND | Prospective 1992 - 1993 | Posterior/flank, Transabdominal 3 bilateral cases
| Setting: Academic
| Mean age: 42 y
| Enrolled: 22
| Evaluated: 22
| 32% Male
| Race: ND
Suzuki 1993 93381846 | Country: Japan | ND | ND | Case series 1992 | Flank
| Setting: Academic
| Mean age: 49.6 y
| Enrolled: 12
| Evaluated: 12
| 50 % Male
| Race: ND
Takeda 1994 94328371 | Country: Japan | ND | ND | Case series 1992-1993 | Abdominal—with and without ultrasonic aspirator and argon beam coagulator.
| Setting: Academic
| Mean age: 50 y
| Enrolled: 17
| Evaluated: 17
| 47% Male
| Race: ND
Guazzoni 1994 95018696 | Country: Italy | Unilateral benign adrenal disease | ND | Prospective 1992-1993 | Anterior
| Setting: Academic
| Mean age: 44 y
| Enrolled: 11
| Evaluated: 11
| 27% Male
| Race: ND
Rutherford 1995 96172118 | Country: Australia | ND | ND | Case series 1993-1994 | Transperitoneal (approach unclear as to anterior or flank)
| Setting: Private?
| Mean age: 55 y
| Enrolled: 60
| Evaluated: 60
| 53% Male
| Race: ND
Suzuki 1995 95333344 | Country: Japan | ND | ND | Case series 1992-1994 | Flank? Not specified, but previous article by Suzuki cited. This study also utilizes the ultrasonic surgical system during laparoscopy to identify structures.
| Setting: academic
| Mean age: 50 y
| Enrolled: 16
| Evaluated: 16
| 56% Male
| Race: ND
Weisnagel 1996 Endocrinologist | Country: Canada | ND | ND | Case series 1992-1995 | Flank
| Setting: academic
| Mean age: ND
| Enrolled: 57
| Evaluated: 57
| 40% Male
| Race: ND
Janetschek 1996 97131418 | Country: Austria | ND | ND | Case series 1992-1995 | Anterior
| Setting: Academic
| Mean age: 51 y
| Enrolled: 18
| Evaluated: 18
| 55% Male
| Race: ND
Marescaux 1996 97147907 | Country: ND | ND | Pheo Tumor > 9 cm | Case series 1992-1995 | Flank
| Setting: ND
| Mean age: 51 y
| Enrolled: 27
| Evaluated: 27
| 33% Male
| Race: ND
Walmsley 1996 97035797 | Country: UK | All patients considered for laparoscopic adrenalectomy | Two excluded, one in 3^rd^ trimester of pregnancy and one with large left adrenal carcinoma. | Prospective case series, single surgeon 1993-1996 | Anterior
| Setting: ND
| Mean age: 42 y
| Enrolled: 12
| Evaluated: 12
| 16% Male
| Race: ND
Fernandez-Cruz 1996 96427220 | Country: Spain | ND | ND | Case series, non-randomized. 1992-1995 | Anterior and flank CO_2_ for non-pheo vs Helium insufflation for pheo.
| Setting: Academic
| Mean age: 43 y
| Enrolled: 31
| Evaluated: 31
| 32% Male
| Race: ND
De Canniere 1996 96396576 | Country: Belgium | ND | ND | Prospective case series 1993-1995 | Transperitoneal (13)
| Setting: Academic, private hospitals | | | | Retroperitoneal (3)
| Mean age: 47(17–72) y
| Enrolled: 16
| Evaluated: 16
| 50% Male
| Race: ND
Horgan 1997 97311351 | Country: US | Laparoscopic adrenalectomy | Adrenal carcinoma or malignant pheo or prior upper abdominal surgery on the involved side | Case series 1994-1996 | Transperitoneal flank approach
| Setting: Academic
| Mean age: 52 (29–71) y
| Enrolled: 16 (19)
| Evaluated: 16 (19)
| 30%Male
| Race:ND
Terachi 1997 98016032 | Country: Japan | Laparoscopic adrenalectomy | ND | Case series 1992-1996 | Transperitoneal anterior approach
| Setting: Academic
| Mean age: ND (23–69)
| Enrolled: 99 (100)
| Evaluated: 99 (100)
| ND % Male
| Race: ND
Gagner 1997 97479849 | Country: Canada & US | Consecutive cases | Procedures performed abroad where follow-up not possible | Retrospective review of case series 1992-1996 | Lateral TLA
| Setting: Academic | | | Probably includes Gagner 1993 article and Lacroix 1998
| Mean age: ND
| Enrolled: 88 (97)
| Evaluated:
| <33% Male
| Race: ND
Lacroix 1998 J Clin Endocrinol Metab | Country: Canada | ND | ND | Case series 1992-1996 | Transperitoneal lateral
| Setting: ND | | | Probably includes Gagner 1993 article
| Mean age: ND
| Enrolled: 74(85)
| Evaluated: 74(85)
| % Male ND
| Race: ND
Shichman 1999 99195885 | Country: US | Consecutive adrenalectomies using the lateral transabdominal approach | ND | Case series 1993-1998 | Transperitoneal lateral
| Setting: ND
| Mean age: 54 y
| Enrolled: 47 (50)
| Evaluated: 47 (50)
| 40% Male
| Race: ND
Pujol 1999 99244754 | Country: Spain | First 30 cases | Suspicion of malignancy or extraadrenal pathology | Case series 1995-1998 | Transperitoneal lateral
| Setting: Academic
| Mean age: 50 y
| Enrolled: 27 (30)
| Evaluated: 27(30)
| 48% Male
| Race: ND
Lucas 1999 20028409 | Country: US | All cases referred for lap. | ND | Case series 1992-1998 | Lateral transabdominal
| Setting: ND
| Mean age: 48.2 (24–73) y
| Enrolled: 36 (42)
| Evaluated: 36 (42)
| % Male ND
| Race: ND
Henry 2000 20493401 | Country: France | ND | ND | 1994-1998 | TLA (flank)
| Setting: Academic
| Mean age: 49.7 (22–76) y
| Enrolled: 159 (169)
| Evaluated:
| 38 % Male
| Race: ND
Lezoche 2000 20533249 (includes Filiponi 1998) | Country: Italy | All patients referred for adrenalectomy One surgical team | >12 cm tumor Known adrenal CA High risk physical state (total of 3 patients excluded) | 1994-1999 | TLA (anterior)
| Setting: Academic
| Mean age: 48.6 y
| Enrolled: 105
| Evaluated: 102 (108)
| 38% Male
| Race: ND
Ishikawa 2000 20370704 | Country: Japan | ND | Malignant or huge tumors | 1993-1999 | TLA (anterior)
| Setting: Academic
| Mean age: (26–82)y
| Enrolled: 55
| Evaluated:
| 27% Male
| Race: ND
Guazzoni 2001 21382597 | Country: Italy | ND | ND | 1992-2000 | TLA (flank)
| Setting: Academic
| Mean age: 39.4 (17–67) y
| Enrolled: 145 (161)
| Evaluated:
| 39% Male
| Race: ND
Pisanu 2001 21178043 | Country: France | ND | >6 cm Suspicion of malignancy | Retrospective 1994-1999 | TLA (flank)
| Setting: ND
| Mean age: 46.5 (13–67) y
| Enrolled: 84 (91)
| Evaluated: 84 (91)
| 48% Male
Porpiglia 2001 21235981 | Country: Italy | Functioning or non-functioning adrenal mass (> 4 cm, inhomogeneous on CT, or increasing in size) | Invasion of surrounding structures | 1995-1999 | TLA (lateral)
| Setting: Academic | | Previous surgery in the adrenal area (e.g. neprhectomy or splenectomy) | Two Centers, 3 surgeons t-test to compare lesion size and operative time Retrospective?
| Mean age: 48(8–81) | | Known malignancies likely to metastasize | Conversions included in results
| Enrolled: 72 (76)
| Evaluated: 72 (76)
| % Male ND
Valeri 2001 21337795 | Country: Italy | ND | ND | Retrospective 1995-2000 | TLA (lateral)
| Setting: ND | | | 1 Center, 1 Surgeon Compares use of harmonic scalpel with traditional laparscopic method Conversions included in results
| Mean age: 48 (19–74)
| Enrolled: 78
| Evaluated: 78
| 38% Male

Evidence Table 7. Surgical complications of transperitoneal laparoscopic adrenalectomy - Part II

Study, Year Identifier | Co-morbidities | | Mean tumor size (cm) | Pre-operative diagnoses, ASA classification | | Pathology | | Operative time (min), Blood loss (ml) (mean) | Complications
Gagner 1993 94078257 | ND | | 4.0 | See Pathology section, ND | | Pheo | 5 | 138 | [underlined: Peri-op]
| | | | | | Cushing's pituitary synd | 4 | | Bleeding | 1
| | | | | | Cushing's adenoma | 4 | | Pancreas tail dissected | 1
| | | | | | Hyper-aldosteronism | 2 | | Hypertension in pheo patient (bag ruptured at resection) | 1
| | | | | | Angio-Myolipoma | 1 | | [underlined: Post-op]
| | | | | | Medullary cyst | 1 | | Anemia requiring 2 units | 2
| | | | | | DHEAS hypersecretion | 1 | | Colic pseudoobstruction (patient with MEN 2B & known megacolon) | 1
| | | | | | | | | Urinary tract infection | 1
| | | | | | | | | Incisional hematoma | 1
Suzuki 1993 93381846 | ND | | 2.3 (1.2–4.3) | Hyperaldosteronism | 5 | Adrenocortical adenoma | 5 | 278 mean, 370 mean | [underlined: Peri-op]
| | | | Pheo | 3 | Adrenocortical nodular hyperplasia | 2 | | Bleeding (2 transfusions) | 3
| | | | Cushing's disease | 2 | Pheo | 2 | | [underlined: Post-op]
| | | | Nonfunctioning tumor | 2 | Adrenomedullary hyperplasia | 1 | | Wound infection | 1
| | | | | | Adrenocortical hyperplasia | 1 | | Mild paralytic ileus | 1
| | | | | | Myelolipoma | 1
Takeda 1994 94328371 | ND | | 7.9 gm | Hyperaldosteronism | 11 | Adrenocortical adenoma (path available only for first 10 patients from Takeda in Surgery, 1994) | 10 | 253, 216 | Bleeding requiring open hemostasis (clip dislocation) | 1
| | | | Cushing's syndrome | 3
| | | | Nonfunctioning adrenal tumors | 3
Guazzoni 1994 95018696 | ND | | 2.2 | Conn's Disease | 7 | Adenoma | 9 | 190, 90
| | | | Pheo | 2 | Pheo | 2
| | | | Cushing's disease | 2
Rutherford 1995 96172118 | ND | | ND | Aldosteronism | 48 | Adenoma | 48 | 124 min in 1993 152 (20 patients) | PE | 1
| | | | Pheo | 3 | Pheo | 3 | in 1994 109 (40 patients) | Portal hernia | 1
| | | | Cushing's syndrome | 1 | Cortical Adenoma | 1 | ND on BL
| | | | Incidentaloma | 8 | Non-funct adenoma | 7
| | | | | | Cortical carcinoma | 1
Suzuki 1995 95333344 | ND | | 4.4 | Aldosteronism | 4 | ND | | 208±28 min | Bleeding | 1
| | | | Cushing's synd | 3 | | | 135±185 cc | Splenic injury | 1
| | | | Pre-Cushing's synd | 2 | | | 1 transfusion required
| | | | Nonfunct adenoma | 7
Weisnagel 1996 Endocrinologist | ND | | 4.1 | Pheo | 2 | Pheo | 22 | 126 (138 on Right 102 on left) | [underlined: Peri-op] | 1
| | | | Nonfunctional tumor | 13 | Cortical adrenal Adenoma | 9 | ND on blood loss | Bleeding | 1
| | | | Aldosterone producing adenoma | 10 | Aldosterone producing adenoma | 10 | | Conversion to open surgery | 2
| | | | Cortisol producing adenoma | 8 | Cushing's disease | 6 | | Hypotension/ hypertension | 9
| | | | Cushing's disease | 6 | Macronodular adrenal hyperplasia | 3 | | [underlined: Post-op]
| | | | Macronodular adrenal hyperplasia | 3 | Ectopic ACTH | 2 | | Subdural hematoma | 1
| | | | Ectopic ACTH | 2 | Mets Angio-myelolipoma | 2 | | Cholecystitis | 1
| | | | Mets | 2 | Adrenal carcinoma | 2 | | Hematomas | 2
| | | | Angiomyelolipoma | 2 | Medullary cyst | 1 | | Wound infection | 1
| | | | | | Retroperitoneal Sarcoma | 1 | | Colonic pseudo obstruction | 1
| | | | | | | | | Anemia | 2
| | | | | | | | | PE | 1
| | | | | | | | | Renovascular hypertension exacerbation | 2
| | | | | | | | | UTI | 1
| | | | | | | | | Pulmonary edema | 1
Janetschek 1996 97131418 | ND | | 4.2 (1–8) | Conn's disease | 7 | Adrenocortical adenoma | 12 | 160 min 76 cc | Bleeding | 2
| | | | Pheo | 6 | Pheo | 6 | | Post-op drain for 1–3 days | 10
| | | | Cushing's | 1 | | | | Transient diabetes insipidus | 1
| | | | Non-functioning adenoma | 4
Marescaux 1996 97147907 | ND | | 2.0 median (0.5 – 8.0) | Conn's | 20 | ND | | 140 (70–240) min 100–300 cc and one patient with 1000 cc. | 5 converted to open lap
| | | | Symptomatic, nonfunct adenoma | 4 | | | | 1 blood transfusion (3 units)
| | | | Cushing's adenoma | 2 | | | | Pleural effusion+chest infection
| | | | Cyst | 1
Walmsley 1996 97035797 | HTN | 7 | 4.6 | Conn's | 3 | Adenoma | 5 | 120 min (60–225) | Hernia at trocar site | 1
| Crohn's | 1 | | Cushing's syndrome | 3 | Lymphangioma | 1 | Blood loss ND | Blood loss with transfusion of 2 units packed cells | 2
| CVA | 1 | | Cushing's disease | 1 | Cushing's disease | 1 | | Pressure sore from OR | 1
| IHD | 2 | | Pheo | 2 | Onychocytoma | 1 | | Wound infection | 1
| Cardiomyo-pathy1 | 1 | | Incidentaloma | 3 | Pheo | 2
| | | | | | Micronodular hyperplasia | 1
| | | | | | Macronodular Hyperplasia | 1
Fernandez-Cruz 1996 96427220 | ND | | 5.3±2.5 | Non-funct adenoma | 3 | ND (see previous column) | | OT 97±26 BL 147 | One extremely obese patient converted to open lap
| | | 2.3±0.7 | Aldost adenoma | 11 | | | 121±40 210 | UTI | 2
| | | 5.0±1.6 | Cushing's disease | 3 | | | 290±37 365
| | | 4.7±1.2 | Cushing's syndrome | 6 | | | 120±43 210
| | | 4.1±2.0 | Pheo | 8 | | | 128±94 204
| | | weighted ave= 3.8 | | | | | wtd 137
| | | | | | | | 217 ave
De Canniere 1996 96396576 | 4 previous abdominal surgeries | | 3 (1.5–5) median | Pheo | 4 | ND | | 132 (59–360) min | Pleural effusion | 1
| 6 with BMI>30 | | | Hyperaldosteronism | 2 | | | ND on BL but no transfusions needed | Basilar artery thrombosis | 1
| | | | Cushing's synd | 2 | | | | 2 converted to open—bleeding in one and difficult dissection in the other
| | | | Cushing's disease | 1
| | | | Non-funct adenoma | 3
| | | | Metastases | 3
| | | | DHEAS and cortisol hyper secretion | 1
| | | | ASA I | 7
| | | | ASA II | 16
| | | | ASA III | 3
Horgan 1997 97311351 | ND | | ND | Cushing's disease | 3 | ND | | OT Median 174 min unilateral | Subcapsular liver
| | | | Pheo | 4 | | | 480 min bilateral | hematoma | 2
| | | | Functional adenoma | 12 | | | BL | Transfusion | 1
| | | | | | | | 15 patients <100 cc | Bleeding trocar site requiring reop to suture | 1
| | | | | | | | 1 patient required intra-op transfusion | Contusion to head of pancreas | 1
| | | | | | | | | Pneumonia | 1
Terachi 1997 98016032 | ND | | 1–7 | Pheo | 8 | ND | | 240±76 Min | [underlined: Intraoperative] | 4%
| | | | Hyperaldosteronism | 41 | | | 68±80 cc | Bleeding | 3
| | | | Cushing's synd | 15 | | | 2 transfusions | Spleen injury | 1
| | | | Pre-Cushing's synd | 6 | | | | [underlined: Post-op] | 11%
| | | | Non-funct adenoma | 22 | | | | Retroperitoneal hematoma | 4
| | | | Adrenal | 2 | | | | Wound infection | 3
| | | | Complicated cyst | 3 | | | | Retroperitoneal chylocele | 1
| | | | Myelolipoma | 3 | | | | Atelectasis | 2
| | | | | | | | | Localized Peritonitis | 1
Gagner 1997 97479849 | ND | | 4.95 (0.7–12) | Pheo | 25 | ND | | OT 123 (80–360) | DVT | 3
| | | | Hyperaldosteronism | 21 | | | No diff in sides | Hematomas (1 reop) | 2
| | | | Cushing's synd | 17 | | | 70 cc (<20 –1300) | Anemia + transfusion | 2
| | | | Non-funct adenoma | 20 | | | | Subdural | 1
| | | | Cushing's disease | 8 | | | | UTI | 1
| | | | Macronodular adrenal hyperplasia | 2 | | | | Colonic pseudoobs | 1
| | | | Ectopic ACTH synd | 2 | | | | Pulmonary edema | 1
| | | | Carcinoma | 3 | | | | Acute cholecystitis | 1
| | | | Myelolipoma | 2
Lacroix 1998 J Clin Endocrinol Metabol | ND | | 4.1 (1–14) | Pheo | 25 | Nonfunct adenomas were Adrenal CA | 2 | OT 126 (first 68 cases) | Overall 15/74 = 20%
| | | | Hyperaldosteronism | 13 | Medullary cyst | 1 | Rt 138 Lt 102 | Anemia (no transfusion) | 3
| | | | Cushing's synd | 17 | Retroperitoneal sarcoma | 1 | BL ND | Wound hematoma | 2
| | | | Non-funct adenoma | 15 | Cortical adenomas | 11 | | Exacerbation of renovascular hypertension | 2
| | | | Cushing's disease | 6 | Others as suspected | | | UTI | 2
| | | | Macronodular adrenal hyperplasia | 3 | | | | DVT with PE | 1
| | | | Ectopic ACTH synd | 2 | | | | Pulmonary edema | 1
| | | | Metastases | 2 | | | | Subdural hematoma (after fall from hypotension in pheo patient) | 1
| | | | Myelolipoma | 2 | | | | Cholecystitis | 1
| | | | | | | | | Colonic Pseudoobstruction | 1
| | | | | | | | | Wound infection | 1
Shichman 1999 99195885 | ND | | 7.1 (Gland size, not tumor size) | Conn's | 15 | ND | | Left 227 | Bleeding from trocar site | 1
| | | | Cushing's adenoma | 13 | | | Right 210 | Retroperitoneal hematoma | 1
| | | | Nonfunc. adenoma | 11 | | | ND on combined or number of each type | Pleural effusion | 1
| | | | Pheo | 7 | | | BL 142 cc | Wound infection | 2
| | | | Metastases | 1 | | | Transfusion 1 (2 units)
| | | | Hyperplasia | 2
| | | | Carney's syndrome | 1
Pujol 1999 99244754 | ND | | 3.1 (adrenal size 6.1) | Conn's | 8 | Nonfunct adenomas were all cortical adenomas except one schwannoma | | 156 min includes time for other procedures (2 cholecystectomies and 1 hiatal hernia) | 2 converted to open (bleeding from renal hilum and bleeding spleen requiring splenectomy)
| | | | Cushing's adenoma | 5 | | | | GI bleed secondary to NG tube Hypercapnia and subcutaneous emphysema
| | | | Nonfunc. Adenoma | 7
| | | | Pheo | 6
| | | | Metastases | 1
Lucas 1999 20028409 | ND | | 2.5 (1–8) | Conn's | 13 | Cortical adenoma | 19 | Overall OT 262 | [underlined: Intraop] (2/36 = 6%) Hypotension in pheo patient | 1
| | | | Cushing's synd | 7 | Unconfirmed adenoma | 1 | Unilateral OT 194 | CO_2_ embolism after inserting needle into liver
| | | | Cushing's disease | 4 | Angiolipoma | 1 | Overall BL 116 | [underlined: Post-op] 6/36 = 17% Atelectasis | 1
| | | | Nonfunc. Adenoma | 1 | Pheo | 3 | Unilateral BL 108 | Nausea/vomiting | 1
| | | | Pheo | 5 | Cortical hyperplasia | 1 | 1 transfusion | Stitch abscess | 1
| | | | Metastases | 2 | Normal adrenal | 1 | | Adrenal insufficiency | 2
| | | | Hyperplasia | 1 | Adrenal pseudocyst | 1 | | Foot drop after prolonged supine position | 1
| | | | Adrenal pseudocyst | 1 | Ganglio-neuroma | 1
| | | | Ganglioneuroma | 1 | Nodular hyperplasia | 1
| | | | Estrogen producing adenoma | 1 | Bilateral hyperplasia | 4
Henry 2000 20493401 | ND | | 3.2 (0.7–11.0) | ASA I 9.8% | | Conn's | 61 | OT 129 (48–300) | 7.5% overall
| | | | ASA II 60% | | Cushing's | 41 | BL ND | Peritoneal hematoma | 3
| | | | ASA III 29% | | Pheo | 29 | | Parietal hematoma | 1
| | | | ASA IV 1% | | Adenoma | 29 | | Periop bleeding | 3
| | | | | | Androgen | 1 | | Spleen infarction | 1
| | | | | | Adrenal CA | 3 | | Pneumotx | 1
| | | | | | Other CA | 5 | | Tumor effraction | 1
| | | | | | | | | DVT | 2
Lezoche 2000 20533249 | 10% associated conditions | | 5.1 right 5.8 left (3.5–12) | ASA I | 79 | Conn's | 34 | OT 85 right 112 left | Blood transfusion | 1
| 11% previous surgery | | | ASA II | 21 | Cushing's | 27 | BL “Decreased in last 40 adrenal-ectomies” | Arrhythmia req. meds | 1
| | | | ASA III | 3 | Pheo | 13 | | Reop for bleeding | 1
| | | | | | Adenoma | 29 | | Abdominal abscess | 1
| | | | | | Androgen | 2 | | Umbilical hernia (repaired) | 1
| | | | | | Other CA | 3
Ishikawa 2000 20370704 | ND | | 3.0±1.6 (1.0–6.5) | Conn's | 30 | ND | | OT 143±42 | None
| | | | Cushing's | 14 | | | 185 in first 14 cases
| | | | Non-functioning | 8 | | | 120 in the last 41
| | | | Pheo | 3 | | | BL 49±50cc
| | | | | | | | 92 in first 14 cases
| | | | | | | | 32+30 in last 41
Guazzoni 2001 21382597 | ND | | 8 (7–10) | Conn's | 51 | ND | | OT 160 | Hemoperitoneum & reop | 3
| | | | Cushing's | 34 | | | | Transfusions | 2
| | | | Pheo | 29 | | | | Wound infection | 2
| | | | Adenoma | 27
| | | | Other CA | 4
Pisanu 2001 21178043 | ND | | 0.5–7.0 | Conn's | 39 | ND | | OT 147 (55–310) | Total 14.2%
| | | | Cushing's | 13 | | | BL ND | Retroperitoneal hematoma 9.5%
| | | | Pheo | 18
| | | | Adenoma | 9
| | | | Other | 5
Porpiglia 2001 21235981 | ND | | 5.0±2.3 (1.8–11.0) | ND | | Adenoma | 22 | R. 130±25 | [underlined: Intraoperative]
| | | | | | Conn's | 22 | L. 140±27 | Acidosis in Cushing's (conversion) | 1
| | | | | | Cushing's synd | 5 | B.240±35 | Vena Caval bleed in Cushing's (conversion) | 1
| | | | | | Pheo | 8 | Unilateral Wtd. Avg 135 (85–200) | R. Adrenal vein bleed (conversion) | 1
| | | | | | Cushing's dis | 4 | BL 80 (50–700) | R. renal vein injury | 1
| | | | | | Hemorrhagic cysts | 5 | | Hypertensive crisis (pheos) | 2
| | | | | | Angio-myolipoma | 2 | | [underlined: Post-op]
| | | | | | Cortical CA | 1 | | PE (died) | 1
| | | | | | Ganglio-neuroma | 1 | | Myocardial infarction | 1
| | | | | | Androgen producing | 1 | | Massive bleed R. Adrenal area (reoperation) | 1
| | | | | | Echinococcus cyst | 1 | | Hematoma (1 had transfusion) | 3
| | | | | | | | | Wound infection (converted to laparotomy - Cushings) | 1
| | | | | | | | | Transfusion altogether | 6
| | | | | | | | | No herniations or port-site Infections
Valeri 2001 21337795 | Left lung CA | 1 | 4.0 cm (1–10) | Incidentaloma | 24 | Adenoma | 19 | OT 120 (60–210) | Post op bleeding (CT guided drainage and transfusion) | 1
| Cholelithiasis | 2 | | Conn's | 20 | Cyst | 5 | BL 200 | UTI | 1
| Thyrotoxicosis | 1 | | Cushing's Dis | 16 | Adenoma | 18 | | Vascular injury | 2
| | | | Pheo Isolated masses in neoplastic patients | 7 | CA | 2 | | Respiratory distress (died) | 1
| | | | Primitive CA | 1 | Adenoma | 16
| | | | Myelolipoma | 1 | Benign Pheo | 9
| | | | | | Adenoma | 2
| | | | | | lung mets | 4
| | | | | | kidney mets | 1
| | | | | | Primitive CA | 1
| | | | | | Myelolipoma | 1

Evidence Table 7. Surgical complications of transperitoneal laparoscopic adrenalectomy - Part III

Study, Year Identifier | Postoperative analgesia | Days hospitalized (mean),Days to recovery (how defined) | Mortality | Comments, Biases or limitations
Gagner 1993 94078257 | ND | 4, ND | None | Failed procedure (1) converted to right flank approach, in 15 cm angiomyolipoma; no data on number of posterior vs transabdominal approach
Suzuki 1993 93381846 | ND | ND, 10 (return to preop activity) | None
Takeda 1994 94328371 | ND | 11.6, 1.8 until eating | None | First seventeen cases at their hospital. Mean length of stay for open adrenalectomy was 17.32 days. Contains some data from article #94233498 which has the first 10 cases as a series.
| | 2.6 until walking
Guazzoni 1994 95018696 | 90 mg ketoprofen (ave) | 2.9 | None
| | 1 to ambulate
| | 8.4 return to work
Rutherford 1995 96172118 | ND | 5.1 ± 0.2 | None | Definite learning curve demonstrated for time of operation (p<0.01). Author also shows positive correlation between operation time and BMI.
| | ND on recovery | | Author compares his results to the open approach but the comparison is not mentioned in the methods. Unclear where the data came from.
Suzuki 199595333344 | ND | “fully recuperated” 4.6 eat at 1.4 | None
| | walk at 1.6
De Canniere 1996 96396576 | | 6 (2–13) | None | 2 failed procedures - bilateral retroperitoneal (1 Cushing's & 1 met) converted to laparoscopic
| | ND on recovery
Weisnagel 1996 Endocrinologist | ND | ND | None | Patient with hematoma was receiving anticoagulation—required laparoscopy to drain hematoma.
Janetschek 1996 97131418 | Tramadol 1–2 d 10 | 4.6 (2–7) | None
| | 24 hours to ambulation
| | Normal activities in 8–14 d
Marescaux 1996 97147907 | ND | 5.3 median (2–14) | None | First 3 procedures were converted to open lap. Hospitalization time is shorter if these patients are excluded (4.6 days)
Walmsley 1996 97035797 | ND | 5.3 for laparoscopy | None | Not clear which patients had open and which had laparoscopic. Author claims all adrenal glands were removed laparoscopically, then gives hospital days as shown at left.
| | 6.5 for open lap
Fernandez-Cruz 1996 96427220 | Mean doses Ketorolac 30mg = 4 | 3.5 | None
| | ND on recovery
Horgan 1997 97311351 | ND | 2.5 excluding 1 patient who required 25 d for pneumonia 3.9 including all patients | None
Terachi 1997 98016032 | 1.5±1.3 days | 7.2±8.7 d at Kyoto hospital (subset of 35 patients) | None
| | Normal diet 1.3±0.6
| | Ambulation 1.4±0.8
Gagner 1997 97479849 | 5.5 injections | 2.4 (1–6) | None | Tumor size increased from 4.1–4.95 over course of study, while hospital stay decreased from 3–2.4. Conversion in 3% of patients, all had large tumors >10 cm. Included patients with previous abdominal surgery 55%, and none needed conversion.
| | | | Pheos had longer OT 2.5 vs. 1.8 hours, 60% of complications, 56% had hyper/hypotension. Possible contraindications: Adrenal CA, malignant pheo, previous trauma, coagulopathy, > 15 cm.
Lacroix 1998 | Mean number or narcotic injections 5.5 | 3 (2–19) | None | 1992-1993 may include subset of Gagner patients.
J Clin Endocrinol Metabol
Shichman 1999 99195885 | 4.8 doses parenteral narcotics and 3.6 doses of oral narcotics | 3 | None | Poor attention to detail. Number of patients does not equal number of operations.
Pujol 1999 99244754 | ND | 3 excluding patient converted to open | None | In graph, one patient appears to have 60 days post-op stay, but not reported in results.
Lucas 1999 20028409 | ND | 2.0 overall | None
| | Unilateral 1.1
| | Bilateral 3.0
Henry 2000 20493401 | ND | 5.4 (3–15) | 0 | All patients cured. No recurrences in 27 months. Inexperience responsible for 4/12 complications. Author's contraind. Local invasion >12 cm, previous surgery
| | Walked on day 1.5 (1–3)
Lezoche 2000 20533249 | 43% got ketoralac at 45mg/patient | 2.5 d (2–3) | None | One conversion due to colonic tear. No correlation of tumor size and OT. BMI correlated with OT.
| | Normal activity 7 d
| | Walking in 6–12 hours post-op
| | Walking in 6–12 hours post-op
Ishikawa 2000 20370704 | 2.9+1.0 doses (2–4) | ND | None | Demonstrates learning curve. First 14 cases operating time = 185±19, compared to 120±38 for the last 41 cases (p<0.001) No complications.
| | Time to ambulation | | Includes 11 patients with partial adrenalectomy
| | 17±3 hours
Guazzoni 200121382597 | ND | 2.8±0.9 | 0 | 4 conversions
| | | | No disease recurrence @ 3 months
| | Normal Activity | | 2 references for RLA vs. TLA
| | 7±2.3
Pisanu 2001 21178043 | ND | | None | 4 conversions (3 for bleeding)
Porpiglia 2001 21235981 | 0.3 Buprenorphine followed by Ketorolac 56±33. | 4.3±2.0 | 1 – PE on day #7. Pt had CML. | 3 Conversions (see complications—two in bilateral operations for Cushing's). 81 yo pt with 10 cm Stage II cortical CA had no recurrence at 40 months of follow-up. No result reported regarding lesion size and OR time (see methods)
| | Normal Activity
| | 12 days (8–20)
Valeri 2001 21337795 | ND | 3.5 | 1 Pt with severe Cushing's and COPD had resp. distress and cardiac arrest 2^nd^post-op day. | Decreased operating time with harmonic scalpel 94.2 min vs. 118 min for trad. Scalpel p=0.004. Not due to learning curve.
| | Includes converted patients

Evidence Table 8. Surgical complications of retroperitoneal laparoscopic adrenalectomy - Part I

Study, Year Identifier | Demographics | Inclusion Criteria | Exclusion Criteria | Study design, Enrollment yrs | Procedure/approach
Walz 1996 96427221 | Country: Germany | ND | ND | Case series 1994-1995 | Posterior (retroperitoneal)
| Setting: Academic
| Mean age: 49 y
| Enrolled: 27
| Evaluated: 27
| 26% Male
| Race: ND
Takeda 1997 97130443 | Country: Japan | Functioning adrenal tumors | ND | Case series 1994-1995 | Retroperitoneal
| Setting: Academic
| Mean age: 39.6 y
| Enrolled: 11
| Evaluated: 11
| 27% Male
| Race: ND
Gasman 1998 98258413 | Country: France | ND | Tumor > 5 cm | Case series 1995-1997 | Retroperitoneal
| Setting: ND | | Previous lumbar incision
| Mean age: 49.6 y
| Enrolled: 22(23)
| Evaluated: 22(23)
| 45% Male
| Race: ND
Baba 1999 99195886 | Country: Japan | ND | ND | Retrospective, Nov 1992-April 1998 | Retroperitoneoscope/ lumbodorsal (26)
| Setting: Academic
| Mean age: 45 y
| Enrolled: 68*
| Evaluated: 26
| % Male: ND
| Race: ND
Fazeli-Matin 1999 99385519 | Country: US | All adrenal lap patients with BMI>30 | ND | All adrenal and renal lap case with BMI>30 1997-1998. | Mostly retroperitoneal
| Setting: Academic
| Mean age: 57 y
| Enrolled: 10
| Evaluated: 10
| 57% Male
| Race: ND
| Age and % male are for all patients.
| See comments.
Lee 2000 Formosan J. of Surgery | Country: Taiwan | ND | ND | Case series? 1996-1999 | Retroperitoneal
| Setting: ND
| Mean age: 48 y
| Enrolled: 30
| Evaluated: 30
| 40% Male
| Race: ND
Subramaniam 2000 20165864 | Country: India | Pheo | ND | Case series 1996-1998 | Retroperitoneal
| Setting: Academic
| Mean age: 33 (13–50) y
| Enrolled: 11 (16)
| Evaluated: 11 (16)
| 27% Male
| Race: ND
Tanaka 2000 20412770 | Country: Japan | All laparoscopic adrenalectomies | ND | Case series 1993-1998 | Various laparoscopic
| Setting: Academic
| Mean age: 45 y
| Enrolled: 54
| Evaluated: 54
| 31% Male
| Race: ND
Bonjer 2000 20541322 | Country: Netherlands | All RLA surgeries (biased) | Tumor > 6 cm | Retrospective 1994-1999 | RLA
| Setting: Academic | | Malignant tumors | Intention to treat
| Mean age: 50 (17–83) y | | Prior peri-renal surgery | Good definitions
| Enrolled: 95 (111)
| Evaluated: 95 (111)
| 52% Male
| Race: ND
Salomon 2001 21329320 (includes Souliq 2000 20566182) | Country: France | Consecutive cases of adrenalectomy | Suspected malignancy (8) | Prospective (Souliq) 1995-2000 | RLA
| Setting: ND | | Tumors > 5cm
| Mean age: 49.3 (17–74)
| Enrolled: 106 (115)
| Evaluated:106 (115)
| 40% Male
| Race: ND
Walz 2001 21270600 | Country: Germany | ACTH induced adrenal hyperplasia, functioning tumors <7 cm, non-functioning tumors >4cm and < 7cm. Suspected metastases. | Tumor > 7cm (8) | Prospective 1994-1999 | RLA
| Setting: Academic | | | Three surgeons
| Mean age: 49±15 y
| Enrolled: 130 (142)
| Evaluated: 130 (142)
| 40% Male
| Race: ND

Evidence Table 8. Surgical complications of retroperitoneal laparoscopic adrenalectomy - Part II

Study, Year Identifier | Co-morbidities | | Mean tumor size (cm) | Pre-operative diagnoses, ASA classification | | Pathology | | Operative time (min), Blood loss (ml) (mean) | Complications
Walz 1996 96427221 | ND | | 3.2 | Cushing adenoma | 8 | ND | | 124±49 min 40 cc | 4 patients converted to open
| | | | Cushing syndrome | 2 | | | | Decrease cardiac output | 1
| | | | Conn's | 5 | | | | Retroperitoneal drainage | 7
| | | | Pheo | 7 | | | | Hyperesthesia of abdominal skin lasting 2–3 months
| | | | Nonfunct adenoma | 4
| | | | Cyst | 1
Takeda 1997 97130443 | Hyper-tension | 11 | 17.3 | Primary aldosteronism | 5 | Same | | 248.3 min 151.4 cc | Pancreatic injury converted to open | 1
| Hypo- kalemia | 4 | | Cushing's synd | 6 | | | No transfusions | Subcutaneous emphysema | 6
| Renal dysfunction | 1 | | | | | | | Conversion to transperitoneal approach | 3
Gasman 1998 98258413 | ND | | 2.6 (1.0–4.0) | Conn's | 12 | ND | | OT 97 (45–160) | 2/22 9% Hematoma | 1
| | | | Cushing's adenoma | 4 | | | BL 70 (0–450) | Fever | 1
| | | | Cushing's disease | 1
| | | | Nonfunc. Adenoma | 2
| | | | Pheo | 2
| | | | Metastases | 1
Baba 1999 99195886 | ND | | ND | ND | | 1° aldo- steronism | 16 | OT - 144 | ND
| | | | | | Cushing's synd | 6 | BL - 43.5
| | | | | | Virilizing adenoma | 1
| | | | | | Pheo | 1
| | | | | | Endocrine-inactive adenoma | 1
| | | | | | Myelolipoma | 1
Fazeli-Matin 1999 99385519 | ND | | ND | ASA 3.1 (mean for all patients in study including those undergoing nephrectomy) | | Adrenal Adenoma | 8 | 180 (150–270) | 1/10 = 10%
| | | | | | Pheo | 1 | 50 (20–390) | No details on type
| | | | | | Mets | 1
Lee 2000 Formosan J Surg | None | | 2.2 (1–4) | Conn's | 19 | Confirmed pre-op diagnose | | 155 min | No intra-op complications
| | | | Cushing's adenoma | 6 | | | <100 cc | Post-op 2/30 = 7%
| | | | Nonfunc. Adenoma | 2 | | | | Retroperitoneal abscess (requiring percutaneous drainage and antibiotics) | 1
| | | | Adrenal cyst | 2 | | | | Retroperitoneal hematoma (spontaneous resolution) | 1
| | | | Pheo | 1
Subramaniam 2000 20165864 | Thyro- toxicosis | 1 | ND | Pheo 11 (5 bilateral) | | ND | | OT 210–240 | ND
| DM | 2 | | | | | | BL 240±200 in successful lap. | 3 patients required ventilatory support overnight
| TB+pleural Effusion | 1 | | | | | | 2000±700 in 3 cases converted to open
| LVH | 5
| LV dysfunction | 2
Tanaka 2000 20412770 | ND | | 2.65 | Conn's | 20 | ND | | OT 227 | ND
| | | | Cushing's adenoma | 18 | | | BL 176
| | | | Nonfunc.Adenoma | 6
| | | | Pheo | 10
Bonjer 2000 20541322 | ND | | 3.4 (0.2–7) | ND | | Conn's | 25 | Unilat 114±4.8, 65± 13cc | 11% overall Hematoma | 3 (1 drained)
| | | | | | Cushing's | 36 | Bilat 214+26, 121±39 cc | UTI | 3
| | | | | | Pheo | 19 | Conversion 183±35, 75±75 cc | Ileus | 1
| | | | | | Adenoma | 11 | Unilat + Conversion 118, 66 cc | Depression Candidemia (patient died) | 1
| | | | | | Metastases | 1
| | | | | | Adrenal CA | 1
| | | | | | Androgen | 2
Salomon 2001 21329320 (includesSouliq 2000 20566182) | ND | | 3.1 (1.0–6.2) | ND | | Conn's | 37 | 118 (45–240) | Overall 15.5% Vascular injury | 3
| | | | | | Cushing's | 37 | 77 cc (0–550) | Adrenal fragmentation | 1
| | | | | | Pheo | 21 | | Wound infection (all were drained and got abx) | 5
| | | | | | Adenoma | 12 | | Lumbar fossa hematoma (2 needed evacuation) | 5
| | | | | | Myelolipoma | 3 | | Parietal dehiscence | 2
| | | | | | Metastases | 3 | | Chronic lumbar pain (no cause found) | 1
| | | | | | Pseudocyst | 1 | | Pneumopathy (lesional edema requiring ventilator for 2 days) | 1
| | | | | | Hemangioma | 1 | | Fever >48 hours | 1
| | | | | | | | | Hypertension (30% of pheos)
Walz 2001 21270600 | Bronchogenic CA | 7 | 2.7±1.4 (0.5 – 7) | ND | | Conn's | 46 | 101±44 Conversions excluded | Pleural tear | 4
| Malignant Pheo | 1 | | | | Cushing's | 29 | 78 min for last 50 procedures | Hypertension 3/28 pheos
| | | | | | Pheo | 28 | 54±72 cc | Relaxation of abdominal wall (temp) | 9
| | | | | | Adenoma | 12 | No transfusions | Hyperesthesia (temp) | 7
| | | | | | Metastases | 2 | | Hematoma (spontaneous resolution) | 1
| | | | | | Bilat Hyperplasia | 10 | | Incisional hernia (repaired) | 1
| | | | | | Cyst | 2
| | | | | | Ganglioneuroma | 1

Evidence Table 8. Surgical complications of retroperitoneal laparoscopic adrenalectomy - Part III

Study, Year Identifier | Postoperative analgesia | Days hospitalized (mean), Days to recovery (how defined) | Mortality | Comments, Biases or limitations
Walz 1996 96427221 | 7.9 mg piritrimide in endoscopy patients (23) | ND | None
| 34 mg for open patients (4)
Takeda 1997 97130443 | ND | ND on hospital days | None
| | 1.55 to oral intake
| | 2.0 to ambulation
Gasman 1998 98258413 | 2.7 gm acetaminophen | 3.35 | None
| 9.6 gm morphine (mean)
Baba 1999 99195886 | ND | 4.7 - patients with primary aldosteronism, | None | Laparoscopic or retroperitoneoscopic by transperitoneal anterior (37), transperitoneal lateral (3), extraperitoneal flank (2) & lumbodorsal in (26); 1 conversion, patient with myelolipoma, to open posterior surgery for sudden onset of tension pneumothorax caused by injury to right medial crus of diaphragm; 11 patients with history of upper or lower abdominal surgery had no complications; 6 patients received surgery with AESOP robotic arm by voice activated camera control, all procedures successful except 1 where robotic arm was prematurely terminated.
| | 7.6 - patient questionnaire survey | | No correlation found between operative time and BMI (p=0.079 by Spearman rank correlation)
| | 1.3 days to unassisted ambulation
Fazeli-Matin 1999 99385519 | Mg narcotics | <1 (<1 – 3) | None | This is a subset of a larger study comparing lap to open adrenalectomy/nephrectomy in obese patients. In the adrenalectomy subset there were only 4 patients in the open controls which made comparison not meaningful. Some demographic data was not broken out by subset and is so noted.
| 9 (0–22) | Weeks of convalescence
| | 2.0 (1–3)
Lee 2000 Formosan J. of Surgery | None | 5.5 (4–8) | None
| | Ambulate 1.0
| | Oral intake 1.0
Subramaniam 2000 20165864 | ND | ND | None
Tanaka 2000 20412770 | ND | 10.6 | None | Study was designed to compare pheo by lap and open, but open had only 7 historical controls.Even so, hospital stay and parenteral analgesics were statistically less in the lap group.No other differences reached significance but study size was very small.There were also no significant differences in operative time, blood loss or hospital stay among different indications for adrenalectomy, though these numbers were also small.
| | Ambulate 1
| | Oral intake 1
Bonjer 2000 20541322 | | 2.0 (1.5–5.0) Unilateral | 1/94 | No correlation between BMI, OT, BL or LOS
| | 12.5 (7.3–16.3) Conversion | | 5 conversions (2 for bleeding, 2 for access and 1 for malignancy)
| | 2.67 Combined
Salomon 2001 21329320 (includes Souliq 2000 20566182) | 36 mg morphine day 1, 120 dextropropxyphene on day 2 and thereafter | ND | None | OT not affected by side, sex, or weight.
| | Ambulatory 1–2 days | | One conversion to open due to adhesions (0.8%)
Walz 2001 21270600 | 50% had no analgesia only 5 patients requested after first day. | 3 Median (1–21) | None | 7 conversions (1 cardiac instability while prone, 1 technical problem gaining pneumoperitoneum, 5 dissection difficulty) No conversions in last 104 cases.
| | | | Larger tumors, pheos and males took longer.Side and BMI not correlated to OT.

Evidence Table 9. Surgical complications of open vs. endoscopic adrenalectomy techniques - Part I

Study, Year Identifier | Demographics | Inclusion Criteria | Exclusion Criteria | Study design, Enrollment yrs | Procedure/approach
Prinz 1995 95266961 | Country: US | Consecutive patients of the same surgeon | Lesions >10 cm | Retrospective cohort | Grp1 - Laparoscopic flank approach | 10
| Setting: Academic | | Bilateral disease | | Grp2 - Anterior open lap | 11
| Mean age: | | Extraadrenal pheo | | Grp3—Posterior open lap | 13
| Grp1: 50±11 y | | One patient excluded for bleeding necessitating conversion to open lap
| Grp2 49±15 y
| Grp3 49±17 y
| Enrolled: 34
| Evaluated: All
| Grp1: 70% Male
| Grp2: 27% Male
| Grp3: 23% Male
Guazzoni 1995 95230788 | Country: Italy | Benign hyperfunctioning tumor | ND | Retrospective and historical control | Grp1:
| Setting: Academic | | | Grp 1 1988-1992 | open/ transperitoneal | 10
| Mean age: | | | Grp 2 1992-1994 | open/retroperitoneal | 10
| Grp1–39 y | | | | Grp2:
| Grp2–41 y | | | | laparoscopic/ anterior | 20
| Enrolled: 40
| Evaluated: 40
| Grp1 35% Male
| Grp2 40% Male
Brunt 1996 96269426 | Country: USA | Benign tumor | Malignant or tumors > 8 cm | Retrospective, | Grp1: open/ anterior transabdominal | 25
| Setting: Academic | | | Open surgeries (Grp1, Grp2) from 1988 - 1993, | Grp2: open/posterior retroperitoneal | 17
| Mean age: | | | Laparoscopic surgeries (Grp3) from 1993 - 1995 | Grp3: laparoscopic/ transabdominal | 24
| Grp1–43 y
| Grp2–55 y
| Grp3–50 y
| Enrolled: 69
| Evaluated: 66
| 29% Male
MacGillivray 1996 97020136 | Country: US | All patients offered adrenalectomy. Patients were given the choice of approach. | ND | Retrospective case series. | Grp1:
| Setting: Academic | | | 1993-??? | open anterior | 5
| Mean age: Grp1-56 y | | | | open posterior | 4
| Grp2–57 y | | | | Grp2:Laparoscopic transperitoneal | 14
| Enrolled: 23 (29*)
| Evaluated: 23 (29*)
| Grp1 25% Male
| Grp2 36% Male
Staren 1996 97015733 | Country: US | All adrenalectomies | ND | Retrospective case series | Grp1 Open (mixed) | 19
| Setting: Academic | | | 1992-1995 | Grp2 Lap mixed | 20
| Mean age:
| Grp1–42 y
| Grp2–50 y
| Enrolled: 41
| Evaluated: 41
| Grp1 30% Male
| Grp2 57% Male
Mugiya 1996 97128195 | Country: Japan | Non-functioning adrenal tumors (incidental findings) | Obvious hormone producing tumors | Case series 1992-1995 | Grp1:Open, ND on approach
| Setting: Academic | | | | Grp2:Laparoscopic (Flank?) ND but cites Suzuki 1993 and 1995
| Mean age:
| Grp1–51.7 y
| Grp2–50.9 y
| Enrolled: Grp1:13
| Grp2:7
| Evaluated:All
| Grp1 -76% Male
| Grp2–29% Male
Bonjer 1997 97315759 (Grp1 and Grp3 are subsets of Bonjer 1998) | Country: Netherlands | Tumor < 6 cm | ND | Retrospective, patients matched by Quetelet index, Open surgeries (Grp1) from Feb 1992 - Jun 1994, Laparoscopic (Grp2) & endoscopic (Grp3) surgeries after Jun 1994, no data for end of enrollment period | Grp1: open/posterior | 12
| Setting: Academic | | | | Grp2:laparoscopic/ transperitoneal | 9
| Median age: | | | | Grp3: endoscopic/ retroperitoneal | 9
| Grp1–36 y
| Grp2–44 y
| Grp3–46 y
| Enrolled: 30
| Evaluated:30% Male ND
Linos 1997 97228299 | Country: Greece | All patients with primary adrenal lesions operated on by the same surgeon. | ND | Retrospective case series 1984-1995 (all laparoscopic surgeries from 1993-1995). | Grp1: open anterior | 86
| Setting: Academic | | | | Grp2: open posterior | 61
| Mean age: | | | | Grp3: laparoscopic transperitoneal | 18
| Grp1 46.4 y
| Grp2 43.8 y
| Grp3 48.7 y
| Enrolled: 165
| Evaluated: 165
| Grp1 43% Male
| Grp2 29% Male
| Grp3 44% Male
| Race ND
Aldrighetti 1997 97472886 | Country: Italy | Adrenal surgery for incidentaloma by a single surgeon and surgical team | 2 patients refused operation | Consecutive case series collected retrospectively | Grp1 Transperitoneal laparotomy (open) | 12
| Setting: Academic | | 1 patient had bilateral metastatic disease from previous hepatocellular carcinoma | Grp1 1992-1993 | Grp2 Laparoscopic Anterior | 8
| Mean age: | | | Grp2 1993-1995
| Grp1 54.5 y
| Grp2 56.3 y
| Enrolled: 23 (27)
| Evaluated: 20 (24)
| Grp1 33% Male
| Grp2 25% Male
| Race: ND
Vargas 1997 97291406 | Country: US | Consecutive adrenalectomies | ND | Retrospective case series | Grp1 Subcostal | 7
| Setting: Academic | | | Laparoscopic 1995-1996 | Flan | 13
| Mean age: | | | Open 1992-1995 | Grp2 Laparoscopic | 18
| Grp1 47 y | | | Patient groups were matched for demographics, histology and tumor size. | Subcostal | 2
| Grp2 47 y
| Enrolled: 40
| Evaluated: 40
| Grp1 60% Male
| Grp2 50% Male
| Race: ND
Jacobs 1997 97336426 | Country: US | Consecutive unilateral adrenalectomies | ND | Retrospective case series | Grp1 Laparoscopic transperitoneal approach | 19
| Setting: Academic | | | 1990-1996 | Grp2
| Mean age: | | | Open cases were the last 19 open cases performed—not matched in any way. | open transperitoneal | 10
| Grp1 46±15 y | | | | open retroperitoneal | 9
| Grp2 49±14 y
| Enrolled: 38
| Evaluated: 38
| Grp1 32% Male
| Grp2 37% Male
| Race: ND
Ishikawa 1997 97426050 | Country: Japan | ND | ND | Case series 1993-1995 and comparison with historical control group | Grp1: Laparoscopic transperitoneal | 14
| Setting: Academic | | | | Grp2: Open posterior | 9
| Mean age: | | | | Grp3: Open abdominal | 10
| Grp1 52±12 y
| Grp2 54±11 y
| Grp3 56±13 y
| Enrolled: 33
| Evaluated: 33
| Grp1 29% Male
| Grp2 33% Male
| Grp3 30% Male
| Race: ND
Korman 1997 97463970 | Country: US | Consecutive adrenalectomies at Cedars-Sinai | Patients requiring en bloc resection of adjacent organs | Case series 1993-1996 | Grp1 Laparoscopic transperitoneal | 10
| Setting: Academic | | | | Grp2 Open (Posterior or transabdominal) | 10
| Mean age:
| Grp1 48±12 y
| Grp2 47±15 y
| Enrolled: 20
| Evaluated: 20
| Grp1 20% Male
| Grp2 30% Male
| Race: ND
Thompson 1997 98087809 | Country: US | 50 patients with successful LA (out of 57 attempts). PA patients were matched for age, gender, tumor type, size, side and BMI. | Unsuccessful LA | Retrospective case series with matched historical controls. 1992-1996 | Grp1 Posterior | 50
| Setting: Academic | | | | Grp 2 TLA | 50
| Mean age:
| Grp1 51 y
| Grp2 50 y
| Enrolled: 100
| Evaluated: 100
| Grp1 40% Male
| Grp2 36% Male
| Race: ND
Yoshimura 1998 99110579 (See Miyake above) | Country: Japan | As in Miyake | ND | Case series 1992-1996 | Grp1 Mixed laparoscopic approaches | 28
| Setting: Academic | | | Historical controls from 1990-1996 | Grp2 Open, mixed approaches | 25
| Mean age:
| Grp1 42.0 (5–62) y
| Grp2 47 (24–70) y
| Enrolled: 53
| Evaluated: 53
| Grp1 43% Male
| Grp2 40% Male
| Race: ND
Ting 1998 98307710 | Country: China | Adrenal surgery by laparoscopy or posterior route | Patient with 7 cm schwannoma that failed laparoscopy | Retrospective review 1981-1997 | Grp1 Laparoscopic transperitoneal | 12
| Setting: Academic | | | | Grp2 Posterior open | 56
| Mean age:
| Grp1 42.5 y
| Grp2 47.5 y
| Enrolled: 68
| Evaluated: 68
| Grp1 8% Male
| Grp2 41% Male
| Race: ND
Winfield 1998 98343464 | Country: US | Patients eligible for laparoscopic adrenalectomy | Lesions > 6.0 cm or primary adrenal CA | Case series 1996-1997 with historical control group 1994-1996 | Grp1 Laparoscopic transperitoneal flank approach | 21
| Setting: Academic | | | | Grp2 Various Open | 17
| Mean age:
| Grp1 52.2 y
| Grp2 53.2 y
| Enrolled: 38
| Evaluated: 38
| Grp1 48% Male
| Grp2 53% Male
| Race: ND
Bonjer 1998 99065956 | Country: Netherlands | Tumor < 6 cm | ND | Retrospective, Open surgeries (Grp1) from Feb 1998 - Jun 1994, All laparoscopic surgeries (Grp2) from site | Grp1: open/posterior | 30
| Setting: Academic | | | | Grp2: endoscopic/ retroperitoneal | 42
| Mean age:
| Grp1-43.5 y
| Grp2–45.0 y
| Enrolled: 72
| Evaluated: 72
| % Male ND
Soares 1999 99088300 | Country: US | 20 consecutive adrenalectomies | Failed laparoscopy | Case series 1994-1997 | Grp1 Laparoscopic mostly transperitoneal | 11
| Setting: Academic | | | | Grp2 Various Open | 8
| Mean age:
| Grp1 48 y
| Grp2 43 y
| Enrolled: 20
| Evaluated: 19
| ND % Male
| Race: ND
Dudley 1999 99290915 | Country: UK | 1^st^ enrollment period: tumor > 5 cm, suspected/confirmed malignant tumor | 2^nd^ enrollment period: tumor > 10 cm, susp malignant change, history thromboembolic disorder | Retrospective, Open surgeries (Grp1) from Sep 1989 - Nov 1994, Laparoscopic surgeries (Grp2) from Nov 1994 - Jul 1997 | Grp1: open/posterior | 15
| Setting: Regional | | | | Grp2: laparoscopic/ transperitoneal | 31
| Mean age:
| Grp1–44 y
| Grp2–40 y
| Enrolled: 46
| 55% Male
Schell 1999 99088298 | Country: US | Adrenalectomy for a variety of neoplasms | ND | Case series 1992-1997 | Grp1 Transperitoneal lateral laparoscopy | 22
| Setting: Academic | | | | Grp2 Open, mixed approaches | 17
| Mean age:
| Grp1 44±14 y
| Grp2 ND
| Enrolled: 39
| Evaluated: 39
| Grp1 35% Male
| Grp2 32% Male
| Race:
| Grp1 80%white
| Grp2 79%white
Imai 1999 99383703 | Country: Japan | Transperitoneal laparoscopic adrenalectomy or matched controls with transretroperitoneal adrenalectomy | Conversion to open laparotomy because of uncontrolled bleeding | Case series 1995-1998 with historical controls matched for age, gender, adrenal disorder, side and size of tumor, and body surface area 1991-1998 (38/40 before 1995) | Grp1 Laparoscopic transperitoneal | 40
| Setting: Academic | | | | Grp2 Open retroperitoneal | 40
| Mean age:
| Grp1 47 y
| Grp2 48 y
| Enrolled: 81
| Evaluated: 80
| Grp1 32% Male
| Grp2 35% Male
| Race: ND
Hobart 1999 99419925 (May overlap with Gill 1999) | Country: US | ND | ND | Case series with prospective data collection for grp1 1997-1998 and retrospective controls from 1995-1997. | Grp1: Needlescopic transperitoneal flank approach | 15
| Setting: Academic | | | | Grp2: Various open Transperitoneal | 15
| Median age:
| Grp1–60 y
| Grp2–52 y
| Enrolled: 30
| Evaluated: 30
| Grp1 33% Male
| Grp2 60% Male
Shen 1999 99194292 | Country: US | ND, if case series, then why the 7 year gap? | | Retrospective 1975-1998 | Grp1 mixed open | 38
| Setting: Acadmic | All patients had aldosteronomas. | | Open 1975-1986 | Grp2 mixed LA | 42
| Mean age: | | | LA 1993-1998
| Grp1 35 y
| Grp2 50 y
| p < 0.05
| Enrolled: 80
| Evaluated: 80
| Grp1 16% Male
| Grp2 69% Male
| p<.05
| Race: ND
Inabnet 2000 20246760 | Country: France | Pheo with tumor size < 7cm | For lap group: | Retrospective chart review 1993-1997 | Grp1 Lateral transabdominal laparoscopy | 11
| Setting: ND | | Multiple endocrine neoplasia | | Grp2 Open transabdominal | 11
| Mean age: | | Extraadrenal lesions
| Grp1 51.4±10 y
| Grp2 45.7±14 y
| Enrolled: 22
| Evaluated: 22
| Grp1 27% Male
| Grp2 36% Male
| Race: ND
Hobart 2000 20233461 | Country: US | Adrenal mass >5 cm | ND | Prospective (grp1) case series and retrospective (grp2 and 3) controls | Grp1:Transabdominal (5) or retroperitoneal (7) or combined (2) laparoscopy
| Setting: Academic | | | 1998-1999 (cases) | Grp2:Open mixed approaches
| Mean age: | | | 1992-1998 (controls) | Grp3 :Transabdominal (26) or retroperitoneal (18) or combined (1) laparoscopy
| Grp1 57.1 y
| Grp2 50.7 y
| Grp3 58.1 y
| Enrolled: 73
| Evaluated: 73
| Grp1 43% Male
| Grp2 50% Male
| Grp3 55% Male
| Race: ND
Rayan 2000 20349754 | Country: US | Unilateral laparoscopic adrenalectomy and all unilateral open adrenalectomy | Patients converted to open | Retrospective chart review | Grp1: Transabdominal flank laparoscopy | 19
| Setting: Academic | | | 1994-1998 Laparoscopic | Grp2: Open, various approaches | 48
| Mean age: | | | 1984-1998 Open
| Grp1 41±14 y
| Grp2 50±16 y
| Enrolled: 67
| Evaluated: 67
| Grp1 21% Male
| Grp2 46% Male
| Race: ND
Sprung 2000 20165080 | Country: US | 14 consecutive patients with pheo referred for laparoscopic surgery to single surgeon. | ND | Case series with historical controls | Grp1
| Setting: Academic | | | 1995-1999 (cases) | Open transabdominal | 20
| Mean age: | | | 1992-1999 (controls) | Grp2:
| Grp1 46±17 y | | | | Lateral transperitoneal | 14
| Grp2 57±15 y
| Enrolled: 34
| Evaluated: 34
| Grp1 40% Male
| Grp2 36% Male
| Race: ND

Evidence Table 9. Surgical complications of open vs. endoscopic adrenalectomy techniques - Part II

Study, Year Identifier | Co-morbidities | | | Mean tumor size (cm) | Pre-operative diagonses, ASA classification | | | | Pathology | | | | Operative time (min), Blood loss (ml) (mean) | | | | Complications
Prinz 1995 95266961 | ND | | | Grp1 4.8 | Grp | 1 | 2 | 3 | ND | | | | Grp1 212±77 | | | | ND
| | | | Grp2 5.1 | Pheo | 4 | 9 | 0 | | | | | Grp2 174±41
| | | | Grp3 3.1 | Nonfunct aden | 3 | | 5 | | | | | Grp3 139±36
| | | | | Functadenoma | 2 | 2 | 7 | | | | | p<0.01 for Grp1 v.3
| | | | | Hemorrhagic Cyst | 1 | | | | | | | Grp1 228±66
| | | | | Mets | 1 | | | | | | | Grp2 391±88
| | | | | | | | | | | | | Grp3 288±118
| | | | | | | | | | | | | p<0.05 for grp1 vs 2
Guazzoni 1995 95230788 | ND | | | Grp1 3.0 | Grp1 | | | | See previous column | | | | Grp1 145 | | | | | | Grp1 | Grp2
| | | | Grp2 3.0 | Conn's dis | | | 7 | | | | | Grp2 170 | | | | Pneumo | | 2 | 0
| | | | | Pheo | | | 10 | | | | | Gp1 450 ml | | | | Thorax wound Infection | | 2 | 1
| | | | | Cushing' synd | | | 3 | | | | | Grp2 100 ml | | | | Hemorrhage | | 3 | 0
| | | | | Grp2 | | | | | | | | | | | | lieus | | 2 | 0
| | | | | Conn' dis | | | 10 | | | | | | | | | Fever | | 2 | 0
| | | | | Pheo | | | 7
| | | | | | Cushing' synd | | | 3
Brunt 1996 96269426 | ND | | | Grp1: 3.4 | Pre-op dx cannot be clarified with data given | | | | | Grp1 | 2 | 3 | OT^a^ | Grp1 | Grp2 | Grp3 | | Grp1 | Grp2 | Grp3
| | | | Grp2: 2.4 | Grp1: 2.8 | | | | Pheo | 18 | 1 | 11 | Unilateral | 142 | 136 | 183 | I^c^ | 11 | 7 | 2
| | | | Grp3: 2.7 | Grp2: 2.9 | | | | Aldosteronoma | 0 | 8 | 6 | Bilateral^b^ | 205 | 323 | 422 | IIA | 5 | 2 | 2
| | | | NS | Grp3: 3.5 | | | | Cortisol aden | 1 | 2 | 1 | [underlined: BL] ^a^ | 408 | 366 | 104 | IIB | 2 | 0 | 0
| | | | | NS | | | | Cushing's synd (adrental hyperplasia) | 1 | 2 | 2 | | | | | III | 0 | 0 | 0
| | | | | | | | | Vascular malform | 1 | 0 | 0 | | | | | IV | 1 | 0 | 0
| | | | | | | | | Susp pheo/malig | 4 | 2 | 2 | | | | | Grp1 - pain (1) at 10 wk
| | | | | | | | | Other | 0 | 2 | 2 | | | | | Grp2 - pain & dysesthesia (3) > 1 mo
MacGillivray, 1996 97020136 | Only listed for open patients: | | | ND | Grp | | 1 | 2 | ND | | | | OT | | Grp1 201±10 | Grp2 289±86 | Grp1 5/9
| Prior nephrectomy Chronic Back pain Cholelithiasis Metastatic gastrinoma | | | | Aldo- Steronoma | | 3 | 7 | | | | | | | p=0.042 | | Atelectasis | | | 2
| | | | | Cushing's synd | | 4 | 4 | | | | | BL | | 500±574 | 198±144 | Prolonged intubation and ICU | | | 1
| | | | | Nonfunct Aden | | 1 | 2 | | | | | | | P=0.072 | | Hypotension and ICU | | | 1
| | | | | Pheo | | 1 | 1 | | | | | | | | | CHF | | | 1
| | | | | | | | | | | | | | | | | Grp2 (3/14) Retroperitoneal hematoma | | | 1
| | | | | | | | | | | | | | | | | (no treatment needed)
| | | | | | | | | | | | | | | | | Abdominal hematoma and transfusion | | | 1
| | | | | | | | | | | | | | | | | Wound infection at trocar site | | | 1
Staren 1996 97015733 | ND | | | Grp1: 9.2(2–25) | See next column—authors describe those as indications. No pathology report is offered. | | | | | | Grp 1 | Grp 2 | OT | Grp1 177 (137–299) | Grp2 206 (90–341) | | ND
| | | | Grp2: 3.8(1–8) | | | | | Pheo | | 12 | 7 | BL | ND
| | | | | | | | | Adrenocortical CA | | 4 | 0
| | | | | | | | | Cortical Adenoma | | 2 | 8
| | | | | | | | | Cushing' disease | | 1 | 0
| | | | | | | | | Aldosteronoma | | 1 | 5
| | | | | | | | | Cyst | | 0 | 1
Mugiya 1996 97128195 | ND | | | 3.8 (1.8–7.5) | All incidentalomas | | | | Grp1Grp2 | | | | OT | Grp1 131±50 | | | Grp1 ND
| | | | | | | | | Adrenocortical Adenoma | | 2 | 6 | | Grp2 197±35 | | | Grp2
| | | | | | | | | Ganglioneuroma | | 2 | 1 | BL | Grp1 251±213 | | | Bleeding necessitating transfusion of 2 units (1)
| | | | | | | | | Adrenocortical Hyperplasia | | 1 | 3 | | Grp2 130±209
| | | | | | | | | Cyst | | 1 | 0
| | | | | | | | | Mets | | 1 | 0
| | | | | | | | | Myelolipoma | | 0 | 1
Bonjer 1997 97315759 (Grp1 and Grp3 are subsets of Bonjer 1998) | ND | | | Grp1: 3.0 | ND, None, analgesic requirement by Medication Quantification Scale | | | | | Grp1 | 2 | 3 | | | OT | BL | Short term - staph sepsis due to phlebitis (1), fever unknown origin (1)
| | | | Grp2: 3.0 | | | | | Cushing's aden | 4 | 2 | 6 | Grp1 | | 60^d^ | 175^e^ | Long term - Grp1: pain at 7 & 14 no (2)
| | | | Grp3: 4.0 (median) | | | | | Conn's aden | 3 | 4 | 2 | Grp2 | | 150^f^ | 150^e^
| | | | | | | | | Pheo | 0 | 0 | 3 | Grp3 | | 75 | 20
| | | | | | | | | Incidentaloma | 2 | 1 | 1 | (median)
| | | | | | | | | Virilizing tumor | 0 | 2 | 0
Linos 1997 97228299 | ND | | | Grp1 8.07 | See Pathology | | | | | Grp1 | Grp2 | Grp3 | OT | | | | [underlined: Grp1]
| | | | Grp2 5.25 | | | | | Pheo | 24 | 10 | 3 | Grp1 155.3 | | | | Transfusion | | | 7
| | | | Grp3 4.03 | | | | | Adrenal Carcinoma | 10 | 0 | 0 | Grp2 108.6 | | | | Splenectomy | | | 4
| | | | | | | | | Cushing's | 8 | 16 | 5 | Grp3 116.1 P<0.0002 for Grp 2 or 3 vs. Grp 1 | | | | Wound infection | | | 1
| | | | | | | | | Conn's | 4 | 11 | 3 | BL ND but transfusions | | | | [underlined: Grp2]
| | | | | | | | | Adrenal adenoma | 12 | 10 | 4 | Grp1 8.1% | | | | Pleural tears | | | 3
| | | | | | | | | Adrenal cyst | 2 | 5 | 1 | Grp2 3.2% | | | | Transfusion | | | 2
| | | | | | | | | Myelolipoma | 4 | 3 | 0 | Grp3 5.5% | | | | Hematoma | | | 1
| | | | | | | | | Nodular hyperplasia | 5 | 6 | 0 | | | | | [underlined: Grp3] One patient converted to open. One transfused
| | | | | | | | | Metastatic CA | 0 | 0 | 2
Aldrighetti 1997 97472886 | % | Grp1 | 2 | Grp1 4.6±0.3 | All incidentaloma | | | | All adenomas (see exclusion criteria) | | | | OT | | | | [underlined: Grp1]
| HTN | 17 | 50 | Grp2 3.4±0.4 | | | | | | | | | Grp1 174±18 | | | | Wound infection | | | 2
| Respiratory dis | 17 | 13 | P=0.03 | | | | | | | | | Grp2 150±18 p=0.12 | | | | [underlined: Grp2]
| Dep | 0 | 38^g^ | | | | | | | | | | BL ND | | | | Arrhythmias | | | 2
| Previous Surg | 17 | 0 | | | | | | | | | | | | | | (SVT treated with meds & Afib converted spontaneously)
| R. sided tumor | 75 | 75
Vargas 1997 97291406 | ND | | | Grp1 11.5±4 | | | Grp1 | 2 | ND | | | | OT | | | | | | Grp1 | 2
| | | | Grp2 13.9±6 | Aldo- Steronoma | | 11 | 11 | | | | | Grp1 178±17 | | | | Chronic pain | | 1 | 1
| | | | Volume P=ns | Cushing's Synd | | 2 | 2 | | | | | Grp2 193±14 p=0.29 | | | | Wound inf. | | 1 | 0
| | | | | Pheo | | 6 | 6 | | | | | BL | | | | Incision hernia | | 2 | 0
| | | | | Adrenal Ca | | 1 | 1 | | | | | Grp1 283±62 | | | | Partial bowel obstruction | | 1 | 0
| | | | | | | | | | | | | Grp2 245±52 p=0.58 | | | | Fluid collection & drainage | | 0 | 1
| | | | | | | | | | | | | Transfusions | | | | P=0.41 for all morbidity
| | | | | | | | | | | | | Grp1 3 Grp2 1 p=.60
Jacobs 1997 97336426 | ND | | | Grp1 2.5±1.2 | | Grp | 1 | 2 | ND | | | | OT | | | | Grp1 Arrhythmia and medical treatment | | | 1
| | | | Grp2 3.3±1.9 | Aldo- Steronoma | | 9 | 4 | | | | | Grp1 164±107 | | | | Grp2
| | | | p=0.34 | Cushing's Synd | | 4 | 3 | | | | | Grp2 151±63 p=NS | | | | Pneumonia | | | 1
| | | | | Pheo | | 3 | 5 | | | | | BL | | | | Sig.Atelectasis | | | 2
| | | | | Nonfunct Mass | | 3 | 5 | | | | | Grp1 109±75 | | | | Wound infection | | | 2
| | | | | Mets | | 0 | 2 | | | | | Grp2 263±242 p=0.02 | | | | Prolonged ileus | | | 1
| | | | | | | | | | | | | Transfusions Grp1=0 | | | | P=0.04 for all complications
| | | | | | | | | | | | | Grp2=1 (3 uints)
Ishikawa 1997 97426050 | ND | | | Grp1 2.6±1.3 | Grp | 1 | 2 | 3 | ND | | | | OT | | | | ND
| | | | Grp2 2.1±0.5 | Aldo- Steronism | 7 | 5 | 0 | | | | | Grp1 185±19
| | | | Grp3 4.2±1.5 | Cushing's Synd | 4 | 2 | 2 | | | | | Grp2 99±29
| | | | P=0.01 for 3 vs. 1 | Pheo | 0 | 0 | 6 | | | | | Grp3 143±35 p=0.01
| | | | | Nonfunct mass | 3 | 2 | 2 | | | | | BL
| | | | | | | | | | | | | Grp1 92±46
| | | | | | | | | | | | | Grp2 126±54
| | | | | | | | | | | | | Grp3 407±285 p=0.01
| | | | | | | | | | | | | grp3 vs.grp1
Korman 1997 97463970 | ND | | | Grp1 2.9±2.0 | Grp | | 1 | 2 | ND | | | | OT | | | | [underlined: Grp1]
| | | | Grp2 6.1±2.8 | Aldo- Steronoma | | 1 | 4 | | | | | Grp1 164±47 | | | | Prolonged ileus | | | 1
| | | | | Cushing's Synd | | 2 | 2 | | | | | Grp2 124±29 p=0.03 | | | | Adrenal insufficiency | | | 1
| | | | | Pheo | | 5 | 2 | | | | | BL | | | | [underlined: Grp2]
| | | | | Adrenal Ca | 0 | 1 | | | | | | Grp1 118±158 | | | | Prolonged ileus | | | 1
| | | | | | | | | | | | | Grp2 210±173 p=0.23 | | | | Pneumothorax | | | 1
| | | | | Mets | | 1 | 1
| | | | | Primary cyst | | 1 | 0
Thompson 1997 98087809 | None | | | 2.9 | % | Grp | 1 | 2 | ND | | | | OT | | | | Grp1 Early 18% incl pneumotx, pleural effusion, atelectasis, seizures and urinary retention.Late 58% incl chronic incisional pain, muscle laxity and numbness
| | | | 2.9 | Aldosteronoma | | 50 | 48 | | | | | Grp1 127 | | | | Grp2 Early 6% Trocar site bleed, pulmonary edema, UTI, DVT and pancreatitis. Late 0%.
| | | | | Cushing's Synd | | 20 | 20 | | | | | Grp2 167 | | | | P=0.25 for early 0.0001 for late
| | | | | Nonfunct Aden | | 16 | 12 | | | | | P < 0.0002
| | | | | Pheo | | 14 | 20 | | | | | BL (transfusions)*
| | | | | | | | | | | | | Grp1 0
| | | | | | | | | | | | | grp2 2
| | | | | | | | | | | | | P= NS
Yoshimura 1998 99110579 (See Miyake above) | ND | | | Grp1 1.9 | Grp | | 1 | 2 | ND | | | | OT | | | | [underlined: Grp1]
| | | | Grp2 3.7 | Aldosteronoma | | 19 | 10 | | | | | Grp1 376±30 | | | | Transfusion | | | 4
| | | | | Cushing's Synd | | 4 | 5 | | | | | Grp2 133±1 p<0.0001 | | | | Subcutaneous emphysema | | | 4
| | | | | Pheo | | 1 | 7 | | | | | BL | | | | Minor bleeding | | | 2
| | | | | Myelo- lipoma | | 2 | 0 | | | | | Grp1 370±134 | | | | [underlined: Grp2]
| | | | | Gangli-neuroma | | 1 | 0 | | | | | Grp2 345±84 p=NS | | | | Transfusion | | | 2
| | | | | Nonfunct aden | | 1 | 1 | | | | | Transfusion | | | | Chest tube | | | 3
| | | | | Adrenal CA | | 0 | 1 | | | | | Grp1 4 Grp2 2 p=NS | | | | NG tube | | | 2
| | | | | Adrenal cyst | | 0 | 1
Ting 1998 98307710 | ND | | | Grp1 1.8 | Grp | | 1 | 2 | ND | | | | Medians | | | | Grp1 None
| | | | Grp2 1.6 | Aldosteronoma | | 9 | 46 | | | | | OT | | | | Grp2 9%
| | | | P= NS | Cushing's synd | | 2 | 9 | | | | | Grp1 160 Grp2 120 | | | | Hemorrhage | | | 2
| | | | | Nonfunct aden | | 1 | 1 | | | | | P<0.01 | | | | Pneumothorax | | | 1
| | | | | | | | | | | | | BL | | | | Chest infection | | | 1
| | | | | | | | | | | | | Grp1 50 Grp2 150 | | | | UTI | | | 1
| | | | | | | | | | | | | P<0.01 | | | | Numbers too small for comparison
Winfield 1998 98343464 | ND | | | Grp1 1.8 | | Grp | 1 | 2 | Same as preop. | | | | OT | Grp1 309(185–480) | | | Intraop
| | | | Grp2 2.5 | Aldosteronoma | | 16 | 6 | | | | | | Grp2 233(165–310) | | | Grp1 3/21 = 14%
| | | | P=0.20 | Cushing's Synd | | 0 | 1 | | | | | | P=0.001 | | | Injury to vessel | | | 1
| | | | | Nonfunct Aden | | 3 | 2 | | | | | (total OR time) | | | | Splenic capsule injury | | | 1
| | | | | Pheo | | 0 | 7 | | | | | BL | Grp1 183(30–500) | | | Pleurotomy | | | 1
| | | | | Virilizing tumor | | 0 | 1 | | | | | | Grp2 266(100–600) | | | Grp2 1/17 = 6% | | | 1
| | | | | Mets | | 2 | 0 | | | | | | P=0.085 | | | Sig.Hemorrhage | | | 1
| | | | | ASA class | | 2.6 | 2.8 | | | | | Transfusions | Grp1 0 | | | Post-op
| | | | | | | | | | | | | | Grp2 1 | | | Grp1 3/21 = 14%
| | | | | | | | | | | | | P=0.862 | | | | Fever <48 hrs | | | 1
| | | | | | | | | | | | | | | | | Incisional pain | | | 1
| | | | | | | | | | | | | | | | | Subcutaneous bleed requiring 2 units | | | 1
| | | | | | | | | | | | | | | | | Grp2 11/17 = 65% Fever <48 hrs | | | 3
| | | | | | | | | | | | | | | | | Pneumothorax | | | 2
| | | | | | | | | | | | | | | | | Pulmonary edema | | | 1
| | | | | | | | | | | | | | | | | Atalectasis | | | 1
| | | | | | | | | | | | | | | | | Prolonged ileus | | | 1
| | | | | | | | | | | | | | | | | Urinary retention | | | 1
| | | | | | | | | | | | | | | | | Anemia | | | 1
| | | | | | | | | | | | | | | | | Persistent flank pain | | | 1
Bonjer 1998 99065956 | ND | | | Grp1: 3.0 | ND | | | | | | Grp1 | Grp2 | | | OT^h^ | BL^h^ | Short term - Grp1:
| | | | Grp2: 3.0 | | | | | Cushing's dis | | 11 | 11 | Grp1 | | 60 | 125 | wound infection | | | 3
| | | | | | | | | Cushing's aden | | 11 | 11 | Grp2 | | 90 | 20 | hematoma | | | 2
| | | | | | | | | Conn's aden | | 8 | - | | | | | neuralgia | | | 1
| | | | | | | | | Pheo | | 8 | - | | | | | incisional hernia | | | 1
| | | | | | | | | Incidentaloma | | 1 | 2 | | | | | pumonary embolism | | | 1
| | | | | | | | | | | | | | | | | Grp2: hematoma | | | 3
| | | | | | | | | | | | | | | | | (1 drained, 2 resolved spontaneously)
Soares 1999 99088300 | Previous Lap | | | TLA 2.0 (1–4) | | | TLA | Open | ND | | | | TLA 116 (72–164) min | | | | TLA Bleeding from short gastric vessel requiring transfusion and reop. | | | 1
| TLA | | 1 | Open 6.4 (1.5–11) | Pheo | | 1 | 3 | | | | | Open 166 (95–306) | | | | Open - No complications
| Open | | 4 | p=0.0005 | Conn's | | 7 | 1 | | | | | P=0.03
| P=0.11 | | | | Cushing's | | 1 | 1 | | | | | TLA 132 (50–300) cc
| | | | | Cortical hyper | | 0 | 1 | | | | | Open 278 (125–500)
| | | | | Nonfunct aden | | 2 | 1 | | | | | P=0.01
| | | | | Myelo-lipoma | | 0 | 1
Dudley 1999 99290915 | ND | | | Grp1: (1.0 – 5.0) | Analgesic requirements not compared as strategy changed over study period | | | | | | Grp1 | Grp2 | OT | | | | Short term - Grp1:
| | | | Grp2: (1.6 – 8.2) | | | | | Viriliz'g tumor | | 1 | 1 | Grp1: 85 | | | | wound infection | | | 3
| | | | | | | | | Cushing's syndrome (adenoma/hyperplasia) | | 4 | 5 | Grp2: 158 | | | | chest infection | | | 5
| | | | | | | | | Cushing's disease (ectoic ACTH) | | 7 | 6 | 2 patients each from both groups need 2 units of blood | | | | pressure sore | | | 1
| | | | | | | | | Conn's (adenoma) | | 2 | 5 | | | | | renal failure | | | 1
| | | | | | | | | Pheo | | 1 | 13 | | | | | urinary infections | | | 2
| | | | | | | | | | | | | | | | | Grp2:
| | | | | | | | | | | | | | | | | wound infection | | | 1
| | | | | | | | | | | | | | | | | port site hernia | | | 1
| | | | | | | | | | | | | | | | | Long term - ‘still under review’
Schell 1999 99088298 | ND | | | ND | Grp | | 1 | 2 | ND | | | | ND | | | | Grp1 None
| | | | | Aldosteronoma | | 7 | 1 | | | | | | | | | Grp2 3/19 = 16%
| | | | | Cushing's Synd | | 3 | 0 | | | | | | | | | Fat necrosis and wound dehiscence | | | 1
| | | | | Cushing' dis | | 1 | 0 | | | | | | | | | Urinary retention | | | 1
| | | | | Pheo | | 4 | 7 | | | | | | | | | Prolonged ventilation and tracheostomy | | | 1
| | | | | Nonfunct aden | | 4 | 5
| | | | | Adrenal CA | | 0 | 4
| | | | | Viriliz'g adenoma | | 1 | 1
| | | | | Other | | 0 | 1
Imai 1999 99383703 | ND | | | Grp1 2.8±1.7 | Grp | | 1 | 2 | ND | | | | OT skin-to-skin (34 patients) | | | | Grp1 2/40 = 5%
| | | | Grp2 2.7±1.4 | Aldosteronoma | | 16 | 17 | | | | | Grp1 180 | | | | Pneumothorax | | | 2
| | | | | Cushing's Synd | | 6 | 7 | | | | | Grp2 127 | | | | Grp2 20/40 = 50%Pneumothorax | | | 1
| | | | | Nonfunct aden | | 10 | 9 | | | | | P < 0.0001 | | | | Pneumothorax | | | 1
| | | | | Pheo | | 8 | 7 | | | | | BL (all cases) | | | | Chronic incisional pain | | | 19
| | | | | | | | | | | | | Grp1 40 grp2 162
| | | | | | | | | | | | | P < 0.0001
Hobart 1999 99419925 (May overlap with Gill 1999) | ND | | | Grp1: 3.0 | Grp | | 1 | 2 | ND | | | | OT | | | | ND
| | | | Grp2 3.7 | Aldosteronoma | | 8 | 6 | | | | | Grp1 163±39
| | | | | Nonfunct aden | | 4 | 3 | | | | | Grp2 136±24
| | | | | Pheo | | 3 | 3 | | | | | P=0.098
| | | | | Cushing's Synd | | 0 | 3 | | | | | BL ND
Shen 1999 99294292 | ND | | | ND | All aldosteronomas | | | | % | | Grp 1 | 2 | ND | | | | Grp1 11%
| | | | | | | | | Aldosteronoma | | 84 | 98 | | | | | Hypotension and anemia | | | 2
| | | | | | | | | Hyperplasia | | 13 | 2 | | | | | Acidosis and hypokalemia | | | 2
| | | | | | | | | Carcinoma | | 3 | 0 | | | | | Grp2 0% p<0.05
Inabnet 2000 20246760 | | | | Grp1 4.1±1.2 | All patients had pheo | | | | No malignancies | | | | OT | | | | Grp1 No complications
| | | | Grp2 4.6±1.2 | | | | | | | | | Grp1 146±36 | | | | Grp2 1/11 = 9% Incisional hernia
| | | | p=NS | | | | | | | | | Grp2 153±55 p=NS
| | | | | | | | | | | | | BL ND
| | | | | | | | | | | | | Grp2 1 transfusion (2u)
Hobart 2000 20233461 | | | | Adrenal size | ND on indication | | | | Grp | 1 | 2 | 3 | OT | | | | Grp1 21% Transfusion | | | 3
| | | | Grp1 8.0 | Grp | 1 | 2 | 3 | Hyperplasia | 0 | 0 | 15 | Grp1 205 | | | | Grp2 50% Pneumothorax | | | 2
| | | | Grp2 7.8 | ASA Score | 3.2 | 3 | 3 | Adenoma | 2 | 4 | 21 | Grp2 216 | | | | Ileus | | | 3
| | | | Grp3 2.2 | | | | | Carcinoma | 4 | 0 | 0 | Grp3 158 | | | | Hypertension | | | 3
| | | | P<0.001 for 1 vs. 3 | | | | | Pheo | 5 | 7 | 6 | P = 0.07 3 vs. 1 | | | | Transfusion | | | 3
| | | | | | | | | Metastases | 1 | 0 | 2 | BL | | | | Grp3 9%
| | | | | | | | | Other | 2 | 1 | 1 | Grp1 400 | | | | Dysrhythmia | | | 1
| | | | | | | | | | | | | grp2 584 | | | | Hypertension | | | 1
| | | | | | | | | | | | | grp3 113 | | | | Transfusion | | | 2
| | | | | | | | | | | | | P < 0.009 3 vs. 1
Rayan 2000 20349754 | | | | Grp1 3.3±1.9 | % | | Grp1 | 2 | ND | | | | OT | | | | Grp1 5% Fever requiring readmission.
| | | | Grp2 5.2±2.9 | Aldosteronoma | | 58 | 12 | | | | | Grp1 198 | | | | Grp2 29% Overall
| | | | p<0.01 | Cushing's Synd | | 16 | 10 | | | | | Grp2 228 p=0.12 | | | | Fever | | | 13
| | | | | Nonfunct aden | | 5 | 19 | | | | | ND on BL | | | | Phlebitis | | | 6
| | | | | Pheo | | 5 | 40 | | | | | | | | | Epidural cath site Infection | | | 2
| | | | | Other ASA score | | 16 | 19 | | | | | | | | | Ileus | | | 2
| | | | | | | | | | | | | | | | | Atrial fibrillation | | | 2
| | | | | | | | | | | | | | | | | IVC thrombosiS | | | 2
| | | | | | | | | | | | | | | | | Perforated duodenal ulcer | | | 2
Sprung 2000 20165080 | | Grp1 | 2 | ND | All patients had Pheo | | | | ND | | | | OT | | | | ND
| HTN | 16 | 13 | | | | | | | | | | Grp1 196±69 | | | | Treatment for hypotension-
| Dm | 3 | 2 | | | | | | | | | | Grp2 177±59 | | | | Grp1 9
| CAD | 1 | 0 | | | | | | | | | | P < 0.3 | | | | Grp2 1 | | p<0.02
| CHF | 2 | 0 | | | | | | | | | | BL (median) | | | | Treatment for hypertension
| | | | | | | | | | | | | Grp1 400 grp2 100 | | | | Grp1 17 | | grp2 13
| | | | | | | | | | | | | P < 0.001 | | | | p=NS
| | | | | | | | | | | | | When surgeon estimated BL as minimal, author assumed 100 for grp2 and 200 for grp1.

a p<0.001 grp3 vs grps 1 &2

b approx

c Grade by Clavien 1992

d p=0.004

e p=0.014

f p=0.005

g p=0.04; others not significant

-4 p<10

Evidence Table 9. Surgical complications of open vs. endoscopic adrenalectomy techniques - Part III

Study, Year Identifier | Postoperative analgesia | Days hospitalized (mean), Days to recovery (how defined) | | | Mortality | Comments, Biases or limitations
Prinz 1995 95266961 | Doses of meperidine | Grp1 2.1±0.9 p<0.001 Grp1 v other 2 grps. | | | None | Non-randomized trial.One surgeon assigned the patients according to his preference. Larger tumors and pheos got into grp2.
| Grp1 1.4±1.1 p<.0001 | Grp2 6.4±1.5
| Grp2 15.8±6.4 | Grp3 5.5±2.9
| Grp3 14.7±7.5 | ND on recovery
Guazzoni 1995 95230788 | Ketoprofen Grp1 320 | Grp1-- 9 Grp2 3.4 | | | None | First 11 laparoscopy patients appear in Guazzoni 1995. Mean age listed in article is not the mean of the listed ages.
| Grp2 175 | Return to work
| Meperidine Grp1 4 patients | Grp1--16 Grp2--9.7
| Grp2 0 patients
Brunt 1996 96269426 | Total parenteral morphine, mg | Grp1: 8.7 p ≤ 0.01 compared to grp3 | | | 1 patient with CAD history from Grp1 at day 4 post-op due to MI | MEN-2A/2B patients - Grp1 (10) & Grp3 (7); previous abdominal operations (3) contributed to increased operating times for 2 patients for the laparoscopic group; significantly less pain meds for laparoscopic (2 patients had no meds) vs open surgery groups (p ≤ 0.001); bilateral procedures - Grp1(3), Grp2(2), Grp3 (3)
| Grp1: 142^i^ | Grp2: 6.2 p ≤ 0.001 compared to grp3
| Grp2: 54^i^ | Grp3: 3.2,
| Grp3: 15.9 | Grp3: 10.6
| *p≤ 0.01 grp3 vs grp 1 & 2 | (prospective recovery follow-up for 17 patients)
MacGillivray 1996 97020136 | ND | Grp1 7.9±4.9 | | | None
| | Grp2 3.0±1.6 p<0.002
| | First oral intake
| | Grp1 3.0±2.1
| | Grp2 1.0±0.4 p<0.002
| | Return to regular activities
| | Grp1 14.6±4.9
| | Grp2 8.9±3.7
Staren 1996 97015733 | ND | Grp1 6.1 (4–8) | | | None | Group one combines both abdominal and posterior approaches.
| | Grp2 2.2 (1–7) p<0.01
Mugiya 1996 97128195 | ND | Days hospitalized—ND | | | None | May contain a subset of Suzuki 1995. Suzuki is second author on this paper and series is collected at the same time as Suzuki.
| | | Grp1 | Grp2
| | Oral intake | 2.7±1.1 | 1.4±0.7
| | Ambulation | 4.4±2.4 | 1.2±0.4
| | Full recovery | 16.1±5.2 | 4.0±1.0
Bonjer 1997 97315759 | Grp1: 34* | Grp1: 6 p=0.024 | | | None | 2 pheo intraoperative SBP < 150mmHg & pulse < 140 per min; Grp 1 conversions to laparotomy (2), tears of peritoneum in Grp 2 (6), pain meds using Medication Quantification Scale by Masters-Steedman.
| Grp2: 20* | Grp2: 6 p=0.027
(Grp1 and Grp3 are subsets of Bonjer 1998) | Grp3: 46 | Grp3: 4(median)
| *p=0.0003 | (median)
| | ND
Linos 1997 97228299 | Grp1 3.4 days anesthesia | Grp1: 8 days (2–25) | | | None | 1 patient in lap group converted to open anterior and included in the interior group for analysis purposes (i.e. not intention-to-treat). Patients with cancer stayed in hospital longer and tended to have anterior approach, but even without these cases grp1 mean hospital days = 7.7. (This is according to the author but the number seems suspect since nearly 1/3 of grp1 patients. Had cancer and a mean LOS of 11 days.)
| Grp2 2.3 days | Grp2: 4.5 days (1–11)
| Grp3 1.1 days | Grp3: 2.3 days (1–5)
| P=0.02 grp3 vs grp1 or 2. | P=0.01 for grp2 vs. grp3 and
| | P=0001 for grp2 vs. grp1
Aldrighetti 1997 97472886 | Grp1 3.0 d | Grp1 7.9±1.0 | | | None | Authors adjust for tumor size, BMI and depression and find it increases the difference between Grp1 and 2. Not clear what adjustment they made and does not have face validity since tumor size in Grp1 is larger. (Author argues that smaller tumor size makes tumor harder to locate).
| Grp2 1.7 d p=0.012 | Grp2 5.3±0.4 p=0.0002
| | Days of ileus
| | Grp1 3.5±0.2
| | Grp2 2.3±0.2 p=0.006
Vargas 1997 97291406 | Morphine required (mg) | Grp1 7.2±0.6 d | | | None | Pheos were successfully treated by laparoscopy. Learning curve demonstrated decreasing OT as learner did more laparoscopies.
| Grp1 94±30 | Grp2 3.1±0.3 d p<0.0001
| Grp2 36±8 p=0.02 | Convalescence
| | Grp1 7±1 wk
| | Grp2 3±0.6 wk p<0.0001
Jacobs 1997 97336426 | ND | Grp1 2.3±0.9 | | | None | Total cost grp1 $10929 Grp2 $13720 p=0.1
| | Grp2 5.1±1.7 p=0.0001 | | | | Grp1 had higher supply charge with p=0.001.
| | ND on recovery
Ishikawa 1997 97426050 | Mean doses | Time to walking (hrs) | | | None
| Grp1: 3.1±0.7 | Grp1 18±2.8
| Grp2: 4.9±1.5 p=0.02 | Grp2 26±3.6 p=0.05
| Grp3: 6.8±1.1 p=0.01 | Grp3 41±12 p=0.01
Korman 1997 97463970 | Days of meds | Grp1 4.1±2.5 | | | None | Total cost for Grp1 $8188±3660
| Grp1: 1.9±1.8 | Grp2 5.9±1.1 p=0.05 | | | | Grp2 12840±6576 p=0.08
| Grp2: 3.4±1.0 p=0.04 | | | | | Grp1 had more pheos, removing pheos from analysis shortened OR time for grp1 and reduced BL so that grp1 was significantly less than grp2.
Thompson 1997 98087809 | Morphine equivalents | Grp1 5.7 | | | None | Not clear how study was designed. Appears controls were chosen retrospectively, but were given complications questionnaire. Was the questionnaire part of another prospective study to look at complications of PA?
| Grp1 48 | Grp2 3.1 p<0.0001 | | | | Patient satisfaction with LA was 9 vs. 7 for PA (1–10) p < 0.0001
| Grp2 28 p=0.002 | Return to normal | | | | Median hospital charges were $7,000 for vs 6,000 for PA p=0.05
| | Grp1 7 weeks
| | Grp2 3.8 weeks p<0.0001
Yoshimura 1998 99110579 (See Miyake above) | Grp1: 2.7±0.5 | Grp1: 12±0.7 | | | None | This study contains all the laparoscopic cases from Miyake 1998 (above) and compares them to historical controls. Hospital LOS is very long in all cases. No explanation given.
| Grp2: 3.4±0.4 p=NS | Grp2: 18.2±3.5 p<0.05
| | Walking
| | Grp1 2.2 grp2 4.1 p<0.0001
| | Oral intake
| | Grp1 1.6 Grp2 2.4 p<0.0005
Ting 1998 98307710 | Median parenteral dose | Medians | | | None
| Grp1: 0 (0–100) | Grp1 3 (2–5)
| Grp2: 225 (0–525) | Grp2 5 (2–17) p<0.01
| P<0.01 | Return to work
| | Grp1 11 (4–28)
| | Grp2 26 (12–36) p<0.01
Winfield 1998 98343464 | Mean parenteral morphine | Grp1 2.7 (2–9) | | | None
| Grp1 32.7 Grp2 74.3 p=0.1 | Grp2 6.2 (4–10) p<0.001
| Mean oral morphine | First oral intake
| Grp1 14.8 Grp2 28.8 p<0.001 | Grp1 0.3 d Grp2 2.5 p<0.001
| | Convalescence
| | Grp1 3.1 wk Renal transplant donors 6.5 p< 0.001
Bonjer 1998 99065956 | Grp1: 3.0 | Grp1: 7 | | | None | Conversions: 2 endoscopic adrenalectomies converted to lumbotomy, 18 in Grp2 with tears of peritoneum, 12 (Grp1–5, Grp2–7) with bilateral disease, pain meds: Grp1–3.0 & Grp2–1.0 using Medication Quantification Scale by Steedman.
| Grp2: 1.0 | Grp2: 4
| p = 0.0005 | p<0.0001
| | ND
Soares 1999 99088300 | Mean morphine | Grp1 2.1 | | | None | No significant difference in mean hospital charges grp1 $13,570 grp2 $26,516 but very small sample size.
| Grp1 23mg | Grp2 5.4 p=0.0004
| Grp2 108mg p=0.0002 | Regular diet
| | Grp1 1.7
| | Grp2 4.6 p=0.001
Dudley 1999 99290915 | Analgesic requirements not compared due to changes in pain relief strategies for both sites during study | Grp1: 8.5 | | | 1 patient with end-stage Cushing's disease had bilateral laparoscopic died at day 8 but no post-op complications | Conversion: 1 pheo & 1 Cushing (ectopic ACTH) from the Grp2, 1 pheo from Grp1 to laparotomy; 5 Conn's in Grp2 had no complications
| | Grp2: 3.5,
| | ND
Schell 1999 99088298 | ND | Grp1 1.7±1.0 | | | None (One patient with metastatic disease died 45 days post-op at home) | OR charges were similar for gp1 $3501 and gp2 $3317. Total hospital charges gp1 $8,698 and gp2 $12,610 (p=0.03).
| | Grp2 7.8±6.7 p<0.0001
| | Regular diet
| | Grp1 1.6±1.0
| | Grp2 6.1±6.9 p<0.0001
| | Independent activity
| | Grp1 1.6±1.0
| | Grp2 7.9±7.3 p<0.0001
Imai 1999 99383703 | Doses | Grp1: 12 | | | None | OR time is skin to skin for 34 patients who had only adrenalectomy.Other 6 patients had multiple procedures.In all 40 patients measuring skin-to-removal has the same p value. Hospital costs grp1 $7,000 grp2 $8,000 p=NS Authors note that hospital stays in Japan are much longer than in US or Europe because hospital cost per day in Japan is very low and patients expect to go home when fully recovered.
| Grp1 2.9 | Grp2: 18 p < 0.0001
| Grp2 5.8 p< 0.0001 | First solid food
| | Grp1 1.3
| | Grp2 1.3
| | Ambulatory
| | Grp1 1.3
| | Grp2 1.5 p =NS
Hobart 1999 99419925 (May overlap with Gill 1999) | ND | Grp1: 1.0±0.3 | | | None | Needlescopic approach had higher intraoperative cost but 18% lower cost overall because of extremely short post-op stay.
| | Grp2: 7.0±1.9
| | P < 0.0001
Shen 1999 99294292 | ND | ND | | | ND | Authors note that populations are different. LA patients are older and with less advanced disease.CT scan may pick up disease earlier, and PCP's may refer earlier knowing LA is available.
Inabnet 2000 20246760 | Days of morphine | Grp1: 5.5±2.2 | | | None | Intraoperative hypertension was higher in grp1 during insufflation but not during dissection, vein ligation or after tumor removal.Patients were not randomized, but two groups had similar size tumors and same pathology.
| Grp1 1.3±0.8 | Grp2: 6.1±1.6 p=NS
| Grp2 2.2±1.2 p<0.05
Hobart 2000 20233461 | Morphine (mg) | Grp1: 2.4 | | | None | 2 patients converted from lap to open in grp1, and 2 converted from retroperitoneal to combined. In grp3 only 1/45 converted to open.
| Grp1 24 | Grp2: 7.7 p<0.001 vs. 1 | | | | 9.9 months of follow-up in group1 with no recurrence of malignancy (but follow-up may be too short).
| Grp2 748 p<0.001 vs. 1 | Grp3: 1.5 p=0.01 vs. 1
| Grp3 19 p=0.03 vs. 1 | Days until PO liquids
| | Grp1 1.3
| | Grp2 3.8 p<0.001 vs. 1
| | Grp3 1 p=0.08 vs. 1
Rayan 2000 20349754 | ND | Grp1: 1.5 | | | None | Not randomized.Higher proportion of aldosteronomas which are easy to resect in the lap group.
| | Grp2: 6.3
| | P<0.001
Sprung 2000 20165080 | ND | Grp1: 7.5 | | | None | One patient with severe hypertensive response was converted to open and included with open patients.Estimate of blood loss is biased toward laparoscopy as noted in the column.
| | Grp2: 3.0 p < 0.0001
| | Ambulating
| | Grp1 4
| | Grp2 1.5 p < 0.002
| | Resuming diet
| | Grp1 3.5
| | Grp2 1.0 p<0.0001

i p ≤0.01 grp3 vs grp 1 &2

Evidence Table 10. Surgical complications of comparative endoscopic adrenalectomy techniques-Part I

Study, Year Identifier | Demographics | Inclusion Criteria | Exclusion Criteria | Study design, Enrollment yrs | Procedure/approach
Fernandez-Cruz 1996 97122978 | Country: Spain | Obese patients with Cushing's syndrome or Cushing's disease | ND | Prospective RCT of transperitoneal and retroperitoneal approaches “Extended over a 2-year period” but date not given. | Transperitoneal 7(10)
| Setting: Academic | | | | Retroperitoneal 8(11)
| Mean age: 45 (16–74)
| Enrolled: 15 (21)
| Evaluated: 15 (21)
| 13% Male
| Race: ND
Duh 1996 96316844 | Country: US | Consecutive cases | ND | Prospective, non-randomized. 1993-1996 | Grp1 Lateral transperitoneal
| Setting: Academic | | | | Grp2 Posterior retroperitoneal
| Mean age: 49 (5–78) y
| Enrolled: 37 (36 patients)
| Evaluated: 37
| 42% Male
| Race: ND
Miyake 1998 98216395 | Country: Japan | Laparoscopy for benign adrenal tumors | Procedure could not be completed because of adhesions (2 patients) | Case series 1992-1997 | Grp1 Laparoscopic Transperitoneal | 17
| Setting: Academic | | | | Grp2 Laparoscopic Retroperitoneal | 12
| Mean age: 42.0 (5–62) y
| Enrolled: 31
| Evaluated: 29
| 45% Male
| Race: ND
Gill 1998 98361244 | Country: US | ND | ND | Case series with prospective data collection for grp1 1997-1998 and retrospective controls from 1996-1997. | Grp1: Needlescopic transperitoneal flank approach | 15
| Setting: Academic | | | | Grp2: Transperitoneal laparoscopic | 21
| Median age:
| Grp1–60 y
| Grp2–52 y
| Enrolled: 36
| Evaluated: 36
| Grp1 79% Male
| Grp2 48% Male
Fernandez-Cruz 1999 99088313 (May have included data from previous Fernandez-Cruz publications) | Country: Spain | All laparoscopic adrenalectomies | 20 excluded because of Pheo | Case series 1992-1997 | Grp1
| Setting: Academic | | | | Lap. Transperitoneal | 19
| Mean age: | | | | Grp2
| Grp1 35.6±21.8 y | | | | Lap. Retroperitoneal | 17
| Grp2 46.8±19.5 y
| Enrolled: 55(62)
| Evaluated: 36(42)
| Grp1 42% Male
| Grp2 35% Male
| Race: ND
Henry 1999 99407199 | Country: France | 150 consecutive lap. Grp1 had tumors <4 cm and benign. Grp2 had larger tumors, metastases and malignant appearing tumors on CT or MRI | Invasive, extraadrenal CA | Consecutive cases divided into two groups by tumor size and appearance. Comparison of outcomes. 1994-1998 | Laparoscopic, approach not specified.
| Setting: Academic | | Large and/or malignant tumors | | Grp1 102
| Mean age: ND | | Multiple or extra-adrenal pheo | | Grp2 48
| Enrolled: 150 | | Previous surgery in adrenal area
| Evaluated: 150
| ND % Male
| Race: ND
Terachi 2000 20370711 | Country: Japan | ND | ND | ND 1992-1996 | Grp1-transperitoneal | 311
| Setting: Academic | | | | Grp2-retroperitoneal | 59
| Mean age: ND
| Enrolled: 370
| Evaluated: 370
| ND % Male
| Race: ND
Takeda 2000 20370713 | Country: Japan | ND | ND | Retrospective 1992-1997 | Grp1 TPA 52
| Setting: Academic | | | | Grp2 RPA 24
| Mean age: 46.7 y
| Enrolled: 76
| Evaluated: 76
| 41% Male
| Race:
Suzuki 2001 21351140 (Mostly subset of Suzuki 1999) | Country: Japan | ND | ND | Non-randomized. | Grp1 TPA 46
| Setting: Academic | | | Approach based on tumor size. | Grp2 LTPA 32
| Mean age: 51.7 y | | | 1992-1997 | Grp3 RPA 40
| Enrolled: 115 | | | Single Surgeon Background matched analysis for subset of patients
| 50% Male
| Race:

Evidence Table 10. Surgical complications of comparative endoscopic adrenalectomy techniques-Part II

Study, Year Identifier | Co-morbidities | Mean tumor size (cm) | Pre-operative diagnoses, ASA classification | | | | Pathology | Operative time (min), Blood loss (ml) (mean) | | Complications
Fernandez-Cruz 1996 97122978 | ND | Overall 5.3 | Cushing's synd | | | 9 | Same | OT 105±19 Retroperit | | Fever 2 (trans)
| | Transperitoneal 5.4 | Cushing's dis | | | 6 | | 89±23 Transperitoneal
| | Retroperitoneal 5.3 | | | | | | for adenoma
| | | | | | | | 305±49 retro
| | | | | | | | 272±47 trans
| | | | | | | | for Cushing's disease
| | | | | | | | BL 180±84 retro
| | | | | | | | 160±74 trans
| | | | | | | | for adenoma
| | | | | | | | 370±86 retro
| | | | | | | | 407±139 trans
| | | | | | | | for Cushing's disease
| | | | | | | | No transfusions in any group
Duh 1996 96316844 | ND | Grp1: | Grp | | 1 | 2 | ND | Grp1 226 min | | Multisystem organ failure and death in patient with ectopic ACTH syndrome
| | 5.3 (1–13) | Aldosteronism | | 10 | 18 | | Grp2 202 min | | Left-sided nerve root pain for 3 months (2)
| | Grp2: | Pheo | | 3 | 4 | | ND on blood loss. One patient needed transfusion | | Left rib pain from positioning (1)
| | 2.6 (1–6) | Cushing synd | | 2 | 6
| | | R/o cancer | | 5 | 6
| | | Others | | 3 | 0
Miyake 1998 98216395 | ND | Grp1 | Grp | | 1 | 2 | ND | OT | | Grp | 1 | 2
| | 1.92±1.0 | Aldosteronoma | | 11 | 9 | | Grp1 423±184 | | Injury to vessel | 1 | 0
| | Grp2 | Cushing's synd | | 2 | 1 | | Grp2 300±73 | p<0.01 | Post-op bleeding | 0 | 2
| | 1.96±0.6 | Pheo | | 1 | 0 | | BL | | Transfusion | 3 | 1
| | | Myelolipoma | | 1 | 1 | | Grp1 406 | | Subcutaneous emphysema | 4 | 0
| | | Ganglioneuroma | | 0 | 1 | | Grp2 164 | p<0.05
| | | Nonfunct aden | | 1 | 0
| | | Primary aldosteronism | | | +
| | | Cushing's | | 1 | 0
Gill 1998 98361244 | ND | Wt in gms | Grp | | 1 | 2 | ND | OT | | Grp1 8%
| | Grp: 41.6 | Aldosteronoma | | 9 | 16 | | Grp1 169 (130–210) | | Cutaneous hyperesthesia | | 1
| | Grp2: 15.7 | Nonfunct aden | | 3 | 3 | | Grp2 220 (114–400)
| | P<0.001 | Pheo | | 2 | 0 | | P=0.050
| | | Mets | | 1 | 2 | | BL | | Grp2 29%
| | | | | | | | Grp1 61 grp2 183 | | Splenic capsule injury | | 1
| | | | | | | | P<0.002 | | Vessel injury | | 1
| | | | | | | | | | Pleurotomy | | 1
| | | | | | | | | | Incisional pain | | 1
| | | | | | | | | | Fever | | 1
| | | | | | | | | | Subcutaneous bleed | | 1
| | | | | | | | | | P=0.2
Fernandez-Cruz 1999 99088313 (May have included data from previous Fernandez-Cruz publications) | ND | ND | Grp | | 1 | 2 | ND | OT | | Grp1
| | | Aldosteronoma | | 6 | 5 | | Grp1 88.75±22.7 | | UTI | | 2
| | | Cushing's synd | | 5 | 5 | | Grp2 105.0±18.7 | | | Grp2
| | | Cushing's dis | | 6 | 6 | | P value not given | | None reported
| | | Nonfunct aden | | 5 | 4 | | BL
| | | | | | | | Grp1 160 grp2 180
| | | | | | | | P value not given
Henry 1999 99407199 | ND | Grp1 2.1 | Grp | | 1 | 2 | Grp1 all benign | OT | | Grp1 8/102 = 8%
| | Grp2 5.2 | Aldosteronoma | | 56 | 0 | Grp2 6 malignant (3 converted to open surgery) | Grp1 131 | | Peroperative bleed | | 1
| | | Cushing's synd | | 33 | 5 | 3 metastases | Grp2 129 | | Peritoneal hematoma | | 2
| | | Nonfunct aden | | 2 | 28 | 1 leiomyosarcoma | P < NS | | Parietal hematoma (All 4 required reop) | | 1
| | | Pheo | | 11 | 14 | 2 adrenocortical CA | BL ND | | Spleen infarction with spontaneous regression | | 1
| | | Androgen tumor | | 0 | 1 | | | | Pneumothorax | | 1
| | | | | | | | | | DVT | | 1
| | | | | | | | | | Grp2 4/48 = 8%
| | | | | | | | | | Peroperative bleed | | 2
| | | | | | | | | | Peritoneal hematoma and reoperation | | 1
| | | | | | | | | | Tumor effraction | | 1
Terachi 2000 20370711 | ND | ND | Aldosteronoma | | | 155 | ND | ND | | [underlined: Intra-op] Grp | 1 | 2
| | | Cushing's synd | | | 61 | | | | Vascular injury
| | | Pre-Cushings | | | 21 | | | | Vena Cava | 2 | 0
| | | Nonfunct aden | | | 87 | | | | Renal Vein | 2 | 0
| | | Pheo Complicated | | | 16 | | | | Adrenal | 3 | 1
| | | Cyst | | | 10 | | | | Other adrenal | 8 | 3
| | | Myelolipoma | | | 9 | | | | Other vessels | 3 | 0
| | | Adrenal CA | | | 4 | | | | Organ Injury
| | | Other | | | 7 | | | | Liver | 4 | 0
| | | | | | | | | | Spleen | 2 | 1
| | | | | | | | | | Pancrease | 0 | 2
| | | | | | | | | | Gall bladder | 1 | 0
| | | | | | | | | | Adrenal gland | 1 | 0
| | | | | | | | | | Total | 8% | 12%
| | | | | | | | | | [underlined: Post-op]
| | | | | | | | | | Bleeding | 5 | 1
| | | | | | | | | | RP chylocele | 1 | 0
| | | | | | | | | | Wound
| | | | | | | | | | infection | 4 | 0
| | | | | | | | | | Atalectasis | 3 | 0
| | | | | | | | | | Pneumo-Thorax | 1 | 0
| | | | | | | | | | Hypercapnia | 2 | 1
| | | | | | | | | | lleus | 2 | 0
| | | | | | | | | | Peritonitis | 1 | 0
| | | | | | | | | | Cardiovascular | 1 | 0
| | | | | | | | | | Compartment syndrome | 1 | 0
| | | | | | | | | | Delirium | 1 | 0
| | | | | | | | | | Total | 7% | 3%
| | | | | | | | | | 3.5% converted to open (2.7% emergently)
Takeda 2000 20370710 | ND | ND | Grp | | 1 | 2 | ND | OT 206±81 | | There were no major complications. Subcutaneous emphysema, transient oliguria, headache and nausea
| | | Aldosteronoma | | 37 | 11 | | 260±79
| | | Cushing's Synd | | 19 | 6 | | BL 153±116
| | | Nonfunct Aden | | 15 | 7 | | 116±98
| | | Pheo | | 5 | 0 | | p=NS for both
Suzuki 2001 21351140 (Mostly subset of Suzuki 1999) | ND | 3.8±0.4 | Grp | 1 | 2 | 3 | ND | 201.1 | 175 | No major complications
| | 3.5±0.4 | Aldosteronoma | 24 | 36 | 39 | | 122.9 | 118 | [underlined: Grp1]
| | 2.3±0.2 | Cushing's Synd | 38 | 40 | 44 | | 174.6 | 176 | Angina | | 1
| | p<0.00 | Nonfunct Aden | 32 | 12 | 11 | | p<0.0001 1 or 3 v.2 | | Atalectasis | | 1
| | 4 1vs.3 | Pheo | 6 | 12 | 6 | | 147.0 | 81 | Mild paralytic ileus | | 1
| | p<0.02 | Background matched subset only | | | | | 68.1 | 49 | Subcut emphysema | | 1
| | 4 2vs.3 | | | | | | 60.7 | 58 | [underlined: Grp2]
| | | | | | | | p= NS | | Shoulder tip pain | | 4
| | | | | | | | | | Mild ileus | | 1
| | | | | | | | | | Pneumotx | | 1
| | | | | | | | | | Grp3
| | | | | | | | | | Shoulder tip pain | | 2
| | | | | | | | | | Subcutaneous emphysema | | 2

Evidence Table 10. Surgical complications of comparative endoscopic adrenalectomy techniques-Part III

Study, Year Identifier | Postoperative analgesia | Days hospitalized (mean), Days to recovery (how defined) | Mortality | Comments, Biases or limitations
Fernandez-Cruz 1996 97122978 | 3.3 trans 3.5 retro | 2.8±0.8 retro | None | May include some patients from the Fernandez-Cruz article above, though difficult to tell. Note that bilateral operations take substantially longer, have greater blood loss and longer hospital stay. Most other studies didn't break this out by type.
| | 3.0±0.7 trans unilateral | | Retroperitoneal approach may have an advantage in that patients absorb less CO2 during the operation, since surface area in retroperitoneal space is less.
| | 6.7±2.1 retro | | Transperitoneal patients had rise in arterial BP during the operation, but outcomes were similar.
| | 6.0±1.6 trans bilateral
| | Time to normal activity
| | 12.3±2.2 retro
| | 12.5±3.5 trans unilateral
| | 19.3±2.05 retro
| | 19.7±3.7 trans bilateral
Duh 1996 96316844 | ND | Grp1: 2.2 d (1–5) | 1 died of multi-organ failure
| | Grp2: 1.5 d (1–4)
Miyake 1998 98216395 | Grp1: 2.9±2.3 | Grp1 12.8±4.0 | None
| Grp2: 2.3±2.9 p=NS | Grp2 10.3±3.7
| | Walking
| | Grp1 2.3 grp2 1.9
| | Oral intake
| | Grp1 1.8 Grp2 1.6
| | None are significant
Gill 1998 98361244 | Morphine | Grp1 1.1 Grp2 2.7 p<0.001 | None | 1 needlescopic converted to laparoscopic because of disorientation early in the series. No cases converted to open.
| Grp1 1.8 | Convalescence (wk)
| Grp2 47.5 | Grp1 2.1 Grp2 3.1 p<0.001
Fernandez-Cruz 1999 99088313 (May have included data from previous Fernandez-Cruz publications) | Doses of ketorolac 30 mg | Grp1: 3±0.7 | None | Author measured pCO2 during operation as well as blood pH to see if either method had less affect on CO2 absorption (similar to his other work). Both approaches had similar rises in blood CO2 and decreases in pH which were managed by appropriate ventilator adjustment.
| Grp1 3.25±0.83 | Grp2: 2.8±0.8
| Grp2 3.5±1.1 p not given | Normal activity
| | Grp1 12.5±3.5
| | Grp2 12.3±2.1 p not given
Henry 1999 99407199 | ND | Grp1: 5.6 | None | Conversion rate in two groups grp1 4.9%, grp2 6.2%. All patients were well at follow-up.
| | Grp2: 5.1
Terachi 2000 20370711 | ND | ND | None | Multicenter trial focusing solely on complications. Not clear which other series it may contain.
Takeda 2000 20370710 | ND | ND | ND
| | Until eating
| | 1.9±0.9
| | 1.1±0.2 p=NS
| | Until Walking
| | 1.4±1.1
| | 1.6±0.7 p=NS
Suzuki 2001 21351140 (Mostly subset of Suzuki 1999) | ND | ND | None | In conducting background matched analysis author excluded all conversions, the first 20 operations, patients with tumors > 5 cm and one patient. With prolonged stay due to retroperitoneal hematoma (reporting bias).
| | Until eating
| | 2.4±0.6 1.5±0.1 1.4±0.1
| | p=0.006 1 vs. 3 p=0.02 1 v. 2
| | Recuperation (days)
| | 4.7 4.8 4.2 p=NS

Evidence Table 11: Morbidity/mortality of adrenocortical carcinoma after surgical excision - Part I

Study, Year Identifier | Demographics | Inclusion Criteria | Exclusion Criteria | Study design, Enrollment yrs | Procedure/approach
Greenberg 1978 | Country: USA | Proven histological diagnosis of ACC | ND | Retrospective cohort | Resection (12)
78122233 | Setting: Academic | | | 1948 - 1975 | Adrenalectomy (A)
| Age: 11 mo-73 y | | | 19 from Tumor Registry of Charity Hospital, 3 from medical school affiliate hospitals | A/nephrectomy (N)
| Enrolled: 22 | | | | A/N/spenectomy
| Evaluated: 12 | | | | A/N/distal pancreatectomy
| 68% Male
| Race: ND
Sullivan 1978 | Country: USA | Histologically proven diagnosis of ACC | ND | Retrospective cohort | Resection | 20
79091488 | Setting: Academic | | | 1950 | Biopsy | 7
| Mean age: 42 (1–69) y
| Male 53
| Female 34
| Enrolled: 28
| Evaluated: 28
| 36% Male
| Race: ND
King 1979 | Country: USA | Clinical & histological records confirming diagnosis of ACC | ND | Retrospective cohort | Exploratory laparotomy (41)
79210894 | Setting: Military hospital registry | | | Jan 1956 – Dec 1977 | complete local resection
| Mean age: 34 (5 mo-77 y) | | | | incomplete resection (extensive local invasion)
| Male 38.2 | | | | incomplete local excision (palliative purposes)
| Female 28.7 | | | | biopsy only
| Enrolled: 49
| Evaluated: 49
| 53% Male
| Race: 100% White
Didolkar 1981 | Country: USA | Histological confirmation on the following: capsular & venous invasion, nuclear & cellular pleomorphism, frequency of mitotic figures, & presence of mets | ND | Retrospective cohort | Curative surgery (16)
81186052 | Setting: Academic | | | 1929 - 1977 | localized disease | 2
| Mean age: 53 (3–74) y | | | | locally invasion to adjacent structures | 14
| Enrolled: 42 | | | | Palliative surgery | 2
| Evaluated: 42
| 57% Male
| Race: White 40
| Black 2
Nader 1983 | Country: USA | Histologically proven ACC | ND | Retrospective cohort | Complete resection (35) of local or regional disease
83232657 | Setting: Academic | | | 1950 - 1981
(Sample is a subset of Venkatesh, 1989) | Mean age:
| Male 48.3 (25–71 y)
| Female 36.6 (5 mo-75 y)
| Enrolled: 77
| Evaluated: 77
| 49% Male
| Race: White 74
| Black 3
Henley 1983 | Country: USA | Primary surgical treatment of adrenal carcinoma | ND | Retrospective cohort | Curative resection | 31
94073723 | Setting: Tertiary referral ctr | | | 1960 - 1980 | Palliative resection | 14
| Mean age: | | | | Biopsy only | 17
| Male 53 y | | | | Total adrenalectomy (A) | 25
| Female 44 y | | | | A/nephrectomy (N) with or without splenectomy (S) | 12
| Enrolled: 62 | | | | A/S | 3
| Evaluated: 62 | | | | Partial adrenalectomy | 2
| 62% Male | | | | A/lymphadenectomy with or without S | 2
| Race: ND | | | | A/N/ tumor extraction from inferior vena cava | 1
Lefevre 1983 | Country: The Netherlands | Pediatric patients who underwent treatment for ACC | ND | Retrospective cohort | Complete resection | 31
| Setting: Unknown | | | 1958 - 1980 | Partial resection | 5
| Mean age: 4 y 7 mo | | | | No surgery | 5
| Enrolled: 42 | | | | ND | 1
| Evaluated: 42
| 38% Male
| Race: ND
Watson 1986 | Country: USA | Exploratory surgery for presumptive adrenal disease - Cushing's Syndrome, evidence of hypercortisolism | ND | Retrospective cohort | Overall surgical approach -
86318058 | Setting: Tertiary referral ctr | | | 1970 - 1979 | Anterior 72%
| Mean age: 55 y^a^ | | | | Posterior 28%
| Enrolled: 80
| Evaluated: 80
| 27% Male
| Race: ND
Nakano 1988 | Country: Japan | Data from Annual of the Pathological Autopsy Cases of histologically proven ACC | Not primary tumor or insufficient histological data | Retrospective cohort | Surgery - 16
88266734 | Setting: Academic | | | 1965 - 1982
| Mean age: 45.7 (4 mo-84 yr)
| Male 54.2 y
| Female 34.7 y
| Enrolled: 91
| Evaluated: 91
| 57% Male
| Race: ND
Venkatesh 1989 | Country: USA | Histologically proven ACC | ND | Retrospective cohort | Complete resection | (50)
89303739 | Setting: Academic | | | 1944 - 1987 | Local disease | 25
(Sample of Nader 1983 is a subset) | Mean age: 42.5 ± 16.1 y | | | | Regional disease | 25
| Female 38.0±17.9 (5 mo-75 y)
| Male 49.0±14.3 (4–70)
| Enrolled: 110
| Evaluated: 110
| 47% Male
| Race: ND
Borrelli 1989 | Country: Italy | Patients with ACC confirmed by histology who underwent surgery. | ND | Retrospective cohort | Adrenalectomy
89307915 | Setting: Academic | | | Site 1 - ‘past 17 yrs’ | Bilateral adrenalectomy
| Mean age: 37 (3–60) y | | | Site 2 - ‘past 3 yrs’ | Adrenalectomy/ nephrectomy
| Female 30 y | | | | Adrenalectomy/nephrectomy/splenectomy resection of tail of pancreas
| Male 53 y
| Enrolled: 14
| Evaluated: 14
| 29% Male
| Race: ND
Luton 1990 | Country: France | Histologically confirmed dx of ACC | ND | Retrospective cohort | 57 of 80 treated surgically were ‘curative procedures’
90220767 | Setting: Hospital | | | 1963 - 1987
(Possible overlap of patient sample with Icard 1992) | Mean age: 46 (6–81y; n=105)
| Enrolled: 105
| Evaluated: 88
| 29% Male (n=105)
| Race: ND
Ribeiro 1990 | Country: Brazil | Pediatric patients diagnosed with adrenocortical carcinoma confirmed by surgery or autopsy | ND | Retrospective cohort | Complete resection | 26
90111798 | Setting: Tertiary referral ctr | | | 1966 - 1987 | Uncomplete resection -
(Possible overlap of patient sample with Sabbaga 1993 and Sandrini 1997) | Median age: 3.9 (1 mo-15.7 y) | | | | Partial resection | 6
| Enrolled: 40 | | | | Biopsy only | 6
| Evaluated: 40
| 30% Male
| Race: ND
Grögndal 1990 | Country: Sweden | Patients who underwent treatment for ACC | ND | Retrospective cohort | Radical resection - 22
91071465 | Setting: Academic | | | 1974 - 1983 | Palliative resection - 12;
| Median age: (17–85) y | | | | Adrenalectomy (A)
| Female 56 y | | | | A/nephrectomy (N)
| Male 58 y | | | | A/N/partical pancreatectomy (P)
| Enrolled: 54 | | | | A/N/extractionof tumor from inferior vena cava
| Evaluated: 54 | | | | A/P
| 52% Male | | | | A/N/liver met resection
| Race: ND | | | | Surgical biopsy
| | | | | See Comments section
Padberg 1991 | Country: German, Belgium | Surgical specimens from adrenocortical tumors | ND | Retrospective cohort | ND
92027041 | Setting: Academic | | | ND
| Mean age: 45 (2–76) y
| Enrolled: 16
| Evaluated: 16
| 31% Male
| Race: ND
Soreide 1992 | Country: Norway | Histologically confirmed malig tumors originating from the adrenal cortex | ND | Retrospective and prospective cohort | Adrenalectomey
93033521 | Setting: Cancer registry | | | 1970 - 1985 | Adrenalectomy/nephroctomy
| Median age: 54 y
| Enrolled: 99
| Evaluated: 99
| 58% Male
| Race: ND
Icard 1992 | Country: France | Surgically treated cases of adrenocortical carcinoma based on initial histological exam | ND | Retrospective cohort | Adrenalectomy | 150
93088173 | Setting: 26 regional hospitals | | | 1/1978 – 3/1991 | Biopsy | 6;
(Possible overlap of patient sample with Luton 1990) | Mean age: 47±16 (17–79) y | | | | Subcostal or bisubcostal | 45%
| Enrolled: 156 | | | | Thoracophreno-laparatomy | 18%
| Evaluated: 156 | | | | Lombotomy | 10%
| 39% Male | | | | Other | 3%
| Race: ND | | | | Complete resection | 127
| | | | | Partial/palliative resection | 29
Pommier 1992 | Country: USA | Patients who underwent treatment for ACC | ND | Retrospective cohort | Complete resection - 53
93088172 | Setting: Academic | | | Jan 1980 – Dec 1999 | 67 primary operations
| Mean age:
| Female 43 y
| Male 37 y
| Enrolled: 73
| Evaluated: 73
| 38% Male
| Race: ND
Sabbaga 1993 | Country: Brazil | Pediatric ACC patients treated & followed for 2 yrs | ND | Retrospective cohort | Complete resection - 37
93922904 | Setting: Tertiary referral ctr | | | 1969 - 1991 | Partial resection - 7
(Possible overlap with Ribeiro 1990, Michalkiewicz 1997, and Sandrini 1997) | Mean age: 41<5 y, 17<2 y
| Enrolled: 55
| Evaluated: 55
| 24% Male
| Race: Caucasian 51
Zografos 1994 | Country: USA | Histologically confirmed adrenal adenocarcinoma | ND | Retrospective cohort | Surgery - 41
94231773 | Setting: Teriary referral ctr | | | Jan 1950 – Dec 1990 | Complete resection - 24
| Median age: 51 (21–75) y
| Enrolled: 53
| Evaluated: 53
| 57% Male
| Race: ND
Kasperlik-Zahuska 1995 | Country: Poland | Histologically confirmed adrenocortical carcinoma | ND | Retrospective cohort | Surgical procedures - 48
95254450 | Setting: Academic | | | 1965 - 1994 | Partial hepatectomy 4
| Mean age: 40.9±15.3 y
| Female 38.2±13.7 (13–70) y
| Male 53.1±18.1 (20–76) y
| Enrolled: 52
| Evaluated: 50
| 19% Male
| Race: ND
Lee 1995 | Country: USA | Primary surgical resection for ACC | ND | Retrospective cohort | Complete resection | 16
96089027 | Setting: Academic | | | 1965 - 1991 | Partial resection | 1
| Mean age: 36 (13–68) y | | | | Distant met unresected | 6
| Enrolled: 23 | | | | Adrenalectomy (A) | 6
| Evaluated: 23 | | | | A/ipsilateral nephrectomy | 7
| 48% Male | | | | Regional surgical procedures
| Race: ND | | | | Hepatic resection | 6
| | | | | Resection and/or open thrombectomy of inferor vena cava | 4
| | | | | Splenectomy | 4
| | | | | Pancreatic resection | 2
| | | | | Intestinal resection | 1
Boscaro 1995 | Country: Italy | Patients who underwent treatment for ACC | ND | Retrospective cohort | Complete adrenalectomy | 26
95379652 | Setting: Academic | | | 1978 - 1993 | Unresectable | 9
(Overlap of patient sample with Barzon 1998) | Median age: 40 (17–69) y | | | | exploratory surgery | 3
| Female 36 (17–67) y | | | | not operable | 6
| Male 44 (18–69) y
| Enrolled: 35
| Evaluated: 35
| 43% Male
| Race: ND
Evans 1996 | Country: USA | Excision of adrenal neoplasm, histologic materials, confirmation of adrenal cortical tumor, minimum 5 yr follow-up | ND | Retrospective cohort | ACC cases -
96143468 | Setting: Academic | | | ND | Adrenalectomy | 29
| Median age^b^: 41 (5 mo-66 y) | | | | Nephroadrenalectomy | 19
| Enrolled: 56
| Evaluated: 56
| 40% Male*
| Race: ND
Sandrini 1997 | Country: Brazil | Pediatric cases of adrenocortical tumor based on gross & histological appearance of tissue obtained from surgery | ND | Retrospective cohort | Complete resection - 47
97358147 | Setting: Tertiary referral ctr | | | 1966 - 1992 | Partial resection - 1
(Possible overlap of patient sample with Ribeiro 1990, Sabbaga 1993, and Michalkiewicz 1997) | Median age: 4.3 (3 d - 15.7 y) | | | | Inoperable - 10
| Enrolled: 58
| Evaluated: 58
| 29% Male
| Race: ND
Michalkiewicz 1997 | Country: USA | Pediatric cases of adrenocortical tumors ≤ 200 cm^3^ and/or wt ≤ 100 g | ND | Retrospective cohort | Complete resection in all cases
97176972 | Setting: Academic | | | May 1988 – Dec 1999
(Possible overlap of patient sample with Sabbaga 1993, and Sandrini 1997) | Mean age: 2 yr (0.3 – 4 y)
| (ACC cases)
| Enrolled: 20
| Evaluated: 20
| 0% Male
| Race: ND
Barzon 1998 | Country: Italy | ACC confirmed by Weiss histology critieria | ND | Retrospective cohort | Surgery of at least total adrenalectomy - 45; complete resection in 18
9805828 | Setting: Academic | | | 1978 - 1995
(Overlap of patient sample with Boscaro 1995) | Median age: 40 (17 – 75) y
| Female 36 (17 – 67)
| Male 44 (18 – 75)
| Enrolled: 45
| Evaluated: 45
| 42% Male
| Race: ND
Khorram-Manesh 1998 | Country: Sweden | Consecutive cases of ACC who underwent surgery | ND | Unclear retrospective or prospective cohort | Adrenalectomy (A) | 9
98260227 | Setting: Academic | | | Jan 1975 – Dec1997 | A/partial liver resecton | 1
| Mean age: 53±3 (36 – 76) y | | | | Adrenonephrectoy | 3
| Enrolled: 18 | | | | A/nephrectomy (N)/splenectomy (S) | 1
| Evaluated: 18 | | | | A/N/S/distal pancreatectomy (D) | 1
| 56% Male | | | | A/liver lobectomy (L) | 1
| Race: ND | | | | A/N/S/D/L | 1
| | | | | A/L/caval wedge resection | 1
Teinturier 1999 | Country: France | Pediatric cases treated for adrenal tumors | ND | Retrospective cohort | Macroscopic complete resection - 45
99133697 | Setting: Pediatric hospital | | | 1973 - 1993 | Microscopically incomplete resection - 9
| Median age: 4 (5 mo - 16 y)
| Enrolled: 54
| Evaluated: 54
| 50% Male
| Race: ND
Harrison 1999 | Country: USA | Patients who underwent curative adrenalectomy | ND | Retrospective cohort | Curative adrenalectomy - all cases
99148327 | Setting: Tertiary referral ctr | | | 1986 - 1996
| Median age: 49 (22 – 77) y
| Enrolled: 46
| Evaluated: 46
| 35% Male
| Race:
Driver 1999 | Country: UK | Cases of adrenocortical tumors from the Manchester | ND | Retrospective cohort | Curative resection - 3
99058793 | Setting: NA | Children's Tumour | | 1954 - 1995 | Palliative procedure - 11
| Mean age: 70 mo (8–180) | Registry for northwest | | | including1 biopsy
| Enrolled: 18 | England - includes all malignant & some benign tumors for ages < 15 yrs
| Evaluated: 14 (with ACC)
| 83% Male
| Race: ND
Tritos 2000 | Country: USA | Pathologcial confirmation of ACC | ND | Retrospective cohort | Resection of primary tumors - 24 (Curative 19);
20114774 | Setting: Tertiary referral ctr | | | 1966 - 1996 | Adrenalectomy (A) | 17
| Mean age: 51.5 (11 – 75) y | | | | A/nephrectomy or splenectomy | 6
| Enrolled: 31 | | | | A/nephrectomy/resection of lung met | 1
| Evaluated: 24^c^
| 48% Male
| Race: ND

a ACC only, n=15

b ACC cases (n=48)

c Patients with curative resection

Evidence Table 11: Morbidity/mortality of adrenocortical carcinoma after surgical excision - Part II

Study, Year Identifier | Co-morbidities | | Mean tumor size (cm) and/or weight (g) | Pre-operative diagnoses, Tumor staging | | | Pathology
Greenberg 1978 | ND | | ND | Stage 1: 5 (long term survivors) | | | Functioning tumors - 7
78122233 | | | | | | | (4 prepubertal patients)
| | | | | | | Nonfunctioning tumors - 15
Sullivan 1978 | ND | | 3.5 – 20 cm | Misdiagnoses of ACC include - | | | Functioning tumors - 13
79091488 | | | (70 – 1500g+) | Nonfunctional upper pole of kidney | | | Cushing and/or virilized | 12
| | | | Enlarged spleen | | | Hypertension & hypokalemia | 1
| | | | Pancreatic pseudocyst | | | Nonfunctioning tumors - 15
| | | | Renal carcinoma, | | | Mets including liver, lung, peritoneal cavity, bone & distant nodes
| | | | Stage^d^ I | 1
| | | | II | 5
| | | | III | 9
| | | | IV | 13
King 1979 | ND | | 12.4 cm | All 18 with functioning tumors had biochemical confirmation, 27 with no physical findings of endocrinopathy did not have urinary steriod test performed | | | Functioning tumors - 18 (11 females)
79210894 | | | (5 – 28.5) | | | | Cushing's syndrome | 8
| | | 848.6 g | | | | Virilization | 7♂
| | | (33 – 3100 g) | | | | Feminization with gynecomastia | 3♀
| | | Functional 11.9 cm^e^ | | | | Met - 29
| | | Nonfunctional 13.9 cm | | | | Liver | 27
| | | | | | | Lung | 23
| | | | | | | Peritoneum | 23
| | | | | | | Lymph nodes | 21
| | | | | | | Bone | 7
| | | | | | | Pancreas | 5
| | | | | | | Kidney, brain | 3
| | | | | | | Spleen, opposite adrenal | 2
| | | | | | | Heat, thyroid | 1
Didolkar 1981 | 2^nd^ primary cancers - | | 10* | Met - 22 | | | Functioning tumors - 10 (9 females)
81186052 | breast | 3 | (1 – 30) | (locally advanced - 17) | | | Cushing's synd | 5
| lymphoma | 2 | *meidan | | | | Cushing's synd /virilization | 3
| uterus | 1 | | | | | Virlization | 1
| colon | 1 | | | | | Feminization | 1
| thyroid | 1 | | | | | Nonfunctioning tumors - 32 (9 females)
| skin | 1
| seminoma | 1
| 1 patient with 3^rd^ dx of meningioma
Nader 1983 | 2^nd^ primary cancers - 6^f^ | | See Comments section | Staging at presentation^g^ | | | Functioning tumors - 26 (18 females)
83232657 | breast | | | Local | 3 | | Nonfunctioning tumors - 51 (21 females)
(Sample is a subset of Venkatesh, 1989) | melanoma | | | Regional | 10 | | Distant met (n=60)
| lymphoma | | | Distant metastases | 56 | | Lung | 43
| cervical | | | No evidence of disease | 8 | | Liver | 39
| sarcoma | | | | | | Peritoneal & pleural | 20
| thyoma | | | | | | Lymph node | 19
| papillary/ follicular | | | | | | Bone | 14
| cancer of thyroid | | | | | | Other adrenal | 8
| | | | | | | IVC | 6
| | | | | | | Spleen | 4
| | | | | | | Pancreas | 4
| | | | | | | Ovary | 2
| | | | | | | Brain | 3
| | | | | | | Sm intestine | 3
| | | | | | | Other kidney | 2
Henley 1983 | ND | | 12.4 | ND, | | | Functioning tumors - 36
94073723 | | | (56 tumors, 4 – 28.5) | Stage^h^ I | 1 | | Nonfunctioning tumors - 26
| | | | II | 20 | | Met | %
| | | | III | 8 | | Local | 42
| | | | IV | 33 | | Liver | 22
| | | | | | | Lung | 13
| | | | | | | Regional lymph | 5
| | | | | | | Distant lymph | 3
| | | | | | | Peritoneum | 5
| | | | | | | Bone | 3
| | | | | | | Sm bowel | 2
Lefevre 1983 | ND | | Surgical patients: ~334.9 g (n=35, 20 – 1400) | Virilization Cushing's synd | 39 | | Malignant | 22
| | | Alive (21): 162.3 g (median = 80 g, 20 – 1000+ g) | Cushing's synd | 16 | | Benign | 7
| | | Dead (14): 593.7 g (median = 510 g, 22 – 1400 g) | | | | Doubtful | 9
| | | Malignant cases ^6^ (18): | | | | Unknown | 4
| | | Alive (6): 338.3 g (median = 225 g, 30 – 1000+ g)
| | | Dead (12): 495.2g (median = 495.2 g, 22 – 1400 g)
Watson 1986 | ND | | ACC cases: | ND | | | Cushing's disease | 40
86318058 | | | 10.5 cm | | | | Adrenocortical adenoma | 25
| | | (5 ‘huge’ tumors) | | | | Adrenocortical carcinoma | 15
| | | 393 g | | | | Ectopic ACTH synd | 6
| | | (58 – 170 g) | | | | Unkown-probable ectopic ACTH synd 2
| | | | | | | Micronodular hyperplasia | 1
Nakano 1988 | ND | | 736.7 g | ND | | | Nonfunctioning tumors - 57 (16 females)
88266734 | | | (12 – 2900 g) | | | | Functioning tumors - 30 (22 females)
| | | Functional - | | | | Cushing's synd | 20
| | | 1010.5 g* | | | | Conn's synd | 2
| | | Nonfunctional - | | | | Adrenogenital synd | 8
| | | 718.9 g* NS | | | | ‘Obscure’ - 4 (1 female)
| | | | | | | Met
| | | | | | | Lung, Liver | 57
| | | | | | | Retroperitoneal lymph nodes | 44
| | | | | | | Peritoneal lymph nodes | 28
| | | | | | | Other adrenal gland | 25
| | | | | | | Mediastinal lymph nodes, Bone | 22
| | | | | | | Kidney | 20
| | | | | | | Cervical lymph nodes, GI | 14
| | | | | | | Brain, Peritoneum | 9
| | | | | | | Pancreas | 8
| | | | | | | Skin & soft tissue, Spleen | 7
| | | | | | | Inguinal lymph nodes, uogenital organs, heart, thyroid | 3
Venkatesh 1989 | 2^nd^ primary cancers - 13 | | ND | Staging at presentation^i^ | | | Functioning tumors - 39 (29 females)
89303739 | breast | 2 | | Local | 5 | | Nonfunctioning tumors - 71 (29 females)
(Sample of Nader 1983 is a subset) | melanomas | 2 | | Regional | 18 | | Met - 83
| thyroid | 2 | | Metastases | 77 | | Lung | 63
| Other:cervical, sarcoma, thymoma, laryngeal, lymphoma, squamous cell of skin, islet cell tumor of pancreas; | | | No evidence of disease | 8 | | Liver | 56
| | | | | | | Peritoneum, Lymph nodes | 23
| 1 w 3^rd^ cancer | | | | | | Bones | 18
| | | | | | | Other adrenal | 8
| | | | | | | Mediastinum | 5
| | | | | | | Spleen, Pancreas, Brain | 4
| | | | | | | Sm intestine, Other kidney | 3
Borrelli 1989 | ND | | (5.4 – 20.16 cm) | Met - 3 | | | Functioning tumors - 7
89307915 | | | Functional | Lung | 2 | | Virilization | 4
| | | 10 cm, 700 g | Liver & spleen | 1 | | Feminizing synd | 1
| | | Nonfunctional - | | | | Cushing's synd | 2
| | | 10.5 cm, 800 g | | | | Nonfunctioning tumors - 7
Luton 1990 | ND | | 532 g | N = 88 | | | Functioning tumors - 83
90220767 | | | (n=76;14 – 3000 g) | Local | 45 | | Nonfunctioning tumors - 22
(Possible overlap of patient sample with Icard 1992) | | | | Regional | 17 | | Met among 88 followed -Liver, Lung | 43
| | | | Met | 26 | | Adjacent organs/tissues | 41
| | | | | | | Bone | 13
| | | | | | | Pancreas | 4
| | | | | | | Sm bowel | 3
| | | | | | | Brain | 2
| | | | | | | Ovary, orbit, skin, pleura, spleen, & contralateral adrenal gland | 1
Ribeiro 1990 | ND | | 256 cm^3^ | ND | | | Functionting tumors - 39
90111798 | | | (n=31, 4.5 – 1190) | | | | Virilization 37
(Possible overlap of patient sample with Sabbaga 1993 and Sandrini 1997) | | | 236 g | | | | Met -Lung 4
| | | (n=26, 3 – 1320) | | | | Lung & liver 1
| | | | | | | 7/38 were >97% height; 9/38 were >97% weight
Gröndal 1990 | Thyrotoxicosis | 2 | Functional - | Met (25) - | [underlined: %] | | Functioning tumors - 21 (12 females)
91071465 | Diabetes | 3 | 13 cm* | Regional lymph nodes | 50 | | Cushing's synd | 9
| | | Nonfunctional - 15 cm* | Lung | 48 | | Cushing's synd/virilism | 3
| | | (5 – 40) | Liver | 26 | | Aldosteronism | 3
| | | *median | Bone | 21 | | Nonfunctioning tumors - 33 (14 females)
| | | | Brain | 4 | | Surgical group n=38:
| | | | Staging^j^ II | 24 | | Met | 16
| | | | III | 11 | | (hepatic hemangiomas 2)
| | | | IV | 65
Padberg 1991 | ND | | 750 g | ND | | | Functioning tumors - 10 (7 females)
92027041 | | | (20 – 3000 g) | | | | Cushing's synd
| | | | | | | Cushing's synd/virilization
| | | | | | | Cushing's synd/pubertas praecox
| | | | | | | Virilization
| | | | | | | Nonfunctioning tumors - 6 (Female 4)
Soreide 1992 | ND | | ND | Staging^k^ | | | Surgical cases -
93033521 | | | | Without met | 30 | | Functioning tumors | 17
| | | | Reg'l lymph nodes | 4 | | Nonfunctioning tumors | 44
| | | | Local invasion | 14
| | | | Distant met | 51
Icard 1992 | ND | | 12 ± 6 cm | Staging^l^ - | | | Functioning tumors - 82 (~60 females)
93088173 | | | (3 – 30, 137 tumors) | I | 8 | | Cushing's synd | 30
(Possible overlap of patient sample with Luton 1990) | | | 714 ± 861 g | II | 75 | | Cushing's synd/virilization | 19
| | | (12 – 4750, 133 tumors) | III | 39 | | Virlization Hypertension | 18
| | | | IV | 34 | | Feminization | 8
| | | | | | | Nonfunctioning tumors - 74 (33 females) | 2
Pommier 1992 | ND | | ND | Distant met in 18, 4 of which were completely resectable; | | | Functioning tumors - 44
93088172 | | | | Staging - | | | Cushing's synd | 22
| | | | I | 3 | | Cushing's synd/virilization | 5
| | | | II | 22 | | Virlization | 15
| | | | III | 20 | | Feminization | 1
| | | | IV | 24 | | Hyperaldosteronism | 1
| | | | | | | Nonfunctioning tumors - 29
| | | | | | | Met (Stage IV, n=53)
| | | | | | | Liver
| | | | | | | Lung
| | | | | | | Lymph nodes
| | | | | | | Bone
| | | | | | | Omentum/peritoneum
| | | | | | | laphram
| | | | | | | Other (skin, brain, palate, bowel, spleen)
Sabbaga 1993 | ND | | ND | Functioning tumors - 100% | | | Met - 20
93922904 | | | | Virilization & Cushing's synd | 40 | | Liver | 6
(Possible overlap with Ribeiro 1990, Michalkiewicz 1997, and Sandrini 1997) | | | | Virilization | 12 | | Lung | 5
| | | | Feminization | 1 | | Bone | 3
| | | | Asymptomatic | 2 | | Pancreas | 3
| | | | Met 10 | | | Brain | 2
Zografos 1994 | Acute myeloblastic leukemia 1 | | Right tumor -14 cm* | Functioning tumors - | 19 | | Mets - 58% (29/50)
94231773 | | | (8 – 30) | Cushing's synd | 14
| | | Left tumor - 11 cm* | Andrenogenital | 1
| | | (3 – 35) | Mixed | 4
| | | * median | Nonfunctioning tumors - | 30
| | | | Unknown | 4
| | | | Met
| | | | Brain | 2
| | | | Pulmonary | 1
| | | | Stage -
| | | | I | 6
| | | | II | 7
| | | | III | 11
| | | | IV | 29
Kasperlik-Zahuska 1995 | Uterine carcinoma | | n=10, 3.2–6 cm | Functioning tumors - 39 | 39 | | ND
95254450 | 1 | | n=15, 6.1–10 cm | Cushing's synd | 25
| | | n=28, > 10 cm | Virilization/hypertension | 8
| | | (3.2 – 20) | Virilization; | 2;
| | | | Local | 17
| | | | Regional | 15
| | | | Distant met | 20
Lee 1995 | ND | | n=15 | Stage^m^ - | | | Functioning tumors - | 15
96089027 | | | 14.5 cm | I | 1 | | Nonfunctioning tumors - | 8
| | | (1.7 – 25) | II | 8 | | Met (18)
| | | 920 g | III | 5 | | Lung | 10
| | | (99 – 3110) | IV | 9 | | Liver | 9
| | | | | | | Bone | 2
| | | | | | | Brain | 2
Boscaro 1995 | ND | | 12 cm | Met - 22 | | [underlined: %] | Functioning tumors - 26 (18 females)
95379652 | | | (4.5 – 21) | Lung | | 45 | Cushing's synd | 18
(Overlap of patient sample with Barzon 1998) | | | | Liver | | 36 | Cushing's synd/virilization | 6
| | | | Bone | | 32 | Cushing's synd/feminization | 1
| | | | Kidney | | 27 | Hyperaldosteronism | 1
| | | | Caval vein & pancreas | | 9 | Nonfunctioning tumors - 9 (4 females)
| | | | Contralateral adrenal,iliac vein & psoas | | 4
| | | | Stage^n^ -I | 1
| | | | II | 10
| | | | II&IV | 24
Evans 1996 | ND | | 15 cm^o^ | Distant met - 9 | | | Functioning tumors - 19
96143468 | | | (5.5 – 25, median 15),4 ‘large’ tumors, 1 size | Liver | 3 | | Cushing's synd | 11
| | | | Lung | 2 | | Cushing's synd/virilization | 5
| | | | Liver & lung | 2 | | Virilization | 2
| | | | Bone | 2 | | Aldosteronism | 1
| | | | | | | Nonfunctioning tumors 29
| | | | | | | Met (carcinoma & adenoma cases)
| | | | | | | Liver | 26
| | | | | | | Lung | 25
| | | | | | | Bone | 8
| | | | | | | Lymph nodes - regional | 7
| | | | | | | Lymph nodes - distant | 4
| | | | | | | Opposite adrenal | 4
| | | | | | | Diaphram, omentum, breast, orbit, sm bowel, brain, spleen | 1 each
Sandrini 1997 | ND | | ND | Stage - I | 3 | | Virilization in 40% (23)
97358147 | | | | II | 22
(Possible overlap of patient sample with Ribeiro 1990, Sabbaga 1993, and Michalkiewicz 1997) | | | | III | 4
| | | | IV | 8
| | | | Mets to liver, lungs & regional lymph nodes
| | | | Benign tumor - 5
| | | | Undeterminable - 2 or 11 (two classifications systems used)
Michalkiewicz 1997 | ND | | 68.5 cm^3^ | ND | | | ACC - low | 6
97176972 | | | (n = 11, 11 – 195) | | | | ACC - high | 4
(Possible overlap of patient sample with Sabbaga 1993 and Sandrini 1997) | | | | | | | ACC - nos | 2
| | | | | | | Virilization | 7
| | | | | | | Cushing's synd/virilization | 4
| | | | | | | Cushing's synd/virilization/lung met | 1
| | | | | | | (Adenoma 8)
Barzon 1998 | ND | | 11.1 ± 0.6 cm | Met - 45 | | [underlined: Percent] | Functioning tumors - 32
9805828 | | | (4 – 21) | Lung | | 67 | Cushing's synd | 21
(Overlap of patient sample with Boscaro 1995) | | | Functional - 11.2 | Liver | | 52 | Cushing's synd/virilization | 5
| | | Nonfunctional - 11 | Bone | | 32 | Virilization | 4
| | | | Kidney | | 27 | Cushing's synd/feminizing | 1
| | | | Caval vein | | 9 | Hyperaldosteronism | 1
| | | | Pancreas | | 9 | Nonfunctioning tumors - 13
| | | | Contralateral adrenal | | 9 | Met 6
| | | | Iliac vein | | 4
| | | | Psoas | | 4
| | | | Stage^p^ - I | 1
| | | | II | 14
| | | | III | 4
| | | | IV | 26
Khorram-Manesh 1998 | ND | | ~11.9 cm | Stage^q^ - | | | ND
98260227 | | | (19 tumors) | II | 10
| | | | III | 1
| | | | IV | 7
Teinturier 1999 | Hemihypertrophy - 3 | | 26 tumors < 10 cm* (local, complete resection) | Functioning tumors - 44 | | | ND
99133697 | Multiple cancers or family history suggesting Li-Fraumeni syndrome - 8 | | 28 tumors > 10 cm | Virilization | | 41
| pP53 mutation - 3 | | | Cushing's synd/virilization | | 8
| | | | Gynecomastia | | 3
| | | | Nonfunctioning tumors - 3
| | | | Stage^r^ -
| | | | I & II | 42 (local)
| | | | III | 5
| | | | Regional lymph nodes 2
| | | | Kidney invasion 1
| | | | Thrombosis of inferior vena cava 2
| | | | IV - Distant met (7)
| | | | Lung | 3
| | | | Liver & lung | 3
| | | | Met pleurisy | 1
Harrison 1999 | ND | | 15 cm | ND | | | ND
99148327 | | | (median, 2.5 – 27)
Driver 1999 | 2^nd^ primary tumors - 3 | | 8 – 25 cm | Functioning tumors - | | | ---
99058793 | | | | Virilization | 11
| | | | Cushingoid appearance 4 with virilization & cushingoid | 8
| | | | Precocious puberty | 4
| | | | Metastases - 8
| | | | Lung | 6
| | | | Liver | 3
| | | | Regional lymph nodes | 2
| | | | Local | 2,
| | | | ND
Tritos 2000 | ND | | 10 cm | Functioning tumors - | | | ND
20114774 | | | (median, n=31, 2 – 25) | (Female 10, NS)
| | | | Cushing's synd | | 13
| | | | Cushing's synd & feminization | | 1
| | | | Vrilization | | 1
| | | | Nonspecific symp/nonfunctioning | | 16
| | | | Stage^s^ I | 2
| | | | II | 9
| | | | III | 4
| | | | IV | 16
| | | | Met
| | | | Lung | 6
| | | | Liver | 5
| | | | Bone | 2
| | | | > 1 met site in 3 cases

d Staging system by Macfarlane, conducted retrospectively

e NS

rd 1 with 3 cancer

g SEER classification

h retrospective

i SEER classification

j TNM classification by Macfarlane-Sullivan

k Retrospectively staged-classification by Macfarlane-Sullivan

l Modified SEER criteria

m Modified Macfarlane criteria

n Macfarlane-Sullivan criteria

o ACC cases

p Modified SEER criteria

q Macfarlane criteria

r based on clinical, radx, surgical data

s TNM system

Evidence Table 11: Morbidity/mortality of adrenocortical carcinoma after surgical excision - Part III

Study, Year Identifier | Mean follow-up (range - mo) | Short term outcome, Mean survival | | Long term outcome, Mean survival | | | | Comments
Greenberg 1978 | ND | 30 day mortality - | | Resection - | | | | 8 dx confirmed at autopsy, 2 had biopsy; 2 groups by age - prepubertal (4) & patients (50s - 70s); males in older group more likely classified as having nonfunctioning tumors
78122233 | | 1 - with Cushing's syndrome 4 d from emerg op for intestinal obstructions, | | 5 yr survival 42.7% (5/12);
| | 1 - Staphylococcal sepsis 10 d after adrenalectomy, nephrectomy & splenectomy, | | Overall 5 yr survival 36% (5/14)
| | 1 – 4 wks had unresectable tumor,
Sullivan 1978 | (1 – 188) | ND | | Resection - 20 | | | | All males were > 39 yrs & 90% were stage 3 or 4 & in addition all males with nonfunctional tumor except 1 case; at least 1 patient refused operation; 1 had diagnosis confirmed at autopsy
79091488 | | | | 1 yr survival 75% (Stage 4 – 8%)
| | | | 2 yr survival 70%
| | | | 5 yr survival 30%
| | | | Stage 1 (1) alive at 150 mo
| | | | Overall 5 yr survival -
| | | | Stage 2 | 80%
| | | | Stage 3 | 11%
King 1979 | (1 mo - 21 yr) | --- | | Complete resection - of 21, 9 alive with no recurrence - avg 7.2 yrs postop (18 mo - 21 yr); 36 died with met avg 8.7 mo after dx (1 – 84 mo); NS for survival by males vs females (37.2 vs 35.3 mo) & by nonfunctioning vs functioning tumors (16% vs 22%); tumor size had no effect on survival duration | | | | Correct histopathologic diagnosis of ACC in 40 prior to death & 9 at autopsy; 6 had incorrect diagnosis of biopsy of met lesions; 2 had no operative intervention prior to death
79210894
Didolkar 1981 | 71 | Mortality at 2^nd^ day postop - cardiopulmonary complications | | Curative resection - | | | | Race ratio reflects the institute's overall ratio of referrals; 1 patient < 20 yr, 4 patients > 70 yr; data reported could not be verified
81186052 | (median, 1 – 301) | | | 5 yr survival 62%
| | | | 24 mo median survival from curative surgery to recurrence (1 – 120mo); overall survival 71 mo median (3 –301 mo);
Nader 1983 | ND | ND | | Complete resection - | | | | Of 18 with 5 yr survival, 10 had ‘large’ tumors (< 7 kg), tumor size unkn for 5, & 3 had met; tumors large enough to be palpated in 12; black to white ratio 3.9% vs institution's 7.9% during survey period
83232657 | | | | disease free at 2 yrs 47%;
(Sample is a subset of Venkatesh, 1989) | | | | Overall survival for all cases regardless of treatment should no difference by gender (p < 0.5) or clinically functioning vs nonfunctioning tumors (p < 0.3)
Henley 1983 | ND | 30 day mortality - | | Curative resection (stages I, II, III) - | | | | 1 LTF after 7 yr with no disease
94073723 | | hemorrhage from attempted resection | 2 | 5 yr survival - 32% (10/31)
| | advanced malig | 3 | Overall 5 yr survival 16% (10/62);
| | pulmonary embolus | 1 | Mortality of 51 (85%) - 19 mo
| | | | Mean survival: | Stage | Mo
| | | | | I | 25
| | | | | II | 24
| | | | | III | 28
| | | | | IV | 12
| | | | NS for survival by gender, grade, tumor sz or functional status, or age groups 40 or older & < 39; Signif for survival by stages I, II, III vs IV & curative vs noncurative resection, both p < 0.0001
Lefevre 1983 | 4.9 yr | ND | | Surgery cases: | | | | All 6 biopsy cases died
| (3 mo - 15 yr) | | | 1 yr survival 82.2% (27/34); 2 yr 63.6% (21/33)
| | | | Malignant surgical cases^6^:
| | | | 1 yr survival 78.9% (14/19); 2 yr 47.4% (9/19)
Watson 1986 | Follow up to 1/83 | Mortality - | | ACC survival - | | | | Tumor related mortality except for one case
86318058 | | Postop complications 1 | | 2 yr survival 33%,
| | (day 0) | | 1 alive at 96 months,
| | Carcinomatosis 1 (day 30) | | Mean survival 18.5 months
Nakano 1988 | ND | ND | | Surgical cases - | | | | Mean age for functioning, 24.2 vs 57.8 yr for nonfunctioning tumors
88266734 | | | | Mean survival 41.3 mo (SEM 14.9, median 15.8)
Venkatesh 1989 | ND | ND | | Complete resection - | 2 yr | | | Recurrences - 11 over 5 yr
89303739 | | | | | [underlined: Disease-free]
(Sample of Nader 1983 is a subset) | | | | 25 with local disease | 68% (17)
| | | | 25 with regional disease
| | | | Overall | 60%
Borrelli1989 | ND | Adrenal insufficiency & myocardial infarction - 2 with functioning tumors | | 2 yr survival 36% (5); | | | | 2 bilateral nonfunctioning tumors; LTF (1); Mortality - 7 (6 with mets, fwup time unk; mean age for patients with functioning tumors = 28 yrs, patients with nonfunctioning tumors = 45 yrs.
89307915 | | | | ‘avg’ survival for nonfunctioning tumor patients - 7.5 mo;
| | | | Still alive (4) ‘avg’ 30 mo with no clinical sign of recurrence
Luton 1990 | 24.9 | ND | | Curative surgery - median disease-free interval 12.1 mo (1 – 175); similar interval for functioning vs nonfunctioning tumors; regional disease at dx assoc with shorter disease-free period (p = 0.024); Median survival (n–88) 14.5 mo; 5 yr survival - 22%; NS for survival by sex, tumor wt, or functional status of tumor; significantly lower survival for >40 yr, p = 0.0035 & distant mets, p = 0.007 | | | | Of 105 dx, 88 treated at site, 80 surgically; ratio of functional vs nonfunctional tumors similar in each of 3 stages (local, regional, met)
90220767 | (median, 12; <1 – 175)
(Possible overlap of patient sample with Icard 1992)
Ribeiro 1990 | ND | ND | | 81.8% (18/22) with complete resection alive; | | | | 2 died prior to surgery; 5 LTF; data reported could not be verified
90111798 | | | | 11 of 12 inoperable tumors died;
(Possible overlap of patient sample with Sabbaga 1993 and Sandrini 1997) | | | | Overall survival 51.4%
Gröndal 1990 | 0.1 – 14 yr | ND | | Radical surgery - | | | | 16 had no surgery due to old age, poor physical condition, progressive met; median tumor sz 11 cm (6 – 19) for 10 long-term survivors (5–10 yr) & 13 cm (5 – 22) for other 12; tumor spill during operation associated with poor survival
91071465 | | | | Survival 45% alive & disease-free 5–10 yrs postop;
| | | | Palliative surgery -
| | | | median survival 10 mo - all died by 48 mo;
| | | | Overall 5 yr survival 19%;
| | | | Overall 5 yr survival by stage -
| | | | II | 54%
| | | | III | 16%
| | | | IV | 6%
Padberg 1991 | 34.4 mo | 30 day mortality - | | 7 alive disease-free 4 – 61 months postop; 2 alive with tumor at 28 & 90 months; 1 unrelated tumor death | | | | Study sample included additional 50 cases of adrenocortical adenoma
92027041 | (1 – 96) | 2 -carcinoma
Soreide 1992 | Fwup to 12/31/90 | 30 day mortality - none | | Curative resection - | | | | Of 99 patients, 18 diag from autopsy & 20 had nonsurgical tx without surgical exploration; surgical patients ‘tended to be younger’ than nonsurgical patients
93033521 | | | | 6 yr survival ~ 60%
Icard 1992 | FU to July 1991 | ND | | 5 yr survival - | | | | Complete follow-up except for 3 cases; 41 of 127 with curative resection had recurrences of which 22 had reoperation (survival - 38 mo), 10 curative, males averaged 5 yr older than females
93088173 | | | | Curative group 42% vs palliative group 9%, p < 0.02
(Possible overlap of patient sample with Luton 1990) | | | | Local disease 53%
| | | | Overall survival 34%;
| | | | 62 alive at end of study with 12 recurrences (mean survival 39 mo, 5–140)
| | | | | 5 yr survival | Mean survival
| | | | Stage I | 33% | 34
| | | | II | 55% | 40
| | | | III | 24% | 22
| | | | IV | 0% | 8
| | | | Significant differences between local, locoregional & met diseases, p < 0.001; NS for survival by sex, functional status, tumor wt or clinical presentation; survival associated with age < 40 yr (p = 0.05), & radical aspect of surgical resection (p < 0.0001)
Pommier 1992 | 28 (median) | Mortality 2 | | Complete resection - | | | | Unresectable in 20 - 14 had exploratory surgery & 6 were inoperable; staging incomplete for 4 with invasive tumors but without met, lymph nodes not excised or biopsied, but considered stage III; recurrent or met disease developed in 45 of 53 with complete resection - disease-free interval mean of ~2.5 yr
93088172 | | | | 5 yr survival 47%,
| | | | Mean survival 28 mo,
| | | | Overall survival:
| | | | mean 21 mo, 5 yr 35%, 10 yr 21%;
| | | | NS for survival by age, gender, or functional status of tumor;
| | | | | Mean survival (mo)
| | | | Stage I or II | 35
| | | | III | 26^t^
| | | | IV | 92^u^
Sabbaga 1993 | Minimum 2yr | ND | | 2 yr survival | | | | Local recurrence in 14 of 37 with complete resection - 38% with survival of 2; tumor sz not assoc with survival (complete sample)
93922904 | | | | complete resection - 68%
(Possible overlap with Ribeiro 1990, Michalkiewicz 1997, and Sandrini 1997) | | | | partial resection - no survivors
| | | | Overall survival - 46%
Zografos 1994 | ND | 4 deaths - | | | Median(mo)^v^ | 5 yr (%)^v^ | | Family history of cancer in 15 of 38 (40%); initial diagnosis prior to histologic proof inaccurate 91% (30/33); local recurrences in 15
94231773 | | Cardiac arrest t completion of operation | 1 | Complete resection | 13 | 38
| | Intraperitoneal bleeding 3^rd^ day postop | 1 | Partial resection | 2 | 0
| | Adrenal insufficiency 2^nd^ & 16^th^ day postop | 2 | Overall | 8 (0.03 – 372) | 19
| | | | Stage^w^ | median(mo) | 5 yr(%)
| | | | I | 46 | 33
| | | | II | 84 | 57
| | | | III | 8 | 18
| | | | IV | 7 7 (2 yr survival)
Kasperlik-Zahuska 1995 | ND | 30 day mortality - 1 | | 2 yr survival 29%; | | | | 2 died from met prior to surgery; 2 had no surgery, only meds; 4 had 2^nd^ surgery within 24 mo for cancer recurrence
95254450
Lee 1995 | 32 FU to Apr 1995 | Mortality (1) at 3 wks of multisystem organ failure from intraabdominal abscess postop | | | Median(mo) | 5 yr (%) | | 11 of 16 who underwent complete resection had recurrence
96089027 | | | | Complete resection | 46 | 46
| | | | Overall | 29
| | | | Local-regional dis (13 | 59
| | | | NS predictor of prognosis - gender, age, tumor wt or functional status; Advanced stage (p = 0.006) & incomplete resection (p = 0.004) were predictors for poor prognosis - all incomplete resections (7) died with median survival 8.5 mo
Boscaro 1995 | ND | Mortality - 3 | | Curative surgery group :
95379652 | | ‘…with very advanced disease died soon after surgery’ | | Median disease-free interval 24 mo (8 – 43)
(Overlap of patient sample with Barzon 1998) | | | | Overall median survival 14 mo; 5 yr survival - 10%;
| | | | Median survival:(12 – 102) | Stage I & II | 40
| | | | (1 – 108) | III & IV | 13
| | | | Sign. better prognosis for earlier stages, p < 0.05; NS survival rates with regards to sex, tumor wt or functional status
Evans 1996 | minimum 5y fwup | ND | | ACC cases - | | | | 48 diagnosed with ACC, 8 with adenomas; 1 LTF; recurrence to local or distant met - median 12 mo
96143468 | | | | 5 yr survival ~40%
| | | | Median survival 33 mo;
| | | | Mortality 39 patients at 1 – 183 mo;
| | | | Presence of met predictor of shorter survival, p < 0.0003
Sandrini 1997 | ND | ND | | Of 54 patients - | | | | Signs of virlization at birth in 3, abdominal mass at 3 days of birth in 1; bone age > 1 yr in 68%, ht & wt ‘often exceeded 50^th^%’; recurrence from 1 – 48 mo postop (median 6 mo); 4 LTF; data reported could not be verified - unkn # adenoma cases
97358147 | | | | 30 (56%) disease-free interval for median 63 mo (1–214)
(Possible overlap of patient sample with Ribeiro 1990, Sabbaga 1993, and Michalkiewicz 1997) | | | | 24 (44%) mortality (recurrence-22, hypertensive encephalopathy-1, choroid plexus carcinoma-1); recurrance median 6 months (1 – 48 mo)
Michalkiewicz 1997 | ND | 30 day mortality - 1 | | Mean survival 29.6 mo for ACC group; | | | | Cohort from International Registry of Childhood Adrenocortical Tumors, underwent same tx protocol; 8 of 20 cases with adenoma
97176972
(Possible overlap of patient sample with Sabbaga 1993 and Sandrini 1997)
Barzon 1998 | ND | ND | | Complete resection - | | | | Sex, functional tumor status, or mitotic index at histology not factors on recurrence or survival rates; recurrence ‘a few months’ after surgery in 7 of 18 who underwent complete resection; 10 had chemotherapy only
9805828 | | | | Median disease-free survival 13mo
(Overlap of patient sample with Boscaro 1995) | | | | 1 yr disease-free survival 24%
| | | | 5 yr disease-free survival 11%;
| | | | Overall median survival 16 mo
| | | | Overall 1 yr survival 71%
| | | | Overall 5 yr survival 29%;
| | | | Stages | Median survival | 1 yr | 5yr
| | | | I & II | 34 (13 – 104) | 93% | 70%
| | | | III & IV | 13 (2 – 108) | 58% | 12%
| | | | Sign longer survival for stages I & II vs later stages, p < 0.005; 3 died within 3 mo postop
Khorram-Manesh 1998 | 0.5 yr* | Mortality - 1 | | Overall 5 yr survival 58% | | | | Reexploration for recurrent disease in 5 (disease-free mean 59 mo) and in 4 (stage II) with no signs of recurrence
98260227 | (8 died, 0.13 – 6) | hepatic failure 6 wks postop
| 7.2*
| (10 alive, 0.58 – 24.5)
| * median
Teinturier 1999 | 3.2 yr | Mortality (1) at 5 month after diagnosis from acute adrenal insufficiency - surgery was incomplete microscopically; | | Overall 5 yr survival 49%; | | | | Recurrence rate 40% (18) with disease-free interval of median 7 mo (2 – 16); total 23 deaths: (1 – 38 mo from dx), 20 due to tumor evolution, 2 of acute adrenal insufficiency, 1 from sacoma of face, incomplete microscopic surgery in 9 cases - 8 developed recurrences
99133697 | (median, 0.1 – 20.3) | | | Disease-free survival 46%;
| | | | Met developed in 24 with complete remission in 5 after med tx & surgery - 2 alive at 4 & 7 yrs;
Harrison 1999 | 20 | ND | | 5 yr survival 36% | | | | ---
99148327 | (median, 1 – 101) | | | Median survival - 28 mo;
| | | | 3 independent predictors of survival: tumor sz > 12 cm, mitotic count ( 6 per 10 high-powered field, intratumoral hemorrhage, p < 0.05
Driver 1999 | ND | ND | | Curative resection - | | | | 14 enrolled/evaluated had ACC; % male based on 18 cases - 14 with ACC, 3 died from 2^nd^ primary tumors possibly radx induced; radx in 12
99058793 | | | | Alive at 114 mo - 2;
| | | | Mortality (12) with median survival - 52 mo (1 – 317), 6 mo (1 – 28) if 2^nd^ primary tumors (3) cases excluded
Tritos 2000 | 37.2 | ND | | ‘Apparently curative resection’ - 19 median survival 26 mo (1 – 205); | | | | 7 patients thought to have inoperable tumors received meds only, dx confirmed by biopsy of liver met; difference in age distribution for curative & inoperable group NS, p = 0.13; the 7 with inoperable disease had met and mean age of 68 (53 – 84)
20114774 | (n-31, 1 – 205) | | | Overall - 31
| | | | 5 yr survival 26%
| | | | 17 mo (1 – 205)
| | | | 7 alive without disease, 2 alive with disease;
| | | | Stages I or II had trend for better 5 yr survival than Stages III or IV, 45% vs 17%, p = 0.064; improved survival factors include age < 54, absence of mets, nonfunctioning tumor status; tumor sz not associated with improved survival

t stat sign for stage III vs stage IV, p < 0.007

u stat sign for stages I or II vs stage IV, p < 0.003

v Patients with complete resection had signif longer survival than patients with incomplete resection, p = 0.002

w p = 0.01

Evidence Table 12. Follow-up studies of incidentally discovered untreated adrenal masses by established protocol - Part I

Study, Year Identifier | Demographics | Inclusion Criteria | Exclusion Criteria | Study design | Enrollment years
Kologlu 1988 | Country: Turkey | Incidentally discovered nonfunctioning adrenal tumors | ND | Unclear retrospective or prospective | ‘four-year period’
89100083 | Setting: Academic
| Mean age: 36 (21 – 65)y
| Enrolled: 12
| Evaluated: 12
| 24% Male
| Race: ND
Jockenhövel 1992 | Country: Germany | Incidentally discovered adrenal mass | ND | Prospective | ‘8 year period’
923729000 | Setting: Academic
| Mean age: 54.9 ± 11.4 (31.1 – 74.7) y
| Enrolled: 50
| Evaluated: 18
| 56% Male
| Race: ND
Barzon 1999 | Country: Italy | “apparently benign adrenalcorticol tumors” | Hypercortisolism, aldosteronism, congenital adrenal hyperplasia, malignancy, myelolipoma, pseudoadrenal mass, adrenal cyst, angioma | Prospective | ~1983-1998
99145008 | Setting: Academic
| Median age:
| Female 59 (24 – 77) y
| Male 52 (19 – 76) y
| Enrolled: 124
| Evaluated: 75
| 31% Male
| Race: ND
Siren 2000 | Country: Finland | Incidentally discovered adrenal tumors (US-2, CT-25) | Malignant or hormonally active tumor | Retrospective and prospective | Jun 1981-Dec 1992
20246761 | Setting: Academic
| Mean age: 59 (19 – 80)^2^
| Enrolled: 27
| Evaluated: 27 (16)
| 26% Male^2^
| Race: ND

Evidence Table 12. Follow-up studies of incidentally discovered untreated adrenal masses by established protocol - Part II

Study, Year Identifier | Mean tumor size (cm - range) | Method of initial diagnosis | Initial diagnoses | Co-morbidities | Method of follow-up Imaging/ biochemical study (n) | Mean follow-up (range)
Kologlu 1988 | 8 – 40 mm | CT | | | Serial CT (‘several’) | ND
89100083
Jockenhövel 1992 | 2.19 ± 0.7 (1.5 – 4) | ND | | | CT, 2 mg dexamethasone suppression test | Median 32.2 mo (11 – 101)
92372900 | | | | | Cortisol serum levels, Corisol urine excretion, CHR-test, ACTH-test, Serum potassium
| | | | | Adosterone und renin suppine & after 2 hr standing
| | | | | Estosterone, androstendione, DHEA-S, estradiol
| | | | | ACTH-test with determination of 17-hydroxyprogesterone, androstenedione & 11-desoxycortisol
| | | | | 24-hr urinary excretion & plasma levels of catecholamines
Barzon 1999 | 2.5 (median 2.5, 1.0 – 5.6) | Abdominal CT or MRI, endocrine & scintigraphic (67) studies | ND | Hypertension - 41 | CT or MRI; | 4 yr (median 4.6, 2 – 10)
99145008 | | | | Diabetes - 9 | Hormonal tests: UFC, 24 hr urinary catecholamines/ metanephrines, plasma control rhythm, morning ACTH & DHEAS, & upright aldosterone/PRA ratio
| | | | Obesity - 15
| | | | Osteoporosis - 18
| | | | Hypothyroidism - 3
| | | | Hyperthyoidism - 2
| | | | Subclinical hyperthyroidism - 1
| | | | Paget's dis - 1
Siren 2000 | 2.5^2^ (1.5 – 4.0) | CT | ND | 1 patient from differ site with hypertension | Medical records and/or clinical exam (16); | 98 mo (n=16, 53 – 196)
20246761 | | | | | CT or MRI (27); if scans normal at yr 1, add'l hormonal & MRI tests;
| | | | | Hormonal tests: 24 hr urine excretion of metanephrines & normetanephrines, & vanillylmandelic acid; 1-mg overnight dexamethasone suppression test; & serum potassium measurement

Evidence Table 12. Follow-up studies of incidentally discovered untreated adrenal masses by established protocol - Part III

Study, Year Identifier | Testing interval (range) | Adrenal-related outcomes | | | | | | Non-adrenal outcomes | Comments
Kologlu 1988 | 3 or 6 mo | ND | | | | | | ND | ---
89100083
Jockenhövel 1992 | NA | 1 adrenal mass increased 0.5 cm 32 mo after initial exam, | | | | | | | 18 had adrenalectomy, ‘6 were recently discovered and exhibited neither indications for malignancy nor endocrine activity of the adrenal tumor and will be monitored’, 5 declined FU protocol
92372900 | | 2 previously discovered sm mass undetectable in subsequent CT,
| | 15 unchanged
Barzon 1999 | 6 mo, 12 mo, 93 mo thereafter | CT or MRI or development of endocrine hypo- or hyperfunction - no change (58); | | | | | | 2 patient with no tumor change died of lung & colon cancer had adenoma confirmed at autopsy | LTF (49); bilaterial tumors (15); 7 with incr mass sz refused operation are being followed; most cases observed within first 3 yrs
99145008 | | Patients with mass changes and/or adrenal hyperfunction (17):
| | [underlined: Age] | [underlined: Tumor Sz (cm)] | [underlined: Fllw-up Sz (cm)] | [underlined: Fllw-up (yr)] | [underlined: Endocrine Abnormalities] | [underlined: Histology]
| | 60 | 2.0 | 3/0 | 7 | unchg | Adrenal
| | adenoma
| | 41 | 1.1 | 4.0 | 10 | unchg | Adrenal
| | adenoma
| | 69 | 3.5/1.5 | 4.5/2.0 | 8 | unchg | FNAB: adrenal
| | adenoma/
| | | hyperplasia
| | 43 | 1.2 | 2.2 | 8 | unchg
| | 59 | 4.0 | 5.0 | 2 | unchg
| | 76 | 2.0 | 3.0 | 4 | unchg | FNAB: adrenal
| | | adenoma
| | 68 | 2.0 | 3.0 | 3 | unchg
| | 71 | 2.0 | 2.4/1.2 | 7
| | 62 | 3.5 | 4.0/1.8 | 4 | unchg
| | 32 | 3.2 | 2.5 | 4 | unchg
| | 31 | 3.0 | 1.0 | 10 | unchg
| | 57 | 3.0 | unchg | 9 | Cushing's synd | Adrenal
| | adenoma
| | 65 | 3.0 | unchg | 8 | Cushing's synd | Adrenal
| | adenoma
| | 75 | 3.0/1.0 | unchg | 2 | noncl hypercort
| | 55 | 3.5 | 4.4 | 6 | non hypercort | Nodular
| | hyperplasia
| | 70 | 3.4 | 4.5 | 2 | non hypercort | Adrenal
| | adenoma
| | 62 | 1.5 | 2.8 | 5 | elev cathecolamines
| | | Pheo
Siren 2000 | Imaging 1 yr from initial CT | Hormonal tests-normal (16); | | | | | | | 8 tumors ≥ 3 cm; 9 died prior to prospective FU period, 3 of 4 autopsied with documented incidentaloma; 2 patient didn't participate
20246761 | | MRI-no incidentaloma (4 tumors/4 patients), no change (7 tumors/5 patients), ↑ size (5 tumors/4 patients), ↓ size (3 tumors/3 patients)

Evidence Table 13: Follow-up studies of incidentally discovered untreated adrenal masses without established protocol - Part I

Study, Year Identifier | Demographics | Inclusion Criteria | Exclusion Criteria | Study design | Enrollment years
Glazer 1982 82227342 | Country: USA | Incidentally discovered adrenal masses without clinical or biochemical evidence of adrenal pathology | CT characteristics of adrenal cyst | Unclear retrospective or prospective | 1979 - 1981
| Setting: Academic
| Mean age: 57 (40 – 76)
| Enrolled: 16
| Evaluated: 16 (10)
| 44% Male
| Race: ND
Mitnick 1983 83248141 | Country: USA | Incidentally discovered adrenal masses > 1.0 cm | Cysts or myelolipoma | Unclear retrospective or prospective | 1979 - 1982
| Setting: Academic
| Mean age: ND (45 – 73)
| Enrolled: 18
| Evaluated: 18 (12)
| 61% Male
| Race: ND
Reincke 1989 89251223 | Country: Germany | Incidentally discovered adrenal tumors | ND | Unclear retrospective or prospective | 1981 -
| Setting: Academic
| Mean age: 54 (25 – 73)
| Enrolled: 32
| Evaluated: 32 (11)
| 28% Male
| Race: ND
Courtade 1997 97305574 | Country: France | Incidentally discovered adrenal tumors (US-14, CT-14) | Pheo and secreting adenoma | Prospective | Jan 1986– Dec 1992
| Setting: Regional
| Mean age: 55 (20 – 77)
| Enrolled: 44
| Evaluated: 44 (18)
| 41% Male
| Race: ND
Barry 1998 98260226 | Country: USA | Asymptomatic incidentally discovered adrenal tumors | ‘Patients who underwent adrenalectomy or in whom the diagnosis of incidentaloma was made elsewhere…’ | Ambidirectional? | 1985-1989
| Setting: Regional
| Mean age: 64 (5 – 86)
| Total in study: 231
| Enrolled: 91
| Evaluated: 91
| 44% Male of total pop.
| Race: ND

Evidence Table 13: Follow-up studies of incidentally discovered untreated adrenal masses without established protocol - Part II

Study, Year Identifier | Mean tumor size (cm - range) | Method of initial diagnosis | Initial diagnoses | Co-morbidities | Method of follow-up Imaging/ biochemical study (n) | Mean follow-up (range)
Glazer 1982 82227342 | 2.4 (1 – 6) | CT (14) and excretory urography (2) | | Neoplastic disease | CT/clincal/biochemical exams
Mitnick 1983 83248141 | 2.9 (1.2 – 5) | CT | | Neoplastic disease 5 (Lymphoma | Serial CT | 15 mo (6 mo – 3 yr)
Reincke 1989 89251223 | 3 (1 – 9) | CT or US | | ND | CT | ND
Courtade 1997 97305574 | 3.5 (0.6 – 10.0) | US or CT, endocrine, & scintigraphic studies | Based on radiology - | ND | Clinical & MRI (18); telephone interviews (14); ‘control’: CT (4), MRI (3) | 43 mo^2^ (4 – 75)
| | | Adenoma - 12
| | | Haematoma - 10
| | | Mets - 8
| | | Cyst - 7
| | | Hyperplasia - 2
| | | Myelolipoma - 2
Barry 1998 98260226 | 2 (1.0 – 6.0) | Abdominal or thoracic CT | ND | ND | 91 of 231 had one or more CT images, CT interval undefined; review of medical records, personal telephone interviews, or correspondence with patients or MDs | 7 yrs^2^ (1 mo – 11.7yr)

Evidence Table 13: Follow-up studies of incidentally discovered untreated adrenal masses without established protocol - Part III

Study, Year Identifier | Testing interval (range) | Adrenal-related outcomes | | | | | Non-adrenal outcomes | Comments
Glazer 1982 82227342 | 9 mo (4 – 16) | No change in mass size | | | | | | 5 had adrenalectomy, 1 died & at autopsy had 3.5 cm adrenal cortical adenoma
Mitnick 1983 83248141 | ND | No change in mass size
Reincke 1989 89251223 | 14 mo (6 – 48) | No change in tumor size
Courtade 1997 97305574 | ND | 3 died - | | | | | 8 died from 1° tumors | Confusing definitions and reporting, fwup data on outcome cannot be reliably derived; LTF (1); no data on FU method for 11 patient who died; 4 bilateral tumors
| | adenoma | 1
| | cyst | 1
| | unk | 1
Barry 1998 98260226 | Ave 49 mo from initial CT (1–123) | No change in 87, 4 tumors > 1 cm incr & were excised: | | | | | --- | Not all 231 patients received CT, 81 died unrelated to adrenal pathology
| | Age at dx | Baseline sz (cm) | Preop sz (cm) | Time (mo) since dx | Pathology
| | 64 | 1.0 | 6.0 | 29 | Hemorrhagic cyst
| | 62 | 2.0 | 3.2 | 6 | Adenoma
| | 45 | 2.8 | 4.8 | 16 | Adenoma
| | 68 | 1.0 | 4.5 | 35 | Adenoma